# Studies Addressing Executive Function

Table H-1 Key outcomes of studies addressing Phe levels and executive function in individuals with PKU

## References

1 Azadi B, Seddigh A, Tehrani-Doost M, et al. Executive dysfunction in treated phenylketonuric patients. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):360-8. [pmid: 19221856].
2 Sharman R, Sullivan K, Young R, et al. Biochemical markers associated with executive function in adolescents with early and continuously treated phenylketonuria. Clin Genet. Feb. 2009;75(2):169-74. [pmid: 19215250].
3 Moyle JJ, Fox AM, Bynevelt M, et al. A neuropsychological profile of off-diet adults with phenylketonuria. J Clin Exp Neuropsychol. May. 2007;29(4):436-41. [pmid: 17497567].
4 Christ SE, Steiner RD, Grange DK, et al. Inhibitory control in children with phenylketonuria. Dev Neuropsychol. 2006;30(3):845-64. [pmid: 17083296].
5 Wasserstein MP, Snyderman SE, Sansaricq C, et al. Cerebral glucose metabolism in adults with early treated classic phenylketonuria. Mol Genet Metab. Mar. 2006;87(3):272-7. [pmid: 16343970].
6 Gassio R, Artuch R, Vilaseca MA, et al. Cognitive functions in classic phenylketonuria and mild hyperphenylalaninaemia: experience in a paediatric population. Dev Med Child Neurol. Jul. 2005;47(7):443-8. [pmid: 15991863].
7 Anderson PJ, Wood SJ, Francis DE, et al. Neuropsychological functioning in children with early-treated phenylketonuria: impact of white matter abnormalities. Dev Med Child Neurol. Apr. 2004;46(4):230-8. [pmid: 15077700].
8 Anderson PJ, Wood SJ, Francis DE, et al. Are neuropsychological impairments in children with early-treated phenylketonuria (PKU) related to white matter abnormalities or elevated phenylalanine levels?. Dev Neuropsychol. 2007;32(2):645-68. [pmid: 17931123].
9 Channon S, Goodman G, Zlotowitz S, et al. Effects of dietary management of phenylketonuria on long-term cognitive outcome. Arch Dis Child. Mar. 2007;92(3):213-8. [pmid: 17068073].
10 Channon S, Mockler C, Lee P. Executive functioning and speed of processing in phenylketonuria. Neuropsychology. Sep. 2005;19(5):679-86. [pmid: 16187886].
11 Channon S, German E, Cassina C, et al. Executive functioning, memory, and learning in phenylketonuria. Neuropsychology. Oct. 2004;18(4):613-20. [pmid: 15506828].
12 Antshel KM, Waisbren SE. Developmental timing of exposure to elevated levels of phenylalanine is associated with ADHD symptom expression. Journal of Abnormal Child Psychology: An official publication of the International Society for Research in Child and Adolescent Psychopathology. [Peer Reviewed]. Dec. 2003;31(6):565-574.
13 Antshel KM, Waisbren SE. Timing is everything: Executive functions in children exposed to elevated levels of phenylalanine. Neuropsychology. [Peer Reviewed]. Jul. 2003;17(3):458-468. [pmid: 12959512].
14 Huijbregts SC, de Sonneville LM, Licht R, et al. Sustained attention and inhibition of cognitive interference in treated phenylketonuria: associations with concurrent and lifetime phenylalanine concentrations. Neuropsychologia. 2002;40(1):7-15. [pmid: 11595258].
15 Luciana M, Sullivan J, Nelson CA. Associations between phenylalanine-to-tyrosine ratios and performance on tests of neuropsychological function in adolescents treated early and continuously for phenylketonuria. Child Dev. Nov-Dec. 2001;72(6):1637-52. [pmid: 11768137].
16 Griffiths P, Campbell R, Robinson P. Executive function in treated phenylketonuria as measured by the one-back and two-back versions of the continuous performance test. J Inherit Metab Dis. Apr. 1998;21(2):125-35. [pmid: 9584263].
17 Pietz J, Dunckelmann R, Rupp A, et al. Neurological outcome in adult patients with early-treated phenylketonuria. Eur J Pediatr. Oct. 1998;157(10):824-30. [pmid: 9809823].
18 Stemerdink BA, van der Meere JJ, van der Molen MW, et al. Information processing in patients with early and continuously-treated phenylketonuria. Eur J Pediatr. Sep. 1995;154(9):739-46. [pmid: 8582426].
19 Weglage J, Pietsch M, Funders B, et al. Neurological findings in early treated phenylketonuria. Acta Paediatr. Apr. 1995;84(4):411-5. [pmid: 7795351].
20 Weglage J, Pietsch M, Funders B, et al. Deficits in selective and sustained attention processes in early treated children with phenylketonuria--result of impaired frontal lobe functions?. Eur J Pediatr. Mar. 1996;155(3):200-4. [pmid: 8929728].
21 Weglage J, Pietsch M, Denecke J, et al. Regression of neuropsychological deficits in early-treated phenylketonurics during adolescence. J Inherit Metab Dis. Aug. 1999;22(6):693-705. [pmid: 10472530].
22 Ris MD, Williams SE, Hunt MM, et al. Early-treated phenylketonuria: adult neuropsychologic outcome. J Pediatr. Mar. 1994;124(3):388-92. [pmid: 8120707].
23 Ris MD, Weber AM, Hunt MM, et al. Adult psychosocial outcome in early-treated phenylketonuria. J Inherit Metab Dis. Aug. 1997;20(4):499-508. [pmid: 9266385].
24 Schmidt E, Rupp A, Burgard P, et al. Sustained attention in adult phenylketonuria: the influence of the concurrent phenylalanine-blood-level. J Clin Exp Neuropsychol. Oct. 1994;16(5):681-8. [pmid: 7836491].
25 de Sonneville LM, Schmidt E, Michel U, et al. Preliminary neuropsychological test results. Eur J Pediatr. Suppl 1. 1990;149:S39-44. [pmid: 2091930].
26 Welsh MC, Pennington BF, Ozonoff S, et al. Neuropsychology of early-treated phenylketonuria: specific executive function deficits. Child Dev. Dec. 1990;61(6):1697-713. [pmid: 2083493].