# Excluded Studies

Reasons for exclusion:

- X-1=Not original research
- X-2=Ineligible population
- X-3=Ineligible study size
- X-4=Not relevant to Key Question 1
- X-5= Not relevant to Key Questions 2-7
- X-6=Ineligible study design
- X-7=Unable to obtain study

1 Abadie V, et al. Neonatal screening and long-term follow-up of phenylketonuria: the French database. Early Hum Dev. 2001. X-4, X-5.
2 Abelson HT, Gorka C, Beardsley GP. Identification of dihydropteridine reductase in human platelets. Blood. 1979. X-2, X-3, X-4.
3 Abu Shahla AN, Abed Y, Abu Shahla NK. Screening programme for phenylketonuria in the Gaza Strip: evaluation and recommendations. J Trop Pediatr. 2004. X-4.
4 Acosta PB, et al. Iron status of children with phenylketonuria undergoing nutrition therapy assessed by transferrin receptors. Genet Med. 2004. X-4, X-5.
5 Acosta PB, et al. Nutrient intakes and physical growth of children with phenylketonuria undergoing nutrition therapy. J Am Diet Assoc. 2003. X-4, X-5.
6 Acosta PB, Sabo R. Challenges of managing patients with inherited metabolic disorders in a developing country. Southeast Asian J Trop Med Public Health. 2003. X-4.
7 Acosta PB, et al. Intake and blood levels of fatty acids in treated patients with phenylketonuria. J Pediatr Gastroenterol Nutr. 2001. X-4, X-5.
8 Acosta PB, et al. Intake of major nutrients by women in the Maternal Phenylketonuria (MPKU) Study and effects on plasma phenylalanine concentrations. Am J Clin Nutr. 2001. X-4, X-5.
9 Acosta PB, et al. Protein status of infants with phenylketonuria undergoing nutrition management. J Am Coll Nutr. 1999. X-4, X-5.
10 Acosta PB, Yannicelli S. Plasma micronutrient concentrations in infants undergoing therapy for phenylketonuria. Biol Trace Elem Res. 1999. X-4, X-5.
11 Acosta PB, et al. Nutrient intake and growth of infants with phenylketonuria undergoing therapy. J Pediatr Gastroenterol Nutr. 1998. X-4.
12 Acosta PB. Nutrition studies in treated infants and children with phenylketonuria: vitamins, minerals, trace elements. Eur J Pediatr. 1996. X-1, X-4, X-5.
13 Acosta PB. Recommendations for protein and energy intakes by patients with phenylketonuria. Eur J Pediatr. 1996. X-1, X-2, X-3, X-4.
14 Acosta PB, Yannicelli S. Protein intake affects phenylalanine requirements and growth of infants with phenylketonuria. Acta Paediatr Suppl. 1994. X-4, X-5.
15 Acosta PB, et al. Trace element status of PKU children ingesting an elemental diet. JPEN J Parenter Enteral Nutr. 1987. X-4.
16 Acosta PB, Stepnick-Gropper S. Problems related to diet management of maternal phenylketonuria. J Inherit Metab Dis. 1986. X-1, X-3, X-5, X-6.
17 Acosta PB, et al. Phenylalanine intakes of 1- to 6-year-old children with phenylketonuria undergoing therapy. Am J Clin Nutr. 1983. X-4, X-5.
18 Acosta PB, et al. Nutrition in pregnancy of women with hyperphenylalaninemia. J Am Diet Assoc. 1982. X-3, X-4, X-5.
19 Acosta PB, et al. Zinc status and growth of children undergoing treatment for phenylketonuria. J Inherit Metab Dis. 1982. X-4, X-5.
20 Acosta PB, et al. Zinc and copper status of treated children with phenylketonuria. JPEN J Parenter Enteral Nutr. 1981. X-4.
21 Acosta PB, Wenz E, Williamson M. Methods of dietary inception in infants with PKU. J Am Diet Assoc. 1978. X-4.
22 Acosta PB, Wenz E, Williamson M. Nutrient intake of treated infants with phenylketonuria. Am J Clin Nutr. 1977. X-4, X-5.
23 Acosta PB, Alfin-Slater RB, Koch R. Serum lipids in children with phenylketonuria (PKU). J Am Diet Assoc. 1973. X-4.
24 Acosta PB, Fiedler JL, Koch R. Mothers' dietary management of PKU children. J Am Diet Assoc. 1968. X-9.
25 Adler C, et al. 7-substituted pterins in humans with suspected pterin-4a-carbinolamine dehydratase deficiency. Mechanism of formation via non-enzymatic transformation from 6-substituted pterins. Eur J Biochem. 1992. X-2, X-3, X-4.
26 Agostoni C, et al. A randomized trial of long-chain polyunsaturated fatty acid supplementation in infants with phenylketonuria. Dev Med Child Neurol. 2006. X-4, X-5.
27 Agostoni C, et al. Long term effects of long chain polyunsaturated fats in hyperphenylalaninemic children. Arch Dis Child. 2003. X-4, X-5.
28 Agostoni C, et al. Biochemical effects of supplemented long-chain polyunsaturated fatty acids in hyperphenylalaninemia. Prostaglandins Leukot Essent Fatty Acids. 2001. X-4, X-5.
29 Agostoni C, et al. Effects of long-chain polyunsaturated fatty acid supplementation on fatty acid status and visual function in treated children with hyperphenylalaninemia. J Pediatr. 2000. X-4, X-5.
30 Agostoni C, et al. Plasma arachidonic acid and serum thromboxane B2 concentrations in phenylketonuric children are correlated with dietary compliance. Z Ernahrungswiss. 1998. X-4.
31 Agostoni C, et al. Plasma arachidonic acid and serum thromboxane B2 concentrations in phenylketonuric children negatively correlate with dietary compliance. Prostaglandins Leukot Essent Fatty Acids. 1997. X-4, X-5.
32 Agostoni C, et al. The effects of n-3 and n-6 polyunsaturated fatty acids on plasma lipids and fatty acids of treated phenylketonuric children. Prostaglandins Leukot Essent Fatty Acids. 1995. X-4, X-5, X-6.
33 Agrawal HC, Bone AH, Davison AN. Effect of phenylalanine on protein synthesis in the developing rat brain. Biochem J. 1970. X-2, X-3, X-4.
34 Aguado C, et al. BH4 responsiveness associated to a PKU mutation with decreased binding affinity for the cofactor. Clin Chim Acta. 2007. X-3.
35 Aguado C, et al. Analysis of the effect of tetrahydrobiopterin on PAH gene expression in hepatoma cells. FEBS Lett. 2006. X-2, X-3, X-4, X-5.
36 Aguiar MJ. Genetic services and research in the state of Minas Gerais, Brazil. Community Genet. 2004. X-1, X-2, X-3, X-4.
37 Ahring K, et al. Dietary management practices in phenylketonuria across European centres. Clin Nutr. 2009. X-2, X-3, X-4, X-5.
38 Airaksinen MM, et al. Protective effect of tryptophan and 5-hydroxytryptophan on experimental phenylketonuria induced with phenylalanine+ p-cholorophenylalanine in rats. Med Biol. 1975. X-2, X-3, X-4.
39 al Aqeel A, et al. Biopterin-dependent hyperphenylalaninemia due to deficiency of 6-pyruvoyl tetrahydropterin synthase. Neurology. 1991. X-2.
40 al-Hosani H, et al. United Arab Emirates National Newborn Screening Programme: an evaluation 1998-2000. East Mediterr Health J. 2003. X-4.
41 Al-Qadreh A, et al. Bone mineral status in children with phenylketonuria under treatment. Acta Paediatr. 1998. X-4, X-5.
42 Alexander FW. The uptake of lead by children in differing environments. Environ Health Perspect. 1974. X-2, X-3, X-4.
43 Alexander FW, Clayton BE, Delves HT. Mineral and trace-metal balances in children receiving normal and synthetic diets. Q J Med. 1974. X-3, X-4, X-5.
44 Allanson J, et al. Combined transient and peripheral defects in tetrahydrobiopterin synthesis. J Pediatr. 1991. X-1, X-2, X-3, X-4, X-5.
45 Allen JR, et al. Decreased bone mineral density in children with phenylketonuria. Am J Clin Nutr. 1994. X-4, X-5.
46 Alm J, et al. Children with inborn errors of phenylalanine metabolism: prognosis and phenylalanine tolerance. Acta Paediatr Scand. 1986. X-4, X-5.
47 Alm J, Larsson A, Rosenqvist U. Health economic analysis of the Swedish neonatal metabolic screening programme. A method of optimizing routines. Med Decis Making. 1982. X-4.
48 Ambrose JA. Analysis of the “report on a cooperative study of various fluorometric procedures and the Guthrie Bacterial Inhibition Assay in the determination of hyperphenylalaninemia” and the significance of this study in the detection, diagnosis, and management of phenylketonuria (PKU). Health Lab Sci. 1973. X-4+.
49 Ambroszkiewicz J, Gajewska J, Laskowska-Klita T. A study of bone turnover markers in prepubertal children with phenylketonuria. Eur J Pediatr. 2004. X-4, X-5.
50 Ambrus CM, et al. In vivo safety of hollow fiber enzyme-reactors with immobilized phenylalanine ammonia-lyase in a large animal model for phenylketonuria. J Pharmacol Exp Ther. 1983. X-2, X-3, X-4.
51 Ambrus CM, et al. Depletion of phenylalanine in the blood of phenylketonuric patients using a PAL-enzyme reactor. An in vitro study. Res Commun Chem Pathol Pharmacol. 1982. X-3, X-4,.
52 Ambrus CM, et al. Phenylalanine depletion for the management of phenylketonuria: use of enzyme reactors with immobilized enzymes. Science. 1978. X-4.
53 ACOG Committee Opinion no. 449: Maternal phenylketonuria. Obstet Gynecol. 2009. X-1, X-2, X-3, X-4.
55 Andersen AE, Avins L. Lowering brain phenylalanine levels by giving other large neutral amino acids. A new experimental therapeutic approach to phenylketonuria. Arch Neurol. 1976. X-2, X-3, X-4.
56 Anderson K, Acosta PB, Kennedy B. Osmolality of enteral formulas for maternal phenylketonuria. J Inherit Metab Dis. 1986. X-2, X-3, X-4, X-5, X-6.
57 Anderson K, Kennedy B, Acosta PB. Computer-implemented nutrition support of phenylketonuria. J Am Diet Assoc. 1985. X-2, X-4.
60 Anderson VA, et al. Relationships between cognitive and behavioral measures of executive function in children with brain disease. Child Neuropsychol. 2002. X-4, X-5.
61 Anderson VE. Maternal effects in genetic diseases. Soc Biol. 1971. X-1.
62 Anderson VE, et al. Manual dexterity in phenylketonuric children. Percept Mot Skills. 1968. X-4.
63 Andrews TM, et al. A relationship between the granulocyte phenylalanine content and the degree of disability in phenylketonuria. Q J Med. 1973. X-5.
64 Annexton M. Diet termination for PKU: Yes or no?. JAMA. 1978. X-1, X-2, X-3, X-4, X-5, X-6, X-7.
65 Antisdel JE, Chrisler JC. Comparison of eating attitudes and behaviors among adolescent and young women with type 1 diabetes mellitus and phenylketonuria. J Dev Behav Pediatr. 2000. X-4, X-5.
66 Antshel KM, Brewster S, Waisbren SE. Child and parent attributions in chronic pediatric conditions: phenylketonuria (PKU) as an exemplar. J Child Psychol Psychiatry. 2004. X-4.
67 Antshel KM, Gurian EA, Waisbren SE. Maternal phenylketonuria: a case study suggesting the use of prenatal psychotherapy to help control phenylalanine levels. Am J Orthopsychiatry. 2002. X-1, X-3, X-4.
68 Aoki K, Ohwada M, Kitagawa T. Long-term follow-up study of patients with phenylketonuria detected by the newborn screening programme in Japan. J Inherit Metab Dis. 2007. X-1, X-2, X-3, X-4, X-5, X-6.
69 Aoki K. Long term follow-up of patients with inborn errors of metabolism detected by the newborn screening program in Japan. Southeast Asian J Trop Med Public Health. 2003. X-4, X-5.
70 Aoki K, Siegel FL. Hyperphenylalaninemia: disaggregation of brain polyribosomes in young rats. Science. 1970. X-2, X-3, X-4.
71 Arnold GL, et al. Prevalence of stimulant use for attentional dysfunction in children with phenylketonuria. J Inherit Metab Dis. 2004. X-4, X-5.
72 Arthur LJ, Hulme JD. Intelligent, small for dates baby born to oligophrenic phenylketonuric mother after low phenylalanine diet during pregnancy. Pediatrics. 1970. X-1, X-3.
73 Artuch R, et al. A longitudinal study of antioxidant status in phenylketonuric patients. Clin Biochem. 2004. X-4, X-5.
74 Artuch R, et al. Plasma phenylalanine is associated with decreased serum ubiquinone-10 concentrations in phenylketonuria. J Inherit Metab Dis. 2001. X-4, X-6.
75 Artuch R, et al. Decreased serum ubiquinone-10 concentrations in phenylketonuria. Am J Clin Nutr. 1999. X-4, X-5.
76 Ascurra de Duarte M. Medical genetics in Paraguay. Community Genet. 2004. X-1, X-2, X-3, X-4, X-5.
77 Atherton ND, Green A. HPLC measurement of phenylalanine in plasma. Clin Chem. 1988. X-2, X-3, X-4.
78 Awiszus D, Unger I. Coping with PKU: results of narrative interviews with parents. Eur J Pediatr. 1990. X-2, X-3, X-4.
79 Ayling JE, et al. Hyperphenylalaninemia and 7-pterin excretion associated with mutations in 4a-hydroxy-tetrahydrobiopterin dehydratase/DCoH: analysis of enzyme activity in intestinal biopsies. Mol Genet Metab. 2000. X-3, X-4.
81 Azen C, et al. Summary of findings from the United States Collaborative Study of children treated for phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
82 Azen CG, et al. Intellectual development in 12-year-old children treated for phenylketonuria. Am J Dis Child. 1991. X-4, X-5.
83 Bachmann C. Interpretation of plasma amino acids in the follow-up of patients: the impact of compartmentation. J Inherit Metab Dis. 2008. X-1, X-2, X-3, X-4.
84 Balbani AP, Stelzer LB, Montovani JC. Pharmaceutical excipients and the information on drug labels. Braz J Otorhinolaryngol. 2006. X-2, X-3, X-4.
85 Banich MT, et al. Interhemispheric interaction during childhood: II. Children with early-treated phenylketonuria. Dev Neuropsychol. 2000. X-3, X-4, X-5.
86 Barbor P. Some inborn errors of metabolism. Nurs Mirror. 1978. X-1.
87 Bardelli T, et al. Two novel genetic lesions and a common BH4-responsive mutation of the PAH gene in Italian patients with hyperphenylalaninemia. Mol Genet Metab. 2002. X-4, X-5.
88 Barden HS, Kessel R, Schuett VE. The costs and benefits of screening for PKU in Wisconsin. Soc Biol. 1984. X-4.
89 Barnico LM, Cullinane MM. Maternal phenylketonuria: an unexpected challenge. MCN Am J Matern Child Nurs. 1985. X-1, X-2, X-3, X-4, X-5.
90 Barretto JR, et al. Poor zinc and selenium status in phenylketonuric children and adolescents in Brazil. Nutr Res. 2008. X-4, X-5.
91 Bartholome K. Genetics and biochemistry of the phenylketonuria-present state. Hum Genet. 1979. X-1, X-2, X-3, X-4, X-5.
92 Bartholome K, et al. Atypical phenylketonuria with normal phenylalanine hydroxylase and dihydropteridine reductase activity in vitro. Pediatrics. 1977. X-1, X-3.
93 Bartholome K, Lutz P, Bickel H. Determination of phenylalanine hydroxylase activity in patients with phenylketonuria and hyperphenylalaninemia. Pediatr Res. 1975. X-4.
94 Barwell B. Phenylketonuria--a problem in pregnancy. Health Visit. 1982. X-1.
95 Batshaw ML, Valle D, Bessman SP. Unsuccessful treatment of phenylketonuria with tyrosine. J Pediatr. 1981. X-3, X-4, X-5.
96 Bayle JH, et al. Hyperphenylalaninemia and impaired glucose tolerance in mice lacking the bifunctional DCoH gene. J Biol Chem. 2002. X-2, X-3, X-4.
97 Beasley MG, Costello PM, Smith I. Outcome of treatment in young adults with phenylketonuria detected by routine neonatal screening between 1964 and 1971. Q J Med. 1994. X-4, X-5.
98 Beblo S, et al. Effect of fish oil supplementation on fatty acid status, coordination, and fine motor skills in children with phenylketonuria. J Pediatr. 2007. X-4, X-5.
99 Beblo S, et al. Fish oil supplementation improves visual evoked potentials in children with phenylketonuria. Neurology. 2001. X-4, X-5.
100 Beckner AS, Centerwall WR, Holt L. Effects of rapid increase of phenylalanine intake in older PKU children. J Am Diet Assoc. 1976. X-4, X-4, X-5.
101 Behbehani AW. Termination of strict diet therapy in phenylketonuria. A study on EEG sleep patterns and computer spectral analysis. Neuropediatrics. 1985. X-4, X-5.
102 Beirne E, Carty MP, Donlon J. Effect of glucagon on hepatic phenylalanine hydroxylase in vivo. Biosci Rep. 1985. X-2, X-3, X-4.
103 Bekhof J, et al. Plasma phenylalanine in patients with phenylketonuria self-managing their diet. Arch Dis Child. 2005. X-4, X-5.
104 Belzecka K, Jakubiec A, Puzynska L. The effect of phenylalanine administration on the activities of phenylalanine hydroxylase, some aminotransferases and decarboxylases in adult rats. Acta Biochim Pol. 1967. X-2, X-3, X-4.
105 Bendelius J. The nutritional challenges of genetic enzyme-deficiency syndromes. School Nurse News. 2003. X-1.
106 Bender DR. Avoiding the cost burden of newborn screening for the poor and uninsured: Mississippi's model. J Health Soc Policy. 1992. X-2, X-3, X-4.
107 Bentovim A, et al. Use of an amino acid mixture in treatment of phenylketonuria. Arch Dis Child. 1970. X-4.
108 Bercovich D, et al. Genotype-phenotype correlations analysis of mutations in the phenylalanine hydroxylase (PAH) gene. J Hum Genet. 2008. X-4.
109 Berman JL. Phenylketonuria. Am Fam Physician. 1971. X-1.
110 Berman JL, Ford R. Intelligence quotients and intelligence loss in patients with phenylketonuria and some variant states. J Pediatr. 1970. X-4, X-5.
111 Berman JL, et al. Causes for high phenylalanine with normal tyrosine in newborn screening programs. Am J Dis Child. 1969. X-4.
112 Berman PW, Waisman HA, Graham FK. Effectiveness of dietary treatment in phenylketonuria: what is the proof?. Dev Med Child Neurol. 1967. X-1.
113 Bernegger C, Blau N. High frequency of tetrahydrobiopterin-responsiveness among hyperphenylalaninemias: a study of 1,919 patients observed from 1988 to 2002. Mol Genet Metab. 2002. X-4.
114 Berry HK, et al. Valine, isoleucine, and leucine. A new treatment for phenylketonuria. Am J Dis Child. 1990. X-4.
115 Berry HK, et al. Reduction of cerebrospinal fluid phenylalanine after oral administration of valine, isoleucine, and leucine. Pediatr Res. 1982. X-4, X-5.
116 Berry HK, et al. Diagnosis of phenylalanine hydroxylase deficiency (phenylketonuria). Am J Dis Child. 1982. X-4.
117 Berry HK. The diagnosis of phenylketonuria: a commentary. Am J Dis Child. 1981. X-1.
118 Berry HK, et al. Intellectual development and academic achievement of children treated early for phenylketonuria. Dev Med Child Neurol. 1979. X-4, X-5.
119 Berry HK, et al. Treatment of children with phenylketonuria using a phenylalanine-free protein hydrolysate (Albumaid XP). Am J Clin Nutr. 1976. X-1, X-2, X-3, X-4.
120 Berry HK. Hyperphenylalaninemias and tyrosinemias. Clin Perinatol. 1976. X-1.
121 Berry HK. Letter: Normal radiographic findings in treated phenylketonuric children. J Pediatr. 1973. X-1.
122 Berry HK, Hunt MM, Sutherland BK. Amino acid balance in the treatment of phenylketonuria. J Am Diet Assoc. 1971. X-4.
123 Berry HK, Wright S. Conference on treatment of phenylketonuria. J Pediatr. 1967. X-1.
124 Berry HK, et al. Treatment of phenylketonuria. Am J Dis Child. 1967. X-1.
125 Berry HK, Sutherland BS, Umbarger B. Detection of phenylketonuria in newborn infants. JAMA. 1966. X-1, X-2, X-3, X-4, X-5.
126 Berry HK, Umbarger B, Sutherland BS. Procedures for monitoring the low-phenylalanine diet in treatment of phenylketonuria. J Pediatr. 1965. X-1.
127 Bessman SP, Williamson ML, Koch R. Diet, genetics, and mental retardation interaction between phenylketonuric heterozygous mother and fetus to produce nonspecific diminution of IQ: evidence in support of the justification hypothesis. Proc Natl Acad Sci U S A. 1978. X-2, X-4.
128 Bessman SP. PKU--some skepticism. N Engl J Med. 1968. X-1, X-2, X-3, X-4, X-5.
129 Beto JA, Holli BB. Cookie for a low-phenylalanine diet. J Am Diet Assoc. 1974. X-1.
130 Bhat M, Haase C, Lee PJ. Social outcome in treated individuals with inherited metabolic disorders: UK study. J Inherit Metab Dis. 2005. X-4, X-5.
131 Bick U, et al. Disturbed myelination in patients with treated hyperphenylalaninaemia: evaluation with magnetic resonance imaging. Eur J Pediatr. 1991. X-3, X-4.
132 Bickel H. Differential diagnosis and treatment of hyperphenylalaninaemia. Prog Clin Biol Res. 1985. X-1.
133 Bickel H. Phenylketonuria: past, present, future. F. P. Hudson Memorial Lecture, Leeds, 1979. J Inherit Metab Dis. 1980. X-1, X-2, X-3, X-4, X-5.
134 Bickel H. Dietary restriction in inborn errors of amino acid metabolism. Curr Concepts Nutr. 1979. X-1.
135 Bickel H. Phenylalaninaemia or classical phenylketonuria (PKU)?. Neuropadiatrie. 1970. X-1.
136 Bilginsoy C, et al. Living with phenylketonuria: perspectives of patients and their families. J Inherit Metab Dis. 2005. X-4.
137 Birch HG, Tizard J. The dietary treatment of phenylketonuria: not proven?. Dev Med Child Neurol. 1967. X-1.
138 Blake EE, Rasberry GW, Long EE. The results of PKU screening in the Georgia public health laboratories January 1967--June 1968. J Med Assoc Ga. 1969. X-4.
139 Blank RH. Public policy implications of human genetic technology: genetic screening. J Med Philos. 1982. X-1, X-2, X-3, X-4.
140 Blaskovics M, et al. EEG pattern in phenylketonuria under early initiated dietary treatment. Am J Dis Child. 1981. X-4.
141 Blaskovics ME. Diagnosis in relationship to treatment of hyperphenylalaninaemia. J Inherit Metab Dis. 1986. X-1, X-2, X-3, X-4.
142 Blaskovics ME. Diagnostic considerations in phenylalaninemic subjects before and after dietary therapy. Ir Med J. 1976. X-1.
143 Blaskovics ME, Schaeffler GE, Hack S. Phenylalaninaemia. Differential diagnosis. Arch Dis Child. 1974. X-4, X-5.
144 Blass EM. Milk-induced hypoalgesia in human newborns. Pediatrics. 1997. X-2, X-3, X-4.
145 Blatteis CM, Billmeier GJ Jr., Gilbert TM. Thermoregulation of phenylketonuric children. Pediatr Res. 1974. X-3, X-4, X-5.
146 Blau N, et al. Management of phenylketonuria in Europe: survey results from 19 countries. Mol Genet Metab. 2010. X-2, X-4.
147 Blau N, et al. Antenatal diagnosis of tetrahydrobiopterin deficiency by quantification of pterins in amniotic fluid and enzyme activity in fetal and extrafetal tissue. Clin Chim Acta. 1994. X-2, X-3, X-4.
148 Blau N, Dhondt JL. Tetrahydrobiopterin deficiency and an international database of patients. Adv Exp Med Biol. 1993. X-1.
149 Blau N, et al. Screening for tetrahydrobiopterin deficiency in newborns using dried urine on filter paper. J Inherit Metab Dis. 1992. X-4, X-5.
150 Blehova B, et al. PKU in Bohemia. Acta Univ Carol Med Monogr. 1973. X-4, X-5.
151 Blehova B, Pazoutova N, Subrt I. Phenylketonuria associated with Down's syndrome. J Ment Defic Res. 1970. X-1.
152 Blumenthal MD. Experiences of parents of retardates and children with cystic fibrosis. Arch Gen Psychiatry. 1969. X-2, X-3, X-4, X-5.
153 Boado RJ, et al. Human LAT1 single nucleotide polymorphism N230K does not alter phenylalanine transport. Mol Genet Metab. 2004. X-2, X-3, X-4.
154 Bodamer OA, Hoffmann GF, Lindner M. Expanded newborn screening in Europe 2007. J Inherit Metab Dis. 2007. X-1, X-4.
155 Bodley JL, et al. Low iron stores in infants and children with treated phenylketonuria: a population at risk for iron-deficiency anaemia and associated cognitive deficits. Eur J Pediatr. 1993. X-4, X-5.
156 Boger WP, McClelland J, Gavin JJ. Phenylketonuria. 3. Measurement of multiple parameters of liver function. Am J Clin Nutr. 1967. X-1, X-2, X-3, X-4, X-5, X-6.
157 Bonafe L, et al. Mutations in the sepiapterin reductase gene cause a novel tetrahydrobiopterin-dependent monoamine-neurotransmitter deficiency without hyperphenylalaninemia. Am J Hum Genet. 2001. X-1, X-3, X-4.
158 Boneh A, et al. Three-year audit of the hyperphenylalaninaemia/phenylketonuria spectrum in Victoria. J Paediatr Child Health. 2006. X-4, X-5.
159 Bonyadi M, et al. Mutations of the phenylalanine hydroxylase gene in Iranian Azeri Turkish patients with phenylketonuria. Genet Test Mol Biomarkers. 2010. X-4.
160 Bosch AM, et al. Remarkable differences: the course of life of young adults with galactosaemia and PKU. J Inherit Metab Dis. 2009. X-4, X-5.
161 Bosch AM, et al. The course of life and quality of life of early and continuously treated Dutch patients with phenylketonuria. J Inherit Metab Dis. 2007. X-4, X-5.
162 Boulos M, et al. Correlation between plasma and urine phenylalanine concentrations. Biol Neonate. 2004. X-4, X-5.
163 Bourget L, Chang TM. Phenylalanine ammonia-lyase immobilized in semipermeable microcapsules for enzyme replacement in phenylketonuria. FEBS Lett. 1985. X-2, X-3, X-4, X-5, X-6.
164 Bowe K. Phenylketonuria: an update for pediatric community health nurses. Pediatr Nurs. 1995. X-1.
165 Boyle PJ. Shaping priorities in genetic medicine. Hastings Cent Rep. 1995. X-1, X-2, X-3, X-4, X-5.
166 Brady RO. Inherited metabolic diseases of the nervous system. Science. 1976. X-1.
167 Braham J. Effect of dietetic therapy on EEG in phenylketonuria. Electroencephalogr Clin Neurophysiol. 1967. X-1, X-2, X-3, X-4, X-5.
168 Brambilla F, Giardini M, Russo R. Prospects for a pharmacological treatment of phenylketonuria. Dis Nerv Syst. 1975. X-4.
169 Brass CA, et al. The effects of hyperphenylalaninemia on fetal development: a new animal model of maternal phenylketonuria. Pediatr Res. 1982. X-2, X-3, X-4.
170 Bremer HJ, Anninos A, Schulz B. Amino acid composition of food products used in the treatment of patients with disorders of the amino acid and protein metabolism. Eur J Pediatr. 1996. X-2, X-3, X-4.
171 Brenton DP, Lilburn M. Maternal phenylketonuria. A study from the United Kingdom. Eur J Pediatr. 1996. X-4, X-5.
172 Brenton DP, et al. Phenylketonuria: treatment in adolescence and adult life. Eur J Pediatr. 1996. X-2, X-3, X-4, X-5.
173 Brenton DP. Maternal phenylketonuria. Eur J Clin Nutr. 1989. X-1.
174 Breslow L, Somers AR. The lifetime health-monitoring program. A practical approach to preventive medicine. N Engl J Med. 1977. X-1, X-2, X-4.
175 Brooks PV, Rogers PJ. Low-protein, low-phenylalanine cakes. J Am Diet Assoc. 1969. X-1.
176 Bross R, et al. Tyrosine requirements in children with classical PKU determined by indicator amino acid oxidation. Am J Physiol Endocrinol Metab. 2000. X-4.
177 Brown AS, et al. Barriers to successful dietary control among pregnant women with phenylketonuria. Genet Med. 2002. X-4, X-5.
178 Brown DF, Taylor AJ. Some children with phenylketonuria. N Z Med J. 1968. X-1, X-3.
179 Brown ES, Warner R. Mental development of phenylketonuric children on or off diet after the age of six. Psychol Med. 1976. X-4, X-5.
180 Brown ES, Waisman HA. Mental retardation in four offspring of a hyperphenylalaninemic mother. Pediatrics. 1971. X-1, X-3, X-4, X-5.
181 Brown ES, Waisman HA. Low-phenylalanine diets for pregnant PKU heterozygotes are unnecessary. Pediatrics. 1967. X-1, X-2, X-3, X-4, X-5, X-6.
182 Brown KJ. “Physiological phenylketonuria”: a biochemical defect caused by delayed maturation of the phenylalanine hydroxylation pathway and by competition with the phenylalanine biosynthetic pathway. Med Hypotheses. 1980. X-1.
183 Brown KJ, et al. The assay on a defined medium of the effects of beta-2-thienylalanine on the growth of anaerobic bacterial isolates from phenylketonuric patients. Med Microbiol Immunol. 1980. X-3, X-4.
184 Brown MC, Guest JF. Economic impact of feeding a phenylalanine-restricted diet to adults with previously untreated phenylketonuria. J Intellect Disabil Res. 1999. X-3, X-4, X-5.
185 Brumm VL, et al. Neuropsychological outcome of subjects participating in the PKU adult collaborative study: a preliminary review. J Inherit Metab Dis. 2004. X-4, X-5.
186 Brunner RL, Jordan MK, Berry HK. Early-treated phenylketonuria: neuropsychologic consequences. J Pediatr. 1983. X-4, X-5.
187 Brunner RL, et al. Beneficial effect of isoleucine on fetal brain development in induced phenylketonuria. Brain Res. 1978. X-2, X-3, X-4, X-5.
188 Bryson G. Biogenic amines in normal and abnormal behavioral states. Clin Chem. 1971. X-1, X-2, X-3, X-4, X-5.
189 Buist NR, et al. A new amino acid mixture permits new approaches to the treatment of phenylketonuria. Acta Paediatr Suppl. 1994. X-4, X-5.
190 Burgard P, Link R, Schweitzer-Krantz S. Phenylketonuria: evidence-based clinical practice. Summary of the roundtable discussion. Eur J Pediatr. 2000. X-1.
191 Burgard P, et al. Rationale for the German recommendations for phenylalanine level control in phenylketonuria 1997. Eur J Pediatr. 1999. X-1.
192 Burgard P, et al. Neuropsychologic functions of early treated patients with phenylketonuria, on and off diet: results of a cross-national and cross-sectional study. Pediatr Res. 1997. X-4, X-5.
193 Burgard P, et al. Intellectual development of the patients of the German Collaborative Study of children treated for phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
194 Burgard P, et al. Phenylalanine hydroxylase genotypes, predicted residual enzyme activity and phenotypic parameters of diagnosis and treatment of phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
195 Burgard P, et al. Psychopathology of patients treated early for phenylketonuria: results of the German collaborative study of phenylketonuria. Acta Paediatr Suppl. 1994. X-4, X-5.
197 Burlina AB, et al. Measurement of neurotransmitter metabolites in the cerebrospinal fluid of phenylketonuric patients under dietary treatment. J Inherit Metab Dis. 2000. X-3, X-4, X-5.
198 Burns JK, et al. Impact of PKU on the reproductive patterns in collaborative study families. Am J Med Genet. 1984. X-2, X-4.
199 Burton BK, et al. The response of patients with phenylketonuria and elevated serum phenylalanine to treatment with oral sapropterin dihydrochloride (6R-tetrahydrobiopterin): a phase II, multicentre, open-label, screening study. J Inherit Metab Dis. 2007. X-4, X-5.
200 Burton JL, Goolamali SK, Shuster S. An abnormality in sebaceous function in phenylketonuria. Br Med J. 1975. X-3, X-4, X-5.
201 Bylinsky G. What science can do about hereditary diseases. Fortune. 1974. X-1.
202 Byrd DJ, et al. A study of urinary tryptophan metabolites in relation to the phenylalanine content of semi-synthetic diets in a patient with phenylketonuria. Acta Vitaminol Enzymol. 1975. X-3.
203 Belanger-Quintana A, et al. Spanish BH4-responsive phenylalanine hydroxylase-deficient patients: evolution of seven patients on long-term treatment with tetrahydrobiopterin. Mol Genet Metab. 2005. X-3, X-4, X-5.
204 Benit P, et al. The mutant genotype is the main determinant of the metabolic phenotype in phenylalanine hydroxylase deficiency. Mol Genet Metab. 1999. X-4, X-5.
205 Boveda MD, et al. The tetrahydrobiopterin loading test in 36 patients with hyperphenylalaninaemia: evaluation of response and subsequent treatment. J Inherit Metab Dis. 2007. X-3, X-4, X-5.
206 Bohles H, et al. Inadequate iron availability as a possible cause of low serum carnitine concentrations in patients with phenylketonuria. Eur J Pediatr. 1991. X-4, X-5.
207 Cabalska B, et al. Hyperphenylalaninemia in Polish children's population. Acta Anthropogenet. 1985. X-4.
208 Cabalska B, et al. Termination of dietary treatment in phenylketonuria. Eur J Pediatr. 1977. X-4.
209 Cabalska B. Phenylketonuria. Early diagnosis and treatment. Probl Med Wieku Rozwoj. 1975. X-1.
210 Cabalska B, Duczynska N. Phenyketonuria. Evaluation of early treatment. Pol Med J. 1970. X-1.
211 Cabalska B, Duczynska N, Wnuk W. The incidence of phenylketonuria and evaluation of its early treatment. Pol Med J. 1969. X-4.
212 Cabalska MB, et al. Longitudinal study on early diagnosis and treatment of phenylketonuria in Poland. Eur J Pediatr. 1996. X-4, X-5.
213 Cahalane SF. Laboratory aspects of phenylketonuria detection and treatment. J Clin Pathol. 1969. X-1, X-2, X-3, X-4, X-5.
214 Calomme M, et al. Effects of selenium supplementation on thyroid hormone metabolism in phenylketonuria subjects on a phenylalanine restricted diet. Biol Trace Elem Res. 1995. X-4, X-5.
215 Calomme MR, et al. Thyroid function parameters during a selenium repletion/depletion study in phenylketonuric subjects. Experientia. 1995. X-4.
216 Camfield CS, et al. Optimal management of phenylketonuria: a centralized expert team is more successful than a decentralized model of care. J Pediatr. 2004. X-4, X-5.
217 Cardona F, et al. The development of auditory and visual evoked potentials in early treated phenylketonuric children. Electroencephalogr Clin Neurophysiol. 1991. X-3, X-4.
218 Carlson HE, et al. Prolactin responses to phenylalanine and tyrosine in phenylketonuria. Metabolism. 1992. X-4, X-5.
219 Carson DJ, et al. Osteopenia and phenylketonuria. Pediatr Radiol. 1990. X-4, X-5.
220 Carson NA. Management of hyperphenylalaninaemia (HPA) in Northern Ireland. Arch Dis Child. 1971. X-3, X-4, X-5.
221 Carson NA. Diagnosis and management of hyperphenylalaninaemia. Arch Dis Child. 1971. X-1, X-2, X-3, X-4, X-5.
222 Cartier L, et al. Prevention of mental retardation in offspring of hyperphenylalaninemic mothers. Am J Public Health. 1982. X-1, X-2, X-3, X-4, X-5.
223 Carvalho RN, et al. Deamidations in recombinant human phenylalanine hydroxylase. Identification of labile asparagine residues and functional characterization of Asn --> Asp mutant forms. J Biol Chem. 2003. X-2, X-3, X-4.
224 Carver MJ, Copenhaver JH, Serpan RA. Free amino acids in foetal rat brain. Influence of l-phenylalanine. J Neurochem. 1965. X-2, X-3, X-4, X-5.
225 Castells S, Brandt IK. Phenylketonuria: evaluation of therapy and verification of diagnosis. J Pediatr. 1968. X-4, X-5.
226 Canada-Canada F, et al. Determination of marker pteridins and biopterin reduced forms, tetrahydrobiopterin and dihydrobiopterin, in human urine, using a post-column photoinduced fluorescence liquid chromatographic derivatization method. Anal Chim Acta. 2009. X-4.
227 Cechak P, Hejcmanova L, Rupp A. Long-term follow-up of patients treated for phenylketonuria (PKU). Results from the Prague PKU Center. Eur J Pediatr. 1996. X-3, X-4, X-5.
228 Centerwall SA, Centerwall WR. Phenylketonuria and phenylalanine diet. J Pediatr. 1969. X-1, X-3, X-4, X-5.
230 Cerone R, Cohen A, Romano C. Prevention and screening. J Perinat Med. 1994. X-4, X-5.
231 Chamberlain J. Screening for the early detection of diseases in Great Britain. Prev Med. 1975. X-4.
232 Chamberlain JM. Which prescriptive screening programmes are worth while?. J Epidemiol Community Health. 1984. X-1, X-2, X-3, X-4.
233 Chamove AS. Analysis of learning in retarded monkeys. J Ment Defic Res. 1984. X-2, X-3, X-4.
234 Chamove AS. Dietary and metabolic effects on rhesus social behavior: phenylalanine-related dietary alterations. Dev Psychobiol. 1980. X-2, X-3, X-4.
235 Chan L, Bell L, Hanley WB. Revision of the Ontario phenylalanine equivalency system and development of a low protein equivalency system. J Can Diet Assoc. 1982. X-1, X-2, X-3, X-4.
236 Chang P, Fisch RO. Observation of behavioral and personality characteristics of phenylketonurics according to their dietary duration: early treatment and normal intelligence. Psychol Rep. 1976. X-4, X-5.
237 Chang PN, Gray RM, O'Brien LL. Patterns of academic achievement among patients treated early with phenylketonuria. Eur J Pediatr. 2000. X-4, X-5.
238 Chang PN, Weisberg S, Fisch RO. Growth development and its relationship to intellectual functioning of children with phenylketonuria. J Dev Behav Pediatr. 1984. X-4, X-5.
239 Chang TM. Medical applications of artificial cells in transfusion, phenylketonuria, essential amino acid production, and liver support. Ann N Y Acad Sci. 1988. X-2, X-4.
243 Chen MM, Bush JW. Maximizing health system output with political and administrative constraints using mathematical programming. Inquiry. 1976. X-2, X-4.
244 Chien YH, et al. Phenylalanine hydroxylase deficiency: intelligence of patients after early dietary treatment. Acta Paediatr Taiwan. 2004. X-4, X-5.
245 Chien YH, et al. Mutation spectrum in Taiwanese patients with phenylalanine hydroxylase deficiency and a founder effect for the R241C mutation. Hum Mutat. 2004. X-4.
246 Chien YH, et al. Cranial MR spectroscopy of tetrahydrobiopterin deficiency. AJNR Am J Neuroradiol. 2002. X-2,X-3, X-4.
247 Chien YH, et al. Treatment and outcome of Taiwanese patients with 6-pyruvoyltetrahydropterin synthase gene mutations. J Inherit Metab Dis. 2001. X-2, X-4.
248 Cho S, McDonald JD. Effect of maternal blood phenylalanine level on mouse maternal phenylketonuria offspring. Mol Genet Metab. 2001. X-2, X-3, X-4.
250 Christensen R, et al. Characterization of transgenic mice with the expression of phenylalanine hydroxylase and GTP cyclohydrolase I in the skin. Exp Dermatol. 2005. X-2, X-4.
251 Christensen R, Kolvraa S, Jensen TG. Manipulation of the phenylalanine metabolism in human keratinocytes by retroviral mediated gene transfer. Cells Tissues Organs. 2005. X-1, X-2, X-4.
252 Christensen R, Guttler F, Jensen TG. Comparison of epidermal keratinocytes and dermal fibroblasts as potential target cells for somatic gene therapy of phenylketonuria. Mol Genet Metab. 2002. X-2, X-4.
253 Christensen R, et al. Development of a skin-based metabolic sink for phenylalanine by overexpression of phenylalanine hydroxylase and GTP cyclohydrolase in primary human keratinocytes. Gene Ther. 2000. X-2, X-4.
255 Ciske JB, et al. Newborn screening in Wisconsin: program overview and test addition. WMJ. 2000. X-1, X-2, X-4.
256 Citron BA, et al. Mutation in the 4a-carbinolamine dehydratase gene leads to mild hyperphenylalaninemia with defective cofactor metabolism. Am J Hum Genet. 1993. X-2, X-4.
257 Clark BJ. After a positive Guthrie--what next? Dietary management for the child with phenylketonuria. Eur J Clin Nutr. 1992. X-1.
258 Clark BJ, Cockburn F. Management of inborn errors of metabolism during pregnancy. Acta Paediatr Scand Suppl. 1991. X-1, X-4.
259 Clarke JT. The Maternal Phenylketonuria Project: a summary of progress and challenges for the future. Pediatrics. 2003. X-1, X-4.
260 Clarke JT, et al. Neuropsychological studies on adolescents with phenylketonuria returned to phenylalanine-restricted diets. Am J Ment Retard. 1987. X-3.
261 Clarke JT, Lowden JA. Hyperphenylalaninemia: effect on the developing rat brain. Can J Biochem. 1969. X-2, X-4.
262 Clayton B, Moncrieff A, Roberts GE. Dietetic treatment of phenylketonuria: a follow-up study. Br Med J. 1967. X-4, X-5.
263 Clayton BE. Experience with a screening service, using the Guthrie test, in the north-west and north-east metropolitan regions. Arch Dis Child. 1971. X-3, X-4, X-5.
264 Clayton BE. Phenylketonuria. J Med Genet. 1971. X-1, X-5.
265 Clayton BE, Heeley AF, Heeley M. An investigation of the hyperaminoaciduria in phenylketonuria associated with the feeding of certain commercial low-phenylalanine preparations. Br J Nutr. 1970. X-4, X-5.
266 Clayton BE, et al. Biochemical and EEG studies in phenylketonuric children during phenylalanine tolerance testc. Arch Dis Child. 1966. X-4, X-5.
267 Cleary MA, et al. Randomised controlled trial of essential fatty acid supplementation in phenylketonuria. Eur J Clin Nutr. 2006. X-4, X-5.
268 Cleary MA, et al. Magnetic resonance imaging in phenylketonuria: reversal of cerebral white matter change. J Pediatr. 1995. X-4, X-5.
269 Cleary MA, et al. Magnetic resonance imaging of the brain in phenylketonuria. Lancet. 1994. X-4, X-5.
270 Clemens PC, et al. Phenylalanine and other amino acids in phenylketonuria. J Inherit Metab Dis. 1993. X-4, X-5.
271 Clemens PC, et al. Newborn screening for hyperphenylalaninemia on day 5: is 240 mumol/liter the most appropriate cut-off level?. Prev Med. 1990. X-4.
272 Clemens PC, et al. Plasma concentrations of phenyllactic acid in phenylketonuria. J Inherit Metab Dis. 1990. X-4, X-5.
273 Clow CL. Genetic services in Canada: the view from Medicare. Prog Clin Biol Res. 1982. X-1.
274 Clow CL, Reade TM, Scriver CR. Management of hereditary metabolic disease. The role of allied health personnel. N Engl J Med. 1971. X-4, X-5.
275 Cockburn F, Clark BJ. Recommendations for protein and amino acid intake in phenylketonuric patients. Eur J Pediatr. 1996. X-1.
276 Coelho JC, et al. Selective screening of 10,000 high-risk Brazilian patients for the detection of inborn errors of metabolism. Eur J Pediatr. 1997. X-4.
277 Coffin M, Sukhatme S. Receiver operating characteristic studies and measurement errors. Biometrics. 1997. X-2, X-4.
278 Cohen BE, et al. Group work with adolescent PKU girls and their mothers. J Inherit Metab Dis. 1988. X-4.
279 Cohen BE, et al. Phenylketonuria (PKU) in Israel. Monogr Hum Genet. 1978. X-1.
280 Cohen BE, et al. Evaluation of dietary treatment in phenylketonuria: a proposed methodology. Dev Med Child Neurol. 1969. X-1.
281 Cohen BE, et al. Screening program for early detection of phenylketonuria in the newborn in Israel. Isr J Med Sci. 1966. X-1.
282 Collins RJ, et al. In vitro OKT3-induced mitogenesis in selenium-deficient patients on a diet for phenylketonuria. Biol Trace Elem Res. 1991. X-4.
283 Colombo JP. Plasma glutamine in a phenylketonuric family with normal and mentally defective members. Arch Dis Child. 1971. X-3, X-4, X-5.
284 Colome C, et al. Plasma thiols and their determinants in phenylketonuria. Eur J Clin Nutr. 2003. X-4.
285 Colome C, et al. Lipophilic antioxidants in patients with phenylketonuria. Am J Clin Nutr. 2003. X-4.
286 Colome C, et al. Is there a relationship between plasma phenylalanine and cholesterol in phenylketonuric patients under dietary treatment?. Clin Biochem. 2001. X-4.
287 Colyar M. Newborn screening tests. Adv Nurse Pract. 2004. X-4.
288 Comar D, et al. Brain uptake of 11C-methionine in phenylketonuria. Eur J Pediatr. 1981. X-4.
289 Copenhaver JH, Carver MJ, Schain RJ. Effects of folic and folinic acids on the metabolism of phenylalanine in phenylketonuria. Metabolism. 1965. X-3, X-4, X-5.
290 Costa LG, et al. Developmental neurotoxicity: do similar phenotypes indicate a common mode of action? A comparison of fetal alcohol syndrome, toluene embryopathy and maternal phenylketonuria. Toxicol Lett. 2002. X-4.
291 Costello PM, et al. Intelligence in mild atypical phenylketonuria. Eur J Pediatr. 1994. X-4, X-5.
292 Courtney-Martin G, et al. Phenylalanine requirement in children with classical PKU determined by indicator amino acid oxidation. Am J Physiol Endocrinol Metab. 2002. X-3, X-4, X-5.
293 Coutts J. The dietary management of phenylketonuria. Proc Nutr Soc. 1979. X-1, X-3, X-4, X-5.
294 Coward RF, Smith P, Seakins JW. Investigation of ketoacidurias by two-dimensional paper chromatography. J Clin Pathol. 1969. X-4.
295 Cowie V. Maternal phenylketonuria: diet in pregnancy reduces danger. Nurs Mirror. 1979. X-1.
296 Cox AW, et al. Children with phenylketonuria: crisis prevention or crisis intervention?. Matern Child Nurs J. 1974. X-1.
297 Coskun T, et al. Neurophysiological studies of patients with classical phenylketonuria: evaluation of results of IQ scores, EEG and evoked potentials. Turk J Pediatr. 1993. X-4, X-5.
298 Craft S, et al. Lateralized deficits in visual attention in males with developmental dopamine depletion. Neuropsychologia. 1992. X-4, X-5.
299 Cristiano RJ, Smith LC, Woo SL. Hepatic gene therapy: adenovirus enhancement of receptor-mediated gene delivery and expression in primary hepatocytes. Proc Natl Acad Sci U S A. 1993. X-2, X-3, X-4.
300 Crocker AC. Current strategies in prevention of mental retardation. Pediatr Ann. 1982. X-1.
301 Crombez E, Koch R, Cederbaum S. Pitfalls in newborn screening. J Pediatr. 2005. X-4.
302 Crone MR, et al. Behavioural factors related to metabolic control in patients with phenylketonuria. J Inherit Metab Dis. 2005. X-4.
303 Crowley C, et al. Clinical trial of ‘off diet’ older phenylketonurics with a new phenylalanine-free product. J Ment Defic Res. 1990. X-4.
304 Cunningham GC. Phenylketonuria. Early detection, diagnosis and treatment. Calif Med. 1966. X-1, X-2, X-3, X-4, X-5, X-7.
305 Curtius HC, Endres W, Blau N. Effect of high-protein meal plus aspartame ingestion on plasma phenylalanine concentrations in obligate heterozygotes for phenylketonuria. Metabolism. 1994. X-4.
306 Curtius HC, et al. 7-Substituted pterins. A new class of mammalian pteridines. J Biol Chem. 1990. X-2, X-3, X-4.
307 Curtius HC, et al. Therapeutic efficacy of tetrahydrobiopterin in Parkinson's disease. Adv Neurol. 1984. X-2, X-4.
308 Curtius HC, et al. Serotonin and dopamine synthesis in phenylketonuria. Adv Exp Med Biol. 1981. X-2, X-3, X-4.
309 Curtius HC, Farner H, Rey F. In vivo studies of the tryptophan-5-hydroxylase system. Quantitation of serotonin and tryptamine using gas chromatography-mass fragmentography. J Chromatogr. 1980. X-3, X-4.
310 Curtius HC, et al. In vivo studies of the phenylalanine-4-hydroxylase system in hyperphenylalaninemics and phenylketonurics. Helv Paediatr Acta. 1978. X-4.
311 Dagenais DL, Courville L, Dagenais MG. A cost-benefit analysis of the Quebec Network of Genetic Medicine. Soc Sci Med. 1985. X-1, X-2, X-3, X-4.
312 Dahri S, et al. Mutation analysis of phenylketonuria patients from Morocco: high prevalence of mutation G352fsdelG and detection of a novel mutation p.K85X. Clin Biochem. 2010. X-3, X-4.
313 Daniele A, et al. Functional and structural characterization of novel mutations and genotype-phenotype correlation in 51 phenylalanine hydroxylase deficient families from Southern Italy. FEBS J. 2009. X-2, X-4.
314 Daniele A, et al. Five human phenylalanine hydroxylase proteins identified in mild hyperphenylalaninemia patients are disease-causing variants. Biochim Biophys Acta. 2008. X-2, X-4.
315 Daniele A, et al. Molecular epidemiology of phenylalanine hydroxylase deficiency in Southern Italy: a 96% detection rate with ten novel mutations. Ann Hum Genet. 2007. X-2, X-4.
316 Danks DM, Cotton RG. Future developments in phenylketonuria. Enzyme. 1987. X-1.
317 Danks DM, Cotton RG. Early diagnosis of hyperphenylalaninemia due to tetrahydrobiopterin deficiency (malignant hyperphenylalaninemia). J Pediatr. 1980. X-1, X-2, X-3, X-4, X-5, X-7.
318 Danks DM. Current status of PKU diagnosis and treatment. Aust Paediatr J. 1979. X-1.
319 Danks DM, et al. Malignant hyperphenylalaninaemia--current status (June 1977). J Inherit Metab Dis. 1978. X-1, X-4, X-5.
320 Danks DM, Cotton RG, Schlesinger P. Letter: Variant forms of phenylketonuria. Lancet. 1976. X-1, X-2, X-3, X-4.
321 Danks DM. Prospects for the prevention of genetic disease. Med J Aust. 1973. X-1.
322 Darling G, et al. Serum selenium levels in individuals on PKU diets. J Inherit Metab Dis. 1992. X-4, X-5.
323 Daubner SC, Hillas PJ, Fitzpatrick PF. Expression and characterization of the catalytic domain of human phenylalanine hydroxylase. Arch Biochem Biophys. 1997. X-2, X-3, X-4.
324 Davidson DC, Maternal PKU. pre-conception treatment--the need for free prescriptions. Midwives Chron. 1989. X-1.
325 Day RW. Public programs to aid in prevention. Ment Retard. 1969. X-1.
326 de Baulny HO, et al. Management of phenylketonuria and hyperphenylalaninemia. J Nutr. 2007. X-1, X-2, X-3, X-4, X-5.
327 De Giorgis GF, et al. Evolution of daytime quiet sleep components in early treated phenylketonuric infants. Brain Dev. 1996. X-4.
328 De Giorgis GF, et al. EEG as a possible prognostic tool in phenylketonuria. Electroencephalogr Clin Neurophysiol. 1983. X-4, X-5.
329 de Sonneville LM, et al. Event-related potential correlates of selective processing in early- and continuously-treated children with phenylketonuria: effects of concurrent phenylalanine level and dietary control. Mol Genet Metab. 2010. X-4, X-5.
331 De Souza NC, Botelho CA, Honer MR. Retrospective study of a pioneer antenatal screening program with 8,477 pregnant women in Brazil. Clin Exp Obstet Gynecol. 2004. X-3, X-4.
332 DeClue TJ, et al. Serum lipid concentrations in subjects with phenylketonuria and their families. Am J Dis Child. 1991. X-4.
333 Demmelmair H, et al. Estimation of arachidonic acid synthesis in full term neonates using natural variation of 13C content. J Pediatr Gastroenterol Nutr. 1995. X-3.
334 Dennis M, et al. Intelligence patterns among children with high-functioning autism, phenylketonuria, and childhood head injury. J Autism Dev Disord. 1999. X-4.
335 Desviat LR, et al. Tetrahydrobiopterin responsiveness: results of the BH4 loading test in 31 Spanish PKU patients and correlation with their genotype. Mol Genet Metab. 2004. X-4, X-5.
336 Dhondt JL, et al. Physical growth in patients with phenylketonuria. J Inherit Metab Dis. 1995. X-4, X-5.
337 Dhondt JL. Strategy for the screening of tetrahydrobiopterin deficiency among hyperphenylalaninaemic patients: 15-years experience. J Inherit Metab Dis. 1991. X-2, X-3, X-4.
338 Dhondt JL, Delcroix M, Farriaux JP. Unconjugated pteridines in human milk. Clin Chim Acta. 1982. X-2, X-3, X-4.
339 Dhondt JL, et al. Developmental aspects of pteridine metabolism and relationships with phenylalanine metabolism. Clin Chim Acta. 1981. X-4.
340 Dhondt JL, et al. Diagnosis of variants of hyperphenylalaninemia by determination of pterins in urine. Clin Chim Acta. 1981. X-4.
341 Dhondt JL, Farriaux JP. Hepatic phenylalanine hydroxylase activity in hyperphenylalaninaemia. J Inherit Metab Dis. 1981. X-4, X-5.
342 Dhondt JL, Farriaux JP. Study of blood aminoacids in experimental hyperphenylalaninemia. Biomedicine. 1977. X-2, X-3, X-4.
343 Dhondt JL, et al. A new experimental model of hyperphenylalaninemia in rat. Effect of p-chlorophenylalanine and cotrimoxazole. Biochimie. 1977. X-2, X-3, X-4.
344 Diamond A, et al. Prefrontal cortex cognitive deficits in children treated early and continuously for PKU. Monogr Soc Res Child Dev. 1997. X-4, X-5.
345 Diamond A, Herzberg C. Impaired sensitivity to visual contrast in children treated early and continuously for phenylketonuria. Brain. 1996. X-4, X-5.
346 Dianzani I, et al. Dihydropteridine reductase deficiency: physical structure of the QDPR gene, identification of two new mutations and genotype-phenotype correlations. Hum Mutat. 1998. X-2, X-3, X-4.
347 Dierks-Ventling C, Cone AL. Phenylketonuria and glutamine. N Engl J Med. 1970. X-1, X-2, X-3, X-4, X-5.
348 DiLella AG, et al. Tight linkage between a splicing mutation and a specific DNA haplotype in phenylketonuria. Nature. 1986. X-4.
349 Ding XQ, et al. MRI abnormalities in normal-appearing brain tissue of treated adult PKU patients. J Magn Reson Imaging. 2008. X-3.
350 Dobbelaere D, et al. Evaluation of nutritional status and pathophysiology of growth retardation in patients with phenylketonuria. J Inherit Metab Dis. 2003. X-4, X-5.
351 Dobrowolski SF, et al. A limited spectrum of phenylalanine hydroxylase mutations is observed in phenylketonuria patients in western Poland and implications for treatment with 6R tetrahydrobiopterin. J Hum Genet. 2009. X-4, X-5.
352 Dobrowolski SF, et al. Biochemical characterization of mutant phenylalanine hydroxylase enzymes and correlation with clinical presentation in hyperphenylalaninaemic patients. J Inherit Metab Dis. 2009. X-4, X-5.
353 Dobrowolski SF, et al. Mutations in the phenylalanine hydroxylase gene identified in 95 patients with phenylketonuria using novel systems of mutation scanning and specific genotyping based upon thermal melt profiles. Mol Genet Metab. 2007. X-4.
354 Dobson J, et al. Cognitive development and dietary therapy in phenylketonuric children. N Engl J Med. 1968. X-4, X-5.
355 Dobson JC, et al. Intellectual assessment of 111 four-year-old children with phenylketonuria. Pediatrics. 1977. X-4, X-5.
356 Dobson JC, et al. Intellectual performance of 36 phenylketonuria patients and their nonaffected siblings. Pediatrics. 1976. X-4, X-5.
357 Dockhorn RJ. Milk allergy in an infant with phenylketonuria. Ann Allergy. 1970. X-3, X-4.
358 Dodge JA. Infantile hypertrophic pyloric stenosis in Belfast, 1957-1969. Arch Dis Child. 1975. X-2, X-3, X-4, X-5.
359 Doggrell SA. Is sapropterin treatment suitable for all subjects with phenylketonuria?. Expert Opin Pharmacother. 2008. X-1, X-2, X-3, X-4, X-5.
360 Doherty LB, Rohr FJ, Levy HL. Detection of phenylketonuria in the very early newborn blood specimen. Pediatrics. 1991. X-3, X-4.
361 Donker DN, et al. Computer analysis of the EEG as an aid in the evaluation of dietetic treatment in phenylketonuria. Electroencephalogr Clin Neurophysiol. 1979. X-3, X-4.
362 Dotremont H, et al. Nutritional value of essential amino acids in the treatment of adults with phenylketonuria. J Inherit Metab Dis. 1995. X-3, X-4, X-5.
363 Downing GJ, et al. Enhancing the quality and efficiency of newborn screening programs through the use of health information technology. Semin Perinatol. 2010. X-1, X-2, X-3, X-4.
364 Drew FE. The PKU law. Wis Med J. 1966. X-4.
365 Drogari E, et al. Timing of strict diet in relation to fetal damage in maternal phenylketonuria. An international collaborative study by the MRC/DHSS Phenylketonuria Register. Lancet. 1987. X-4, X-5.
366 Drtilkova I, et al. Controlled comparison of the effect of dosulepin and diazepam in hyperkinetic children with phenylketonuria. Act Nerv Super (Praha). 1978. X-4.
367 Dumars KW, et al. Prevention of developmental disabilities: a model for organizing clinical activities. Res Dev Disabil. 1987. X-1, X-2, X-3, X-4.
368 Durham-Shearer SJ, et al. Knowledge, compliance and serum phenylalanine concentrations in adolescents and adults with phenylketonuria and the effect of a patient-focused educational resource. J Hum Nutr Diet. 2008. X-4, X-5.
369 Doskeland AP, Flatmark T. Recombinant human phenylalanine hydroxylase is a substrate for the ubiquitin-conjugating enzyme system. Biochem J. 1996. X-2, X-3, X-4.
370 Eaton BM, Sooranna SR. Transport of large neutral amino acids into BeWo cells. Placenta. 2000. X-1, X-2, X-3, X-4.
371 Eavri R, Lorberboum-Galski H. A novel approach for enzyme replacement therapy. The use of phenylalanine hydroxylase-based fusion proteins for the treatment of phenylketonuria. J Biol Chem. 2007. X-2, X-3, X-4.
372 Economou-Petersen E, et al. Molecular basis for nonphenylketonuria hyperphenylalaninemia. Genomics. 1992. X-2, X-3, X-4.
373 Efe E, Savaser S. The effect of two different methods used during peripheral venous blood collection on pain reduction in neonates. Agri. 2007. X-4.
374 Efron ML, et al. Effect of elevated plasma phenylalanine levels on other amino acids in phenylketonuric and normal subjects. J Pediatr. 1969. X-4, X-5.
375 Efron ML. Diet therapy for inborn errors of amino acid metabolism. J Am Diet Assoc. 1967. X-1.
376 Eggertsen SC, Schneeweiss R, Bergman JJ. An updated protocol for pediatric health screening. J Fam Pract. 1980. X-1, X-2, X-3, X-4.
377 Eisenberg L. Prevention: rhetoric and reality. J R Soc Med. 1984. X-1.
378 Eisensmith RC, et al. Molecular basis of phenylketonuria and a correlation between genotype and phenotype in a heterogeneous southeastern US population. Pediatrics. 1996. X-4, X-5.
379 Embury SP. Phenylketonuria: report of a case managed in a rural Nebraska community. Nebr Med J. 1973. X-3.
380 Emery AE, Farquhar JW, Timson J. Amniotic fluid amino acids in maternal phenylketonuria. Clin Chim Acta. 1972. X-3, X-4, X-5.
381 Epps RP. Phenylketonuria in an American Negro infant. Clin Pediatr (Phila). 1968. X-3.
382 Epstein CM, et al. EEG mean frequencies are sensitive indices of phenylalanine effects on normal brain. Electroencephalogr Clin Neurophysiol. 1989. X-2, X-4, X-5.
383 Erlandsen H, et al. Correction of kinetic and stability defects by tetrahydrobiopterin in phenylketonuria patients with certain phenylalanine hydroxylase mutations. Proc Natl Acad Sci U S A. 2004. X-2, X-4, X-5.
384 Erlandsen H, et al. Structural comparison of bacterial and human iron-dependent phenylalanine hydroxylases: similar fold, different stability and reaction rates. J Mol Biol. 2002. X-2, X-3, X-4.
385 Fan GX, et al. Molecular studies and prenatal diagnosis of phenylketonuria in Chinese patients. Southeast Asian J Trop Med Public Health. 1999. X-3, X-4.
386 Fan GX, Jun Y, Rui-guan C. Neonatal screening of phenylketonuria and congenital hypothyroidism in China. Southeast Asian J Trop Med Public Health. 1999. X-1, X-4.
387 Fang B, et al. Gene therapy for phenylketonuria: phenotypic correction in a genetically deficient mouse model by adenovirus-mediated hepatic gene transfer. Gene Ther. 1994. X-2, X-3, X-4.
388 Farquhar JW. Baby of a phenylketonuric mother. Inferences drawn from a single case. Arch Dis Child. 1974. X-3.
389 Farquhar JW, Miller MC, Lindsay G. Maternal phenylketonuria. Br Med J. 1971. X-3, X-4, X-5.
390 Farrugia R, et al. Molecular genetics of tetrahydrobiopterin (BH4) deficiency in the Maltese population. Mol Genet Metab. 2007. X-4.
391 Faust D, Libon D, Pueschel S. Neuropsychological functioning in treated phenylketonuria. Int J Psychiatry Med. 1986. X-4, X-5.
392 Fehrenbach AM, Peterson L. Parental problem-solving skills, stress, and dietary compliance in phenylketonuria. J Consult Clin Psychol. 1989. X-2, X-4.
393 Feillet F, et al. Challenges and pitfalls in the management of phenylketonuria. Pediatrics. 2010. X-1, X-2, X-3, X-4.
394 Feillet F, et al. Evaluation of neonatal BH4 loading test in neonates screened for hyperphenylalaninemia. Early Hum Dev. 2008. X-4, X-5.
395 Feillet F, et al. Pharmacokinetics of sapropterin in patients with phenylketonuria. Clin Pharmacokinet. 2008. X-4, X-5.
396 Feillet F, et al. Maternal phenylketonuria: the French survey. Eur J Pediatr. 2004. X-4, X-5.
397 Feinberg I. Eye movement ativity during sleep and intellectual function in mental retardation. Science. 1968. X-2, X-3, X-4.
398 Feldmann R, et al. Phenylketonuria: no specific frontal lobe-dependent neuropsychological deficits of early-treated patients in comparison with diabetics. Pediatr Res. 2002. X-4, X-5.
399 Fellman JH, Fujita TS, Roth ES. Assay, properties and tissue distribution of p-hydroxyphenylpyruvate hydroxylase. Biochim Biophys Acta. 1972. X-2, X-3, X-4.
400 Feng YK, et al. Infantile spasms. A retrospective study of 105 cases. Chin Med J (Engl). 1991. X-4.
401 Fernhoff PM, et al. Coordinated system for comprehensive newborn metabolic screening. South Med J. 1982. X-3, X-4.
402 Ficner R, et al. Three-dimensional structure of the bifunctional protein PCD/DCoH, a cytoplasmic enzyme interacting with transcription factor HNF1. EMBO J. 1995. X-2, X-3, X-4.
403 Fiedler AE, et al. Phenylalanine levels in PKU following minor surgery. Am J Med Genet. 1982. X-4.
404 Fiege B, Blau N. Assessment of tetrahydrobiopterin (BH4) responsiveness in phenylketonuria. J Pediatr. 2007. X-4, X-5.
405 Fiege B, et al. Extended tetrahydrobiopterin loading test in the diagnosis of cofactor-responsive phenylketonuria: a pilot study. Mol Genet Metab. 2005. X-4, X-5.
406 Fiege B, et al. Plasma tetrahydrobiopterin and its pharmacokinetic following oral administration. Mol Genet Metab. 2004. X-3, X-4.
407 Filer LJ Jr., Stegink LD. Aspartame metabolism in normal adults, phenylketonuric heterozygotes, and diabetic subjects. Diabetes Care. 1989. X-1, X-2, X-3, X-4.
408 Finkelson L, Bailey I, Waisbren SE. PKU adults and their return to diet: predicting diet continuation and maintenance. J Inherit Metab Dis. 2001. X-4, X-5.
409 Fiori L, et al. Incidence of BH4-responsiveness in phenylalanine-hydroxylase-deficient Italian patients. Mol Genet Metab. 2005. X-4, X-5.
410 Fisberg RM, et al. Nutritional evaluation of children with phenylketonuria. Sao Paulo Med J. 1999. X-4, X-5.
411 Fisberg RM, et al. Plasma zinc, copper, and erythrocyte superoxide dismutase in children with phenylketonuria. Nutrition. 1999. X-4, X-5.
412 Fisch RO, et al. Phenylketonuria: current dietary treatment practices in the United States and Canada. J Am Coll Nutr. 1997. X-1, X-3, X-4.
413 Fisch RO, et al. Phenylketonuric patients decades after diet. J Inherit Metab Dis. 1995. X-4, X-5.
414 Fisch RO, et al. Bony changes of PKU neonates unrelated to phenylalanine levels. J Inherit Metab Dis. 1991. X-4.
415 Fisch RO, et al. Contact with phenylketonurics and their families beyond pediatric age: conclusion from a survey and conference. Ment Retard. 1977. X-1, X-4.
416 Fisch RO, Bilek MK, Bruhl HH. Causes of death of institutionalized phenylketonuric (PKU) patients-A national survey. Minn Med. 1976. X-4.
417 Fisch RO, Chang PN. A phenylketonuric with superior intelligence. Minn Med. 1973. X-3, X-4.
418 Fisch RO, Solberg JA, Borud L. Responses of children with phenylketonuria to dietary treatment. J Am Diet Assoc. 1971. X-3, X-4, X-5.
419 Fisch RO, et al. Twelve years of clinical experience with phenylketonuria. A statistical evaluation of symptoms, growth, mental development, electroencephalographic records, serum phenylalanine levels, and results of dietary management. Neurology. 1969. X-1.
420 Fischer GM, et al. Metabolism of carnitine in phenylacetic acid-treated rats and in patients with phenylketonuria. Biochim Biophys Acta. 2000. X-4.
421 Fischer M. Mandatory legislation for the screening of newborns for PKU in the United States. Ment Retard. 1971. X-1, X-2, X-3, X-4.
422 Fishler K, et al. School achievement in treated PKU children. J Ment Defic Res. 1989. X-4, X-5+. X-4, X-5.
423 Fishler K, et al. Psychoeducational findings among children treated for phenylketonuria. Am J Ment Defic. 1987. X-4, X-5.
424 Flannery DB, Hitchcock E, Mamunes P. Dietary management of phenylketonuria from birth using a phenylalanine-free product. J Pediatr. 1983. X-3, X-4, X-5.
425 Fomous C, Miller N. The role of National Library of Medicine web sites in newborn screening education. Ment Retard Dev Disabil Res Rev. 2006. X-1, X-2, X-3, X-4.
426 Ford RC, Sollee ND, Kang ES. Treatment in phenylketonuria: statistical questions. Pediatrics. 1971. X-1.
427 Forsum E, Hambraeus L. Biological evaluation of a whey protein fraction, with special reference to its use as a phenylalanine-low protein source in the dietary treatment of PKU. Nutr Metab. 1972. X-4.
428 Fossbakk A, Haavik J. An oxygraphic method for determining kinetic properties and catalytic mechanism of aromatic amino acid hydroxylases. Anal Biochem. 2005. X-2, X-3, X-4.
429 Fox JG. Experience of the Manitoba Perinatal Screening Program, 1965-85. CMAJ. 1987. X-4.
430 Fox JG, et al. Newborn screening for hereditary metabolic disorders in Manitoba, 1965-1970. Can Med Assoc J. 1971. X-2, X-3, X-4.
431 France-Dawson M. Sickle cell disease: implications for nursing care. J Adv Nurs. 1986. X-2, X-3, X-4.
432 Francis DE. Inborn errors of metabolism: the need for sugar. J Hum Nutr. 1979. X-1.
433 Francis DE. Therapeutic special diets. Practitioner. 1974. X-1.
434 Francis I. Newborn screening in Australia and New Zealand 1984-1990. Human Genetics Society of Australasia/Australian College of Paediatrics Committee on Newborn Metabolic Screening. Med J Aust. 1991. X-1.
435 Frank N, Fitzgerald R, Legge M. Phenylketonuria--the lived experience. N Z Med J. 2007. X-3.
436 Frankenburg WK, Goldstein AD, Olson CO. Behavioral consequences of increased phenylalanine intake by phenylketonuric children: a pilot study describing a methodology. Am J Ment Defic. 1973. X-4.
437 Francois B, Diels M, de la Brassinne M. Iatrogenic skin lesions in phenylketonuric children due to a low tyrosine intake. J Inherit Metab Dis. 1989. X-4.
438 Freeto S, et al. A rapid ultra performance liquid chromatography tandem mass spectrometric method for measuring amino acids associated with maple syrup urine disease, tyrosinaemia and phenylketonuria. Ann Clin Biochem. 2007. X-2, X-3, X-4.
439 Friedman EG, et al. The International Collaborative Study on maternal phenylketonuria: organization, study design and description of the sample. Eur J Pediatr. 1996. X-4, X-5.
440 Friedmann T, Roblin R. Gene therapy for human genetic disease?. Science. 1972. X-1, X-2, X-3, X-4.
441 Fuller R, Shuman J. Treated phenylketonuria: intelligence and blood phenylalanine levels. Am J Ment Defic. 1971. X-4, X-5.
442 Fuller RN, Shuman JB. Phenylketonuria and intelligence: trimodal response to dietary treatment. Nature. 1969. X-4, X-5.
443 Gabrovska D, et al. The nutritional evaluation of underutilized cereals and buckwheat. Food Nutr Bull. 2002. X-1, X-2, X-3, X-4.
444 Galli C, et al. Reduced plasma C-20 and C-22 polyunsaturated fatty acids in children with phenylketonuria during dietary intervention. J Pediatr. 1991. X-4, X-5.
445 Galloway A, Stevenson J. An audit of the organisation of neonatal screening for phenylketonuria and congenital hypothyroidism in the Northern Region. Public Health. 1996. X-4.
446 Gassio R, et al. Cognitive functions in patients with phenylketonuria in long-term treatment with tetrahydrobiopterin. Mol Genet Metab. 2010. X-3.
447 Gassio R, et al. School performance in early and continuously treated phenylketonuria. Pediatr Neurol. 2005. X-4, X-5.
449 Gassio R, et al. Do adult patients with phenylketonuria improve their quality of life after introduction/resumption of a phenylalanine-restricted diet?. Acta Paediatr. 2003. X-4, X-5.
450 Gaull GE. Inborn errors of amino acid metabolism and hereditary ataxia. Adv Neurol. 1978. X-2, X-3, X-4.
451 Gazmararian JA, Solomon FM. Receipt of home health care after early discharge: results from a national managed care organization. Matern Child Health J. 1997. X-2, X-3, X-4.
452 Geison RL, Waisman HA. Effects of excess dietary phenylalanine on composition of cerebral lipids. J Neurochem. 1970. X-2, X-3, X-4, X-5.
453 Gelmann GR. PKU alert. MCN Am J Matern Child Nurs. 1984. X-1, X-2, X-3, X-4.
454 Gerald PS. The dangers of a successful PKU program. Pediatrics. 1967. X-1, X-2, X-3, X-4, X-5.
455 Gerasimova NS, Steklova IV, Tuuminen T. Fluorometric method for phenylalanine microplate assay adapted for phenylketonuria screening. Clin Chem. 1989. X-4, X-5.
456 Gerdes AM, et al. Plasma amino acids in phenylketonuric children treated either with phenylalanine-free amino acids or a protein hydrolysate. Acta Paediatr Scand. 1990. X-4.
458 Gershon ES, Shader RI. Screening for aminoacidurias in psychiatric inpatients. Arch Gen Psychiatry. 1969. X-2, X-3, X-4, X-5.
459 Gersting SW, et al. Pahenu1 is a mouse model for tetrahydrobiopterin-responsive phenylalanine hydroxylase deficiency and promotes analysis of the pharmacological chaperone mechanism in vivo. Hum Mol Genet. 2010. X-2, X-3, X-4, X-5.
460 Gersting SW, et al. Loss of function in phenylketonuria is caused by impaired molecular motions and conformational instability. Am J Hum Genet. 2008. X-2, X-3, X-4.
461 Geyer B. PKU. Can Nurse. 1985. X-1.
462 Ghavami M, Levy HL, Erbe RW. Prevention of fetal damage through dietary control of maternal hyperphenylalaninemia. Clin Obstet Gynecol. 1986. X-1, X-3, X-4, X-5.
463 Gibbings B. Phenylketonuria--a personal view. Mod Midwife. 1994. X-1.
464 Gibbings B. Keeping phenylketonuria under control. Mod Midwife. 1994. X-1.
465 Gibson JB, et al. Sugar nucleotide concentrations in red blood cells of patients on protein- and lactose-limited diets: effect of galactose supplementation. Am J Clin Nutr. 1996. X-2, X-3, X-4.
466 Giovannini M, et al. Treating phenylketonuria: a single centre experience. J Int Med Res. 2007. X-4, X-5.
467 Giovannini M, et al. Fatty acid metabolism in phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
468 Giovannini M, et al. Pattern reversal visual evoked potentials in phenylketonuria. J Inherit Metab Dis. 1988. X-4, X-5.
469 Giovannini M, et al. Serotonin and noradrenaline concentrations and serotonin uptake in platelets from hyperphenylalaninaemic patients. J Inherit Metab Dis. 1988. X-4, X-5.
470 Gjetting T, et al. In vitro expression of 34 naturally occurring mutant variants of phenylalanine hydroxylase: correlation with metabolic phenotypes and susceptibility toward protein aggregation. Mol Genet Metab. 2001. X-1, X-2, X-3, X-4.
471 Glass B. Human heredity and ethical problems. Perspect Biol Med. 1972. X-1.
472 Gleason LA, et al. A treatment program for adolescents with phenylketonuria. Clin Pediatr (Phila). 1992. X-4.
473 Godin C, Dolan G. Tryptophan metabolism in normal and phenylketonuric rats. Biochim Biophys Acta. 1966. X-2, X-3, X-4.
474 Godin C, Dolan G. Metabolism of radioactive phenylalanine in rats with different dietary intakes of phenylalanine. J Nutr. 1966. X-2, X-3, X-4.
475 Gokmen-Ozel H, et al. Long-term efficacy of ‘ready-to-drink’ protein substitute in phenylketonuria. J Hum Nutr Diet. 2009. X-4, X-5.
476 Goldenberg RL. Maternal and child health in Alabama. J Med Assoc State Ala. 1979. X-1.
477 Goldstein DS. On the dialectic between molecular biology and integrative physiology: toward a new medical science. Perspect Biol Med. 1997. X-1.
478 Goltsov AA, et al. A single polymorphic STR system in the human phenylalanine hydroxylase gene permits rapid prenatal diagnosis and carrier screening for phenylketonuria. Hum Mol Genet. 1993. X-3, X-4, X-5.
479 Gourovitch ML, et al. Interhemispheric transfer in children with early-treated phenylketonuria. J Clin Exp Neuropsychol. 1994. X-4.
480 Gramer G, et al. Pharmacokinetics of tetrahydrobiopterin following oral loadings with three single dosages in patients with phenylketonuria. J Inherit Metab Dis. 2009. X-4, X-5.
481 Gramer G, et al. Effects and clinical significance of tetrahydrobiopterin supplementation in phenylalanine hydroxylase-deficient hyperphenylalaninaemia. J Inherit Metab Dis. 2007. X-1, X-2, X-3, X-4, X-5.
482 Grant DB, Smith I. Survey of neonatal screening for primary hypothyroidism in England, Wales, and Northern Ireland 1982-4. Br Med J (Clin Res Ed). 1988. X-2, X-3, X-4.
483 Greengard O, Brass CA. Developmental changes of cerebral phenylalanine uptake from severely elevated blood levels. Neurochem Res. 1984. X-2, X-3, X-4.
484 Greeves LG, et al. Effect of genotype on changes in intelligence quotient after dietary relaxation in phenylketonuria and hyperphenylalaninaemia. Arch Dis Child. 2000. X-4, X-5.
485 Greeves LG, et al. Fractures and phenylketonuria. Acta Paediatr. 1997. X-1, X-4.
486 Greeves LG, Thomas PS, Carson DJ. Radiological assessment of the hand and wrist in phenylketonuria and hyperphenylalaninaemia. Pediatr Radiol. 1995. X-4, X-5.
487 Gregory CO, Yu C, Singh RH. Blood phenylalanine monitoring for dietary compliance among patients with phenylketonuria: comparison of methods. Genet Med. 2007. X-4, X-5.
488 Greve LC, et al. Breast-feeding in the management of the newborn with phenylketonuria: a practical approach to dietary therapy. J Am Diet Assoc. 1994. X-4.
490 Griffiths P, et al. Neuropsychological outcome of experimental manipulation of phenylalanine intake in treated phenylketonuria. J Inherit Metab Dis. 1998. X-4, X-5.
491 Griffiths P, Tarrini M, Robinson P. Executive function and psychosocial adjustment in children with early treated phenylketonuria: correlation with historical and concurrent phenylalanine levels. J Intellect Disabil Res. 1997. X-4, X-5.
492 Griffiths P, Smith C, Harvie A. Transitory hyperphenylalaninaemia in children with continuously treated phenylketonuria. Am J Ment Retard. 1997. X-4, X-5.
493 Griffiths P, Paterson L, Harvie A. Neuropsychological effects of subsequent exposure to phenylalanine in adolescents and young adults with early-treated phenylketonuria. J Intellect Disabil Res. 1995. X-4, X-5.
495 Gropper SS, et al. Immune status of children with phenylketonuria. J Am Coll Nutr. 1995. X-4.
496 Gropper SS, Yannicelli S. Plasma molybdenum concentrations in children with and without phenylketonuria. Biol Trace Elem Res. 1993. X-4.
497 Gropper SS, et al. Nutrient intakes of adolescents with phenylketonuria and infants and children with maple syrup urine disease on semisynthetic diets. J Am Coll Nutr. 1993. X-4.
498 Gropper SS, et al. Trace element status of children with PKU and normal children. J Am Diet Assoc. 1988. X-4.
499 Gross PT, et al. EEG in phenylketonuria. Attempt to establish clinical importance of EEG changes. Arch Neurol. 1981. X-4, X-5.
500 Grosse SD. Late-treated phenylketonuria and partial reversibility of intellectual impairment. Child Dev. 2010. X-1, X-2, X-3, X-4, X-5.
501 Grossi-Bianchi ML, et al. Phenylketonuria: treatment and neuropsychiatric longitudinal study of 31 cases. Panminerva Med. 1968. X-4, X-5.
502 Grotz RT, Henderson ND, Katz S. A comparison of the functional and intellectual performance of phenylketonuric, anoxic, and Down's syndrome individuals. Am J Ment Defic. 1972. X-4.
503 Grover R, et al. Evaluation of the expanded newborn screening program in New York City. Pediatrics. 1978. X-1, X-2, X-3, X-4.
504 Grubbs S, Brundage SC. Preconception management of chronic diseases. J S C Med Assoc. 2002. X-1, X-2, X-3, X-4.
505 Gudat JC, Maclaren NK. Neonatal screening for congenital disorders. J Fla Med Assoc. 1980. X-1.
506 Gugerty LB, Ryan S. Smothered with good intentions. Am J Nurs. 1970. X-4, X-5.
507 Guldberg P, et al. In vivo assessment of mutations in the phenylalanine hydroxylase gene by phenylalanine loading: characterization of seven common mutations. Eur J Pediatr. 1995. X-2, X-3, X-4.
508 Guldberg P, et al. Molecular heterogeneity of nonphenylketonuria hyperphenylalaninemia in 25 Danish patients. Genomics. 1994. X-4, X-5.
509 Gunter R, Wright ET, Brown WJ. Protein activators, learning and neural changes in phenylketonuric rats. J Ment Defic Res. 1968. X-2.
510 Guth HJ, et al. Which organic acids does hemofiltrate contain in the presence of acute renal failure?. Int J Artif Organs. 1999. X-2, X-3, X-4.
511 Guthrie R, Susi A. Laboratory confirmation of phenylketonuria. Combined paper chromatography and “inhibition assay”. Padiatr Padol. 1982. X-1, X-2, X-3, X-4.
512 Gamez A, et al. Structure-based epitope and PEGylation sites mapping of phenylalanine ammonia-lyase for enzyme substitution treatment of phenylketonuria. Mol Genet Metab. 2007. X-2, X-3, X-4.
513 Gamez A, et al. Development of pegylated forms of recombinant Rhodosporidium toruloides phenylalanine ammonia-lyase for the treatment of classical phenylketonuria. Mol Ther. 2005. X-2, X-3, X-4.
514 Gamez A, et al. Toward PKU enzyme replacement therapy: PEGylation with activity retention for three forms of recombinant phenylalanine hydroxylase. Mol Ther. 2004. X-2, X-3, X-4.
516 Guttler F, et al. Cognitive development in offspring of untreated and preconceptionally treated maternal phenylketonuria. J Inherit Metab Dis. 1990. X-1, X-3, X-5.
517 Guttler F. Impact of medical genetics concerning phenylketonuria: accomplishments, status and practical future possibilities. Clin Genet. 1989. X-1, X-2, X-3, X-4.
518 Guttler F, Lou H. Dietary problems of phenylketonuria: effect on CNS transmitters and their possible role in behaviour and neuropsychological function. J Inherit Metab Dis. 1986. X-1, X-2, X-3, X-4.
519 Guttler F, et al. Effects of oral phenylalanine load on plasma glucagon, insulin, amino acid and glucose concentrations in man. Scand J Clin Lab Invest. 1978. X-2, X-4, X-5.
520 Guttler F, Hansen G. Different phenotypes for phenylalanine hydroxylase deficiency. Ann Clin Biochem. 1977. X-2, X-3, X-4.
521 Guttler F, Wamberg E. On indications for treatment of the hyperphenylalaninemic neonate. Acta Paediatr Scand. 1977. X-1.
522 Guttler F, Wamberg E. Fasting serum phenylalanine in untreated institutionalised patients with phenylketonuria. J Ment Defic Res. 1977. X-4.
523 Guttler F, Olesen ES, Wamberg E. Diurnal variations of serum phenylalanine in phenylketonuric children on low phenylalanine diet. Am J Clin Nutr. 1969. X-3, X-4, X-5.
524 Haar DJ. Improved phenylketonuric diet control through group education of mothers. Nurs Clin North Am. 1966. X-4.
525 Hackney IM, et al. Phenylketonuria: mental development, behavior, and termination of low phenylalanine diet. J Pediatr. 1968. X-4, X-5.
526 Hadasova E, Brysova V, Kadlcakova E. N-acetylation in healthy and diseased children. Eur J Clin Pharmacol. 1990. X-4, X-5.
527 Hall SK, Robinson P, Green A. Could salivary phenylalanine concentrations replace blood concentrations?. Ann Clin Biochem. 2000. X-4, X-5.
528 Hambraeus L, Holmgren G, Samuelson G. Dietary treatment of adult patients with phenylketonuria. Nutr Metab. 1971. X-4.
529 Hambraeus L, Wranne L, Lorentsson R. Whey protein formulas in the treatment of phenylketonuria in infants. Nutr Metab. 1970. X-4.
530 Hambroeus L, et al. Use of a formula based on whey protein concentrate in the feeding of an infant with hyperphenylalaninemia. Nutr Metab. 1974. X-4.
531 Hanley WB, et al. Newborn phenylketonuria (PKU) Guthrie (BIA) screening and early hospital discharge. Early Hum Dev. 1997. X-1, X-4.
533 Hanley WB, Bell L. Maternal phenylketonuria: finding and treating women before conception. Can Med Assoc J. 1982. X-1, X-2, X-3, X-4, X-5.
534 Hanley WB, Linsao LS, Netley C. The efficacy of dietary therapy for phenylketonuria. Can Med Assoc J. 1971. X-4, X-5.
535 Hanley WB, et al. Malnutrition with early treatment of phenylketonuria. Pediatr Res. 1970. X-4, X-5.
536 Hansen H, Shahidi A, Stein ZA. Screening for phenylketonuria in New York City. Threshold values reconsidered. Public Health Rep. 1978. X-4.
537 Hansen H. Variability of reproductive casualty in maternal phenylalaninemia. Early Hum Dev. 1978. X-2, X-4, X-5.
538 Hansen H. Prevention of mental retardation due to PKU: selected aspects of program validity. Prev Med. 1975. X-4.
539 Hansen H. Risk of fetal damage in maternal phenylketonuria. J Pediatr. 1973. X-1, X-3, X-4, X-5.
540 Hansen H. Phenylketonuria. Br Med J. 1968. X-1, X-3, X-4, X-5.
541 Harada T, Kagamiyama H, Hatakeyama K. Feedback regulation mechanisms for the control of GTP cyclohydrolase I activity. Science. 1993. X-2, X-4.
542 Hardelid P, et al. The birth prevalence of PKU in populations of European, South Asian and sub-Saharan African ancestry living in South East England. Ann Hum Genet. 2008. X-1, X-2, X-3, X-4.
543 Harding CO, et al. Expression of phenylalanine hydroxylase (PAH) in erythrogenic bone marrow does not correct hyperphenylalaninemia in Pah(enu2) mice. J Gene Med. 2003. X-2, X-3, X-4.
544 Hargreaves IP, et al. Blood mononuclear cell coenzyme Q10 concentration and mitochondrial respiratory chain succinate cytochrome-c reductase activity in phenylketonuric patients. J Inherit Metab Dis. 2002. X-4, X-5.
545 Hargreaves KM, Pardridge WM. Neutral amino acid transport at the human blood-brain barrier. J Biol Chem. 1988. X-2, X-3, X-4.
546 Harper PS. Genetic registers and the prevention of inherited disorders. Proc Annu Symp Eugen Soc. 1983. X-4.
547 Harper PS. Inborn errors of metabolism-the relationship of clinical and biochemical abnormalities. Acta Univ Carol Med Monogr. 1973. X-4.
548 Hashem N, et al. Preliminary studies on the molecular basis of hyperphenylalaninemia in Egypt. Hum Genet. 1996. X-4.
549 Hashishe MM. Genetic study of phenylketonuria. J Egypt Public Health Assoc. 1992. X-4.
550 Hassemer DJ, et al. Laboratory quality control issues related to screening newborns for cystic fibrosis using immunoreactive trypsin. Pediatr Pulmonol Suppl. 1991. X-2, X-3, X-4.
551 Haworth C, Walmsley TA. A study of the chromatographic behaviour of tryptophan metabolites and related compounds by chromatography on thin layers of silica gel. I. Qualitative separation. J Chromatogr. 1972. X-2, X-3, X-4.
552 Hayes JS, et al. Managing PKU: an update. MCN Am J Matern Child Nurs. 1987. X-1, X-3, X-4, X-5.
553 Heeley AF. The effect of pyridoxine on tryptophan metabolism in phenylketonuria. Clin Sci. 1965. X-4.
554 Heffernan JF, Trahms CM. A model preschool for patients with phenylketonuria. J Am Diet Assoc. 1981. X-1.
555 Held KR, et al. Plasma amino acid pattern at noon in early treated hyperphenylalaninemic, phenylketonuric, and normal children. Ann Nutr Metab. 1983. X-4.
556 Hendrikx MM, et al. Phenylketonuria and some aspects of emotional development. Eur J Pediatr. 1994. X-4, X-5.
557 Hennermann JB, et al. Long-term treatment with tetrahydrobiopterin increases phenylalanine tolerance in children with severe phenotype of phenylketonuria. Mol Genet Metab. 2005. X-3, X-4.
558 Heredero-Baute L. Community-based program for the diagnosis and prevention of genetic disorders in Cuba. Twenty years of experience. Community Genet. 2004. X-1, X-2, X-3, X-4.
559 Hevel JM, et al. Can the DCoHalpha isozyme compensate in patients with 4a-hydroxy-tetrahydrobiopterin dehydratase/DCoH deficiency?. Mol Genet Metab. 2006. X-1, X-2, X-3, X-4.
560 Hickey CA, Covington C. Maternal phenylketonuria: case management as a preventive approach to a chronic condition affecting pregnancy. NAACOGS Clin Issu Perinat Womens Health Nurs. 1990. X-1.
561 Hill A, Macaulay J, Zaleski WA. Plasma glutamine in phenylketonuria. Clin Biochem. 1972. X-4, X-5.
562 Hill A, Hoag GN, Zaleski WA. The investigation of aromatic acids in phenylketonuria, alkaptonuria and tyrosinosis using gas-liquid chromatography. Clin Chim Acta. 1972. X-3, X-4, X-5.
563 Hillman L, et al. Decreased bone mineralization in children with phenylketonuria under treatment. Eur J Pediatr. 1996. X-4, X-5.
564 Hirakawa H, et al. Expression analysis of the aldo-keto reductases involved in the novel biosynthetic pathway of tetrahydrobiopterin in human and mouse tissues. J Biochem. 2009. X-2, X-3, X-4.
565 Hjelm M, Seakins J, Antoshechkin A. Indications of changed amino acid homeostasis in untreated and treated PKU. Acta Paediatr Suppl. 1994. X-4, X-5.
566 Hjelm M, et al. Computer model of the metabolism of phenylalanine in normal subjects and in patients with phenylketonuria. Comput Programs Biomed. 1984. X-2, X-3, X-4.
567 Hoeksma M, et al. Phenylketonuria: High plasma phenylalanine decreases cerebral protein synthesis. Mol Genet Metab. 2009. X-4, X-5.
568 Hoeksma M, et al. The intake of total protein, natural protein and protein substitute and growth of height and head circumference in Dutch infants with phenylketonuria. J Inherit Metab Dis. 2005. X-4, X-5.
569 Hogan SE, et al. Experience with adolescents with phenylketonuria returned to phenylalanine-restricted diets. J Am Diet Assoc. 1986. X-3.
570 Holm VA, et al. Physical growth in phenylketonuria: II. Growth of treated children in the PKU collaborative study from birth to 4 years of age. Pediatrics. 1979. X-4, X-5.
571 Holm VA, Knox WE. Physical growth in phenylketonuria: I. A retrospective study. Pediatrics. 1979. X-4, X-5.
572 Holtzman NA, et al. Effect of age at loss of dietary control on intellectual performance and behavior of children with phenylketonuria. N Engl J Med. 1986. X-4, X-5.
573 Holtzman NA. Pitfalls of newborn screening (with special attention to hypothyroidism): when will we ever learn?. Birth Defects Orig Artic Ser. 1983. X-1.
574 Holtzman NA. Anatomy of a trial. Pediatrics. 1977. X-1, X-2, X-3, X-4, X-5, X-6.
575 Holtzman NA, Welcher DW, Mellits ED. Termination of restricted diet in children with phenylketonuria: a randomized controlled study. N Engl J Med. 1975. X-4, X-5.
576 Hommes FA, Lee JS. The control of 5-hydroxytryptamine and dopamine synthesis in the brain: a theoretical approach. J Inherit Metab Dis. 1990. X-1, X-2, X-3, X-4.
577 Hommes FA, Eller AG, Taylor EH. Turnover of the fast components of myelin and myelin proteins in experimental hyperphenylalaninaemia. Relevance to termination of dietary treatment in human phenylketonuria. J Inherit Metab Dis. 1982. X-2, X-3, X-4.
578 Horovitz DD, de Mattos RA, Llerena JC Jr. Medical genetic services in the state of Rio de Janeiro, Brazil. Community Genet. 2004. X-1, X-2, X-3, X-4.
579 Hoskins JA, et al. Enzymatic control of phenylalanine intake in phenylketonuria. Lancet. 1980. X-3, X-4.
580 Howell RR. Phenylketonuria in the general population. N Engl J Med. 1970. X-1, X-2, X-3, X-4, X-5, X-6.
581 Howells DW, et al. Insertion of an extra codon for threonine is a cause of dihydropteridine reductase deficiency. Am J Hum Genet. 1990. X-2, X-3, X-4.
582 Howells DW, Smith I, Hyland K. Estimation of tetrahydrobiopterin and other pterins in cerebrospinal fluid using reversed-phase high-performance liquid chromatography with electrochemical and fluorescence detection. J Chromatogr. 1986. X-4.
583 Howse JL, Weiss M, Green NS. Critical role of the March of Dimes in the expansion of newborn screening. Ment Retard Dev Disabil Res Rev. 2006. X-1, X-2, X-3, X-4.
584 Hrutkay V. Workshop for parents of children with PKU. J Am Diet Assoc. 1971. X-4.
585 Hsia DY. Phenylketonuria: a study of human bichemical genetics. Pediatrics. 1966. X-1, X-2, X-3, X-4, X-5.
586 Hsieh MC, et al. Comparative diagnostic value of phenylalanine challenge and phenylalanine hydroxylase activity in phenylketonuria. Clin Genet. 1983. X-4.
587 Hudson FP, Clothier C. Letter: Phenylalaninaemia. Arch Dis Child. 1975. X-1, X-2, X-3.
588 Hudson FP. Phenylketonuria. Nurs Mirror Midwives J. 1973. X-1.
589 Hudson FP, Mordaunt VL, Leahy I. Evaluation of treatment begun in first three mohs oflife in 184 cases of phenylketonuria. Arch Dis Child. 1970. X-4, X-5.
590 Hudson FP. Phenylketonuria. Proc R Soc Med. 1967. X-1, X-2, X-3, X-4, X-5, X-6.
591 Hudson FP. Hyperphenylalaninemia without phenylketonuria. Dev Med Child Neurol. 1967. X-1.
592 Hudson FP. Termination of dietary treatment of phenylketonuria. Arch Dis Child. 1967. X-3, X-4, X-5.
593 Huemer M, et al. Total homocysteine, B-vitamins and genetic polymorphisms in patients with classical phenylketonuria. Mol Genet Metab. 2008. X-4, X-5.
594 Hughes JV, Johnson TC. Abnormal amino acid metabolism and brain protein synthesis during neural development. Neurochem Res. 1978. X-1, X-2, X-3, X-4, X-5, X-6.
595 Huijbregts S, et al. Inhibition of prepotent responding and attentional flexibility in treated phenylketonuria. Dev Neuropsychol. 2002. X-4, X-5.
596 Huijbregts SC, et al. Motor function under lower and higher controlled processing demands in early and continuously treated phenylketonuria. Neuropsychology. 2003. X-4, X-5.
597 Huijbregts SC, et al. Short-term dietary interventions in children and adolescents with treated phenylketonuria: effects on neuropsychological outcome of a well-controlled population. J Inherit Metab Dis. 2002. X-4, X-5.
599 Huner G, et al. Breastfeeding experience in inborn errors of metabolism other than phenylketonuria. J Inherit Metab Dis. 2005. X-2, X-3, X-4.
600 Hunt MM, Berry HK, White PP. Phenylketonuria, adolescence, and diet. J Am Diet Assoc. 1985. X-1,.
601 Hunt MM, Sutherland BS, Berry HK. Nutritional management in phenylketonuria. Am J Dis Child. 1971. X-1.
602 Hurst JD, Stullenbarger B. Implementation of a self-care approach in a pediatric interdisciplinary phenylketonuria (PKU) clinic. J Pediatr Nurs. 1986. X-4.
603 Hussar DA. New drugs08, part 2. Nursing. 2008. X-1, X-2, X-3.
604 Hussar DA. New drugs: nebivolol hydrochloride, nilotinib, and sapropterin dihydrochloride. J Am Pharm Assoc (2003). 2008. X-1, X-2, X-3, X-4, X-5.
605 Hvas AM, Nexo E, Nielsen JB. Vitamin B12 and vitamin B6 supplementation is needed among adults with phenylketonuria (PKU). J Inherit Metab Dis. 2006. X-4, X-5.
606 Hyanek J, et al. Maternal hyperphenylalaninemias in healthy Czech population of pregnant women: 30 years experience with screening, prevention and treatment. Bratisl Lek Listy. 2004. X-4, X-5.
607 Hyland K. Inherited disorders affecting dopamine and serotonin: critical neurotransmitters derived from aromatic amino acids. J Nutr. 2007. X-1, X-2, X-3, X-4.
608 Hyanek J, et al. Changes in phenylalanine tolerance while monitoring the dietetic treatment of pregnant women suffering from hyperphenylalaninaemia. J Inherit Metab Dis. 1988. X-3, X-4, X-5.
609 Ievers-Landis CE, et al. Situational analysis of dietary challenges of the treatment regimen for children and adolescents with phenylketonuria and their primary caregivers. J Dev Behav Pediatr. 2005. X-4, X-5.
610 Iijima S, et al. Studies on the experimental phenylketonuria in rats. Tohoku J Exp Med. 1975. X-2, X-3, X-4.
611 Iino T, et al. Tetrahydrobiopterin is synthesized from 6-pyruvoyl-tetrahydropterin by the human aldo-keto reductase AKR1 family members. Arch Biochem Biophys. 2003. X-2, X-3, X-4.
612 Illsinger S, et al. Branched chain amino acids as a parameter for catabolism in treated phenylketonuria. Amino Acids. 2005. X-4, X-5.
613 Ismail SR, et al. Newborn screening for certain treatable inborn errors of metabolism in Alexandria. J Egypt Public Health Assoc. 1996. X-2, X-3, X-4.
614 Jadhav M. Neglected mental defects. Indian Pediatr. 1968. X-4.
615 Jammes JL, Rosenberger PB. Rocking behavior and heart rate in the mentally retarded. J Nerv Ment Dis. 1971. X-4.
616 Jancar J. Increased life expectancy in people with untreated phenylketonuria. J Intellect Disabil Res. 1998. X-4.
617 Jardim LB, et al. Possible high frequency of tetrahydrobiopterin deficiency in south Brazil. J Inherit Metab Dis. 1994. X-2, X-4.
618 Jenkins T. The role of screening in the prevention of inherited disease in South Africa. S Afr Med J. 1977. X-4.
619 Jenkins T. Prevention of hereditary disease. S Afr Med J. 1974. X-1, X-2, X-3, X-4, X-5.
620 Jenner FA. Medical research council unit for metabolic studies in psychiatry, Sheffield. Psychol Med. 1973. X-1.
621 Jervis GA, Drejza EJ. Phenylketonuria: blood levels of phenylpyruvic and ortho-hydroxyphenylacetic acids. Clin Chim Acta. 1966. X-4, X-5.
622 Jiang J, et al. A survey for the incidence of phenylketonuria in Guangdong, China. Southeast Asian J Trop Med Public Health. 2003. X-3, X-4.
623 Jochum F, et al. Effects of a low selenium state in patients with phenylketonuria. Acta Paediatr. 1997. X-4.
624 Johannik K, et al. Localized brain proton NMR spectroscopy in young adult phenylketonuria patients. Magn Reson Med. 1994. X-4.
625 John SW, et al. In vitro and in vivo correlations for I65T and M1V mutations at the phenylalanine hydroxylase locus. Hum Mutat. 1992. X-2, X-4.
626 Johnson CF. Phenylketonuria: a diagnosis that affects the entire family. Med Times. 1979. X-1.
627 Johnson CF, et al. Congenital and neurological abnormalities in infants with phenylketonuria. Am J Ment Defic. 1978. X-4.
628 Johnson CF. Phenylketonuria and the obstetrician. Obstet Gynecol. 1972. X-1, X-2, X-3, X-4, X-5, X-6.
629 Johnson CF. What is the best age to discontinue the low phenylalanine diet in phenylketonuria? A presentation of some contributory data. Clin Pediatr (Phila). 1972. X-1.
630 Johnson CF. The phenylketonuria controversy 1968. J Iowa Med Soc. 1969. X-4.
631 Johnson WG. DNA polymorphism-diet-cofactor-development hypothesis and the gene-teratogen model for schizophrenia and other developmental disorders. Am J Med Genet. 1999. X-2, X-3, X-4.
632 Jolly H, Wolff OH. New frontiers in paediatrics. Looking at handicapped children today. Trans Med Soc Lond. 1971. X-4.
634 Jordan MK, et al. Preliminary support for the oral administration of valine, isoleucine and leucine for phenylketonuria. Dev Med Child Neurol. 1985. X-3.
635 Jounela AJ, Kivimaki T. Possible sensitivity to meperidine in phenylketonuria. N Engl J Med. 1973. X-4.
636 Juengst ET. “Prevention” and the goals of genetic medicine. Hum Gene Ther. 1995. X-1, X-2, X-3, X-4.
637 Jung SC, et al. Protective effect of recombinant adeno-associated virus 2/8-mediated gene therapy from the maternal hyperphenylalaninemia in offsprings of a mouse model of phenylketonuria. J Korean Med Sci. 2008. X-2, X-3, X-4.
638 Justice P, Smith GF. Phenylketonuria. Am J Nurs. 1975. X-1, X-2, X-3, X-4, X-5, X-6.
639 Kahn LI. From the Clinical Conference St. Louis Children's Hospital. Phenylketonuria. Diagnostic and therapeutic dilemma. Clin Pediatr (Phila). 1970. X-1.
640 Kaiser LL, Allen L. Position of the American Dietetic Association: nutrition and lifestyle for a healthy pregnancy outcome. J Am Diet Assoc. 2002. X-1, X-2, X-3, X-4.
641 Kalaydjieva L, Kremensky I. Screening for phenylketonuria in a totalitarian state. J Med Genet. 1992. X-4.
642 Kalkanoglu HS, et al. Behavioural effects of phenylalanine-free amino acid tablet supplementation in intellectually disabled adults with untreated phenylketonuria. Acta Paediatr. 2005. X-4, X-5.
643 Kalsner LR, et al. Tyrosine supplementation in phenylketonuria: diurnal blood tyrosine levels and presumptive brain influx of tyrosine and other large neutral amino acids. J Pediatr. 2001. X-4, X-5.
644 Kalverboer AF, et al. Social behaviour and task orientation in early-treated PKU. Acta Paediatr Suppl. 1994. X-2, X-3, X-4, X-5.
645 Kamerling JP, et al. Gas chromatography of urinary N-phenylacetylglutamine. J Chromatogr. 1979. X-2, X-3, X-4.
646 Kanabus P. Urinary excretion of 5-hydroxyindoleacetic acid and N1-methyl-2-pyridone-5-carboxamide by normal and phenylketonuric children. Acta Vitaminol Enzymol. 1975. X-3, X-4.
647 Kand'ar R, et al. Determination of branched chain amino acids, methionine, phenylalanine, tyrosine and alpha-keto acids in plasma and dried blood samples using HPLC with fluorescence detection. Clin Chem Lab Med. 2009. X-4.
648 Kang ES, Sollee ND, Gerald PS. Results of treatment and termination of the diet in phenylketonuria (PKU). Pediatrics. 1970. X-4, X-5.
649 Kang TS, et al. Converting an injectable protein therapeutic into an oral form: phenylalanine ammonia lyase for phenylketonuria. Mol Genet Metab. 2010. X-2, X-3, X-4, X-5.
650 Kanufre VC, et al. Breastfeeding in the treatment of children with phenylketonuria. J Pediatr (Rio J). 2007. X-4.
651 Karacic I, et al. Genotype-predicted tetrahydrobiopterin (BH4)-responsiveness and molecular genetics in Croatian patients with phenylalanine hydroxylase (PAH) deficiency. Mol Genet Metab. 2009. X-4, X-5.
652 Karagoz T, et al. Immune function in children with classical phenylketonuria and tetrahydrobiopterin deficiencies. Indian Pediatr. 2003. X-4.
653 Kasnauskiene J, et al. The molecular basis of phenylketonuria in Lithuania. Hum Mutat. 2003. X-2, X-4.
654 Katon W, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. 2001. X-2, X-4.
655 Kaufman S. A model of human phenylalanine metabolism in normal subjects and in phenylketonuric patients. Proc Natl Acad Sci U S A. 1999. X-2, X-3, X-4, X-5.
656 Kaufman S. Genetic disorders involving recycling and formation of tetrahydrobiopterin. Adv Pharmacol. 1998. X-1.
657 Kaufman S. Unsolved problems in diagnosis and therapy of hyperphenylalaninemia caused by defects in tetrahydrobiopterin metabolism. J Pediatr. 1986. X-1.
658 Kaufman S. Hyperphenylalaninaemia caused by defects in biopterin metabolism. J Inherit Metab Dis. 1985. X-1.
659 Kaufman S, et al. Use of tetrahydropterins in the treatment of hyperphenylalaninemia due to defective synthesis of tetrahydrobiopterin: evidence that peripherally administered tetrahydropterins enter the brain. Pediatrics. 1982. X-2, X-3, X-4, X-5.
660 Kaufman S. Establishment of tetrahydrobiopterin as the hydroxylase cofactor and a review of some recent studies in man. Psychopharmacol Bull. 1978. X-1, X-2, X-3, X-4.
661 Kaufman S, Milstien S. Phenylketonuria and its variants. Ann Clin Lab Sci. 1977. X-4.
662 Kaufman S. Letter: Pterin administration as a therapy for P.K.U. due to dihydropteridine-reductase deficiency?. Lancet. 1975. X-1, X-2, X-3, X-4.
664 Keleske L, Solomons G, Opitz E. Parental reactions to phenylketonuria in the family. J Pediatr. 1967. X-4, X-5.
665 Kemper AR, Brewer CA, Singh RH. Perspectives on dietary adherence among women with inborn errors of metabolism. J Am Diet Assoc. 2010. X-4.
666 Kennedy B, Anderson K, Acosta PB. Nutrition support of inborn errors of amino acid metabolism. Int J Biomed Comput. 1985. X-1, X-4.
667 Kennedy JL Jr., et al. The early treatment of phenylketonuria. Am J Dis Child. 1967. X-1.
668 Kerr GR, et al. The development of infant monkeys fed low phenylalanine diets. Pediatr Res. 1969. X-2, X-3, X-4.
669 Kerr GR, et al. “Fetal PKU:” the effect of maternal hyperphenylalaninemia during pregnancy in the rhesus monkey (Macaca mulatta). Pediatrics. 1968. X-2, X-3, X-4.
670 Kerr GR, Waisman HA. Dietary induction of hyperphenylalaninemia in the rat. J Nutr. 1967. X-2, X-3, X-4.
671 Kibayashi M, Nagao M, Chiba S. Mutation analysis of the phenylalanine hydroxylase gene and its clinical implications in two Japanese patients with non-phenylketonuria hyperphenylalaninemia. J Hum Genet. 1998. X-2, X-3, X-4.
672 Kieckhefer GM, Trahms CM. Supporting development of children with chronic conditions: from compliance toward shared management. Pediatr Nurs. 2000. X-4.
673 Kietduriyakul V, et al. The incidence of phenylketonuria in Thailand. J Med Assoc Thai. 1989. X-3, X-4.
674 Kilpatrick NM, et al. The implication of phenylketonuria on oral health. Pediatr Dent. 1999. X-4.
675 Kim SW, et al. Structural and functional analyses of mutations of the human phenylalanine hydroxylase gene. Clin Chim Acta. 2006. X-2, X-4.
676 Kindt E, et al. Fasting plasma amino acid concentrations in PKU children on two different levels of protein intake. Acta Paediatr Scand. 1988. X-4.
677 Kindt E, Halvorsen S, Lie SO. Does a marginal protein intake result in osteoporosis?. J Inherit Metab Dis. 1987. X-3, X-4, X-5.
678 Kindt E, et al. Net protein utilization determined by rat bioassay of a protein hydrolysate and a diet for children with phenylketonuria. Br J Nutr. 1985. X-2, X-3, X-4.
679 Kindt E, et al. Is phenylalanine requirement in infants and children related to protein intake?. Br J Nutr. 1984. X-4, X-5.
680 Kindt E, et al. Protein requirements in infants and children: a longitudinal study of children treated for phenylketonuria. Am J Clin Nutr. 1983. X-4, X-5.
681 Kindt E, Halvorsen S. The need of essential amino acids in children. An evaluation based on the intake of phenylalanine, tyrosine, leucine, isoleucine, and valine in children with phenylketonuria, tyrosine amino transferase defect, and maple syrup urine disease. Am J Clin Nutr. 1980. X-3, X-4.
682 King WC. Oral characteristics of phenylketonuric children. ASDC J Dent Child. 1969. X-4.
683 Kirkman HN, et al. Fifteen-year experience with screening for phenylketonuria with an automated fluorometric method. Am J Hum Genet. 1982. X-4.
684 Kirkman HN. Projections of a rebound in frequency of mental retardation from phenylketonuria. Appl Res Ment Retard. 1982. X-1.
685 Kitagawa T, et al. Treatment of phenylketonuria with a formula consisting of low-phenylalanine peptide. A collaborative study. Enzyme. 1987. X-4.
686 Kitagawa T, Smith BA, Brown ES. Gas-liquid chromatography of phenylalanine and its metabolites in serum and urine of various hyperphenylalaninemic subjects, their relatives, and controls. Clin Chem. 1975. X-4, X-5.
687 Kleiman S, et al. Phenylketonuria: variable phenotypic outcomes of the R261Q mutation and maternal PKU in the offspring of a healthy homozygote. J Med Genet. 1993. X-3, X-4.
688 Kluge C, et al. Chromosomal localization, genomic structure and characterization of the human gene and a retropseudogene for 6-pyruvoyltetrahydropterin synthase. Eur J Biochem. 1996. X-4.
689 Knox WE. What's new in pku. N Engl J Med. 1970. X-1, X-2, X-3, X-4, X-5, X-6.
690 Knudsen GM, et al. Blood-brain barrier transport of amino acids in healthy controls and in patients with phenylketonuria. J Inherit Metab Dis. 1995. X-3, X-4.
691 Kobe B, et al. Structural basis of autoregulation of phenylalanine hydroxylase. Nat Struct Biol. 1999. X-2, X-4.
692 Koch R, Trefz F, Waisbren S. Psychosocial issues and outcomes in maternal PKU. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4, X-5.
693 Koch R. Maternal phenylketonuria and tetrahydrobiopterin. Pediatrics. 2008. X-1, X-2, X-3, X-4, X-5.
695 Koch R, et al. Large neutral amino acid therapy and phenylketonuria: a promising approach to treatment. Mol Genet Metab. 2003. X-3.
696 Koch R, et al. Phenylketonuria in adulthood: a collaborative study. J Inherit Metab Dis. 2002. X-4, X-5.
697 Koch R, Guttler F. Benefits of mutation analysis and examination of brain phenylalanine levels in the management of phenylketonuria. Pediatrics. 2000. X-1, X-2, X-3, X-4, X-5.
699 Koch R, et al. Long-term beneficial effects of the phenylalanine-restricted diet in late-diagnosed individuals with phenylketonuria. Mol Genet Metab. 1999. X-4, X-5.
700 Koch R, et al. The relationship of genotype to phenotype in phenylalanine hydroxylase deficiency. Biochem Mol Med. 1997. X-4, X-5.
701 Koch R, et al. Outcome implications of the International Maternal Phenylketonuria Collaborative Study (MPKUCS): 1994. Eur J Pediatr. 1996. X-1, X-2, X-3, X-4, X-5.
702 Koch R, et al. Care of the adult with phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
705 Koch R, et al. A preliminary report of the collaborative study of maternal phenylketonuria in the United States and Canada. J Inherit Metab Dis. 1990. X-4, X-5, X-6.
706 Koch R, et al. Treatment outcome of maternal phenylketonuria. Acta Paediatr Jpn. 1988. X-4, X-5.
707 Koch R, et al. The effects of diet discontinuation in children with phenylketonuria. Eur J Pediatr. 1987. X-4, X-5.
708 Koch R, et al. Paired comparisons between early treated PKU children and their matched sibling controls on intelligence and school achievement test results at eight years of age. J Inherit Metab Dis. 1984. X-4, X-5.
709 Koch R, et al. Preliminary report on the effects of diet discontinuation in PKU. J Pediatr. 1982. X-4, X-5.
710 Koch R, Schaeffler G, Shaw NF. Results of loading doses of aspartame by two phenylketonuric (PKU) children compared with two normal children. J Toxicol Environ Health. 1976. X-3, X-4.
711 Koch R, et al. Use of aspartame in phenylketonuric heteroxygous adults. J Toxicol Environ Health. 1976. X-4.
712 Koch R, et al. An approach to management of phenylketonuria. J Pediatr. 1970. X-4, X-5.
713 Koch R, et al. Clinical observations on phenylketonuria. Am J Dis Child. 1967. X-4.
714 Koch RK. Issues in newborn screening for phenylketonuria. Am Fam Physician. 1999. X-1, X-4.
715 Koepp P, Hoffmann B. Aromatic acid excretion in classical phenylketonuria and hyperphenylalaninemic variants. Helv Paediatr Acta. 1974. X-4.
716 Koff E, et al. Intelligence and phenylketonuria: effects of diet termination. J Pediatr. 1979. X-4, X-5.
717 Koff E, Boyle P, Pueschel SM. Perceptual-motor functioning in children with phenylketonuria. Am J Dis Child. 1977. X-4, X-5.
718 Kohner EM, Porta M. Protocols for screening and treatment of diabetic retinopathy in Europe. Eur J Ophthalmol. 1991. X-1, X-2, X-3, X-4.
719 Kohsaka M, Okita M, Shohmori T. The effect of insulin on elder phenylketonuric patients. Folia Psychiatr Neurol Jpn. 1979. X-3, X-4.
720 Kolb SE, Aguilar MC, Kaye C. A conference for the education of families who have a member with phenylketonuria. J Pediatr Nurs. 1999. X-1, X-4, X-5.
721 Koletzko B, et al. Does dietary DHA improve neural function in children? Observations in phenylketonuria. Prostaglandins Leukot Essent Fatty Acids. 2009. X-4, X-5.
722 Koletzko B, et al. Dietary long-chain polyunsaturated fatty acid supplementation in infants with phenylketonuria: a randomized controlled trial. J Inherit Metab Dis. 2007. X-4, X-5.
723 Koletzko B, Decsi T, Demmelmair H. Arachidonic acid supply and metabolism in human infants born at full term. Lipids. 1996. X-3.
724 Kolodny EH, Yatziv S. Laboratory approaches for inherited neurometabolic diseases. Dev Med Child Neurol. 1985. X-4.
725 Komrower GM, et al. The Manchester regional screening programme: a 10-year exercise in patient and family care. Br Med J. 1979. X-1, X-4, X-5.
726 Komrower GM. Phenylketonuria. Some current problems. Arch Dis Child. 1970. X-4, X-5.
727 Korinthenberg R, Ullrich K, Fullenkemper F. Evoked potentials and electroencephalography in adolescents with phenylketonuria. Neuropediatrics. 1988. X-4, X-5.
728 Kornreich HK, et al. Phenylketonuria and scleroderma. J Pediatr. 1968. X-1, X-3, X-4, X-5.
729 Koslow SH, Butler IJ. Biogenic amine synthesis defect in dihydropteridine reductase deficiency. Science. 1977. X-3, X-4.
730 Kosower EM. The therapeutic possibilities arising from the chemical modification of proteins. Proc Natl Acad Sci U S A. 1965. X-2, X-3, X-4, X-5.
731 Krauch G, et al. Comparison of the protein quality of dietetically treated phenylketonuria patients with the recommendations of the WHO Expert Consultation. Eur J Pediatr. 1996. X-2, X-3, X-4, X-5.
732 Krause W, et al. Phenylalanine alters the mean power frequency of electroencephalograms and plasma L-dopa in treated patients with phenylketonuria. Pediatr Res. 1986. X-3, X-4, X-5, X-6, X-5.
733 Krause W, et al. Biochemical and neuropsychological effects of elevated plasma phenylalanine in patients with treated phenylketonuria. A model for the study of phenylalanine and brain function in man. J Clin Invest. 1985. X-4, X-5.
734 Krips C, Lines DR. Phenylketonuria: reduction of serum levels of phenylalanine following oral administration of B-2 thienylalanine. Aust Paediatr J. 1972. X-4.
735 Kugel RB. Mental retardation, 1990: an overview. J Okla State Med Assoc. 1990. X-1, X-2, X-3, X-4.
736 Kuhara T, et al. Urinary metabolic profile of phenylketonuria in patients receiving total parenteral nutrition and medication. Rapid Commun Mass Spectrom. 2009. X-2, X-3, X-4.
737 Kure S, et al. Tetrahydrobiopterin-responsive phenylalanine hydroxylase deficiency. J Pediatr. 1999. X-3.
738 Laakso J, et al. Inborn errors in metabolism and 4-boronophenylalanine-fructose-based boron neutron capture therapy. Radiat Res. 2003. X-2, X-3, X-4.
739 Laclair CE, et al. Purification and use of glycomacropeptide for nutritional management of phenylketonuria. J Food Sci. 2009. X-2, X-3, X-4, X-5.
740 Ladodo KS. Peculiarities of dietetic therapy in infants' hereditary diseases. Nutr Metab. 1977. X-4.
741 Lake DM. Nursing implications from an investigation of mothering, diet, and development in two groups of children with phenylketonuria. ANA Clin Sess. 1968. X-4.
742 Lam M, et al. Retention of phenylalanine ammonia-lyase activity in wheat seedlings during storage and in vitro digestion. J Agric Food Chem. 2008. X-2, X-3, X-4.
743 Lam WK, et al. Histidinaemia: a benign metabolic disorder. Arch Dis Child. 1996. X-2, X-3, X-4.
745 Landi A, et al. Pattern-reversal visual evoked potentials in phenylketonuric children. Childs Nerv Syst. 1987. X-4, X-5.
746 Landolt MA, et al. Quality of life and psychologic adjustment in children and adolescents with early treated phenylketonuria can be normal. J Pediatr. 2002. X-4.
747 Landvogt C, et al. Reduced cerebral fluoro-L-dopamine uptake in adult patients suffering from phenylketonuria. J Cereb Blood Flow Metab. 2008. X-3, X-4.
748 Lane JD, Neuhoff V. Phenylketonuria: clinical and experimental considerations revealed by the use of animal models. Naturwissenschaften. 1980. X-2, X-3, X-4.
749 Lang MJ, et al. Nonphenylketonuric hyperphenylalaninemia. Am J Dis Child. 1989. X-2, X-4, X-5.
750 Langdell JI. Phenylketonuria: some effects of body chemistry on learning. J Am Acad Child Psychiatry. 1967. X-4.
751 Langenbeck U, et al. Metabolic phenotypes of phenylketonuria. Kinetic and molecular evaluation of the Blaskovics protein loading test. J Inherit Metab Dis. 2009. X-4.
752 Langenbeck U. Classifying tetrahydrobiopterin responsiveness in the hyperphenylalaninaemias. J Inherit Metab Dis. 2008. X-2, X-3, X-4.
753 Langenbeck U, Behbehani A, Mench-Hoinowski A. A synopsis of the unconjugated acidic transamination metabolites of phenylalanine in phenylketonuria. J Inherit Metab Dis. 1992. X-4, X-5.
754 Langenbeck U, et al. Absence of a significant renal threshold for two aromatic acids in phenylketonuric children over two years of age. Eur J Pediatr. 1980. X-4, X-5.
755 Larsson A. Neonatal screening for metabolic and endocrine disorders. Ups J Med Sci Suppl. 1987. X-4.
756 Larsson A, et al. Screening for congenital hypothyroidism. I. Laboratory results of a pilot study based on dried blood samples collected for PKU screening. Acta Paediatr Scand. 1981. X-2, X-4.
757 Larsson BA, et al. Alleviation of the pain of venepuncture in neonates. Acta Paediatr. 1998. X-4.
758 Larsson BA, et al. Venipuncture is more effective and less painful than heel lancing for blood tests in neonates. Pediatrics. 1998. X-4.
759 Larsson BA, et al. Does a local anaesthetic cream (EMLA) alleviate pain from heel-lancing in neonates?. Acta Anaesthesiol Scand. 1995. X-4.
760 Larue C, et al. An extracorporeal hollow-fiber reactor for phenylketonuria using immobilized phenylalanine ammonia lyase. Dev Pharmacol Ther. 1986. X-2, X-3, X-4.
761 Laufs S, Blau N, Thony B. Retrovirus-mediated double transduction of the GTPCH and PTPS genes allows 6-pyruvoyltetrahydropterin synthase-deficient human fibroblasts to synthesize and release tetrahydrobiopterin. J Neurochem. 1998. X-2, X-3, X-4, X-5.
762 Lawson MS, et al. Evaluation of a new mineral and trace metal supplement for use with synthetic diets. Arch Dis Child. 1977. X-3, X-4, X-5.
763 Leandro P, et al. The V388M mutation results in a kinetic variant form of phenylalanine hydroxylase. Mol Genet Metab. 2000. X-2, X-3, X-4.
764 Lebech M, et al. Feasibility of neonatal screening for toxoplasma infection in the absence of prenatal treatment. Danish Congenital Toxoplasmosis Study Group. Lancet. 1999. X-2, X-3, X-4.
765 Ledley FD. Somatic gene therapy for human disease: a problem of eugenics?. Trends Genet. 1987. X-1, X-2, X-3, X-4.
766 Ledley FD, Hahn T, Woo SL. Selection for phenylalanine hydroxylase activity in cells transformed with recombinant retroviruses. Somat Cell Mol Genet. 1987. X-2, X-3, X-4.
767 Ledley FD. Somatic gene therapy for human disease: background and prospects. Part II. J Pediatr. 1987. X-1, X-2, X-3, X-4.
768 Ledley FD, Woo SL. P-chlorophenylalanine does not inhibit production of recombinant human phenylalanine hydroxylase in NIH3T3 cells or E. coli. Biochem Biophys Res Commun. 1987. X-2, X-3, X-4.
769 Lee DH, et al. The molecular basis of phenylketonuria in Koreans. J Hum Genet. 2004. X-4, X-5.
770 Lee NC, et al. Long-term follow-up of Chinese patients who received delayed treatment for 6-pyruvoyl-tetrahydropterin synthase deficiency. Mol Genet Metab. 2006. X-2, X-3, X-4, X-5.
772 Lee PJ, et al. Adults with late diagnosed PKU and severe challenging behaviour: a randomised placebo-controlled trial of a phenylalanine-restricted diet. J Neurol Neurosurg Psychiatry. 2009. X-4, X-5.
773 Lee PJ. Pregnancy issues in inherited metabolic disorders. J Inherit Metab Dis. 2006. X-1, X-2, X-3, X-4.
774 Lee PJ, et al. Maternal phenylketonuria: report from the United Kingdom Registry 1978-97. Arch Dis Child. 2005. X-4, X-5.
776 Leeming RJ, Hall SK, Green A. The origin of red blood cell biopterin. Mol Genet Metab. 1998. X-2, X-3, X-4.
777 Leeming RJ. Microtiter plate assay for biopterin using cryopreserved Crithidia fasciculata. Methods Enzymol. 1997. X-2, X-3, X-4.
778 Leeming RJ, et al. A microtitre plate method for measuring biopterin with cryopreserved Crithidia fasciculata. Adv Exp Med Biol. 1993. X-2, X-3, X-4.
779 Leeming RJ, et al. Relationship between plasma and red cell biopterins in acute and chronic hyperphenylalaninaemia. J Inherit Metab Dis. 1990. X-4+.
780 Leeming RJ, et al. Blood spots on Guthrie cards can be used for inherited tetrahydrobiopterin deficiency screening in hyperphenylalaninaemic infants. Arch Dis Child. 1984. X-4+. 1628398.
781 Leeming RJ, et al. Biopterin derivatives in normal and phenylketonuric patients after oral loads of L-phenylalanine, L-tyrosine, and L-tryptophan. Arch Dis Child. 1976. X-4, X-5.
782 Leeming RJ, et al. Biopterin derivatives in human body fluids and tissues. J Clin Pathol. 1976. X-2, X-3, X-4, X-5.
783 Legido A, et al. Treatment variables and intellectual outcome in children with classic phenylketonuria. A single-center-based study. Clin Pediatr (Phila). 1993. X-4, X-5.
784 Lehmann WD, Heinrich HC. Impaired phenylalanine-tyrosine conversion in patients with iron-deficiency anemia studied by a L-(2H5)phenylalanine-loading test. Am J Clin Nutr. 1986. X-2, X-4.
785 Lei XD, Kaufman S. Human white blood cells and hair follicles are good sources of mRNA for the pterin carbinolamine dehydratase/dimerization cofactor of HNF1 for mutation detection. Biochem Biophys Res Commun. 1998. X-2, X-4.
786 Lenke RR. Maternal phenylketonuria and hyperphenylalanemia: a problem born of success. J Pediatr Perinat Nutr. 1987. X-1.
787 Lenke RR, Levy HL. Maternal phenylketonuria--results of dietary therapy. Am J Obstet Gynecol. 1982. X-1.
788 Lenke RR, Levy HL. Maternal phenylketonuria and hyperphenylalaninemia. An international survey of the outcome of untreated and treated pregnancies. N Engl J Med. 1980. X-1.
789 Leonard CO, Chase GA, Childs B. Genetic counseling: a consumers' view. N Engl J Med. 1972. X-1, X-4, X-5.
790 Leuzzi V, et al. The spectrum of phenylalanine variations under tetrahydrobiopterin load in subjects affected by phenylalanine hydroxylase deficiency. J Inherit Metab Dis. 2006. X-4, X-5.
791 Leuzzi V, et al. Executive function impairment in early-treated PKU subjects with normal mental development. J Inherit Metab Dis. 2004. X-4, X-5.
792 Leuzzi V, et al. Clinical significance of brain phenylalanine concentration assessed by in vivo proton magnetic resonance spectroscopy in phenylketonuria. J Inherit Metab Dis. 2000. X-4.
793 Leuzzi V, et al. Derangement of the dopaminergic system in phenylketonuria: study of the event-related potential (P300). J Inherit Metab Dis. 2000. X-4, X-5.
795 Leuzzi V, et al. Neuropsychological and neuroradiological (MRI) variations during phenylalanine load: protective effect of valine, leucine, and isoleucine supplementation. J Child Neurol. 1997. X-4.
796 Leuzzi V, et al. Biochemical, clinical and neuroradiological (MRI) correlations in late-detected PKU patients. J Inherit Metab Dis. 1995. X-4, X-5.
797 Leuzzi V, et al. Visual, auditory, and somatosensorial evoked potentials in early and late treated adolescents with phenylketonuria. J Clin Neurophysiol. 1994. X-4, X-5.
798 Leuzzi V, et al. Neuroradiological (MRI) abnormalities in phenylketonuric subjects: clinical and biochemical correlations. Neuropediatrics. 1993. X-4, X-5.
799 Levy H, et al. Recommendations for evaluation of responsiveness to tetrahydrobiopterin (BH(4)) in phenylketonuria and its use in treatment. Mol Genet Metab. 2007. X-1, X-4.
802 Levy HL, et al. Congenital heart disease in maternal phenylketonuria: report from the Maternal PKU Collaborative Study. Pediatr Res. 2001. X-4, X-5.
803 Levy HL. Comments on final intelligence in late treated patients with phenylketonuria. Eur J Pediatr. 2000. X-1, X-2, X-3, X-4, X-5.
804 Levy HL. Inherited metabolic disorders: from the newborn to the mother and beyond. Southeast Asian J Trop Med Public Health. 1999. X-4.
805 Levy HL, et al. Fetal ultrasonography in maternal PKU. Prenat Diagn. 1996. X-4.
806 Levy HL, et al. Maternal non-phenylketonuric mild hyperphenylalaninemia. Eur J Pediatr. 1996. X-4, X-5.
807 Levy HL, et al. Maternal mild hyperphenylalaninemia: results of treated and untreated pregnancies in two sisters. J Pediatr. 1994. X-3.
808 Levy HL. Maternal PKU. Prog Clin Biol Res. 1985. X-1.
809 Levy HL. Maternal PKU: control of an emerging problem. Am J Public Health. 1982. X-1, X-2, X-3, X-4, X-5.
810 Levy HL, Mitchell ML. The current status of newborn screening. Hosp Pract (Off Ed). 1982. X-1.
811 Levy HL. Treatment of phenylketonuria. Prog Clin Biol Res. 1979. X-1.
812 Levy HL, Barkin E. Comparison of amino acid concentrations between plasma and erythrocytes. Studies in normal human subjects and those with metabolic disorders. J Lab Clin Med. 1971. X-1.
813 Levy HL, et al. Screening the “normal” population in Massachusetts for phenylketonuria. N Engl J Med. 1970. X-3, X-4, X-5.
814 Lichter-Konecki U, et al. Relation between phenylalanine hydroxylase genotypes and phenotypic parameters of diagnosis and treatment of hyperphenylalaninaemic disorders. German Collaborative Study of PKU. J Inherit Metab Dis. 1994. X-4, X-5.
815 Lillevali H, Ounap K, Metspalu A. Phenylalanine hydroxylase gene mutation R408W is present on 84% of Estonian phenylketonuria chromosomes. Eur J Hum Genet. 1996. X-4.
816 Lin CM, et al. Expression of human phenylalanine hydroxylase activity in T lymphocytes of classical phenylketonuria children by retroviral-mediated gene transfer. J Inherit Metab Dis. 1997. X-2, X-4.
817 Lindner M, et al. Blood phenylalanine concentrations in patients with PAH-deficient hyperphenylalaninaemia off diet without and with three different single oral doses of tetrahydrobiopterin: assessing responsiveness in a model of statistical process control. J Inherit Metab Dis. 2009. X-4, X-5.
818 Lindner M, et al. Tetrahydrobiopterin sensitivity in German patients with mild phenylalanine hydroxylase deficiency. Hum Mutat. 2003. X-4.
819 Lines DR, Waisman HA. The effect of feeding -2-thienylalanine on phenylalanine metabolism in the rhesus monkey. Aust N Z J Med. 1973. X-2.
820 Lines DR, Waisman HA. Placental transport of phenylalanine in the rat: maternal and fetal metabolism. Proc Soc Exp Biol Med. 1971. X-2.
821 Link R. Phenylketonuria diet in adolescents--energy and nutrient intake--is it adequate?. Postgrad Med J. 1989. X-1.
822 Lipinska L, Laskowska-Klita T, Cabalska B. Riboflavin status in phenylketonuric patients in the course of dietary treatment. J Inherit Metab Dis. 1994. X-4, X-5.
823 Lipson A, et al. The selenium status of children with phenylketonuria: results of selenium supplementation. Aust Paediatr J. 1988. X-4.
824 Liu KM, et al. Long-term follow-up of Taiwanese Chinese patients treated early for 6-pyruvoyl-tetrahydropterin synthase deficiency. Arch Neurol. 2008. X-2.
825 Liu SR, Zuo QH. Newborn screening for phenylketonuria in eleven districts. Chin Med J (Engl). 1986. X-4.
826 Liu TT, et al. Tetrahydrobiopterin-deficient hyperphenylalaninemia in the Chinese. Clin Chim Acta. 2001. X-2, X-4.
827 Liu TT, et al. Identification of three novel 6-pyruvoyl-tetrahydropterin synthase gene mutations (226C>T, IVS3+1G>A, 116-119delTGTT) in Chinese hyperphenylalaninemia caused by tetrahydrobiopterin synthesis deficiency. Hum Mutat. 2001. X-2, X-4.
828 Liu TT, et al. Mutation analysis of the 6-pyruvoyl-tetrahydropterin synthase gene in Chinese hyperphenylalaninemia caused by tetrahydrobiopterin synthesis deficiency. Hum Mutat. 1998. X-4.
829 Liu TT, Hsiao KJ. Identification of a common 6-pyruvoyl-tetrahydropterin synthase mutation at codon 87 in Chinese phenylketonuria caused by tetrahydrobiopterin synthesis deficiency. Hum Genet. 1996. X-4.
830 Lloyd B, et al. Blood selenium concentrations and glutathione peroxidase activity. Arch Dis Child. 1989. X-4, X-5.
831 Lloyd JK. Dietary problems associated with the care of chronically sick children. J Hum Nutr. 1979. X-4.
832 Lo WH, et al. Molecular basis of PKU in China. Chin Med Sci J. 1993. X-4.
833 Lombeck I, Jochum F, Terwolbeck K. Selenium status in infants and children with phenylketonuria and in maternal phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
834 Lombeck I, et al. Selenium intake of infants and young children, healthy children and dietetically treated patients with phenylketonuria. Eur J Pediatr. 1984. X-3.
835 Lombeck I, et al. Selenium supplementation: plasma glutathione peroxidase an indicator of selenium intake. Klin Padiatr. 1982. X-3.
836 Lombeck I, et al. Selenium requirements in patients with inborn errors of amino acid metabolism and selenium deficiency. Eur J Pediatr. 1980. X-3.
837 Lombeck I, et al. The selenium state of children. II. Selenium content of serum, whole blood, hair and the activity of erythrocyte glutathione peroxidase in dietetically treated patients with phenylketonuria and maple-syrup-urine disease. Eur J Pediatr. 1978. X-4, X-5.
838 Lombeck I, et al. Trace element disturbances in dietetically treated patients with phenylketonuria and maple syrup urine disease. Monogr Hum Genet. 1978. X-4.
839 Lombeck I, et al. Serum-selenium concentrations in patients with maple-syrup-urine disease and phenylketonuria under dieto-therapy. Clin Chim Acta. 1975. X-4, X-5.
840 Longhi R, et al. Trace elements nutriture in hyperphenylalaninemic patients. Long-term follow up study. Eur J Pediatr. 1987. X-4.
841 Longo N, et al. Noninvasive measurement of phenylalanine by iontophoretic extraction in patients with phenylketonuria. J Inherit Metab Dis. 2007. X-4.
842 Lonsdale D, Foust M. Normal mental development in treated phenylketonuria. Report of ten cases. Am J Dis Child. 1970. X-3, X-5.
843 Loo YH, et al. Experimental maternal phenylketonuria: an examination of two animal models. Dev Neurosci. 1983. X-2, X-4.
844 Loo YH, Scotto L, Horning MG. Aromatic acid metabolites of phenylalanine in the brain of the hyperphenylalaninemic rat: effect of pyridoxamine. J Neurochem. 1977. X-2.
845 Loo YH, Mack K. Effect of vitamin B 6 on phenylalanine metabolism in the brain of normal and p-chlorophenylalanine-treated rats. J Neurochem. 1972. X-2.
846 Loo YH, Mack K. Effect of hyperphenylalaninemia on vitamin B 6 metabolism in developing rat brain. J Neurochem. 1972. X-2.
847 Lopes FM, et al. Toxoplasma gondii infection in pregnancy. Braz J Infect Dis. 2007. X-4.
848 Lott JW. PKU: a nursing update. J Pediatr Nurs. 1988. X-1.
849 Lou HC, et al. Unchanged MRI of myelin in adolescents with PKU supplied with non-phe essential amino acids after dietary relaxation. Acta Paediatr. 1994. X-3, X-4, X-5.
850 Lou HC, et al. An occipito-temporal syndrome in adolescents with optimally controlled hyperphenylalaninaemia. J Inherit Metab Dis. 1992. X-4, X-5.
851 Lou HC, et al. Increased vigilance and dopamine synthesis by large doses of tyrosine or phenylalanine restriction in phenylketonuria. Acta Paediatr Scand. 1987. X-3, X-4.
852 Luciana M, Hanson KL, Whitley CB. A preliminary report on dopamine system reactivity in PKU: acute effects of haloperidol on neuropsychological, physiological, and neuroendocrine functions. Psychopharmacology (Berl). 2004. X-3, X-4, X-5.
854 Luder AS, Greene CL. Maternal phenylketonuria and hyperphenylalaninemia: implications for medical practice in the United States. Am J Obstet Gynecol. 1989. X-1.
855 Ludolph AC, Vetter U, Ullrich K. Studies of multimodal evoked potentials in treated phenylketonuria: the pattern of vulnerability. Eur J Pediatr. 1996. X-4.
856 Ludolph AC, et al. Neurological outcome in 22 treated adolescents with hyperphenylalaninemia. A clinical and electrophysiological study. Acta Neurol Scand. 1992. X-4, X-5.
857 Lukacs Z, Santer R. Evaluation of electrospray-tandem mass spectrometry for the detection of phenylketonuria and other rare disorders. Mol Nutr Food Res. 2006. X-4.
858 Lunde HA, et al. Serum carnosinase in blood and homocarnosine in CSF of patients with Folling's disease (PKU). J Oslo City Hosp. 1987. X-4.
859 Lutcke A, Bickel H. Electroencephalographic manifestations of cerebral attacks and intellectual development in phenylketonuria. Electroencephalogr Clin Neurophysiol. 1969. X-1, X-2, X-3, X-4, X-5.
860 Lutz P, Schmidt H, Batzler U. Study design and description of patients. Eur J Pediatr. 1990. X-4, X-5.
861 Lykkelund C, et al. Increased neurotransmitter biosynthesis in phenylketonuria induced by phenylalanine restriction or by supplementation of unrestricted diet with large amounts of tyrosine. Eur J Pediatr. 1988. X-3, X-4, X-5.
862 Lynch BC, et al. Maternal phenylketonuria: successful outcome in four pregnancies treated prior to conception. Eur J Pediatr. 1988. X-3, X-4, X-5.
863 MacCready RA. Admissions of phenylketonuric patients to residential institutions before and after screening programs of the newborn infant. J Pediatr. 1974. X-4, X-5.
864 MacCready RA, Levy HL. The problem of maternal phenylketonuria. Am J Obstet Gynecol. 1972. X-1.
865 MacDonald A, et al. Long-term compliance with a novel vitamin and mineral supplement in older people with PKU. J Inherit Metab Dis. 2008. X-4, X-5.
866 Macdonald A, et al. Does maternal knowledge and parent education affect blood phenylalanine control in phenylketonuria?. J Hum Nutr Diet. 2008. X-4.
867 MacDonald A, et al. Home delivery of dietary products in inherited metabolic disorders reduces prescription and dispensing errors. J Hum Nutr Diet. 2006. X-4.
868 MacDonald A, et al. ‘Ready to drink’ protein substitute is easier is for people with phenylketonuria. J Inherit Metab Dis. 2006. X-4.
869 MacDonald A, et al. Protein substitute dosage in PKU: how much do young patients need?. Arch Dis Child. 2006. X-4, X-5.
870 MacDonald A, et al. Breast feeding in IMD. J Inherit Metab Dis. 2006. X-2, X-3, X-4.
871 MacDonald A, Asplin D. Phenylketonuria: practical dietary management. J Fam Health Care. 2006. X-1, X-2, X-4.
872 MacDonald A, et al. A new, low-volume protein substitute for teenagers and adults with phenylketonuria. J Inherit Metab Dis. 2004. X-4.
873 MacDonald A, et al. Are tablets a practical source of protein substitute in phenylketonuria?. Arch Dis Child. 2003. X-4.
874 MacDonald A, et al. Free use of fruits and vegetables in phenylketonuria. J Inherit Metab Dis. 2003. X-4, X-5.
875 MacDonald A, et al. Administration of protein substitute and quality of control in phenylketonuria: a randomized study. J Inherit Metab Dis. 2003. X-4, X-5.
876 MacDonald A, et al. Does a single plasma phenylalanine predict quality of control in phenylketonuria?. Arch Dis Child. 1998. X-4.
877 MacDonald A, et al. Factors affecting the variation in plasma phenylalanine in patients with phenylketonuria on diet. Arch Dis Child. 1996. X-4, X-5.
878 MacDonald A, et al. Feeding problems in young PKU children. Acta Paediatr Suppl. 1994. X-4.
879 Mace JW, et al. The child with an unusual odor. A clinical resume. Clin Pediatr (Phila). 1976. X-3, X-4.
880 Mackey SA, Berlin CM Jr. Effect of dietary aspartame on plasma concentrations of phenylalanine and tyrosine in normal and homozygous phenylketonuric patients. Clin Pediatr (Phila). 1992. X-3, X-4.
881 MacLeod EL, et al. Reassessment of phenylalanine tolerance in adults with phenylketonuria is needed as body mass changes. Mol Genet Metab. 2009. X-3, X-4.
882 Maddox MA. Is there a link between dementia and phenylketonuria?. J Gerontol Nurs. 1990. X-4.
883 Magee AC, et al. Follow up of fetal outcome in cases of maternal phenylketonuria in Northern Ireland. Arch Dis Child Fetal Neonatal Ed. 2002. X-4, X-5.
885 Mallolas J, et al. Mutational spectrum of phenylalanine hydroxylase deficiency in the population resident in Catalonia: genotype-phenotype correlation. Hum Genet. 1999. X-4.
886 Manara R, et al. Brain MRI diffusion-weighted imaging in patients with classical phenylketonuria. Neuroradiology. 2009. X-4, X-5.
887 Manz F, et al. Acid-base status in dietary treatment of phenylketonuria. Pediatr Res. 1977. X-4.
888 Marholin D 2nd, et al. Effects of diet and behavior therapy on social and motor behavior of retarded phenylketonuric adults: an experimental analysis. Pediatr Res. 1978. X-3, X-4.
889 Marino MA. Developing and testing a programmed instruction unit on PKU. J Am Diet Assoc. 1980. X-2, X-4.
890 Marsh J, Sargent E. Factors affecting the duration of postnatal visits. Midwifery. 1991. X-2, X-3, X-4.
891 Marsh RW. The feasibility of treating Down's disease with a reduced phenylalanine diet. N Z Med J. 1971. X-2.
892 Martin PH. Six years of newborn PKU screening. J Indiana State Med Assoc. 1968. X-4.
893 Martinez-Cruz F, et al. Oxidative stress induced by phenylketonuria in the rat: Prevention by melatonin, vitamin E, and vitamin C. J Neurosci Res. 2002. X-2, X-3, X-4.
894 Matalon KM, Acosta PB, Azen C. Role of nutrition in pregnancy with phenylketonuria and birth defects. Pediatrics. 2003. X-4, X-5.
897 Matalon R, et al. Response of patients with phenylketonuria in the US to tetrahydrobiopterin. Mol Genet Metab. 2005. X-4, X-5.
898 Matalon R, et al. Biopterin responsive phenylalanine hydroxylase deficiency. Genet Med. 2004. X-4, X-5.
899 Matalon R, et al. Maternal PKU Collaborative Study: pregnancy outcome and postnatal head growth. J Inherit Metab Dis. 1994. X-4, X-5.
900 Matalon R, et al. Maternal PKU collaborative study: the effect of nutrient intake on pregnancy outcome. J Inherit Metab Dis. 1991. X-4, X-5.
901 Matalon R, et al. Screening for biopterin defects in newborns with phenylketonuria and other hyperphenylalaninemias. Ann Clin Lab Sci. 1982. X-4.
902 Matthews WS, et al. Social quotients of children with phenylketonuria before and after discontinuation of dietary therapy. Am J Ment Defic. 1986. X-4.
903 Mazur A, et al. Evaluation of somatic development in adult patients with previously undiagnosed and/or untreated phenylketonuria. Med Princ Pract. 2010. X-4, X-5.
904 Mazur A, et al. Measurement of functional independence level and falls-risk in individuals with undiagnosed phenylketonuria. Acta Biochim Pol. 2009. X-4.
905 Mazzarella G, et al. Antenatal and perinatal care in southern Italy. II. The clinicians' reactions. Paediatr Perinat Epidemiol. 1991. X-2, X-3, X-4.
906 MC MS, Stephenson JB. Treatment of classical phenylketonuria. Arch Dis Child. 1968. +. X-4, X-5.
907 McBurnie MA, et al. Physical growth of children treated for phenylketonuria. Ann Hum Biol. 1991. X-4, X-5.
908 McCabe ER, et al. Evaluation of a phenylalanine-free product for treatment of phenylketonuria. Am J Dis Child. 1987. X-4.
909 McCabe ER, McCabe L. Issues in the dietary management of phenylketonuria: breast-feeding and trace-metal nutriture. Ann N Y Acad Sci. 1986. X-4.
910 McCabe L, et al. The management of breast feeding among infants with phenylketonuria. J Inherit Metab Dis. 1989. X-4.
911 McCormack MK. Clinical teratology. Am Fam Physician. 1983. X-1, X-2, X-3, X-4.
912 McCormack MK. Screening for genetic traits and diseases. Am Fam Physician. 1981. X-1, X-2, X-3, X-4.
913 McDonald JD, et al. Cardiovascular defects among the progeny of mouse phenylketonuria females. Pediatr Res. 1997. X-2, X-3, X-4.
914 McDonnell GV, et al. A neurological evaluation of adult phenylketonuria in Northern Ireland. Eur Neurol. 1998. X-4.
915 McElwain WP. Progress report on the PKU testing program. J Ky Med Assoc. 1972. X-4.
916 McGill JJ. The management of phenylketonuria (PKU). Southeast Asian J Trop Med Public Health. 1999. X-1.
917 McKean CM. Effects of totally synthetic, low phenylalanine diet on adolescent phenylketonuric patients. Arch Dis Child. 1971. X-3, X-4, X-5.
918 McKean CM, Peterson NA. Glutamine in the phenylketonuric central nervous system. N Engl J Med. 1970. X-4, X-5.
919 McKean CM. Growth of phenylketonuric children on chemically defined diets. Lancet. 1970. X-3, X-4, X-5.
920 McKenzie RL, et al. Selenium concentration and glutathione peroxidase activity in blood of New Zealand infants and children. Am J Clin Nutr. 1978. X-4+.
921 McKnight RP, et al. Evaluation of the PaT Stat Kinetic UV Test set for the determination of phenylalanine and tyrosine in serum or plasma. Clin Biochem. 1983. X-2, X-3, X-4.
922 McLean A, Marwick MJ, Clayton BE. Enzymes involved in phenylalanine metabolism in the human foetus and child. J Clin Pathol. 1973. X-2, X-4.
923 McLeay AC. The Guthrie test and skin cleansing. Med J Aust. 1973. X-4.
924 McMurry MP, et al. Bone mineral status in children with phenylketonuria--relationship to nutritional intake and phenylalanine control. Am J Clin Nutr. 1992. X-4.
925 Mehl AL, Thomson V. Newborn hearing screening: the great omission. Pediatrics. 1998. X-2, X-3, X-4.
926 Mekanandha V, et al. Phenylketonuria: report of two untreated cases with biochemical study of homozygote and heterozygote. J Med Assoc Thai. 1975. X-3.
927 Menkes JH, Holtzman NA. Phenylalaninemia or classical phenylketonuria. Neuropadiatrie. 1970. X-1, X-2, X-3, X-4, X-5.
928 Menkes JH, Holtzman NA. Neonatal hyperphenylalaninemia: a differential diagnosis. Neuropadiatrie. 1970. X-3, X-4, X-5.
929 Menzel H, et al. Glutathione peroxidase and glutathione S-transferase activity of platelets. Eur J Pediatr. 1983. X-4.
930 Merino V, et al. Noninvasive sampling of phenylalanine by reverse iontophoresis. J Control Release. 1999. X-2, X-4.
931 Merrick J, Aspler S, Schwarz G. Should adults with phenylketonuria have diet treatment?. Ment Retard. 2001. X-1, X-3, X-4, X-5.
932 Mesmacque-Caby D, Farriaux JP, Fontaine G. Letter: Dietary phenylalanine requirements in infants with hyperphenylalaninaemia. Arch Dis Child. 1974. X-1.
933 Michals K, et al. Nutrition and reproductive outcome in maternal phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
934 Michals K, et al. Blood phenylalanine levels and intelligence of 10-year-old children with PKU in the National Collaborative Study. J Am Diet Assoc. 1988. X-4, X-5.
935 Michals K, Lopus M, Matalon R. Phenylalanine metabolites as indicators of dietary compliance in children with phenylketonuria. Biochem Med Metab Biol. 1988. X-4, X-5.
936 Michals K, Matalon R. Phenylalanine metabolites, attention span and hyperactivity. Am J Clin Nutr. 1985. X-4, X-5.
937 Michals K, et al. Return to diet therapy in patients with phenylketonuria. J Pediatr. 1985. X-4, X-5.
938 Michals-Matalon K, et al. Response of phenylketonuria to tetrahydrobiopterin. J Nutr. 2007. X-1, X-4.
939 Michals-Matalon K, et al. Nutrient intake and congenital heart defects in maternal phenylketonuria. Am J Obstet Gynecol. 2002. X-4, X-5.
940 Michel U, Schmidt E, Batzler U. Results of psychological testing of patients aged 3-6 years. Eur J Pediatr. 1990. X-4, X-5.
941 Miller AL, Hawkins RA, Veech RL. Phenylketonuria: phenylalanine inhibits brain pyruvate kinase in vivo. Science. 1973. X-2, X-3, X-4.
942 Millner BN. Insurance coverage of special foods needed in the treatment of phenylketonuria. Public Health Rep. 1993. X-2, X-3, X-4, X-5.
943 Milner RD, Wirdnam PK. The pancreatic beta cell fraction in children with errors of amino acid metabolism. Pediatr Res. 1982. X-4.
944 Milstien S, Kaufman S, Summer GK. Hyperphenylalaninemia due to dihydropteridine reductase deficiency: diagnosis by measurement of oxidized and reduced pterins in urine. Pediatrics. 1980. X-3, X-4, X-5.
945 Miranda da Cruz BD, Seidler H, Widhalm K. Iron status and iron supplementation in children with classical phenylketonuria. J Am Coll Nutr. 1993. X-4.
946 Missiou-Tsagaraki S. Screening for glucose-6-phosphate dehydrogenase deficiency as a preventive measure: prevalence among 1,286,000 Greek newborn infants. J Pediatr. 1991. X-2, X-4.
947 Missiou-Tsagaraki S, Soulpi K, Loumakou M. Phenylketonuria in Greece: 12 years' experience. J Ment Defic Res. 1988. X-2, X-4.
948 Mitchell JJ, et al. Tetrahydrobiopterin-responsive phenylketonuria: the New South Wales experience. Mol Genet Metab. 2005. X-4, X-5.
949 Moats RA, et al. Brain phenylalanine concentrations in phenylketonuria: research and treatment of adults. Pediatrics. 2003. X-3.
950 Moats RA, et al. Brain phenylalanine concentration in the management of adults with phenylketonuria. J Inherit Metab Dis. 2000. X-4, X-5.
951 Modan-Moses D, et al. Peak bone mass in patients with phenylketonuria. J Inherit Metab Dis. 2007. X-4, X-5.
952 Montford AA. Classical phenylketonuria. Nurs Times. 1969. X-1.
953 Mordaunt VL, Cunningham GC, Kan K. Computer assisted management of a regionalized newborn screening program. J Med Syst. 1988. X-4.
954 Morisi G, et al. Age and sex specific reference serum selenium levels estimated for the Italian population. Ann Ist Super Sanita. 1989. X-4.
955 Morrow T. Recently-approved sapropterin reduces phenylalanine levels. Manag Care. 2008. X-1, X-2, X-3, X-4, X-5.
956 Moseley K, Koch R, Moser AB. Lipid status and long-chain polyunsaturated fatty acid concentrations in adults and adolescents with phenylketonuria on phenylalanine-restricted diet. J Inherit Metab Dis. 2002. X-4, X-5.
957 Moser HW, Raymond GV, Dubey P. Adrenoleukodystrophy: new approaches to a neurodegenerative disease. JAMA. 2005. X-2, X-3, X-4.
958 Moser HW. Genetic causes of mental retardation. Ann N Y Acad Sci. 2004. X-1, X-2, X-3, X-4.
959 Mostafawy A, et al. A study of cerebral atrophy in phenylketonuria. Sonoencephalographic examination of 45 PKU patients. Neuropadiatrie. 1970. X-4, X-5.
960 Motulsky AG, Omenn GS. Special award lecture: biochemical genetics and psychiatry. Proc Annu Meet Am Psychopathol Assoc. 1975. X-1+.
961 Motzfeldt K, Lilje R, Nylander G. Breastfeeding in phenylketonuria. Acta Paediatr Suppl. 1999. X-1, X-3, X-4, X-5.
962 Mowat DR, et al. Maternal phenylketonuria: a continuing problem. Med J Aust. 1999. X-4, X-5.
964 Moynihan P. Dietary therapy in chronically sick children: dental health considerations. Quintessence Int. 2006. X-4.
965 Muntau AC, et al. Tetrahydrobiopterin as an alternative treatment for mild phenylketonuria. N Engl J Med. 2002. X-4, X-5.
966 Murphy D. Termination of dietary treatment of phenylketonuria. Ir J Med Sci. 1969. X-1+.
967 Murphy GH, et al. Adults with untreated phenylketonuria: out of sight, out of mind. Br J Psychiatry. 2008. X-4, X-5.
968 Musson DG, et al. Relative bioavailability of sapropterin from intact and dissolved sapropterin dihydrochloride tablets and the effects of food: a randomized, open-label, crossover study in healthy adults. Clin Ther. 2010. X-2, X-4, X-5.
969 Moller HE, et al. Kinetics of phenylalanine transport at the human blood-brain barrier investigated in vivo. Brain Res. 1997. X-3, X-4.
970 Moller HE, et al. In-vivo NMR spectroscopy in patients with phenylketonuria: changes of cerebral phenylalanine levels under dietary treatment. Neuropediatrics. 1995. X-3, X-4.
971 Monch E, et al. Utilisation of amino acid mixtures in adolescents with phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
972 Monch E, et al. Examination of urine metabolites in the newborn period and during protein loading tests at 6 months of age--Part 1. Eur J Pediatr. 1990. X-4, X-5.
973 Nagasaki Y, et al. Reversal of hypopigmentation in phenylketonuria mice by adenovirus-mediated gene transfer. Pediatr Res. 1999. X-2, X-3, X-4.
974 Nahum LH. Dietary therapy and cognitive development in phenylketonuria. Conn Med. 1968. X-1.
975 Nakhost Z, et al. Synthesis of low-phenylalanine polypeptides. Int J Pept Protein Res. 1982. X-2, X-3, X-4.
976 Naughten E, Saul IP. Maternal phenylketonuria--the Irish experience. J Inherit Metab Dis. 1990. X-4, X-5.
977 Naughten ER. Continuation vs discontinuation of diet in phenylketonuria. Eur J Clin Nutr. 1989. X-1+.
978 Naughten ER, et al. Phenylketonuria: outcome and problems in a “diet-for-life” clinic. Eur J Pediatr. 1987. X-4, X-5+. X-4, X-5.
979 Naylor EW, Chace DH. Automated tandem mass spectrometry for mass newborn screening for disorders in fatty acid, organic acid, and amino acid metabolism. J Child Neurol. 1999. X-4.
980 Netley C, Hanley WB, Rudner HL. Phenylketonuria and its variants: observations on intellectual functioning. Can Med Assoc J. 1984. X-4, X-5.
981 Neto EC, et al. Persistent tyrosinemia detected by thin-layer chromatography. Southeast Asian J Trop Med Public Health. 1999. X-2, X-3, X-4.
982 Newberger EH, Howard RB. A conceptual approach to the child with exceptional nutritional requirements. The management of patients with complex nutritional problems is addressed with a simple conceptual model. Clin Pediatr (Phila). 1973. X-1, X-4.
983 Newson A. Should parental refusals of newborn screening be respected?. Camb Q Healthc Ethics. 2006. X-1, X-2, X-3, X-4, X-5.
984 Ng TW, et al. Maternal phenylketonuria in Western Australia: pregnancy outcomes and developmental outcomes in offspring. J Paediatr Child Health. 2003. X-3.
985 Niederwieser A, et al. Atypical phenylketonuria with “dihydrobiopterin synthetase” deficiency: absence of phosphate-eliminating enzyme activity demonstrated in liver. Eur J Pediatr. 1985. X-3, X-4.
986 Niederwieser A, Ponzone A, Curtius HC. Differential diagnosis of tetrahydrobiopterin deficiency. J Inherit Metab Dis. 1985. X-2, X-3, X-4.
987 Niederwieser A, et al. Excretion of pterins in phenylketonuria and phenylketonuria variants. Helv Paediatr Acta. 1980. X-4.
988 Nielsen JB, Nielsen KE, Guttler F. Tetrahydrobiopterin responsiveness after extended loading test of 12 Danish PKU patients with the Y414C mutation. J Inherit Metab Dis. 2010. X-4, X-5.
989 Ning C, et al. The screening diagnosis of tetrahydrobiopterin deficient phenylketonuria. J Tongji Med Univ. 1992. X-4.
990 Nitowsky HM. Presciptive screening for inborn errors of metabolism: a critique. Am J Ment Defic. 1973. X-1.
991 Nord AM, McCabe L, McCabe ER. Biochemical and nutritional status of children with hyperphenylalaninaemia. J Inherit Metab Dis. 1988. X-4, X-5.
992 Novello AC. Inherited metabolic diseases: collaborating for the health of all children. Biochem Med Metab Biol. 1993. X-1, X-2, X-3, X-4, X-5.
993 O'Brien D. Inborn errors of metabolism. Am J Clin Nutr. 1979. X-1, X-2, X-3, X-4, X-5.
994 O'Flynn ME. Newborn screening for phenylketonuria: thirty years of progress. Curr Probl Pediatr. 1992. X-1, X-2, X-3, X-4, X-5.
995 O'Flynn ME, et al. The diagnosis of phenylketonuria: a report from the Collaborative Study of Children Treated for Phenylketonuria. Am J Dis Child. 1980. X-4.
996 O'Flynn ME, Hsia D. Some observations on the dietary treatment of phenylketonuria. J Pediatr. 1968. X-4, X-5.
997 O'Flynn ME, Tillman P, Hsia DY. Hyperphenylalanemia without phenylketonuria. Am J Dis Child. 1967. X-1.
998 O'Grady DJ, Mulhern T, Berry HK. Normal IQ distributions of early-treated phenylketonuric children and their unaffected siblings: failure to replicate a trimodal response or negative skew. Nature. 1972. X-4, X-5.
999 O'Grady DJ, Berry HK, Sutherland BS. Cognitive development in early treated phenylketonuria. Am J Dis Child. 1971. X-3, X-5.
1000 O'Grady DJ, Berry HK, Sutherland BS. Phenylketonuria: intellectual developmental and early treatment. Dev Med Child Neurol. 1970. X-4, X-5.
1001 O'sullivan KR, Mathias PM. Analysis of selenium content in commercial dietetic products. Eur J Clin Nutr. 1990. X-2, X-3, X-4.
1002 Oberdoerster J, Guizzetti M, Costa LG. Effect of phenylalanine and its metabolites on the proliferation and viability of neuronal and astroglial cells: possible relevance in maternal phenylketonuria. J Pharmacol Exp Ther. 2000. X-2, X-3, X-4.
1003 Oh HJ, et al. Long-term enzymatic and phenotypic correction in the phenylketonuria mouse model by adeno-associated virus vector-mediated gene transfer. Pediatr Res. 2004. X-2, X-3, X-4.
1004 Ohtahara S, et al. Prenatal etiologies of West syndrome. Epilepsia. 1993. X-2, X-3, X-4.
1005 Okano Y, et al. Effects of tetrahydrobiopterin and phenylalanine on in vivo human phenylalanine hydroxylase by phenylalanine breath test. Mol Genet Metab. 2007. X-2, X-4.
1006 Okano Y, et al. In vivo studies of phenylalanine hydroxylase by phenylalanine breath test: diagnosis of tetrahydrobiopterin-responsive phenylalanine hydroxylase deficiency. Pediatr Res. 2004. X-4.
1007 Okano Y, Isshiki G. Newborn mass screening and molecular genetics of phenylketonuria in east Asia. Southeast Asian J Trop Med Public Health. 1995. X-2, X-4.
1008 Oldendorf WH. Saturation of blood brain barrier transport of amino acids in phenylketonuria. Arch Neurol. 1973. X-4, X-5.
1009 Oldendorf WH, Sisson BW, Silverstein A. Brain uptake of selenomethionine Se 75. II. Reduced brain uptake of selenomethionine Se 75 in phenylketonuria. Arch Neurol. 1971. X-3, X-4, X-5.
1010 Oldendorf WH, Sisson WB. Brain uptake of 75 Se-selenomethionine. Trans Am Neurol Assoc. 1970. X-2.
1011 Olsson GM, Montgomery SM, Alm J. Family conditions and dietary control in phenylketonuria. J Inherit Metab Dis. 2007. X-4, X-5.
1012 Opladen T, et al. Severe mucitis after sublingual administration of tetrahydrobiopterin in a patient with tetrahydrobiopterin-responsive phenylketonuria. Eur J Pediatr. 2005. X-1, X-3.
1013 Oppliger T, et al. Structural and functional consequences of mutations in 6-pyruvoyltetrahydropterin synthase causing hyperphenylalaninemia in humans. Phosphorylation is a requirement for in vivo activity. J Biol Chem. 1995. X-2, X-3, X-4.
1014 Ormazabal A, et al. Platelet serotonin concentrations in PKU patients under dietary control and tetrahydrobiopterin treatment. J Inherit Metab Dis. 2005. X-4, X-5.
1015 Oseid B. Breast-feeding and infant health. Semin Perinatol. 1979. X-1, X-2, X-3, X-4.
1016 Oura T. Life-long treatment for phenylketonuria. Southeast Asian J Trop Med Public Health. 1999. X-1.
1017 Overgaard C, Knudsen A. Pain-relieving effect of sucrose in newborns during heel prick. Biol Neonate. 1999. X-2, X-3, X-4.
1018 Owada M, Aoki K, Kitagawa T. Taste preferences and feeding behaviour in children with phenylketonuria on a semisynthetic diet. Eur J Pediatr. 2000. X-4, X-5.
1019 Owada M, et al. Dietary treatment of PKU using a low-phenylalanine peptide milk. Acta Paediatr Jpn. 1988. X-4, X-5.
1020 Ozalp I, et al. Newborn PKU screening in Turkey: at present and organization for future. Turk J Pediatr. 2001. X-4.
1021 Ozalp I, et al. Genetic and neurological evaluation of untreated and late-treated patients with phenylketonuria. J Inherit Metab Dis. 1994. X-4, X-5.
1022 Ozalp I, et al. Inherited metabolic disorders in Turkey. J Inherit Metab Dis. 1990. X-4, X-5.
1023 Ozanne AE, Krimmer H, Murdoch BE. Speech and language skills in children with early treated phenylketonuria. Am J Ment Retard. 1990. X-4.
1024 Ozboy O. Development of corn starch-gum bread for phenylketonuria patients. Nahrung. 2002. X-1, X-2, X-3, X-4.
1025 Page T. Metabolic approaches to the treatment of autism spectrum disorders. J Autism Dev Disord. 2000. X-1, X-2, X-3, X-4.
1026 Pangkanon S, et al. Detection of phenylketonuria by the newborn screening program in Thailand. Southeast Asian J Trop Med Public Health. 2009. X-4.
1027 Parker CE, et al. Clinical experience in dietary management of phenylketonuria with a new phenylalanine-free product. J Pediatr. 1977. X-4, X-5.
1028 Parker WC. Some ethical and legal aspects of genetic counseling. Birth Defects Orig Artic Ser. 1970. X-1, X-4.
1029 Partington MW. Long term studies of untreated phenylketonuria II: the plasma phenylalanine level. Neuropadiatrie. 1978. X-4.
1030 Partington MW, Laverty T. Long term studies of untreated phenylketonuria I: intelligence or mental ability. Neuropadiatrie. 1978. X-4.
1031 Partington MW, Vickery SK. Phenylketonemia in phenylketonuria. Neuropadiatrie. 1974. X-4.
1032 Partington MW. Phenylketonuria and diet. Can Med Assoc J. 1967. X-1, X-2, X-3, X-4, X-5.
1033 Paul D. Contesting consent: the challenge to compulsory neonatal screening for PKU. Perspect Biol Med. 1999. X-1.
1034 Paul M, et al. Neonatal screening for congenital toxoplasmosis in the Poznan region of Poland by analysis of Toxoplasma gondii-specific IgM antibodies eluted from filter paper blood spots. Pediatr Infect Dis J. 2000. X-2, X-4.
1035 Paulissen JP, Zeldes M. PKU program in Illinois. A 10 year study. IMJ Ill Med J. 1971. X-4.
1036 Pearsen KD, et al. Phenylketonuria: MR imaging of the brain with clinical correlation. Radiology. 1990. X-4.
1037 Peat B. Pregnancy complicated by maternal phenylketonuria. Aust N Z J Obstet Gynaecol. 1993. X-3.
1038 Peck H, Pollitt RJ. The occurrence of gamma-glutamylphenylalanine in the urine of newborn phenylketonurics. Clin Chim Acta. 1979. X-4.
1039 Pedersen HE. Cerebrospinal fluid cholesterols and phospholipids in phenylketonuria. Acta Neurol Scand. 1974. X-4, X-5.
1040 Pedersen HE, Birket-Smith E. Neurological abnormalities in phenylketonuria. Acta Neurol Scand. 1974. X-4, X-5.
1041 Peng SS, et al. Diffusion tensor images in children with early-treated, chronic, malignant phenylketonuric: correlation with intelligence assessment. AJNR Am J Neuroradiol. 2004. X-4, X-5.
1042 Pennington BF, et al. Neuropsychological deficits in early treated phenylketonuric children. Am J Ment Defic. 1985. X-3.
1043 Perez VJ. Phenylketonuria or phenylpyruvic oligophrenia in the rat: behavioural and biochemical correlates. J Ment Defic Res. 1965. X-2.
1044 Perry TL, et al. Unrecognized adult phenylketonuria. Implications for obstetrics and psychiatry. N Engl J Med. 1973. X-3, X-4, X-5.
1045 Perry TL. Phenylketonuria and glutamine. N Engl J Med. 1970. X-1, X-2, X-3, X-4, X-5.
1046 Perry TL, et al. Glutamine depletion in phenylketonuria.A possible cause of the mental defect. N Engl J Med. 1970. X-3, X-4, X-5.
1047 Perry TL, et al. Identification of the diketopiperazine of histidylproline in human urine. J Biol Chem. 1965. X-3, X-4, X-5.
1048 Peterson RM, et al. Phenylketonuria. Experience at one center in the first year of screening in California. Calif Med. 1968. X-1, X-4.
1049 Pey AL, et al. Identification of pharmacological chaperones as potential therapeutic agents to treat phenylketonuria. J Clin Invest. 2008. X-2, X-3, X-4.
1050 Pey AL, Martinez A. Tetrahydrobiopterin for patients with phenylketonuria. Lancet. 2007. X-1, X-2, X-3, X-4, X-5, X-6.
1051 Pey AL, et al. Specific interaction of the diastereomers 7(R)- and 7(S)-tetrahydrobiopterin with phenylalanine hydroxylase: implications for understanding primapterinuria and vitiligo. FASEB J. 2006. X-2, X-3, X-4.
1052 Pey AL, Martinez A. The activity of wild-type and mutant phenylalanine hydroxylase and its regulation by phenylalanine and tetrahydrobiopterin at physiological and pathological concentrations: an isothermal titration calorimetry study. Mol Genet Metab. 2005. X-2, X-3, X-4.
1053 Pey AL, et al. Mechanisms underlying responsiveness to tetrahydrobiopterin in mild phenylketonuria mutations. Hum Mutat. 2004. X-2, X-3, X-4.
1055 Pietz J, et al. Phenylalanine can be detected in brain tissue of healthy subjects by 1H magnetic resonance spectroscopy. J Inherit Metab Dis. 2003. X-2, X-3, X-4.
1056 Pietz J, et al. Large neutral amino acids block phenylalanine transport into brain tissue in patients with phenylketonuria. J Clin Invest. 1999. X-3, X-4.
1058 Pietz J, et al. Psychiatric disorders in adult patients with early-treated phenylketonuria. Pediatrics. 1997. X-4.
1059 Pietz J, et al. Phenylketonuria: findings at MR imaging and localized in vivo H-1 MR spectroscopy of the brain in patients with early treatment. Radiology. 1996. X-4.
1060 Pietz J, Meyding-Lamade UK, Schmidt H. Magnetic resonance imaging of the brain in adolescents with phenylketonuria and in one case of 6-pyruvoyl tetrahydropteridine synthase deficiency. Eur J Pediatr. 1996. X-4, X-5.
1061 Pietz J, et al. Effect of high-dose tyrosine supplementation on brain function in adults with phenylketonuria. J Pediatr. 1995. X-4.
1062 Pietz J, et al. EEGs in phenylketonuria. I: Follow-up to adulthood. II: Short-term diet-related changes in EEGs and cognitive function. Dev Med Child Neurol. 1993. X-4.
1063 Pietz J, et al. EEG development in early treated PKU patients from birth to 6 years of age. Eur J Pediatr. 1990. X-4, X-5.
1064 Pietz J, et al. Long-term development of intelligence (IQ) and EEG in 34 children with phenylketonuria treated early. Eur J Pediatr. 1988. X-4.
1065 Pitt D, et al. Genetic screening of newborn in Australia: results for 1979. Med J Aust. 1981. X-1, X-2, X-3, X-4.
1066 Pitt D, Gooch J. The problem of maternal phenylketonuria. Aust Paediatr J. 1974. X-3, X-4, X-5.
1067 Pitt DB, Danks DM. The natural history of untreated phenylketonuria over 20 years. J Paediatr Child Health. 1991. X-4, X-5.
1068 Pitt DB. Phenylketonuria. Proc Aust Assoc Neurol. 1968. X-4.
1069 Plass AM, et al. Neonatal screening for treatable and untreatable disorders: prospective parents' opinions. Pediatrics. 2010. X-2, X-4.
1071 Platt LD, et al. Maternal phenylketonuria collaborative study, obstetric aspects and outcome: the first 6 years. Am J Obstet Gynecol. 1992. X-4, X-5.
1072 Pollitt RJ. Newborn mass screening versus selective investigation: benefits and costs. J Inherit Metab Dis. 2001. X-1, X-2, X-3, X-4.
1073 Pollitt RJ. Neonatal screening. J Clin Pathol. 1993. X-1, X-2, X-3, X-4, X-5.
1074 Pollitt RJ. Phenylpropionic acid in the urine of patients with phenylketonuria and normals. Clin Chim Acta. 1974. X-3, X-4, X-5.
1075 Poncet IB, et al. Biochemical effects of induced phenylketonuria in rats. Biol Neonate. 1975. X-2, X-3, X-4.
1076 Ponzone A, et al. Unresponsiveness to tetrahydrobiopterin of phenylalanine hydroxylase deficiency. Metabolism. 2010. X-3, X-4, X-5.
1077 Ponzone A, et al. Impact of neonatal protein metabolism and nutrition on screening for phenylketonuria. J Pediatr Gastroenterol Nutr. 2008. X-4, X-5.
1078 Ponzone A, et al. Differential diagnosis of hyperphenylalaninaemia by a combined phenylalanine-tetrahydrobiopterin loading test. Eur J Pediatr. 1993. X-3, X-4.
1079 Ponzone A, et al. Hyperphenylalaninemia and pterin metabolism in serum and erythrocytes. Clin Chim Acta. 1993. X-4, X-5.
1080 Ponzone A, et al. Catalytic activity of tetrahydrobiopterin in dihydropteridine reductase deficiency and indications for treatment. Pediatr Res. 1993. X-3, X-4.
1081 Ponzone A, et al. Tetrahydrobiopterin loading test in hyperphenylalaninemia. Pediatr Res. 1991. X-3, X-4, X-5.
1082 Poser CM. Ten-year follow-up of treatment of two phenylketonuric brothers. Arch Neurol. 1967. X-3, X-4, X-5.
1083 Potkin SG, et al. Plasma phenylalanine, tyrosine, and tryptophan in schizophrenia. Arch Gen Psychiatry. 1983. X-2, X-4.
1084 Powell JE, et al. Population screening for neonatal liver disease: potential for a community-based programme. J Med Screen. 2003. X-2, X-3, X-4.
1085 Pratt OE. A new approach to the treatment of phenylketonuria. J Ment Defic Res. 1980. X-4.
1086 Prince AP, McMurray MP, Buist NR. Treatment products and approaches for phenylketonuria: improved palatability and flexibility demonstrate safety, efficacy and acceptance in US clinical trials. J Inherit Metab Dis. 1997. X-4, X-5.
1087 Prince AP, Leklem JE. Vitamin B-6 status of school-aged patients with phenylketonuria. Am J Clin Nutr. 1994. X-4, X-5.
1088 Przyrembel H. Recommendations for protein and amino acid intake in phenylketonuria patients. Eur J Pediatr. 1996. X-1, X-2, X-3, X-4, X-5.
1089 Pueschel SM, et al. Neurophysiological, psychological, and nutritional investigations during discontinuation of the phenylalanine-restricted diet in children with classic phenylketonuria. J Ment Defic Res. 1983. X-3, X-4, X-5.
1090 Pueschel SM, Yeatman S. An educational and counseling program for phenylketonuric adolescent girls and their parents. Soc Work Health Care. 1977. X-4.
1091 Pueschel SM, Hum C, Andrews M. Nutritional management of the female with phenylketonuria during pregnancy. Am J Clin Nutr. 1977. X-1, X-2, X-3, X-4, X-5.
1092 Pueschel SM, Yeatman S, Hum C. Discontinuing the phenylalamine-restricted diet in young children with PKY. Psychosocial aspects. J Am Diet Assoc. 1977. X-4.
1093 Perez-Duenas B, et al. Global and regional volume changes in the brains of patients with phenylketonuria. Neurology. 2006. X-4, X-5.
1094 Perez-Duenas B, et al. Characterization of tremor in phenylketonuric patients. J Neurol. 2005. X-4, X-5.
1095 Perez-Duenas B, et al. Tetrahydrobiopterin responsiveness in patients with phenylketonuria. Clin Biochem. 2004. X-4, X-5.
1096 Perez-Duenas B, et al. New approach to osteopenia in phenylketonuric patients. Acta Paediatr. 2002. X-3, X-4, X-5.
1097 Poge AP, et al. Long-chain polyunsaturated fatty acids in plasma and erythrocyte membrane lipids of children with phenylketonuria after controlled linoleic acid intake. J Inherit Metab Dis. 1998. X-4, X-5.
1098 Qu Y, et al. Quantitative amino acid analysis using a Beckman system gold HPLC 126AA analyzer. Clin Chim Acta. 2001. X-2, X-3, X-4, X-5.
1099 Quentin CD, et al. Microanalysis with 14C-dansyl chloride of amino acids and amines in the cerebrospinal fluid of patients with phenylketonuria. I. Analysis in untreated phenylketonuria. Neuropadiatrie. 1974. X-3, X-4, X-5.
1100 Raine DN, et al. Screening for inherited metabolic disease by plasma chromatography (Scriver) in a large city. Br Med J. 1972. X-3, X-4, X-5.
1101 Raine DN. Early detection of phenylketonuria and other aminoacidopathies in a large city using plasma chromatography. Arch Dis Child. 1971. X-4, X-5.
1102 Rampini S, et al. Aromatic acids in urine of healthy infants, persistent hyperphenylalaninemia, and phenylketonuria, before and after phenylalanine load. Pediatr Res. 1974. X-4, X-5.
1103 Ramus SJ, et al. Genotype and intellectual phenotype in untreated phenylketonuria patients. Pediatr Res. 1999. X-4+.
1104 Randell EW, Lehotay DC. An automated enzymatic method on the Roche COBAS MIRA S for monitoring phenylalanine in dried blood spots of patients with phenylketonuria. Clin Biochem. 1996. X-4, X-5.
1105 Read CY. The demands of biochemical genetic disorders: a survey of mothers of children with mitochondrial disease or phenylketonuria. J Pediatr Nurs. 2003. X-1, X-2, X-4.
1106 Realmuto GM, et al. Psychiatric diagnosis and behavioral characteristics of phenylketonuric children. J Nerv Ment Dis. 1986. X-4, X-5.
1107 Reber M, Kazak AE, Himmelberg P. Phenylalanine control and family functioning in early-treated phenylketonuria. J Dev Behav Pediatr. 1987. X-4, X-5.
1108 Rebrin I, Bailey SW, Ayling JE. Activity of the bifunctional protein 4a-hydroxy-tetrahydropterin dehydratase/DCoH during human fetal development: correlation with dihydropteridine reductase activity and tetrahydrobiopterin levels. Biochem Biophys Res Commun. 1995. X-2, X-3, X-4, X-5.
1109 Rebuffat A, et al. Comparison of adeno-associated virus pseudotype 1, 2, and 8 vectors administered by intramuscular injection in the treatment of murine phenylketonuria. Hum Gene Ther. 2010. X-2, X-4.
1110 Redford-Ellis M, et al. Aminoaciduria in handicapped children: a study using ion-exchange chromatography as a screening test. Lancet. 1981. X-3, X-4, X-5.
1111 Reilly C, et al. Trace element nutrition status and dietary intake of children with phenylketonuria. Am J Clin Nutr. 1990. X-4, X-5.
1112 Reiss MJ. What sort of people do we want? The ethics of changing people through genetic engineering. Notre Dame J Law Ethics Public Policy. 1999. X-1, X-2, X-3, X-4, X-5.
1113 Rey F, et al. Long-term follow up of patients with classical phenylketonuria after diet relaxation at 5 years of age. The Paris Study. Eur J Pediatr. 1996. X-4, X-5.
1114 Rey F, Blandin-Savoja F, Rey J. Kinetics of phenylalanine disappearance after intravenous load in phenylketonuria and its genetic variants. Pediatr Res. 1979. X-4, X-5.
1115 Reynolds GP, Seakins JW, Gray DO. The uri nary excretion of 2-phenylethylamine in phenylketonuria. Clin Chim Acta. 1978. X-3, X-4, X-5.
1116 Richardson MA, et al. Investigation of the phenylalanine hydroxylase gene and tardive dyskinesia. Am J Med Genet B Neuropsychiatr Genet. 2006. X-2, X-3, X-4, X-5.
1117 Rincic MM, Rogers PJ. A low-protein, low-phenylalanine vegetable casserole. J Am Diet Assoc. 1969. X-4.
1118 Riordan FA, et al. Bloodspot 17 alpha-hydroxyprogesterone radioimmunoassay for diagnosis of congenital adrenal hyperplasia and home monitoring of corticosteroid replacement therapy. Lancet. 1984. X-2, X-3, X-4, X-5.
1121 Riva E, et al. Early breastfeeding is linked to higher intelligence quotient scores in dietary treated phenylketonuric children. Acta Paediatr. 1996. X-4, X-5.
1122 Riva E, et al. PKU-related dysgammaglobulinaemia: the effect of diet therapy on IgE and allergic sensitization. J Inherit Metab Dis. 1994. X-4, X-5.
1123 Rivera I, et al. The correlation of genotype and phenotype in Portuguese hyperphenylalaninemic patients. Mol Genet Metab. 2000. X-4.
1124 Robertson EF, et al. Management of phenylketonuria: South Australian experience of 13 cases. Med J Aust. 1976. X-4, X-5.
1125 Robertson JA, Schulman JD. Pregnancy and prenatal harm to offspring: the case of mothers with PKU. Hastings Cent Rep. 1987. X-1, X-2, X-3, X-4, X-5.
1126 Robinson M, et al. Increased risk of vitamin B12 deficiency in patients with phenylketonuria on an unrestricted or relaxed diet. J Pediatr. 2000. X-4, X-5.
1127 Robson JR. Hardness of finger nails in well-nourished and malnourished populations. Br J Nutr. 1974. X-4, X-5.
1128 Rocha JC, et al. The use of prealbumin concentration as a biomarker of nutritional status in treated phenylketonuric patients. Ann Nutr Metab. 2010. X-4, X-5.
1129 Roemer K, Johnson PA, Friedmann T. Knock-in and knock-out. Transgenes, Development and Disease: A Keystone Symposium sponsored by Genentech and Immunex, Tamarron, CO, USA, January 12-18, 1991. New Biol. 1991. X-1, X-2, X-3, X-4.
1130 Rogers S. Significance of dialysis against enzymes to the specific therapy of cancer and genetic deficiency diseases. Nature. 1968. X-2, X-3, X-4, X-5.
1131 Rohr F, et al. The Resource Mothers Study of Maternal Phenylketonuria: preliminary findings. J Inherit Metab Dis. 2004. X-4, X-5.
1132 Rohr FJ, Munier AW, Levy HL. Acceptability of a new modular protein substitute for the dietary treatment of phenylketonuria. J Inherit Metab Dis. 2001. X-4, X-5.
1133 Rohr FJ, Lobbregt D, Levy HL. Tyrosine supplementation in the treatment of maternal phenylketonuria. Am J Clin Nutr. 1998. X-3, X-4, X-5.
1134 Rohr FJ, et al. New England Maternal PKU Project: prospective study of untreated and treated pregnancies and their outcomes. J Pediatr. 1987. X-3.
1135 Rolle-Daya H, Pueschel SM, Lombroso CT. Electroencephalographic findings in children with phenylketonuria. Am J Dis Child. 1975. X-4.
1136 Romano C, Grossi-Bianchi ML, Sietti C. Phenylketonuria: detection, biological study and treatment (43 cases). Panminerva Med. 1968. X-1.
1137 Rome RM. Routine antenatal tests. Aust Fam Physician. 1978. X-4.
1138 Romstad A, et al. Molecular analysis of 16 Turkish families with DHPR deficiency using denaturing gradient gel electrophoresis (DGGE). Hum Genet. 2000. X-2, X-3, X-4, X-5.
1139 Romstad A, et al. Single-step mutation scanning of the 6-pyruvoyltetrahydropterin synthase gene in patients with hyperphenylalaninemia. Clin Chem. 1999. X-2, X-3, X-4.
1140 Rose HJ, et al. Fat intakes of children with PKU on low phenylalanine diets. J Hum Nutr Diet. 2005. X-4, X-5.
1141 Rosen FS. Latent inherited disease. Am J Med Sci. 1968. X-1, X-2, X-3, X-4, X-5.
1142 Rosner F. Judaism, genetic screening and genetic therapy. Mt Sinai J Med. 1998. X-4.
1143 Ross LJ. Developmental disabilities: genetic implications. J Obstet Gynecol Neonatal Nurs. 1994. X-1, X-4.
1144 Rosskamp R, et al. Circulating serum phenylalanine concentrations and the effect of arginine infusion on plasma levels of growth hormone and insulin in treated phenylketonuric children. Acta Endocrinol (Copenh). 1987. X-4.
1145 Roth KS. Newborn metabolic screening: a search for “nature's experiments”. South Med J. 1986. X-1, X-2, X-4.
1146 Rothenberg MB, Sills EM. Iatrogenesis: the PKU anxiety syndrome. J Am Acad Child Psychiatry. 1968. X-4.
1147 Rothova N, et al. Results of phenylalanine tolerance tests and EEG examination in patients under treatment for phenylketonuria. Acta Univ Carol Med Monogr. 1977. X-4.
1148 Rottoli A, et al. Should genetic analysis in newborn screening and a heterozygote test for hyperphenylalaninaemia be recommended? An Italian study. J Med Screen. 1999. X-4.
1149 Rottoli A, et al. Plasma chromium and manganese levels in treated PKU patients. J Inherit Metab Dis. 1986. X-4, X-5.
1151 Rouse B, et al. Maternal phenylketonuria syndrome: congenital heart defects, microcephaly, and developmental outcomes. J Pediatr. 2000. X-4, X-5.
1152 Rouse B, et al. Maternal Phenylketonuria Collaborative Study (MPKUCS) offspring: facial anomalies, malformations, and early neurological sequelae. Am J Med Genet. 1997. X-4, X-5.
1153 Rouse B, et al. Maternal phenylketonuria pregnancy outcome: a preliminary report of facial dysmorphology and major malformations. J Inherit Metab Dis. 1990. X-4, X-5.
1154 Rowley PT. Genetic screening: marvel or menace?. Science. 1984. X-4.
1155 Ruch T, Kerr D. Decreased essential amino acid requirements without catabolism in phenylketonuria and maple syrup urine disease. Am J Clin Nutr. 1982. X-3, X-4, X-5.
1157 Rupp A, Burgard P. Comparison of different indices of dietary control in phenylketonuria. Acta Paediatr. 1995. X-4, X-5.
1158 Russell FF, Mills BC, Zucconi T. Relationship of parental attitudes and knowledge to treatment adherence in children with PKU. Pediatr Nurs. 1988. X-4.
1159 Rylance G. Outcome of early detected and early treated phenylketonuria patients. Postgrad Med J. 1989. X-4, X-5.
1160 Roricht S, et al. Impairment of callosal and corticospinal system function in adolescents with early-treated phenylketonuria: a transcranial magnetic stimulation study. J Neurol. 1999. X-4, X-5.
1161 Safos S, Chang TM. Enzyme replacement therapy in ENU2 phenylketonuric mice using oral microencapsulated phenylalanine ammonia-lyase: a preliminary report. Artif Cells Blood Substit Immobil Biotechnol. 1995. X-2, X-3, X-4.
1162 Samid D, et al. Selective activity of phenylacetate against malignant gliomas: resemblance to fetal brain damage in phenylketonuria. Cancer Res. 1994. X-2, X-3, X-4.
1163 Sanjurjo P, et al. Dietary threonine reduces plasma phenylalanine levels in patients with hyperphenylalaninemia. J Pediatr Gastroenterol Nutr. 2003. X-4, X-5.
1164 Sanjurjo P, et al. Polyunsaturated fatty acid status in patients with phenylketonuria. J Inherit Metab Dis. 1994. X-4, X-5.
1165 Santillan DA, Santillan MK, Hunter SK. Cell encapsulation as a potential nondietary therapy for maternal phenylketonuria. Am J Obstet Gynecol. 2009. X-2, X-3, X-4, X-5.
1166 Sardharwalla IB, Wraith JE. A clinician's view of the mass screening of the newborn for inherited diseases: current practice and future considerations. J Inherit Metab Dis. 1989. X-1.
1167 Sarkissian CN, et al. Preclinical evaluation of multiple species of PEGylated recombinant phenylalanine ammonia lyase for the treatment of phenylketonuria. Proc Natl Acad Sci U S A. 2008. X-2, X-3, X-4.
1168 Sarkissian CN, et al. A different approach to treatment of phenylketonuria: phenylalanine degradation with recombinant phenylalanine ammonia lyase. Proc Natl Acad Sci U S A. 1999. X-1, X-2, X-3, X-4.
1169 Saudubray JM, et al. Intellectual and school performances in early-treated classical PKU patients. The French collaborative study. Eur J Pediatr. 1987. X-4, X-5.
1170 Saugstad LF. The influence of obstetric complications on the clinical picture in classical phenylketonuria. Clin Genet. 1973. X-4, X-5.
1171 Saugstad LF, Wehn M. EEG in phenylketonuria. Electroencephalogr Clin Neurophysiol. 1967. X-4, X-5.
1172 Saunders C. Phenylketonuria 1969. Postgrad Med. 1969. X-1.
1173 Sawabe K, et al. Cellular accumulation of tetrahydrobiopterin following its administration is mediated by two different processes. direct uptake and indirect uptake mediated by a methotrexate-sensitive process. Mol Genet Metab. 2005. X-2, X-3, X-4.
1174 Scaglioni S, et al. Body mass index rebound and overweight at 8 years of age in hyperphenylalaninaemic children. Acta Paediatr. 2004. X-4.
1175 Scaglioni S, et al. Pubertal maturation and classical phenylketonuria. J Inherit Metab Dis. 1986. X-1, X-4, X-5.
1176 Schadewaldt P, et al. Significance of L-alloisoleucine in plasma for diagnosis of maple syrup urine disease. Clin Chem. 1999. X-2, X-4.
1177 Schaefer F, et al. Growth and skeletal maturation in children with phenylketonuria. Acta Paediatr. 1994. X-4, X-5.
1178 Schafer EW, McKean CM. Evidence that monoamines influence human evoked potentials. Brain Res. 1975. X-3, X-4, X-5.
1179 Schallreuter KU, et al. In vivo evidence for compromised phenylalanine metabolism in vitiligo. Biochem Biophys Res Commun. 1998. X-2, X-4.
1180 Scheibenreiter S, et al. Austrian report on longitudinal outcome in phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
1182 Schlesinger P, et al. Urinary dihydroxanthopterin in the diagnosis of malignant hyperphenylalaninemia and phenylketonuria. Clin Chim Acta. 1979. X-4.
1183 Schmidt DR, et al. Treatment of infants with congenital toxoplasmosis: tolerability and plasma concentrations of sulfadiazine and pyrimethamine. Eur J Pediatr. 2006. X-2, X-4.
1184 Schmidt E, Burgard P, Rupp A. Effects of concurrent phenylalanine levels on sustained attention and calculation speed in patients treated early for phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
1186 Schmidt H, et al. Intelligence and professional career in young adults treated early for phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
1187 Schmidt H, et al. Continuation vs discontinuation of low-phenylalanine diet in PKU adolescents. Eur J Pediatr. 1987. X-4, X-5.
1188 Schneider AJ. Newborn phenylalanine/tyrosine metabolism. Implications for screening for phenylketonuria. Am J Dis Child. 1983. X-1, X-2, X-3, X-4.
1189 Schoedon G, Redweik U, Curtius HC. Purification of GTP cyclohydrolase I from human liver and production of specific monoclonal antibodies. Eur J Biochem. 1989. X-2, X-3, X-4.
1190 Schor DP. PKU and temperament. Rating children three through seven years old in PKU families. Clin Pediatr (Phila). 1983. X-4.
1191 Schuett VE, Brown ES, Michals K. Reinstitution of diet therapy in PKU patients from twenty-two US clinics. Am J Public Health. 1985. X-1, X-4, X-5.
1192 Schuett VE, Brown ES. Diet policies of PKU clinics in the United States. Am J Public Health. 1984. X-1, X-2, X-3, X-4, X-5.
1193 Schuett VE, Gurda RF, Brown ES. Diet discontinuation policies and practices of PKU clinics in the United States. Am J Public Health. 1980. X-1, X-4.
1194 Schuler A, et al. A longitudinal study of phenylketonuria based on the data of the Budapest Screening Center. Eur J Pediatr. 1996. X-4, X-5.
1195 Schulpi KH, Scarpalezou A. Triglycerides, cholesterol, HDL, LDL, and VLDL cholesterol in serum of phenylketonuric children under dietary control. Clin Pediatr (Phila). 1989. X-4.
1196 Schulpis KH, et al. Serum paraoxonase/arylesterase activities in phenylketonuric patients on diet. Eur J Clin Nutr. 2007. X-4, X-5.
1197 Schulpis KH, et al. Increased plasma adiponectin concentrations in poorly controlled patients with phenylketonuria normalize with a strict diet: evidence for catecholamine-mediated adiponectin regulation and a complex effect of phenylketonuria diet on atherogenesis risk factors. Metabolism. 2005. X-4, X-5.
1198 Schulpis KH, et al. Low total antioxidant status is implicated with high 8-hydroxy-2-deoxyguanosine serum concentrations in phenylketonuria. Clin Biochem. 2005. X-4, X-5.
1199 Schulpis KH, et al. Morning preprandial plasma ghrelin and catecholamine concentrations in patients with phenylketonuria and normal controls: evidence for catecholamine-mediated ghrelin regulation. J Clin Endocrinol Metab. 2004. X-4, X-5.
1200 Schulpis KH, et al. The association of serum lipids, lipoproteins and apolipoproteins with selected trace elements and minerals in phenylketonuric patients on diet. Clin Nutr. 2004. X-4, X-5.
1201 Schulpis KH, Kariyannis C, Papassotiriou I. Serum levels of neural protein S-100B in phenylketonuria. Clin Biochem. 2004. X-4, X-5.
1202 Schulpis KH, et al. Effect of diet on plasma total antioxidant status in phenylketonuric patients. Eur J Clin Nutr. 2003. X-4, X-5.
1203 Schulpis KH, et al. In vivo effects of high phenylalanine blood levels on Na+,K+-ATPase, Mg2+-ATPase activities and biogenic amine concentrations in phenylketonuria. Clin Biochem. 2002. X-4.
1204 Schulpis KH, Karikas GA, Papakonstantinou E. Homocysteine and other vascular risk factors in patients with phenylketonuria on a diet. Acta Paediatr. 2002. X-4, X-5.
1205 Schulpis KH, Papakonstantinou ED, Tzamouranis J. Plasma leptin concentrations in phenylketonuric patients. Horm Res. 2000. X-4.
1206 Schulpis KH, et al. Biotin recycling impairment in phenylketonuric children with seborrheic dermatitis. Int J Dermatol. 1998. X-4.
1207 Schulpis KH, et al. Elevated serum prolactin concentrations in phenylketonuric patients on a ‘loose diet’. Clin Endocrinol (Oxf). 1998. X-4, X-5.
1208 Schulpis KH, et al. Haemostatic variables in phenylketonuric children under dietary treatment. J Inherit Metab Dis. 1996. X-4, X-5.
1209 Schulpis KH, et al. Serum carnitine level in phenylketonuric children under dietary control in Greece. Acta Paediatr Scand. 1990. X-4.
1210 Schulte FJ, et al. Sleep patterns in hyperphenylalaninemia: a lesson on serotonin to be learned from phenylketonuria. Pediatr Res. 1973. X-4.
1211 Schulz B, Bremer HJ. Nutrient intake and food consumption of adolescents and young adults with phenylketonuria. Acta Paediatr. 1995. X-4, X-5.
1212 Schulze A, Mayatepek E, Hoffmann GF. Evaluation of 6-year application of the enzymatic colorimetric phenylalanine assay in the setting of neonatal screening for phenylketonuria. Clin Chim Acta. 2002. X-4.
1213 Schwahn B, et al. Decreased trabecular bone mineral density in patients with phenylketonuria measured by peripheral quantitative computed tomography. Acta Paediatr. 1998. X-4, X-5.
1214 Schweitzer-Krantz S, Burgard P. Survey of national guidelines for the treatment of phenylketonuria. Eur J Pediatr. 2000. X-1, X-2, X-3, X-4.
1215 Scriver CR. Child health, the genome project and phenylketonuria. Turk J Pediatr. 1993. X-1, X-2, X-3, X-4.
1216 Scriver CR. Screening for medical intervention: the PKU experience. Prog Clin Biol Res. 1982. X-4.
1217 Scriver CR, Clow CL. Phenylketonuria: epitome of human biochemical genetics (second of two parts). N Engl J Med. 1980. X-1, X-2, X-3, X-4.
1218 Scriver CR. Realized and potential neutralization of mutant genes in man by nutritional selection. Fed Proc. 1976. X-1, X-2, X-3, X-4.
1219 Scriver CR. Phenylketonuria: the glutamine hypothesis. N Engl J Med. 1970. X-1, X-2, X-3, X-4.
1220 Scriver CR, Katz L, Clow C. Phenylketonuria and diet. Can Med Assoc J. 1968. X-4, X-5.
1221 Seashore MR, et al. Development of guidelines for treatment of children with phenylketonuria: report of a meeting at the National Institute of Child Health and Human Development held August 15, 1995, National Institutes of Health, Bethesda, Maryland. Pediatrics. 1999. X-1, X-2, X-3, X-4.
1223 Sharma SD, et al. Development of a refractory stage in a dog model for phenylketonuria. Res Commun Chem Pathol Pharmacol. 1981. X-2, X-3, X-4.
1224 Sharman R, et al. A preliminary investigation of the role of the phenylalanine:tyrosine ratio in children with early and continuously treated phenylketonuria: toward identification of “safe” levels. Dev Neuropsychol. 2010. X-4, X-5.
1226 Shaw DW, et al. MR imaging of phenylketonuria. AJNR Am J Neuroradiol. 1991. X-3, X-4.
1227 Shaw KN, et al. Cystathioninuria. Am J Dis Child. 1967. X-1, X-2, X-3, X-4.
1228 Shedlovsky A, et al. Mouse models of human phenylketonuria. Genetics. 1993. X-2, X-3, X-4.
1229 Shen RS, et al. An enzymatic assay of plasma phenylalanine and tyrosine for the detection and management of phenylketonuria. Biochem Med. 1981. X-2, X-3, X-4.
1230 Shiloh S, St James P, Waisbren S. The development of a patient knowledge test on maternal phenylketonuria. Patient Educ Couns. 1990. X-4.
1231 Shintaku H, et al. Diagnosis of tetrahydrobiopterin (BH4) responsive mild phenylketonuria in Japan over the past 10 years. Ann Acad Med Singapore. 2008. X-4, X-5.
1232 Shintaku H, et al. Long-term treatment and diagnosis of tetrahydrobiopterin-responsive hyperphenylalaninemia with a mutant phenylalanine hydroxylase gene. Pediatr Res. 2004. X-4, X-5.
1233 Shintaku H, et al. Tetrahydrobiopterin deficiency: assay for 6-pyruvoyl-tetrahydropterin synthase activity in erythrocytes, and detection of patients and heterozygous carriers. Eur J Pediatr. 1988. X-2, X-3, X-4.
1234 Shroyer K. Our encounter with PKU. Calif Med. 1970. X-1, X-2, X-3, X-4, X-5.
1235 Shulman S, et al. Children with phenylketonuria: the interface of family and child functioning. J Dev Behav Pediatr. 1991. X-4.
1236 Sibinga MS, Friedman CJ. Diet therapy and other sources of influence on the outcome of children with phenylketonuria. Dev Med Child Neurol. 1972. X-4, X-5.
1237 Sibinga MS, Friedman CJ. Complexities of parental understanding of phenylketonuria. Pediatrics. 1971. X-4.
1238 Sibinga MS, et al. The depressing effect of diet on physical growth in phenylketonuria. Dev Med Child Neurol. 1971. X-4.
1239 Sibinga MS, et al. The effect of immobilization and sensory restriction on children with phenylketonuria. Pediatr Res. 1968. X-4.
1240 Siegel FS, et al. School behavior profile ratings of phenylketonuric children. Am J Ment Defic. 1968. X-4.
1241 Sierra C, et al. Antioxidant status in hyperphenylalaninemia. Clin Chim Acta. 1998. X-4.
1242 Sievers E, et al. Molybdenum supplementation in phenylketonuria diets: adequate in early infancy?. J Pediatr Gastroenterol Nutr. 2000. X-3, X-4.
1243 Sievers E, et al. Trace element excess in PKU diets?. J Inherit Metab Dis. 1990. X-3, X-4.
1244 Simpson D. Phenylketonuria. Midwives Chron. 1989. X-1, X-2, X-3, X-4.
1245 Simpson N, et al. Audit of neonatal screening programme for phenylketonuria and congenital hypothyroidism. Arch Dis Child Fetal Neonatal Ed. 1997. X-4.
1246 Sinai LN, et al. Phenylketonuria screening: effect of early newborn discharge. Pediatrics. 1995. X-2, X-4.
1247 Singh RH, et al. Impact of a camp experience on phenylalanine levels, knowledge, attitudes, and health beliefs relevant to nutrition management of phenylketonuria in adolescent girls. J Am Diet Assoc. 2000. X-4, X-5.
1248 Sitta A, et al. Evidence that DNA damage is associated to phenylalanine blood levels in leukocytes from phenylketonuric patients. Mutat Res. 2009. X-4, X-5.
1249 Sitta A, et al. Effect of short- and long-term exposition to high phenylalanine blood levels on oxidative damage in phenylketonuric patients. Int J Dev Neurosci. 2009. X-4, X-5.
1250 Sitta A, et al. L-carnitine blood levels and oxidative stress in treated phenylketonuric patients. Cell Mol Neurobiol. 2009. X-4, X-5.
1251 Sitta A, et al. Investigation of oxidative stress parameters in treated phenylketonuric patients. Metab Brain Dis. 2006. X-3, X-4, X-5.
1252 Smith BA, Waisman HA. Adequate phenylalanine intake for optimum growth and development in the treatment of phenylketonuria. Am J Clin Nutr. 1971. X-4, X-5.
1253 Smith HG, Smith WR, Jepson JB. Interconversions of indolic acids by bacteria and rat tissue--possible relevance to Hartnup disorder. Clin Sci. 1968. X-2, X-3, X-4.
1254 Smith I, Beasley MG, Ades AE. Effect on intelligence of relaxing the low phenylalanine diet in phenylketonuria. Arch Dis Child. 1991. X-4, X-5.
1255 Smith I, Beasley MG, Ades AE. Intelligence and quality of dietary treatment in phenylketonuria. Arch Dis Child. 1990. X-4, X-5.
1256 Smith I, Glossop J, Beasley M. Fetal damage due to maternal phenylketonuria: effects of dietary treatment and maternal phenylalanine concentrations around the time of conception (an interim report from the UK Phenylketonuria Register). J Inherit Metab Dis. 1990. X-4, X-5.
1257 Smith I, Beasley M. Intelligence and behaviour in children with early treated phenylketonuria. A report from the MRC/DHSS phenylketonuria register. Eur J Clin Nutr. 1989. X-4, X-5.
1258 Smith I, et al. Behavior disturbance in 8-year-old children with early treated phenylketonuria. Report from the MRC/DHSS Phenylketonuria Register. J Pediatr. 1988. X-4.
1259 Smith I, et al. Fetal damage despite low-phenylalanine diet after conception in a phenylketonuric woman. Lancet. 1979. X-1, X-3, X-4.
1260 Smith I, et al. Effect of stopping low-phenylalanine diet on intellectual progress of children with phenylketonuria. Br Med J. 1978. X-4, X-5.
1261 Smith I, et al. Effect of stopping the low phenylalanine diet on the intellectual progress of children with phenylketonuria. Ann Clin Biochem. 1977. X-4, X-5.
1262 Smith I, et al. Comparison of an amino acid mixture and protein hydrolysates in treatment of infants with phenylketonuria. Arch Dis Child. 1975. X-4, X-5.
1263 Smith I, Clayton BE, Wolff OH. New variant of phenylketonuria with progressive neurological illness unresponsive to phenylalanine restriction. Lancet. 1975. X-1, X-3, X-4.
1264 Smith I, Clayton BE, Wolff OH. Letter: A variant of phenylketonuria. Lancet. 1975. X-1, X-3, X-4.
1265 Smith I, Wolff OH. Natural history of phenylketonuria and influence of early treatment. Lancet. 1974. X-4, X-5.
1266 Smith I, Wolff OH. Duration of treatment of phenylketonuria. Lancet. 1974. X-1, X-2, X-3, X-4, X-5.
1267 Smith I, Lloyd J. Proceedings: Atypical phenylketonuria accompanied by a severe progressive neurological illness unresponsive to dietary treatment. Arch Dis Child. 1974. X-4, X-5.
1268 Smith ML, et al. Randomised controlled trial of tyrosine supplementation on neuropsychological performance in phenylketonuria. Arch Dis Child. 1998. X-4.
1269 Snyderman SE, et al. Plasma and cerebrospinal fluid amino acid concentrations in phenylketonuria during the newborn period. J Pediatr. 1981. X-4, X-5.
1270 Soeters RP, et al. Maternal phenylketonuria: comparison of two treated full term pregnancies. Eur J Pediatr. 1986. X-1, X-3, X-4.
1271 Solomons G, Keleske L, Opitz E. Evaluation of the effects of terminating the diet in phenylketonuria. J Pediatr. 1966. X-3, X-4, X-5.
1272 Soltan HC. PKU screening. Can Med Assoc J. 1973. X-4.
1273 Sorensen MK. A yeast-leavened, low-protein, low-electrolyte bread. J Am Diet Assoc. 1970. X-4.
1274 Spencer DA. Letter: Untreated phenylketonuria. Lancet. 1974. X-1, X-3, X-4.
1275 Sprinkle RH, Hynes DM, Konrad TR. Is universal neonatal hemoglobinopathy screening cost-effective?. Arch Pediatr Adolesc Med. 1994. X-1, X-2, X-3, X-4.
1276 St James PJ, et al. Unplanned pregnancies in young women with diabetes. An analysis of psychosocial factors. Diabetes Care. 1993. X-4.
1277 St James PS, Shapiro E, Waisbren SE. The Resource Mothers Program for Maternal Phenylketonuria. Am J Public Health. 1999. X-4, X-5.
1278 Starfield B. Motherhood and apple pie: the effectiveness of medical care for children. Milbank Mem Fund Q Health Soc. 1985. X-1, X-2, X-3, X-4, X-5.
1279 Steele S. Phenylketonuria: counseling and teaching functions of the nurse on an interdisciplinary team. Issues Compr Pediatr Nurs. 1989. X-1, X-2, X-3, X-4.
1280 Stegink LD, et al. Plasma amino acid concentrations and amino acid ratios in normal adults and adults heterozygous for phenylketonuria ingesting a hamburger and milk shake meal. Am J Clin Nutr. 1991. X-4.
1281 Stegink LD, et al. Repeated ingestion of aspartame-sweetened beverages: further observations in individuals heterozygous for phenylketonuria. Metabolism. 1990. X-3, X-4.
1282 Stegink LD, et al. Repeated ingestion of aspartame-sweetened beverage: effect on plasma amino acid concentrations in individuals heterozygous for phenylketonuria. Metabolism. 1989. X-2, X-3, X-4, X-5.
1283 Stegink LD, et al. Aspartame-sweetened beverage: effect on plasma amino acid concentrations in normal adults and adults heterozygous for phenylketonuria. J Nutr. 1987. X-3, X-4.
1284 Stegink LD, et al. Plasma phenylalanine levels in phenylketonuric heterozygous and normal adults administered aspartame at 34 mg/kg body weight. Toxicology. 1981. X-4.
1285 Stein ZA. Strategies for the prevention of mental retardation. Bull N Y Acad Med. 1975. X-1, X-2, X-3, X-4, X-5.
1286 Steiner G, et al. Plasma glutathione peroxidase after selenium supplementation in patients with reduced selenium state. Eur J Pediatr. 1982. X-4, X-5.
1287 Steiner KC, Smith HA. Survey of departments of health about PKU screening programs. Public Health Rep. 1975. X-2, X-3, X-4.
1288 Steiner KC, Smith HA. Opinions of Mississippi pediatricians, obstetricians and gynecologists relative to PKU screening and diet. J Miss State Med Assoc. 1973. X-1, X-2, X-3, X-4.
1289 Steiner KC, Smith HA. Application of cost-benefit analysis to a PKU screening program. Inquiry. 1973. X-4.
1290 Steinfeld R, et al. A hypothesis on the biochemical mechanism of BH(4)-responsiveness in phenylalanine hydroxylase deficiency. Amino Acids. 2003. X-3.
1291 Steinhausen HC. Psychological evaluation of treatment in phenylketonuria: intellectual, motor and social development. Neuropadiatrie. 1974. X-4.
1292 Stemerdink BA, et al. Behaviour and school achievement in patients with early and continuously treated phenylketonuria. J Inherit Metab Dis. 2000. X-4, X-5.
1294 Stemerdink BA, et al. Information processing deficits in children with early and continuously treated phenylketonuria?. Acta Paediatr Suppl. 1994. X-4, X-5.
1295 Stern J, Cowie V. Iherited abnormalities affecting the nervous system: genetic and psychiatric aspects. Biochem J. 1969. X-1, X-2, X-3, X-4, X-5.
1296 Stevens H. Medical legal aspects of clinical monitoring. Ann Clin Lab Sci. 1976. X-1, X-2, X-3, X-4.
1297 Steventon GB, et al. The activity of wild type and mutant phenylalanine hydroxylase with respect to the C-oxidation of phenylalanine and the S-oxidation of S-carboxymethyl-L-cysteine. Mol Genet Metab. 2009. X-2, X-3, X-4.
1298 Stewart JM, Ashley CG. Phenylketonuria. Report of the Oregon Detection and Evaluation Program. J Lancet. 1967. X-4.
1299 Stewart RM, et al. Carbohydrate metabolism in phenylketonuria. Pediatr Res. 1980. X-3, X-4.
1300 Stewart RM, et al. The pituitary-thyroid axis in adults with phenylketonuria. J Clin Endocrinol Metab. 1976. X-4.
1301 Stickle DF, et al. Effects of sterilizing gamma irradiation on bloodspot newborn screening tests and whole blood cyclosporine and tacrolimus measurements. Am J Clin Pathol. 2003. X-2, X-3, X-4.
1302 Stimson CW. Genetic aspects in the diagnosis and management of mental retardation. Arch Phys Med Rehabil. 1971. X-2, X-4.
1303 Stojiljkovic M, et al. The Missense p.S231F phenylalanine hydroxylase gene mutation causes complete loss of enzymatic activity in vitro. Protein J. 2009. X-2, X-3, X-4.
1304 Stone K. HIV in pregnancy. S D J Med. 2002. X-1, X-2, X-3, X-4.
1305 Sueoka H, Nagao M, Chiba S. Rapid mutation screening of phenylketonuria by polymerase chain reaction-linked restriction enzyme assay and direct sequence of the phenylalanine hydroxylase gene: clinical application in northern Japan and northern China. Genet Test. 2000. X-4.
1306 Sugita M, et al. Studies on the transport mechanism of aminoacids in the renal tubules. I. Studies on the mechanism of aminoaciduria from the analytical standpoint of titration curve. Jpn Circ J. 1967. X-2, X-4.
1307 Sullivan JE. Emotional outcome of adolescents and young adults with early and continuously treated phenylketonuria. J Pediatr Psychol. 2001. X-4, X-5.
1308 Sumi-Ichinose C, et al. Genetically rescued tetrahydrobiopterin-depleted mice survive with hyperphenylalaninemia and region-specific monoaminergic abnormalities. J Neurochem. 2005. X-2, X-3, X-4.
1309 Surtees R, Hyland K. L-3,4-dihydroxyphenylalanine (levodopa) lowers central nervous system S-adenosylmethionine concentrations in humans. J Neurol Neurosurg Psychiatry. 1990. X-2, X-3, X-4.
1310 Sutherland BS, Berry HK, Umbarger B. Growth and nutrition in treated phenylketonuric patients. JAMA. 1970. X-3, X-4, X-5.
1311 Sutherland BS, Umbarger B, Berry HK. The clinical management of phenylketonuria. GP. 1967. X-1.
1312 Sutnick M, Grover W, Patel M. Impairment of hepatic pyruvate metabolism in phenylketonuria. Life Sci. 1974. X-2, X-3, X-4, X-5.
1314 Swan DW. Phenylketonuria: a library study. N S Med Bull. 1972. X-4.
1315 Symula DJ, et al. A candidate mouse model for Hartnup disorder deficient in neutral amino acid transport. Mamm Genome. 1997. X-2, X-3, X-4.
1316 Szabo L, Somogyi C, Mate M. Experience based on 800,000 newborn screening tests of the Budapest Phenylketonuria Centre. Acta Paediatr Hung. 1985. X-4.
1317 Szeinberg A, Cohen BE. Early blood sampling in neonatal programs for the detection of phenylketonuria. Padiatr Padol. 1982. X-3, X-4.
1318 Szeinberg A, Cohen BE. The place of large-scale screening in the prevention of hereditary diseases. Phenylketonuria. Isr J Med Sci. 1973. X-4.
1319 Szeinberg A, et al. [Inhibition of phenylalanine hydroxylation during treatment of carcinoid syndrome with p-chlorophenylalanine]. Isr J Med Sci. 1970. X-4.
1320 Tabanlioglu D, Ersoy-Evans S, Karaduman A. Acrodermatitis enteropathica-like eruption in metabolic disorders: acrodermatitis dysmetabolica is proposed as a better term. Pediatr Dermatol. 2009. X-3, X-4.
1321 Tada K, et al. Follow-up study of a nation-wide neonatal metabolic screening program in Japan. A collaborative study group of neonatal screening for inborn errors of metabolism in Japan. Eur J Pediatr. 1984. X-4, X-5.
1322 Takahashi T, et al. Transient hyperphenylalaninaemia with a high neopterin to biopterin ratio in urine. J Inherit Metab Dis. 1985. X-2, X-3, X-4.
1323 Talkowski ME, et al. Convergent patterns of association between phenylalanine hydroxylase variants and schizophrenia in four independent samples. Am J Med Genet B Neuropsychiatr Genet. 2009. X-4.
1324 Tamimie HS. Influence of niacin and L-tryptophan on the growth depressive performance of chicks fed high levels of L-phenylalanine and L-methionine. Life Sci. 1967. X-2, X-3, X-4.
1325 Tamimie HS. Feeding chicks high levels of L-phenylalanine and L-methionine supplemented diets in the study of experimental aspects of phenylketonuria and homocystinuria. Poult Sci. 1967. X-2, X-3, X-4.
1326 Tavil B, et al. Haematological findings in children with inborn errors of metabolism. J Inherit Metab Dis. 2006. X-4, X-5.
1327 Taylor CJ, Moore G, Davidson DC. The effect of treatment on zinc, copper and calcium status in children with phenylketonuria. J Inherit Metab Dis. 1984. X-4, X-5.
1328 Taylor EH, Hommes FA. Effect of experimental hyperphenylalaninemia on myelin metabolism at later stages of brain development. Int J Neurosci. 1983. X-2, X-3, X-4.
1329 Teigen K, Froystein NA, Martinez A. The structural basis of the recognition of phenylalanine and pterin cofactors by phenylalanine hydroxylase: implications for the catalytic mechanism. J Mol Biol. 1999. X-2, X-3, X-4.
1330 Terry PO. Clinical social work roles in an integrative, interdisciplinary team: enhancing parental compliance. Soc Work Health Care. 1981. X-4.
1331 Tessari P, et al. Phenylalanine and tyrosine kinetics in compensated liver cirrhosis: effects of meal ingestion. Am J Physiol Gastrointest Liver Physiol. 2008. X-2, X-3, X-4, X-5.
1332 Thalhammer O, et al. Intellectual level (IQ) in heterozygotes for phenylketonuria (PKU). Is the PKU gene also acting by means other than phenylalanine-blood level elevation?. Hum Genet. 1977. X-4, X-5.
1333 Thompson AJ, et al. Brain MRI changes in phenylketonuria. Associations with dietary status. Brain. 1993. X-4, X-5.
1334 Thompson GN, et al. Protein metabolism in phenylketonuria and Lesch-Nyhan syndrome. Pediatr Res. 1990. X-4, X-5.
1335 Thompson GN, Halliday D. Significant phenylalanine hydroxylation in vivo in patients with classical phenylketonuria. J Clin Invest. 1990. X-4, X-5.
1336 Thony B, Blau N. Mutations in the BH4-metabolizing genes GTP cyclohydrolase I, 6-pyruvoyl-tetrahydropterin synthase, sepiapterin reductase, carbinolamine-4a-dehydratase, and dihydropteridine reductase. Hum Mutat. 2006. X-2, X-3, X-4.
1337 Thony B, Ding Z, Martinez A. Tetrahydrobiopterin protects phenylalanine hydroxylase activity in vivo: implications for tetrahydrobiopterin-responsive hyperphenylalaninemia. FEBS Lett. 2004. X-2, X-3, X-4.
1338 Thony B, et al. Retrovirus-mediated gene transfer of 6-pyruvoyl-tetrahydropterin synthase corrects tetrahydrobiopterin deficiency in fibroblasts from hyperphenylalaninemic patients. Hum Gene Ther. 1996. X-2, X-3, X-4, X-5.
1339 Thony B, et al. Human 6-pyruvoyltetrahydropterin synthase: cDNA cloning and heterologous expression of the recombinant enzyme. Biochem Biophys Res Commun. 1992. X-2, X-3, X-4.
1340 Tice KS, et al. Reproductive counselling for adolescent females with phenylketonuria. J Inherit Metab Dis. 1980. X-4.
1341 Tischler B, Lowry RB. Phenylketonuria in British Columbia, Canada. Monogr Hum Genet. 1978. X-1.
1342 Tishler PV. Phenylketonuria: therapeutic problems. Br Med J. 1969. X-1, X-2, X-3, X-4, X-5.
1343 Tiwary CM. Proposed guidelines for screening of metabolic and endocrine diseases of dependent neonates of the U.S. Armed Forces. Derived from a survey of state guidelines for neonatal screening of metabolic diseases. Clin Pediatr (Phila). 1987. X-1, X-2, X-3, X-4.
1344 Tizard J. The dietary treatment of phenylketonuria: not proven?. Dev Med Child Neurol. 1967. X-1.
1345 Tocci PM, Beber B. Anomalous phenylalanine loading responses in relation to cleft lip and cleft palate. Pediatrics. 1973. X-2, X-3, X-4, X-5.
1347 Trefz FK, et al. Significance of genotype in tetrahydrobiopterin-responsive phenylketonuria. J Inherit Metab Dis. 2009. X-4+.
1348 Trefz FK, et al. Long-term treatment of patients with mild and classical phenylketonuria by tetrahydrobiopterin. Mol Genet Metab. 2005. X-3.
1349 Trefz FK, Blau N. Potential role of tetrahydrobiopterin in the treatment of maternal phenylketonuria. Pediatrics. 2003. +. X-4.
1350 Trefz FK, Cipcic-Schmidt S, Koch R. Final intelligence in late treated patients with phenylketonuria. Eur J Pediatr. 2000. X-4, X-5.
1351 Trefz FK, et al. Genotype-phenotype correlations in phenylketonuria. Clin Chim Acta. 1993. X-4, X-5.
1352 Trefz FK, et al. Significance of the in vivo deuterated phenylalanine load for long-term phenylalanine tolerance and psycho-intellectual outcome in patients with PKU. Eur J Pediatr. 1990. X-4, X-5.
1353 Trefz FK, et al. PKU and NON-PKU hyperphenylalaninemia: differentiation, indication for therapy and therapeutic results. Acta Paediatr Jpn. 1988. X-1.
1354 Truswell AS. ABC of nutrition. Therapeutic diets. Br Med J (Clin Res Ed). 1985. X-1, X-2, X-3, X-4.
1355 Tsakiris S, et al. Reduced acetylcholinesterase activity in erythrocyte membranes from patients with phenylketonuria. Clin Biochem. 2002. X-4, X-5.
1356 Turri MO, et al. Structure, genomic localization and recombinant expression of the mouse 6-pyruvoyl-tetrahydropterin synthase gene. Biol Chem. 1998. X-2, X-3, X-4.
1357 Tyfield LA, et al. Discordant phenylketonuria phenotypes in one family: the relationship between genotype and clinical outcome is a function of multiple effects. J Med Genet. 1995. X-3, X-4.
1358 Tylek-Lemanska D, Otarzewski M, Kostyk E. Measurement of phenylalanine in blood on filter paper as a method of monitoring PKU treatment. J Med Screen. 2002. X-4, X-5.
1359 Tymstra T. False positive results in screening tests: experiences of parents of children screened for congenital hypothyroidism. Fam Pract. 1986. X-2, X-3, X-4.
1360 Ullrich K, et al. Effect of L-dopa on visual evoked potentials and neuropsychological tests in adult phenylketonuria patients. Eur J Pediatr. 1996. X-3, X-4.
1361 Uma SM, et al. Aminoacidopathies in Andhra Pradesh. report of a screening programme. J Inherit Metab Dis. 1982. X-3.
1362 Vallian S, Barahimi E, Moeini H. Phenylketonuria in Iranian population: a study in institutions for mentally retarded in Isfahan. Mutat Res. 2003. X-4.
1363 van Bakel MM, et al. Antioxidant and thyroid hormone status in selenium-deficient phenylketonuric and hyperphenylalaninemic patients. Am J Clin Nutr. 2000. X-4, X-5.
1364 van Calcar SC, et al. Improved nutritional management of phenylketonuria by using a diet containing glycomacropeptide compared with amino acids. Am J Clin Nutr. 2009. X-4, X-5.
1365 van der Meer SB, et al. Clinical outcome of long-term management of patients with vitamin B12-unresponsive methylmalonic acidemia. J Pediatr. 1994. X-2, X-3, X-4.
1366 van der Schot LW, Doesburg WH, Sengers RC. The phenylalanine response curve in relation to growth and mental development in the first year of life. Acta Paediatr Suppl. 1994. X-4, X-5.
1367 Van Duser AL. Phenylketonuria: comments. and the law. Wis Med J. 1966. X-4.
1368 van Rijn M, et al. A survey of natural protein intake in Dutch phenylketonuria patients: insight into estimation or measurement of dietary intake. J Am Diet Assoc. 2008. X-3, X-4, X-5.
1369 van Rijn M, et al. Protein metabolism in adult patients with phenylketonuria. Nutrition. 2007. X-3, X-4.
1370 van Rijn M, et al. A different approach to breast-feeding of the infant with phenylketonuria. Eur J Pediatr. 2003. X-4, X-5.
1371 van Spronsen FJ. Phenylketonuria management from an European perspective: a commentary. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
1372 van Spronsen FJ, Ahring KK, Gizewska M. PKU-what is daily practice in various centres in Europe? Data from a questionnaire by the scientific advisory committee of the European Society of Phenylketonuria and Allied Disorders. J Inherit Metab Dis. 2009. X-2, X-4, X-5.
1373 van Spronsen FJ, et al. Does impaired growth of PKU patients correlate with the strictness of dietary treatment? National Dutch PKU Steering Committee. Acta Paediatr. 1997. X-4, X-5.
1374 van Spronsen FJ, et al. Large daily fluctuations in plasma tyrosine in treated patients with phenylketonuria. Am J Clin Nutr. 1996. X-4, X-5.
1375 van Spronsen FJ, et al. Phenylketonuria: plasma phenylalanine responses to different distributions of the daily phenylalanine allowance over the day. Pediatrics. 1996. X-3, X-4.
1376 van Spronsen FJ, et al. Plasma phenylalanine and tyrosine responses to different nutritional conditions (fasting/postprandial) in patients with phenylketonuria: effect of sample timing. Pediatrics. 1993. X-3, X-4.
1377 VanZutphen KH, et al. Executive functioning in children and adolescents with phenylketonuria. Clin Genet. 2007. X-4, X-5.
1378 Varughese KI, Xuong NH, Whiteley JM. Structural and mechanistic implications of incorporating naturally occurring aberrant mutations of human dihydropteridine reductase into a rat model. Int J Pept Protein Res. 1994. X-2, X-3, X-4.
1379 Vellan EJ, Gjessing LR, Seip M. Hair amino acids in cystinosis, homocystinuria, Folling's disease and tyrosinosis. Acta Paediatr Scand. 1969. X-2.
1380 Verduci E, et al. Apolipoprotein B gene polymorphism and plasma lipid levels in phenylketonuric children. Prostaglandins Leukot Essent Fatty Acids. 2004. X-4, X-5.
1381 Verduci E, et al. Phenylalanine hydroxylase mutations and phenylalanine-tyrosine metabolism in heterozygotes for phenylalanine hydroxylase deficiency. Acta Paediatr. 2002. X-4.
1382 Verkerk PH, et al. Predictors of mean phenylalanine levels during the first five years of life in patients with phenylketonuria who were treated early. Dutch National PKU Steering Committee. Acta Paediatr Suppl. 1994. X-4, X-5.
1383 Verlinsky Y, et al. Preimplantation testing for phenylketonuria. Fertil Steril. 2001. X-2, X-3, X-4.
1384 Verlinsky Y, et al. Prepregnancy testing for single-gene disorders by polar body analysis. Genet Test. 1999. X-2, X-3, X-4.
1386 Vichinsky E, et al. Newborn screening for sickle cell disease: effect on mortality. Pediatrics. 1988. X-2, X-3, X-4.
1387 Vilaseca MA, et al. Long-chain polyunsaturated fatty acid status in phenylketonuric patients treated with tetrahydrobiopterin. Clin Biochem. 2010. X-4.
1388 Vilaseca MA, et al. Quality of dietary control in phenylketonuric patients and its relationship with general intelligence. Nutr Hosp. 2010. X-4, X-5.
1389 Vilaseca MA, et al. Controlled diet in phenylketonuria may cause serum carnitine deficiency. J Inherit Metab Dis. 1993. X-4, X-5.
1390 Vilaseca MA, Farre C, Ramon F. Phenylalanine determined in plasma with use of phenylalanine dehydrogenase and a centrifugal analyzer. Clin Chem. 1993. X-3, X-4, X-5.
1391 Vlaardingerbroek H, et al. Essential polyunsaturated fatty acids in plasma and erythrocytes of children with inborn errors of amino acid metabolism. Mol Genet Metab. 2006. X-2, X-3, X-4.
1392 Vollmer DW, Jinks DC, Guthrie R. Isocratic reverse-phase liquid chromatography assay for amino acid metabolic disorders using eluates of dried blood spots. Anal Biochem. 1990. X-2, X-3, X-4.
1393 von Strandmann EP, et al. Dimerization co-factor of hepatocyte nuclear factor 1/pterin-4alpha-carbinolamine dehydratase is necessary for pigmentation in Xenopus and overexpressed in primary human melanoma lesions. Am J Pathol. 2001. X-2, X-3, X-4.
1394 Vyborova L, et al. Psychic changes in phenylketonuric children at phenylalanine load. Act Nerv Super (Praha). 1981. X-4.
1395 Waisbren S, White DA. Screening for cognitive and social-emotional problems in individuals with PKU: tools for use in the metabolic clinic. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4, X-5.
1398 Waisbren SE, et al. Social factors and the meaning of food in adherence to medical diets: results of a maternal phenylketonuria summer camp. J Inherit Metab Dis. 1997. X-4.
1399 Waisbren SE, et al. Psychosocial factors in maternal phenylketonuria: women's adherence to medical recommendations. Am J Public Health. 1995. X-4, X-5.
1400 Waisbren SE, Zaff J. Personality disorder in young women with treated phenylketonuria. J Inherit Metab Dis. 1994. X-4, X-5.
1401 Waisbren SE, et al. The New England Maternal PKU Project: identification of at-risk women. Am J Public Health. 1988. X-4.
1402 Waisbren SE, et al. Predictors of intelligence quotient and intelligence quotient change in persons treated for phenylketonuria early in life. Pediatrics. 1987. X-4, X-5.
1403 Waisman HA. Role of hyperphenylalaninemia in pregnant women as a cause of mental retardation in offspring. Am J Obstet Gynecol. 1967. X-1.
1404 Walker V, et al. Hyperphenylalaninaemia of various types among three-quarters of a million neonates tested in a screening programme. Arch Dis Child. 1981. X-4, X-5.
1405 Wall A, et al. Phenylketonuria: management in primary care. J Fam Health Care. 2006. X-1.
1406 Wall TC, et al. Does early discharge with nurse home visits affect adequacy of newborn metabolic screening?. J Pediatr. 2003. X-4.
1407 Walter JH, White FJ. Blood phenylalanine control in adolescents with phenylketonuria. Int J Adolesc Med Health. 2004. X-4, X-5.
1408 Walter JH, et al. How practical are recommendations for dietary control in phenylketonuria?. Lancet. 2002. X-4, X-5.
1409 Walter JH, et al. Biochemical control, genetic analysis and magnetic resonance imaging in patients with phenylketonuria. Eur J Pediatr. 1993. X-4, X-5.
1410 Wang L, et al. Mutations in the regulatory domain of phenylalanine hydroxylase and response to tetrahydrobiopterin. Genet Test. 2007. X-4.
1411 Wang L, et al. Long-term outcome and neuroradiological findings of 31 patients with 6-pyruvoyltetrahydropterin synthase deficiency. J Inherit Metab Dis. 2006. X-2, X-3, X-4, X-5.
1412 Wang L, et al. Structure-based chemical modification strategy for enzyme replacement treatment of phenylketonuria. Mol Genet Metab. 2005. X-2, X-3, X-4.
1413 Wang T, et al. Founder effect of a prevalent phenylketonuria mutation in the Oriental population. Proc Natl Acad Sci U S A. 1991. X-3, X-4.
1414 Wapnir RA, Lifshitz F. Intestinal transport of aromatic amino acids, glucose and electrolytes in a patient with phenylketonuria. Clin Chim Acta. 1974. X-3.
1415 Wappner R, et al. Management of phenylketonuria for optimal outcome: a review of guidelines for phenylketonuria management and a report of surveys of parents, patients, and clinic directors. Pediatrics. 1999. X-1, X-2, X-3, X-4.
1416 Ward J. New developments in common genetic diseases. J Tenn Med Assoc. 1986. X-1.
1417 Ward RA. Communication: A comment on “application of cost-benefit analysis to a PKU screening program”. Inquiry. 1974. X-1, X-2, X-3, X-4.
1418 Wardley BL, Taitz LS. Clinical trial of a concentrated amino acid formula for older patients with phenylketonuria (Maxamum XP). Eur J Clin Nutr. 1988. X-4.
1419 Warwick WJ. Phenylketonuria and the practice of medicine. JAMA. 1969. X-1, X-2, X-3, X-4, X-5.
1421 Waters PJ, Scriver CR, Parniak MA. Homomeric and heteromeric interactions between wild-type and mutant phenylalanine hydroxylase subunits: evaluation of two-hybrid approaches for functional analysis of mutations causing hyperphenylalaninemia. Mol Genet Metab. 2001. X-2, X-3, X-4.
1422 Watkins ML, Crump EP, Hara S. Management of transient hyperphenylalaninemia and tyrosinemia in low birth weight Negro infants fed high protein diets. J Natl Med Assoc. 1971. X-4, X-5.
1423 Watson BM, Schlesinger P, Cotton RG. Dihydroxanthopterinuria in phenylketonuria and lethal hyperphenylalaninemia patients. Clin Chim Acta. 1977. X-4.
1424 Watts RW, et al. Organic acidurias and amino acidurias in the aetiology of long-term mental handicap. J Ment Defic Res. 1980. X-4.
1425 Watts RW, Purkiss P, Chalmers RA. A new variant form of phenylketonuria. Q J Med. 1979. X-3, X-4.
1426 Weetch E, Macdonald A. The determination of phenylalanine content of foods suitable for phenylketonuria. J Hum Nutr Diet. 2006. X-2, X-3, X-4.
1427 Weglage J, Moller HE, Feldmann R. Self-assessed and objective blood phenylalanine levels in patients with early treated phenylketonuria. Acta Paediatr. 2010. X-4, X-5.
1428 Weglage J, et al. Individual blood-brain barrier phenylalanine transport in siblings with classical phenylketonuria. J Inherit Metab Dis. 2002. X-3.
1430 Weglage J, et al. Normal clinical outcome in untreated subjects with mild hyperphenylalaninemia. Pediatr Res. 2001. X-4, X-5.
1433 Weglage J, et al. Intellectual, neurologic, and neuropsychologic outcome in untreated subjects with nonphenylketonuria hyperphenylalaninemia. German Collaborative Study on Phenylketonuria. Pediatr Res. 1997. X-2, X-3, X-4, X-5.
1434 Weglage J, et al. Psychosocial aspects in phenylketonuria. Eur J Pediatr. 1996. X-4, X-5.
1435 Weglage J, et al. Untreated non-phenylketonuric-hyperphenylalaninaemia: intellectual and neurological outcome. Eur J Pediatr. 1996. X-4.
1436 Weglage J, et al. Sustained attention in untreated non-PKU-hyperphenylalaninemia. J Clin Exp Neuropsychol. 1996. X-2, X-3, X-4, X-5.
1438 Weglage J, et al. No fine motor deficits in patients with untreated non-phenylketonuria hyperphenylalaninaemia. Acta Paediatr. 1996. X-2, X-3, X-4, X-5.
1440 Weglage J, Rupp A, Schmidt E. Personality characteristics in patients with phenylketonuria treated early. Pediatr Res. 1994. X-4.
1442 Weglage J, et al. Psychological and social findings in adolescents with phenylketonuria. Eur J Pediatr. 1992. X-4, X-5.
1443 Weigel C, et al. Carnitine status in early-treated children, adolescents and young adults with phenylketonuria on low phenylalanine diets. Ann Nutr Metab. 2008. X-4, X-5.
1444 Weigel C, et al. Effects of various dietary amino acid preparations for phenylketonuric patients on the metabolic profiles along with postprandial insulin and ghrelin responses. Ann Nutr Metab. 2007. X-3, X-4.
1445 Weiss DJ, et al. Dehydrogenase based reagentless biosensor for monitoring phenylketonuria. Biosens Bioelectron. 2007. X-2, X-3, X-4.
1446 Weissman A, et al. Heel-lancing in newborns: behavioral and spectral analysis assessment of pain control methods. Pediatrics. 2009. X-2, X-4.
1447 Welch JP. Children of mothers with phenylketonuria. Lancet. 1970. X-1, X-2, X-3, X-4, X-5.
1449 Wendel U, Langenbeck U. Towards self-monitoring and self-treatment in phenylketonuria--a way to better diet compliance. Eur J Pediatr. 1996. X-1, X-2, X-3, X-4.
1450 Wendel U, et al. Six-year follow up of phenylalanine intakes and plasma phenylalanine concentrations. Eur J Pediatr. 1990. X-4, X-5.
1451 White DA, Waisbren S, van Spronsen FJ. Final commentary: a new chapter. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4, X-5.
1452 White DA, et al. Age-related working memory impairments in children with prefrontal dysfunction associated with phenylketonuria. J Int Neuropsychol Soc. 2002. X-4, X-5.
1453 White JE, Kronmal RA, Acosta PB. Excess weight among children with phenylketonuria. J Am Coll Nutr. 1982. X-4.
1454 Wilcken B, et al. Expanded newborn screening: outcome in screened and unscreened patients at age 6 years. Pediatrics. 2009. X-1, X-2, X-3, X-4.
1455 Wilcken B. An introduction to nutritional treatment in inborn errors of metabolism--different disorders, different approaches. Southeast Asian J Trop Med Public Health. 2003. X-1.
1456 Wilcken B, Smith A, Brown DA. Urine screening for aminoacidopathies: is it beneficial? Results of a long-term follow-up of cases detected bny screening one millon babies. J Pediatr. 1980. X-1, X-2, X-3, X-4.
1457 Wildner M. Health economic issues of screening programmes. Eur J Pediatr. 2003. X-1, X-2, X-3, X-4.
1458 Wiles NJ, et al. Reduced disability at five years with early treatment of inflammatory polyarthritis: results from a large observational cohort, using propensity models to adjust for disease severity. Arthritis Rheum. 2001. X-2, X-3, X-4.
1459 Wiley V, Carpenter K, Wilcken B. Newborn screening with tandem mass spectrometry: 12 months' experience in NSW Australia. Acta Paediatr Suppl. 1999. X-1, X-2, X-3, X-4.
1460 Wilke BC, et al. Selenium, glutathione peroxidase (GSH-Px) and lipid peroxidation products before and after selenium supplementation. Clin Chim Acta. 1992. X-4, X-5.
1461 Williamson M, Dobson JC, Koch R. Collaborative study of children treated for phenylketonuria: study design. Pediatrics. 1977. X-1, X-2, X-3, X-4, X-5.
1462 Williamson ML, et al. Correlates of intelligence test results in treated phenylketonuric children. Pediatrics. 1981. X-4, X-5.
1463 Winter GB, Murray JJ, Goose DH. Prevalence of dental caries in phenylketonuric children. Caries Res. 1974. X-4.
1464 Wiseman A. Gene therapy for the circumvention of inborn errors of metabolism (IEM) caused by single-nucleotide-polymorphisms (SNPs). Med Hypotheses. 2004. X-1, X-2, X-3, X-4.
1465 Wolf B, Heard GS. Screening for biotinidase deficiency in newborns: worldwide experience. Pediatrics. 1990. X-1, X-2, X-3, X-4.
1466 Wolf-Novak LC, et al. Aspartame ingestion with and without carbohydrate in phenylketonuric and normal subjects: effect on plasma concentrations of amino acids, glucose, and insulin. Metabolism. 1990. X-3, X-4, X-5.
1467 Wolff OH. Controlled observations of phenylketonuric children on and during withdrawal from low phenylalanine diet. Arch Dis Child. 1968. X-3, X-4, X-5.
1468 Wong PW, et al. Glutamine in pku. N Engl J Med. 1971. X-1, X-4, X-5.
1469 Wong RG, et al. Mineral balance in treated phenylketonuric children. J Am Diet Assoc. 1970. X-4.
1470 Woo SL, et al. Molecular basis of phenylketonuria and recombinant DNA strategies for its therapy. Enzyme. 1987. X-2, X-3, X-4.
1471 Woo SL, et al. Molecular basis of phenylketonuria and potential somatic gene therapy. Cold Spring Harb Symp Quant Biol. 1986. X-1.
1472 Woo SL, et al. Prenatal diagnosis of classical phenylketonuria by gene mapping. JAMA. 1984. X-2, X-3, X-4, X-5.
1473 Wood AC Jr., Friedman CJ, Steisel IM. Psychosocial factors in phenylketonuria. Am J Orthopsychiatry. 1967. X-1.
1474 Woodring JH, Rosenbaum HD. Bone changes in phenylketonuria reassessed. AJR Am J Roentgenol. 1981. X-4.
1475 Woodside G. In defense of PKU screening. Hosp Physician. 1977. X-1.
1476 Woolf LI, et al. Arterial plasma amino acids in patients with serious postoperative infection and in patients with major fractures. Surgery. 1976. X-2, X-3, X-4.
1477 Woolf LI. Mass screening of the newborn for metabolic disease. Arch Dis Child. 1968. X-3, X-4, X-5.
1478 Woolf LI. The dietary treatment of phenylketonuria: not proven. Dev Med Child Neurol. 1967. X-1.
1479 Woolley DW, Van der Hoeven T. Serotonin deficiency in infancy as a cause of a mental defect in experimental phenylketonuria. Int J Neuropsychiatry. 1965. X-4.
1480 Wrona RM. A clinical epidemiologic study of hyperphenylalaninemia. Am J Public Health. 1979. X-4, X-5.
1481 Wu JT, et al. Manual fluorometry of phenylalanine from blood specimens collected on filter paper: a modified procedure. Clin Chem. 1979. X-2, X-3, X-4.
1482 Wuu KD, et al. Chromosomal and biochemical screening on mentally retarded school children in Taiwan. Jinrui Idengaku Zasshi. 1991. X-3, X-4.
1483 Xu K, et al. Screening for inborn errors of metabolism using gas chromatography-mass spectrometry. J Chromatogr B Biomed Sci Appl. 2001. X-1, X-2, X-3, X-4.
1484 Yalaz K, et al. Phenylketonuria in pediatric neurology practice: a series of 146 cases. J Child Neurol. 2006. X-4, X-5.
1485 Yang S, et al. A murine model for human sepiapterin-reductase deficiency. Am J Hum Genet. 2006. X-2, X-3, X-4.
1486 Yannicelli S, Ryan A. Improvements in behaviour and physical manifestations in previously untreated adults with phenylketonuria using a phenylalanine-restricted diet: a national survey. J Inherit Metab Dis. 1995. X-4, X-5.
1487 Ye J, et al. Screening for tetrahydrobiopterin deficiency among hyperphenylalaninemia patients in Southern China. Chin Med J (Engl). 2002. X-4.
1488 Yildirim S, et al. Assessment of tetrahydrobiopterin responsiveness in Turkish hyperphenylalaninemic patients. Turk J Pediatr. 2007. X-4, X-5.
1489 Yoon HR, et al. Tandem mass spectrometric analysis for disorders in amino, organic and fatty acid metabolism: two year experience in South Korea. Southeast Asian J Trop Med Public Health. 2003. X-4.
1490 Yordam N, et al. Screening for congenital hypothyroidism in Turkey. Eur J Pediatr. 1995. X-1, X-2, X-3, X-4.
1491 Yu JS, Stuckey SJ, O'Halloran MT. The dangers of dietary therapy in phenylketonuria. Med J Aust. 1970. X-1.
1492 Yu JS, Stuckey SJ, O'Halloran MT. Atypical phenylketonuria. An approach to diagnosis and management. Arch Dis Child. 1970. X-3, X-4, X-5.
1493 Yu JS, O'Halloran MT. Children of mothers with phenylketonuria. Lancet. 1970. X-1, X-2, X-3, X-4, X-5.
1494 Yu JS, O'Halloran MT. Children of mothers with phenylketonuria. Lancet. 1970. X-1, X-3, X-4, X-5.
1495 Zachara BA, et al. Red blood cell glutathione peroxidase activity as a function of selenium supplementation in dietary treated children with phenylketonuria. Biomed Biochim Acta. 1987. X-4.
1496 Zelnicek E, Podhradska J. Determination of urinary phenylpyruvic acid in phenylketonurics by enol-borate method. Clin Chim Acta. 1974. X-2, X-3, X-4, X-5.
1497 Zeman J, Bayer M, Stepan J. Bone mineral density in patients with phenylketonuria. Acta Paediatr. 1999. X-4, X-5.
1498 Zeman J, et al. Intellectual and school performance in adolescents with phenylketonuria according to their dietary compliance. The Czech-Slovak Collaborative Study. Eur J Pediatr. 1996. X-4, X-5.
1499 Zhongshu Z, et al. Clinical analysis of West syndrome associated with phenylketonuria. Brain Dev. 2001. X-4, X-5.
1500 Zorzi G, et al. Detection of sepiapterin in CSF of patients with sepiapterin reductase deficiency. Mol Genet Metab. 2002. X-2, X-3, X-4.
1501 Zorzi G, Thony B, Blau N. Reduced nitric oxide metabolites in CSF of patients with tetrahydrobiopterin deficiency. J Neurochem. 2002. X-2, X-3, X-4.
1502 Zschocke J, Hoffmann GF. PAH gene mutation analysis in clinical practice--comments on mutation analysis anticipates dietary requirements in phenylketonuria. Eur J Pediatr. 2000. X-1.
1503 Zschocke J, et al. Automated sequencing detects all mutations in Northern Irish patients with phenylketonuria and mild hyperphenylalaninaemia. Acta Paediatr Suppl. 1994. X-2, X-3, X-4.
1504 Zschocke J, et al. Non-phenylketonuria hyperphenylalaninaemia in Northern Ireland: frequent mutation allows screening and early diagnosis. Hum Mutat. 1994. X-1, X-2, X-3, X-4.
1505 Zurfluh MR, et al. Molecular genetics of tetrahydrobiopterin-responsive phenylalanine hydroxylase deficiency. Hum Mutat. 2008. X-2, X-3, X-4.
1506 Zurfluh MR, et al. Pharmacokinetics of orally administered tetrahydrobiopterin in patients with phenylalanine hydroxylase deficiency. J Inherit Metab Dis. 2006. X-4, X-5.
1507 Zurfluh MR, et al. Screening for tetrahydrobiopterin deficiencies using dried blood spots on filter paper. Mol Genet Metab. 2005. X-1, X-2, X-3, X-4.
1508 Sapropterin. Phenylketonuria: for a minority of patients. Prescrire Int. 2010. X-1, X-2, X-3, X-4.
1509 Proceedings of the International Conference on Tetrahydrobiopterin, Phenylketonuria, and Nitric Oxide Synthase, St. Moritz/Champer, Switzerland, March 23-28, 2008. J Inherit Metab Dis. 2009. X-1, X-2, X-3, X-4, X-5.
1510 Sapropterin (Kuvan) for phenylketonuria. Med Lett Drugs Ther. 2008. X-1, X-2, X-3, X-4, X-5.
1511 Phenylketonuria. Nurs Times. 2005. X-1.
1512 Phenylketonuria: from biochemistry to treatment. Proceedings of a round table. Troina, Italy, May 12-14, 1997. Abstracts. J Inherit Metab Dis. 1998. X-1, X-2, X-3, X-4, X-5.
1513 Phenylketonuria, an international survey of management over 40 years. Proceedings of a workshop. Fulda, November 16-19, 1994. Eur J Pediatr. 1996. X-1, X-2, X-3, X-4, X-5.
1515 American Academy of Pediatrics Committee on Genetics: Maternal phenylketonuria. Pediatrics. 1991. X-1, X-2, X-3, X-4, X-5.
1516 A protocol for screening for diabetic retinopathy in Europe. Retinopathy Working Party. Diabet Med. 1991. X-1, X-2, X-3, X-4.
1517 Phenylketonuria: diagnosis and management. Proceedings of a symposium. London. 17 June 1987. Postgrad Med J. 1989. X-1.
1518 Newborn screening for metabolic disorders in Australia and New Zealand: results for 1983. Human Genetics Society of Australasia Newborn Screening Committee. Med J Aust. 1985. X-4.
1519 Aspartame. Review of safety issues. Council on Scientific Affairs. JAMA. 1985. X-1, X-2, X-3, X-4.
1520 Should dietary treatment of phenylketonuria be continued after infancy?. Nutr Rev. 1985. X-1.
1521 American Academy of Pediatrics Committee on Genetics: New issues in newborn screening for phenylketonuria and congenital hypothyroidism. Pediatrics. 1982. X-1, X-2, X-3, X-4, X-5.
1522 Routine neonatal screening for phenylketonuria in the United Kingdom 1964-78. Medical Research Council Steering Committee for the MRC/DHSS Phenylketonuria Register. Br Med J (Clin Res Ed). 1981. X-4.
1523 One million babies. Med J Aust. 1979. X-1.
1524 PKU children need prolonged, rigid diet, researchers indicate. Am Fam Physician. 1978. X-1.
1525 National Health and Medical Research Council. Statements adopted at 85th session, Adelaide, June 1978. Med J Aust. 1978. X-1, X-2, X-3, X-4.
1526 Recommended guidelines for screening programs for hyperphenylalaninemia in newborn infants. Pediatrics. 1977. X-1, X-2, X-3, X-4.
1527 Editorial: Phenylketonuria--the present state. Med J Aust. 1976. X-1, X-2, X-3, X-4.
1528 American Academy of Pediatrics. Committee on Nutrition: special diets for infants with inborn errors of amino acid metabolism. Pediatrics. 1976. X-1, X-2, X-3, X-4, X-5.
1529 Effect of cotrimoxazole on the response to phenylalanine loading in man. Clin Chim Acta. 1976. X-3, X-4, X-5.
1530 Synthetic sweetners: cyclamates, saccharin, aspartame. Med Lett Drugs Ther. 1975. X-1.
1531 Massachusetts Department of Public Health. Cost-benefit analysis of newborn screening for metabolic disorders. N Engl J Med. 1974. X-4.
1532 Editorial: Embryopathy and phenylketonuria in pregnancy. Med J Aust. 1974. X-1, X-2, X-3, X-4.
1533 Editorial: The duration of treatment of phenylketonuria. Lancet. 1974. X-1, X-2, X-3, X-4.
1534 Letter: Phenylketonuria and psychosis. N Engl J Med. 1973. X-1, X-2, X-3, X-4.
1535 American Academy of Pediatrics Committee on Children with Handicaps: phenylketonuria and the phenylalaninemias of infancy. Pediatrics. 1972. X-1, X-2, X-3, X-4, X-5.
1536 Phenylketonuria: a multidisciplinary approach to management. Med J Aust. 1971. X-1.
1537 Diagnosis and treatment of metabolic errors. Can Med Assoc J. 1971. X-4, X-5.
1538 Results of dietary control in phenylketonuria. Med J Aust. 1970. X-9.
1539 Treatment of phenylketonuria. Lancet. 1970. X-1, X-2, X-3, X-4, X-5.
1540 Phenylketonuria. Br Med J. 1970. X-1, X-2, X-3, X-4, X-5.
1541 The newborn phenylketonuria screening program in Ontario. Can Med Assoc J. 1969. X-4, X-5.
1542 Phenylketonuria. Med Lett Drugs Ther. 1969. X-1+.
1543 Dietary treatment of phenylketonuria. Br Med J. 1968. X-1, X-2, X-3, X-4, X-5.
1544 Screening tests for phenylketonuria. Br Med J. 1968. X-4.
1545 Recommendations concerning PKU diagnosis, treatment and follow-up. Md State Med J. 1968. X-1, X-2, X-3, X-4.
1547 Children of phenylketonuric mothers. Med J Aust. 1967. X-9.
1548 The diet in phenylketonuria. Med J Aust. 1967. X-1.
1549 Maternal phenylketonuria. N Engl J Med. 1966. X-1, X-2, X-3, X-4, X-5.
1550 Major breakthrough in prevention of mental disease. Ir Nurs Hosp World. 1966. X-4.
1551 Pyridoxine and phenylketonuria. JAMA. 1966. X-1, X-2, X-3, X-4, X-5.
1552 Synthetic foods and deficiency states. Lancet. 1965. X-1, X-2, X-3, X-4, X-5.
1553 Portnoi P, et al. A survey of feeding practices in infants with phenylketonuria. Journal of Human Nutrition & Dietetics. 1999. X-1, X-4.
1554 MacDonald A, et al. Abnormal feeding behaviours in phenylketonuria. Journal of Human Nutrition & Dietetics. 1997. X-4.
1555 Thompson S, Rohr FJ. Alternative therapies in phenylketonuria. Topics in Clinical Nutrition. 2009. X-1, X-2, X-3, X-4, X-5.
1556 Ferguson C, Morris AM. Changes in serum phenylalanine after overnight fasts in youngsters with phenylketonuria. Journal of Human Nutrition & Dietetics. 1999. X-4, X-5.
1557 Poustie VJ, Wildgoose J. Dietary interventions for phenylketonuria. Cochrane Database of Systematic Reviews. 2010. X-1, X-2, X-3, X-4.
1558 Huntington K, Buist NRM. Medical food for treatment of inborn errors of metabolism and state legislative mandates. Topics in Clinical Nutrition. 2009. X-1, X-2, X-3, X-4.
1559 Ferguson C. Monitoring the effect of varying the distribution of phenylalanine exchanges and protein substitute on serum phenylalanine -- a preliminary study. Journal of Human Nutrition & Dietetics. 1996. X-4.
1560 Freehauf CL, et al. Network phenylketonuria conference: an effective tool for facilitating adherence to diet therapy in individuals with phenylketonuria. Topics in Clinical Nutrition. 2009. X-1, X-2, X-3, X-4.
1561 LaVoie SM, Harding CO, Gillingham MB. Normal fatty acid concentrations in young children with phenylketonuria. Topics in Clinical Nutrition. 2009. X-4, X-5.
1562 Poustie VJ, Rutherford P. Tyrosine supplementation for phenylketonuria. Cochrane Database of Systematic Reviews. 1999. X-1, X-2, X-3, X-4.
1564 Wang JB, et al. Rare diseases and legislation in China. The Lancet. 2010. X-1, X-2, X-3, X-4, X-5.
1566 Ryan AS, et al. Effects of long-chain polyunsaturated fatty acid supplementation on neurodevelopment in childhood: A review of human studies. Prostaglandins Leukotrienes and Essential Fatty Acids. 2010. X-1.
1569 Nagel-Edwards KM, Ko JY. Excipient choices for special populations. International Journal of Pharmaceutical Compounding. 2008. X-1, X-2, X-4.
1570 Park JW, et al. Tissue-specific activation of mitogen-activated protein kinases for expression of transthyretin by phenylalanine and its metabolite, phenylpyruvic acid. Experimental and Molecular Medicine. 2010. X-2, X-3, X-4.
1574 Draganov G, Peikov P, Obreshkova D. Food supplements containing L-tyrosine as a precursor of catecholamines in human health. Acta Medica Bulgarica. 2009. X-1, X-2, X-3, X-4.
1576 Martynyuk AE, van Spronsen FJ, Van der Zee EA. Animal models of brain dysfunction in phenylketonuria. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-4.
1577 Janzen D, Nguyen M. Beyond executive function: Non-executive cognitive abilities in individuals with PKU. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
1578 van Spronsen FJ, Enns GM. Future treatment strategies in phenylketonuria. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
1579 Christ SE, et al. Executive function in early-treated phenylketonuria: Profile and underlying mechanisms. Molecular Genetics and Metabolism. 2009. X-1.
1580 Matsumoto A, et al. Prognostic factors for epileptic seizures in severe motor and intellectual disabilities syndrome (SMIDS)-A clinical and electroencephalographic study. Epilepsy Research. 2009. X-2, X-3, X-4.
1582 Sapropterin: A guide to its use in hyperphenylalaninaemia. Drugs and Therapy Perspectives. 2009. X-1, X-2, X-3, X-4, X-5.
1584 Wood PA. Potential of nutrigenetics in the treatment of metabolic disorders. Expert Review of Endocrinology and Metabolism. 2008. X-1.
1585 Saldanha LG, Salem N Jr, Brenna JT. Workshop on DHA as a required nutrient: Overview. Prostaglandins Leukotrienes and Essential Fatty Acids. 2009. X-1, X-4.
1589 Zhan JY, Qin YF, Zhao ZY. Neonatal screening for congenital hypothyroidism and phenylketonuria in China. World Journal of Pediatrics. 2009. X-1, X-2, X-3, X-4.
1590 Houlton S. Niche becomes the norm. Manufacturing Chemist. 2009. X-4.
1592 Cruz NV, et al. Follow-up study of immune defects in patients with dysmorphic disorders. Annals of Allergy, Asthma and Immunology. 2009. X-2, X-4.
1596 Kyprianou N, et al. Assessment of mitochondrial respiratory chain function in hyperphenylalaninaemia. Journal of Inherited Metabolic Disease. 2009. X-4, X-5.
1597 Bailliard F, Anderson RH. Tetralogy of Fallot. Orphanet Journal of Rare Diseases. 2009. X-2, X-3, X-4.
1606 Calvo AC, et al. Anabolic function of phenylalanine hydroxylase in Caenorhabditis elegans. FASEB Journal. 2008. X-2, X-3, X-4.
1609 Dezortova M, Hajek M. <sup>1</sup>H MR spectroscopy in pediatrics. European Journal of Radiology. 2008. X-4.
1610 Bichet DG. Vasopressin Receptor Mutations in Nephrogenic Diabetes Insipidus. Seminars in Nephrology. 2008. X-1, X-2, X-3, X-4.
1611 Afzal M, et al. Genetics and public health in post-genomic era. Trends in Medical Research. 2008. X-1, X-2, X-3, X-4, X-5.
1612 Mancano MA. New drugs of 2007. Pharmacy Times. 2008. X-1.
1614 Burton BK, Kar S, Kirkpatrick P. Sapropterin. Nature Reviews Drug Discovery. 2008. X-1, X-2, X-3, X-4, X-5.
1621 Slavik S, Popovich NG. Understanding and treating Autistic behaviors. U.S. 2007. X-1, X-2, X-3, X-4, X-5.
1623 L-tyrosine. Alternative Medicine Review. 2007. X-1, X-2, X-3, X-4, X-5.
1631 Guymer RH. 2006 Council Lecture: Lancelot to the rescue: Realizing the promise of genomic medicine. Clinical and Experimental Ophthalmology. 2007. X-1, X-2, X-3, X-4, X-5.
1633 Jenkins KJ, et al. Noninherited risk factors and congenital cardiovascular defects: Current knowledge - A scientific statement from the American Heart Association Council on Cardiovascular Disease in the Young. Circulation. 2007. X-1, X-2, X-3, X-4.
1636 Hargreaves IP. Coenzyme Q<sub>10</sub> in phenylketonuria and mevalonic aciduria. Mitochondrion. 2007. X-1, X-2, X-3, X-4.
1641 Giovannini M, et al. Phenylketonuria: Dietary and therapeutic challenges. Journal of Inherited Metabolic Disease. 2007. X-1, X-2, X-3, X-4, X-5.
1642 Ohura T, et al. Clinical pictures of 75 patients with neonatal intrahepatic cholestasis caused by citrin deficiency (NICCD). Journal of Inherited Metabolic Disease. 2007. X-2, X-3, X-4.
1645 Martinez FD. Genes, environments, development and asthma: A reappraisal. European Respiratory Journal. 2007. X-1, X-2, X-3, X-4.
1647 Morgan SL, Baggott JE. Medical foods: Products for the management of chronic diseases. Nutrition Reviews. 2006. X-1, X-2, X-3, X-4.
1655 Ding Z, Georgiev P, Thony B. Administration-route and gender-independent long-term therapeutic correction of phenylketonuria (PKU) in a mouse model by recombinant adeno-associated virus 8 pseudotyped vector-mediated gene transfer. Gene Therapy. 2006. X-2, X-3, X-4.
1657 Smith BH, et al. Genetic epidemiology and primary care. British Journal of General Practice. 2006. X-1, X-2, X-3, X-4.
1662 Moritani T, et al. Diffusion-weighted imaging of acute excitotoxic brain injury. American Journal of Neuroradiology. 2005. X-1, X-2, X-3, X-4.
1673 Brunetti-Pierri N, Lee B. Gene therapy for inborn errors of liver metabolism. Molecular Genetics and Metabolism. 2005. X-1, X-2, X-3, X-4, X-5.
1677 Shah S, Chan D. Licensing highlights. IDrugs. 2005. X-1.
1679 Black H. Newborn screening report sparks debate in USA. Lancet. 2005. X-1, X-2, X-3, X-4.
1681 Hanley WB, et al. Maternal phenylketonuria collaborative study (MPKUCS) - The ‘outliers’. Journal of Inherited Metabolic Disease. 2004. X-4, X-5.
1686 Macdonald A, et al. Protein substitutes for PKU: What's new?. Journal of Inherited Metabolic Disease. 2004. X-1, X-2, X-3, X-4, X-5.
1693 Cerone R, et al. Long-term follow-up of a patient with mild tetrahydrobiopterin-responsive phenylketonuria. Molecular Genetics and Metabolism. 2004. X-3, X-4.
1699 Scarabino T, et al. White matter lesions in phenylketonuria: Evaluation with magnetic resonance imaging and magnetic resonance spectroscopy. Rivista di Neuroradiologia. 2003. X-4.
1703 Daher R, et al. A neonatal screening in Lebanon: Results of five years' experience. Annals of Saudi Medicine. 2003. X-3, X-4.
1707 Skene L, Nisselle P. Could parental refusal of newborn screening be overridden by a court?. Medicine Today. 2003. X-1, X-4.
1711 Christensen R, Jensen UB, Jensen TG. Skin genetically engineered as a bioreactor or a ‘metabolic sink’. Cells Tissues Organs. 2002. X-1, X-2, X-4.
1713 Zimmermann MB, Kohrle J. The impact of iron and selenium deficiencies on iodine and thyroid metabolism: Biochemistry and relevance to public health. Thyroid. 2002. X-1, X-2, X-3, X-4.
1715 Koch R, Guttler F, Blau N. Mental illness in mild PKU responds to biopterin. Molecular Genetics and Metabolism. 2002. X-3.
1718 D'Cunha C, Bingham W, Sankaran K. Maternal-fetal therapy part I: Medical. Perinatology. 2002. X-1.
1719 Burke W, et al. Genetic test evaluation: Information needs of clinicians, policy makers, and the public. American Journal of Epidemiology. 2002. X-1, X-2, X-4.
1721 Ristoff E, Larsson A. Oxidative stress in inborn errors of metabolism: Lessons from glutathione deficiency. Journal of Inherited Metabolic Disease. 2002. X-1, X-2, X-3, X-4, X-5.
1723 Kienzle Hagen ME, et al. Experimental hyperphenylalaninemia provokes oxidative stress in rat brain. Biochimica et Biophysica Acta - Molecular Basis of Disease. 2002. X-2, X-3, X-4.
1724 Werner-Felmayer G, Golderer G, Werner ER. Tetrahydrobiopterin biosynthesis, utilization and pharmacological effects. Current Drug Metabolism. 2002. X-1, X-2, X-3, X-4.
1725 Shintaku H. Disorders of tetrahydrobiopterin metabolism and their treatment. Current Drug Metabolism. 2002. X-1, X-2, X-3, X-4.
1727 Ramos ESM, Tanus FH, Cestari TF. Cutaneous manifestation of internal diseases in infants and children. Clinics in Dermatology. 2002. X-1, X-2, X-3, X-4, X-5.
1730 Evengard B, et al. Low incidence of toxoplasma infection during pregnancy and in newborns in Sweden. Epidemiology and Infection. 2001. X-2, X-3, X-4.
1732 Leandro P, et al. Glycerol increases the yield and activity of human phenylalanine hydroxylase mutant enzymes produced in a prokaryotic expression system. Molecular Genetics and Metabolism. 2001. X-1, X-2, X-3, X-4.
1734 Erlandsen H, Stevens RC. A structural hypothesis for BH<sub>4</sub> responsiveness in patients with mild forms of hyperphenylalaninaemia and phenylketonuria. Journal of Inherited Metabolic Disease. 2001. X-4.
1735 Gregersen N, et al. The role of chaperone-assisted folding and quality control in inborn errors of metabolism: Protein folding disorders. Journal of Inherited Metabolic Disease. 2001. X-1, X-2, X-3, X-4.
1736 Dudesek A, et al. Molecular analysis and long-term follow-up of patients with different forms of 6-pyruvoyl-tetrahydropterin synthase deficiency. European Journal of Pediatrics. 2001. X-2, X-3, X-4.
1737 van Spronsen FJ, Smit PGA, Koch R. Phenylketonuria: Tyrosine beyond the phenylalanine-restricted diet. Journal of Inherited Metabolic Disease. 2001. X-1, X-2, X-3, X-4.
1739 Denecke J, et al. Prolactin, a marker for cerebral dopamine deficiency in patients suffering from phenylketonuria (PKU)?. Journal of Inherited Metabolic Disease. 2000. X-4, X-5.
1748 Eisensmith RC, Kuzmin AI, Krougliak VA. Prospects for the treatment of phenylketonuria by gene therapy. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
1749 Moats RA, Scadeng M, Nelson MD Jr. MR imaging and spectroscopy in PKU. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1.
1750 Waisbren SE. Developmental and neuropsychological outcome in children born to mothers with phenylketonuria. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
1751 Matalon KM, et al. Congenital heart disease in maternal phenylketonuria: Effects of blood phenylalanine and nutrient intake. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-4, X-5.
1752 Dyer CA. Pathophysiology of phenylketonuria. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
1753 Hyland K. Presentation, diagnosis, and treatment of the disorders of monoamine neurotransmitter metabolism. Seminars in Perinatology. 1999. X-1, X-2, X-3, X-4.
1754 Nagatsu T, Ichinose H. Regulation of pteridine-requiring enzymes by the cofactor tetrahydrobiopterin. Molecular Neurobiology. 1999. X-1, X-2, X-4.
1755 Jochum F, et al. Is there any health risk of low dietary selenium supply in PKU-children. Nutrition Research. 1999. X-4.
1762 Thony B, et al. Hyperphenylalaninemia with high levels of 7-biopterin is associated with mutations in the PCBD gene encoding the bifunctional protein pterin-4a-carbinolamine dehydratase and transcriptional coactivator (DCoH). American Journal of Human Genetics. 1998. X-3, X-4.
1767 Hovgaard L, et al. Drug delivery studies in Caco-2 monolayers. VI. Studies of enzyme substitution therapy for phenylketonuria - A new application of Caco-2 monolayers. International Journal of Pharmaceutics. 1998. X-2, X-3, X-4.
1768 Silva LCS, et al. Evaluation of an aspartame loading test for the detection of heterozygotes for classical phenylketonuria. Clinical Genetics. 1997. X-2, X-3, X-4.
1770 Knappskog PM, et al. PKU mutation (D143G) associated with an apparent high residual enzyme activity: Expression of a kinetic variant form of phenylalanine hydroxylase in three different systems. Human Mutation. 1996. X-2, X-4.
1774 Johnen G, et al. Characterization of the wild-type form of 4a-carbinolamine dehydratase and two naturally occuring mutants associated with hyperphenylalaninemia. Proceedings of the National Academy of Sciences of the United States of America. 1995. X-2, X-3, X-4.
1777 Widhalm K, et al. Screening for biotinidase deficiency in Austria. Screening. 1995. X-2, X-3, X-4, X-5.
1780 Goldstein DS, et al. Monoaminergic effects of folinic acid, L-DOPA, and 5-hydroxytryptophan in dihydropteridine reductase deficiency. Journal of Neurochemistry. 1995. X-3, X-4.
1781 Tu JB. Theory and practice of psychopharmacogenetics. American Journal of Medical Genetics. 1994. X-1, X-2, X-3, X-4.
1784 Wachbroit RS. Distinguishing genetic disease and genetic susceptibility. American Journal of Medical Genetics. 1994. X-1, X-2, X-3, X-4.
1785 Shortland GJ, et al. Phenylalanine kinetics in sick preterm neonates with respiratory distress syndrome. Pediatric Research. 1994. X-2, X-3, X-4.
1788 Trefz F, et al. Neuropsychological and biochemical investigations in heterozygotes for phenylketonuria during ingestion of high dose aspartame (a sweetener containing phenylalanine). Human Genetics. 1994. X-4, X-5.
1791 Milstien S, Kaufman S, Sakai N. Tetrahydrobiopterin biosynthesis defects examined in cytokine-stimulated fibroblasts. Journal of Inherited Metabolic Disease. 1993. X-2, X-3, X-4.
1794 Coskun T, et al. Serum selenium levels in phenylketonuric children on low phenylalanine diet. Doga - Turkish Journal of Medical Sciences. 1993. X-4.
1795 Acosta PB, et al. Nutrition studies in treated infants with phenylketonuria. International Pediatrics. 1993. X-4.
1796 Lucas A, Baker BA, Morley RM. Hyperphenylalaninaemia and outcome in intravenously fed preterm neonates. Archives of Disease in Childhood. 1993. X-2.
1799 Standing SJ, Taylor RP. Phenylalanine: Application of a simple HPLC technique to its measurement in dried blood spots. Annals of Clinical Biochemistry. 1992. X-4.
1825 Nielsen JB, Lou HC, Guttler F. Effects of diet discontinuation and dietary tryptophan supplementation on neurotransmitter metabolism in phenylketonuria. Brain Dysfunction. 1988. X-4.
1828 Pardridge WM. Dietary phenylalanine and brain function. Journal of Applied Nutrition. 1987. X-4.
1829 Portols M, et al. Elevated serum neopterin levels in the newborn of opiate-addicted mothers and in phenylketonuric patients treated with phenylalanine-free diets. Medical Science Research. 1987. X-3, X-4, X-5.
1839 Kolodny EH. The adrenoleukodystrophy - adrenomyeloneuropathy complex: Is it treatable?. Annals of Neurology. 1987. X-2, X-3, X-4.
1844 Ledley FD, et al. Retroviral-mediated gene transfer of human phenylalanine hydroxylase into NIH 3T3 and hepatoma cells. Proceedings of the National Academy of Sciences of the United States of America. 1986. X-2, X-3, X-4.
1845 Pineault M, Chessex P, Lepage D. Total parenteral nutrition in very low birth weight infants with Travasol 10% blend C. Journal of Parenteral and Enteral Nutrition. 1986. X-2, X-4.
1846 Ziegler I, Rokos H. Pteridines and the immune response. EOS Rivista di Immunologia ed Immunofarmacologia. 1986. X-1, X-2, X-3, X-4, X-5.
1847 Caballero B, Mahon BE, Rohr FJ. Plasma amino acid levels after single-dose aspartame consumption in phenylketonuria, mild hyperphenylalaninemia, and heterozygous state for phenylketonuria. Journal of Pediatrics. 1986. X-4.
1850 Wolf B, Heard GS, Weissbecker KA. Biotinidase deficiency: Initial clinical features and rapid diagnosis. Annals of Neurology. 1985. X-1, X-2, X-3, X-4.
1851 Stewart Truswell A. Therapeutic diets. British Medical Journal. 1985. X-1, X-2, X-3, X-4, X-5.
1854 Wood JG. Aspartame and phenylketonuria. Lancet. 1985. X-4.
1855 Kitagawa T. Treatment and prenatal diagnosis of inborn errors of metabolism. Jikeikai Medical Journal. 1985. X-1, X-2, X-3, X-4.
1856 McInnes RR, Kaufman S, Warsh JJ. Biopterin synthesis defect. Treatment with L-dopa and 5-hydroxytryptophan compared with therapy with a tetrahydropterin. Journal of Clinical Investigation. 1984. X-3, X-4, X-5.
1858 Tada K. Treatment of inborn errors of metabolism. Acta Paediatrica Japonica (Overseas Edition). 1982. X-4, X-5.
1860 Casey CE, Ernest AE, Hambidge KM. Zinc absorption and low phenylalanine diets. Pediatric Research. 1980. X-4.
1861 Calvo AC, et al. Effect of pharmacological chaperones on brain tyrosine hydroxylase and tryptophan hydroxylase 2. Journal of Neurochemistry. 2010. X-2, X-3, X-4.
1862 Dericioglu N, Saygi S. Generalized seizures aggravated by levetiracetam in an adult patient with phenylketonuria. Metabolic Brain Disease. 2010. X-1, X-3, X-4.
1864 Nascimento C, et al. Polyol Additives Modulate the In Vitro Stability and Activity of Recombinant Human Phenylalanine Hydroxylase. Applied biochemistry and biotechnology ABAB. 2010. X-2, X-3, X-4.
1865 Sempere A, et al. Study of inborn errors of metabolism in urine from patients with unexplained mental retardation. Journal of Inherited Metabolic Disease. 2010. X-3, X-4.
1869 Peng ZY, et al. Arabidopsis Hormone Database: a comprehensive genetic and phenotypic information database for plant hormone research in Arabidopsis. Nucleic acids research. 2009. X-2, X-3, X-4.
1872 Walter JH, et al. Bloodspot acylcarnitine and amino acid analysis in cord blood samples: efficacy and reference data from a large cohort study. Journal of Inherited Metabolic Disease. 2009. X-3, X-4.
1873 van Spronsen FJ, Hoeksma M, Reijngoud DJ. Brain dysfunction in phenylketonuria: Is phenylalanine toxicity the only possible cause?. Journal of Inherited Metabolic Disease. 2009. X-1, X-2, X-3, X-4.
1879 Rocha JC, Martel F. Large neutral amino acids supplementation in phenylketonuric patients. Journal of Inherited Metabolic Disease. 2009. X-1, X-2, X-3, X-4, X-5.
1882 García-Cazorla A, et al. Mental retardation and inborn errors of metabolism. Journal of Inherited Metabolic Disease. 2009. X-1, X-2, X-3, X-4.
1886 Siddique RA, et al. Nutrigenomics: nutrient-gene interactions. Food reviews international. 2009. X-1, X-2, X-3, X-4.
1887 Ney DM, et al. Nutritional management of PKU with glycomacropeptide from cheese whey. Journal of Inherited Metabolic Disease. 2009. X-1, X-3, X-4.
1888 McInnis S, Clemens S, Kermode AR. The ornamental variety, Japanese striped corn, contains high anthocyanin levels and PAL specific activity: establishing the potential for development of an oral therapeutic. Plant cell reports. 2009. X-2, X-3, X-4.
1890 van Spronsen FJ, et al. Phenylalanine tolerance can already reliably be assessed at the age of 2 years in patients with PKU. Journal of Inherited Metabolic Disease. 2009. X-4, X-5.
1892 Zheng H, et al. Preparation and characterisation of the pearl oyster (Pinctada martensii) meat protein hydrolysates with a high Fischer ratio. International journal of food science & technology. 2009. X-2, X-3, X-4.
1895 Williams CP. Resources for Genetic Metabolic Dietitians and Consumers. Topics in Clinical Nutrition. 2009. X-1, X-2, X-3, X-4.
1897 Frazier DM. Tandem Mass Spectrometry Newborn Screening and Its Impact on Inborn Errors of Metabolism. Topics in Clinical Nutrition. 2009. X-2, X-3, X-4.
1898 Sarkissian CN, Gámez A, Scriver CR. What we know that could influence future treatment of phenylketonuria. Journal of Inherited Metabolic Disease. 2009. X-1, X-2, X-3, X-4, X-5.
1901 Ney DM, et al. Dietary Glycomacropeptide Supports Growth and Reduces the Concentrations of Phenylalanine in Plasma and Brain in a Murine Model of Phenylketonuria. Journal of Nutrition. 2008. X-2, X-3, X-4.
1906 Zhong YF, Butts T, Holland PWH. HomeoDB: a database of homeobox gene diversity. Evolution & development. 2008. X-1.
1910 Riccioni G, et al. Plasma Antioxidants and Asymptomatic Carotid Atherosclerotic Disease. Annals of nutrition & metabolism. 2008. X-2, X-3, X-4.
1913 Kaiser L, Allen LH. Position of the American Dietetic Association: Nutrition and Lifestyle for a Healthy Pregnancy Outcome. Journal of the American Dietetic Association. 2008. X-1, X-2, X-3, X-4.
1915 Zschocke J, Aulehla-Scholz C, Patton S. Quality of diagnostic mutation analyses for phenylketonuria. Journal of Inherited Metabolic Disease. 2008. X-1, X-2, X-3, X-4.
1916 Singh RH, Jurecki E, Rohr F. Recommendations for personalized dietary adjustments based on patient response to tetrahydrobiopterin (BH4) in phenylketonuria. Topics in Clinical Nutrition. 2008. X-1, X-2, X-3, X-4.
1918 Goldson A, et al. Screening of phenylalanine ammonia lyase in plant tissues, and retention of activity during dehydration. Journal of the science of food and agriculture. 2008. X-2, X-3, X-4.
1920 Li JT, et al. Trans-natural antisense transcripts including noncoding RNAs in 10 species: implications for expression regulation. Nucleic acids research. 2008. X-2, X-4.
1921 van Spronsen FJ, Burgard P. The truth of treating patients with phenylketonuria after childhood: The need for a new guideline. Journal of Inherited Metabolic Disease. 2008. X-1, X-2, X-3, X-4.
1922 Fodero KM, Wunderlich SM. The use of the Mini Nutrition Assessment tool to measure the nutrition status of community-dwelling seniors taking part in government-sponsored programs. Topics in Clinical Nutrition. 2008. X-1, X-2, X-3, X-4.
1923 Sauer SW. Biochemistry and bioenergetics of glutaryl-CoA dehydrogenase deficiency. Journal of Inherited Metabolic Disease. 2007. X-2, X-3, X-4.
1924 Shanaiah N, et al. Class selection of amino acid metabolites in body fluids using chemical derivatization and their enhanced ^13^C NMR. Proceedings of the National Academy of Sciences of the United States of America. 2007. X-1, X-2, X-3, X-4.
1925 Kong L, et al. CPC: assess the protein-coding potential of transcripts using sequence features and support vector machine. Nucleic acids research. 2007. X-2, X-3, X-4.
1928 Hsien TJ, Chen S. A facile HPLC method for optical purity and quantitative measurements of phenylalanine from the hydrolyzed aspartame under different pH and temperature after its derivatization with a fluorescent reagent. Amino Acids. 2007. X-2, X-3, X-4.
1930 Huemer M, et al. Growth and body composition in children with classical phenylketonuria: Results in 34 patients and review of the literature. Journal of Inherited Metabolic Disease. 2007. X-4.
1934 Matthews DE. An Overview of Phenylalanine and Tyrosine Kinetics in Humans. Journal of Nutrition. 2007. X-1, X-2, X-3, X-4.
1939 Isaacs JS, Zand DJ. Single-Gene Autosomal Recessive Disorders and Prader-Willi Syndrome: An Update for Food and Nutrition Professionals. Journal of the American Dietetic Association. 2007. X-1, X-2, X-3, X-4.
1941 Fernstrom JD, Fernstrom MH. Tyrosine, Phenylalanine, and Catecholamine Synthesis and Function in the Brain. Journal of Nutrition. 2007. X-1, X-2, X-3, X-4.
1943 Lopes DCF, Delvivo FM, Silvestre MPC. Dietary supplements for phenylketonuria: removing Phe by activated carbon. Nutrition and food science. 2006. X-2, X-3, X-4, X-5.
1944 Lopansri BK, et al. Elevated Plasma Phenylalanine in Severe Malaria and Implications for Pathophysiology of Neurological Complications. Infection and immunity IAI. 2006. X-4.
1947 Wu J, et al. KOBAS server: a web-based platform for automated annotation and pathway identification. Nucleic acids research. 2006. X-1, X-2, X-3, X-4.
1950 Loi C, et al. Effects of an immune-enhancing diet in endotoxemic rats. Nutrition. 2005. X-2.
1952 Lopes DCF, Delvivo FM, Silvestre MPC. Use of activated carbon for removing phenylalanine from reconstituted skim milk powder hydrolysates. Lebensmittel-Wissenschaft und - Technologie. 2005. X-2, X-3, X-4, X-5.
1953 Caldwell J. Pharmacogenetics and individual variation in the range of amino acid adequacy: the biological aspects. Journal of Nutrition. 2004. X-1, X-2, X-4.
1958 Spaapen LJM, Rubio-Gozalbo ME. Tetrahydrobiopterin-responsive phenylalanine hydroxylase deficiency, state of the art. Molecular Genetics and Metabolism. 2003. X-1, X-2, X-3, X-4, X-5.
1961 Lucock M, et al. The impact of phenylketonuria on folate metabolism. Molecular Genetics and Metabolism. 2002. X-4, X-5.
1962 Al-Dhalimy M, et al. Long-term therapy with NTBC and tyrosine-restricted diet in a murine model of hereditary tyrosinemia type I. Molecular Genetics and Metabolism. 2002. X-2, X-3, X-4.
1964 Matalon KM. Developments in phenylketonuria. Topics in Clinical Nutrition. 2001. X-1, X-2, X-3, X-4.
1966 Koch R, Acosta PB, Dobson JC. Two metabolic factors in causation. Mentally retarded child and his family : a multidisciplinary handbook. Richard Koch, James C, editors. 1976. X-1, X-4.
1967 Acosta PB, et al. PKU collaborative study--clinical effects of phenylalanine restricted diets. Proceedings Western Hemisphere Nutrition Congress. 1974. X-4, X-5.
1969 v Spronsen FJ, et al. Phenylketonuria: tyrosine supplementation in phenylalanine-restricted diets. American Journal of Clinical Nutrition. 2001. X-1, X-2, X-3, X-4.
1970 v Gool CJAW, v Houwelingen AC, Hornstra G. The essential fatty acid status in phenylketonuria patients under treatment. Journal of nutritional biochemistry. 2000. X-3.
1972 Sheard NF. Importance of diet in maternal phenylketonuria. Nutrition Reviews. 2000. X-1, X-2, X-3, X-4, X-5.
1974 Tomoeda K, et al. Mutations in the 4-hydroxyphenylpyruvic acid dioxygenase gene are responsible for tyrosinemia type III and hawkinsinuria. Molecular Genetics and Metabolism. 2000. X-2, X-3, X-4, X-5.
1977 Lichter-Konecki U, Hipke CM, Konecki DS. Human phenylalanine hydroxylases gene expression in kidney and other nonhepatic tissues. Molecular Genetics and Metabolism. 1999. X-2, X-3, X-4, X-5.
1978 Duran GP, et al. Necessity of complete intake of phenylalanine-free amino acid mixture for metabolic control of phenylketonuria. Journal of the American Dietetic Association. 1999. X-3, X-4.
1979 Farges MC, et al. Oral administration of a glutamine-enriched diet before or after endotoxin challenge in aged rats has limited effects. Journal of Nutrition. 1999. X-2, X-3, X-4.
1983 Endres W. Diet in phenylketonuria: how long?. Annals of nutrition & metabolism. 1998. X-1, X-2, X-3, X-4, X-5.
1984 Lock EA, et al. The effect of a low-protein diet and dietary supplementation of threonine on tyrosine and 2-(2-nitro-4-trifluoromethylbenzoyl) cyclohexane-1,3-dione-induced corneal lesions, the extent of tyrosinemia, and the activity of enzymes involved in tyrosine catabolism in the rat. Toxicology and applied pharmacology. 1998. X-2.
1985 Su CL, Austic RE. Improved model of maternal phenylketonuria in rats by use of lower dietary concentrations of alpha-methylphenylalanine and L-phenylalanine in a semipurified diet. Nutrition Research. 1998. X-2, X-3, X-4.
1986 Koch R, et al. Mild hyperphenylalaninemia and heterozygosity of the phenylalanine hydroxylase gene. Molecular Genetics and Metabolism. 1998. X-2, X-3, X-4, X-5.
1988 Prasad C, Dalton L, Levy H. Role of diet therapy in management of hereditary metabolic diseases. Nutrition Research. 1998. X-1, X-2, X-3, X-4.
1991 Velazquez A. Gene-nutrient interactions in single-gene defects and polygenic diseases: methodologic considerations. Genetic variation and dietary response. 1997. X-1, X-2, X-3, X-4.
1995 Allen JR, et al. Body protein in prepubertal children with phenylketonuria. European Journal of Clinical Nutrition. 1996. X-4.
1998 Agostoni C, Riva E, Giovannini M. Dietary fiber in weaning foods of young children. Pediatrics. 1995. X-1, X-2, X-3, X-4.
2000 Fernandez-Canon JM, Penalva MA. Fungal metabolic model for human type I hereditary tyrosinaemia. Proceedings of the National Academy of Sciences of the United States of America. 1995. X-2, X-3, X-4.
2002 Eisensmith RC, Woo SLC. Molecular genetics of phenylketonuria: from molecular anthropology to gene therapy. Advances in genetics. 1995. X-1, X-2, X-3, X-4, X-5.
2003 Acosta PB, Yannicelli S. Nutrition support of inherited disorders of amino acid metabolism. 2. Topics in Clinical Nutrition. 1995. X-1, X-2, X-3, X-4, X-5.
2005 Lajtha A, Reilly MA, Dunlop DS. Aspartame consumption: lack of effects on neural function. Journal of nutritional biochemistry. 1994. X-1, X-2, X-3, X-4, X-5.
2009 Schoeffer A, et al. Effect of dosage and timing of amino acid mixtures on nitrogen retention in patients with phenylketonuria. Journal of nutritional medicine. 1994. X-4.
2010 Bresson JL, et al. Inborn errors of metabolism: a model for the evaluation of essential amino acids requirements. Nestlé Nutrition workshop series. 1994. X-1, X-2, X-3, X-4.
2011 Potocnik U, Widhalm K. Long-term follow-up of children with classical phenylketonuria after diet discontinuation: a review. Journal of the American College of Nutrition. 1994. X-1.
2013 Beaudette T. Metabolic disorders of childhood: nutritional management. Seminars in nutrition. 1994. X-1.
2014 Miller ME, Plumeau P, Blakely E. Elevated phenylalanine concentrations in benign hyperphenylalaninemia from evaporated milk feedings. Clinical Pediatrics. 1993. X-1, X-2, X-3, X-4.
2015 Gropper SS, Chaung HC. Immune status of children with Phenylketonuria. Highlights of agricultural research. 1993. X-4.
2018 Phenylketonuria due to phenylalanine hydroxylase deficiency: an unfolding story. BMJ : British medical journal. 1993. X-1, X-2, X-3, X-4, X-5.
2020 Vasconcellos AMH, et al. Adsorption of phenylalanine from casein hydrolysates. Applied biochemistry and biotechnology. 1992. X-4.
2025 Springer MA, et al. Eosinophilia-myalgia syndrome in a child with phenylketonuria. Pediatrics. 1992. X-1, X-3, X-4.
2026 Friedman JF. Low protein food products: A cornerstone in the management of PKU. Topics in Clinical Nutrition. 1992. X-1, X-2, X-3, X-4.
2027 Brodie M. Maternal phenylketonuria: an Arkansas experience. Topics in Clinical Nutrition. 1992. X-1, X-3.
2028 Shukla TP. Nutraceutical foods. Cereal foods world. 1992. X-1, X-2, X-3, X-4.
2029 Bessman SP. Phenylketonuria--a genetic intrauterine nutritional deficiency. Nutrition & the M. 1992. X-1, X-2, X-3, X-4.
2030 Duch DS, Smith GK. Biosynthesis and function of tetrahydrobiopterin. Journal of nutritional biochemistry. 1991. X-1, X-2, X-3, X-4.
2031 Roe CR, et al. Carnitine and the organic acidurias. Nestle nutrition workshop series. 1991. X-1.
2033 Boyce RA. The dietetic implications of maternal phenylketonuria. Australian journal of nutrition and dietetics. 1991. X-1.
2034 McCabe ERB, et al. Maternal phenylketonuria. Pediatrics. 1991. X-1, X-2, X-3, X-4.
2035 Acosta PB. Phenylketonuria--impact of nutrition support on reproductive outcomes. Nutrition today. 1991. X-1, X-2, X-3, X-4, X-5.
2038 Smith I, Cook B, Beasley M. Review of neonatal screening programme for phenylketonuria. BMJ : British medical journal. 1991. X-1, X-4.
2039 Litov RE, Combs GF Jr. Selenium in pediatric nutrition. Pediatrics. 1991. X-1.
2040 Krywawych S, Haseler M, Brenton DP. Theoretical and practical aspects of preventing fetal damage in women with phenylketonuria. Nestle nutrition workshop series. 1991. X-1, X-2, X-3, X-4.
2041 Trace element intake in PKU children. Nutrition & the M. 1991. X-1, X-2, X-3, X-4, X-5.
2043 MacDonald A. Measuring clinical outcome. Journal of Human Nutrition and Dietetics. 1990. X-1, X-2, X-3, X-4.
2047 Ambulatory nutrition care: infants. Journal of the American Dietetic Association. 1989. X-1, X-2, X-3, X-4, X-5.
2048 Ambulatory Nutrition Care: pregnant women. Journal of the American Dietetic Association. 1989. X-1, X-2, X-3, X-4, X-5.
2049 Huether G. Amino acid availability and brain development: effects of nutritional and metabolic inadequacies. European Journal of Clinical Nutrition. 1989. X-1.
2051 Kaufman S. An evaluation of the possible neurotoxicity of metabolites of phenylalanine. Journal of Pediatrics. 1989. X-4.
2053 Beaudette T. Maternal nutritional status: effect on pregnancy outcome. Seminars in nutrition. 1989. X-1, X-2, X-3, X-4.
2054 Coleman M. Nutritional treatments currently under investigation in autism. Clinical nutrition. 1989. X-1, X-2, X-3, X-4.
2059 Wraith JE, Coutts J. Inborn errors of metabolism in children. Nutrition in the clinical management of disease. Dickerson John WT, Harry A, editors. 1988. X-1.
2063 Kaufman S. Classical phenylketonuria and its variants caused by defects in biopterin metabolism. UCLA symposia on molecular and cellular biology. 1987. X-1.
2066 DiLella AG, Marvit J, Woo SLC. The molecular genetics of phenylketonuria. UCLA symposia on molecular and cellular biology. 1987. X-4.
2068 Vidailhet M. Nutritional aspects of inborn errors of metabolism. Nestle nutrition workshop series. 1987. X-1, X-2, X-3, X-4.
2069 Koch R. Phenylketonuria. Annual review of nutrition. 1987. X-1, X-2, X-3, X-4, X-5.
2070 Levy HL, Waisbren SE. The PKU paradigm: the mixed results from early dietary treatment. UCLA symposia on molecular and cellular biology. 1987. X-1.
2072 Ledley FD, Woo SLC. Prospects for somatic gene therapy of phenylketonuria. UCLA symposia on molecular and cellular biology. 1987. X-2, X-3, X-4.
2073 Huether G. Regulation of the free amino acid pool of the developing brain: a lesson learned from expreimental phenylketonuria. UCLA symposia on molecular and cellular biology. 1987. X-1.
2074 Christensen HN. Role of membrane transport in interorgan amino acid flows: where do the depleted amino acids go in phenylketonuria?. UCLA symposia on molecular and cellular biology. 1987. X-2, X-4.
2076 Advantages of supplementary alanine in infants with genetic defects of amino acid metabolism. Nutrition Reviews. 1986. X-1, X-2, X-3, X-4.
2078 Laberge C, Lescault A, Tanguay RM. Hereditary tyrosinemias (type I): a new vista on tyrosine toxicity and cancer. Advances in experimental medicine and biology. 1986. X-2, X-4.
2079 Anderson K. Vitamin B-6 status of children with phenylketonuria. Nutrition reports international. 1986. X-4.
2080 When is breastfeeding contraindicated?. Nutrition & the M. 1986. X-1, X-2, X-3, X-4, X-5.
2081 Guttler F, Lou H. Aspartame may imperil dietary control of phenylketonuria. Lancet. 1985. X-1, X-2, X-3, X-4.
2083 Caballero B. Dietary management of inborn errors of amino acid metabolism. Clinical nutrition. 1985. X-1, X-4.
2084 Collins JE, Leonard JV. The dietary management of inborn errors of metabolism. Human nutrition : applied nutrition. 1985. X-1, X-4.
2085 Chan WY, Rennert OM. Genetic trace metal disturbances. Journal of the American College of Nutrition. 1985. X-1, X-2, X-3, X-4.
2086 Lou H. Large doses of tryptophan and tyrosine as potential therapeutic alternative to dietary phenylalanine restriction in phenylketonuria. Lancet. 1985. X-3, X-4, X-5.
2088 Wallen MA, Packman S. Nutrition and inborn errors of metabolism. Nutrition update. 1985. X-1, X-2, X-3, X-4.
2089 Wong LTK, Ireton CI, Davidson AGF. Personal computer program for the dietary management of phenylketonuria. Journal of the Canadian Dietetic Association. 1985. X-1, X-2, X-3, X-4.
2092 Farquhar DL, Steven F, Westwood A. Preliminary report on inverse diurnal variation of phenylalanine: implications in maternal phenylketonuria. Human nutrition : applied nutrition. 1985. X-3.
2096 Aspartame. Nutrition and food science. 1984. X-1, X-2, X-3, X-4.
2098 Franz M. Is aspartame safe?. Diabetes forecast. 1984. X-1, X-2, X-3, X-4.
2099 Cederbaum SD. Phenylketonuria. Genetic factors in nutrition. Antonio Velazquez, Hector Bourges, editors. 1984. X-1.
2103 FDA approves aspartame as soft-drink sweetener. JAMA : Journal of the American Medical Association. 1983. X-1, X-2, X-3, X-4.
2104 McCabe ERB, et al. Newborn screening for phenylketonuria: predictive validity as a function of age. Pediatrics. 1983. X-4.
2109 McCormick RD. Synthetic sweeteners--though choice limited by regulatory actions, the need remains. Processed prepared foods. 1983. X-1, X-2, X-3, X-4.
2110 Bell L, Acosta PB, Chan L. Amino acid content of low-protein recipes. Journal of the American Dietetic Association. 1982. X-2, X-3, X-4.
2113 Nutrition and pregnancy. Nutrition in practice. 1982. X-1, X-2, X-3, X-4.
2117 McSwigan JD, et al. Amelioration of maze deficits from induced hyperphenylalaninemia in adult rats using valine, isoleucine, and leucine. Behavioral and neural biology. 1981. X-2, X-3, X-4.
2118 Lo GS, et al. Biochemical and neurological effects of an experimental phenylketonuria-like condition in infant rats during the first 2 weeks after birth. American Journal of Clinical Nutrition. 1981. X-2, X-4.
2119 Lo GS, Longenecker JB. Induction of an experimental phenylketonuria-like condition in infant rats during the first 2 weeks after birth. American Journal of Clinical Nutrition. 1981. X-2, X-4.
2121 Berger LR. When should one discourage breast-feeding. Pediatrics. 1981. X-1, X-2, X-3, X-4.
2122 Atypical phenylketonuria due to dihydrobiopterin synthetase deficiency. Nutrition Reviews. 1980. X-3, X-4.
2123 Catching up on an inborn error. F.D.A. 1980. X-1.
2124 Lowe TL, et al. Detection of phenylketonuria in autistic and psychotic children. JAMA. 1980. X-3.
2129 Bijlani RL. Malnutrition and brain--the role of infections. American Journal of Clinical Nutrition. 1980. X-1, X-2, X-3, X-4.
2130 Levitsky DA, Strupp BJ. Malnutrition and tests of brain function. Nutrition and behavior. Sanford A. 1981. X-2.
2132 Berman JL. PKU--hypothesis concerning failures of screening. Journal of Pediatrics. 1980. X-1, X-2, X-3, X-4.
2133 Shaw JCL. Trace elements in the fetus and young infant. II. Copper, manganese, selenium, and chromium. American Journal of Diseases of Children. 1980. X-1, X-2, X-3, X-4.
2135 Binder J, et al. Delayed elevation of serum phenylalanine level in a breast-fed child. Pediatrics. 1979. X-3, X-4.
2137 Stegink LD, et al. Effect of aspartame loading upon plasma and erythrocyte amino acid levels in phenylketonuric heterozygotes and normal adult subjects. Journal of Nutrition. 1979. X-3, X-4.
2138 Sepe SJ, Levy HL, Mount FW. An evaluation of routine follow-up blood screening of infants for phenylketonuria. New England Journal of Medicine. 1979. X-4.
2139 Rodriguez JA, Borisy GG. Experimental phenylketonuria: Replacement of carboxyl terminal tyrosine by phenylalanine in infant rat brain tubulin. Science. 1979. X-2, X-3, X-4.
2141 Hsia YE, Levy HL, Sepe SJ. Follow-up screening for phenylketonuria. New England Journal of Medicine. 1979. X-1, X-4.
2142 The growing problems of phenylketonuria. Lancet. 1979. X-1, X-2, X-3, X-4.
2143 Kirk TR, Allen RJ. Hyperphenylalaninemia and pregnancy. Lancet. 1979. X-1, X-2, X-3, X-4, X-5.
2147 Bessman SP. The Justification Theory: The essential nature of the non-essential amino acids. Nutrition Reviews. 1979. X-1, X-2, X-3, X-4.
2148 Buist NRM, et al. Maternal phenylketonuria. Lancet. 1979. X-1, X-2, X-3, X-4, X-5.
2150 Nielsen KB, Wamberg E, Weber J. Successful outcome of pregnancy in a phenylketonuric woman after low-phenylalanine diet introduced before conception. Lancet. 1979. X-1, X-3, X-4.
2151 Reyzer N. Diagnosis: PKU. American journal of nursing. 1978. X-1, X-2, X-3, X-4.
2152 Drop in IQ seen among children taken off PKU diet. Medical world news. 1978. X-1, X-4, X-5.
2153 Kaufman S, et al. Hyperphenylalaninemia due to a deficiency of biopterin--a variant form of phenylketonuria. New England Journal of Medicine. 1978. X-3, X-4.
2156 Weininger J, Briggs GM. Nutrition update, 1978. Journal of nutrition education. 1978. X-1, X-2, X-3.
2157 Nyham WL. Nutritional treatment of children with inborn errors of metabolism. 1978. X-1.
2160 Knox WE. Something's new in PKU. New England Journal of Medicine. 1978. X-1, X-2, X-3, X-4.
2166 Rothman KJ, Pueschel SN. Birthweight of children with phenylketonuria. Pediatrics. 1976. X-4.
2167 Duncan P. The dietary treatment of two pregnant PKU women. 1976. X-3.
2170 Graves MM, et al. The efficacy of adherence interventions for chronically ill children: A meta-analytic review. Journal of Pediatric Psychology. 2010. X-1.
2171 Siegel MS, Smith WE. Psychiatric features in children with genetic syndromes: Toward functional phenotypes. Child and Adolescent Psychiatric Clinics of North America. 2010. X-1, X-2, X-3, X-4.
2172 Leu-Semenescu S, et al. Sleep and rhythm consequences of a genetically induced loss of serotonin. Sleep: Journal of Sleep and Sleep Disorders Research. 2010. X-2, X-3, X-4.
2173 Slaughter JL, et al. Utilization of blood spot testing for metabolic-genetic disorders in Honduras: Is it time for newborn screening?. Journal of Child Neurology. 2010. X-2, X-3, X-4.
2174 Hebebrand J, et al. Child and adolescent psychiatric genetics. European Child & Adolescent Psychiatry. 2010. X-1, X-2, X-3, X-4.
2176 Brumback RA. The Silver Jubilee: Journal of Child Neurology turns 25. Journal of Child Neurology. 2010. X-1, X-2, X-3, X-4, X-5.
2177 Schnetz-Boutaud NC, et al. Examination of tetrahydrobiopterin pathway genes in autism. Genes, Brain & Behavior. 2009. X-1, X-2, X-3, X-4.
2178 Doehring A, et al. Cross-sectional assessment of the consequences of a GTP cyclohydrolase 1 haplotype for specialized tertiary outpatient pain care. The Clinical Journal of Pain. 2009. X-2, X-3, X-4.
2179 Evans S, et al. The impact of visual media to encourage low protein cooking in inherited metabolic disorders. Journal of Human Nutrition and Dietetics. 2009. X-4.
2181 He B, et al. Association of genetic polymorphisms in the type II deiodinase gene with bipolar disorder in a subset of Chinese population. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2009. X-2, X-3, X-4.
2182 Porta F, et al. Dopamine agonists in 6-pyruvoyl tetrahydropterin synthase deficiency. Neurology. 2009. X-2, X-3, X-4.
2183 Müller U. The monogenic primary dystonias. Brain: A Journal of Neurology. 2009. X-1, X-2, X-3, X-4.
2184 van Spronsen F. Adults with late diagnosed PKU and severe challenging behaviour. Journal of Neurology, Neurosurgery & Psychiatry. 2009. X-1, X-2, X-3, X-4.
2188 Albrecht J, Garbade SF, Burgard P. Neuropsychological speed tests and blood phenylalanine levels in patients with phenylketonuria: A meta-analysis. Neuroscience and Biobehavioral Reviews. 2009. X-1.
2189 Matson JL, Boisjoli JA. The token economy for children with intellectual disability and/or autism: A review. Research in Developmental Disabilities. 2009. X-1, X-2, X-3, X-4.
2190 Rowbotham I, et al. Cognitive control in adolescents with neurofibromatosis type 1. Neuropsychology. 2009. X-2, X-4.
2191 Vlahou CH, et al. Age and body satisfaction predict diet adherence in adolescents with inflammatory bowel disease. Journal of Clinical Psychology in Medical Settings. 2008. X-2, X-3, X-4.
2192 Bray MS. Implications of gene-behavior interactions: Prevention and intervention for obesity. Obesity. Special Issue: Gene-Nutrition and Gene-Physical Activity Interactions in the Etiology of Obesity. 2008. X-1, X-2, X-3, X-4.
2195 Marovic S, Snyders F. Addressing complexities of medical noncompliance in serious childhood illness: Collaborating at the interface of providers, families, and health care systems. Families, Systems, & Health. 2008. X-1, X-2, X-3, X-4.
2197 Kahana S, Drotar D, Frazier T. Meta-analysis of psychological interventions to promote adherence to treatment in pediatric chronic health conditions. Journal of Pediatric Psychology. 2008. X-1, X-2, X-3, X-4.
2198 DeRoche K, Welsh M. Twenty-five years of research on neurocognitive outcomes in early-treated phenylketonuria: Intelligence and executive function. Developmental Neuropsychology. 2008. X-1, X-2, X-3, X-4.
2199 Gassió R, et al. Cognitive functions and the antioxidant system in phenylketonuric patients. Neuropsychology. 2008. X-4, X-5.
2200 Crespi B, Badcock C. The evolutionary social brain: From genes to psychiatric conditions. Behavioral and Brain Sciences. 2008. X-1, X-2, X-3, X-4.
2201 Ryan MM, et al. Dietary L-tyrosine supplementation in nemaline myopathy. Journal of Child Neurology. 2008. X-2, X-3, X-4.
2202 Echenne B, et al. Monoamine metabolism study in severe, early-onset epilepsy in childhood. Epileptic Disorders. 2008. X-2, X-3, X-4.
2203 Wolf JM, Miller GE, Chen E. Parent psychological states predict changes in inflammatory markers in children with asthma and healthy children. Brain, Behavior, and Immunity. 2008. X-2, X-3, X-4.
2204 Gold AP, Rapin I. In memoriam: Niels L. Low, MD (1916-2007). Journal of Child Neurology. 2008. X-1, X-2, X-3, X-4.
2206 Koch R, Verma S, Gilles FH. Neuropathology of a 4-month-old infant born to a woman with phenylketonuria. Developmental Medicine & Child Neurology. 2008. X-1, X-2, X-3, X-4.
2207 McHugh PC, et al. Proteomic analysis of embryonic stem cell-derived neural cells exposed to the antidepressant paroxetine. Journal of Neuroscience Research. 2008. X-1, X-2, X-3, X-4.
2208 Willis GL. Parkinson's disease as a neuroendocrine disorder of circadian function: Dopamine-melatonin imbalance and the visual system in the genesis and progression of the degenerative process. Reviews in the Neurosciences. 2008. X-1, X-2, X-3, X-4.
2209 Ogawa A, et al. A case of 6-pyruvoyl-tetrahydropterin synthase deficiency demonstrates a more significant correlation of L-Dopa dosage with serum prolactin levels than CSF homovanillic acid levels. Brain & Development. 2008. X-1, X-2, X-3, X-4.
2210 Brandies R, Yehuda S. The possible role of retinal dopaminergic system in visual performance. Neuroscience and Biobehavioral Reviews. 2008. X-1, X-4.
2211 Olsson GM, et al. The Adolescent Adjustment Profile (AAP) in comparisons of patients with obesity, phenylketonuria or neurobehavioural disorders. Nordic Journal of Psychiatry. 2008. X-4.
2212 Hoffer LJ. Vitamin therapy in schizophrenia. Israel Journal of Psychiatry and Related Sciences. 2008. X-1, X-2, X-3, X-4.
2213 Fisher EB, et al. Healthy coping, negative emotions, and diabetes management: A systematic review and appraisal. The Diabetes Educator. 2007. X-1, X-2, X-3, X-4.
2214 Diamond A. Consequences of variations in genes that affect dopamine in prefrontal cortex. Cerebral Cortex. Special Issue: Dynamic landscape of the frontal lobe: A tribute to Patricia S. Goldman-Rakic. 2007. X-1, X-2, X-3, X-4.
2215 Steiner CE, et al. Genotype and natural history in unrelated individuals with phenylketonuria and autistic behavior. Arquivos de Neuro-Psiquiatria. 2007. X-3.
2216 Moyle JJ, et al. Meta-analysis of neuropsychological symptoms of adolescents and adults with PKU. Neuropsychology Review. 2007. X-1, X-4.
2217 Tanaka Y, et al. Early initiation of L-dopa therapy enables stable development of executive function in tetrahydrobiopterin (BH4) deficiency. Developmental Medicine & Child Neurology. 2007. X-3.
2218 Burton H, et al. Review of specialist dietitian services in patients with inherited metabolic disease in the United Kingdom. Journal of Human Nutrition and Dietetics. 2007. X-1, X-2, X-4.
2220 Friedman J, et al. Dopa-responsive hypersomnia and mixed movement disorder due to sepiapterin reductase deficiency. Neurology. 2006. X-2, X-3, X-4.
2222 Russell VA, et al. Response variability in attention-deficit/hyperactivity disorder: A neuronal and glial energetics hypothesis. Behavioral and Brain Functions. 2006. X-2, X-4.
2223 Hewitt P, Cottle M, Coleman C. The Long-Term Use of a Low-Phenylalanine Diet in Late-Treated Phenylketonuria: A Single Case Report. Journal of Applied Research in Intellectual Disabilities. 2006. X-1, X-3.
2224 Bjerkensted L, et al. Support for limited brain availability of tyrosine in patients with schizophrenia. International Journal of Neuropsychopharmacology. 2006. X-1, X-2, X-3, X-4.
2225 Farrow C, Blissett J. Breast-feeding, maternal feeding practices and mealtime negativity at one year. Appetite. 2006. X-4.
2226 Van Hove JLK, et al. Expanded motor and psychiatric phenotype in autosomal dominant Segawa syndrome due to GTP cyclohydrolase deficiency. Journal of Neurology, Neurosurgery & Psychiatry. 2006. X-2, X-3, X-4.
2227 Watson MS. Current status of newborn screening: Decision-making about the conditions to include in screening programs. Mental Retardation and Developmental Disabilities Research Reviews. 2006. X-1, X-2, X-3, X-4.
2228 Therrell BL, Hannon WH. National evaluation of US newborn screening system components. Mental Retardation and Developmental Disabilities Research Reviews. 2006. X-1, X-2, X-3, X-4.
2229 Brosco JP, Seider MI, Dunn AC. Universal newborn screening and adverse medical outcomes: A historical note. Mental Retardation and Developmental Disabilities Research Reviews. 2006. X-1, X-4.
2230 Richardson MA, et al. Evidence for a tetrahydrobiopterin deficit in schizophrenia. Neuropsychobiology. 2005. X-2, X-3, X-4.
2232 Neville BGR, et al. Sepiapterin reductase deficiency: A congenital dopa-responsive motor and cognitive disorder. Brain: A Journal of Neurology. 2005. X-2, X-3, X-4.
2234 Buizer AI, et al. Visuomotor control in survivors of childhood acute lymphoblastic leukemia treated with chemotherapy only. Journal of the International Neuropsychological Society. 2005. X-2, X-4.
2236 Kerruish NJ, Robertson SP. Newborn screening: New developments, new dilemmas. Journal of Medical Ethics: Journal of the Insitute of Medical Ethics. 2005. X-1, X-4.
2238 Rose SA, Feldman JF, Jankowski JJ. The structure of infant cognition at 1 year. Intelligence. 2005. X-2, X-4, X-5.
2239 Wiesel FA, et al. Kinetics of tyrosine transport and cognitive functioning in schizophrenia. Schizophrenia Research. 2005. X-2, X-3, X-4.
2240 Blissett J, et al. Maternal Core Beliefs and Children's Feeding Problems. International Journal of Eating Disorders. 2005. X-1, X-2, X-4.
2241 Griffiths P, et al. Speed of decision-making and set-switching: Subtle executive deficits in children with treated phenylketonuria. Educational and Child Psychology. 2005. X-4, X-5.
2242 Kelly CB, et al. The MTHFR C677T polymorphism is associated with depressive episodes in patients from Northern Ireland. Journal of Psychopharmacology. 2004. X-2, X-3, X-4.
2243 DiMatteo MR. The role of effective communication with children and their families in fostering adherence to pediatric regimens. Patient Education and Counseling. Special Issue: Educating and Counseling Children about Physical Health. 2004. X-1, X-2, X-3, X-4.
2246 Finger S, Christ SE, Pearl S. Buck and Phenylketonuria (PKU). Journal of the History of the Neurosciences. 2004. X-1, X-2, X-3, X-4.
2247 Kao CD, et al. Subtle brain dysfunction in treated 6-pyruvoyl-tetrahydropterin synthase deficiency: Relationship to motor tasks and neurophysiological tests. Brain & Development. 2004. X-2, X-4, X-5.
2248 Mathews CA, et al. Genetic studies of neuropsychiatric disorders in Costa Rica: A model for the use of isolated populations. Psychiatric Genetics. 2004. X-1, X-2, X-3, X-4.
2249 Henderson CM. Genetically-Linked Syndromes in Intellectual Disabilities. Journal of Policy and Practice in Intellectual Disabilities. 2004. X-1, X-2, X-3, X-4.
2250 Pelletier S, Dorval M. Predictive Genetic Testing Raises New Professional Challenges for Psychologists. Canadian Psychology/Psychologie canadienne. 2004. X-1, X-4.
2251 Richardson MA, et al. Branched Chain Amino Acid Treatment of Tardive Dyskinesia in Children and Adolescents. Journal of Clinical Psychiatry. 2004. X-2, X-3, X-4.
2252 Rose SA, Feldman JF, Jankowski JJ. Dimensions of cognition in infancy. Intelligence. 2004. X-2, X-4.
2255 Casanova MF, Araque JM. Mineralization of the basal ganglia: implications for neuropsychiatry, pathology and neuroimaging. Psychiatry Research. 2003. X-1.
2256 Blau N, et al. Cerebrospinal fluid pterins and folates in Aicardi-Goutières syndrome: A new phenotype. Neurology. 2003. X-2, X-3, X-4.
2257 Poplawski NK. Investigating intellectual disability: A genetic perspective. Journal of Paediatrics and Child Health. 2003. X-1, X-4.
2258 Fitzgerald B, et al. Studio sul trattamento dietetico di adulti con fenilchetonuria non trattata e grave disabilità intellettiva. Giornale Italiano delle Disabilita. 2003. X-3, X-4.
2260 Szydlo D, van Wattum PJ, Woolston J. Psychological aspects of diabetes mellitus. Child and Adolescent Psychiatric Clinics of North America. 2003. X-1, X-2, X-3, X-4.
2263 Agostoni C, et al. Plasma long-chain polyunsaturated fatty acids and neurodevelopment through the first 12 months of life in phenylketonuria. Developmental Medicine & Child Neurology. 2003. X-4, X-5.
2264 Bergqvist AGC, et al. Selenium deficiency associated with cardiomyopathy: A complication of the ketogenic diet. Epilepsia. 2003. X-2, X-3, X-4.
2265 Richardson MA, et al. Phenylalanine hydroxylase gene in psychiatric patients: Screening and functional assay of mutations. Biological Psychiatry. 2003. X-2, X-3, X-4.
2266 Kalter H. Teratology in the 20th century Environmental causes of Congenital malformations in humans and how their environmental causes were established. Neurotoxicology and Teratology. Special Issue: Teratology in the twentieth century. 2003. X-1, X-2, X-3, X-4.
2267 Christ SE. Asbjørn Følling and the Discovery of Phenylketonuria. Journal of the History of the Neurosciences. 2003. X-1, X-2, X-3, X-4.
2268 Giżewska M, et al. Different presentations of late-detected phenylketonuria in two brothers with the same R408W/R111X genotype in the PAH gene. Journal of Intellectual Disability Research. 2003. X-1, X-3.
2269 Barendregt M. Genetic explanation in psychology. Journal of Mind and Behavior. 2003. X-1, X-2, X-3, X-4.
2270 Liem DG, Mennella JA. Sweet and sour preferences during childhood: Role of early experiences. Developmental Psychobiology. 2002. X-2, X-4.
2271 Swoboda KJ, Hyland K. Diagnosis and treatment of neurotransmitter-related disorders. Neurologic Clinics. 2002. X-1, X-2, X-3, X-4.
2273 Huijbregts SCJ, et al. The neuropsychological profile of early and continuously treated phenylketonuria: Orienting, vigilance, and maintenance versus manipulation-functions of working memory. Neuroscience and Biobehavioral Reviews. 2002. X-4, X-5.
2274 Mennella JA, Beauchamp GK. Flavor experiences during formula feeding are related to preferences during childhood. Early Human Development. 2002. X-2, X-3, X-4.
2276 Ortega AN, et al. Childhood asthma, chronic illness, and psychiatric disorders. Journal of Nervous and Mental Disease. 2002. X-4.
2277 Gijsman HJ, et al. A dose-finding study on the effects of branch chain amino acids on surrogate markers of brain dopamine function. Psychopharmacology. 2002. X-2, X-3, X-4.
2280 Steyaert J, Fryns JP. Psychiatric genetics: The case of single gene disorders. European Child & Adolescent Psychiatry. 2002. X-1, X-2, X-3, X-4.
2282 Kasim S, et al. Phenylketonuria presenting in adulthood as progressive spastic paraparesis with dementia. Journal of Neurology, Neurosurgery & Psychiatry. 2001. X-3, X-4.
2284 Hahn H, et al. Neurologic and psychiatric manifestations in a family with a mutation in exon 2 of the guanosine triphosphate-cyclohydrolase gene. Archives of Neurology. 2001. X-2, X-3, X-4.
2285 White DA, et al. Deficits in memory strategy use related to prefrontal dysfunction during early development: Evidence from children with phenylketonuria. Neuropsychology. 2001. X-4, X-5.
2286 Mackner LM, McGrath AM, Stark LJ. Dietary recommendations to prevent and manage chronic pediatric health conditions: Adherence, intervention, and future directions. Journal of Developmental and Behavioral Pediatrics. 2001. X-1, X-2, X-3, X-4.
2287 Schultz SK, et al. The association between risk factors for tardive dyskinesia and phenylalanine-induced abnormal movements in schizophrenia. Human Psychopharmacology: Clinical and Experimental. 2001. X-2, X-4.
2290 Tyrer SP, Hill SC. Psychopharmacological treatments for patients with intellectual disability. Hong Kong Journal of Psychiatry. 2000. X-1, X-2, X-3, X-4.
2292 Baumeister AA, Bacharach VR. Early generic educational intervention has no enduring effect on intelligence and does not prevent mental retardation: The Infant Health and Development Program. Intelligence. 2000. X-1, X-2, X-3, X-4.
2294 Peterson L, Tremblay G. Self-monitoring in behavioral medicine: Children. Psychological Assessment. 1999. X-1, X-2, X-4.
2295 Sullivan JE, Chang P. Review: Emotional and behavioral functioning in phenylketonuria. Journal of Pediatric Psychology. 1999. X-1, X-2, X-3, X-4.
2296 Richardson MA, et al. Phenylalanine kinetics are associated with tardive dyskinesia in men but not in women. Psychopharmacology. 1999. X-2, X-3, X-4, X-5.
2298 Ellis CR, Singh NN, Ruane AL. Nutritional, dietary, and hormonal treatments for individuals with mental retardation and developmental disabilities. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
2299 Shiwach RS, Sheikha S. Delusional disorder in a boy with phenylketonuria and amine metabolites in the cerebrospinal fluid after treatment with neuroleptics. Journal of Adolescent Health. 1998. X-3, X-4.
2300 Baumeister AA, Baumeister AA. Dietary treatment of destructive behavior associated with hyperphenylalaninemia. Clinical Neuropharmacology. 1998. X-1, X-2, X-3, X-4.
2301 Costigan CL, et al. Family process and adaptation to children with mental retardation: Disruption and resilience in family problem-solving interactions. Journal of Family Psychology. 1997. X-2, X-4.
2305 Harvey EL, Kirk SF. The use of a low phenylalanine diet in response to the challenging behaviour of a man with untreated phenylketonuria and profound learning disabilities. Journal of Intellectual Disability Research. 1995. X-1, X-3.
2307 Sabelli HC, Javaid JI. Phenylethylamine modulation of affect: Therapeutic and diagnostic implications. The Journal of Neuropsychiatry and Clinical Neurosciences. 1995. X-1, X-2, X-3, X-4.
2308 Wahlsten D. The intelligence of heritability. Canadian Psychology/Psychologie canadienne. 1994. X-1, X-2, X-3, X-4.
2310 Güttler F, Guldberg P, Henriksen KF. Mutation genotype of mentally retarded patients with phenylketonuria. Developmental Brain Dysfunction. 1993. X-2, X-3, X-4.
2311 Pavone L, et al. Late diagnosed phenylketonuria patients: Clinical presentation and results of treatment. Developmental Brain Dysfunction. 1993. X-4, X-5.
2312 Vaz Osório R, et al. Phenylketonuria in Portugal: Multidisciplinary approach. Developmental Brain Dysfunction. 1993. X-1, X-2, X-3, X-4.
2314 McCombe PA, et al. Spasticity and white matter abnormalities in adult phenylketonuria. Journal of Neurology, Neurosurgery & Psychiatry. 1992. X-3, X-4.
2315 Elliott TR, Herrick SM, Witty TE. Problem-solving appraisal and the effects of social support among college students and persons with physical disabilities. Journal of Counseling Psychology. 1992. X-2, X-3, X-4.
2316 Hoskin RG, Sasitharan T, Howard R. The use of a low phenylalanine diet with amino acid supplement in the treatment of behavioural problems in a severely mentally retarded adult female with phenylketonuria. Journal of Intellectual Disability Research. 1992. X-1, X-3.
2317 Miladi N, et al. Phenylketonuria: An underlying etiology of autistic syndrome: A case report. Journal of Child Neurology. 1992. X-1, X-3, X-4.
2319 Ewart CK. Social action theory for a public health psychology. American Psychologist. 1991. X-1, X-2, X-3, X-4.
2320 Crowley C, et al. Clinical trial of “off diet” older phenylketonurics with a new phenylalanine-free product. Journal of Mental Deficiency Research. 1990. X-4, X-5.
2323 Pennington BF, Smith SD. Genetic influences on learning disabilities: An update. Journal of Consulting and Clinical Psychology. 1988. X-1, X-2, X-4.
2324 Archer LA, Cunningham CE, Whelan DT. Coping with dietary therapy in phenylketonuria: A case report. Canadian Journal of Behavioural Science/Revue canadienne des sciences du comportement. Special Issue: Child and adolescent health. 1988. X-1, X-3.
2325 Barclay A, Walton O. Phenylketonuria: Implications of initial serum phenylalanine levels on cognitive development. Psychological Reports. 1988. X-4, X-5.
2328 Harper M, Reid AH. Use of a restricted protein diet in the treatment of behaviour disorder in a severely mentally retarded adult female phenylketonuric patient. Journal of Mental Deficiency Research. 1987. X-1, X-3.
2330 No authorship, i. Medical malpractice claims. Mental & Physical Disability Law Reporter. 1986. X-1, X-2, X-3, X-4.
2332 Schor DP. Phenylketonuria and temperament in middle childhood. Children's Health Care. 1986. X-4.
2333 Davis DD, et al. Cognitive styles in children with dietary treated phenylketonuria. Educational & Psychological Research. 1986. X-3, X-4.
2336 Kaplan RM. The connection between clinical health promotion and health status: A critical overview. American Psychologist. 1984. X-1, X-2, X-3, X-4.
2337 Mims SK, McIntyre CW, Murray ME. An analysis of visual motor problems in children with dietary treated phenylketonuria. Educational & Psychological Research. 1983. X-3.
2339 Gilka L. Hyperactivity, learning disabilities, GABA, inborn errors of metabolism, and modern environmental factors. International Journal of Biosocial Research. 1983. X-1, X-2, X-3, X-4.
2340 Leeming RJ, Pheasant AE, Blair JA. The role of tetrahydrobiopterin in neurological disease: A review. Journal of Mental Deficiency Research. 1981. X-1.
2341 Tu Jb. Phenylketonuria: The inadvisability of neuroleptic medication. Biological Psychiatry. 1980. X-3, X-4.
2342 Fox RA, Roseen DL. A parent administered token program for dietary regulation of phenylketonuria. Journal of Behavior Therapy and Experimental Psychiatry. 1977. X-3, X-4.
2345 Meltzer HY. Biochemical studies in schizophrenia. Schizophrenia Bulletin. 1976. X-1, X-2, X-3, X-4.
2348 Curran WJ. Ethical and legal considerations in high risk studies of schizophrenia. Schizophrenia Bulletin. 1974. X-1, X-2, X-3, X-4.
2350 Formentin P, Mack J, Hockey A. Carrier detection and assessment of dietary treatment in phenylketonuria. Australian Journal of Mental Retardation. 1972. X-4.
2352 Anderman S, et al. Intelligence and serum phenylalanine in levels in phenylketonuric children. Proceedings of the Annual Convention of the American Psychological Association. 1971. X-9.
2357 Baumeister AA. The Effects of Dietary Control on Intelligence in Phenylketonuria. American Journal of Mental Deficiency. 1967. X-1, X-2, X-3, X-4.
2358 Bruhl HH, Arnesen JF, Bruhl MG. Effect of a low-phenylalanine diet on older phenylketonuria patients. (long range controlled study). American Journal of Mental Deficiency. 1964. X-9.
2359 Vandeman PR. Termination of dietary treatment for phenylketonuria. American Journal of Diseases of Children. 1963. X-3, X-4.
2360 Mackay RI, et al. Mono-amine oxidase inhibitors and mental subnormality: Experiences with nialminide. Journal of Mental Deficiency Research. 1963. X-3, X-4.
2361 Anderson PJ, Leuzzi V. White matter pathology in phenylketonuria. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
2362 Brumm VL, Grant ML. The role of intelligence in phenylketonuria: a review of research and management. Mol Genet Metab. 2010. X-1.
2363 Christ SE, Moffitt AJ, Peck D. Disruption of prefrontal function and connectivity in individuals with phenylketonuria. Mol Genet Metab. 2010. X-3, X-4, X-5.
2364 White DA, et al. Age-related decline in the microstructural integrity of white matter in children with early- and continuously-treated PKU: a DTI study of the corpus callosum. Mol Genet Metab. 2010. X-4, X-5.
2365 Antshel KM. ADHD, learning, and academic performance in phenylketonuria. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
2366 Brumm VL, Bilder D, Waisbren SE. Psychiatric symptoms and disorders in phenylketonuria. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4, X-5.
2367 Gentile JK, Ten Hoedt AE, Bosch AM. Psychosocial aspects of PKU: hidden disabilities--a review. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
2368 Feillet F, et al. Outcomes beyond phenylalanine: an international perspective. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
2369 de Groot MJ, et al. Pathogenesis of cognitive dysfunction in phenylketonuria: review of hypotheses. Mol Genet Metab. 2010. X-1, X-2, X-3, X-4.
2370 Feillet F, Agostoni C. Nutritional issues in treating phenylketonuria. J Inherit Metab Dis. 2010. X-1, X-2, X-3, X-4.
2371 van Spronsen FJ, et al. Large neutral amino acids in the treatment of PKU: from theory to practice. J Inherit Metab Dis. 2010. X-1, X-2, X-3, X-4.
2372 Harding CO, Gibson KM. Therapeutic liver repopulation for phenylketonuria. J Inherit Metab Dis. 2010. X-1, X-2, X-3, X-4.
2373 Macdonald A, et al. The reality of dietary compliance in the management of phenylketonuria. J Inherit Metab Dis. 2010. X-2, X-3, X-4.
2374 Muntau AC, Gersting SW. Phenylketonuria as a model for protein misfolding diseases and for the development of next generation orphan drugs for patients with inborn errors of metabolism. J Inherit Metab Dis. 2010. X-1, X-3, X-4.
2375 Opladen T, et al. Erratum to: Phenylalanine loading in pediatric patients with dopa-responsive dystonia: revised test protocol and pediatric cutoff values. J Inherit Metab Dis. 2010. X-1, X-2, X-3, X-4.
2376 Opladen T, et al. Phenylalanine loading in pediatric patients with dopa-responsive dystonia: revised test protocol and pediatric cutoff values. J Inherit Metab Dis. 2010. X-2, X-3, X-4.
2377 Singh RH, et al. BH(4) therapy impacts the nutrition status and intake in children with phenylketonuria: 2-year follow-up. J Inherit Metab Dis. 2010. X-3.
2378 Thony B. Long-term correction of murine phenylketonuria by viral gene transfer: liver versus muscle. J Inherit Metab Dis. 2010. X-2, X-3, X-4.
2379 Dobrowolski SF, et al. The phenylalanine hydroxylase c.30C>G synonymous variation (p.G10G) creates a common exonic splicing silencer. Mol Genet Metab. 2010. X-2, X-3, X-4.
2380 Gersting SW, et al. Activation of phenylalanine hydroxylase induces positive cooperativity toward the natural cofactor. J Biol Chem. 2010. X-2, X-3, X-4, X-5.
2381 MacLeod EL, et al. Breakfast with glycomacropeptide compared with amino acids suppresses plasma ghrelin levels in individuals with phenylketonuria. Mol Genet Metab. 2010. X-4, X-5.
2382 Somaraju UR, Merrin M. Sapropterin dihydrochloride for phenylketonuria. Cochrane Database of Systematic Reviews. 2010. X-1, X-2, X-3, X-4.
2383 Webster D, Wildgoose J. Tyrosine supplementation for phenylketonuria. Cochrane Database of Systematic Reviews. 2010. X-1, X-2, X-3, X-4.
2384 Schulpis KH, et al. The effect of diet on total antioxidant status, ceruloplasmin, transferrin and ferritin serum levels in phenylketonuric children. Acta Paediatrica, International Journal of Paediatrics. 2010. X-4, X-5.
2385 Frye RE, Huffman LC, Elliott GR. Tetrahydrobiopterin as a novel therapeutic intervention for autism. Neurotherapeutics. 2010. X-2, X-3, X-4.
2386 Bauman ML. Medical comorbidities in autism: Challenges to diagnosis and treatment. Neurotherapeutics. 2010. X-1, X-2, X-3, X-4.
2387 Röser D, et al. Congenital toxoplasmosis—a report on the Danish neonatal screening programme 1999-2007. Journal of inherited metabolic disease. 2010. X-1, X-2, X-3, X-4.
2388 Zhang Dl, et al. Determination of unconjugated aromatic acids in urine by capillary electrophoresis with dual electrochemical detection - Potential application in fast diagnosis of phenylketonuria. Electrophoresis. 2010. X-2, X-3, X-4.
2389 Dhondt JL. Lessons from 30 years of selective screening for tetrahydrobiopterin deficiency. Journal of inherited metabolic disease. 2010. X-2, X-3, X-4.
2390 Niu DM, et al. Nationwide survey of extended newborn screening by tandem mass spectrometry in Taiwan. Journal of inherited metabolic disease. 2010. X-1, X-2, X-3, X-4.
2391 Mohsen SM, et al. Quality characteristics improvement of low-phenylalanine toast bread. International journal of food science & technology. 2010. X-2, X-3, X-4.
2392 Flydal MI, et al. Superstoichiometric binding of L-Phe to phenylalanine hydroxylase from Caenorhabditis elegans: evolutionary implications. Amino acids. 2010. X-2, X-3, X-4.
2393 Surendran S, Rajasankar S. Parkinson's disease: Oxidative stress and therapeutic approaches. Neurological Sciences. 2010. X-1, X-2, X-3, X-4.
2394 Wetmore DZ, Garner CC. Emerging pharmacotherapies for neurodevelopmental disorders. Journal of Developmental and Behavioral Pediatrics. Special Issue: The genetics and genomics of childhood neurodevelopmental disorders: An update. 2010. X-1, X-2, X-3, X-4.
2395 Barschak AG, et al. Oxidative stress in plasma from maple syrup urine disease patients during treatment. Metabolic Brain Disease. 2008. X-1, X-2, X-3, X-4.
2397 From the Centers for Disease Control and Prevention. Barriers to dietary control among pregnant women with phenylketonuria--United States, 1998-2000. JAMA. 2002. X-1, X-4.
2398 Barriers to dietary control among pregnant women with phenylketonuria--United States, 1998-2000. MMWR Morb Mortal Wkly Rep. 2002. X-1, X-2, X-3, X-4.
2399 Bachman RP, et al. Phenylalanine embryopathy in three siblings: implications of maternal diet therapy. Am J Dis Child. 1993. X-4.
2400 Bankier A. Syndrome quiz. Maternal phenylketonuria. Aust Fam Physician. 1990. X-4.
2401 Blomquist HK, Gustavson KH, Holmgren G. Severe mental retardation in five siblings due to maternal phenyketonuria. Neuropediatrics. 1980. X-4.
2402 Bouchlariotou S, Tsikouras P, Maroulis G. Undiagnosed maternal phenylketonuria: own clinical experience and literature review. J Matern Fetal Neonatal Med. 2009. X-4.
2403 Bradburn NC, et al. Lactation and phenylketonuria. Am J Perinatol. 1985. X-4.
2404 Bush RT, Dukes PC. Progeny, pregnancy and phenylketonuria. N Z Med J. 1975. X-4.
2405 Bush RT, Dukes PC. Women with phenylketonuria: successful management of pregnancy and implications. N Z Med J. 1985. X-1, X-2, X-3, X-4.
2406 Davidson DC. Maternal phenylketonuria. Postgrad Med J. 1989. X-1, X-2, X-3, X-4.
2407 Davidson DC, et al. Outcome of pregnancy in a phenylketonuric mother after low phenylalanine diet introduced from the ninth week of pregnancy. Eur J Pediatr. 1981. X-4.
2408 De Klerk JB, et al. Maternal PKU syndrome in an exceptional family with unexpected PKU. J Inherit Metab Dis. 1987. X-1, X-2, X-3, X-4.
2410 Farquhar DL, et al. Pre-conceptual dietary management for maternal phenylketonuria. Acta Paediatr Scand. 1987. X-3.
2412 Fisch RO, Stassart JP. Normal infant by a gestational carrier for a phenylketonuria mother: alternative therapy. Mol Genet Metab. 2004. X-4.
2413 Fox C, Marquis J, Kipp DE. Nutritional factors affecting serum phenylalanine concentration during pregnancy for identical twin mothers with phenylketonuria. Acta Paediatr. 2000. X-1, X-2, X-3, X-4.
2414 Gambol PJ. Maternal phenylketonuria syndrome and case management implications. J Pediatr Nurs. 2007. X-1, X-2, X-3, X-4.
2415 Giovannini M, et al. Fatty acid supplementation in a case of maternal phenylketonuria. J Inherit Metab Dis. 1994. X-1, X-2, X-3, X-4.
2416 Huang RT, et al. Successful management of a pregnancy with maternal phenylketonuria: report of a case. J Formos Med Assoc. 1993. X-1, X-2, X-3, X-4.
2417 Kecskemethy HH, Lobbregt D, Levy HL. The use of gelatin capsules for ingestion of formula in dietary treatment of maternal phenylketonuria. J Inherit Metab Dis. 1993. X-4.
2418 Kesby G. Repeated adverse fetal outcome in pregnancy complicated by uncontrolled maternal phenylketonuria. J Paediatr Child Health. 1999. X-3.
2419 Knerr I, et al. An exceptional Albanian family with seven children presenting with dysmorphic features and mental retardation: maternal phenylketonuria. BMC Pediatr. 2005. X-4.
2420 Koch R, et al. Maternal phenylketonuria. J Inherit Metab Dis. 1986. X-1, X-2, X-3, X-4.
2422 Komrower GM, et al. Management of maternal phenylketonuria: an emerging clinical problem. Br Med J. 1979. X-4.
2423 Lacey DJ, Terplan K. Abnormal cerebral cortical neurons in a child with maternal PKU syndrome. J Child Neurol. 1987. X-2, X-3, X-4.
2424 Lenke RR, et al. Tyrosine supplementation during pregnancy in a woman with classical phenylketonuria. A case report. J Reprod Med. 1983. X-4.
2425 Levy HL, Kaplan GN, Erickson AM. Comparison of treated and untreated pregnancies in a mother with phenylketonuria. J Pediatr. 1982. X-4.
2426 Levy HL, et al. Maternal phenylketonuria: magnetic resonance imaging of the brain in offspring. J Pediatr. 1996. X-1, X-2, X-3, X-4.
2427 Levy HL, et al. Comparison of phenylketonuric and nonphenylketonuric sibs from untreated pregnancies in a mother with phenylketonuria. Am J Med Genet. 1992. X-4.
2428 Lorijn RH, Sengers RC, Trijbels JM. Maternal phenylketonuria: the outcome of pregnancy. Eur J Obstet Gynecol Reprod Biol. 1981. X-4.
2429 Matalon R, Michals K, Gleason L. Maternal PKU: strategies for dietary treatment and monitoring compliance. Ann N Y Acad Sci. 1986. X-1, X-2, X-3, X-4.
2430 Messer SS. PKU: a mother's perspective. Pediatr Nurs. 1985. X-1, X-2, X-3, X-4.
2431 Michels VV, Justice CL. Treatment of phenylketonuria during pregnancy. Clin Genet. 1982. X-4.
2432 Murphy D, Saul I, Kirby M. Maternal phenylketonuria and phenylalanine restricted diet. Studies of 7 pregnancies and of offsprings produced. Ir J Med Sci. 1985. X-3.
2433 Scott TM, Fyfe WM, Hart DM. Maternal phenylketonuria: abnormal baby despite low phenylalanine diet during pregnancy. Arch Dis Child. 1980. X-1, X-2, X-3, X-4.
2434 Superti-Furga A, et al. Maternal phenylketonuria syndrome in cousins caused by mild, unrecognized phenylketonuria in their mothers homozygous for the phenylalanine hydroxylase Arg-261-Gln mutation. Eur J Pediatr. 1991. X-2, X-3, X-4.
2435 Tenbrinck MS, Stroud HW. Normal infant born to a mother with phenylketonuria. JAMA. 1982. X-1, X-2, X-3, X-4.
2436 Thompson GN, et al. Pregnancy in phenylketonuria: dietary treatment aimed at normalising maternal plasma phenylalanine concentration. Arch Dis Child. 1991. X-4.
2437 Timlin JB. A case of phenylketonuria. Midwives Chron. 1978. X-3, X-4.
2438 Ugarte M, Maties M, Ugarte JL. The offspring of a phenylketonuric couple. J Ment Defic Res. 1980. X-1, X-2, X-3, X-4.
2439 Unger S, et al. A case of maternal PKU syndrome despite intensive patient counseling. Wien Med Wochenschr. 2009. X-4.
2440 Usha R, et al. Late diagnosis of phenylketonuria in a Bedouin mother. Am J Med Genet. 1992. X-4.
2441 Wilkinson H, Holbrook IB. Maternal phenylketonuria. Ann Clin Biochem. 1998. X-1, X-2, X-3, X-4.
2442 Zaleski LA, Casey RE, Zaleski W. Maternal phenylketonuria: dietary treatment during pregnancy. Can Med Assoc J. 1979. X-3, X-4.
2443 Burgard P. Development of intelligence in early treated phenylketonuria. Eur J Pediatr. 2000. X-1.
2444 Enns GM, et al. Suboptimal outcomes in patients with PKU treated early with diet alone: revisiting the evidence. Mol Genet Metab. 2010. X-1.
2445 Griffiths P. Neuropsychological approaches to treatment policy issues in phenylketonuria. Eur J Pediatr. 2000. X-1.
2446 Pietz J. Neurological aspects of adult phenylketonuria. Curr Opin Neurol. 1998. X-1.
2447 Waisbren SE, et al. Phenylalanine blood levels and clinical outcomes in phenylketonuria: a systematic literature review and meta-analysis. Mol Genet Metab. 2007. X-1.
2448 Leandro J, et al. Phenylketonuria as a protein misfolding disease: The mutation pG46S in phenylalanine hydroxylase promotes self-association and fibril formation. Biochim Biophys Acta. 2011. X-1, X-2, X-3, X-4.
2449 Levy HL. Newborn screening conditions: What we know, what we do not know, and how we will know it. Genet Med. 2010. X-1, X-2, X-3, X-4.
2450 Roser D, et al. Congenital toxoplasmosis--a report on the Danish neonatal screening programme 1999-2007. J Inherit Metab Dis. 2010. X-2, X-3, X-4.
2451 Niu DM, et al. Nationwide survey of extended newborn screening by tandem mass spectrometry in Taiwan. J Inherit Metab Dis. 2010. X-2, X-3, X-4.
2454 Burton BK, Leviton L. Reaching out to the lost generation of adults with early-treated phenylketonuria (PKU). Mol Genet Metab. 2010. X-4.
2455 Dubois EA, Cohen AF. Sapropterin. Br J Clin Pharmacol. 2010. X-1, X-2, X-3, X-4, X-5.
2456 Zhao Y, et al. Detection of tetrahydrobiopterin by LC-MS/MS in plasma from multiple species. Bioanalysis. 2009. X-2, X-3, X-4.
2457 Thai PK, et al. Sweetness intensity perception and pleasantness ratings of sucrose, aspartame solutions and cola among multi-ethnic Malaysian subjects. Food Quality and Preference. 2011. X-2, X-3, X-4.
2458 Betancur C. Etiological heterogeneity in autism spectrum disorders: More than 100 genetic and genomic disorders and still counting. Brain Research. 2011. X-1, X-2, X-3, X-4.
2459 Ribeiro CAJ, Hickmann FH, Wajner M. Neurochemical evidence that 3-methylglutaric acid inhibits synaptic Na<sup>+</sup>,K<sup>+</sup>-ATPase activity probably through oxidative damage in brain cortex of young rats. International Journal of Developmental Neuroscience. 2011. X-2, X-3, X-4.
2460 Vela-Amieva M, et al. Correspondence on “experience with hyperphenylalaninemia in a developing country: Unusual clinical manifestations and a novel gene mutation”. Journal of Child Neurology. 2011. X-1, X-2, X-3, X-4.
2461 Karam PE, et al. Experience with hyperphenylalaninemia in a developing country: Unusual clinical manifestations and a novel gene mutation. Journal of Child Neurology. 2011. X-1, X-2, X-3, X-4.
2462 Huijbregts S, Swaab H, de Sonneville L. Cognitive and motor control in neurofibromatosis type I: Influence of maturation and hyperactivity-inattention. Developmental Neuropsychology. 2010. X-2, X-3, X-4.
2463 Glaser V, et al. The intra-hippocampal leucine administration impairs memory consolidation and LTP generation in rats. Cellular and Molecular Neurobiology. 2010. X-2, X-3, X-4.
2464 Kirby A, Woodward A, Jackson S. Benefits of omega-3 supplementation for schoolchildren: Review of the current evidence. British Educational Research Journal. 2010. X-1, X-2, X-3, X-4.
2465 Kolling J, Wyse ATS. Creatine prevents the inhibition of energy metabolism and lipid peroxidation in rats subjected to GAA administration. Metabolic Brain Disease. 2010. X-1, X-2, X-3, X-4.
2466 Bongiovanni R, et al. Relationships between large neutral amino acid levels in plasma, cerebrospinal fluid, brain microdialysate and brain tissue in the rat. Brain Research. 2010. X-2, X-3, X-4.
2467 Moraes TB, et al. Lipoic acid prevents oxidative stress <i>in vitro</i> and <i>in vivo</i> by an acute hyperphenylalaninemia chemically-induced in rat brain. Journal of the Neurological Sciences. 2010. X-2, X-3, X-4.
2468 Amaral AU, et al. α-ketoisocaproic acid and leucine provoke mitochondrial bioenergetic dysfunction in rat brain. Brain Research. 2010. X-2, X-3, X-4.
2469 Fernandes CG, et al. Experimental evidence that phenylalanine provokes oxidative stress in hippocampus and cerebral cortex of developing rats. Cellular and Molecular Neurobiology. 2010. X-1, X-2, X-3, X-4.
2470 la Fougère C, et al. Uptake and binding of the serotonin 5-HT<sub>1A</sub> antagonist [^18^F]-MPPF in brain of rats: Effects of the novel P-glycoprotein inhibitor tariquidar. NeuroImage. 2010. X-2, X-3, X-4.
2471 Nakashima A, et al. Role of N-terminus of tyrosine hydroxylase in the biosynthesis of catecholamines. Journal of Neural Transmission. 2009. X-2, X-3, X-4.
2472 Vásquez-Vivar J, et al. Tetrahydrobiopterin in the prevention of hypertonia in hypoxic fetal brain. Annals of Neurology. 2009. X-2, X-3, X-4.
2473 Delwing D, et al. Protective effect of antioxidants on cerebrum oxidative damage caused by arginine on pyruvate kinase activity. Metabolic Brain Disease. 2009. X-2, X-3, X-4.
2474 Pascucci T, et al. 5-Hydroxytryptophan rescues serotonin response to stress in prefrontal cortex of hyperphenylalaninaemic mice. International Journal of Neuropsychopharmacology. 2009. X-1, X-2, X-3, X-4.
2475 Viggiano D. The hyperactive syndrome: Metanalysis of genetic alterations, pharmacological treatments and brain lesions which increase locomotor activity. Behavioural Brain Research. 2008. X-2, X-3, X-4.
2476 Kim DH, et al. The effects of acute and repeated oroxylin A treatments on Aβ<sub>25-35</sub>-induced memory impairment in mice. Neuropharmacology. 2008. X-1, X-2, X-3, X-4.
2477 Sato K, et al. Differential involvement of striosome and matrix dopamine systems in a transgenic model of dopa-responsive dystonia. PNAS Proceedings of the National Academy of Sciences of the United States of America. 2008. X-2, X-3, X-4.
2478 Pascucci T, et al. Reduced availability of brain amines during critical phases of postnatal development in a genetic mouse model of cognitive delay. Brain Research. 2008. X-1, X-2, X-3, X-4.
2479 Delwing D, et al. Protective effect of nitric oxide synthase inhibition or antioxidants on brain oxidative damage caused by intracerebroventricular arginine administration. Brain Research. 2008. X-2, X-3, X-4.
2480 Neckameyer WS, et al. Compartmentalization of neuronal and peripheral serotonin synthesis in <i>Drosophila melanogaster</i>. Genes, Brain & Behavior. 2007. X-2, X-3, X-4.
2481 Stefanello FM, et al. Reduction of gangliosides, phospholipids and cholesterol content in cerebral cortex of rats caused by chronic hypermethioninemia. International Journal of Developmental Neuroscience. 2007. X-1, X-2, X-3, X-4.
2482 Funchal C, et al. Effect of the branched-chain α-keto acids accumulating in maple syrup urine disease on S100B release from glial cells. Journal of the Neurological Sciences. 2007. X-2, X-3, X-4.
2483 Embury JE, et al. PKU is a reversible neurodegenerative process within the nigrostriatum that begins as early as 4 weeks of age in <i>Pah</i><sup>enu2</sup> mice. Brain Research. 2007. X-1, X-2, X-3, X-4.
2484 MacFabe DF, et al. Neurobiological effects of intraventricular propionic acid in rats: Possible role of short chain fatty acids on the pathogenesis and characteristics of autism spectrum disorders. Behavioural Brain Research. 2007. X-2, X-3, X-4.
2485 Gu XL, Yu LC. Involvement of Opioid Receptors in Oxytocin-Induced Antinociception in the Nucleus Accumbens of Rats. The Journal of Pain. 2007. X-1, X-2, X-3, X-4.
2486 Ettl AK, Holzschuh J, Driever W. The zebrafish mutation <i>m865</i> affects formation of dopaminergic neurons and neuronal survival, and maps to a genetic interval containing the <i>sepiapterin reductase</i> locus. Brain Structure & Function. Special issue dedicated to Bodo Christ. 2006. X-2, X-3, X-4.
2487 Le Masurier M, et al. Effect of acute tyrosine depletion in using a branched chain amino-acid mixture on dopamine neurotransmission in the rat brain. Neuropsychopharmacology. 2006. X-1, X-2, X-3, X-4.
2488 Stefanello FM, et al. Methionine alters Na<sup>+</sup>,K<sup>+</sup>-ATpase activity, lipid peroxidation and nonenzymatic antioxidant defenses in rat hippocampus. International Journal of Developmental Neuroscience. 2005. X-1, X-2, X-3, X-4.
2489 Golub MS, Germann SL, Hogrefe CE. Endocrine disruption and cognitive function in adolescent female rhesus monkeys. Neurotoxicology and Teratology. 2004. X-1, X-2, X-3, X-4.
2490 Vasques VdC, et al. Intrahippocampal administration of the α-keto acids accumulating in maple syrup urine disease provokes learning deficits in rats. Pharmacology, Biochemistry and Behavior. 2004. X-2, X-3, X-4.
2491 Bridi R, et al. Induction of oxidative stress in rat brain by the metabolites accumulating in maple syrup urine disease. International Journal of Developmental Neuroscience. 2003. X-2, X-3, X-4.
2492 Pilla C, et al. Kinetic studies on the inhibition of creatine kinase activity by branched-chain α-amino acids in the brain cortex of rats. International Journal of Developmental Neuroscience. 2003. X-1, X-2, X-3, X-4.
2493 Cabib S, et al. The Behavioral Profile of Severe Mental Retardation in a Genetic Mouse Model of Phenylketonuria. Behavior Genetics. 2003. X-2, X-3, X-4.
2494 Girard TA, et al. Developmental binge exposure to ethanol and artificial rearing do not affect the social transfer of diet preference. Alcoholism: Clinical and Experimental Research. 2003. X-2, X-3, X-4.
2495 Glushakov AV, et al. Specific inhibition of N-methyl-D-aspartate receptor function in rat hippocampal neurons by L-phenylalanine at concentrations observed during phenylketonuria. Molecular Psychiatry. 2002. X-2, X-3, X-4.
2496 D'Hooge R, De Deyn PP. Applications of the Morris water maze in the study of learning and memory. Brain Research Reviews. 2001. X-1, X-2, X-3, X-4.
2497 Butcher R, Vorhees C, Berry H. A learning impairment associated with induced phenylketonuria. Life Sciences. 1970. X-2, X-3, X-4.
2498 Polidora VJ, Cunningham RF, Waisman HA. Dosage parameters of a behavioral deficit associated with phenylketonuria in rats. Journal of Comparative and Physiological Psychology. 1966. X-2, X-3, X-4.
2499 Karrer R, Cahilly G. Experimental attempts to produce phenylketonuria in animals: A critical review. Psychological Bulletin. 1965. X-1, X-2, X-3, X-4.
2500 Louttit RT. Effect of phenylalanine and isocarboxazid feeding on brain serotonin and learning behavior in the rat. Journal of Comparative and Physiological Psychology. 1962. X-1, X-2, X-3, X-4.
2501 Kaplan AR. Phenylketonuria: A review. Eugenics Quarterly. 1962. X-1, X-2, X-3, X-4.
2502 Allen RJ, Gibson RM. Phenylketonuria with normal intelligence. American Journal of Diseases of Children. 1961. X-3, X-4, X-5.
2503 King FJ, Bowman BH. Phenylketonuria: Five affected members in one sibship. Journal of Heredity. 1960. X-3, X-4.
2504 Lewis E. The development of concepts in a girl after dietary treatment for phenylketonuria. British Journal of Medical Psychology. 1959. X-3, X-4.
2505 Memory and disorders. Nature. 1970. X-1, X-2, X-3, X-4.
2506 Letter: Screening for phenylketonuria. British Medical Journal. 1974. X-1, X-2, X-3, X-4.
2507 Letter: Management of women with phenylketonuria. The New England journal of medicine. 1974. X-1, X-2, X-3, X-4.
2508 Phenylketonuria. Smith-Hurd Illinois annotated statutes. 1982. X-1, X-2, X-3, X-4.
2509 Nutrition classics, the Journal of Clinical Investigation, volume 34, 1955: Studies on phenylketonuria. I. Restricted phenylalanine intake in phenylketonuria. By Marvin D. Armstrong and Frank H. Tyler. Nutrition Reviews. 1983. X-1, X-2, X-3, X-4.
2510 Phenylketonuria. Biology and Society. 1986. X-1, X-2, X-3, X-4, X-5.
2511 Phenylketonuria in adolescence. International Symposium on the Advances in the Management of PKU. Brussels, Belgium, October 1986. Dedicated to Horst Bickel. European Journal of Pediatrics. 1987. X-1, X-2, X-3, X-4.
2512 Phenylketonuria: Past, present and future. Biology and Society. 1988. X-1, X-2, X-3, X-4, X-5.
2513 National Institutes of Health (NIH) to host a consensus development conference on screening and management for phenylketonuria (PKU). Pediatric nursing. 2000. X-1, X-2, X-3, X-4.
2514 Acharya K, Ackerman PD, Ross LF. Pediatricians' attitudes toward expanding newborn screening. Pediatrics. 2005. X-2, X-3, X-4.
2515 Adamsen D, et al. Pteridines. 2009. X-1, X-2, X-3, X-4.
2516 Adamsen D, et al. Journal of Inherited Metabolic Disease. 2010. X-1, X-2, X-3, X-4.
2517 Adelman CS. The constitutionality of mandatory genetic screening statutes. Case Western Reserve law review. 1981. X-1, X-2, X-3, X-4.
2518 Agostoni C, Heird W. Long chain polyunsaturated fatty acids in chronic childhood disorders: panacea, promising, or placebo. Journal of Pediatric Gastroenterology and Nutrition. 2004. X-1, X-2, X-3, X-4.
2519 Ahring K, et al. Blood phenylalanine control in phenylketonuria: A survey of 10 European centres. European Journal of Clinical Nutrition. 2011. X-1, X-4.
2520 Alejandre MJ, et al. Lipid composition of brain myelin from normal and hyperphenylalaninemic chick embryos. Comparative biochemistry and physiology. 1984. X-2, X-3, X-4.
2521 Allard P, et al. Determination of phenylalanine and tyrosine in dried blood specimens by ion-exchange chromatography using the Hitachi L-8800 analyzer. Clinical Biochemistry. 2004. X-4.
2522 Alonso-Fernandez JR, Colon C. The contributions of Louis I Woolf to the treatment, early diagnosis and understanding of phenylketonuria. Journal of medical screening. 2009. X-1, X-2, X-3, X-4.
2523 Anderson PJ, Leuzzi V. White matter pathology in phenylketonuria. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2524 Antshell KM, Waisbren SE. Developmental Timing of Exposure to Elevated Levels of Phenylalanine is Associated with ADHD Symptom Expression. Journal of Abnormal Child Psychology. 2003. X-4.
2525 Aoki K. Newborn screening in Japan. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2526 Arnold GL, et al. Iron and protein sufficiency and red cell indices in phenylketonuria. Journal of the American College of Nutrition. 2001. X-4.
2527 Arnold GL, et al. Factors affecting cognitive, motor, behavioral and executive functioning in children with phenylketonuria. Acta Paediatrica, International Journal of Paediatrics. 1998. X-4, X-5.
2528 Arnopp JJ, et al. Results of screening for phenylketonuria using a lower cutoff value in early collected specimens. Screening. 1995. X-4.
2529 Bailey DB Jr, et al. Ethical, legal, and social concerns about expanded newborn screening: Fragile X syndrome as a prototype for emerging issues. Pediatrics. 2008. X-1, X-2, X-3, X-4.
2530 Bartholome K. Deficiency of tyrosine hydroxylase or tryptophan hydroxylase: A possible cause of two hypothetical metabolic diseases. Acta Paediatrica Scandinavica. 1983. X-4.
2531 Beck M, et al. Effect of storage on phenylalanine and tyrosine measurements in whole-blood samples. Clinical Chemistry. 2001. X-4.
2532 Becker K, Harenz J, Kalle N. Comparative column chromatographic estimations of phenylalanine in plasma, whole blood, native and paper-dried capillary blood of healthy children and adults, and patients with hyperphenylalaninaemia. Journal of Inherited Metabolic Disease. 1985. X-4.
2533 Behbehani AW, Langenbeck U. A combined study of neurophysiological, biochemical, and psychological parameters in children with phenylketonuria. Journal of Inherited Metabolic Disease. 1982. X-4, X-5.
2534 Behbehani AW, et al. Termination of strict diet in phenylketonuria: Neurophysiological, psychological and biochemical studies. Journal of Inherited Metabolic Disease. 1986. X-1, X-2, X-3, X-4.
2535 Bekhof J, et al. Influence of knowledge of the disease on metabolic control in phenylketonuria. European Journal of Pediatrics. 2003. X-4.
2536 Berman JL, Justice P, Hsia DY. Effect of vitamin B 6 on blood 5-hydroxytryptamine concentration. Annals of the New York Academy of Sciences. 1969. X-4.
2537 Berry HK. Comparison of fluorimetric and chromatographic procedures for determination of serum phenylalanine. Clinica chimica acta. international journal of clinical chemistry. 1968. X-4.
2538 Berry HK, Sutherland BS, Umbarger B. Diagnosis and treatment: interpretation of results of blood screening studies for detection of phenylketonuria. Pediatrics. 1966. X-4.
2539 Bhagavan NV. Letter: Hazards in indiscriminate use of sweeteners containing phenylalanine. The New England journal of medicine. 1975. X-1, X-2, X-3, X-4.
2540 Bickel H. Early diagnosis and treatment of inborn errors of metabolism. Enzyme. 1987. X-1, X-2, X-3, X-4.
2541 Bik-Multanowski M, et al. Use of handheld computers for assessment of prefrontal cortex function in patients with phenylketonuria. Molecular Genetics and Metabolism. 2005. X-4, X-5.
2542 Bik-Multanowski M, et al. Assessment of brain phenylalanine dynamics in phenylketonuria patients. Polish Journal of Radiology. 2006. X-3.
2543 Bik-Multanowski Miroslaw M, Pietrzyk JJ, Mozrzymas R. Routine use of CANTAB system for detection of neuropsychological deficits in patients with PKU. Molecular Genetics and Metabolism. 2011. X-4, X-5.
2544 Blau K. Aromatic acid excretion in phenylketonuria. Analysis of the unconjugated aromatic acids derived from phenylalanine. Clinica chimica acta. international journal of clinical chemistry. 1970. X-4.
2545 Blau N, Barnes I, Dhondt JL. International database of tetrahydrobiopterin deficiencies. Journal of Inherited Metabolic Disease. 1996. X-2, X-3, X-4.
2546 Blau N, Curtius HC. Cofactor defects in atypical phenylketonuria. Current trends in infant screening: proceedings of the 7th International Screening Symposium. 1989. X-1, X-2, X-3, X-4.
2547 Blau N, et al. Prenatal diagnosis of atypical phenylketonuria. Journal of Inherited Metabolic Disease. 1989. X-3, X-4.
2548 Blyumina MG, Sitnichenko EI. Concentration of phenylalanine in the blood serum of patients with various degrees of phenylketonuria. Soviet genetics. 1971. X-4.
2549 Bodamer OA, et al. Neonatal screening in Austria. Current situation, new developments and future perspectives. Padiatrische Praxis. 2002. X-2, X-3, X-4.
2550 Bowman BH. Genetic counseling in cystic fibrosis. American family physician. 1973. X-1, X-2, X-3, X-4.
2551 Bowman JE. To screen or not to screen: when should screening be offered?. Community Genetics. 1998. X-1, X-2, X-3, X-4.
2552 Brown ES, et al. Effects of oral contraceptives and obesity on carrier tests for phenylketonuria. Clinica chimica acta. international journal of clinical chemistry. 1973. X-4.
2553 Brumm VL, Bilder D, Waisbren SE. Psychiatric symptoms and disorders in phenylketonuria. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2554 Brumm VL, Grant ML. The role of intelligence in phenylketonuria: A review of research and management. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2555 Buist NR, Brandon GR, Penn RL Jr. Letter: Follow-up screening for phenylketonuria. The New England journal of medicine. 1974. X-1, X-2, X-3, X-4.
2556 Buist NRM. Erratum: A new amino acid mixture permist new approaches to the treatment of phenylketonuria (Acta Paediatrica 1994, 83 Suppl (75-77)). Acta Paediatrica, International Journal of Paediatrics. 1995. X-1, X-2, X-3, X-4.
2557 Buist NRM, et al. Towards improving the diet for hyperphenylalaninemia and other metabolic disorders. International Pediatrics. 1993. X-1, X-2, X-3, X-4.
2558 Butterworth T. Dermatologic disorders in institutionalized mental defectives. Birth defects original article series. 1971. X-1, X-2, X-3, X-4.
2559 Cabalska B, et al. Maternal phenylketonuria in Poland. International Pediatrics. 1996. X-4, X-5.
2560 Calhoun JA. Executive functions: A discussion of the issues facing children with autism spectrum disorders and related disorders. Seminars in Speech and Language. 2006. X-1, X-2, X-3, X-4.
2561 Cerone R, et al. Effects of stopping phenylalanine-restricted diet on intellectual progress of children with phenylketonuria. Journal of Inherited Metabolic Disease. 1986. X-4, X-5.
2562 Cerone R, et al. Maternal phenylketonuria: An experience from Italy. International Pediatrics. 1996. X-4, X-5.
2563 Chamove AS, Davenport JW. Differential reinforcement of latency (DRL) in phenylketonuric monkeys. Developmental psychobiology. 1970. X-2, X-3, X-4.
2564 Chang PN, Cook RD, Fisch RO. Prognostic factors of the intellectual outcome of phenylketonurics: On and off diet. Journal of Psychiatric Treatment and Evaluation. 1983. X-4, X-5.
2565 Charoensiriwatana W, et al. Neonatal screening program in Thailand. The Southeast Asian journal of tropical medicine and public health. 2003. X-2, X-3, X-4.
2566 Cipriano LE, Rupar CA, Zaric GS. The cost-effectiveness of expanding newborn screening for up to 21 inherited metabolic disorders using tandem mass spectrometry: Results from a decision-analytic model. Value in Health. 2007. X-2, X-3, X-4.
2567 Clark SJ, et al. Myocardial injury in infants ventilated on the paediatric intensive care unit: A case control study. Critical Care. 2006. X-2, X-3, X-4.
2568 Coburn SP, Seidenberg M, Fuller RW. Daily rhythm in plasma tyrosine and phenylalanine. Proceedings of the Society for Experimental Biology and Medicine. 1968. X-1, X-2, X-3, X-4.
2569 Cockburn F, et al. Recommendations on the dietary management of phenylketonuria. Archives of Disease in Childhood. 1993. X-1, X-2, X-3, X-4.
2570 Cohen BE, Szeinberg A, Zarfin Y. Maternal hyperphenylalaninaemia in Israel. Journal of Inherited Metabolic Disease. 1986. X-3, X-4, X-5.
2571 Collins MA. Neuroamine condensations in human subjects. Advances in experimental medicine and biology. 1980. X-1, X-2, X-3, X-4.
2572 Cone TE Jr. Diagnosis and treatment: some diseases, syndromes, and conditions associated with an unusual odor. Pediatrics. 1968. X-1, X-2, X-3, X-4.
2573 Constantinou MA, et al. <sup>1</sup>H NMR-based metabonomics for the diagnosis of inborn errors of metabolism in urine. Analytica Chimica Acta. 2005. X-3, X-4.
2574 Couce ML, et al. Inborn errors of metabolism in a neonatology unit: Impact and long-term results. Pediatrics International. 2011. X-2, X-3, X-4.
2575 Cramer DW, Wise LA. The epidemiology of recurrent pregnancy loss. Seminars in Reproductive Medicine. 2000. X-1, X-2, X-3, X-4.
2576 Darvish M, Ebrahimi SA, Ghadam P. Development of micellar electro kinetic chromatography for the separation and quantitation of L-valine, L-leucine, L-isoleucin and L-phenylalanine in human plasma and comparison with HPLC. Pakistan Journal of Biological Sciences. 2007. X-2, X-3, X-4.
2577 Daugaard L, et al. Human Gene Therapy. 2010. X-1, X-2, X-3, X-4.
2578 de Carvalho TM, et al. Newborn screening: a national public health programme in Brazil. Journal of Inherited Metabolic Disease. 2007. X-2, X-3, X-4.
2579 de Groot MJ, et al. Pathogenesis of cognitive dysfunction in phenylketonuria: Review of hypotheses. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2580 De Klerk JBC, et al. Maternal PKU syndrome in an exceptional family with unexpected PKU. Journal of Inherited Metabolic Disease. 1987. X-3, X-4.
2581 Desper MM. PKU: symptoms, diagnosis, treatment, prognosis. Rn. 1967. X-1, X-2, X-3, X-4.
2582 Desviat LR, et al. Relationship between mutation genotype and biochemical phenotype in a heterogeneous Spanish phenylketonuria population. European Journal of Human Genetics. 1997. X-4.
2583 Detmar S, et al. Parental opinions about the expansion of the neonatal screening programme. Community Genetics. 2008. X-2, X-3, X-4.
2584 Dhondt JL, Cotton RGH, Danks DM. Liver enzyme activities in hyperphenylalaninaemia due to a defective synthesis of tetrahydrobiopterin. Journal of Inherited Metabolic Disease. 1985. X-2, X-3, X-4.
2585 Dhondt JL, et al. Pterins analysis in amniotic fluid for the prenatal diagnosis of GTP cyclohydrolase deficiency. Journal of Inherited Metabolic Disease. 1990. X-2, X-3, X-4.
2586 Diamond A. Evidence for the importance of dopamine for prefrontal cortex functions early in life. Philosophical Transactions of the Royal Society B: Biological Sciences. 1996. X-1, X-2, X-3, X-4.
2587 Dobrowolski SF, et al. Molecular genetics and impact of residual in vitro phenylalanine hydroxylase activity on tetrahydrobiopterin responsiveness in Turkish PKU population. Molecular Genetics and Metabolism. 2011. X-4.
2588 Dontanville VK, Cunningham GC. Effect of feeding on screening for PKU in infants. Pediatrics. 1973. X-4.
2589 Dougherty FE, Levy HL. Phenylketonuria. Annales Nestle. 1998. X-1, X-2, X-3, X-4.
2590 Dougherty FE, Levy HL. Present newborn screening for phenylketonuria. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
2591 Elsas LJ, Greto J, Wierenga A. The effect of blood phenylalanine concentration on Kuvan response in phenylketonuria. Molecular Genetics and Metabolism. 2011. X-4.
2592 Endres W, Blau N, Curtius HC. Newborn screening and treatment of hyperphenylalaninemia due to tetrahydrobiopterin deficiency. Current trends in infant screening: proceedings of the 7th International Screening Symposium. 1989. X-1, X-2, X-3, X-4.
2593 Erbe RW. Issues in newborn genetic screening. Birth defects original article series. 1981. X-1, X-2, X-3, X-4.
2594 Espejo AJ, et al. Recent patents in diagnosis and treatment for Inborn errors of metabolism. Recent Patents on Endocrine, Metabolic and Immune Drug Discovery. 2010. X-1, X-2, X-3, X-4.
2595 Farrell MH, Certain LK, Farrell PM. Genetic counseling and risk communication services of newborn screening programs. Archives of Pediatrics and Adolescent Medicine. 2001. X-2, X-3, X-4.
2596 Feillet F, et al. Outcomes beyond phenylalanine: An international perspective. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2598 Feuchtbaum L, et al. California's experience implementing a pilot newborn supplemental screening program using tandem mass spectrometry. Pediatrics. 2006. X-2, X-3, X-4.
2599 Fisch RO, Tagatz G, Stassart JP. Gestational carrier - A reproductive haven for offspring of mothers with phenylketonuria (PKU): An alternative therapy for maternal PKU. Journal of Inherited Metabolic Disease. 1993. X-1, X-2, X-3, X-4.
2600 Fitzgerald B, et al. An investigation into diet treatment for adults with previously untreated phenylketonuria and severe intellectual disability. Journal of Intellectual Disability Research. 2000. X-3, X-4.
2601 Galluzzo CR, Ortisi MT, Castelli L. Plasma lipid concentrations in 42 treated phenylketonuric children. Journal of Inherited Metabolic Disease. 1985. X-4.
2602 Garrahan K. Study seeks to learn best course of action for mothers-to-be with controlled PKU. JAMA : the journal of the American Medical Association. 1987.
2603 Gauffin F, et al. Quantitation of RNA decay in dried blood spots during 20 years of storage. Clinical Chemistry and Laboratory Medicine. 2009. X-2, X-3, X-4.
2604 Geelhoed EA, et al. Economic evaluation of neonatal screening for phenylketonuria and congenital hypothyroidism. Journal of Paediatrics and Child Health. 2005. X-2, X-3, X-4.
2605 Gentile JK, Ten Hoedt AE, Bosch AM. Psychosocial aspects of PKU: Hidden disabilities - A review. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2606 Gersting SW, et al. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2607 Getchell JP, et al. HIV screening of newborns. Biochemical Medicine and Metabolic Biology. 1993. X-2, X-3, X-4.
2608 Giovannini M, et al. Long-chain polyunsaturated fatty acids profile in plasma phospholipids of hyperphenylalaninemic children on unrestricted diet. Prostaglandins Leukotrienes and Essential Fatty Acids. 2011. X-4.
2609 Glazer RI, Weber G. The effects of phenylpyruvate and hyperphenylalaninemia on incorporation of (6- 3 H)glucose into macromolecules of slices of rat cerebral cortex. Journal of Neurochemistry. 1971. X-2, X-3, X-4.
2610 Goodwin G, et al. Newborn screening: An overview with an update on recent advances. Current Problems in Pediatric and Adolescent Health Care. 2002. X-1, X-2, X-3, X-4.
2611 Gropper SS, et al. Iron deficiency without anemia in children with phenylketonuria. International Pediatrics. 1994. X-4.
2612 Gruemer HD, et al. Amino acid transport and mental retardation. Clinical Chemistry. 1971. X-1, X-2, X-3, X-4.
2613 Guldberg P, Henriksen KF, Guttler F. Molecular analysis of phenylketonuria in Denmark: 99% of the Mutations detected by denaturing gradient gel electrophoresis. Genomics. 1993. X-3, X-4.
2614 Guldberg P, et al. Aberrant phenylalanine metabolism in phenylketonnria heterozygotes. Journal of Inherited Metabolic Disease. 1998. X-1, X-2, X-3, X-4.
2615 Guldberg P, et al. A European multicenter study of phenylalanine hydroxylase deficiency: Classification of 105 mutations and a general system for genotype-based prediction of metabolic phenotype. American Journal of Human Genetics. 1998. X-4.
2616 Guttler F, et al. Relationship among genotype, biochemical phenotype, and cognitive performance in females with phenylalanine hydroxylase deficiency: Report from the maternal phenylketonuria collaborative study. Pediatrics. 1999. X-4.
2617 Guttler F, et al. Molecular genetics and outcome in PKU. Mental Retardation and Developmental Disabilities Research Reviews. 1999. X-1, X-2, X-3, X-4.
2618 Guttler F, Woo SLC. Molecular genetics of PKU. Journal of Inherited Metabolic Disease. 1986. X-1, X-2, X-3, X-4.
2619 Hackney IM. Autistic behaviour patterns in phenylketonuric children. Canadian Psychiatric Association journal. 1967. X-4.
2620 Han YJ, Lee DH, Kim JW. Newborn screening in Korea. The Southeast Asian journal of tropical medicine and public health. 2003. X-2, X-3, X-4.
2621 Hannon WH. Performance evaluation for screening laboratories of the Asia-Pacific region. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2622 Harding CO, et al. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2623 Hardy DT, et al. Quantitative determination of plasma phenylalanine and tyrosine by electrospray ionization tandem mass spectrometry. Annals of Clinical Biochemistry. 2002. X-2, X-3, X-4.
2624 Harris H. The development of Penrose's ideas in genetics and psychiatry. The British journal of psychiatry : the journal of mental science. 1974. X-1, X-2, X-3, X-4.
2625 Hayakawa H, Narisawa K, Arai N. Differential diagnosis of variant forms of hyperphenylalaninaemia by urinary pterins. Journal of Inherited Metabolic Disease. 1983. X-2, X-3, X-4.
2626 Hayashi T, Tsuchiya H, Naruse H. The stabilization of alpha-keto acids in biological samples using hydrazide gel column treatment. Clinica Chimica Acta. 1983. X-1, X-2, X-3, X-4.
2627 Hennermann JB, et al. Phenylketonuria and hyperphenylalaninemia in eastern Germany: A characteristic molecular profile and 15 novel mutations. Human Mutation. 2000. X-2, X-3, X-4.
2628 Hisashige A. Health economic analysis of the neonatal screening program in Japan. International Journal of Technology Assessment in Health Care. 1994. X-1, X-2, X-3, X-4.
2629 Hitzeroth HW. Prevention of genetic disabilities: Metabolic defects. Rehabilitation in South Africa. 1982. X-4.
2630 Hitzeroth HW, Niehaus CE, Brill SC. Phenylketonuria in South Africa: A report on the status quo. South African Medical Journal. 1995. X-2, X-3, X-4.
2631 Holtzman NA. Ethical issues in the prenatal diagnosis of phenylketonuria. Pediatrics. 1984. X-1, X-2, X-3, X-4.
2632 Holtzman NA, Howell RR, Lawson WG. Maternal phenylketonuria. Pediatrics. 1985. X-1, X-2, X-3, X-4.
2633 Holtzman NA, Mellits ED, Kallman CH. Neonatal screening for phenylketonuria. II. Age dependence of initial phenylalanine in infants with PKU. Pediatrics. 1974. X-1, X-2, X-3, X-4.
2634 Hoskins MN. Direct amino acid analyses of mozzarella cheese. Journal of the American Dietetic Association. 1985. X-1, X-2, X-3, X-4.
2635 Hutchesson ACJ, et al. A comparison of disease and gene frequencies of inborn errors of metabolism among different ethnic groups in the West Midlands, UK. Journal of Medical Genetics. 1998. X-4.
2636 Hutchesson ACJ, et al. Screening for tyrosinaemia type I. Archives of Disease in Childhood. 1996. X-2, X-3, X-4.
2637 Hwu WL, et al. Neonatal screening and monitoring system in Taiwan. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2638 Imashuku S, et al. Abnormal serum phenylalanine-tyrosine ratio and hyperferritinemia in malignant histiocytosis. Pediatric Hematology and Oncology. 1988. X-2, X-3, X-4.
2639 Ipsiroglu OS, et al. Transcultural pediatrics: Compliance and outcome of PKU patients from families with an immigration background. Wiener Klinische Wochenschrift. 2005. X-3, X-4.
2640 Jailkhani R, et al. Selective screening for inborn errors of metabolism in children: Single centre experience from Karnataka. Journal of Clinical and Diagnostic Research. 2008. X-2, X-3, X-4.
2641 Jeong JS, et al. Determination of phenylalanine in blood by high-performance anion-exchange chromatography-pulsed amperometric detection to diagnose phenylketonuria. Journal of Chromatography A. 2009. X-2, X-3, X-4.
2642 Johnson R, Gardner R, Kozlowski R. Phenylketonuria--oral manifestations. ASDC journal of dentistry for children. 1970. X-1, X-2, X-3, X-4.
2643 Joseph R, et al. Newborn screening in Singapore. The Southeast Asian journal of tropical medicine and public health. 1999. X-2, X-3, X-4.
2644 Jusiene R, Kucinskas V. Familial variables as predictors of psychological maladjustment in Lithuanian children with phenylketonuria. Medical Science Monitor. 2004. X-4.
2645 Kamaryt J, Mrskos A. Is the inhibition of glutamic-pyruvic transaminase by phenylalanine one of the causes of hypoglucosemia in phenylketonurics?. Acta Universitatis Carolinae. 1973. X-5.
2646 Karamifar H, et al. Incidence of neonatal hyperphenylalaninemia in Fars province, south Iran. Iranian Journal of Pediatrics. 2010. X-3, X-4.
2647 Kasper DC, et al. The National Austrian Newborn Screening Program - Eight years experience with mass spectrometry. Past, present, and future goals. Wiener Klinische Wochenschrift. 2010. X-2, X-3, X-4.
2648 Kaufman S. Experiencing classical enzymology in its prime. Protein science : a publication of the Protein Society. 1996. X-1, X-2, X-3, X-4.
2649 Kemper AR, et al. Primary care physicians' attitudes regarding follow-up care for children with positive newborn screening results. Pediatrics. 2006. X-2, X-3, X-4.
2650 Kesby GJ. Repeated adverse fetal outcome in pregnancy complicated by uncontrolled maternal phenylketonuria. Journal of Paediatrics and Child Health. 1999. X-3, X-4.
2651 Khatib IM, Hijazi SS. Phenylketonuria: Recent developments. Jordan Medical Journal. 1985. X-1.
2652 Khoury MJ, et al. Genetic test evaluation: Information needs of clinicians, policy makers, and the public. American Journal of Epidemiology. 2002. X-4.
2653 Kilbey MM, Harris RT. Behavioral, biochemical and maturation effects of early DL-para-chlorophenylalanine treatment. Psychopharmacologia. 1971. X-4.
2654 Kirkman HN. Newborn screening in North Carolina: the evolution of policy and practice. North Carolina medical journal. 2008. X-1, X-2, X-3, X-4.
2655 Kling S, Nash C, Jones D. Newborn screening in the 80's - The automation of follow-up. Journal of Medical Systems. 1988. X-1, X-2, X-3, X-4.
2656 Knutson LM, Leavitt RL, Sarton KR. Race, ethnicity and other factors influencing children's health and disability: Implications for pediatric physical therapists. Pediatric Physical Therapy. 1995. X-1, X-2, X-3, X-4.
2657 Koch R, et al. Treatment of maternal phenylketonuria. International Pediatrics. 1991. X-1, X-2, X-3, X-4.
2659 Koch R, Gross Friedman E, Wenz E. Maternal phenylketonuria. Journal of Inherited Metabolic Disease. 1986. X-1, X-2, X-3, X-4.
2661 Kochen W, Byrd DJ, Schurrle L. Proceedings: New aspects of tryptophan metabolism in untreated phenylketonuria and the urinary indole excretion in relation to phenylalanine content of semi-synthetic diets. Hoppe-Seyler's Zeitschrift fur physiologische Chemie. 1974. X-1, X-2, X-3, X-4.
2662 Koletzko B, et al. Omega-3 LC-PUFA supply and neurological outcomes in children with phenylketonuria (PKU). Journal of Pediatric Gastroenterology and Nutrition. 2009. X-4.
2663 Komrower GM. The philosophy and practice of screening for inherited diseases. Pediatrics. 1974. X-1, X-2, X-3, X-4.
2664 Kreis R, et al. Reproducibility of cerebral phenylalanine levels in patients with phenylketonuria determined by 1H-MR spectroscopy. Magnetic Resonance in Medicine. 2009. X-4.
2665 Kremensky I, et al. Laboratory diagnosis of inherited disorders and congenital anomalies in Bulgaria. Balkan Journal of Medical Genetics. 2000. X-2, X-3, X-4.
2666 Lagler FB, et al. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2667 Lagler FB, et al. Basic and Clinical Pharmacology and Toxicology. 2010. X-2, X-3, X-4.
2668 Langenbeck U, et al. Predicting the phenylalanine blood concentration from urine analyses. An approach to noninvasive monitoring of patients with phenylketonuria. Journal of Inherited Metabolic Disease. 2005. X-3, X-4.
2669 Langenbeck U, et al. Correlative study of mental and biochemical phenotypes in never treated patients with classic phenylketonuria. Brain Dysfunction. 1988. X-1, X-2, X-3, X-4.
2670 Langenbeck U, et al. Modelling the phenylalanine blood level response during treatment of phenylketonuria. Journal of Inherited Metabolic Disease. 2001. X-1, X-2, X-3, X-4.
2671 Largilliere C, Dhondt JL, Farriaux JP. Hepatic phenylalanine hydroxylase and dietary tolerance in hyperphenylalaninaemic patients. Journal of Inherited Metabolic Disease. 1986. X-4.
2672 Leandro J, et al. Molecular Genetics and Metabolism. 2009. X-1, X-2, X-3, X-4.
2673 Ledley FD, Grenett HE, DiLella AG. Gene transfer and expression of human phenylalanine hydroxylase. Science. 1985. X-2, X-3, X-4.
2674 Leuzzi V, et al. The pathogenesis of the white matter abnormalities in phenylketonuria. A multimodal 3.0 tesla MRI and magnetic resonance spectroscopy (<sup>1</sup>H MRS) study. Journal of Inherited Metabolic Disease. 2007. X-4.
2675 Levy HL, Ghavami M. Maternal phenylketonuria: A metabolic teratogen. Teratology. 1996. X-1, X-2, X-3, X-4.
2676 Levy HL, et al. Persistent mild hyperphenylalaninemia in the untreated state. A prospective study. The New England journal of medicine. 1971. X-4, X-5.
2677 Lin WD, et al. A pilot study of neonatal screening by electrospray ionization tandem mass spectrometry in Taiwan. Acta Paediatrica Taiwanica. 2001. X-1, X-2, X-3, X-4.
2678 Lindee MS. Genetic disease in the 1960s: A structural revolution. American Journal of Medical Genetics - Seminars in Medical Genetics. 2002. X-1, X-2, X-3, X-4.
2679 Lines DR. Letter: Urinary phenylalanine excretion in phenylketonuria and hyperphenylalaninemia. Acta Paediatrica Scandinavica. 1974. X-1, X-2, X-3, X-4.
2680 Lino PR, et al. FEBS Journal. 2009. X-4.
2681 Liu W, et al. Screening for tetrahydrobiopterin deficiency among hyperphenylalaninemia patients in Southern China. Chinese Medical Journal. 2002. X-2, X-3, X-4.
2682 Loo YH, Ritman P. Phenylketonuria and vitamin B6 function. Nature. 1967. X-1, X-2, X-3, X-4.
2683 Lord B, Wastell C, Ungerer J. Parent reactions to childhood phenylketonuria. Families, Systems and Health. 2005. X-2, X-3, X-4+.
2684 Lou HC, Guttler F, Lykkelund C. Decreased vigilance and neurotransmitter synthesis after discontinuation of dietary treatment for phenylketonuria in adolescents. European Journal of Pediatrics. 1985. X-3, X-4.
2685 Lubenow N, et al. Phenylketonuria screening with a fluorometric microplate assay. European Journal of Clinical Chemistry and Clinical Biochemistry. 1994. X-2, X-3, X-4.
2687 Lundstedt G, et al. Adjustment and intelligence among children with phenylketonuria in sweden. Acta Paediatrica, International Journal of Paediatrics. 2001. X-4.
2688 Maillot F, et al. A practical approach to maternal phenylketonuria management. Journal of Inherited Metabolic Disease. 2007. X-3, X-4.
2689 Mamas M, et al. The role of metabolites and metabolomics in clinically applicable biomarkers of disease. Archives of Toxicology. 2011. X-1, X-2, X-3, X-4.
2690 Martinez A, et al. Journal of Inherited Metabolic Disease. 2010. X-2, X-3, X-4.
2691 Martinez A, et al. Pteridines. 2009. X-2, X-3, X-4.
2692 Matsubara Y, Heininger JA, Lin YY. Improved diagnosis of classical vs atypical phenylketonuria by liquid chromatography. Clinical Chemistry. 1984. X-1, X-2, X-3, X-4.
2693 Matsuda I. Bioethical considerations in neonatal screening: Japanese experiences. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2694 McCabe ERB, McCabe L, Mosher GA. Newborn screening for phenylketonuria: Predictive validity as a function of age. Pediatrics. 1983. X-4.
2695 McInnes LA, et al. A genetic study of autism in Costa Rica: Multiple variables affecting IQ scores observed in a preliminary sample of autistic cases. BMC Psychiatry. 2005. X-2, X-3, X-4.
2696 McKean CM, Boggs DE. Influence of high concentrations of phenylalanine on the amino acids of cerebrospinal fluid and blood. Proceedings of the Society for Experimental Biology and Medicine. 1966. X-1, X-2, X-3, X-4.
2697 Meberg A, Johansen KB. Screening for neonatal hyperbilirubinaemia and ABO alloimmunization at the time of testing for phenylketonuria and congenital hypothyreosis. Acta Paediatrica, International Journal of Paediatrics. 1998. X-2, X-3, X-4.
2698 Meier DS, Weiner HL, Guttmann CRG. Time-Series Modeling of Multiple Sclerosis Disease Activity: A Promising Window on Disease Progression and Repair Potential?. Neurotherapeutics. 2007. X-1, X-2, X-3, X-4.
2699 Meyerson MD, Weddington GT. Syndromes, communicative disorders, and black children. Journal of the National Medical Association. 1986. X-1, X-2, X-3, X-4.
2700 Michals K, et al. Phenylalanine metabolites in treated phenylketonuric children. Journal of Inherited Metabolic Disease. 1986. X-4.
2701 Milstien S. Interconversion of 6- and 7-substituted tetrahydropterins via enzyme- generated 4a-hydroxytetrahydropterin intermediates. Methods in Enzymology. 1997. X-4.
2702 Morrow G 3rd. Latrogenesis imperfecta--a new pediatric problem. Pediatrics. 1975. X-1, X-2, X-3, X-4.
2703 Mukti AG, et al. A universal precautions education intervention for health workers in Sardjito and PKU Hospital Indonesia. The Southeast Asian journal of tropical medicine and public health. 2000. X-2, X-3, X-4.
2704 Mulder CJJ, Bartelsman JFWM. Case-finding in coeliac disease should be intensified. Best Practice and Research in Clinical Gastroenterology. 2005. X-1, X-2, X-3, X-4.
2705 Murphey RM. Phenylketonuria (PKU) and the single gene: An old story retold. Behavior Genetics. 1983. X-1, X-2, X-3, X-4.
2706 Nakamura K, Hattori K, Endo F. Newborn screening for lysosomal storage disorders. American Journal of Medical Genetics, Part C: Seminars in Medical Genetics. 2011. X-1, X-2, X-3, X-4.
2707 Narisawa K, Hayakawa H, Arai N. Diagnosis of variant forms of hyperphenylalaninemia using filter paper spots of urine. Journal of Pediatrics. 1983. X-1, X-2, X-3, X-4.
2708 Novotny EJ Jr, et al. In vivo measurement of phenylalanine in human brain by proton nuclear magnetic resonance spectroscopy. Pediatric Research. 1995. X-1, X-2, X-3, X-4.
2709 Ounap K, et al. Development of the phenylketonuria screening programme in Estonia. Journal of medical screening. 1998. X-2, X-3, X-4.
2710 Ozalp I, et al. Neonatal PKU screening in Turkey: 7 years experience in a developing country. Screening. 1995. X-1, X-2, X-3, X-4.
2711 Ozcebe H. The status of child health and child survival and development programs in Turkey. The Turkish journal of pediatrics. 1998. X-1, X-2, X-3, X-4.
2712 Padilla CD. Newborn screening in the Philippines. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2713 Palmer CG, et al. Fetal karyotype following ascertainment of fetal anomalies by ultrasound. Prenatal Diagnosis. 1987. X-2, X-3, X-4.
2714 Paro-Panjan D, Neubauer D. Congenital hypotonia: Is there an algorithm?. Journal of Child Neurology. 2004. X-1, X-2, X-3, X-4.
2715 Parvaneh K, Reza AM, Feisal R. Prevalence of seizure in PKU: An analytic historical study. Iranian Journal of Child Neurology. 2010. X-4.
2716 Pascucci T, et al. Journal of Inherited Metabolic Disease. 2010. X-2, X-3, X-4.
2717 Pasquier Rivero DA, et al. Experimental hyperphenilalanaemia and the thyroid gland. Acta anatomica. 1972. X-2, X-3, X-4.
2718 Paul DB. Contested conceptions: PKU in the postwar discourse on reproduction. Medicina nei secoli. 2002. X-1, X-2, X-3, X-4.
2719 Paul DB. Patient advocacy in newborn screening: Continuities and discontinuities. American Journal of Medical Genetics, Part C: Seminars in Medical Genetics. 2008. X-1, X-2, X-3, X-4.
2720 Peng H, et al. Retroviral-mediated gene transfer and expression of human phenylalanine hydroxylase in primary mouse hepatocytes. Proceedings of the National Academy of Sciences of the United States of America. 1988. X-1, X-2, X-3, X-4.
2721 Peng H, Chen G. Neural precursors derived from human embryonic stem cells. Science in China. 2005. X-1, X-2, X-3, X-4.
2722 Peterson AG, et al. Maternal PKU--a problem born of success. The Ohio State medical journal. 1984. X-1, X-2, X-3, X-4.
2723 Pho LT, et al. Attitudes and Psychosocial Adjustment of Unaffected Siblings of Patients with Phenylketonuria. American Journal of Medical Genetics. 2004. X-1, X-2, X-3, X-4.
2724 Pines M. Heredity insurance. The New York times magazine. 1978. X-1, X-2, X-3, X-4.
2725 Polekhina G, et al. Crystal structure of maleylacetoacetate isomerase/glutathione transferase zeta reveals the molecular basis for its remarkable catalytic promiscuity. Biochemistry. 2001. X-1, X-2, X-3, X-4.
2726 Pollitt RJ. International perspectives on newborn screening. Journal of Inherited Metabolic Disease. 2006. X-1, X-2, X-3, X-4.
2727 Pontoni G, et al. Diagnosis and follow-up of inborn errors of amino acid metabolism: Use of proton magnetic resonance of biological fluids. Amino Acids. 1996. X-1, X-2, X-3, X-4.
2728 Porta F, et al. Impact of metabolic control on bone quality in phenylketonuria and mild hyperphenylalaninemia. Journal of Pediatric Gastroenterology and Nutrition. 2011. X-4.
2729 Porta F, et al. Phalangeal Quantitative Ultrasound in Children with Phenylketonuria: A Pilot Study. Ultrasound in Medicine and Biology. 2008. X-4.
2730 Porter IH. The detection of carriers and the problem of heterogeneity in genetic counseling. Birth defects original article series. 1970. X-4.
2731 Pratt OE. Transport inhibition in the pathology of phenylketonuria and other inherited metabolic diseases. Journal of Inherited Metabolic Disease. 1982. X-1, X-2, X-3, X-4.
2732 Puntis JWL, et al. Aluminium and hyperphenylalaninaemia in parenterally fed infants. Intensive Therapy and Clinical Monitoring. 1989. X-2, X-3, X-4.
2733 Rashed MS, Rahbeeni Z, Ozand PT. Application of electrospray tandem mass spectrometry to neonatal screening. Seminars in Perinatology. 1999. X-2, X-3, X-4.
2734 Ratrisawadi V, et al. Neonatal screening program in Rajavithi Hospital, Thailand. The Southeast Asian journal of tropical medicine and public health. 1999. X-2, X-3, X-4.
2735 Reilly P. There's another side to genetic screening. Prism. 1976. X-1, X-2, X-3, X-4.
2736 Rhoades E, King P. Public health explores expanding newborn screening for cystic fibrosis, congenital adrenal hyperplasia, and medium-chain acyl coenzyme A dehydrogenase deficiency (MCAD). The Journal of the Oklahoma State Medical Association. 2001. X-1, X-2, X-3, X-4.
2737 Rivero A, et al. Comparison of two different methods for measurement of phenylalanine in dried blood spots. Clinical Chemistry and Laboratory Medicine. 2000. X-2, X-3, X-4.
2738 Roato I, et al. Bone impairment in phenylketonuria is characterized by circulating osteoclast precursors and activated T cell increase. PLoS ONE. 2010. X-2, X-3, X-4.
2739 Roe CR, Mochel F. Anaplerotic diet therapy in inherited metabolic disease: Therapeutic potential. Journal of Inherited Metabolic Disease. 2006. X-1, X-2, X-3, X-4.
2740 Rohr FJ, et al. Use of the Guthrie bacterial inhibition assay to monitor blood phenylalanine for dietary treatment of phenylketonuria. Screening. 1996. X-4.
2741 Rollins G. Life-long adherence to diet recommended for PKU patients. Report on medical guidelines & outcomes research. 2001. X-1, X-2, X-3, X-4.
2742 Ross LF. Mandatory versus voluntary consent for newborn screening?. Kennedy Institute of Ethics Journal. 2010. X-1, X-2, X-3, X-4.
2743 Rottoli A, Lista G, Zecchini G. Plasma selenium levels in treated phenylketonuric patients. Journal of Inherited Metabolic Disease. 1985. X-4.
2744 Sahota A, Blair JA, Barford PA. Neonatal screening for dihydropteridine reductase deficiency. Journal of Inherited Metabolic Disease. 1985. X-1, X-2, X-3, X-4.
2745 Sahota A, Leeming RJ, Blair JA. Partial dihydropteridine reductase deficiency and mental retardation. Journal of Inherited Metabolic Disease. 1986. X-1, X-2, X-3, X-4.
2746 Samilchuk E, et al. Mutation and linkage analysis in genetic counseling for phenylketonuria in Kuwait. Medical Principles and Practice. 1999. X-4.
2747 Sandler M. Inborn errors and disturbances of central neurotransmission (with special reference to phenylketonuria). Journal of Inherited Metabolic Disease. 1982. X-1, X-2, X-3, X-4.
2748 Sanjurjo P, Ruiz JI, Montejo M. Inborn errors of metabolism with a protein-restricted diet: Effect on polyunsaturated fatty acids. Journal of Inherited Metabolic Disease. 1997. X-4.
2749 Saxena A. Issues in newborn screening. Genetic Testing. 2003. X-1, X-2, X-3, X-4.
2750 Schild S. Parents of children with PKU. Children today. 1972. X-1, X-2, X-3, X-4.
2751 Schlesinger K, Schreiber RA, Griek BJ. Effects of experimentally induced phenylketonuria on seizure susceptibility in mice. Journal of comparative and physiological psychology. 1969. X-1, X-2, X-3, X-4.
2753 Schuler A, et al. Twenty years of experience with phenylketonuria in Hungary. International Pediatrics. 1996. X-1, X-2, X-3, X-4.
2754 Schulpis KH, Papakonstantinou E, Kalogirou S. Biotinidase activity in patients with phenylketonuria. Journal of Inherited Metabolic Disease. 1995. X-4.
2755 Schumacher U, et al. High concentrations of phenylalanine stimulate peroxisome proliferator-activated receptor : Implications for the pathophysiology of phenylketonuria. Neurobiology of Disease. 2008. X-1, X-2, X-3, X-4.
2756 Scriver CR. Diagnosis and treatment: interpreting the positive screening test in the newborn infant. Pediatrics. 1967. X-1, X-2, X-3, X-4.
2757 Scriver CR. PKU beyond: when do costs exceed benefits?. Pediatrics. 1974. X-1, X-2, X-3, X-4.
2758 Scriver CR. Garrod's foresight. our hindsight. Journal of Inherited Metabolic Disease. 2001. X-1, X-2, X-3, X-4.
2759 Scriver CR, et al. PAHdb 2003: What a locus-specific knowledgebase can do. Human Mutation. 2003. X-2, X-3, X-4.
2760 Sempere A, et al. Study of inborn errors of metabolism in urine from patients with unexplained mental retardation. Journal of Inherited Metabolic Disease. 2010. X-1, X-2, X-3, X-4.
2761 Shakespeare L, et al. Elevated phenylalanine on newborn screening: Follow-up testing may reveal undiagnosed galactosaemia. Annals of Clinical Biochemistry. 2010. X-1, X-2, X-3, X-4.
2762 Sharrard M, Pollitt R. Metabolic screening in children: newborn screening for metabolic diseases past, present and future. Paediatrics and Child Health. 2007. X-1, X-2, X-3, X-4.
2763 Shaw DWW, Weinberger E, Maravilla KR. Cranial MR in phenylketonuria. Journal of Computer Assisted Tomography. 1990. X-1, X-2, X-3, X-4.
2764 Shintaku H, et al. Tetrahydrobiopterin, responsive, hyperphenylalaninemia without biopterin deficiency. Pteridines. 2000. X-4, X-5.
2765 Sierra SS, et al. Basic and Clinical Pharmacology and Toxicology. 2010. X-1, X-2, X-3, X-4.
2766 Simon E, et al. Evaluation of quality of life and description of the sociodemographic state in adolescent and young adult patients with phenylketonuria (PKU). Health and quality of life outcomes. 2008. X-4.
2767 Simopoulos AP. Genetic screening: programs, principles, and research--thirty years later. Reviewing the recommendations of the Committee for the Study of Inborn Errors of Metabolism (SIEM). Public health genomics. 2009. X-1, X-2, X-3, X-4.
2768 Simpson N, et al. The cost-effectiveness of neonatal screening for cystic fibrosis: An analysis of alternative scenarios using a decision model. Cost Effectiveness and Resource Allocation. 2005. X-1, X-2, X-3, X-4.
2769 Smith AM, et al. Phenylketonuria affects the selenium status of children, adolescents, and young adults. Journal of Trace Elements in Experimental Medicine. 1994. X-4.
2770 Smith I, Beasley M, Ades A. Intellectual progress and quality of phenylalanine control in early treated children with phenylketonuria. International Pediatrics. 1991. X-4, X-5.
2772 Song F, et al. Phenylketonuria mutations in Northern China. Molecular Genetics and Metabolism. 2005. X-2, X-3, X-4.
2773 Song YZ, et al. Selective screening for inborn errors of metabolism and secondary methylmalonic aciduria in pregnancy at high risk district of neural tube defects: A human metabolome study by GC-MS in China. Clinical Biochemistry. 2008. X-2, X-3, X-4.
2774 Speer A, Dahl HH, Riess O. Typing of families with classical phenylketonuria using three alleles of the HindIII linked restriction fragment polymorphism, detectable with a phenylalanine hydroxylase cDNA probe. Family typing for PKU by linked HindIII RFLP. Clinical Genetics. 1986. X-2, X-3, X-4.
2775 Starfield B, Holtzman NA. A comparison of effectiveness of screening for phenylketonuria in the United States, United Kingdom and Ireland. The New England journal of medicine. 1975. X-2, X-3, X-4.
2776 Stemerdink NBA, et al. Prefrontal dysfunction in early and continuously treated phenylketonuria. Developmental Neuropsychology. 1999. X-4.
2777 Storhaug K, Vandvik IH. Frambu Health Centre: promoting family focused care for disabled children. International journal of rehabilitation research. 1983. X-1, X-2, X-3, X-4.
2778 Sumi-Ichinose C, et al. Advanced research on dopamine signaling to develop drugs for the treatment of mental disorders: Regulation of dopaminergic neural transmission by tyrosine hydroxylase protein at nerve terminals. Journal of Pharmacological Sciences. 2010. X-1, X-2, X-3, X-4.
2779 Szybowska M, et al. Assessing the informational needs of adolescents with a genetic condition: What do they want to know?. Journal of Genetic Counseling. 2007. X-1, X-2, X-3, X-4.
2780 Takarada Y, et al. Rapid single-base mismatch detection in genotyping for phenylketonuria. Applied Biochemistry and Biotechnology - Part B Molecular Biotechnology. 2003. X-1, X-2, X-3, X-4.
2781 Tan IK, Gajra B, Lim MSF. Study of inherited metabolic disorders in Singapore - 13 Years experience. Annals of the Academy of Medicine Singapore. 2006. X-1, X-2, X-3, X-4.
2782 Tanzer F, Sancaktar M, Buyukkayhan D. Neonatal screening for biotidinidase deficiency: Results of a 1-year pilot study in four cities in central Anatolia. Journal of Pediatric Endocrinology and Metabolism. 2009. X-2, X-3, X-4.
2783 Targum SD, Lang W. Neurobehavioral problems associated with phenylketonuria. Psychiatry (Edgemont). 2010. X-4.
2784 Teigen K, Flydal MI, Martinez A. Pteridines. 2009. X-1, X-2, X-3, X-4.
2785 Tenenholz B, et al. A simplified PKU gene carrier detection test using fasting blood. Clinical Genetics. 1983. X-4.
2786 Terr AI, Allen RJ, Vanselow NA. Immunologic responsiveness in phenylketonuria. JAMA : the journal of the American Medical Association. 1966. X-4.
2787 Terwolbeck K, et al. Increased plasma T<sub>4</sub>-levels in children with low selenium state due to reduced type I iodothyronine 5'deiodinase activity?. Journal of Trace Elements and Electrolytes in Health and Disease. 1993. X-2, X-3, X-4.
2788 Therrell BL. Challenges and opportunities in establishing and maintaining newborn screening systems. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2789 Therrell BL, Brown LO. Computerized newborn screening in Texas - A multiple microcomputer approach. Journal of Medical Systems. 1988. X-1, X-2, X-3, X-4.
2790 Thomason MJ, et al. A systematic review of evidence for the appropriateness of neonatal screening programmes for inborn errors of metabolism. Journal of Public Health Medicine. 1998. X-1, X-2, X-3, X-4.
2791 Thompson AJ, et al. Neurological deterioration in young adults with phenylketonuria. Lancet. 1990. X-3.
2792 Thompson GN, et al. Pregnancy in phenylketonuria: Dietary treatment aimed at normalising maternal plasma phenylalanine concentration. Obstetrical and Gynecological Survey. 1992. X-3, X-4, X-5.
2793 Thony B, Heizmann CW, Mattei MG. Chromosomal location of two human genes encoding tetrahydrobiopterin-metabolizing enzymes: 6-Pyruvoyl-tetrahydropterin synthase maps to 11q22.3-q23.3, and pterin-4alpha- carbinolamine dehydratase maps to 10q22. Genomics. 1994. X-2, X-3, X-4.
2794 Tiwary CM. Neonatal screening for metabolic and endocrine diseases. The Nurse practitioner. 1987. X-1, X-2, X-3, X-4.
2795 Tizard J. National and international studies in mental retardation. The British journal of medical psychology. 1971. X-1, X-2, X-3, X-4.
2796 Toft PB, et al. Brain magnetic resonance imaging in children with optimally controlled hyperphenylalaninaemia. Journal of Inherited Metabolic Disease. 1994. X-4.
2797 Tomandl J, et al. Determination of urinary pterins for the diagnosis of hyperphenylalaninemia variant forms. Scripta Medica Facultatis Medicae Universitatis Brunensis Masarykianae. 1999. X-3, X-4.
2798 Tomatir AG, et al. Midwives' approach to genetic diseases and genetic counseling in Denizli, Turkey. Journal of Genetic Counseling. 2006. X-1, X-2, X-3, X-4.
2799 Tomatir AG, et al. Nurses' professed knowledge of genetics and genetic counseling. Tohoku Journal of Experimental Medicine. 2006. X-1, X-2, X-3, X-4.
2800 Tuchman M, et al. Acidic metabolites of phenylalanine in plasma of phenylketonurics. Biochemical Medicine. 1985. X-4.
2801 Tuerck JM, Buist NRM. Pacific Northwest Regional Newborn Screening: A paradigm of prevention. Journal of Medical Systems. 1988. X-1, X-2, X-3, X-4.
2802 Van Gool CJAW, Van Houwelingen AC, Hornstra G. The essential fatty acid status in phenylketonuria patients under treatment. Journal of Nutritional Biochemistry. 2000. X-4.
2803 van Spronsen FJ, et al. Phenylalanine tolerance can already reliably be assessed at the age of 2 years in patients with PKU. Journal of Inherited Metabolic Disease. 2009. X-4.
2804 Velazquez A, et al. Diagnosis of inborn errors of metabolism. Archives of Medical Research. 2000. X-1, X-2, X-3, X-4.
2805 Verkerk PH, et al. Impaired prenatal and postnatal growth in Dutch patients with phenylketonuria. Archives of Disease in Childhood. 1994. X-4.
2806 Verma IC. Burden of genetic disorders in India. Indian journal of pediatrics. 2000. X-1, X-2, X-3, X-4.
2807 Vohra K, et al. Metabolic screening via heel stick versus umbilical arterial catheter - A comparison. Clinical Pediatrics. 1996. X-1, X-2, X-3, X-4.
2808 Vorhees CV, Butcher RE, Berry HK. Reduced activity in rats with induced phenylketonuria. Developmental psychobiology. 1972. X-2, X-3, X-4.
2809 Vugteveen I, et al. Serum vitamin B12 concentrations within reference values do not exclude functional vitamin B12 deficiency in PKU patients of various ages. Molecular Genetics and Metabolism. 2011. X-4.
2810 Wada Y, Nakajima H, Irie M. Newborn mass screening in Japan - 1984. Japanese Journal of Human Genetics. 1984. X-1, X-2, X-3, X-4.
2812 Wang W, et al. Development of a newborn screening laboratory quality assurance system in Shandong, China. The Southeast Asian journal of tropical medicine and public health. 2003. X-1, X-2, X-3, X-4.
2813 Wang ZX, Zhou ZS, Yu WM. Brain white matter lesions of children with phenylketonuria before and after treatment. [Chinese, English]. Chinese Journal of Contemporary Pediatrics. 2006. X-4, X-5.
2814 Wasant P, Liammongkolkul S, Srisawat C. Neonatal screening for congenital hypothyroidism and phenylketonuria at Siriraj Hospital, Mahidol University, Bangkok, Thailand--a pilot study. The Southeast Asian journal of tropical medicine and public health. 1999. X-2, X-3, X-4.
2815 Weglage J, et al. Progression of cerebral white matter abnormalities in early treated patients with phenylketonuria during adolescence. Neuropediatrics. 1997. X-4.
2816 Weglage J, et al. Neurological deterioration in adult phenylketonuria. Journal of Inherited Metabolic Disease. 2000. X-1, X-2, X-3, X-4, X-5.
2817 Weglage J, et al. Non-PKU hyperphenylalaninemia: Is dietary treatment necessary?. International Pediatrics. 1996. X-1, X-2, X-3, X-4.
2818 Wendel U, Koppelkamm M, Hummel W. Enzymatic phenylalanine estimation for the management of patients with phenylketonuria. Clinica Chimica Acta. 1991. X-2, X-3, X-4, X-5.
2819 Wendel U, et al. A new approach to the newborn screening for hyperphenylalaninemias: Use of L-phenylalanine dehydrogenase and microtiter plates. Clinica Chimica Acta. 1990. X-1, X-2, X-3, X-4.
2820 Whitehead H, et al. Maternal phenylketonuria 1987 to 1993, pregnancy outcome and early infant development: The Northern Ireland experience. British Journal of Obstetrics and Gynaecology. 1996. X-4, X-5.
2821 Wilcken B. Mini-Symposium: Newborn screening for inborn errors of metabolism - Clinical effectiveness. Journal of Inherited Metabolic Disease. 2006. X-1, X-2, X-3, X-4.
2822 Wiley V, et al. Newborn screening--is it really that simple?. The Southeast Asian journal of tropical medicine and public health. 2003. X-2, X-3, X-4.
2823 Wilfond BS, Fost N. The cystic fibrosis gene: Medical and social implications for heterozygote detection. Journal of the American Medical Association. 1990. X-1, X-2, X-3, X-4.
2824 Williamson M, Koch R, Henderson R. Phenylketonuria in school age retarded children. American Journal of Mental Deficiency. 1968. X-4, X-9.
2825 Wong HB. Paediatric liver disorders in Singapore. Annals of the Academy of Medicine, Singapore. 1986. X-1, X-2, X-3, X-4.
2826 Wraith JE. Lysosomal disorders. Seminars in Neonatology. 2002. X-1, X-2, X-3, X-4.
2827 Wu JT. Screening for inborn errors of amino acid metabolism. Annals of Clinical and Laboratory Science. 1991. X-1, X-2, X-3, X-4.
2828 Wuu KD, et al. Screening for inherited metabolic diseases and congenital hypothyroidism in 4,744 mentally retarded school children in Taiwan. Japanese Journal of Human Genetics. 1988. X-2, X-3, X-4.
2829 Yan S, Wu G. Connecting mutant phenylalanine hydroxylase with phenylketonuria. Journal of Clinical Monitoring and Computing. 2008. X-2, X-3, X-4.
2830 Yanling Y, et al. A clinical investigation of 228 patients with phenylketonuria in mainland China. The Southeast Asian journal of tropical medicine and public health. 1999. X-1, X-4.
2831 Yarbro MT, Anderson JA. L-tryptophan metabolism in phenylketonuria. The Journal of pediatrics. 1966. X-4.
2832 Yuwiler A, Geller E. Influence of mode and duration of phenylalanine administration on biochemical parameters in rats of various ages. Developmental psychobiology. 1970. X-2, X-3, X-4.
2833 Zekanowski C, et al. Mutations of the phenylalanine hydroxylase gene mild hyperphenylalaninemia: A novel mutation in exon 3. Human Mutation. 1997. X-2, X-3, X-4.
2834 Zelnicek E, Slama J. Phenylpyruvate and o-hydroxyphenylacetate in phenylketonuric urine. Clinica chimica acta. international journal of clinical chemistry. 1971. X-4.
2836 Levy HL, et al. Maternal mild hyperphenylalaninaemia: an international survey of offspring outcome. Lancet. 1994. X-5.
2837 Mabry CC, et al. Maternal Phenylketonuria. A Cause of Mental Retardation in Children without the Metabolic Defect. N Engl J Med. 1963. X-3.
2839 Trefz FK, Aulela-Scholz C, Blau N. Successful treatment of phenylketonuria with tetrahydrobiopterin. Eur J Pediatr. 2001. X-3.
2840 Steinfeld R, et al. Tetrahydrobiopterin monotherapy for phenylketonuria patients with common mild mutations. Eur J Pediatr. 2002. X-3.
2841 Steinfeld R, et al. Efficiency of long-term tetrahydrobiopterin monotherapy in phenylketonuria. J Inherit Metab Dis. 2004. X-3.
2842 Feldmann R, et al. Frontal lobe-dependent functions in treated phenylketonuria: blood phenylalanine concentrations and long-term deficits in adolescents and young adults. J Inherit Metab Dis. 2005. X-4, X-5.
2843 Bick U, et al. White matter abnormalities in patients with treated hyperphenylalaninaemia: magnetic resonance relaxometry and proton spectroscopy findings. Eur J Pediatr. 1993. X-3, X-5.
2845 Hegge KA, et al. Sapropterin: a new therapeutic agent for phenylketonuria. Ann Pharmacother. 2009. X-1.
2846 Botkin JR. Evidence-based reviews of newborn-screening opportunities. Pediatrics. 2010. X-1.
2850 Kirkham JJ, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010. X-4.
2852 Pietz J, et al. The dynamics of brain concentrations of phenylalanine and its clinical significance in patients with phenylketonuria determined by in vivo 1H magnetic resonance spectroscopy. Pediatr Res. 1995. X-3, X-5.
2863 Bishop DV. Which neurodevelopmental disorders get researched and why?. PLoS One. 2010. X-2, X-3, X-4.
2864 Campistol J, et al. Neurocognitive function in mild hyperphenylalaninemia. Developmental Medicine & Child Neurology. 2011. X-1, X-2, X-3.
2865 Chace DH, Spitzer AR. Altered metabolism and newborn screening using tandem mass spectrometry: Lessons learned from the bench to bedside. Current Pharmaceutical Biotechnology. 2011. X-1, X-2, X-3, X-4.
2866 Cotugno G, et al. Adherence to diet and quality of life in patients with phenylketonuria. Acta Paediatrica, International Journal of Paediatrics. 2011. X-4.
2868 Dawson C, et al. Dietary treatment of phenylketonuria: the effect of phenylalanine on reaction time. J Inherit Metab Dis. 2011. X-4, X-5.
2869 Diamond A. Biological and social influences on cognitive control processes dependent on prefrontal cortex. Neurology and Neurosurgery. Elsevier. (P.O. Box 211, Amsterdam 1000 AE, Netherlands): Netherlands. 2011:319-339. X-1, X-2, X-3, X-4.
2870 Draganov G, Ribarova F, Peykov P. L-tyrosine containing food supplements - Health claims. Pharmacia. 2009. X-2, X-3, X-4.
2871 Elespuru RK. Assessment of heritable genetic effects using new genetic tools and sentinels in an era of personalized medicine. Environ Mol Mutagen. 2011. X-1, X-2, X-3, X-4.
2873 Embury JE, et al. Hepatitis virus protein X-phenylalanine hydroxylase fusion proteins identified in PKU mice treated with AAV-WPRE vectors. Gene therapy & molecular biology. 2008. X-2, X-3, X-4.
2878 Koura HM, et al. A long-term study of bone mineral density in patients with phenylketonuria under diet therapy. Archives of Medical Science. 2011. X-4.
2879 Kumar N. Acute and subacute encephalopathies: Deficiency states (nutritional). Seminars in Neurology. 2011. X-1, X-2, X-3, X-4.
2883 Leuzzi V, et al. Phenotypic variability, neurological outcome and genetics background of 6-pyruvoyl-tetrahydropterin synthase deficiency. Clinical Genetics. 2010. X-2, X-3, X-4.
2887 Mussa A, et al. Bone impairment and osteoclastogenesis in phenylalanine hydroxylase deficiency. Molecular Genetics and Metabolism. 2010. X-4.
2888 Mutze U, et al. Transition of young adults with phenylketonuria from pediatric to adult care. Journal of Inherited Metabolic Disease. 2011. X-4.
2889 Ohashi A, et al. Membrane transport of sepiapterin and dihydrobiopterin by equilibrative nucleoside transporters: a plausible gateway for the salvage pathway of tetrahydrobiopterin biosynthesis. Mol Genet Metab. 2011. X-2, X-3, X-4.
2890 Okano Y, et al. Molecular characterization of phenylketonuria and tetrahydrobiopterin- responsive phenylalanine hydroxylase deficiency in Japan. Journal of Human Genetics. 2011. X-4.
2891 Opladen T, et al. Diagnosis of tetrahydrobiopterin deficiency using filter paper blood spots: Further development of the method and 5 years experience. Journal of Inherited Metabolic Disease. 2011. X-2, X-3, X-4.
2893 Rakovich T, et al. Queuosine deficiency in eukaryotes compromises tyrosine production through increased tetrahydrobiopterin oxidation. Journal of Biological Chemistry. 2011. X-2, X-3, X-4.
2894 Ribas GS, et al. Oxidative stress in phenylketonuria: What is the evidence?. Cellular and Molecular Neurobiology. 2011. X-1, X-2, X-3, X-4.
2895 Roato I, et al. Increased circulating osteoclast precursors and activated T cells are involved in bone impairment in phenylketonuria. Osteoporosis International. 2011. X-4.
2897 Sanayama Y, et al. Experimental evidence that phenylalanine is strongly associated to oxidative stress in adolescents and adults with phenylketonuria. Molecular Genetics and Metabolism. 2011. X-4.
2898 Schulpis KH, et al. Glutamine, ornithine, citrulline and arginine levels in children with phenylketonuria: The diet effect. Clinical Biochemistry. 2011. X-4.
2899 Serono M. Sapropterin dihydrochloride. Australian Prescriber. 2011. X-1, X-2, X-3, X-4, X-5, X-6.
2901 Sitta A, et al. Evidence that L-carnitine and selenium supplementation reduces oxidative stress in phenylketonuric patients. Cell Mol Neurobiol. 2011. X-4.
2902 Sladkevicius E, et al. Cost effectiveness of establishing a neonatal screening programme for phenylketonuria in Libya. Appl Health Econ Health Policy. 2010. X-2, X-3, X-4.
2903 Staudigl M, et al. The interplay between genotype, metabolic state and cofactor treatment governs phenylalanine hydroxylase function and drug response. Human Molecular Genetics. 2011. X-2, X-3, X-4.
2904 Sundermann B, et al. Tackling frontal lobe-related functions in PKU through functional brain imaging: A Stroop task in adult patients. Journal of Inherited Metabolic Disease. 2011. X-4, X-5.
2906 ten Hoedt AE, et al. High phenylalanine levels directly affect mood and sustained attention in adults with phenylketonuria: a randomised, double-blind, placebo-controlled, crossover trial. J Inherit Metab Dis. 2011. X-3.
2907 Ten Hoedt AE, et al. MY PKU: Increasing self-management in patients with phenylketonuria. A randomized controlled trial. Orphanet Journal of Rare Diseases. 2011. X-4.
2908 ten Hoedt AE, et al. Parenting a child with phenylketonuria or galactosemia: implications for health-related quality of life. J Inherit Metab Dis. 2011. X-2, X-3, X-4.
2909 Van Rijn M, et al. Adult patients with well-controlled phenylketonuria tolerate incidental additional intake of phenylalanine. Annals of Nutrition and Metabolism. 2011. X-3, X-4.
2910 Vugteveen I, et al. Serum vitamin B12 concentrations within reference values do not exclude functional vitamin B12 deficiency in PKU patients of various ages. Mol Genet Metab. 2011. X-4.
2911 Warlich M, et al. Lentiviral ‘gene ontology’ (LEGO) vectors enable highly efficient ex vivo transduction of hepatocytes suitable for cell transplantation. Journal of Hepatology. 2011. X-2, X-3, X-4.
2912 Whiteley P, et al. The ScanBrit randomized controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutritional Neuroscience. 2010. X-2, X-3, X-4.
2913 Yagi H, et al. Complete restoration of phenylalanine oxidation in phenylketonuria mouse by a self-complementary adeno-associated virus vector. J Gene Med. 2011. X-2, X-3, X-4.
2914 Yi SH, et al. A cross-sectional study of docosahexaenoic acid status and cognitive outcomes in females of reproductive age with phenylketonuria. J Inherit Metab Dis. 2011. X-4, X-5.
2915 Zellner M, et al. A proteomics study reveals a predominant change in MaoB expression in platelets of healthy volunteers after high protein meat diet: Relationship to the methylation cycle. Journal of Neural Transmission. 2011. X-2, X-3, X-4.
2931 Macdonald A, et al. Adjusting diet with sapropterin in phenylketonuria: what factors should be considered?. Br J Nutr. 2011. X-1.
2932 Bik-Multanowski M, Pietrzyk JJ. Blood phenylalanine clearance and BH(4)-responsiveness in classic phenylketonuria. Mol Genet Metab. 2011. X-4, X-5.
2933 Giugliani L, et al. Tetrahydrobiopterin responsiveness of patients with phenylalanine hydroxylase deficiency. J Pediatr (Rio J). 2011. X-4.
2934 Lachmann RH. Sapropterin hydrochloride: enzyme enhancement therapy for phenylketonuria. Therapeutic Advances in Endocrinology and Metabolism. 2011. X-1, X-2, X-3, X-4.
2940 Blau N, et al. Optimizing the use of sapropterin (BH(4)) in the management of phenylketonuria. Mol Genet Metab. 2009. X-1.
2941 Burton BK, et al. Tetrahydrobiopterin therapy for phenylketonuria in infants and young children. J Pediatr. 2011. X-3.