# Meta-analysis Methods

The association of blood phenylalanine levels with IQ was meta-analyzed using a hierarchical mixed-effects model, estimated using Markov chain Monte Carlo (MCMC) methods1. The advantages of using a Bayesian approach to meta-analysis were recognized over a decade ago2 and they have been applied extensively ever since3, 4, 5, 6, 7, 8, 9, 10. It allows for straightforward probabilistic inference across studies, and readily combines both fixed and random effects. In contrast to the more indirect measures of inference afforded by classical methods, all inference from Bayesian models is in the form of probability statements that describe the uncertainty in the unknown quantities of interest (θ), given the information at hand (y):

Pr ( θ y ) ∝ Pr ( y θ ) Pr ( θ )

The left side of this equation is the posterior distribution of all unknown parameters in the model, while right side shows that this posterior quantity is the product of a data likelihood and the prior distribution (i.e. before data are observed) of the model. While the use of priors allows for the incorporation of extant information into the analysis, we used uninformative priors on all parameters, allowing the results from the included studies to provide all the evidence.

Using random effects for meta-analysis permits us to abandon the tenuous assumption that the effects across studies are independent and identically distributed. Rather, we view them as exchangeable samples from a “population” of PKU studies. This conditional independence (i.e., conditional on population parameters) assumption avoids either having to combine studies in a single estimate (which assumes they are identical) or keeping them entirely separate (which assumes they are completely different), but rather, allows for some mixture of the two extremes. In contrast, fixed effects models force one of these unlikely extremes. Moreover, the degree to which studies are pooled is dictated by the heterogeneity across studies, rather than via arbitrary weighting factors.

We specified random effects for the intercept and slope parameters of a linear relationship between blood Phe level and IQ. Importantly, this allowed each study to have its own parameters, each sampled from a notional population of parameters. Those with smaller sample sizes were automatically shrunk towards the population means for each parameter, with larger studies influencing the estimate of the population mean more than being influenced by it. In turn, the magnitude of the effect (i.e. slope) was specified partly as a function of a fixed effect for whether measurements of Phe were carried out during the critical period. Hence, the overall model was a hierarchical mixed effects model. Bayesian hierarchical models are very easily estimated using Markov chain Monte Carlo (MCMC) methods11.

The core of the model is a linear relationship between the expected IQ (μ) and Phe (x):

μ_i_ = β_0 j [ i ]_ + β_1 i_ x_i_

The subscript j[i] denote parameters for study j corresponding to observation i. Hence, both the intercept and slope are allowed to vary by study. Note that by “observation” we refer here not to individuals, but to groups of individuals within a study that share a characteristic. For example, within the same study, one group of individuals might have been measured for Phe in the critical period, and others not; these groups were considered separate observations in this analysis. One study12 reported a range of Phe measurements, rather than a single value, so we imputed values by randomly sampling at every iteration from a uniform distribution across the reported range.

Though age was included as an additional linear predictor in early versions of the model, it did not appear to be an important covariate, and models in which it was included did not exhibit good convergence. Hence, age was omitted from the final model. We suspect that the important aspects of age might be adequately characterized by the four combinations of historical or concurrent Phe measurement and measurement in or outside the critical period.

The intercept was modeled as a random effect, where each study is assumed to be an exchangeable sample from a population of PKU studies:

β_0 j [ i ]_ ∼ N ( μ_β_ , τ_β_ )

The slope of the relationship included a study-level random effect and fixed effects corresponding to whether the Phe measurement was concurrent with the measurement of IQ (an indicator variable):

β_1 i_ = α_0 i_ + α_1_ crit_j [ i ]_ α_0 i_ ∼ N ( μ_α_ , τ_α_ )

Finally, the expected value of IQ was used to model the distribution of observed IQ values y_i_, with error described by the inverse variance τ

y_i_ ∼ N ( μ_i_ , τ )

Twelve studies provided only summarized data, with no individual measurements of Phe or IQ. For studies that provided only data summaries, we were unable to estimate the quantities as specified above. Instead, we employed reported correlation coefficients to obtain additional inference regarding the relationship of these variables. Inference regarding the linear relationship (slope) between Phe and IQ can be obtained from the correlation coefficient (ρ), using the Fisher transformation. Here, the hyperbolic function can be used to transform the correlation to a normally-distributed random variable:

arctanh ( r_j_ ) ∼ N ( arctanh ( ρ_j_ ) , (1)/(sqrt(n_j_ − 3)) )

where r_j_ is the reported Pearson correlation from study j, with a standard error that is solely a function of the corresponding sample size (for a Spearman correlation, the standard error is the inverse square root of n-2). This provides a measure of precision for the reported correlations, which in turn becomes a measure of precision for the slope of the relationship between Phe and IQ. The expected value of the slope is obtained in the model by converting ρ using the fundamental relationship:

β_1 j_ = ρ_j_ ( (s_y j_)/(s_x j_) )

where s_xj_ and s_yj_ are the reported standard deviations of the Phe levels and IQs, respectively, for study j.

The full model structure is illustrated in Figure F-1. Note the distinction between the influence of studies with group-summarized data and that of studies with individual-level data.

Figure F-1 Directed acyclic graph (DAG) showing the meta-analysis model structure

Note: Unfilled circles represent stochastic nodes, shaded circles represent data, triangles represent deterministic nodes and squares represent factor potentials (arbitrary log-probability terms).The large enclosing square represents the collection of n unique studies in the meta-analysis; the smaller enclosing box represents the distinct groups (i.e. subsets that had distinct covariates) within each study. Different information was contributed depending on whether the study provided group- summarized data (n_1_ studies) or individual-level data (n_2_ studies), as indicated by the dashed boxes; group-level data provided inference on the slope parameter only, while individual-level data informed both the slope and intercept.

This directed acyclic graph (DAG) illustrates the meta-analysis model structure. A DAG1 is the most common way to graphically describe a hierarchical model. The arrows represent parent-child relationships, such that the arrow points to a dependency of the element from which the arrow originates. For example, alpha0 has two dependencies, mu and tau_slope, which represent the mean and inverse-variance of a normal distribution. Unfilled circles represent stochastic nodes, shaded circles represent data, triangles represent deterministic nodes and squares represent factor potentials (arbitrary log-probability terms that typically act as constraints on the model). The large enclosing square represents the collection of n unique studies in the meta-analysis; the smaller enclosing box represents the distinct groups (i.e. subsets that had distinct covariates) within each study. Different information was contributed depending on whether the study provided group-summarized data (n1 studies) or individual-level data (n2 studies), as indicated by dashed boxes; group-level data provided inference on the slope parameter only, while individual-level data informed both the slope and intercept.

All stochastic parameters were specified using diffuse prior distributions. For continuous parameters on the real line (e.g. linear model coefficients), a normal distribution with mean zero and precision (inverse-variance) 0.01 was used. For precision parameters, the standard deviation was modeled uniformly on the interval (0, 1000) and then transformed to inverse variance; this provides a better non-informative prior than modeling the precision directly 13.

In order to evaluate the effect of particular levels of Phe on the likelihood of cognitive impairment, we chose a threshold value of IQ to bound the definition of impairment. While discretizing a continuous variable into one dichotomous variable is subjective and problematic, we felt that for a standardized measure like IQ, a boundary of one standard deviation below the mean (IQ=85) was a reasonable choice. This threshold value was used to define indicator variables that were set to one if the value of the predicted IQ was below 85 during the current iteration of the MCMC sampler, and zero otherwise. Hence, the total number of ones divided by the number of MCMC iterations represents a posterior probability of observing IQ<85. This corresponds to the integral of the posterior distribution of IQ up to an 85 score. To illustrate the variation of this probability in response to Phe, this probability was calculated for a range of blood Phe levels from 200 to 3000 μmol/L, in increments of 200. This was done for critical period and non-critical period Phe measurement, under both the historical and concurrent measurement models.

This model was coded in PyMC version 2.1^14^, which implements several MCMC algorithms for fitting Bayesian hierarchical models. The model was run for one million iterations, with the first 900,000 discarded as a burn-in interval. The remaining sample was thinned by a factor of ten to account for autocorrelation, yielding 10,000 samples for inference. Convergence of the chain was checked through visual inspection of the traces of all parameters, and via the Geweke15 diagnostic. Posterior predictive checks1 were performed, which compare data simulated from the posterior distribution to the observed data. This exercise showed no substantial lack of fit for any of the studies included in the dataset.

## References

1 Gelman Andrew, Carlin John B, Stern Hal S, Rubin Donald B. 2003. Bayesian Data Analysis, Second Edition (Chapman & Hall/CRC Texts in Statistical Science). 2nd ed. Chapman and Hall/CRC. July. 29.
2 Smith T, Spiegelhalter D. Bayesian approaches to random-effects meta-analysis: a comparative study. Statistics in Medicine. January. 1. 1995;14:2685-2699. [pmid: 8619108].
3 Tweedie RL, Scott DJ, Biggerstaff JB, Mengersen KL. Bayesian meta-analysis, with application to studies of ETS and lung cancer. Lung cancer (Amsterdam, Netherlands). Suppl 1. March. 1996;14:S171-94.
4 Sutton AJ, Abrams KR. Bayesian methods in meta-analysis and evidence synthesis. Statistical Methods In Medical Research. January. 1. 2001;10(4):277-303. [pmid: 11491414].
5 Brophy J, Joseph L. 2001. β-blockers in congestive heart failure: a Bayesian meta-analysis. Annals of Internal Medicine. January. 1.
6 Brophy JM, Bélisle P. 2003. Evidence for Use of Coronary Stents: A Hierarchical Bayesian Meta-Analysis. Annals of Internal Medicine.
7 Babapulle M, Joseph L, Bélisle P, Brophy J. 2004. A hierarchical Bayesian meta-analysis of randomised clinical trials of drug-eluting stents. The Lancet. January. 1.
8 Kaizar Eloise E, Greenhouse Joel B, Seltman Howard, Kelleher Kelly. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Clinical Trials. April. 1. 2006;3(2):73-90. [doi: 10.1191/1740774506cn139oa]. [pmid: 16773951].
9 Afilalo Jonathan, Duque Gustavo, Steele Russell, Jukema J Wouter, de Craen Anton J M, Eisenberg Mark J. Statins for Secondary Prevention in Elderly Patients. Journal of the American College of Cardiology. January. 2008;51(1):37-45. [doi: 10.1016/j.jacc.2007.06.063]. [pmid: 18174034].
10 Baldwin David, Woods Robert, Lawson Richard, Taylor David. Efficacy of drug treatments for generalised anxiety disorder: systematic review and meta-analysis. BMJ. Clinical research ed. 2011;342:d1199. [pmid: 21398351].
11 Brooks Steve, Gelman Andrew, Galin Jones, Xiao-Li Meng. 2010. Handbook of Markov Chain Monte Carlo. Methods and Applications. Chapman & Hall/CRC. June. 1.
12 Seashore MR, Friedman E, Novelly RA, Bapat V. Loss of intellectual function in children with phenylketonuria after relaxation of dietary phenylalanine restriction. Pediatrics. February. 1985;75(2):226-232. [pmid: 3969322].
13 Gelman Andrew. Prior distributions for variance parameters in hierarchical models. Bayesian Analysis. 2006;1(3):515-533.
14 Patil A, Huard D, Fonnesbeck C. PyMC: Bayesian Stochastic Modelling in Python. Journal Of Statistical Software. January. 1. 2010;35(4):1-80. [pmid: 21603108].
15 Geweke J, Berger JO, Dawid AP. Evaluating the accuracy of sampling-based approaches to the calculation of posterior moments. In Bayesian Statistics 4. 1992.