# Quality of the Literature

## Randomized Trials

Table E-1 Quality assessment of randomized trials addressing adjuvant treatment of PKU

Domain | Selection bias & confounding | | | | | Performance bias | Attrition bias | | | Detection bias | | | | Reporting bias | | Final rating
Author, Year | Random assignment adequate | Allocation adequately concealed | Baseline characteristics similar between groups | Analysis controlled for baseline differences | Recruitment strategy differed across groups | Impact of concurrent interventions ruled out | High rate of attrition | Attrition resulted in group differences | ITT analysis | Outcome assessors blinded to intervention status | Inclusion/exclusion criteria measured with valid & reliable instruments | Interventions assessed with valid & reliable measures | Outcomes assessed with valid & reliable measures | Outcomes and harms pre-specified | Pre-specified outcomes reported
BH4
Trefz 2009^1^ | + | + | + | + | - | + | - | NA | - | + | + | + | + | - | + | Fair
Levy 2007^2^ | + | + | + | NA | - | + | - | NA | + | + | + | + | + | + | + | Good
LNAAs
Schindeler 2007^3^ | + | + | NA | NA | - | + | - | NA | + | + | + | + | + | - | + | Fair
Matalon 2007^4^ | - | - | NA | NA | - | + | - | NA | NA | + | + | + | + | - | + | Poor

+=yes/positive, -=no/negative; LNAAs=large neutral amino acids

## Open Label Trials

Table E-2 Quality assessment of open label trials addressing adjuvant treatment of PKU

Author, Year | Consecutive enrollment | Incomplete outcome data adequately addressed | Standard approach for outcome assessment | Final rating
BH4
Burton 2011^5^ | + | + | - | Fair
Vernon 2010^6^ | + | + | + | Good
Lee 2008^7^ | + | + | + | Good
LNAAs
Matalon 2006^8^ | - | + | - | Poor

+=yes, -=no; LNAAs=large neutral amino acids

## BH4 Case Series

Table E-3 Quality assessment of case series addressing BH4

Domain | Selection bias & confounding | Performance bias | Attrition bias | | Detection bias | | | | | | Reporting bias | | Final Rating
Author, Year | Confounding and modifying variables considered | Impact of concurrent interventions ruled out | High rate of attrition | Attrition resulted in group differences | Outcome assessors blinded | Inclusion/exclusion assessed with valid & reliable measures | Interventions measured with valid & reliable measures | Outcomes assessed with valid & reliable measures | Confounders assessed with valid & reliable measures | Accounted for secular trends & regression to mean | Outcomes and harms pre-specified | Pre-specified outcomes reported
Trefz 2011^9^ | - | - | - | NA | - | - | + | + | - | NA | - | + | Poor
Burton 2010^10^ | + | + | - | NA | - | + | - | - | + | NA | - | + | Poor
Burlina 2009^11^ | - | + | - | NA | - | + | + | + | + | - | - | + | Poor
Lambruschini 2005^12^ | + | + | + | + | - | + | + | + | + | NA | + | + | Poor

+=yes, -=no, NA=not applicable

## BH4 Cohort Studies

Table E-4 Quality assessment of cohort studies addressing BH4

Domain | Selection bias & confounding | | | | | | | Performance bias | Attrition bias | | | | Detection bias | | | | | Reporting bias | | Final Rating
Author, Year | Allocation balanced between groups | Inclusion/exclusion criteria uniformly applied | Comparison group appropriate | Baseline characteristics similar between groups | Analysis controlled for baseline differences | Recruitment strategy differed between groups | Confounding/modifying variables taken into account | Impact of concurrent interventions ruled out | Length of follow-up different between groups | High rate of attrition | Attrition resulted in group differences | ITT analysis | Outcome assessors blinded | Inclusion/exclusion assessed with valid & reliable measures | Interventions measured with valid & reliable measures | Outcomes assessed with valid & reliable measures | Confounders assessed with valid & reliable measures | Outcomes and harms pre-specified | Pre-specified outcomes reported
Humphrey 2011^13^ | - | + | + | - | - | - | + | + | - | - | - | - | - | + | + | + | - | - | + | Poor

+=yes, -=no, NA=not applicable

## Harms Reporting in Studies of BH4 and LNAAs

Table E-5 Quality assessment of studies reporting harms of adjuvant therapies for PKU

Author, Year | Harms predefined using standardized/precise definitions | Serious events precisely defined | Severe events precisely defined | Deaths/group specified | Active harms collection | Passive harms collection | Specified who collected harms | Training/background of individuals(s) collecting harms specified | Timing of harms collection specified | Standard scale for harms collection used | Specified whether reported harms encompass all events collected | Number participants withdrawing/lost to followup reported by group | Total number participants affected by harms specified by group | Number for each type of harm specified by group | Analyses for harms data specified
BH4
Humphrey 2011^13^
Burton 2011^14^ | - | + | + | + | + | + | - | - | + | - | + | + | + | + | +
Burton 2010^10^ | - | - | - | - | - | - | - | - | - | - | - | NA | - | - | -
Vernon 2010^6^ | - | - | - | - | - | - | - | - | - | - | - | + | - | - | -
Burlina 2009^11^ | - | - | - | - | - | - | - | - | - | - | - | NA | - | - | -
Trefz 2009^1^ | - | U | - | - | + | + | + | + | + | - | + | + | + | + | +
Lee 2008^7^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | U
Levy 2007^2^ | - | - | - | - | - | - | - | - | - | - | - | NA | - | - | -
Lambruschini 2005^12^ | - | - | - | - | U | U | + | - | - | - | NA | + | NA | NA | NA
LNAAs
Schindeler 2007^3^ | - | - | - | - | - | + | - | - | - | U | - | NA | - | - | -
Matalon 2007^4^ | - | - | - | - | - | - | - | - | - | - | - | NA | - | - | -
Matalon 2006^8^ | - | - | - | - | - | - | - | - | - | - | - | NA | - | - | -

+= yes/positive; -=no/negative; LNAA=large neutral amino acids; NA=not applicable; U=unsure

## Studies Addressing Phe Levels and IQ

Table E-6 Quality assessment of studies addressing Phe levels and IQ in individuals with PKU

Author, Year | Recruitment approach clearly documented | Impact of concurrent intervention ruled out | High rate of attrition | All eligible participants included in analysis | Attrition resulted in group differences | Inclusion/exclusion criteria measured with valid &reliable instruments | Outcomes assessed with valid & reliable instruments | Confounders assessed with valid & reliable instruments | Outcomes pre-specified | Pre-specified outcomes reported | Final Rating
Viau 2011^15^ | - | + | - | - | NA | + | + | + | + | + | Fair
Azadi 2009^16^ | - | + | - | - | NA | + | + | - | + | + | Poor
Anastasoie 2008^17^ | - | - | NA | - | - | + | + | - | + | + | Poor
Wasserstein 2006^18^ | - | + | - | - | NA | + | - | - | + | + | Poor
Pfaender 2005^19^ | - | + | - | - | NA | + | + | - | + | + | Poor
Rupp 2001^20^ | + | + | + | - | NA | + | + | - | + | + | Poor
Weglage 2001^21^ | - | + | NA | - | NA | - | + | - | + | + | Poor
Griffiths 2000^22^ | - | + | NA | - | NA | + | + | + | + | + | Fair
Weglage 2000^23, 24^ | - | + | - | - | NA | + | + | + | + | + | Fair
Cerone 1999 25 | - | + | NA | - | NA | + | + | - | + | + | Poor
Weglage 1995^26-28^ | - | + | - | - | NA | CD | + | - | + | + | Poor
Leuzzi 1998^29^ | + | + | - | - | NA | + | + | - | + | + | Fair
Ris 1997^30, 31^ | + | + | - | + | NA | + | + | + | + | + | Good
Jones 1995^32^ | - | + | - | - | NA | + | + | - | + | + | Poor
Schmidt 1994^33^ | - | + | + | - | CD | + | + | - | + | + | Poor
Welsh 1990^34^ | - | + | - | - | NA | + | + | - | + | + | Poor
Seashore 1985^35^ | + | + | - | - | NA | + | + | - | + | + | Fair

+=yes, -=no, CD=cannot determine, NA=not applicable

## References

1 Trefz FK, Burton BK, Longo N, et al. Efficacy of sapropterin dihydrochloride in increasing phenylalanine tolerance in children with phenylketonuria: a phase III, randomized, double-blind, placebo-controlled study. J Pediatr. May. 2009;154(5):700-7. [pmid: 19261295].
2 Levy HL, Milanowski A, Chakrapani A, et al. Efficacy of sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) for reduction of phenylalanine concentration in patients with phenylketonuria: a phase III randomised placebo-controlled study. Lancet. Aug. 11. 2007;370(9586):504-10. [pmid: 17693179].
3 Schindeler S, Ghosh-Jerath S, Thompson S, et al. The effects of large neutral amino acid supplements in PKU: an MRS and neuropsychological study. Mol Genet Metab. May. 2007;91(1):48-54. [pmid: 17368065].
4 Matalon R, Michals-Matalon K, Bhatia G, et al. Double blind placebo control trial of large neutral amino acids in treatment of PKU: effect on blood phenylalanine. J Inherit Metab Dis. Apr. 2007;30(2):153-8. [pmid: 17334706].
5 Burton BK, Nowacka M, Hennermann JB, et al. Safety of extended treatment with sapropterin dihydrochloride in patients with phenylketonuria: Results of a phase 3b study. Mol Genet Metab. Aug. 2011;103(4):315-22. [pmid: 21646032].
6 Vernon HJ, Koerner CB, Johnson MR, et al. Introduction of sapropterin dihydrochloride as standard of care in patients with phenylketonuria. Mol Genet Metab. Jul. 2010;100(3):229-33. [pmid: 20418136].
7 Lee P, Treacy EP, Crombez E, et al. Safety and efficacy of 22 weeks of treatment with sapropterin dihydrochloride in patients with phenylketonuria. Am J Med Genet A. Nov. 15. 2008;146A(22):2851-9. [pmid: 18932221].
8 Matalon R, Michals-Matalon K, Bhatia G, et al. Large neutral amino acids in the treatment of phenylketonuria (PKU). J Inherit Metab Dis. Dec. 2006;29(6):732-8. [pmid: 16988900].
9 Trefz FK, Scheible D, Frauendienst-Egger G. Long-term follow-up of patients with phenylketonuria receiving tetrahydrobiopterin treatment. J Inherit Metab Dis. 2010. Mar. 9. [pmid: 20217238].
10 Burton BK, Bausell H, Katz R, et al. Sapropterin therapy increases stability of blood phenylalanine levels in patients with BH4-responsive phenylketonuria (PKU). Mol Genet Metab. Oct-Nov. 2010;101(2-3):110-4. [pmid: 20638313].
11 Burlina A, Blau N. Effect of BH(4) supplementation on phenylalanine tolerance. J Inherit Metab Dis. Feb. 2009;32(1):40-5. [pmid: 19067227].
12 Lambruschini N, Perez-Duenas B, Vilaseca MA, et al. Clinical and nutritional evaluation of phenylketonuric patients on tetrahydrobiopterin monotherapy. Mol Genet Metab. Dec. Suppl 1. 2005;86:S54-60. [pmid: 16040265].
13 Humphrey M, Nation J, Francis I, et al. Effect of tetrahydrobiopterin on Phe/Tyr ratios and variation in Phe levels in tetrahydrobiopterin responsive PKU patients. Mol Genet Metab. Sep-Oct. 2011;104(1-2):89-92. [pmid: 21624843].
14 Duch DS, Smith GK. Biosynthesis and function of tetrahydrobiopterin. Journal of nutritional biochemistry. Aug. 1991. 1991;2(8):411-23.
15 Viau KS, Wengreen HJ, Ernst SL, et al. Correlation of age-specific phenylalanine levels with intellectual outcome in patients with phenylketonuria. J Inherit Metab Dis. Aug. 2011;34(4):963-71. [pmid: 21556836].
16 Azadi B, Seddigh A, Tehrani-Doost M, et al. Executive dysfunction in treated phenylketonuric patients. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):360-8. [pmid: 19221856].
17 Anastasoaie V, Kurzius L, Forbes P, et al. Stability of blood phenylalanine levels and IQ in children with phenylketonuria. Mol Genet Metab. Sep-Oct. 2008;95(1-2):17-20. [pmid: 18703366].
18 Wasserstein MP, Snyderman SE, Sansaricq C, et al. Cerebral glucose metabolism in adults with early treated classic phenylketonuria. Mol Genet Metab. Mar. 2006;87(3):272-7. [pmid: 16343970].
19 Pfaendner NH, Reuner G, Pietz J, et al. MR imaging-based volumetry in patients with early-treated phenylketonuria. AJNR Am J Neuroradiol. Aug. 2005;26(7):1681-5. [pmid: 16091513].
20 Rupp A, Kreis R, Zschocke J, et al. Variability of blood-brain ratios of phenylalanine in typical patients with phenylketonuria. J Cereb Blood Flow Metab. Mar. 2001;21(3):276-84. [pmid: 11295882].
21 Weglage J, Wiedermann D, Denecke J, et al. Individual blood-brain barrier phenylalanine transport determines clinical outcome in phenylketonuria. Ann Neurol. Oct. 2001;50(4):463-7. [pmid: 11601498].
22 Griffiths PV, Demellweek C, Fay N, et al. Wechsler subscale IQ and subtest profile in early treated phenylketonuria. Arch Dis Child. Mar. 2000;82(3):209-15. [pmid: 10685922].
23 Weglage J, Grenzebach M, Pietsch M, et al. Behavioural and emotional problems in early-treated adolescents with phenylketonuria in comparison with diabetic patients and healthy controls. J Inherit Metab Dis. Jul. 2000;23(5):487-96. [pmid: 10947203].
24 Weglage J, Funders B, Wilken B, et al. School performance and intellectual outcome in adolescents with phenylketonuria. Acta Paediatr. Jun-Jul. 1993;82(6-7):582-6. [pmid: 8338995].
25 Cerone R, Schiaffino MC, Di Stefano S, et al. Phenylketonuria: diet for life or not?. Acta Paediatr. Jun. 1999;88(6):664-6. [pmid: 10419254].
26 Weglage J, Pietsch M, Denecke J, et al. Regression of neuropsychological deficits in early-treated phenylketonurics during adolescence. J Inherit Metab Dis. Aug. 1999;22(6):693-705. [pmid: 10472530].
27 Weglage J, Pietsch M, Funders B, et al. Deficits in selective and sustained attention processes in early treated children with phenylketonuria--result of impaired frontal lobe functions?. Eur J Pediatr. Mar. 1996;155(3):200-4. [pmid: 8929728].
28 Weglage J, Pietsch M, Funders B, et al. Neurological findings in early treated phenylketonuria. Acta Paediatr. Apr. 1995;84(4):411-5. [pmid: 7795351].
29 Leuzzi V, Rinalduzzi S, Chiarotti F, et al. Subclinical visual impairment in phenylketonuria. A neurophysiological study (VEP-P) with clinical, biochemical, and neuroradiological (MRI) correlations. J Inherit Metab Dis. Jun. 1998;21(4):351-64. [pmid: 9700592].
30 Ris MD, Weber AM, Hunt MM, et al. Adult psychosocial outcome in early-treated phenylketonuria. J Inherit Metab Dis. Aug. 1997;20(4):499-508. [pmid: 9266385].
31 Ris MD, Williams SE, Hunt MM, et al. Early-treated phenylketonuria: adult neuropsychologic outcome. J Pediatr. Mar. 1994;124(3):388-92. [pmid: 8120707].
32 Jones SJ, Turano G, Kriss A, et al. Visual evoked potentials in phenylketonuria: association with brain MRI, dietary state, and IQ. J Neurol Neurosurg Psychiatry. Sep. 1995;59(3):260-5. [pmid: 7673953].
33 Schmidt E, Rupp A, Burgard P, et al. Sustained attention in adult phenylketonuria: the influence of the concurrent phenylalanine-blood-level. J Clin Exp Neuropsychol. Oct. 1994;16(5):681-8. [pmid: 7836491].
34 Welsh MC, Pennington BF, Ozonoff S, et al. Neuropsychology of early-treated phenylketonuria: specific executive function deficits. Child Dev. Dec. 1990;61(6):1697-713. [pmid: 2083493].
35 Seashore MR, Friedman E, Novelly RA, et al. Loss of intellectual function in children with phenylketonuria after relaxation of dietary phenylalanine restriction. Pediatrics. Feb. 1985;75(2):226-32. [pmid: 3969322].