# Tools Used To Assess the Quality of the Literature

Quality Assessment Form: Studies Addressing IQ and Phe Levels

Quality Assessment Form: Before-and-After Studies

Quality Assessment Form: RCTs and Other Intervention Studies

Quality Assessment Form: Harms Reporting