# Evidence Tables

Table C-1 Adjuvant treatment for phenylketonuria (PKU) – BH4 evidence tables

Table C-2 Adjuvant treatment for phenylketonuria (PKU) – LNAA evidence tables

Table C-3 Studies addressing Phe levels and IQ