# Data Extraction Forms

Treatment for Phenylketonuria (PKU): Abstract Review Form

Treatment for Phenylketonuria (PKU): Full Text Review Form