# Search Strategies

[Last updated August 1, 2011]

Table A-1 MEDLINE search strategies (pubmed gov interface)

Search terms | | Search results
#1 | phenylketonurias[mh] OR phenylketonuria[tiab] OR phenylketonurias[tiab] OR phenylalanine hydroxylase deficiency[tiab] OR phenylalanine hydroxylase/deficiency[mh] OR pku[tiab] OR hyperphenylalaninemia[tiab] | 6949
#2 | therapy[sh] OR pharmaceutical preparations[mh] OR therapeutics[mh] OR diet therapy[mh] OR “diet therapy”[Subheading] OR diet[tiab] OR dietary[tiab] OR 5,6,7,8-tetrahydrobiopterin[nm] OR sapropterin[tiab] OR tetrahydrobiopterin[tiab] OR bh4[tiab] OR kuvan[tiab] OR amino acids, neutral[mh] OR large neutral amino acid[tiab] OR large neutral amino acids[tiab] OR lnaa[tiab] | 6,456,812
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 2281
#4 | #3 AND editorial[pt] | 23
#5 | #3 AND letter[pt] | 89
#6 | #3 AND comment[pt] | 48
#7 | #3 AND case reports[pt] | 260
#8 | #3 AND review[pt] | 315
#9 | #3 AND news[pt] | 6
#10 | #3 AND practice guideline[pt] | 6
#11 | #3 AND meta-analysis[pt] | 5
#12 | #3 AND historical article[pt] | 18
#13 | #3 AND jsubsetk | 2
#14 | #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 | 699
#15 | #3 NOT #14 | 1582

Key: jsubsetk consumer health subset; [la] language; [mh] medical subject heading; [nm] substance name; [sh] subheading; [tiab] keyword in title or abstract.

Table A-2 CINAHL search strategies (EBSCO Host interface)

Search terms | | Search results
#1 | (MH “Phenylketonuria+”) OR phenylketonuria OR hyperphenylalaninemia OR pku OR phenylalanine hydroxylase deficiency | 385
#2 | (MH “Therapeutics+”) OR therapeutics OR (MH “Drug Therapy+”) OR drug therapy OR (MH “Amino Acids+”) OR (MH “Nutritional Support+”) OR (MH “Natural and Biologically Based Therapies+”) OR (MH “Diet+”) OR (MH “Diet Therapy+”) OR (MH “Dietary Supplements+”) OR diet OR diet therapy OR dietary OR sapropterin OR tetrahydrobiopterin OR bh4 OR kuvan OR large neutral amino acids OR lnaa | 744,844
#3 | #1 AND #2 | 234
#4 | #3 AND limiters: English language; Human | 86
#5 | #3 AND limiters: English language; Human; Exclude MEDLINE records | 9

Table A-3 EMBASE Drugs and Pharmacology search strategies (Ovid interface)

Search terms | | Search results
#1 | (phenylketonuria or pku or hyperphenylalaninemia).mp or exp phenylketonuria/ or exp hyperphenylalaninemia/ | 7703
#2 | (therapy or therapies or treatment or treatments or management or diet or dietary or medical food or medical foods or nutriceutical or nutraceutical or therapeutic or therapeutics or sapropterin or tetrahydrobiopterin or bh4 or kuvan or large neutral amino acid or large neutral amino acids or lnaa).mp. or exp therapy/ or sapropterin/ or tetrahydrobiopterin/ or kuvan/ | 7,754,746
#3 | 1 and 2 | 3983
#4 | limit 3 to human and English language | 2527
#5 | 4 and review.pt | 445
#6 | 4 and conference paper.pt | 221
#7 | 4 and editorial.pt | 39
#8 | 4 and letter.pt | 72
#9 | 4 and note.pt | 42
#10 | 4 and short survey.pt | 36
#11 | 4 and case report/ | 266
#12 | 4 and practice guideline/ | 46
#13 | 4 and systematic review/ | 8
#14 | 4 and meta analysis/ | 6
#15 | 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 | 1104
#16 | 4 not 15 | 1423

Key: / all fields; exp explode term; .mp map term as keyword; .pt publication type.

Table A-4 AGRICOLA results (National Agricultural Library interface, keyword search)

Search terms | | Search results
#1 | (phenylketonuria phenylketonurias pku hyperphenylalaninemia) AND (therapy therapies treatment treatments management diet diets dietary medicine medication medications therapeutic therapeutics sapropterin tetrahydrobiopterin bh4 kuvan large neutral amino acid large neutral amino acids lnaa) Note: limited to English language, terms searched as any of these, keywords anywhere | 262

Table A-5 PsycINFO results (CSA Illumina interface)

Search terms | | Search results
#1 | DE=phenylketonuria OR phenylketonuria OR “phenylalanine hydroxylase deficiency” OR pku OR hyperphenylalaninemia | 1963
#2 | DE=“drug therapy” OR DE=“medical treatment general” OR “dietary restraint” OR “medical management” OR “diet therapy” OR dietary OR “drug therapy” OR sapropterin OR tetrahydrobiopterin OR bh4 OR kuvan OR “large neutral amino acid” OR “large neutral amino acids” OR lnaa | 127,501
#3 | #1 and #2 | 377
#4 | limit #3 to human and English language | 314
#5 | #4 AND (PT=(abstract collection) or PT=(authored book) or PT=(bibliography) or PT=(book) or PT=(chapter) or PT=(classic book) or PT=(column/opinion) or PT=(comment/reply) or PT=(dissertation abstract) or PT=(dissertation) or PT=(edited book) or PT=(editorial) or PT=(electronic collection) or PT=(encyclopedia entry) or PT=(encyclopedia) or PT=(handbook/manual) or PT=(letter) or PT=(obituary) or PT=(publication information) or PT=(reference book) or PT=(reprint) or PT=(review-book) or PT=(review-media) or PT=(review-software) or PT=(textbook/study guide) or PT=(conference proceedings)) | 113
#6 | #4 AND (PT=(journal article) or PT=(journal) or PT=(peer reviewed journal) or PT=(peer-reviewed status-unknown)) | 207^*^

Key: DE descriptor; PT publication type

* articles may be indexed as more than one publication type