# Appendixes

Appendix A Search Strategies

Appendix B Data Extraction Forms

Appendix C Evidence Tables

Appendix D Tools Used To Assess the Quality of the Literature

Appendix E Quality of the Literature

Appendix F Meta-analysis Methods

Appendix G Excluded Studies

Appendix H Studies Addressing Executive Function

Appendix I Studies Addressing Maternal PKU

Appendix J Summary of New Drug Application Studies of Sapropterin

Appendix K Recent Conference Abstracts Addressing Adjuvant Treatment