# Acronyms and Abbreviations

ADHD: Attention deficit hyperactivity disorder
AE: Adverse effects
AHRQ: Agency for Healthcare Research and Quality
BCI: Bayesian credible intervals
CI: Confidence interval
DQ: Developmental quotient
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
G: Group
IQ: Intelligence quotient
KQ: Key Question
LNAAs: Large neutral amino acids
MCMC: Markov chain Monte Carlo
Mg/dl: Milligram/deciliter
Mg/kg/d: Milligrams/kilogram/day
N,n: Number
NA: Not applicable
NDA: New drug application
NIH: National Institutes of Health
NR: Not reported
PAH: Phenylalanine hydroxylase
PET: Positron emission tomography
Phe: Phenylalanine
PKU: Phenylketonuria
RCT: Randomized controlled trial
TEP: Technical Expert Panel
TOO: Task Order Officer
Tx: Treatment