# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

Dr. Mary Beth Bauer was instrumental in completing evidence tables and verifying the accuracy of data extracted into tables.

Ms. Allison Glasser assisted with managing the day-to-day work of the review and developing meeting materials, tables, and appendixes.

Ms. Sharana Jones helped with coordinating project workflow, developing and formatting tables, and coordinating meetings.

Mr. Yichuan Wang, Ms. Sanura Latham, and Ms. Leah Vance assisted with formatting tables and appendixes.