# Technical Expert Panel

Teresa J. Brady, Ph.D.

Patient Representative

Jeffrey R. Curtis, M.D., M.P.H.

Assistant Professor

Division of Clinical Immunology and Rheumatology

Associate Director

Center for Education and Research on Therapeutics of MSK disorders

University of Alabama at Birmingham

Birmingham, AL

Marion McDonagh, Pharm.D.

Assistant Professor

Informatics and Clinical Epidemiology

Oregon Health & Science University

Portland, OR

Christopher T. Ritchlin, M.D., M.P.H.

Internal Medicine, Rheumatology

School of Medicine and Dentistry

University of Rochester

Rochester, NY