# Results

## Introduction

Figure 1 depicts the disposition of identified articles. We included 258 published articles reporting on 211 studies: 31 head-to-head randomized controlled trials (RCTs), 1 head-to-head nonrandomized controlled trial, 44 placebo-controlled trials, 28 meta-analyses or systematic reviews, and 107 observational studies. Our findings include studies rated good or fair for internal validity, unless a particular study rated poor provides some unique information that we judged to be of interest. Most studies were of fair quality; we designate in the text only those of good or poor quality. Evidence tables for included studies, by Key Question (KQ), can be found in Appendix E.

Figure 1 Disposition of articles (PRISMA figure)

KQ, key question; n, number of studies; PRIMSA, Preferred Reporting Items for Systematic Reviews and Meta Analyses

* The first number listed includes all references identified in both the original and update reports. The number in parentheses indicates references identified in the update report only.

Figure 1 is a Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) flow diagram that documents the disposition of the articles reviewed for this review. There were 3,868 citations identified from searches across databases, of which 1,912 are new to this update report. Additionally, 357 articles (161 articles indentified in the update report only), were detected from manually reviewing the reference lists of pertinent review articles, from dossiers, from peer review, and from public comment. Of the total 4,225 abstracts screened (2,073 abstracts screened in the update report only), 3,173 citations were excluded (1,476 citations excluded in the update report only). Working from 1,052 articles retrieved for full text review (597 articles retrieved for the update report only), 794 were excluded (465 were excluded in the update report only) at this stage. Of the studies excluded at the full text review 4 (1 from the update report) were excluded because the article was not published in English, 150 (90 from the update report) were excluded because the outcomes were not of interest, 87 (27 from the update report) were excluded because the pharmaceutical intervention was not of interest, 50 (27 from the update report) were excluded because it was not the correct population, 140 (56 from the update report) were excluded for wrong publication type, 326 (236 from the update report) were excluded for wrong study design, one (zero from the update report) was excluded because the full text article could not be retrieved, and 36 (28 from the update report) were of poor quality and therefore excluded. We included 258 published articles (132 from the update report) reporting on 211 studies. Most included studies were relevant for more than one Key Question. For Key Question 1 a total of 125 studies (62 from the update) were included; 30 of the Key Question 1 includes (13 new to the update report) were included in the Key Question 1 quantitative synthesis. For Key Question 2 a total of 80 studies (47 new to the update report) were included. For Key Question 3, 201 studies (101 new to the update report) were included; 42 of the included Key Question 3 studies (22 new to the update report) were included in the Key Question 3 quantitative synthesis. For Key Question 4 6 studies were included (2 new to the update report).

Of the 211 included studies, 104 (49 percent) were supported by pharmaceutical companies; 42 (20 percent) were funded by governmental or independent funds; and 20 (10 percent) were supported by a combination of pharmaceutical and government funding. We could not determine the source of support for 45 (21 percent) studies.

This chapter is organized by Key Question. We then present findings in order by class of drugs and combinations of drugs as appropriate to the particular key question. Generally, the chapter is organized using the following categories: individual oral disease-modifying antirheumatic drug (DMARD) versus oral DMARD, oral DMARD combinations (with or without corticosteroids) versus oral DMARD combinations, biologic versus biologic, biologic versus oral DMARD, biologics plus oral DMARD versus biologic, biologic plus oral DMARD versus oral DMARD, and early RA strategies. For purposes of this review, we defined strategies as studies where drug regimens were not fixed, but rather when a clinician made dose adjustments or drug changes according to patient response.

Across all Key Questions, we included head-to-head studies, observational studies, and systematic reviews. When comparative evidence is available, we discuss it before presenting indirect analyses of placebo-controlled trials.

Table 7 gives the numbers of trials for drug class comparisons reported only from head-to-head studies; when some groupings have important subcomparisons, we note these as well. Additionally, we included 107 observational studies in the report.

Table 7 Number of head-to-head trials by drug comparison for rheumatoid arthritis

Drug Comparison | Number of Trials;^†^ Quality Rating
Oral DMARDs vs. oral DMARDs | 8 fair; 1 good
Oral DMARD combinations | 3 fair; 3 good
Biologic DMARDs vs. biologic DMARDs | 1 fair
Biologic DMARDs vs. oral DMARDs | 4 fair; 1 good
Biologic DMARD+oral DMARD combinations | 9 fair; 3 good
Early RA Strategies | 1 fair; 3 good

DMARD = disease modifying anti-rheumatic drug

† Trials may fall into more than one drug comparison category, depending on the treatment arms discussed in the report.

Table 8 lists abbreviations and full names of diagnostic scales and health status or quality-of-life instruments encountered in these studies, as well information about clinical significance when available. For further details about such instruments and scales, see Appendix G.

Table 8 Disease activity, radiographic progression, functional capacity, and quality-of-life measures

Abbreviated Name | Complete Name of Measure or Instrument | Range of Scores | Improvement Denoted by | Clinically Significant Improvement
ACR-N | American College of Rheumatology percent improvement from baseline to endpoint | 0 to 100 percent | Increase | --
ACR 20/50/70^*^ | American College of Rheumatology response scores based on 20, 50, or 70 percent criteria for improvement | 0 to 100 percent | Increase | ACR 20 is 20% minimal improvement; ACR 50/70 considered more clinically significant45
ASHI | Arthritis-Specific Health Index (Medical Outcomes Study Short Form SF-36 Arthritis-specific Health Index) | 0 to 100 | Increase | --
DAS^*^ | Disease Activity Score | 0 to 10 | Decrease | DAS <1.6 correlates with remission45, 46
DAS 28 | Disease Activity Score Short Form | 0 to 10 | Decrease | DAS28 <2.6 correlates with remission 45, 47
DLQI | Dermatology Life Quality Index | 0 to 30 | Decrease | --
EQ-5D^*^ | EuroQol EQ-5D Quality of Life Questionnaire | 0 to 1 | Increase | --
EULAR response | European League Against Rheumatism response | N/A | N/A | --
HAQ^*^(D-HAQ) | Health Assessment Questionnaire (Dutch Version) | 0 to 3 | Decrease | HAQ >= 0.22 change48
HAQ-DI | Disability Index of the Heath Assessment Questionnaire | 0 to 3 | Decrease | --
SF-36^*^ | Medical Outcomes Study Short Form 36 Health Survey | 0 to 100 | Increase | SF36 physical or mental component two standard error of the mean (SEM)49–52
SHS^*^ | Sharp/van der Heijde Method (SHS) for Scoring Radiographs (SHS is frequently modified by individual authors to meet study requirements and needs; there is no standard modified SHS) | Erosion: 0 to 160 for hands; 0 to 120 for feet Joint space narrowing: 0 to 168 Total: 0 to 448 | Decrease | Changes in joint damage around the level of 5 units of the Sharp/van der Heijde method as minimally clinically important53

* These key scales are defined in Appendix G.

-- = less commonly used measures for which there is little or no research regarding what constitutes a clinically significant improvement

## Key Question 1 Reductions in Disease Activity, Limitations of Disease Progression, and Maintenance of Remission

This Key Question concerned three main topics. Specifically, for patients with rheumatoid arthritis (RA), do drug therapies differ in their ability to reduce disease activity, to slow or limit progression of radiographic joint damage, or to maintain remission? Evidence Tables in Appendix E document details about all these studies.

### Overview

Individual study details are found in the Evidence Tables, Appendix E. The main drug classes that we compared include oral disease-modifying antirheumatic drug (DMARDs), biologic DMARDs (also referred to simply as biologics), and various combined therapies.

Overall strength of evidence by disease activity and radiographic changes, when available, is listed in Table 9. Table 10 provides information on comparisons made, symptom response, and quality ratings. Table 11 provides information on radiographic joint damage, indicating whether the study populations included patients with early RA. When possible, we describe whether treatment effects reach minimal clinically important differences (MCIDs). In this section, achieving at least an American College of Rheumatology 20% improvement criteria (ACR), a disease activity score (DAS)<1.6, a DAS28<2.6, or a Sharp/van de Heijde change in joint damage of 5.0 are considered minimally clinically important (Table 9).

Table 9 Disease activity and remission for oral DMARD versus oral DMARD studies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Corticosteroid vs. Corticosteroid
Kirwan et al., 2004^54^ | RCT 143 12 weeks | Population-based; active RA; mean disease duration 9 years | BUD (3 mg/day) vs. BUD (9 mg/day) vs. PNL (7.5 mg/day) | No significant difference between 9 mg BUD and PNL for ACR 20, DAS (ACR 20: 42% vs. 56%; P=0.11) at 12 weeks | Fair
Leflunomide vs. MTX
Emery et al., 2000^105^ | RCT 999 1 year with optional 2nd year | Mean disease duration 3.5 to 3.8 years | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Lower ACR 20 responses at 12 months (50.5% vs. 64.8%; P<0.001); no significant differences in ACR at 2 years (64.3% vs. 71.7%; P=NS, NR) | Fair
Strand et al., 1999^56, 104^ | RCT 482 12 months (1 year continuation) | Mean disease duration 6.5 to 7 years | LEF (20 mg/day) vs. MTX (7.5 to 15 mg/week) | At 1 year, ACR 20 numerically higher for LEF but not significant (52% vs. 46%; P=NR); at 2 years, ACR 20 difference not significant (79% vs. 67%; P=0.049) | Fair
Leflunomide vs. Sulfasalazine
Smolen et al., 1999;^107^ Smolen, 1999;^108^ Larsen et al., 2001^60^ | RCT 358 24 weeks (12- and 24-month followup) | Mean disease duration 5.7 to 7.6 years | LEF (20 mg/day) vs. SSZ (2 g/day) | Similar ACR 20 response rates (48% vs. 44%; P=NR) | Fair
Sulfasalazine vs. MTX
Capell et al., 2006^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland; multicenter; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | At 18 months, no significant difference in DAS for SSZ vs. MTX (−0.30 vs. −0.26; P=0.79); no significant difference in any ACR responses | Fair
Dougados et al., 1999^57^ | RCT 209 (146) 52 weeks (5-year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in DAS between SSZ vs. MTX (−1.15 vs. −0.87; P=NS, NR); no significant difference in ACR 20 responses; P=NR | Fair
Haagsma et al., 1997^58^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week | No significant difference in DAS for SSZ vs. MTX (−1.6 vs. −1.7; P=NS, NR) | Fair

ACR = American College of Rheumatology; BUD = budesonide; CI = confidence interval; DAS = disease activity score; DMARD = disease-modifying antirheumatic drug; g = gram; LEF = leflunomide; MTX = methotrexate; mg = milligram; NR = not reported; NS = not significant; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Table 10 Radiographic joint damage in oral DMARD versus oral DMARD

Study | Study Design N Duration | Population with Early RA (<3 years) | Comparison (dose) | Radiographic Outcomes
Leflunomide vs. MTX
Emery et al., 2000^105^ | RCT 999 1 year with optional 2nd year | No | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Larsen score change at 1 year: 0.3 vs. 0.3; P=NS Larsen score change at 2 years: 1.27 vs. 1.31; P=NS, NR
Strand et al., 1999^104^ | RCT 482 12 months (1 year continuation) | No | LEF (20 mg/day) vs. MTX (7.5 to 10 mg/week) | Total Sharp score change at 1 year: 0.53 vs. 0.88;P=0.05 Total Sharp score at 2 years: 1.6 vs. 1.2; P=0.659
Leflunomide vs. Sulfasalazine
Smolen et al., 1999;^107^ Larsen, et. al., 2001;^60^ Sharp et al., 2000^109^ | RCT 358 24 weeks (12- and 24-month followup) | No | LEF (20 mg/day) vs. SSZ (2 g/day) | Larsen score change at 24 weeks: 0.01 vs. 0.01; P=NS Larsen score change at 1 year: 0.02 vs. 0.02; P=NS Larsen score change at 2 years: −0.07 vs. −0.03; P=NR
Sulfasalazine vs. MTX
Capell et al., 2006^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Yes (70% 1 year or less) | SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | No significant difference in total modified Sharp/van der Heijde score change (data NR)
Dougados et al., 1999^57^ | RCT 209 (146) 52 weeks (5 years) | Yes | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | Total modified Sharp/van der Heijde score change: 4.64 vs. 4.50 vs. 3.36; P=NS, NR; change at 5 years: 8.5 vs. 7.5; P=0.7

DMARD = disease-modifying antirheumatic drug; g = gram; LEF = leflunomide; mg = milligram; MTX = methotrexate; NR = not reported; NS = not significant; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Table 11 Disease activity and remission for oral DMARD combinations versus monotherapy or combinations with or without corticosteroid studies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Sulfasalazine+MTX vs. Sulfasalazine or MTX monotherapy
Capell et al., 2006^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland, 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day)+MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | Combination therapy better than monotherapy MTX or SSZ for DAS (−0.67, −0.30, −0.26; P=0.039 for SSZ+MTX vs. SSZ; P= 0.023 for SSZ+MTX vs. MTX) No significant difference in ACR responses | Fair
Dougados et al., 1999^57^ Maillefert et al., 2003^111^ | RCT 209 (146) 52 weeks (5-year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day)+MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in ACR responses (65 vs. 59 vs. 59; P=NS, NR) DAS change (−1.26 vs. −1.15 vs. −0.87; P=0.019) DAS change NS at year 5 | Fair
Haagsma et al., 1997^58^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (2 to 3 g/day)+MTX (7.5 to 15 mg/week) vs. SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in ACR or DAS responses | Fair
*Schipper et al., 2008^110^ | Prospective cohort 230 52 weeks (primary outcome at 6 months) | Netherlands; early RA; sulfasalazine resistant; mean disease duration 3 months-1 year | SSZ (750 to 3g/day)+MTX (7.5–30 mg/week) vs. MTX (7.5–30 mg/week) | No significant difference for DAS responses DAS28 change (−0.8 vs. −0.9; P 0.737) | Fair
MTX+Hydroxychloroquine+Sulfasalazine vs. one or two oral DMARDs
O’Dell et al., 2002^61^ | RCT 171 2 years | Mean disease duration 5.8 to 7.9 years | 1: MTX (7.5 titrated to 17.5 mg/week)+SSZ (2 g/day)+HCQ (400 mg/day) vs. 2: MTX+HCQ vs. 3: MTX+SSZ | ACR 20: 78%, 60%, 49% 1 vs. 2: P=0.05 1 vs. 3: P=0.002 | Good
O’Dell et al., 1996^62^ | RCT 102 2 years | Poor response to at least 1 DMARD; mean disease duration 6 to 10 years | 1: MTX (7.5 to 17.5 mg/week)+SSZ (1 g/day)+HCQ (400 mg/day) vs. 2: MTX vs. 3: SSZ (+ HCQ | 50% improvement (defined by authors): 77%, 40%, 33% 1 vs. 3: P<0.001 1 vs. 2: P=0.003 | Good
Oral DMARD+Corticosteroid vs. Oral DMARD
*Choy, et al., 2008^64^ | RCT 467 2 years | England/Wales, Multicenter: early RA; mean disease duration 2.7–5.1 months | MTX (≤15 mg/week)+PNL (60 mg/day stepped down and stopped at 34 weeks) vs. MTX | No significant differences for DAS (−1.37 vs. −1.42; P=0.19); DAS 28 remission 20% vs. 18%; P=NR | Good
Svensson et al., 2005^65^ | Open-label trial 250 2 years | Population-based; active RA; early RA | DMARD (SSZ or MTX, dosages NR)+PNL (7.5 mg/day) vs. DMARD | More patients in DMARD+PNL combination group achieve remission (DAS<2.6) than DMARD-only group (55.5% vs. 43.8%; P=0.0005) | Fair

* New study added since last review

ACR = American College of Rheumatology; DAS = disease activity score, DMARD = disease-modifying antirheumatic drug; g = gram; HQC = hydroxychloroquine; MTX = methotrexate; mg = milligram; NHS = National Health Service; NR = not reported; NS = not significant; PNL = prednisolone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Oral DMARD versus oral DMARD. One trial found no statistically significant difference by ACR 20 between budesonide and prednisolone for disease activity outcomes.54 The strength of evidence is low.

Two trials found no statistically significant difference by ACR 20 between methotrexate (MTX) and leflunomide for disease activity outcomes at 2 years or radiographic changes. These results are limited by the use of lower doses of MTX.55, 56 The strength of evidence is low.

Three trials did not find a significant difference by ACR 20 between MTX and sulfasalazine for disease activity outcomes. These results are limited by the lower doses of MTX used in the earlier studies57–59 The strength of evidence is low.

One trial found that leflunomide lessens disease activity outcomes by ACR 20 at 2 years compared to sulfasalazine but did not detect differences in radiographic changes.60 The strength of evidence is insufficient for disease activity and low for radiographic changes.

No fair or good evidence exists for comparing hydroxychloroquine monotherapy with other oral DMARD monotherapy.

Oral DMARD combinations. Combination therapy with sulfasalazine and MTX compared to monotherapy provides different results depending on the population.57–59 Two trials and one cohort of DMARD naïve patients with early RA showed no difference in ACR 20 response between combination sulfasalazine and MTX versus monotherapy.57, 58 The strength of evidence is moderate. The one trial in those without early RA (up to 10 years duration) supported combination therapy with sulfasalazine and MTX versus monotherapy with either drug; the changes in DAS scores were greater for combination therapy than for monotherapy, but MCID was not reached by ACR 20 response.57 The strength of evidence is low

The strength of evidence is low for suggesting that sulfasalazine and MTX compared with monotherapy alone limit progression of radiographic joint damage.

The strength of evidence is moderate for suggesting that combinations of MTX, sulfasalazine, and hydroxychloroquine lessen disease activity by ACR 20 resonse compared to one or two drugs.61, 62

Low doses of glucocorticoids taken with an oral DMARD (generally MTX or sulfasalazine) reduce x-ray progression over 1–2 years.63–65 The strength of evidence is low. However, the evidence is conflicting for change in DAS over 2 years; one study found significant change and one did not.64, 65 The strength of evidence is insufficient.

Biologic DMARDs. We found one head-to-head randomized controlled trial (RCT) that compared one biologic DMARD with another66 providing low strength of evidence that abatacept lessens disease activity at 1 year compared with infliximab. However, remission by DAS did not reach significance at 1 year. Other existing direct head-to-head evidence is limited to a nonrandomized, open-label effectiveness trial67 and six prospective cohort studies.68–73 Because of the methodological limitations of observational studies, findings of these studies must be interpreted cautiously. The studies that compared etanercept with infliximab reported a faster onset of response for etanercept during the first months of therapy but no differences in efficacy by ACR 20 and ACR 50 thereafter.67–71, 73 The faster onset of etanercept might be attributable partly to necessary dose adjustments for patients treated with infliximab. The strength of evidence is low.

Adalimumab lessens disease activity over 1 year compared with infliximab by DAS28, but MCID can not be determined.71, 73 Evidence is limited to two cohort studies. There were no differences in achievement of ACR 70 for adalimumab compared with etancercept.73 The strength of evidence is low for both of these comparisons.

A cohort of patients who had failed at least one anti-tumor necrosis factor (TNF) drug were subsequently treated with rituximab, and their outcomes were compared with those of patients treated with other anti-TNF agents. The results indicated that the patients treated with rituximab had a greater reduction in disease activity at 6 months than the patients treated with the other anti-TNF agents. The MCID can not be determined.72 The strength of evidence is low.

Mixed treatment comparisons performed in this report suggest higher efficacy for improving disease activity (ACR 50) for etanercept compared with individual biologics including abatacept, adalimumab, anakinra, infliximab, rituximab, and tocilizumab; nonsignificant differences with golimumab were reported. The strength of evidence is low and should be interpreted cautiously given the indirectness of the evidence.

Anakinra appears to have lower efficacy based on our mixed treatment comparisons. However, ACR 50 was significant only for for adalimumab and etanercept. Prior indirect comparisons have found similar results.74, 75 The strength of evidence is low and should be interpreted cautiously given the indirectness of the evidence.

Mixed treatment comparisons found no significant differences in disease activity with abatacept, adalimumab, golimumab, infliximab, rituximab, and tocilizumab. The strength of evidence is low and should be interpreted cautiously given the indirectness of the evidence.

Biologic DMARD versus oral DMARD. Population-based, observational evidence from prospective cohort studies and RCTs of individual drugs indicated that biologic DMARDs as a class (adalimumab, anakinra, etanercept, infliximab) were more efficacious by ACR 20, 50 and remission by DAS28 than oral DMARDs as a class (MTX, leflunomide).67, 68, 76–78 The strength of evidence for available comparisons is moderate.

Radiographic outcomes were significantly better in patients treated with biologic DMARDs adalimumab and etanercept than in patients treated with MTX. How such intermediate outcomes translate to the long-term clinical progression of the disease remains unclear. The strength of the evidence for the available comparisons is low.

Individual trials of adalimumab and etanercept favor approved doses of biologic versus MTX. The strength of evidence for these comparisons is low.

Biologic DMARD combinations. There are no synergistic effects of a combination treatment of etanercept and anakinra79 or etanercept and abatacept by ACR/20/50 response80 compared with etanercept monotherapy. The strength of evidence is low.

Overall, moderate evidence suggests that some benefit in ACRresponse to biologic DMARD combinations over monotherapy, at least in relation to combining MTX with adalimumab, infliximab, or rituximab. A combination of MTX with either adalimumab,76 or infliximab,68, 81–83 or rituximab84 led to statistically significantly greater improvements in ACRresponse and radiographic progression than with biologic DMARD monotherapy. A combination of etanercept with MTX trended toward greater improvements in disease activity and radiographic outcomes than with monotherapy but not all studies reached statistical significance.68, 81, 85–88 A combination of etanercept with sulfasalazine did not achieve better outcomes than etanercept monotherapy at 1 year.85 All RCTs were funded by the makers of the biologic DMARDs. Except for the PREMIER study on adalimumab,76 none of these trials was conducted in patients with early RA. The strength of evidence is low for the individual comparisons. No evidence is available on abatacept, anakinra, certolizumab pegol, golimumab, tocilizumab, and combinations with oral DMARDs.

Overall, the evidence is high for combination of biologic DMARDs with oral DMARDs versus oral DMARDs. A combination of MTX with abatacept,89 adalimumab,76 etanercept,86, 90, 91 golimumab,92 or infliximab82 led to significantly greater improvements in disease activity by ACR 20/50 response than MTX alone.

Evidence from two prospective cohorts for anti-TNF drugs with MTX compared to anti-TNF with leflunomide note similar efficacy.93, 94 Anti-TNF drugs included anakinra, etanercept, and adalimumab. The strength of evidence is low.

None of the RCTs can be considered an effectiveness study. Of four population-based prospective cohort studies, only one was conducted in the United States. The generalizability of results to the average population of community rheumatology patients, therefore, remains unclear. All RCTs were funded by the makers of the biologic DMARDs.

Strategies limited to early RA. Combination therapy, which included two oral DMARDs (MTX and sulfasalazine) plus a stepped-down prednisolone treatment, demonstrated less radiographic progression by modified Sharp/van der Heijde score (5.6 vs. 8.6; P=0.001) than sulfasalazine alone.95, 96 The strength of evidence is low.

Combination of three oral DMARDs (MTX, sulfasalazine, and hydroxychloroquine) plus prednisolone led to less radiographic change than one oral DMARD (sulfasalazine, which could be changed to MTX).97, 98 The MCID can not be determined. The strength of evidence is low.

Evidence from one trial found that in patients not responding to methotrexate in DAS response-driven treatment, combination of three oral DMARDs (MTX, sulfasalazine, and hydroxychloroquine) resulted in less response by European League Against Rheumatism (EULAR) criteria compared to infliximab plus MTX.99 The MCID cannot be determined. The strength of evidence is low.

A strategy of either (1) MTX, sulfasalazine, and tapered high-dose prednisone, or (2) MTX and infliximab resulted in less radiographic change over 12 months than (3) sequential DMARD therapy or (4) stepped-up combination therapy.100 At 4 years, the remission by DAS among groups was similar.101–103 The strength of evidence is low.

### Rheumatoid Arthritis: Detailed Analysis

Oral DMARD versus oral DMARD. Table 9 presents disease activity and remission and Table 10 presents radiographic joint damage results in these comparisons.

Corticosteroids versus corticosteroids. We found one head-to-head RCT (N=143) comparing two corticosteroids (Table 9).54 It examined the efficacy of low-dose budesonide (3 mg/day), high-dose budesonide (9 mg/day), and prednisolone (7.5 mg/day) over 12 weeks. Mean disease duration of RA was 9 years. When comparing drugs, the percentage achieving ACR 20 response criteria for high-dose budesonide (9 mg) was significantly greater than that for lower- dose budesonide (3 mg) (42 percent vs. 22 percent; P<0.001), but the percentages for high-dose budesonide and prednisolone did not differ significantly (42 percent vs. 56 percent; P=0.11). Similarly, high-dose budesonide and prednisolone did not differ significantly for tender joint count, swollen joint count, and the DAS.

Leflunomide versus MTX. We found two trials comparing leflunomide (20 mg/day) with MTX (studies ranging from 7.5 mg/week to 15 mg/week) and two systematic reviews with meta-analysis of leflunomide.55, 104–106 We describe these two studies in detail here first. One trial randomized 482 patients to leflunomide (n=182) or MTX (n=182) over 12 months.104 Mean disease duration of RA across these groups was 6.5 years to 7 years. The proportion of patients meeting ACR 20 response criteria at 12 months was higher for leflunomide than MTX but not statistically significantly so (52 percent vs. 46 percent; P=NR). Proportions meeting ACR 50 and ACR 70 criteria also did not differ significantly. Leflunomide had less disease progression by Sharp score than MTX (respectively, 0.53 vs. 0.88; P=0.05) (Table 10).

A continuation study followed the same cohort for 2 years (leflunomide, n=98; MTX, n=101).56 At 2 years, leflunomide was associated with a higher proportion of patients meeting ACR 20 response criteria than MTX (79 percent vs. 67 percent; P=0.049). The percentage of patients meeting either ACR 50 or ACR 70 criteria at 2 years did not differ significantly, and the change in total Sharp score also did not differ significantly at 2 years (1.6 vs. 1.2; P=0.659).

These 2-year follow-up results are limited by the 45 percent attrition rate from the initial study.

The other trial comparing leflunomide to MTX examined 999 patients for 12 months with an optional second year (leflunomide, n=501; MTX, n=498).105 Mean disease duration across the groups was 3.5 to 3.8 years. At 12 months, the proportion of patients meeting ACR 20 response criteria was lower for leflunomide than for MTX (50.5 percent vs. 64.8 percent; P<0.001), but differences were not significant at 2 years (64.3 percent vs. 71.7 percent; P=not significant [NS], not reported [NR]). Radiological outcomes at 12 months using Larsen Scale scores for joint narrowing were statistically equivalent (0.03 increase in both groups). After 2 years, no further increase in joint damage occurred in patients treated with leflunomide; patients taking MTX had a small improvement (data NR). The overall result was a small significant difference in Larsen Scale scores favoring MTX after 2 years (data NR).

In the systematic review that included two trials comparing leflumonide with MTX (n=1,348), there were no differences in achieving an ACR 20 response at 12 months (odds ratio [OR], 1.08; 95% CI, 0.75 to 1.55) or at 2 years (OR, 1.05; 95% CI, 0.81 to 1.37). Patients receiving leflunomide and MTX did not differ in ACR 50 and ACR 70 responses, and the two drugs also did not differ in delaying bone erosions or joint damage assessed by total Sharp score.55 This systematic review was limited by the small number of studies that the authors could use for the individual comparisons in the meta-analysis. Similarly, the second systematic review examined the efficacy and safety of oral DMARDs in adults with RA to inform the EULAR recommendations.106 In the four studies included comparing leflunomide with MTX (N=1,889), there were no differences in ACR 20 response (MTX, OR, 1.04; 95% CI, 0.60 to 1.79). It should be noted that the mean dose of MTX was 12.5 mg/week. MTX could be increased to ≥15 mg/week in all studies, but dosing was not as high as currently recommended in most studies.

Leflunomide versus sulfasalazine. One study107 with a 2-year followup60 compared leflunomide with sulfasalazine (Tables 9 and 10). In addition, one systematic review did a meta-analysis of leflunomide against sulfasalazine.55 Given that the systematic review included only one trial with this comparison, we describe it in detail first.107, 108 This study was a 24-week, double-blind, multinational RCT of 358 patients on 20 mg/day leflunomide (n=133) or 2 g/day sulfasalazine (n=133).107 Mean disease duration across groups was 5.7 to 7.6 years. ACR 20 response at 24 weeks was similar for leflunomide and sulfasalazine (48 percent vs. 44 percent; P=NR). The percentage achieving ACR 50 response criteria was also similar in the two groups (33 percent leflunomide, 30 percent sulfasalazine). Larsen Scale scores were also similar for leflunomide and sulfasalazine, and the Larsen Scale change score at endpoint was 0.01 for both drugs (Table 10). In the followup study, patients who completed the first study could opt to continue on the 12- and 24-month double-blind extension.60 At 12 months (leflunomide, n=80; sulfasalazine, n=76), ACR 20 response was similar for leflunomide and sulfasalazine (77 percent vs. 73 percent; P=NR). At 24 months (leflunomide, n=28; sulfasalazine, n=27), ACR 20 response was significantly greater for leflunomide than for sulfasalazine (82 percent vs. 60 percent; P=0.0085). Changes in Larsen Scale scores were also similar for leflunomide and sulfasalazine (mean change: 0.02 vs. 0.02 at 12 months, −0.07 vs. −0.03 at 24 months; P=NR). Changes in Sharp scores were also not significantly different (mean change: 0.97 vs. 1.38; P=0.685). However, these long-term results are significantly limited by the attrition rates of 65 percent to 70 percent.

The systematic review with a meta-analysis compared leflunomide (10 to 20 mg/day) with sulfasalazine (2 g/day).55 The analysis included the study described above.60, 107–109 Response to the two drugs did not differ as measured by either ACR 20 or ACR 50 criteria at 6 months and 12 months. However, leflunomide was more efficacious at 24 months (ACR 20: OR, 0.73; 95% CI, 0.57 to 0.93; P=0.012; ACR 50: OR, 0.48; 95% CI, 0.28 to 0.80; P=0.0048). The groups did not differ in the ACR 70 at 6, 12, or 24 months. Leflunomide and sulfasalazine also did not differ in delaying bone erosions or joint damage by Sharp score or Larsen Scale score at 6, 12, or 24 months. Again, these results are significantly limited because they include only the one study.107

Sulfasalazine versus MTX. Three RCTs.57–59 and one systematic review106 examined the efficacy of sulfasalazine and MTX (Tables 9 and 10). Overall, findings from these studies showed similar improvement rates between sulfasalazine and MTX for any ACR, DAS, and radiological outcomes. Two of the trials included patients with disease burden of less than 1 year and used a lower dose of weekly MTX (7.5 mg) than the doses generally used in the United States.57, 58 These trials also included a combination therapy arm, which we describe below (in the section on Oral DMARD combinations versus oral DMARD combinations or oral DMARD monotherapy).

One trial randomized 209 patients to receive 2 g/day to 3 g/day sulfasalazine (n=68), 7.5 mg/week to 15 mg/week MTX (n=69), or a combination of sulfasalazine and MTX (n=68) for 52 weeks.57 Mean disease duration for the groups ranged from 2.3 months to 3.4 months. The trial did not detect any differences between the MTX and sulfasalazine groups in improvement as measured on the ACR 20 (59 percent sulfasalazine; 59 percent MTX; P=NR). The DAS change score favored sulfasalazine therapy (−1.15, sulfasalazine; −0.87, MTX; P=NR), but the statistical analysis examined only the comparison with combination therapy (reported under Oral DMARD combinations versus oral DMARD combinations or oral DMARD monotherapy). The mean total modified Sharp/van der Heijde scores of 8.5 for sulfasalazine and 7.5 for MTX indicated that the radiological scores at 5 years did not differ significantly (P=0.7).

Another RCT, lasting 52 weeks (N=105), also demonstrated similar ACR 20 and DAS results for sulfasalazine and MTX.58 This trial compared 1 g/day to 3 g/day sulfasalazine (n=34) with 7.5 mg/week to 15 mg/week MTX (n=35) and with a combination (discussed later in this chapter); mean disease duration was 2.6 to 3.1 months. The mean change in DAS over 52 weeks was −1.6 in the sulfasalazine group and −1.7 in the MTX group (P=NS). The percentage of patients achieving improvement on the ACR 20 was 25 percent for sulfasalazine and 25 percent for MTX.

Finally, one trial included a population with disease duration of up to 10 years.59 The investigators gave 687 patients sulfasalazine (up to 4 g/day) for 6 months. Those with DAS ≥2.4 were offered inclusion into a Phase II study and randomized to (1) sulfasalazine (n=55), (2) MTX (n=54) (maximum dose, 25 mg/week), and (3) sulfasalazine plus MTX (n=56). At 18 months, the DAS change was similar for sulfasalazine and MTX alone (−0.30 vs. −0.26; P=0.79). The ACR 20, 50, and 70 responses were also similar (ACR 20, 18 percent vs. 15 percent; ACR 50, 6 percent vs. 7 percent; ACR 70, 2 percent vs. 2 percent; P=NR). The groups also did not differ in modified Sharp/van der Heijde score, total erosions, and joint space narrowing (data NR) (Table 9). However, 18 months is a short period for observing radiological outcomes, and this study was not powered to detect radiological progression.

Similarly, a systematic review that examined the efficacy and safety of oral DMARDs in adults with RA to inform the EULAR recommendations.106 In the two studies (N=193), there were no differences in ACR 50 response (MTX, OR, 1.57; 95% CI, 0.82 to 3.00). The mean dose of MTX was 14.2 mg/week, which is lower than currently recommended.

Oral DMARD combinations versus oral DMARD combinations or oral DMARD monotherapy, with or without corticosteroids. Table 11 presents disease activity and remission and Table 12 provides radiographic joint damage results for these comparisons.

Table 12 Radiographic joint damage in oral DMARD combinations versus monotherapy combinations with or without corticosteroid studies

Study | Study Design N Duration | Population with Early RA (< 3 years) | Comparison (dose) | Radiographic Outcomes
Sulfasalazine+MTX vs. Sulfasalazine or MTX
Capell et al., 2006^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Yes (70% 1 year or less) | SSZ (≤4 g/day)+MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | No significant difference in total Sharp score (data NR)
Dougados et al., 1999;^57^ Maillefert et al., 2003^111^ | RCT 209 (146) 52 weeks (5-year followup) | Yes | SSZ (2 to 3 g/day)+ MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | 5-year mean modified Sharp/van der Heijde score change: 8.5 vs. 7.5; P=0.7
Oral DMARD+Corticosteroid vs. Oral DMaRD
*Choy, et al., 2008^64^ | RCT 467 2 years | Yes | MTX (≤15 mg/week)+PNL (60 mg/day stepped down and stopped at 34 weeks) vs. MTX | Larsen score change 7.41 vs. 4.70; P=0.008
Svensson et al., 2005^65^ | Open-label RCT trial 250 2 years | Yes | DMARD (SSZ or MTX, dosages NR)+PNL (7.5 mg/day) vs. DMARD | Median modified Sharp/van der Heijde score change: 1.8 vs. 3.5; P=0.019 Erosion score median change: 0.5 vs. 1.25; P=0.007 Joint space narrowing score median change: 1.0 vs. 2.0; P=0.08

* New study added since last review.

ACR = American College of Rheumatology; DAS = disease activity score, DMARD = disease-modifying antirheumatic drug; g = gram; HQC = hydroxychloroquine; LEF = leflunomide; MTX = methotrexate; mg = milligram; NR = not reported; NS = not significant; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Sulfasalazine plus MTX versus sulfasalazine or MTX. Three RCTs,57–59 one systematic review and one observational cohort110 compared the efficacy of sulfasalazine and MTX versus that of either sulfasalazine or MTX alone (Tables 11 and 12). Findings from two of these randomized trials consistently reported no significant differences in ACR, DAS, or radiological outcomes.57, 58 They included patients with disease duration of less than 1 year and again used a lower dose of weekly MTX (7.5 mg) than the doses generally used in the United States.57, 58 The third trial included patients with RA duration of up to 10 years, and their DAS results favored the sulfasalazine-MTX combination therapy over monotherapy.59

Biologic DMARDs versus biologic DMARDs. We identified one head-to-head RCT,66 one nonrandomized, open-label effectiveness trial,67 and six prospective cohort studies (Table 13);68–73 all but three studies66, 71, 72 compared etanercept with infliximab. Other comparisons included adalimumab with infliximab,71, 73 adalimumab with etanercept,73 abatacept with infliximab66 and rituximab compared with other anti-TNF agents.72 All studies had minimal exclusion criteria, enrolling patients who were starting treatments with biologic DMARDs. Mean disease durations ranged from 7.3 years to 14.5 years, indicating that most patients suffered from advanced RA; the proportion of patients with early RA in these studies remains unclear. One study contained a multinational patient population,66 one was conducted in the United States;68 the other six were carried out in Sweden,67, 69, 72 Denmark,73 the Netherlands,71 and Spain.70

Table 13 Disease activity and remission for biologic DMARD versus biologic DMARD studies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Abatacept vs. Infliximab
*Schiff, et al., 2008^66^ ATTEST study | RCT 431 1 year | Patients who have failed MTX; active RA; mean disease duration 7.3–8.4 years | ABA (~10 mg/kg every 4 weeks) vs. INF (3 mg/kg every 8 weeks) | Greater decrease in DAS28 for ABA vs. INF at 1 year (estimate of difference −0.62 95% CI, −0.96 to −0.29). Trend toward greater remission for ABA vs. INF at 1 year (estimate of difference 6.5%; 95% CI, −2.2 to 15.2, P=NS, NR) | Fair
*Hetland et al., 2010^73^ DANBIO | Prospective cohort 2,326 6 months(48 months) | Patients with RA initiating therapy with biologic DMARDs | ADA (mean: 40 mg) wks) vs. ETN (mean 45 mg) vs. INF (mean 3.5 mg/kg) | Higher achievement of ACR 70 response after 6 months for ADA than INF (OR 2.05, 95% CI, 1.52 to 2.76, P=NR) | Fair
*Kievit et al., 2008^71^ | Prospective cohort 707 1 year | Population-based, Netherlands, Anti-TNF naïve patients, failed at least 2 DMARDs; mean disease duration 6–7.7 years | ADA vs. INF (dosages NR) | Greater decrease in DAS28 for ADA vs. INF at 1 year (ADA −1.8, INF −1.2; P<0.05) | Fair
Adalimumab vs. Etanercept
*Hetland et al., 2010^73^ DANBIO | Prospective cohort 2,326 6 monhs (48 months) | Patients with RA initiating therapy with biologic DMARDs | ADA (mean: 40 mg) wks) vs. ETN (mean 45 mg) vs. INF (mean 3.5 mg/kg) | No difference in achievement of ACR 70 response after 6 months for ADA vs. ETN (OR 1.15, 95% CI, 0.82 to 1.60, P=NR) | Fair
Etanercept vs. Infliximab
Geborek et al., 2002^67^ | Nonrandomized, open-label trial 369 1 year | Population-based; active RA; had failed at least 2 DMARDs; mean disease duration 14.5 years | ETN (25 mg twice weekly) vs. INF (3 mg/kg or higher) | Higher ACR 20 responses for ETN at 3 (data NR; P<0.02) and 6 months (data NR; P<0.05); no significant differences in ACR response rates at 1 year (data NR) | Fair
*Fernandez-Nebro et al., 2007^70^ | Prospective cohort 161 6 years | Tertiary care center, Spain; Anti-TNF naïve patients; mean disease duration 9.5–9.9 years | ETN vs. INF (dosages NR) | Significantly greater decrease t in DAS28 at 6 months for ETN vs. INF (−1.7 vs. −1.3; P=0.03); No difference in EULAR responses between ETN vs. INF at 6 months | Fair
*Hetland et al., 2010^73^ DANBIO | Prospective cohort 2,326 6 monhs (48 months) | Patients with RA initiating therapy with biologic DMARDs | ADA (mean: 40 mg) wks) vs. ETN (mean 45 mg) vs. INF (mean 3.5 mg/kg) | Higher achievement of ACR 70 response after 6 months for ETN vs. INF (OR 1.78, 95% CI, 1.28 to 2.50, P=NR) | Fair
*Kievit et al., 2008^71^ | Prospective cohort 707 1 year | Population-based, Netherlands, Anti-TNF naïve patients, failed at least 2 DMARDs; mean disease duration 6–7.7 years | ETN vs. INF (dosages NR) | Greater decrease in DAS28 for ETN vs. INF at 1 year (ETN −1.8, INF −1.2; P<0.05) | Fair
Kristensen et al., 2002^69^ | Prospective cohort 949 3 years | Population-based, Inadequate response to at least 2 DMARDs | ETN (25 mg twice weekly) vs. INF (3 mg/kg or higher) | No difference in ACR 50 response at 3 years (data NR) | Fair
Weaver et al., 2006^68^ | Prospective cohort 1,371 1 year | Population-based; patients with active RA who required change in therapy; mean disease duration 9.3 years | ETN (25 mg twice weekly) vs. INF (3.8 mg/kg or higher) | Higher ACR 20 response rates for ETN than INF at 1 year (41% vs. 26%; P=NR) | Fair
Rituximab vs. Anti-tumor Necrosis Factor Therapies
*Finckh et al., 2007^72^ | Prospective cohort 116 6 months | Population-based, Switzerland; Patients who have failed at least 1 Anti-TNF treatment; mean disease duration 9–10 yrs | RTX (2 infusions, 1000 mg) vs. anti-TNF agent (INF, ETN or ADA, dosages NR) | Greater reduction in DAS28 at 6 months for RTX vs. Anti-TNF (−1.6 vs. −0.98; P=0.01) | Fair

* New study added since last review.

ACR = American College of Rheumatology; ADA = adalimumab; ATTEST = Abatacept or infliximab vs. placebo, a trial for tolerability, efficacy, and safety in treating rheumatoid arthritis; CI = confidence interval; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; ETN = etanercept; INF = infliximab; mg/kg = milligram/kilogram; mACR = modified American College of Rheumatology; NR = not reported; NS = not significant; PCS = physical component score; RA = rheumatoid arthritis; TNF = tumor necrosis factor; US = United States; vs. = versus

Abatacept versus infliximab. One head-to-head multinational RCT (N=431) examined the effectiveness of abatacept (10 mg/kg every 4 weeks) and infliximab (3 mg/kg every 8 weeks) over 1 year.66 All participants had active RA, were MTX-resistant, and continued on background MTX for the study. At 1 year abatacept had a greater reduction in DAS28 than infliximab (−2.88 vs. −2.25; estimate of difference −0.62; 95% CI, −0.96 to −0.29). There was also a nonsignificant trend in DAS, ESR (erythrocyte sedimentation rate) defined, remission (18.7% vs. 12.2%; estimate of difference 6.5; 95% CI, −2.2 to 15.2). Additionally, ACR 20 response was significantly higher for abatacept than infliximab (72.4 percent vs. 55.8 percent, estimate of difference 16.7 percent; 95% CI, 5.5 to 27.8) but ACR 50 and ACR 70 did not reach statistical significance. This study is limited by the fixed dosing of infliximab, which may be lower than generally used in practice. Additionally, the study was powered only to detect differences between the biologics with placebo at 197 days.

Adalimumab versus etanercept. One 52-week prospective observational study used the nationwide Danish DANBIO registry to examine TNF inhibitors adalimumab, etanercept, and infliximab in patients (n=2,326) with RA in whom the first biologic treatment was initiated.73 Twenty-nine percent received adalimumab (mean: 40 mg), 22 percent received etanercept (mean: 45 mg), and 49 percent received infliximab (mean: 3.5 mg/kg). After correction for differences in sex, age, disease duration, seropositivity, DAS28, concomitant MTX and prednisolone treatement, number of previous DMARDs, Health Assessment Questionnaire (HAQ) at baseline, the odds of achieving an ACR 70 at 6 months was not significant for adalimumab compared with etanercept (OR 1.15; 95% CI, 0.82 to 1.60). However, achieving a good EULAR response was higher for adalimumab (OR 1.49; 95% CI, 1.13 to 1.96). Results were similar at 12 months (data NR). This study is limited by the lack of blinding to treatment

Etanercept versus infliximab. The nonrandomized, open-label effectiveness study (N=369) assessed the effectiveness and safety of etanercept (25 mg twice weekly) and infliximab (3 mg/kg or higher every 8 weeks).67 Study duration was 12 months. Comparisons of etanercept and infliximab with the leflunomide arm are reported in the section below comparing oral DMARDs with biologic DMARDs. Etanercept had significantly greater improvement on the ACR 20 at 3 months (P<0.02; data NR) and 6 months (P<0.05; data NR) and on the ACR 50 at 3 months (P<0.005; data NR) than infliximab. The authors attributed these differences partly to a high need of dose adjustments (57 percent) in the infliximab group during the first months of the study. No significant differences between the therapy groups could be detected after 6 months.

Three prospective cohort studies provide similar results, initially favoring etanercept, but with differences lessening over longer time periods.69–71 The first prospective cohort study (N=161) in anti-TNF naïve patients found a higher change in DAS28 at 6 months for etanercept than infliximab (−1.7 vs. −1.3; P=0.03), but no differences in EULAR responses.70 The second prospective cohort (N=707) in anti-TNF naïve patients found a higher change in DAS28 at 12 months for etanercept than infliximab (−1.8 vs. −1.2, P<0.05). A prospective cohort (N=949) with longer followup found that etanercept treatments led to greater improvement on the ACR 50 than infliximab during the first months of treatment, but no differences were noted thereafter for up to 36 months.69 The authors of this study created an index called the LUNDEX (an index of drug efficacy in clinical practice developed at Lund University in Sweden, calculated as the proportion of starters still on the drug at time T times the proportion responding at time T), which takes adherence and efficacy together into consideration. Patients on etanercept achieved higher LUNDEX scores than patients on infliximab, which reflected a significantly lower level of adherence of patients on infliximab compared with those on etanercept (data NR; P<0.001).

Findings from the U.S. prospective cohort study, which was based on the RADIUS (Rheumatoid Arthritis DMARD Intervention and Utilization Study) program and funded by the maker of etanercept, reported similar results.68 Etanercept-treated patients had greater responses than infliximab-treated patients on the modified ACR 20 (mACR 20, which omits ESR and C-reactive protein [CRP] values because they are infrequently measured in clinical practice); percentage improvement rates were 43 percent for etanercept plus MTX, 41 percent for etanercept monotherapy, 35 percent for infliximab plus MTX, and 26 percent for infliximab monotherapy (P=NR). Similarly a Danish cohort (described above in adalimumab vs. etanercept) found a higher odds of achieving an ACR 70 and a good EULAR response at 6 months for etanercept compared with infliximab (good EULAR for etanercept: OR, 1.41; 95% CI, 1.09 to 1.84).73

Adalimumab versus infliximab. In addition to examining the effects of etanercept, two prospective cohort studies examined adalimumab with infliximab.71, 73 The first (N=116) examined adalimumab with infliximab in anti-TNF naïve patients as part of the Dutch Rheumatoid Arthritis Monitoring (DREAM) register. Adalimumab-treated patients had a greater decrease in DAS28 than infliximab-treated patients at 1 year (−1.8 vs. −1.2, P<0.05).71 Similarly, the Danish cohort (described above in adalimumab vs. etanercept) found a higher odds of achieving an ACR 70 and good EULAR response at 6 months for adalimub compared with infliximab (good EULAR for adalimumab: OR 2.10; 95% CI 1.66 to 2.66).73

Rituximab versus anti-TNF. One cohort study (N=116) examined the effectiveness of rituximab (1,000 mg x 2 with concomitant IV glucocorticoids) compared to other anti-TNF agents in patients who had inadequate response to previous ant-TNF therapy.72 The population included Swiss patients receiving anti-TNF therapy in 2003. Patients included in this analyses had an inadequate response to at least one anti-TNF agent (infliximab, etanercept, or adalimumab) and initiated a second or third anti-TNF or rituximab. At 6 months, rituximab-treated patients had a greater decrease in DAS28 than patients treated with an alternative anti-TNF agent (−1.6 vs. −0.98, P=0.01).72

Indirect head-to-head comparisons of biologic DMARDs. Multiple placebo-controlled RCTs and meta-analyses25, 29, 112 provide evidence on the efficacy of abatacept,66, 113–117 adalimumab,118–127 anakinra,75, 128–134 etanercept,86, 126, 135–145 infliximab,66, 126, 135, 146–156, rituximab,84, 157–163 certolizumab pegol,164–168 golimumab,166, 169–171 and tocilizumab.164, 172–178 Most of these studies were conducted in patients who previously failed oral DMARD treatment.

Using information from these placebo-controlled trials, several research groups did meta-analyses to produce adjusted indirect comparisons of biologic DMARDs.28, 74, 75, 179, 180 The underlying assumption for adjusted indirect comparisons to be valid is that the relative efficacy of an intervention is consistent across included studies.181 In the more recent analysis, findings suggested that efficacy does not differ substantially for adalimumab, etanercept, and infliximab, abatacept, and rituximab.27, 74, 180 However, given the wide confidence intervals, clinically significant differences cannot be excluded with certainty. Compared with anakinra, point estimates favored adalimumab, etanercept, and infliximab, but the results were not all statistically significantly different.74, 180 Adjusted indirect comparisons of anti-TNF drugs as a class with anakinra showed a statistically significantly greater efficacy of the anti-TNF drugs on ACR 20 but not on ACR 50.^74^

Mixed treatment comparisons. Our team conducted mixed treatment comparisons (MTC) meta-analyses using Bayesian methods for ACR 20/50/70 that included RCTs of abatacept, adalimumab, anakinra, etanercept, golimumab, infliximab, rituximab, and tocilizumab in MTX- resistant patients. A summary of the studies included and network diagram are described in Table 14 and Figure 2. In the analysis of ACR 50, the data show that etanercept has the highest mean treatment response and anakinra the lowest mean response. Point estimates favor other biologics over anakinra; but the differences were only statistically significant for comparisons with adalimumab and etanercept for ACR 50. In addition, point estimates for etanercept are favored over the other included biologics (ACR 50 OR range for etanercept 2.39–5.20). The differences showed statistically significant improvements in disease activity with etanercept than with abatacept, adalimumab, anakinra, infliximab, rituximab, or tocilizumab, but no statistically significant differences between etanercept and golimumab.

Table 14 Summary of the 30 studies included in mixed treatment comparison meta-analysis

Treatment | Author and Year | Study Name | Time-Point for ACR 50 (weeks) | Total N
Abatacept | Kremer, 2006^116^ | AIM | 24 | 652
| Kremer, 2003^113^ | NR | 24 | 234
| Schiff, 2008^a,66^ | ATTEST | 28 | 266
Adalimumab | Weinblatt, 2003^123^ | ARMADA | 24 | 129
| Furst, 2003^121^ | STAR | 24 | 636
| Keystone, 2004^120^ | NR | 52 | 619
| van de Putte, 2004^122^ | NR | 26 | 438
| van de Putte, 2003^119^ | NR | 12 | 212
| Kim, 2007^127^ | NR | 24 | 128
| Chen, 2008^182^ | NR | 12 | 47
Anakinra | Cohen, 2002^131^ | NR | 24 | 153
| Cohen, 2004^133^ | NR | 24 | 506
| Bresnihan, 1998^128^ | NR | 24 | 353
Etanercept | Moreland, 1999^140^ | NR | 26 | 158
| Weinblatt, 1999^142^ | NR | 24 | 89
| Lan, 2004^143^ | NR | 12 | 58
| Moreland, 1997^144^ | NR | 12 | 88
Golimumab | Keystone, 2009^169^ | GO-FORWARD | 14 | 222
| Kay, 2008^166^ | NR | 16 | 70
Infliximab | Abe, 2006^153^ | NR | 14 | 147
| Kavanaugh, 2000^154^ | NR | 12 | 21
| Zhang, 2006^156^ | NR | 18 | 173
| Maini, 1999^148^ | ATTRACT | 30 | 428
| Westhovens, 2006^155^ | START | 22 | 1,084
| Schiff, 2008^a,66^ | ATTEST | 28 | 275
Rituximab | Edwards, 2004^84^ | NR | 24 | 80
| Emery, 2010^162^ | SERENE | 24 | 512
Tocilizumab | Kremer, 2010^178^ | LITHE | 24 | 1,196
| Smolen, 2008^164^ | OPTION | 24 | 623
| Genovese, 2008^176^ | TOWARD | 24 | 1,220
| Maini, 2006^174^ | CHARISMA | 16 | 148

NR = not reported

a Schiff 2008 (ATTEST) is listed twice as the study included comparisons with both abatacept and infliximab.

Figure 2 Evidence network for ACR 50 mixed treatment comparisons

Note: The total number of trials does not appear to equal 30 (the total number of studies included in the analysis) because some trials have multiple arms that were included.

Figure 2 displays the evidence network for the ACR50 mixed treatment comparisons meta-analysis. The diagram graphically displays the number of studies that comprise the evidence base for the analysis, and indicates the number of head-to-head and placebo-controlled studies underpinning the pairwise comparisons. Centered around placebo, there are eight biologic DMARDS displayed in boxes with a line connecting each drug-drug and each drug-placebo comparison. Next to each line is a number that represents the number of studies for each comparison. The diagram generally resembles a wagon wheel. There are two trials listed on the line connecting golimumab with placebo, seven trials between adalimumab and placebo, four trials between tocilizumab and placebo, two trials between rituximab and placebo, four trials between etanercept and placebo, three trials between anakinra and placebo, three trials between abatacept and placebo, and six trials between infliximab and placebo. Additionally, between abatacept and infliximab, there is a one trial listed that includes a head-to-head comparison between these two biologic DMARDs. There is a note at the bottom of the figure indicating that the total number of trials does not appear to equal 30, the total number of studies included in the analysis, because some trials have multiple arms that were included.

As described in Appendix K four sensitivity analyses were conducted to examine various sources of potential heterogeneity. The four analyses are described below and results are presented in Table 15.

- Sensitivity Analysis 1: Four trials with early escape designs were removed in the main MTC analysis because a large number of crossovers (from placebo to active treatment) in these studies might have led to inaccurate calculations of treatment effects. These four studies were included in a sensitivity analysis to gauge potential impact on overall results.
- Sensitivity Analysis 2: Some trials included in the MTC did not have patients in the relevant arms on a background dose of MTX. To separate the effects that combination therapy may have on the relative treatment effects, monotherapy trials were removed in a sensitivity analysis.
- Sensitivity Analysis 3: To evaluate whether study duration influenced our findings, and to compare with other analyses that have used a 6-month cutoff, the ACR 50 analysis was rerun with studies of durations of 22 weeks or longer.
- Sensitivity Analysis 4: Two trials with etanercept, Lan 2004^143^ and Moreland 1997,^144^ had both a high ACR 50 response and low placebo response. Due to the relatively large differences between treatment and placebo response, we removed these two trials in a sensitivity analysis.

Table 15 Expected (mean) ACR 50 treatment response of biologic DMARDs

| Scenario
Treatment | ACR 50 | Sensitivity Analysis 1 | Sensitivity Analysis 2 | Sensitivity Analysis 3 | Sensitivity Analysis 4
Placebo | 0.0943 | 0.0874 | 0.1029 | 0.0922 | 0.0964
Abatacept | 0.2767 | 0.2603 | 0.2972 | 0.2762 | 0.2818
Adalimumab | 0.3591 | 0.3381 | 0.3734 | 0.3377 | 0.3824
Anakinra | 0.2220 | 0.2076 | 0.2663 | 0.2171 | 0.2283
Certolizumab | NA | 0.4837 | NA | NA | NA
Etanercept | 0.6353 | 0.6129 | 0.6844 | 0.6088 | 0.7129
Golimumab | 0.3909 | 0.3691 | 0.4173 | NA | 0.3986
Infliximab | 0.2810 | 0.2643 | 0.3017 | 0.2960 | 0.2861
Rituximab | 0.2957 | 0.2770 | 0.3179 | 0.2911 | 0.3041
Tocilizumab | 0.3118 | 0.2948 | 0.3300 | 0.3324 | 0.3153

NA = not applicable

In the analysis of ACR 50, the data show that etanercept has the highest mean treatment response and anakinra the lowest mean response. Under each scenario, this trend was maintained. Ranking of the other biologics show that golimumab and adalimumab have the second and third highest response in the ACR 50 analysis and Sensitivity Analyses 2 and 4. In Sensitivity Analysis 3, which included studies with durations of 22 weeks or more, adalimumab and tocilizumab rank behind etanercept, respectively (there are no longer any studies of golimumab included in this analysis). In the sensitivity analysis including all 34 potential studies (Sensitivity Analysis 1), certolizumab pegol has the second highest response, but this relative ranking may be due to the difference in study design, with the required early escape biasing results in favor of active treatment. The results from the sensitivity analyses show the model to be fairly robust.

These findings are consistent with a good-quality German retrospective cohort study based on the RABBIT (German acronym for Rheumatoid Arthritis – Observation of Biologic Therapy) database, which reports higher discontinuation rates due to lack of efficacy for patients on anakinra than for patients on either etanercept or infliximab after 12 months of treatment (30 percent vs. 20 percent vs. 20 percent; P=NR).88 In addition, they are consistent with several cohort studies reporting greater improvements in disease activity with etanercept than with infliximab.68–71 Similarly, one meta-analysis of short-term (12–30 week) treatment of etanercept, adalimumab, and infliximab found higher risk ratios for reaching ACR 50 for etanercept than adalimumab and infliximab (ACR 50 for etanercept 5.28, 95% CI, 3.12 to 8.92; adalimumab 3.50, 95% CI, 2.75 to 4.44, infliximab 2.68, 95% CI, 1.79 to 3.99.^183^

Comparisons with other MTC meta-analyses of biologic DMARDs. We compared our analysis with four other reviews using MTC meta-analyses that compared biologic DMARDs (Nixon 2007,184 Devine 2011,185 Bergman 2010,186 and CADTH 2010^187^). All the meta-analyses present arm-based random effects logistic regression models within a Bayesian framework. Two of the MTC analyses, Devine 2011 and Nixon 2007, use meta-regression to adjust for study-level covariables. Some differences exist between the inclusion/exclusion criteria of our analysis compared with the others, shown in Table 16.

Table 16 Exclusion criteria of MTC meta-analyses

| Exclusions
Study | 6-Month Duration | MTX Naïve | Monotherapy | Biologic Failure | Low-Dose MTX
Devine, 2011 | x | | | x
Bergman, 2010 | x | x
CADTH, 2010 | x | x | x | x | x
Nixon, 2007 | x | | x
RTI-UNC EPC 2011 analysis | Limited to 6-month duration In sensitivity analysis | x | Removed these studies in a sensitivity analysis | x

These differences in criteria led to a different set of studies included in the MTC. Studies included in the other meta-analyses, including our MTC meta-analysis, are listed in Table 14. Reasons for exclusion from our MTC are listed beside trial name. Figure 3 illustrates the relative treatment effect for ACR response.

Figure 3 Relative treatment effect for ACR 50 response for biologics

Figure 3 displays a forest plot of the relative ACR50 treatment effect between eight biologic DMARDs: abatacept, adalimumab, anakinra, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative treatment effect of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 56 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents no difference between the two drugs. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one favor the first drug listed in the comparison, while odds ratios less than one favor the second drug listed in the comparison. Most ACR50 comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: adalimumab versus anakinra, OR 1.88 and 95 percent credible interval of 1.01 to 3.98; etanercept versus abatacept, OR 5.20 and 95 percent credible interval of 2.00 to 11.78; etanercept versus adalimumab, OR 3.50 and 95 percent credible interval of 1.37 to 7.63; etanercept versus anakinra, OR 7.17 and 95 percent credible interval of 2.46 to 16.86; etanercept versus infliximab, OR 4.17 and 95 percent credible interval of 2.00 to 11.17; etanercept versus rituximab, OR 3.76 and 95 percent credible interval of 1.51 to 12.67; and etanercept versus tocilizumab, OR 3.59 and 95 percent credible interval of 1.73 to 9.80.

Biologic DMARD versus oral DMARD. Four RCTs, a nonrandomized trial, and a prospective cohort study determined the comparative efficacy and safety of various biologic and oral DMARDs with approved doses. The RCTs compared adalimumab,76 etanercept,77, 86 and tocilizumab173 with MTX; the nonrandomized trial compared etanercept and infliximab with leflunomide;67 and the cohort study assessed differences in class effects (Table 17).78 No evidence exists on abatacept, anakinra, and rituximab, certolizumab, golimumab, or on oral DMARDs other than MTX and leflunomide. Disease activity and remission results are presented in Table 17 and radiographic damage in Table 18.

Table 17 Disease activity and remission for biologic DMARD versus oral DMARD

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Adalimumab vs. Oral DMARD
(DMARD naïve)
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (<3 years) | ADA (40 mg biweekly) vs. MTX (20 mg/week) | Lower ACR 50 response rates for ADA than MTX (37% vs. 43%; P=NR) | Fair
Etanercept vs. Oral DMARD
(DMARD naive)
Bathon et al., 2000;^77^ Genovese et al., 2002;^188^ Genovese et al., 2005^189^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Early, aggressive RA; MTX-naive; mean disease duration 11.7 months | ETN (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | Similar ACR 20 at 12 months for ETN vs. MTX (72% vs. 65%; P=0.16) | Fair
(Prior DMARD failure)
Klareskog et al., 2004^86^ van der Heijde et al., 2006^136^ van der Heijde et al., 2006^138^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 1 DMARD other than MTX; mean disease duration 6.6 years | ETN (25 mg twice weekly) vs. MTX (7.5 titrated to 20 mg/week) | Higher area under curve of ACR-N for ETN than MTX(14.7%-years vs. 12.2%-years; P= NR) at 24 weeks; but similar ACR 20 at 52 weeks (76% vs. 75%, P=NR) | Fair
Geborek et al., 2002^67^ | Nonrandomized, open-label trial 369 12 months | Population-based; active RA; had failed at least 2 DMARDs; mean disease duration 14.5 years | ETN (25 mg twice weekly) vs. INF (3 mg/kg or higher) vs. LEF (20 mg/day) | Higher ACR 20/50 responses for ETN and INF vs. LEF at 3 months (data NR; P<0.05) and for ETN vs. LEF at 6 months (data NR; P<0.05); results for 12 months: NR | Fair
Tocilizumab vs. MTX
(DMARD naïve)
*Nishimoto et al., 2009^173^ SATORI study | RCT 127 24 weeks | Active RA; inadequate response to MTX | TCZ (8 mg every 4 weeks) vs. MTX (8 mg/week) | Higher ACR 20 response for TCZ than MTX (80.3% vs. 25.0%; P<0.001) | Fair
Biologic class vs. DMARD class
Listing et al., 2006^78^ | Prospective cohort 1,083 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 9.6 years | Biologics as a class (ADA, ANA, ETN, INF; dose NR) vs. DMARDs as a class (dose NR) | Significantly higher chance of remission for biologics than oral DMARDs (OR, 1.95; 95% CI, 1.20 to 3.19) | Fair

* New study added since last review.

ACR = American College of Rheumatology; ADA = adalimumab; ANA = anakinra; CI = confidence interval; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; ERA = early rheumatoid arthritis; ETN = etanercept; INF = infliximab; LEF = leflunomide; mg = milligram; MTX = methotrexate; NR = not reported; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; TCZ = tocilizumab; vs. = versus

Table 18 Radiographic joint damage in biologic DMARDs versus oral DMARD studies

Study | Study Design N Duration | Population With Early RA (<3 years) | Comparison (dose) | Radiographic Outcomes
Adalimumab vs. Oral DMARD
Breedveld et al., 2006^76, *^Hoff et al., 2009^190^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly) vs. MTX (20 mg/week) | Total modified Sharp score change: 5.5 vs. 10.4; P<0.001 Erosion score change: 3.0 vs. 6.4; P<0.001 Joint space narrowing score change: 2.6 vs. 4.0; P<0.001
Etanercept vs. Oral DMARD
Bathon et al., 2000;^77^ Genovese et al., 2002;^188^ Genovese et al., 2005^189^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Yes; MTX-naive patients with early, aggressive RA | ETN (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | Total Sharp score change: 1.0 vs. 1.59; P= 9,111 Erosion score change: 0.47 vs. 1.03; P=0.006
Klareskog et al., 2004^86^ van der Heijde et al., 2006^136^ van der Heijde et al., 2006^138^ TEMPO study | RCT 686 (503 for 2-year results) 52 weeks (2 years, 100 weeks) | No | ETN (25 mg twice weekly) vs. MTX (7.5 titrated to 20 mg/week) | At 1 year: Total modified Sharp score change: 0.52 vs. 2.80; P=0.047 Erosion score change: 0.21 vs. 1.68; P<0.008 Joint space narrowing score change: 0.32 vs. 1.12; P=NR (NS)

* New study added since last review.

ADA = adalimumab; DMARD = disease modifying antirheumatic drug; ERA = early rheumatoid arthritis; ETN = etanercept; INF = infliximab; LEF = leflunomide; mg = milligram; MTX = methotrexate; NR = not reported; P=NR (NS), p value not reported but authors stated it was not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial; TCZ = tocilizumab; TEMPO = Trial of etanercept and Methotrexate with radiographic patient outcomes; vs. = versus

Biologic DMARDs as a class versus oral DMARDs as a class. A prospective cohort study examined differences in clinical and functional remission between biologics as a class (adalimumab, anakinra, etanercept, infliximab (n=818) and oral DMARDs as a class (n=265) in patients who had failed two previous DMARD treatments.78 This study was population-based and part of RABBIT, a German long-term, prospective cohort study of RA patients who had required a change in therapy in daily rheumatologic care. Patients on biologics were younger and had a significantly more active disease at baseline. In a multivariate logistic regression, adjusting for baseline confounders, the investigators determined that patients on biologics had a statistically significantly greater chance of remission (DAS<2.6) after 12 months of treatment (OR, 1.95; 95% CI, 1.20 to 3.19). Likewise, patients treated with biologics had an almost four times higher likelihood of achieving functional independence than patients treated with oral DMARDs (OR, 3.88; 95% CI, 1.71 to 8.79). Nevertheless, both groups had a substantial risk of relapse during the treatment period. Approximately one-half of the patients who were in remission at 6 months achieved a sustained remission until 12 months (biologics, 55 percent; oral DMARDs, 58 percent).

Adalimumab versus MTX. The PREMIER study was conducted in MTX-naive patients with early (disease duration<3 years), aggressive RA.76 This multinational study randomized 799 patients with early RA to a combination of adalimumab (40 mg every other week) and MTX (20 mg/week), adalimumab monotherapy (40 mg every other week), or MTX monotherapy (20 mg/week). Two treatment arms of this 2-year study assessed differences in the efficacy of adalimumab monotherapy (40 mg every other week) and MTX monotherapy (20 mg/week). After 2 years, the proportion of patients who met ACR 50 criteria was lower for those on adalimumab than for those on MTX monotherapy (37 percent vs. 43 percent; P=NR). In contrast, radiographic progression was statistically significantly lower in patients treated with adalimumab than with MTX (5.5 vs. 10.4 Sharp units; P<0.001) (Table 18). No difference was apparent in clinical remission (DAS 28<2.6) between the two treatment groups (both 25 percent); discontinuation rates due to lack of efficacy were similar in the adalimumab and MTX groups (19.0 percent vs. 17.9 percent; P=NR). We report on results of the other comparisons of the PREMIER study in the respective sections (below) on Biologic DMARD plus oral DMARD versus biologic DMARD and Biologic DMARD plus oral DMARD versus oral DMARD.

Etanercept versus MTX. Two trials (in six publications) compared etanercept (10 mg or 25 mg twice weekly) with MTX (20 mg/week) over 52 weeks.77, 86, 136, 138, 188, 189 The ERA (Early Rheumatoid Arthritis) study (N=632) was conducted in patients with early RA who were MTX-naive.77, 188, 189 The TEMPO (Trial of Etanercept and Methotrexate with Radiographic Patient Outcomes) trial86, 136, 138 randomized 686 patients to etanercept plus MTX (25 mg twice weekly plus up to 20 mg/week MTX), etanercept monotherapy (25 mg twice weekly), and MTX monotherapy (up to 20 mg/week).86, 136, 138 Patients had active RA and had failed at least one DMARD other than MTX. About 57 percent of the study population was MTX naive. Patients who had either failed prior MTX treatment or experienced toxic effects were excluded from this study.

Both studies failed to show statistically significant differences between etanercept and MTX in clinical and health outcome measures (SF-36, the Health Assessment Questionnaire [HAQ], the Arthritis-Specific Health Index [ASHI]), and ACR 20/50/70 responses at study endpoints (52 weeks). By contrast, radiographic outcomes were significantly better in patients on etanercept than in those on MTX. For example, in the ERA trial, 72 percent of patients on etanercept and 60 percent on MTX had no radiographic progression of disease (P=0.007). Improved radiographic outcomes were maintained during an open-label extension of the ERA study to 2 years188 and 5 years.189

Etanercept or infliximab versus leflunomide. No RCT compared biologic DMARDs to leflunomide. The only head-to-head evidence came from a nonrandomized, open-label study (N=369) that accessed the efficacy and safety of etanercept (25 mg twice weekly), infliximab (3 mg/kg or higher every 8 weeks), and leflunomide (20 mg/day).67 This study has been described in greater detail in the section (above) on Biologic DMARD versus biologic DMARD. At 3 months and 6 months, a greater percentage of patients on etanercept met ACR 20 and ACR 50 criteria than those on leflunomide (data NR; P<0.05). A greater percentage of patients on infliximab achieved ACR 20 and ACR 50 criteria at 3 months than those on leflunomide (data NR; P<0.05). The authors did not report 12-month data. Both etanercept and infliximab led to significant reductions in prednisolone dosage; by contrast, the investigators did not find any reduction in prednisolone dosage with leflunomide. These findings must be viewed cautiously. Baseline characteristics of patients differed substantially between the leflunomide group and the biologic groups. Leflunomide patients were older and had significantly more joint damage than patients on etanercept or infliximab. Such differences can potentially confound results, introducing bias that would support differences in results among these treatment groups.

Golimumab versus MTX. Two RCTs compared unapproved doses of golimumab (100 mg) with MTX.92, 169 These two studies are referenced in other sections of this report for study arms using approved doses (e.g., golimumab 50 mg plus MTX compared with MTX section), but we do not include them in Table 17 and 18, the overview, our conclusions, or in strength of evidence tables due to the use of unapproved doses in the golimumab plus placebo arms, because it is difficult to draw conclusions about the comparative effectiveness of the approved use of golimumab (50 mg every 4 weeks) with MTX.

The GO-FORWARD study was a phase III, multicenter 52-week trial that randomized subjects (assigned in a 3:3:2:2 ratio) to receive placebo injections plus MTX, golimumab 100 mg injections plus placebo, golimumab 50 mg injections plus MTX, or golimumab 50 mg injections plus MTX 52.^169^ At week 16, patients in the first three groups who had less than 20% improvement in tender and swollen joints were allowed to enter an early escape The trial found no difference in the ACR 20 response between those treated with golimumab 100 mg and those treated with MTX at 52 weeks (ACR 20 45 percent vs. 44 percent, P=NS, NR).

The GO-BEFORE study was a phase III, multicenter trial that randomized subjects to subcutaneous placebo injections plus MTX, golimumab 100 mg injections plus placebo, golimumab 50 mg injections plus MTX, or golimumab 100 mg injections plus MTX capsules.92 At week 24, there were no differences in ACR 20, 50, or 70 between those treated with golimumab 100 mg and those treated with MTX (ACR 50: 32.7 percent vs. 29.4 percent, P=NR) data NR).

Tocilizumab versus MTX. The SATORI study, a multisite RCT in Japan, examined 127 patients with active RA and an inadequate response to MTX.173 Subjects were randomized to MTX (8 mg/week) plus placebo or to tocilizumab (8 mg/kg every 4 weeks) plus placebo. After 24 weeks, those treated with tocilizumab had significantly higher ACR 20 response than those treated with MTX (80.3 percent vs. 25.0 percent, P<0.001). The study findings are limited by a high withdrawal rate; 48% of patients in the MTX group, compared with 11% in the tocilizumab group withdrew during the study, mostly due to unsatisfactory response. Additionally, the dose of MTX used in this study is below the dose usually considered therapeutic. Mulitnational evidence-based recommendations suggest starting MTX at 10–15 mg/week, with the escalation of 5 mg every 2–4 weeks up to 20–30 mg week.191 Thus, this study does not provide evidence that is relevant to determine how tocilizumab compares with MTX as it is generally used in clinical practice.

Biologic combinations: Biologic DMARD plus biologic DMARD versus biologic DMARD. A 24-week RCT did not detect any synergistic effects of a combination treatment of etanercept (25 mg/week or 50 mg/week) and anakinra (100 mg/day) compared with etanercept monotherapy (Table 19).79 Overall, 242 patients who were on stable doses of MTX treatment were enrolled. At endpoint, combination treatment did not lead to greater efficacy than etanercept only. Furthermore, the frequency of serious adverse events was substantially higher in the combination groups (14.8 percent for 50 mg etanercept plus anakinra, 4.9 percent for 25 mg etanercept plus anakinra, and 2.5 percent for etanercept only; P=NR). Likewise, withdrawals because of adverse events were higher in the combination groups than in the etanercept group (8.6 percent vs. 7.4 percent; P=NR).

Table 19 Disease activity and remission for biologic DMARD+biologic DMARD versus biologic DMARD studies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
ETN+AKA vs. ETN
Genovese et al., 2004^79^ | RCT 242 24 weeks | Inadequate control of disease with MTX; mean disease duration 9.9 years | ETN (25 mg twice weekly)+ANK (100 mg/day) vs. ETN (25 mg/week) | Higher ACR 50 response rates for ETN monotherapy (31% vs. 41%; P=0.914) | Fair
ETN+ABA vs. ETN
*Weinblatt, et al., 2007^80^ | RCT 121 1 year 2-year long-term extension | Patients on ETN; mean disease duration 12.8–13 yrs | ETN (25 mg twice weekly)+ABA 2g/kg increased to 10 mg/kg after 1 year) vs. ETN (25 mg twice weekly) | No difference in mACR 20/50/70 response rates at 1 year | Fair

* New study added since last review.

ABA = abatacept; ACR = American College of Rheumatology; ANK = anakinra; ETN = etanercept; kilogram = kg; mACR = modified American College of Rheumatology; milligram = mg; RCT = randomized controlled trial; vs. = versus; yr = year

Similarly, a 1-year RCT (N=121) followed by a 2-year open-label long-term extension (N=80) found no significant differences in modified ACR 20 at 1 year or at 2 and 3 years in the long-term extension for patients treated with abatacept (2 mg/kg for RCT, 10 mg in long-term extension) combined with etanercept (25 mg twice weekly) compared to etanercept only (Table 19).80 Although the initial RCT dosing of abatacept was lower than currently used clinically, the frequency of serious adverse events was higher in the abatacept combined with etanercept-treated patients than in the etanercept-only treated patients.

Biologic DMARD plus oral DMARD versus biologic DMARD. The majority of trials assessed a combination of a biologic DMARD and MTX against a monotherapy of the respective biologic DMARD.68, 76, 81, 84, 86, 87, 126 Only one trial used sulfasalazine as a oral DMARD in combination with a biologic DMARD.85 No evidence is available on combination treatments of abatacept or anakinra. Disease activity and remission results are presented in Table 20 and radiographic joint damage in Table 21.

Table 20 Disease activity and remission for biologic DMARD+oral DMARD versus biologic DMARD studies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Adalimumab+MTX vs. Adalimumab
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (<3 years) | ADA (40 mg biweekly)+MTX (20 mg/week) vs. ADA (40 mg biweekly) | Significantly higher ACR 50 response rates for ADA+MTX than ADA (59% vs. 37%; P<0.001) | Fair
Etanercept+vs. Etanercept
Combe et al., 2006^85^ | RCT 260 24 weeks | Active RA despite SSZ treatment; mean disease duration 6.6 years | ETN (25 mg twice weekly)+SSZ (2, 2.5, or 3 g/day) vs. ETN (25 mg twice weekly) | Similar ACR 20 response rates between ETN+SSZ and ETN (74% vs. 74%; P=NR) | Fair
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006;^138^ *Kavanaugh et al., 2008^192^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 1 DMARD other than MTX; mean disease duration 6.6 years | ETN (25 mg twice weekly)+MTX (7.5 titrated to 20 mg/week) vs. MTX (7.5 titrated to 20 mg/week) | Significantly higher area under curve of ACR-N for ETN+MTX than ETN (18.3%-years vs. 14.7%-years; P<0.0001) at 24 weeks | Fair
Van Riel et al., 2006^87^ | Open-label RCT 315 16 weeks | Inadequate control of disease with MTX; mean disease duration 10.9 years | ETN (25 mg twice weekly)+MTX (>12.5 mg/week) vs. ETN (25 mg twice weekly) | Similar proportions of patients achieved an improvement of >1.2 units of DAS 28 (75% vs. 73%; P=0.66) | Fair
Hyrich et al., 2006^81^ | Prospective cohort 2,711 6 months | Population-based; patients with active RA who required change in therapy; mean disease duration 14.3 years | ETN (25 mg twice weekly)+MTX (dose NR) vs. ETN (25 mg twice weekly)+other DMARD (dose NR) vs. ETN (25 mg twice weekly) | Significantly higher EULAR response rates for ETN+MTX than ETN (OR, 1.98; 95% CI, 1.45–2.71) | Good
Weaver et al., 2006^68^ | Prospective cohort 3,034 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETN (25 mg twice weekly)+MTX (dose NR) vs. ETN (25 mg twice weekly) | Similar mACR 20 response rates for ETN+MTX and ETN (43% vs. 41%; P=NR) | Fair
Zink et al., 2005^88^ | Retrospective cohort 1,523 | Patients with RA who had a change in treatment regimen | ETN+MTX vs. ETN (dosages NR) | Discontinuation due to lack of efficacy: Greater in ETN monotherapy vs. combination (ETN+MTX: 16.9%; ETN: 19.9%; P=NR) | Good
Infliximab+MTX vs. Infliximab
Zink et al., 2005^88^ | Retrospective cohort 1,523 1 year | Patients with RA who had a change in treatment regimen | INF+MTX vs. INF, (dosages NR) | Greater in INF monotherapy than combination (INF+MTX: 17.9%, INF: 45%)
Hyrich et al., 2006^81^ | Prospective cohort 2,711 6 months | Population-based; patients with active RA who required change in therapy; mean disease duration 14.3 years | INF (3 mg/kg)+MTX (dose NR) vs. INF (3 mg/kg)+other DMARD (dose NR) vs. INF (3 mg/kg) | Higher EULAR response rates for INF+MTX than INF (OR, 1.35; 0.92–2.00) | Good
Rituximab+MTX vs. MTX
Edwards et al., 2004^84^ | RCT 161 24 weeks | Active RA despite MTX treatment; mean disease duration 10.4 years | RTX (1,000 mg/days 1 & 15)+MTX (>10 mg/day) vs. RTX (1,000 mg/days 1 & 15) | Higher ACR 50 response rates for the RTX+MTX combination than for RTX monotherapy (43% vs. 33%; P=NR) | Fair

* New study added since last review.

ACR = American College of Rheumatology; ACR-N = American College of Rheumatology percent improvement from baseline to endpoint; ADA = adalimumab; CI = confidence interval; ETN = etanercept; ETN+ABA = etanercept plus abatacept; ETN+AKA = etanercept plus anakinra; EULAR = European League Against Rheumatism response; INF = infliximab; kg = kilogram; mg = milligram; MTX = methotrexate; NR = not reported; NS = not significant; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; RTX = rituximab; SSZ = sulfasalazine; vs. = versus

Table 21 Radiographic joint damage biologic DMARD+oral DMARD versus biologic DMARD studies

Study | Study Design N Duration | Population with Early RA (<3 years) | Comparison (dose) | Radiographic Outcomes
Adalimumab+MTX vs. Adalimumab
Breedveld et al., 2006;^76^ *Hoff et al., 2009^190^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly)+MTX (20 mg/week) vs. ADA (40 mg biweekly) | Total modified Sharp score change: 1.9 vs. 5.5; P<0.001 Erosion score change: 1.0 vs. 3.0; P<0.001 Joint space narrowing score change: 0.9 vs. 2.6; P<0.001
Etanercept+MTX vs. Etanercept
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006^138^ TEMPO study | RCT 686 52 weeks | No | ETN (25 mg twice weekly)+MTX (20 mg/week) vs. ETN (25 mg twice weekly) | At 1 year: Total modified Sharp score change: −0.54 vs. 0.52; P=0.0006 Erosion score change: −0.30 vs. 0.21; P<0.0001 Joint space narrowing score change: −0.23 vs. 0.32; P=0.0007 At 2 years: Total modified Sharp score change: −0.56 vs. 1.10; P<0.05 Erosion score change: −0.76 vs. 0.36; P<0.05 Joint space narrowing score change: 0.20 vs. 0.74; P=NR (NS)

* New study added since last review.

ADA = adalimumab; CI = confidence interval; ETN = etanercept; mg = milligram; MTX = methotrexate; NR = not reported; NS = not significant; P=NR (NS) = p value not reported but authors stated it was not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial; vs. = versus

Adalimumab plus MTX versus adalimumab. The PREMIER study was conducted in MTX-naive patients with early (disease duration<3 years), aggressive RA.76 Details of this study are reported above in Biologic DMARD versus oral DMARD. After 2 years, significantly more patients on the combination therapy achieved response criteria on ACR 50 than patients on adalimumab monotherapy (59 percent vs. 37 percent; P<0.001); in addition, they had statistically significantly less progression on a modified Sharp/van der Heijde score (1.9 vs. 5.5 Sharp units; P<0.001). After 2 years of treatment, 49 percent of patients on the combination therapy and 23 percent on adalimumab monotherapy achieved remission (DAS 28<2.6; P<0.001). Discontinuation rates because of lack of efficacy were lower in the combination group than in the monotherapy group (4.2 percent vs. 19.0 percent; P=NR). We report on results of the other comparisons of the PREMIER study in the respective sections on Biologic DMARD versus oral DMARD and Biologic DMARD plus oral DMARD versus oral DMARD.

Etanercept plus MTX versus etanercept. Two RCTs (in four publications)86, 87, 136, 138 and two prospective cohort studies68, 81 assessed differences in efficacy between an etanercept-MTX combination and etanercept monotherapy in patients with active, DMARD-resistant disease. Findings of these studies consistently supported greater efficacy for the combination therapy than for the etanercept monotherapy.

The TEMPO trial (described above in Biologic DMARD versus oral DMARD) enrolled a mixed population of MTX-naive patients (about 57 percent) and patients who had been on prior MTX treatment (about 43 percent). Patients who had either failed prior MTX treatment or experienced toxic effects were excluded from this study. Results of the etanercept-MTX combination (25 mg twice weekly plus up to 20 mg/week) and the etanercept monotherapy (25 mg twice weekly) arms showed that the combination treatment was significantly more efficacious than etanercept alone. After 52 weeks, 69 percent in the combination group and 48 percent in the etanercept group achieved ACR 50 response criteria (P<0.0001). Likewise, a statistically significantly higher proportion of patients in the combination than in the monotherapy group met ACR 20 and ACR 70 response criteria. The proportion of patients achieving remission (DAS<1.6) was 35 percent in the combination group and 16 percent in the monotherapy group (P<0.0001). In addition, the combination regimen led to significantly better radiographic outcomes (changes in total Sharp score: −0.54 vs. 0.52; P<0.0001) than the etanercept monotherapy.136

A German retrospective cohort study based on the RABBIT database did not find differences in discontinuation rates due to lack of efficacy between patients on etanercept monotherapy and those on an etanercept-MTX combination (19.9 percent vs. 16.9 percent; P=NR).88

Results of year 2 of the TEMPO trial confirmed the long-term sustainability of findings from efficacy RCTs.138 ACR response criteria, DAS remission rates, quality-of-life measures, and radiographic progression were statistically significantly better in the combination group than in the etanercept monotherapy group. Attrition was 39 percent after 2 years and could compromise the internal validity of the long-term results.

The other three studies included a 16-week, open-label RCT (N=315),87 a 12-month prospective cohort study,68 and a 6-month prospective cohort study.81 Their results were generally consistent with findings from the TEMPO trial. Both prospective cohort studies were population-based, one in the United States68 and the other in the United Kingdom,81 and both have a high generalizabilty.

The UK study also compared the effectiveness of the etanercept-MTX combination and a combination of etanercept and other DMARDs (leflunomide, azathioprine, sulfasalazine, hydroxychloroquine, cyclosporine A, penicillamine, gold, minocycline) as a class.81 After adjusting for potential confounders, the investigators reported statistically significantly higher response rates for MTX as a cotherapy than for other DMARDs (OR, 1.66; 95% CI, 1.14 to 2.42).

Etanercept plus sulfasalazine versus etanercept. A 24-week RCT assessed the comparative efficacy of etanercept and sulfasalazine combination therapy (respectively, 25 mg twice weekly plus 2, 2.5, or 3 g/day), etanercept monotherapy (25 mg twice weekly), and sulfasalazine monotherapy (2, 2.5, or 3 g/day) in patients with active RA who had failed previous sulfasalazine treatment.85 Because sulfasalazine monotherapy resembles a placebo treatment (patients had to have failed it to be eligible), we focus on results from the combination (n=101) and etanercept monotherapy (n=103) arms. After 24 weeks, both groups had similar clinical responses on multiple outcome measures (ACR 20/50/70, DAS28). On ACR 20, the primary efficacy variable, 74 percent of patients in both groups met the relevant response criteria. Likewise, results on patient-reported measures of quality of life (HAQ, EuroQOL, general health VAS) were similar for patients on the combination and monotherapy interventions.

Golimumab plus MTX versus golimumab. Two RCTs compared golimumab plus MTX with unapproved does of golimumab (100 mg).92, 169 These two studies are referenced in other sections of this report for study arms using approved doses (e.g., golimumab 50 mg plus MTX compared with MTX section), but we do not include them in Table 20 and 21 the overview, our conclusions, because it is difficult to draw conclusions about the comparative effectiveness of the approved use of golimumab (50 mg every 4 weeks) plus MTX.

The GO-BEFORE study was a phase III, multicenter trial that randomized subjects to subcutaneous placebo injections plus MTX, golimumab 100 mg injections plus placebo, golimumab 50 mg injections plus MTX, or golimumab 100 mg injections plus MTX capsules.92 The GO-FORWARD study was a phase III, multicenter 52-week trial that randomized subjects (assigned in a 3:3:2:2 ratio) to receive placebo injections plus MTX, golimumab 100 mg injections plus placebo, golimumab 50 mg injections plus MTX, or golimumab 50 mg injections plus MTX 52.^169^ For both trials, the golimumab plus placebo arm of the trial used an unapproved dose of golimumab, thus it is difficult to draw conclusions about the comparative effectiveness of the approved use of golimumab (50 mg every 4 weeks and combination therapy with golimumab plus MTX.

Infliximab plus MTX versus infliximab. No RCT examined the comparative efficacy and effectiveness of a combination of infliximab and MTX against infliximab monotherapy in patients with RA. Of note, infliximab is not FDA approved for use as monotherapy. The only comparative evidence includes one U.S. and one U.K. prospective cohort study (already described).68, 81 Both studies indicated that EULAR and modified ACR response criteria were greater for patients in the studies’ infliximab combination groups. Remission rates, however, were similar in both studies for the two regimens. At 6 months, U.K. patients in the combination group had higher EULAR response rates than those in the monotherapy group (OR, 1.35; 95% CI, 0.92 to 2.00).81 At 12 months, mACR 20 responses were similar for U.S. patients in the combination and the monotherapy groups (OR, 0.96; 95% CI, 0.76 to 1.21; P=0.72).68

A German retrospective cohort study assessing discontinuation rates in clinical practice reported findings similar to those noted above. Discontinuation rates because of lack of efficacy were higher among patients on an infliximab monotherapy than among those on an infliximab-MTX combination regimen (45 percent vs. 18 percent; P=NR).88 Overall discontinuation rates, however, were statistically significantly higher in the monotherapy than in the combination group (56 percent vs. 34 percent; hazard ratio, 1.9; 95% CI, 1.1 to 3.1).

Rituximab plus MTX versus rituximab. One RCT enrolled patients with highly active, long-standing, DMARD-resistant RA to compare the efficacy of rituximab and MTX (1,000 mg on day 1 and day 15 plus MTX 10 mg or more/week), rituximab monotherapy (1,000 mg on day 1 and day 15), rituximab and cyclophosphamide, and MTX monotherapy.84 Because cyclophosphamide is not a drug of interest for this report and because MTX monotherapy resembles a placebo treatment (patients had to have failed MTX treatment to be eligible), we focus on results of the rituximab-MTX combination (n=40) and the rituximab monotherapy (n=40) arms. After 24 weeks, patients on the combination intervention experienced changes in DAS outcomes similar to those for patients on rituximab monotherapy (−2.6 vs. −2.2; P=NR). A similar proportion of patients in both treatment groups achieved a good or moderate EULAR response (83 percent vs. 85 percent; P=NR). However, the proportion of patients meeting all three ACR response criteria was higher for patients treated with the rituximab combination treatment than for patients on rituximab monotherapy (ACR 20, 73 percent vs. 65 percent; ACR 50, 43 percent vs. 33 percent; ACR 70, 23 percent vs. 15 percent; P=NR). Higher ACR response rates for the combination treatment were maintained during a 48-week, double-blinded followup. After 48 weeks, 35 percent of patients on the combination regimen and 15 percent of patients on rituximab monotherapy met the ACR 50 response criteria.

Biologic combinations: Biologic DMARD plus oral DMARD versus oral DMARD. The evidence is limited to six studies and one systematic review193 comparing a combination regimen of abatacept plus MTX89 adalimumab plus MTX76 or a combination of etanercept plus MTX86, 90 or a combination regimen of infliximab plus MTX82 with MTX monotherapy. One study examined etanercept plus sulfasalazine versus sulfasalazine monotherapy.85 Four studies and a systematic review193 were conducted in patients with early, aggressive RA.76, 82, 89, 90 Table 22 presents disease activity and remission results, followed by radiographic joint damage in Table 23.

Table 22 Disease activity and remission for biologic DMARD+oral DMARD versus oral DMARD

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Abatacept+MTX vs. MTX
*Westhovens et al., 2009^89^ | RCT 509 2 year (1 year reported) | Early RA, MTX-naïve or previous MTX ≤10 mg/week for 3 weeks or less, with none for prior 3 months | Abatacept (~10 mg/kg)+MTX vs. MTX | Significantly higher ACR 50 response rates for ABA+MTX than MTX (57.4% vs. 42.3%; P<0.001) Higher remission rates for ABA+MTX than MTX (41.4% vs. 23.3%; P<0.001) | Good
Adalimumab+MTX vs. MTX
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (<3 years) | ADA (40 mg biweekly)+MTX (20 mg/week) vs. MTX (20 mg/week) | Significantly higher ACR 50 response rates for ADA+MTX than MTX (59% vs. 43%; P<0.001) | Fair
Etanercept+MTX vs. MTX
*Emery et al., 2008^90^; Emery et al., 2010^91^ COMET study | RCT 542 52 weeks^†^ 2 years91 | MTX-naïve patients; Early RA, mean disease duration 9 months | ETN (50 mg/week)+MTX 7.5 mg vs. MTX | Higher ACR 20 response rates between ETN+MTX vs. MTX (86%, 67%, P<0.001) Higher remission between ETN+MTX vs. MTX (50%, 28%, P<0.001) | Fair
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006,^138^ *Kavanaugh et al., 2008^192^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 1 DMARD other than MTX; mean disease duration 6.6 years | ETN (25 mg twice weekly)+MTX (7.5 titrated to 20 mg/week) vs. MTX (7.5 titrated to 20 mg/week) | Significantly higher area under curve of ACR-N for ETN+MTX than MTX (18.3%-years vs. 12.2%-years; P<0.0001) at 24 weeks | Fair
Etanercept+Sulfasalazine vs. Sulfasalazine
Combe et al., 2006^85^ *Combe et al., 2009^145^ | RCT 260 24 weeks 2 years | Active RA despite SSZ treatment; mean disease duration 6.6 years | ETN (25 mg twice weekly)+SSZ (2, 2.5, or 3 g/day) vs. SSZ (2, 2.5, or 3 g/day) | Higher ACR 20 response rates between ETN+SSZ and SSZ (74% vs. 28%; P=NR) Higher remission at 2 years ETN+SSZ than SSZ (DAS <2.5; 57% vs.4.0%; P<0.01) | Fair
Golimumab+MTX vs. MTX
*Emery et al., 2009^92^ GO-BEFORE | RCT 637 24 weeks | MTX-naïve patient with active RA | GOL (50 mg)+MTX vs. MTX | Higher ACR 50 response rates between GOL+MTX and MTX (40.3% vs. 29.4%; P=0.042) | Fair
Infliximab+MTX vs. MTX
St Clair et al., 2004;^82^ Smolen et al., 2006;^83^ *Smolen et al., 2009^194^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX-naive; mean disease duration 0.9 years | INF (3 mg/kg/8 weeks)+MTX (20 mg/week) vs. INF (6 mg/kg/8 weeks)+MTX (20 mg/week) vs. MTX (20 mg/week) | Significantly greater improvement of ACR-N for INF 3 mg+MTX and INF 6 mg+MTX than MTX (38.9% vs. 46.7% vs. 26.4%; P<0.001) Higher remission in INF+MTX vs. MTX (DAS28-ESR<2.6; 21.3%, 12.3%; P<0.001) | Fair

* New study added since last review.

† In COMET, subjects were randomized to one of four treatment groups: (1) ETN+MTX for year 1 followed by the same treatment for year 2, (2) ETN+MTX for year 1 followed by ETN alone for year 2, (3) MTX for year 1 followed by ETN+MTX for year 2, or (4) MTX for year 1 followed by continued MTX for year 2. Thus, all subjects were treated with ETN+MTX or MTX for 1 year and we present the 52-week outcomes in this table

ADA = adalimumab; ETN = etanercept; mg = milligram; MTX = methotrexate; RA = rheumatoid arthritis; RCT = randomized controlled trial; TEMPO = Trial of etanercept and Methotrexate with radiographic patient outcomes; vs. = versus

Table 23 Radiographic joint damage of biologic DMARD+oral DMARD versus oral DMARD

Study | Study Design N Duration | Study Population | Comparison (dose) | Results
Abatacept+MTX vs. MTX
*Westhovens et al., 2009^89^ | RCT 509 2 year (1 year reported) | Early RA, MTX-naïve or pervious MTX ≤10 mg/week for 3 weeks or less, with none for prior 3 months | Abatacept (~10 mg/kg)+MTX vs. MTX | Genant modified Sharp total score mean change 0.63 vs. 1.06; P<0.040
Adalimumab+MTX vs. MTX
Breedveld et al., 2006,^76^ *Hoff et al., 2009^190^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly)+MTX (20 mg/week) vs. MTX (20 mg/week) vs. ADA (40 mg biweekly) | Total modified Sharp score change: 1.9 vs. 10.4; P<0.001 Erosion score change: 1.0 vs. 6.4; P<0.001 Joint space narrowing score change: 0.9 vs. 4.0; P<0.001
Etanercept+MTX vs. MTX
*Emery et al., 2008;^90^ Emery et al., 2010^91^ COMET study | RCT 542 52 weeks^†^ 2 years91 | MTX-naïve patients; early RA, mean disease duration 9 months | ETN (50 mg/week)+MTX 7.5 mg vs. MTX | Lower radiographic progression between ETN+MTX vs. MTX (mTSS −2.44, −0.27 P<0.001)

* New study added since last review.

† In COMET, subjects were randomized to one of four treatment groups: (1) ETN+MTX for year 1 followed by the same treatment for year 2, (2) ETN+MTX for year 1 followed by ETN alone for year 2, (3) MTX for year 1 followed by ETN+MTX for year 2, or (4) MTX for year 1 followed by continued MTX for year 2. Thus, all subjects were treated with ETN+MTX or MTX for 1 year and we present the 52-week outcomes in this table.

ADA = adalimumab; ETN = etanercept; mg = milligram; MTX = methotrexate; RA = rheumatoid arthritis; RCT = randomized controlled trial; TEMPO = Trial of etanercept and Methotrexate with radiographic patient outcomes; vs. = versus

Abatacept plus MTX versus MTX. One multinational RCT randomized 509 subjects with early RA to receive abatacept plus MTX or placebo plus MTX.89 The trial enrolled subjects with early agressive RA who were MTX-naïve and seropositive for rheumatoid factor, anti-cyclic citrullinated protein type 2, or both, and had radiographic evidence of joint erosions. At 1 year, subjects treated with abatacept plus MTX had statistically significantly greater improvement in ACR 50 measures, remission defined by DAS28 less than 2.6 (41.4 percent vs. 23.3 percent; P<0.001) and less radiographic progression (mean change TS 0.63 vs. 1.06; P 0.040).

Adalimumab plus MTX versus MTX. The PREMIER study was conducted in MTX-naive patients with early (disease duration <3 years), aggressive RA76 (see Biologic DMARD plus oral DMARD versus biologic DMARD). Two treatment arms of this 2-year study assessed differences in efficacy between a combination of adalimumab (40 mg every other week) and MTX (20 mg/week) and MTX monotherapy (20 mg/week).76 After 2 years, statistically significantly more patients on the combination therapy met ACR 50 response criteria than patients on MTX monotherapy (59 percent vs. 43 percent; P<0.001); in addition, they had statistically significantly less progression on the modified SHS score (changes in total Sharp score: 5.5 vs. 10.4; P<0.001). After 2 years of treatment, 49 percent of patients on the combination therapy and 25 percent on MTX monotherapy achieved remission (DAS28<2.6; P<0.001). Discontinuation rates because of lack of efficacy were lower in the combination than in the MTX group (4.2 percent vs. 17.9 percent; P=NR).

Etanercept plus MTX versus MTX. Two trials (in six publications) compared etanercept (10 mg or 25 mg twice weekly or 50 mg weekly) with MTX (20 mg/week) over 52 weeks.86, 136, 138, 192 The COMET (Combination of Methotrexate and Etanercept in Active Early Rheumatoid Arthritis) study (N=542) was conducted in patients with early RA who were MTX-naïve.90 The TEMPO trial,86, 136, 138, 192 described above in the section, Biologic DMARD versus biologic DMARD randomized 686 patients to etanercept plus MTX (25 mg twice weekly plus up to 20 mg/week), etanercept monotherapy (25 mg twice weekly), and MTX monotherapy (up to 20 mg/week).86, 136, 138 The COMET trial90 compared 542 early RA patients with etanercept (50 mg weekly) plus MTX (7.5 mg weekly) versus MTX in year 1. However, subjects were actually randomized to one of four treatment groups: (1) etanercept plus MTX for year 1 and year 2 (EM/EM), (2) etanercept plus MTX for year 1 followed by etanercept alone for year 2 (EM/E), (3) MTX for year 1 followed by year 2 (M/EM), or (4) MTX for year 1 followed by continued MTX for year 2 (M/M).91. Both studies showed statistically significant differences between etanercept plus MTX versus MTX in achieving ACR 20 response criteria at 24 weeks86 and 52 weeks.90 In the COMET study, patients treated with etanercept plus MTX had a higher remission (50 percent vs. 28 percent, P<0.001) and less radiographic progression than MTX only.90 After 2 years, remission remained higher for patients in the EM/EM group compared with the M/M group (57 percent vs. 35 percent, P=0.002) and radiographic progression was also less (10 percent vs. 33 percent, P=0.009).91

Golimumab plus MTX versus MTX. The GO-BEFORE study was a phase III, multicenter RCT in MTX-naïve patients with active RA that randomized subjects to subcutaneous placebo injections plus MTX capsules, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 100 mg injections plus MTX capsules.92 The trial reported a higher ACR 50 response at week 24 for golimumab 50 mg plus MTX than MTX only (ACR 50: 40.3 percent vs. 29.4 percent; P=0.042).

Infliximab plus MTX versus MTX. The ASPIRE (Active-controlled Study of Patients Receiving Infliximab for the Treatment of Rheumatoid Arthritis of Early Onset) trial enrolled 1,049 patients with early RA (disease duration <3 years) who were MTX-naive.82 This study compared the benefits of initiating treatment with MTX (20 mg/week) alone or of using two different combinations of MTX and infliximab (3 mg/kg or 6 mg/kg) over 54 weeks. At endpoint, patients in the combination groups had significantly higher ACR-N (ACR-N is the percentage of ACR improvement from baseline to endpoint) scores than patients on MTX monotherapy (38.9 percent [3 mg infliximab plus MTX] versus 46.7 percent [6 mg infliximab plus MTX] versus 26.4 percent [MTX]; P<0.001); remission rates were 31 percent, 21 percent, and 15 percent, respectively. The patients treated with infliximab plus MTX also had higher remission rates than patients treated with MTX alone (DAS28 ESR <2.6; 21.3 percent vs. 12.3 percent, P<0.001).194

Biologic plus MTX versus MTX. One systematic review with meta-analysis of seven trials (N=2,763 patients) examined four combinations of biologics with MTX, including infliximab, adalimumab, etanercept, and abatacept, compared to MTX only.193 Overall, clinical remission was higher for the compination therapy as compared with MTX only (RR, 1.74; 95% CI, 1.54 to 1.98). Radiographic nonprogression was also higher for combination therapy (RR, 1.30; 95% CI, 1.01 to 1.68). These results are limited by the heterogeneity in the definity of clinical remission and radiographic nonprogression. None of the included trials lasted more than 1 year.

Biologic combinations: Biologic DMARD plus oral DMARD versus biologic DMARD plus oral DMARD. Three prospective cohorts compared patients taking an anti-TNF plus oral DMARD to patients taking another anti-TNF plus oral DMARD.93, 94, 195 Each compared a different anti-TNF-oral DMARD combination and followup ranged from 6 months to 17 months. Comparisons included anakinra plus MTX versus anakinra plus LEF,93 etanercept plus oral DMARD versus infliximab versus oral DMARD,195 and ‘anti-TNF’ (infliximab, etanercept or adalimumab) plus MTX versus anti-TNF plus MTX.94 Overall, all three studies found similar disease activity responses (measured by ACR 20, EULAR and DAS28) for patients on anti-TNF plus oral DMARD compared to patients taking another anti-TNF plus oral DMARD. Similarly, radiographic progression was similar among anti-TNF+MTX groups.94 Table 24 presents disease activity and remission while Table 25 presents radiographic joint damage.

Table 24 Disease activity and remission for biologic DMARD+oral DMARD versus biologic DMARD+oral DMARD

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Anakinra+MTX vs. Anakinra+Leflunomide
*Karanikolas, et al., 2008^93^ | Prospective cohort 128 48 weeks | Patients failed oral DMARD | ANK (100 mg/day)+MTX (25 mg/week) vs. ANK+LEF (20 mg/week) | No significant difference in ACR 20 response between ANK +MTX and ANK+LEF (65%, 81%; P=NS, NR) | Fair
Etanercept+Oral DMARD vs. Infliximab+Oral DMARD
*Hyrich, et al., 2006^195^ | Prospective cohort 2,879 6 months | Population-based, UK; patients failed at least 2 DMARDs; mean disease duration 14 years | ETN (dose NR) vs. INF (NR) (98% also received MTX) | Similar good EULAR response between ETN and INF (17.3% vs. 18.7%; P=NR | Fair
Anti-TNF+MTX vs. Anti-TNF+Leflunomide
*Finckh et al., 2009^94^ SCQM cohort | Prospective Cohort 1,218 17 months (mean) | Population-based: treatment with INF, ETN or ADA; mean disease duration 8.4–8.9 years | Anti-TNF(INF or ETN or ADA)(dose NR)+MTX (NR) vs. anti-TNF (INF or ETN or ADA) (NR)+LEF | Similar DAS 28 improvement at 1 yr for anti-TNF+MTX and anti-TNF+LEF (0.74; 95% CI, 0.63 to 0.84 vs. 0.63; 95% CI, 0.45 to 0.82, P=NR) | Fair

* New study added since last review.

ACR = American College of Rheumatology; ADA = adalimumab; ANK = anakinra; CI = confidence interval; DMARD = disease modifying anti-rheumatic drug; ETN = etanercept; EULAR = European League Against Rheumatism response; INF = infliximab; LEF = leflunomide; mg = milligram; NR = not reported; NS = not significant; SCQM = Swiss Clinical Quality Management; TNF = tumor necrosis factor; vs. = versus

Table 25 Radiographic joint damage for biologic DMARD+oral DMARD versus biologic DMARD+oral DMARD

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Anti-TNF+MTX vs. Anti-TNF+Leflunomide
*Finckh et al., 2009^94^ SCQM cohort | Prospective cohort 1,218 17 months (mean) | Population-based: treatment with INF, ETN or ADA; mean disease duration 8.4–8.9 years | Anti-TNF(INF or ETN or ADA)(NR)+MTX (NR) vs. anti-TNF (INF or ETN or ADA) (NR)+LEF | Similar nonsignificant radiographic progression for anti-TNF +MTX and anti-TNF+LEF (0.91%; 95% CI, 0.54 to 1.27 vs. 0.74%; 95% CI, 0.21 to 1.27, P=NS, NR) | Fair

* New study added since last review.

ADA = adalimumab; ASPIRE = Active-Controlled Study of Patients Receiving Infliximab for Treatment of Rheumatoid Arthritis of Early Onset; SCQM = Swiss Clinical Quality Management; INF = infliximab; kg = kilogram; LEF = leflunomide; mg = milligram; NR = not reported; NS = not reported; RA = rheumatoid arthritis; RCT = randomized controlled trial; TNF = tumor necrosis factor; vs. = versus

Treatment strategies. Treatment strategies are guided by clinical response and may involve drug combinations. Disease activity and remission are presented in Table 26 and radiographic joint damage in Table 27. Available treatment strategy studies focus on early RA patients.

Table 26 Disease activity and remission for early RA DMARD strategies

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Two Oral DMARDs+Corticosteroid vs. Oral DMARD
Boers et al., 1997;^95^ Landewe et al., 2002^96^ COBRA Study | RCT 155 (148) 56 weeks (5-year followup) | Multicenter; early RA; mean disease duration 4 months | SSZ (2 g/day)+MTX (7.5 mg/day stopped after 40 weeks)+PNL (60 mg/day tapered over 28 weeks) vs. SSZ | Pooled disease index: mean change better in combo group than SSZ alone at 28 weeks (1.4 vs. 0.8; P<0.0001) vs. no longer significant at 52 weeks (1.1 vs. 0.9; P=0.20) (Pooled index included tender joint count, grip strength, ESR, VAS, MACTAR questionnaire) | Good
Three Oral DMARDs+Corticosteroid vs. Oral DMARDs
Mottonen et al., 1999;^97^ Korpela et al., 2004^98^ FIN-RACo study | RCT 199 24 months (5-year follow-up) | Multicenter; early RA; mean disease duration 7.3–8.6 months | MTX (7.5 to 10 mg/week)+HCQ (300 mg/day)+SSZ (2 g/day)+PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd line) ± PNL | Remission (defined by ACR preliminary criteria modified by authors) higher in combination group (37.9% vs. 18.4%; P=0.011); ACR 50 higher in combination group (71% vs. 58%; P=0.058); (5-year remission, NS, 28% vs. 22%; P=NS) | Fair
Three Oral DMARDs vs. Biologic+Oral DMARD
Van Vollenhoven et alo., 2009^99^ Swefot trial | RCT 258 12 months | Swedish, multicenter; early RA; mean disease duration 6.2–6.3 months | DAS-driven treatment; MTX up to 20mg /wk for 3–4 months, if DAS >3.2 randomized to MTX (up to 20 mg/week) +SSZ (1,000 mg twice/day)+HCQ (400 mg/day vs. MTX (up to 20 mg/week)+INF (3 mg/kg) | EULAR good response lower in combination oral DMARD group (25% vs. 39%; P=0.0160 | Fair
Other Combination Strategies
Goekoop-Ruiterman et al., 2005;^100^ *Allaart et al., 2006;^101^ *Goekoop-Ruiterman et al., 2007;^102^ *van der Kooij, et al., 2009;^103^ *van der Kooij et al., 2009;^196^ *van der Kooij et al., 2008^197^ BeSt study | RCT 508 12 months 2 years 4 years | Multicenter; early RA; median duration between diagnosis and inclusion 2 weeks (IQR 1 to 5); median duration of symptoms 23 weeks (IQR 14 to 53) | DAS-driven treatment; 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: stepped-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/d to 7.5 mg/day) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | DAS ≤2.4: 53%, 64%, 71%, 74%; P=0.004 for 1 vs. 3; P=0.001 for 1 vs. 4; P=NS for other comparisons Shorter time to DAS<2.4 for initial combination therapy groups (groups 3 and 4) than monotherapy groups (groups 1 and 2) (Median months; 3,3,9,9 P<0.001) Similar remission among groups at 4 years (DAS<1.6; 50%, 41%, 38%, 42%; P=0.40) | Good

* New study added since last review.

BeST = Dutch acronym for Behandel Sstrategieen; COBRA = Combinatietherapie Bij Reumatoide Artritis; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; ERA = early rheumatoid arthritis; ESR = erythrocyte sedimentation rate; ETN = etanercept; g = gram; HCQ = hydroxychloroquine; INF = infliximab; IQR = interquartile range; kilogram = kg; MACTAR = McMaster Toronto Arthritis Questionnaire mg = milligram; MTX = methotrexate; NR = not reported; NS = not significant; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; VAS = visual analog scale; vs. = versus

Table 27 Radiographic joint damage in early RA strategy studies

Study | Study Design N Duration | Population with Early RA (<3 years) | Comparison (dose) | Radiographic Outcomes
Two Oral DMARDs+Corticosteroid vs. Oral DMARD
Boers et al., 1997;^95^ Landewe et al., 2002^96^ COBRA Study | RCT 155 (148) 56 weeks (5-year followup) | Yes | SSZ (2 g/day)+MTX (7.5 mg/day stopped after 40 weeks)+PNL (60 mg/day tapered over 28 weeks) vs. SSZ | 56 week Modified Sharp/van der Heijde 5.6 vs. 8.6; P=0.001
Two Oral DMARDs+Corticosteroid vs. Oral DMARD
Mottonen et al., 1999;^97^ Korpela et al., 2004^98^ FIN-RACo study | RCT 199 24 months (5 years) | Yes | MTX (7.5 to 10 mg/week)+HCQ (300 mg/day),+SSZ (2 g/day)+PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd line) ± PNL | 2-year Larsen score change: 2 vs. 10; P=0.002 2-year erosion score change: 2 vs. 3; P=0.006 5-year median Larsen score: 11 vs. 24; P =0.001
Other combination strategies
Goekoop-Ruiterman, 2005^100^ *Allaart et al., 2006;^101^ *Goekoop-Ruiterman et al., 2007;^102^ *van der Kooij, et al., 2009;^103^ *van der Kooij, et al., 2009;^196^ *van der Kooij et al., 2008^197^ BeST study | RCT 508 12 months (2 years, 4 years) | Yes | DAS-driven treatment: 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: stepped-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/day-7.5 mg/day) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | Median modified Sharp/van der Heijde score change: 2.0, 2.5, 1.0, 0.5; P=0.003 for 1 vs. 3, P<0.001 for 1 vs. 4; P=0.007 for 2 vs. 3; P<0.001 for 2 vs. 4 In year 2, less joint damage in groups 3 and 4 (median modified Sharp/van der Heijde score change: 2.0, 2.0, 1.0, 1.0; P=0.004) In year 4, less joint damage in groups 3 and 4 (median modified Sharp/van der Heijde score change: 5.0, 5.5, 3.0, 2.5; P<0.05 for 1 and 2 vs. 4)

* New study added since last review.

BeST = Dutch acronym for Behandel Sstrategieen; COBRA = Combinatietherapie Bij Reumatoide Artritis; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; ETN = etanercept; FIN-RACo = Finnish Rheumatoid Arthritis Combination Therapy; g = gram; HCQ = hydroxychloroquine; INF = infliximab; kg = kilogram; mg = milligram; MTX = methotrexate; NR = not reported; NS = not significant; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Two oral DMARDs plus corticosteroid versus oral DMARD. One multicenter RCT, known as COBRA (Combinatietherapie Bij Reumatoide Artritis), assessed differences in efficacy between a combination of stepped-down prednisolone, MTX, and sulfasalazine and sulfasalazine only.95 The investigators randomized 155 Dutch patients with early RA for 56 weeks. Patients with active RA were included if they had had symptoms for fewer than 2 years and had not used DMARDs in the past. Patients were then followed indefinitely in an open-label prospective cohort (5-year follow-up data reported).96 Combination therapy included a stepped-down prednisolone treatment (60 mg/day tapered over 28 weeks), MTX (7.5 mg/week stopped after 40 weeks), and sulfasalazine (2 g/day). Mean duration of RA was 4 months. The authors applied a pooled index, which yielded a weighted change score of five disease activity measures: tender joint count, grip strength, erythrocyte sedimentation rate (ESR), assessor’s global assessment by visual analog scale (VAS), and the McMaster Toronto arthritis questionnaire (MACTAR) (score range not given). At 28 weeks, patients on combination therapy had an improved change score in this index (mean change 1.4 vs. 0.8; P<0.0001). At 52 weeks, however, the change results on the pooled index were no longer significant (mean change 1.1 vs. 0.9; P=0.20). In terms of radiographic progression, patients on combination therapy had statistically significantly less progression than the monotherapy patients on the modified Sharp/van der Heijde score at 28 weeks (1 vs. 4; P<0.0001), 56 weeks (2 vs. 6; P<0.004), and 80 weeks (4 vs. 12; P<0.01). Over 5 years, the modified Sharp/van der Heijde change score per year was lower for combination therapy than for monotherapy (5.6 vs. 8.6; P=0.001).96

Three oral DMARDs plus corticosteroid versus oral DMARD. The FIN-RACo (Finnish Rheumatoid Arthritis Combination Therapy) RCT assessed the efficacy of a complex combination of prednisolone (5 to 10 mg/day), MTX (7.5 to 10 mg/week), sulfasalazine (2 g/day), and hydroxychloroquine (300 mg/day) against that of monotherapy with a DMARD with or without prednisolone.97 The investigators randomized 199 patients with early RA to either combination therapy or monotherapy. Patients on monotherapy were initially started on sulfasalazine (2 to 3 g/day) but could be changed to MTX (7.5 to 15 mg/week), then changed to a third DMARD if needed (azathioprine, auranofin, hydroxychloroquine, injectable gold, penicillamine, or podophyllotoxin). If patients reached remission in the first year, they could be tapered and prednisolone and MTX could be discontinued at 9 months and 18 months, respectively. Adding prednisolone (up to 10 mg/day) in the monotherapy group was left up to the treating physician and allowed in patients with continuously active disease. After 2 years, remission (judged by the authors using modified ACR 20) was higher in the combination group than in the monotherapy group (37.9 percent vs. 18.4 percent; P=0.011); the proportion achieving ACR 50 response criteria was higher in the combination group than in monotherapy group but did not reach statistical significance (71 percent vs. 58 percent; P=0.058). Larsen Scale radiographic scores had also improved at 2 years in the combination group as compared with the monotherapy group (Larsen Scale score increase 2 vs. 10; P=0.002). Subsequently, patients in this trial were followed for 5 years.98 Those in the monotherapy group were allowed to be treated with combinations of DMARDs if their response was insufficient. At 5 years, the median Larsen Scale score remained lower in the combination therapy group than in the monotherapy group (11 vs. 24; P=0.001). This trial can be considered an effectiveness trial given the flexibility of dosing in an effort to follow clinical practice.

Three oral DMARDs versus biologic plus oral DMARD. One multicenter RCT in Sweden examined the efficacy of an oral DMARD combination versus a biologic plus oral DMARD.99 A total of 487 patients with early RA were initially treated MTX (up to 20 mg/wk) and if they did not respond after 3–4 months, they were randomized to MTX (up to 20 mg/wk) plus sulfasalazine (1000 mg twice/day) plus hydroxychloroquine (400 mg/day) versus MTX (up to 20 mg/wk) plus infliximab (3 mg/kg at week 0, 2, 6 and then every 2 months). Of the 487 patients enrolled, 29.8% (n=145) responded to MTX monotherapy and 258 were randomized to the combination oral DMARD arm versus the infliximab plus MTX arm. At 1 year, significantly more patients in the infliximab plus MTX arm achieved a good EULAR response, defined as a decrease of DAS28 score by at least 1.2 after randomization and a resulting DAS28 of 3.2 or lower (RR: 1.59, 95% CI 1.10 to 2.30). ACR 20 and 50 responses were also significantly higher for the infliximab plus MTX arm (ACR 50: 25% vs. 15%; P = 0.0424).

Other combination strategies. One good-quality RCT examined four different treatment strategies over 12 months.100 The BeSt Study (Dutch acronym for Behandel Strategieen, “treatment strategies”) randomized 508 patients with early RA to one of four groups: (1) sequential DMARD, starting with MTX (15 mg/week), (2) stepped-up combination therapy with MTX (15 to 30 mg/week) followed by sulfasalazine (2 g/day), hydroxychloroquine, and prednisone, (3) initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone 60 mg/day to 7.5 mg/day in 7 weeks, and (4) initial combination therapy with MTX 25 to 30 mg/week and infliximab 3 mg/kg every 8 weeks (dose titrated up to 10 mg/kg dependent upon DAS 44>2.4). This design called for frequent changes in treatment strategy; the DAS (i.e., DAS in 44 joints) was calculated every 3 months and if it was greater than 2.4, the therapeutic strategies were adjusted. At 12 months, more patients in group 3 (MTX, sulfasalazine, tapered high-dose prednisone) and in group 4 (MTX with infliximab) reached a DAS of 2.4 or less. Respectively, these proportions were 53 percent, 64 percent, 71 percent, and 74 percent (P=0.004 for group 1 vs. group 3; P=0.001 for group 1 vs. group 4; P=NS for other comparisons). Additionally, the median change in modified Sharp/van der Heijde score was lower for groups 3 and 4 than for groups 1 and 2 (2.0, 2.5, 1.0, and 0.5, respectively; P=0.003 for group 1 vs. group 3; P<0.001 for group 1 vs. group 4; P=0.007 for group 2 vs. group 3; P<0.001 for group 2 vs. group 4). Interestingly, at four years, the remission rates were similar among the groups (DAS<1.6; 50 percent, 41 percent, 38 percent, 42 percent, P=0.40).196

## Key Question 2 Functional Capacity and Quality of Life

This question specifically examined the issue of whether drug therapies differed in their ability to improve functional capacity or quality of life for patients with RA. Findings are organized as for KQ 1. Table 8 (above) lists the abbreviated and full names of all instruments and scales referred to in this section. For the purposes of this report we divided outcomes into functional capacity and health-related quality of life. Functional capacity, functional status, and functional ability are three concepts often used interchangeably to refer to similar capabilities. We use these terms to refer to condition-specific measures, such as the Health Assessment Questionnaire (HAQ), developed to assess function in patients with RA or other rheumatic diseases. Quality of life is a far broader construct comprising physical health, mental or emotional health, a variety of symptom states (e.g., pain, fatigue), and coping, spiritual and other domains. We use the term quality of life when referring to generic measures, such as the Medical Outcomes Study Short Form 36 Health Survey (SF-36), that have been developed to assess health-related quality of life in both healthy persons and those with different conditions. Outcomes for functional capacity and health-related quality of life were often secondary outcomes in these studies.

### Overview

Details of the individual studies are found in the Evidence Tables in Appendix E. Many of the studies in this section are described in more detail in the corresponding KQ 1 sections. For each comparison, tables in Appendix I provide the strength of evidence for functional capacity and quality-of-life outcomes.

Small differences in outcome measures may be statistically significant, yet clinically unimportant. Therefore, in the text below, we consider whether treatment effects reach minimal clinically important differences (MCIDs) for the HAQ and SF-36, the two most commonly reported outcome measures in this section. When we describe “no difference” between two treatments, we use this to indicate that the available evidence did not support a statistically or clinically significant difference between the two treatments. When we describe greater improvements with one treatment compared with another, the difference was both statistically significant and reached the threshold for a MCID. For the HAQ, we considered a difference of ≥0.22 to be a MCID.48 For the SF-36, some have suggested an improvement of 3 to 5 for the MCID.50, 198 Data from clinical trials of rheumatoid arthritis patients suggest slightly lower values, with ranges of 2.6–4.4 for the physical component score (PCS) and 2.2–4.7 for the mental component score (MCS).49 We used these lower ranges to take a conservative approach on what might be a MCID.

Oral disease-modifying antirheumatic drugs (DMARDs) versus oral DMARD. One head-to-head RCT found that patients treated with prednisolone (7.5 mg/d) had greater improvements in functional capacity and quality of life than those treated with budesonide (3 or 9 mg/d) (low strength of evidence). The differences reached thresholds for MCIDs (difference in improvement in mean HAQ: 0.28 to 0.39 units, P<0.01; difference in improvement in SF-36 PCS: 3.7 to 5.4 units, P<0.05).54

The evidence from two RCTs56, 104, 105, 199 does not support a clinically significant difference between leflunomide and methotrexate (MTX) for improvement in functional capacity (low strength of evidence), although some results reached statistically significant differences favoring leflunomide (mean improvement in HAQ-DI at 12 months: −0.45 vs. −0.26, P ≤0.01). Evidence from one study found greater improvement in quality of life with leflunomide than with MTX (SF-36 PCS mean improvement at 12 months of 7.6 vs. 4.6, P<0.01, low strength of evidence).

One RCT107 with a 2-year followup200 provides low strength of evidence that leflunomide yields greater improvements in functional capacity at 24 weeks, 6 months, and 24 months than sulfasalazine (improvement in HAQ at 24 months: −0.65 vs. −0.36, P<0.01).

Evidence from three RCTs57–59 provides moderate strength of evidence that there is no difference in functional capacity between patients treated with sulfasalazine and MTX.

Oral DMARD combinations. Three RCTs compared a combination of two oral DMARDs (sulfasalazine plus MTX) to monotherapy with either drug and provide moderate strength of evidence that there is no statistically significant difference in functional capacity (between-group differences for change in HAQ ranged from 0.03 to 0.25, all P values=NS).57–59

Two RCTs provide moderate strength of evidence that using corticosteroids and one oral DMARD results in greater improvements in functional capacity than using oral DMARD monotherapy (difference in mean change in HAQ −0.28, P=0.02).64, 65 One RCT provides low strength of evidence supporting no difference in quality-of-life outcomes for the same comparison.64

Biologic DMARD versus biologic DMARD. We found one head-to-head RCT and three prospective cohort studies that compared one biologic DMARD with another.66, 68, 70, 71 The head-to-head RCT66 provides low strength of evidence that there is no difference in functional capacity between those treated with abatacept and infliximab; the difference for quality-of-life outcomes was statistically significant, but the difference did not reach the MCID (difference in SF-36 PCS at 1 year 1.93, 95% CI, 0.02 to 3.84).

Data from the three prospective cohort studies do not provide any convincing evidence of a difference between biologic treatments.68, 70, 71 Overall, the strength of evidence (Appendix I) for all comparisons of biologic DMARDs from these studies was low or insufficient and does not suggest a significant difference between etanercept, infliximab, and adalimumab. Some individual studies reported statistically significant differences favoring etanercept over infliximab for functional capacity (one of three studies) or for quality of life (one study), or adalimumab over infliximab for functional capacity and quality of life (one study), but differences did not reach MCIDs or data were not reported. We rated the risk of bias moderate to high for this body of evidence. Because of the methodological limitations of observational studies, findings of these studies should be interpreted cautiously.

Biologic DMARD versus oral DMARD. We found four RCTs76, 77, 86, 173 and one prospective cohort study78 that included comparisons of monotherapy with a biologic DMARD to monotherapy with an oral DMARD. We found no evidence on approved doses of biologic DMARDs other than etanercept, adalimumab, and tocilizumab and no studies comparing biologics with oral DMARDs other than MTX. The evidence from these studies is mixed. Overall, the strength of the evidence is insufficient for biologics as a class compared to oral DMARDs as a class. Two of the RCTs found no differences when comparing either adalimumab76 or etanercept86 with MTX. One RCT77 found that etanercept resulted in better improvement of function and quality of life during the first 12 weeks of treatment, and that a greater percentage of patients treated with etanercept 25 mg or etanercept 10 mg had significant improvements in functional capacity compared with MTX at 24 months (≥0.5 unit improvement in HAQ-DI: 55 percent vs. 43 percent vs. 37 percent, P=0.021 and<0.001, respectively). One RCT found subjects treated with tocilizumab had significantly greater improvements in functional capacity than those treated with MTX, but this trial used a dose of MTX below the dose usually considered therapeutic; thus, it does not provide evidence to determine how tocilizumab compares with MTX as it is generally used in clinical practice.173 All RCTs were funded by the makers of the biologic DMARDs. Population-based, observational evidence from the cohort study indicated that biologic DMARDs as a class resulted in better functional capacity than oral DMARDs as a class in patients with active RA who required a change in therapy.78

Biologic DMARD combinations. One RCT provides low strength of evidence that there is no difference in functional capacity between a combination of etanercept plus abatacept compared with etanercept alone.80 The same RCT provides low strength of evidence that the combination results in statistically significantly greater improvement in physical, but not mental, health-related quality of life (as measured by the SF-36 PCS and MCS, respectively). Of note, the study concluded that abatacept in combination with etanercept should not be used for patients with RA due to limited efficacy findings and safety concerns (more serious adverse events).

For studies comparing a biologic DMARD plus an oral DMARD versus a biologic DMARD, we stratified by population. Based on results of two RCTs, we conclude that biologic DMARDs plus MTX result in greater improvements in functional capacity (difference in improvement in HAQ-DI at 1 year −0.3, P ≤0.002, moderate strength of evidence) and quality of life (low strength of evidence) than biologic DMARDs alone for MTX naïve subjects or those not recently on MTX.76, 86 However, for subjects with active RA despite treatment with the same oral DMARD used in the combination therapy, we conclude that there is no difference in improvements in functional capacity or quality of life (moderate strength of evidence) between a biologic DMARD plus an oral DMARD and biologic DMARD monotherapy.68, 85, 201 For most individual medications in these comparisons, the evidence is limited to a single study. All RCTs were funded by the makers of the biologic DMARDs. No evidence (for biologic DMARD plus oral DMARD vs. biologic DMARD) was available for approved doses of biologic DMARDs other than adalimumab, etanercept, or infliximab and combinations with oral DMARDs other than MTX and sulfasalazine.

Results from seven RCTs and one prospective cohort study suggest greater improvement in functional capacity with combination treatment with a biologic DMARD plus an oral DMARD than with oral DMARD monotherapy (high strength of evidence).68, 76, 82, 85, 86, 89, 90, 92, 136, 138, 145 Five of the RCTs enrolled all or a majority of subjects with early RA;76, 82, 89, 90, 92 Effect sizes for studies finding a clinically important and statistically significant difference between groups ranged from 0.3 to 0.35 for difference in improvement in HAQ-DI and from 9 percent to 38 percent for difference in percentage of subjects with clinically significant improvement in HAQ. All but two of the trials reported results that reached MCIDs; for the two that did not, point estimates were in the direction favoring combination therapy.89, 92 Four of the RCTs also reported quality-of-life outcomes, finding greater improvement in the biologic DMARD plus oral DMARD combination therapy group (moderate strength of evidence).82, 86, 89, 90, 136, 138 The specific comparisons in these studies were a combination regimen of abatacept plus MTX,89 adalimumab plus MTX,76 golimumab plus MTX,92 infliximab plus MTX,68, 82 or etanercept plus MTX68, 86, 90, 136, 138 with MTX monotherapy; and a combination of etanercept plus sulfasalzine with sulfasalazine monotherapy.85, 145

Treatment strategies for early RA. Based on the results of two RCTs (three publications),95, 97, 98, 202 we concluded that combination strategies using corticosteroids plus multiple oral DMARDs result in more rapid improvement in functional capacity (difference in mean change in HAQ at 28 weeks −0.5, P<0.0001) and less work disability (median 12.4 days per patient-observation year vs. 32.2 days, P<0.008) than oral DMARD monotherapy (low strength of evidence for each outcome).

One RCT (the BeSt study) in patients with early RA found that patients treated with initial combination therapy with prednisone (study group 3) or initial combination therapy with infliximab (group 4) had more rapid improvement in functional ability than those treated with sequential DMARD monotherapy (group 1) or with step-up combination therapy (group 2) (statistically significantly greater improvements at 3, 6, 9, and 12 months).100–103, 196 By 2 years, improvement was maintained in all groups, but there were no statistically significant differences between groups (low strength of evidence).

### Detailed Analysis

Oral DMARD versus oral DMARD. Functional capacity and health-related quality-of-life outcomes are presented in Table 28.

Table 28 Oral DMARD versus oral DMARD studies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Corticosteroid vs. Corticosteroid
Kirwan et al., 2004^54^ | RCT 143 12 weeks | Population-based; active RA; mean disease duration 9 years | BUD (3 mg/day) vs. BUD (9 mg/day) vs. PNL (7.5 mg/day) | Improvement in mean HAQ scores: PNL 0.393 units better than BUD 3 mg; P<0.001 PNL 0.276 units better than BUD 9 mg; P<0.01 | Improvement in SF-36 physical component: mean change 5.4 units better for PNL than BUD 3 mg, P<0.01; 3.7 units better than BUD 9 mg, P<0.05 | Fair
Leflunomide vs. MTX
Emery et al., 2000^105^ | RCT 999 1 year with optional second year | Mean disease duration 3.5 to 3.8 years | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Change in HAQ at 12 months, minimal quantitative (data NR) but significant (P<0.05); at 24 months, difference NS | NR | Fair
Strand, et al., 1999^104^ Cohen et al., 2001^56, 199^ | RCT 482 12 months (1-year continuation) | Mean disease duration 6.5 to 7 years | LEF (20 mg/day) vs. MTX (7.5 to 15 mg/week) | Mean improvement in HAQ-DI greater in LEF than MTX at 12 months (−0.45 vs. −0.26; P ≤0.01) and MHAQ (−0.29 vs. −0.15; P<0.01) | Mean improvement in SF-36 physical greater in LEF than MTX at 12 months (7.6 vs. 4.6; P<0.01) but not mental component (1.5 vs. 0.9; P=NS) | Fair
Leflunomide vs. Sulfasalazine
Smolen et al., 1999^107^ Scott et al., 2001^200^ | RCT 358 (146) 24 weeks (12- and 24-month followup) | Mean disease duration 5.7 to 7.6 years | LEF (20 mg/day) vs. SSZ (2 g/day) | Improvement in HAQ scores at 24 weeks greater in LEF than SSZ (−0.50 vs. −0.29; P<0.03) and continued in 2-year followup group at 6 and 24 months (−0.50 vs. −0.29; −0.65 vs. −0.36; both P<0.01) | NR | Fair
Sulfasalazine vs. MTX
Capell et al., 2007^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland; 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | No significant difference between groups in change from baseline HAQ (SSZ: −0.25; MTX: −0.19; P=0.99) | NR | Fair
Dougados et al., 1999^57^ | RCT 209 (146) 52 weeks (5 year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day)+MTX (7.5 to 15 mg/week) | No statistically significant difference in change from baseline HAQ to 1 year (SSZ −0.74 vs. MTX −0.73; P=NS) | NR | Fair
Haagsma et al., 1997^58^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | Difference in change from baseline HAQ to 52 weeks not significant (SSZ −0.32; 95% CI, −0.53 to −0.10, MTX −0.46; 95% CI, −0.68 to −0.25; P=NR) | NR | Fair

BUD = budesonide; combo = combination therapy; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; ETN = etanercept; HAQ = Health Assessment Questionnaire; HAQ-DI = Health Assessment Questionnaire – Disability Index; HCQ = hydroxychloroquine; INF = infliximab; LEF = leflunomide; mg = milligram; MTX = methotrexate; NHS = National Health Service; NR = not reported; NS = not significant; PNL = prednisolone; PRED = prednisone; RCT = randomized controlled trial; SF-36 = Medical Outcomes Test, Short Form 36; SOFI = Signals of Functional Impairment Scale; SSZ = sulfasalazine

Corticosteroids versus corticosteroids. One 12-week head-to-head RCT (N=143) compared budesonide (3 mg/day or 9 mg/day; n=37 and 36, respectively) and prednisolone (7.5 mg/day; n=39).54 Mean disease duration of RA was 9 years. Overall, prednisolone produced greater improvement in functional capacity and health-related quality of life than either dose of budesonide. At 12 weeks, those treated with prednisolone had better improvement in mean HAQ scores than budesonide (Table 28). Those treated with prednisolone also had better improvement in health-related quality of life as measured by the physical subscale of the SF-36. Improvement on the mental subscale of the SF-36 was not statistically significantly different between groups. Of note, functional capacity and health-related quality of life were secondary outcome measures; the study had not been designed to compare differences in either the HAQ or the SF-36.

Leflunomide versus MTX. We found two RCTs104, 105 comparing leflunomide (20 mg/day) with MTX (7.5 mg/week to 15 mg/week)104, 105 and two systematic reviews.55, 106 We describe the individual studies first.

The first trial randomized 482 patients to leflunomide (n=182) or MTX (n=182) over 12 months.104, 199 Patients receiving leflunomide reported greater mean improvement in the HAQ-DI that was statistically significant (Table 28), but the difference between groups did not reach the MCID. Those receiving leflunomide had greater improvement on the SF-36 physical component than those receiving MTX at 12 months that was statistically significant and reached the MCID. At 12 months, the two groups did not differ significantly in improvement in the SF-36 mental summary score or in work productivity. A 2-year followup of 235 patients (leflunomide, n=98; MTX, n=101) found greater mean improvement in the HAQ-DI (−0.60 vs. −0.37; P=0.005) and MHAQ scores (−0.43 vs. −0.28; P ≤0.05) with leflunomide than with MTX.56 The groups did not differ significantly in mean improvement in the SF-36 physical or mental summary scores at 24 months. These 2-year results are limited by the high attrition rate (45 percent) from the initial study.

A 1-year multinational RCT (N=999) comparing leflunomide and MTX with an optional second year enrolled RA subjects with a mean disease duration of 3.5 years to 3.8 years.105 At 12 months, a statistically significant but minimal quantitative difference (number not reported, shown in bar graph)105 for change in the HAQ (P<0.05) was reported between the two groups; at 24 months, however, the groups did not differ significantly.

One systematic review with meta-analysis included 33 trials comparing leflunomide, either as monotherapy or combined with another medication, with placebo or other oral DMARDs in patients with active RA.55 MHAQ scores improved significantly more in patients treated with leflunomide than in those treated with MTX at 6, 12, and 24 months. The leflunomide group and the MTX group did not differ in improvement on the HAQ index at either 12 months or 24 months. Work productivity did not improve significantly in the leflunomide group when compared with the MTX group (weighted mean difference [WMD], −2.3 points; 95% CI, −6.37 to 1.77). When comparing leflunomide with MTX, changes in SF-36 scores showed better improvement in the physical summary score with leflunomide (WMD, −3.0 points; 95% CI, −5.41 to −0.59) but not the mental summary score (WMD, −0.6 points; 95% CI, −3.01 to 1.81). The only study that contributed to this outcome (SF-36 physical summary score) was the RCT (N=482) described above in this section.104, 199 This systematic review was limited by the number of studies included for meta-analysis; only one study was available for each individual functional capacity or quality-of-life outcome measure except for change in HAQ scores.

The second systematic review aimed to assess the efficacy and safety of oral DMARDs in adults with RA to inform the European League Against Rheumatism (EULAR) recommendations.106 The review included a total of 97 RCTs (14,159 patients) covering a variety of comparisons. The results were not significantly different for leflunomide and MTX for pain (four studies, 1,475 patients, SRM −0.04, 95% CI, −0.33 to 0.26) or for disability (four studies, 1,465 patients, SRM −0.09, 95% CI, −0.30 to 0.11). The mean dose of MTX, reported in three studies, was 12.5 mg/week. MTX could be increased to ≥15 mg/week in all studies, but dosing was not as high as currently recommended in most studies.

Leflunomide versus sulfasalazine. One RCT107 with a 2-year followup200 compared leflunomide (20 mg/day) with sulfasalazine (2 g/day) and placebo; one systematic review included a meta-analysis of leflunomide.55 The RCT was a multinational, multicenter study of 358 patients (leflunomide, n=133; sulfasalazine, n=133; placebo, n=92).107 Baseline HAQ scores were similar for all groups. The leflunomide group had significantly greater improvement in HAQ scores at 24 weeks, 6 months, and 24 months compared with the sulfasalzine group (Table 28).200 Subjects completing the first 6 months were given the option to continue. Those in the placebo group were switched to sulfasalazine if they continued in the study. The study was limited by only including 146 (leflunomide, n=60; sulfasalazine, n=60; placebo then sulfasalzine, n=26) of the original 358 subjects and having a 21 percent attrition rate (116 completed the study).

One systematic review with meta-analysis compared leflunomide (10 to 20 mg/day) with other DMARDs in patients with active RA.55 For the comparison of leflunomide and sulfasalazine, the meta-analysis included one study (N=229) with changes in HAQ at 6, 12, and 24 months.200 At 6 and 24 months, the leflunomide group had greater improvements in the HAQ-DI than the sulfasalazine group (WMD −0.25 point; 95% CI, −0.42 to −0.08; WMD −0.29 point; 95% CI, −0.57 to −0.01, respectively). This evidence is limited because the meta-analysis included only one study for this outcome; they did not pool data from multiple studies.

Sulfasalazine versus MTX. Three RCTs57–59 and one systematic review106 compared sulfasalazine with MTX. Their findings are consistent and do not support a difference in functional capacity between the groups (Table 28). These included a multinational 52-week RCT of 209 DMARD-naive subjects,57 a 52-week RCT of 105 DMARD-naive subjects in academic and peripheral clinics in the Netherlands,58 and an 18-month RCT of 165 subjects at eight sites in Scotland.59

The systematic review aimed to assess the efficacy and safety of oral DMARDs to inform the EULAR recommendations and included a variety of comparisons.106 The results were not significantly different for sulfasalazine versus MTX for disability (two studies, 208 patients, SRM 0.62, 95% CI, −0.86 to 2.10).

Oral DMARD combinations: MTX plus sulfasalazine versus monotherapy with MTX or sulfasalazine. Three RCTs (four publications) compared MTX plus sulfasalazine to either drug alone.57–59, 111 Two of the RCTs included patients with disease duration of less than 1 year;57, 58 the third included patients with RA of up to 10 years.59 Findings of these studies do not support a difference in functional capacity between combination therapy and either monotherapy. Study data are presented in Table 29.

Table 29 Oral DMARD combination studies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Sulfasalazine+MTX versus Sulfasalazine or MTX Monotherapy
Capell et al., 2007^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland; 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day)+MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | Change from baseline HAQ: no significant difference between groups (SSZ+MTX −0.50 vs. SSZ −0.25; P=0.51), (SSZ+MTX −0.50 vs. MTX −0.19; P=0.57) | NR | Fair
Dougados et al., 1999^57^ Maillefert et al., 2003^111^ | RCT 209 (146) 52 weeks (5-year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) plus MTX (7.5 to 15 mg/week) | No statistically significant difference in change from baseline HAQ to 1 year (SSZ+MTX −0.70 vs. SSZ −0.74 vs. MTX −0.73; P= NS) or in mean HAQ at 5 years (combination 0.6 vs. either single therapy 0.6; P=0.9) | NR | Fair
Haagsma et al., 1997^58^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day)+MTX (7.5 to 15 mg/week) | Difference in change from baseline HAQ to 52 weeks NS (SSZ+MTX −0.51: 95% CI, −0.76 to −0.26 vs. SSZ −0.32: 95% CI, −0.53 to −0.10 vs. MTX −0.46: 95% CI, −0.68 to −0.25; P=NR) | NR | Fair
Oral DMARD+Corticosteroid vs. Oral DMARD
*Choy et al., 2008^64^ | RCT 467 2 years | England/Wales, Multicenter: early RA; mean disease duration 2.7 to 5.1 months | MTX (≤15 mg/week)+PNL (60 mg/day stepped down and stopped at 34 weeks) vs. MTX | Difference in mean change in HAQ: −0.28 with additional PNL compared to MTX alone (P=0.02) | Mean change in SF-36 PCS and MCS: No difference between groups (P=0.22 and NR, respectively) | Good
Svensson et al., 2005^65^ | Open-label trial 250 2 years | Population-based; active RA; duration 1 year or less | DMARD (SSZ or MTX, dosages NR)+PNL (7.5 mg/day) vs. DMARD | Greater improvement in DMARD+PNL group than DMARD-only group (from mean HAQ of 1.0 to 0.4 at 1 year and 0.5 at 2 years vs. 1.0, 0.6, and 0.7; P=NR) Mean SOFI index decreased from 8 at baseline to 4 at 1 year and 4 at 2 years vs. 9, 6, and 7 respectively; P=NR) | NR | Fair

* New study added since last review.

CI = confidence interval; DAS = disease activity score; DMARD = disease modifying antirheumatic drug; g = gram; HAQ = Health Assessment Questionnaire; mg = milligram; MTX = methotrexate; NHS = National Health Service; NR = not reported; NS = not significant; PCS = physical component score; PNL = prednisolone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SF-36 = Medical Outcomes Test, Short Form 36; SOFI = Signals of Functional Impairment Scale; SSZ = sulfasalazine; vs. = versus; yrs = years

A multinational RCT of 209 DMARD-naive subjects compared sulfasalazine (n=68), MTX (n=69), and the sulfasalazine-MTX combination (n=68) for 52 weeks. No statistically significant difference in changes in HAQ scores occurred from baseline to 1 year.57 A long-term followup comparing the combination therapy to monotherapy (combining the two monotherapy groups) did not find a significant difference in mean HAQ scores at 5 years (combination 0.6; monotherapy 0.6; P=0.9).111

A 52-week RCT of 105 DMARD-naive subjects in Dutch academic and peripheral clinics reported a change in HAQ scores between baseline and 52 weeks of −0.51 (95% CI, −0.76 to −0.26) for the MTX-sulfasalazine combination therapy, a change of −0.32 (95% CI, −0.53 to −0.10; P=NR) for sulfasalazine, and a change of −0.46 (95% CI, −0.68 to −0.25; P=NR) for MTX.58 The HAQ was a secondary outcome in this study; the authors did not attempt to explain these results or compare the values, but the differences between groups did not reach thresholds for MCIDs and the 95% CIs overlap between all groups.

The third study was an 18-month RCT of 165 subjects at eight sites in Scotland. The investigators found no significant difference between the combination therapy and the monotherapy groups in changes from baseline HAQ scores.59

Oral DMARD plus corticosteroid versus oral DMARD. We found two RCTs; both found that corticosteroids and one oral DMARD results in greater improvements in functional capacity than using oral DMARD monotherapy (Table 29).64, 65 The first was a 2-year RCT (N=467) comparing MTX plus prednisolone (60 mg/day stepped down and stopped at 34 weeks) with MTX monotherapy in subjects with early RA.64 The study reported greater improvements in functional capacity for subjects treated with MTX plus prednisolone than subjects treated with MTX alone, but found no difference in quality of life between groups.

One open-label RCT compared oral DMARD use with and without prednisolone in patients with active RA for 1 year or less.65 This 2-year study compared prednisolone (7.5 mg/day) added to an initial DMARD (chosen by the treating physician) with an oral DMARD only in patients with early RA. The authors reported greater improvement in functional capacity for the prednisolone group than the nonprednisolone group. The DMARD plus prednisolone group also had greater improvement in the mean Signals of Functional Impairment (SOFI) index. Scores on the HAQ and the SOFI index were not statistically compared for the two groups; the clinical relevance of these results is uncertain. In addition, the results should be interpreted cautiously, given the open-label design and potential for bias.

Biologic DMARD versus biologic DMARD. We identified one head-to-head RCT and three prospective cohort studies meeting our inclusion criteria (Table 30).66, 68, 70, 71 Three of these included comparisons of etanercept with infliximab;68, 70, 71 one study compared each of the following: adalimumab versus etanercept,71 abatacept versus infliximab,66 and adalimumab versus infliximab.71 Mean disease durations ranged from 6 years to 9.9 years; the proportion of patients with early RA in these studies remains unclear. One study was conducted in the United States;68 the others were carried out in the Netherlands,71 Spain,70 or were multinational.66

Table 30 Biologic DMARD versus biologic DMARD studies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Abatacept vs. Infliximab
*Schiff et al., 2008^66^ ATTEST | RCT 431 1 year | Multinational; Active RA with inadequate response to MTX | ABA (~10 mg/kg every 4 weeks) vs. INF (3 mg/kg every 8 weeks) Study also had a third arm (placebo) | Percentage of patients with improvement in HAQ-DI at 1 year: 57.7% vs. 52.7%; estimate of difference (95% CI, 5.0 (−6.5 to 16.5) | SF-36 PCS: between group difference at 1 year favoring ABA of 1.93, 95% CI, 0.02 to 3.84 SF-36 MCS: difference of 1.92, 95% CI, −0.30 to 4.15 | Fair
Etanercept vs. Infliximab
*Fernandez-Nebro et al., 2007^70^ | Prospective cohort 161 6 years | Tertiary care center, Spain; Anti-TNF naïve patients; mean disease duration 9.5 to 9.9 years | ETN vs. INF (dosages NR) | Mean change in HAQ at 6 months: −0.46 vs. −0.32; P=0.218 | NR | Fair
*Kievit et al., 2008^71^ DREAM register | Prospective cohort study 707 1 year | Population-based, Netherlands, Anti-TNF naïve patients, failed at least 2 DMARDs; mean disease duration 6 to 7.7 years | ETN vs. INF (dosages NR) | Mean change in HAQ at 12 months: −0.35 vs. −0.26; P=NS | SF-36 PCS: ADA and ETN patients had greater improvement than INF; P=0.001 (data NR, in Figure only) | Fair
Weaver et al., 2006^68^ | Prospective cohort study 1,371 12 months | Population-based, US; patients with active RA who required change in therapy; mean disease duration 9.3 years | ETN (25 mg twice weekly) vs. INF (3.8 mg/kg or higher) | Mean percentage improvements in HAQ at 12 months: 17% vs. 1%; P=NR | NR | Fair
Adalimumab vs. Etanercept
*Kievit et al., 2008^71^ DREAM register | Prospective cohort study 707 1 year | Population-based, Netherlands, Anti-TNF naïve patients, failed at least 2 DMARDs; mean disease duration 6 to 7.7 years | ADA vs. ETN (dosages NR) | Mean change in HAQ at 12 months: −0.42 vs. −0.35; P=NS | SF-36 PCS: ADA and ETN patients had greater improvement than INF; P=0.001 (data NR, in Figure only) | Fair
Adalimumab vs. Infliximab
*Kievit et al., 2008^71^ DREAM register | Prospective cohort study 707 1 year | Population-based, Netherlands, Anti-TNF naïve patients, failed at least 2 DMARDs; mean disease duration 6 to 7.7 years | ADA vs. INF (dosages NR) | Mean change in HAQ at 12 months: −0.42 vs. −0.26; P<0.05) | SF-36 PCS: ADA and ETN patients had greater improvement than INF; P=0.001 (data NR, in Figure only) | Fair

* New study added since last review.

ADA = adalimumab; CI = confidence interval; DMARD = disease modifying antirheumatic drug; ETN = etanercept; HAQ = Health Assessment Questionnaire; HAQ-DI = Health Assessment Questionnaire – Disability Index; INF = infliximab; MCS = mental component score; mg/kg = milligram/killigram; NR = not reported; NS = not significant; PCS = physical component score; RA = rheumatoid arthritis; SF-36 = Medical Outcomes Test, Short Form 36; TNF = tumor necrosis factor; US = United States; vs. = versus

Abatacept versus infliximab. One head-to-head multinational RCT (N=431) conducted in subjects with active RA who had an inadequate response to MTX did not find a difference in functional capacity between those treated with abatacept and infliximab. It found greater improvement in health-related quality of life for those treated with abatacept that reached statistical significance, but did not reach the threshold for a MCID (SF-36 PCS: difference of 1.93 at 1 year, 95% CI, 0.02 to 3.84).66

Etanercept versus infliximab. Two of the three cohort studies comparing etanercept with infliximab reported no difference in functional capacity outcomes; one reported greater improvement with etanercept.68 Only one of the three studies reported a quality-of-life outcome, finding greater improvement in the SF-36 PCS with etanercept than with infliximab.71

The first cohort study (N=161) was conducted in anti-tumor necrosis factor (TNF) naïve patients and found no difference in functional capacity between etanercept than infliximab.70 The second cohort study (N=707) was conducted in anti-TNF naïve patients that had failed at least two DMARDs and also found no difference in functional capacity between etanercept than infliximab, but reported statistically significantly greater improvement in health-related quality of life for those treated with etanercept, but the actual data were not reported.71

The third cohort study comparing etanercept with infliximab was based on the RADIUS (Rheumatoid Arthritis DMARD Intervention and Utilization Study) program. RADIUS was a primary care-based U.S. study that enrolled patients who were initiating any new DMARD at study entry.68 Mean disease duration was 9.3 years, indicating that most patients suffered from advanced RA. The percentage of patients with early RA was not reported. Patients treated with etanercept had a greater mean percentage improvement on the HAQ at 12 months than patients treated with infliximab (17 percent vs. 1 percent; P=NR). Among patients older than 65 years, after adjusting for baseline covariates, the authors reported that the etanercept-treated patients had a greater mean percentage improvement in the HAQ at 12 months than infliximab-treated patients (22 percent vs. 4 percent; P=NR). However, the authors did not describe direct statistical comparisons between etanercept and infliximab. The study was designed to compare combinations of etanercept or infliximab with MTX to monotherapy with etanercept, infliximab, or MTX.

Adalimumab versus etanercept. One cohort study (N=707) conducted in anti-TNF naïve patients that had failed at least two DMARDs reported no difference in functional capacity or health-related quality of life between adalimumab and etanercept.71

Adalimumab versus infliximab. One cohort study (N=707) conducted in anti-TNF naïve patients that had failed at least two DMARDs reported greater improvement in functional capacity that reached statistical significance but did not reach the MCID (mean change in HAQ at 12 months: −0.42 vs. −0.26, P<0.05). It also reported greater improvement in health-related quality of life (data NR, P=0.001) for subjects treated with adalimumab than for those treated with infliximab.71

Placebo-controlled studies. Multiple placebo-controlled RCTs and systematic reviews of placebo-controlled trials provide evidence on the efficacy of abatacept,66, 113, 116, 203–207 adalimumab,119–125 anakinra,75, 128, 129, 131–134 etanercept,86, 136–145 infliximab,66, 135, 148–156 rituximab,84, 158–161, 208 certolizumab pegol,164, 165, 168, 209 golimumab,166, 169, 170, 210 and tocilizumab.164, 172, 174–178 Most of these studies were conducted in patients who had failed oral DMARD treatment.

Biologic DMARD versus oral DMARD. We found four RCTs and one prospective cohort study that included comparisons of approved doses of biologic DMARD monotherapy with oral DMARD monotherapy (Table 31). The RCTs compared etanercept with MTX,77, 86 adalimumab with MTX,76 and tocilizumab with MTX;173 the cohort study assessed differences in class effects.78 No head-to-head evidence exists for the other biologic DMARDs or for oral DMARDs other than MTX (although anakinra and infliximab were included in the prospective cohort study comparing biologics as a class to oral DMARDs as a class).

Table 31 Biologic DMARD versus oral DMARD studies: functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Adalimumab vs. MTX
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (<3 years) | ADA (40 mg biweekly) vs. MTX (20 mg/week) | At 1 year, ADA and MTX monotherapy groups had similar improvement in HAQ-DI (−0.8 vs. −0.8; P=NR). Improvements remained similar after 2 years | NR | Fair
Etanercept vs. MTX
Bathon et al., 2000;^77^ Genovese et al., 2002;^188^ Genovese et al., 2005;^189^ Kosinski et al., 2002^211^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Early, aggressive RA; MTX-naive; mean disease duration 11.7 months | ETN (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | Better improvement in HAQ early in treatment (first 12 weeks) for ETN than MTX (P<0.0001). No significant difference in HAQ scores during weeks 16 to 52 Significantly greater percentage of patients with at least a 0.5 unit improvement in HAQ-DI at 24 months for ETN 25 mg than for either ETN 10 mg or MTX (55% vs. 43% vs. 37%; P=0.021 and P<0.001, respectively) | Better improvement in SF-36 physical summary and SF-36 arthritis-specific health index for ETN group than the MTX group during first 12 weeks (P<0.0001) No significant difference in weeks 16 to 52 | Fair
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006^138^ TEMPO study | RCT 686(503 for 2-year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 2 DMARDs; mean disease duration 6.6 years | ETN (25 mg twice weekly) vs. MTX (20 mg/week) | Similar improvement in mean HAQ scores for MTX and ETN (scores fell from 1.7 to 1.1 and 1.7 to 1.0; P=0.3751) | NR | Good
Tocilizumab vs. MTX
*Nishimoto et al., 2009^173^ SATORI | RCT 127 24 weeks | Active RA with inadequate response to MTX | TCZ (8 mg every 4 weeks) +placebo vs. MTX (8 mg/week)+placebo | Percentage of patients with a decrease of at least 0.22 units in MHAQ at last observation: 67% vs. 34% (P<0.001) | NR | Fair
Biologic Class vs. Oral DMARD Class
Listing et al., 2006^78^ | Prospective cohort study 1,083 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 9.6 years | Biologics as a class (ADA, ANA, ETN, INF; dose NR) vs. DMARDs as a class (dose NR) | Severely disabled patients (≤50% of full function) in biologic group more likely to achieve physical independence (≥67% of full function, Hanover Functional Status Questionnaire) than DMARD group (OR, 3.88; 95% CI, 1.7 to 8.8) Functional remission (≥83% of full function) more often achieved in biologic group than in DMARD group (OR, 2.18; 95% CI, 1.04 to 4.6) | NR | Fair

* New study added since last review.

ADA = adalimumab; ANA = anakinra; CI = confidence interval; DMARD = disease modifying antirheumatic drug; ERA = early rheumatoid arthritis; ETN = etanercept; GOL = Golimumab; HAQ = Health Assessment Questionnaire; HAQ-DI = Health Assessment Questionnaire – Disability Index; INF = infliximab; mg = milligram; MHAQ = modified Health Assessment Questionnaire; MTX = methotrexate; NR = not reported; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; SF-36 = Medical Outcomes Test, Short Form 36; TCZ = tocilizumab

Adalimumab versus MTX. The only data come from the PREMIER study, a multinational 2-year RCT of 799 patients with early, aggressive RA who had not previously received MTX.76 Two treatment arms of this 2-year study were adalimumab monotherapy and MTX monotherapy. After 1 year, the adalimumab and MTX monotherapy groups had no difference in improvements in functional status measured using the HAQ-DI. Improvements remained similar after 2 years (−0.9 vs. −0.9; P=NR). After 2 years, 19 percent of patients in both monotherapy groups had HAQ-DI scores of zero.

Etanercept versus MTX. Two trials (seven publications) compared etanercept with MTX over 52 weeks.77, 86, 136, 138, 188, 189, 211 ERA was a 52-week multicenter RCT of 632 patients with early RA in the United States that compared etanercept with MTX.77, 188, 189, 211 The treatment groups were similar at baseline. Most patients were female, white, and rheumatoid factor positive and had had RA for fewer than 18 months. Patients treated with etanercept had better early responses for functional status and health-related quality of life. Compared with patients treated with MTX, patients treated with etanercept showed better improvement early in treatment (during the first 12 weeks) on the HAQ (P<0.0001), the SF-36 physical subscale (P<0.0001), and the SF-36 arthritis-specific health index (ASHI) (P<0.0001). From weeks 16 to 52, these measures did not differ significantly; both groups showed similar improvement. These results may be attributed to an earlier response to etanercept than to MTX and the fact that patients were increased to the maximum MTX dose over 2 months. After 12 months, approximately 55 percent of patients in both the MTX and the 25- mg etanercept groups had at least a 0.5 unit improvement in the HAQ-DI. At 24 months, 55 percent of the 25- mg etanercept group had this level of improvement, as did 37 percent of the MTX group (P<0.001) and 43 percent of the 10- mg etanercept group (P=0.021).

TEMPO was a 52-week RCT of RA patients who had failed previous DMARD therapy that compared etanercept with MTX and with combination therapy with both drugs.86 Baseline HAQ scores were similar for all three groups. At 52 weeks, improvement of functional status did not differ significantly between the MTX group and the etanercept group.

Golimumab versus MTX. Two RCTs compared unapproved doses of golimumab (100 mg) with MTX.92, 169 These two studies are referenced in other sections of this report for study arms using approved doses (e.g., golimumab 50 mg plus MTX compared with MTX section), but we do not include them in Table 31, the overview, our conclusions, or in strength of evidence tables due to the use of unapproved doses in the golimumab plus placebo arms, because it is difficult to draw conclusions about the comparative effectiveness of the approved use of golimumab (50 mg every 4 weeks) with MTX.

The GO-FORWARD study was a phase III, multicenter trial that randomized subjects (assigned in a 3:3:2:2 ratio) to receive placebo injections plus MTX, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 50 mg injections plus MTX capsules.169 The trial found no difference in the improvement in functional capacity (change in median HAQ-DI) between those treated with golimumab 100 mg and those treated with MTX at 24 weeks.

The GO-BEFORE study was a phase III, multicenter trial that randomized subjects to subcutaneous placebo injections plus MTX capsules, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 100 mg injections plus MTX capsules.92 The trial reported a median percent improvement in HAQ-DI of 36.95 for the MTX group compared with 31.05 for the golimumab 100 mg plus placebo group (P=NR).

Tocilizumab versus MTX. The only data come from the Study of Active controlled TOcilizumab monotherapy for Rheumatoid arthritis patients with an Inadequate response to methotrexate (SATORI), a 24-week RCT of 127 patients with active RA and an inadequate response to MTX conducted at 25 sites in Japan.173 Subjects were randomized to MTX monotherapy (8 mg/week) plus tocilizumab placebo or to tocilizumab plus MTX placebo. After 24 weeks, those treated with tocilizumab had significantly greater improvements in the percentage of subjects achieving at least a 0.22 unit improvement in MHAQ scores, which was considered significant clinical improvement and the MCID. Of note, the dose of MTX used in this study is below the dose usually considered therapeutic. Multinational evidence-based recommendations suggest starting MTX at 10–15 mg/week, with escalation of 5 mg every 2–4 weeks up to 20–30 mg/week.191 Thus, this study does not provide evidence that is relevant to determine how tocilizumab compares with MTX as it is generally used in clinical practice.

Biologic DMARD as a class versus oral DMARD as a class. One prospective cohort study examined differences in clinical and functional remission between biologics as a class (adalimumab, anakinra, etanercept, infliximab; n=818) and oral DMARDs as a class (n=265) in patients who had failed two previous oral or biologic DMARD treatments.78 This study was population-based and part of the RABBIT study, a German long-term, prospective cohort study of RA patients who required a change in therapy in daily rheumatologic care. Patients on biologics were younger and had a significantly more active disease at baseline. Severely disabled patients receiving biologic therapies were more likely to achieve physical independence than controls on conventional oral DMARD therapy (Table 31). Functional remission was more often achieved in patients receiving biologics than in controls.

Biologic combinations: biologic DMARD plus biologic DMARD versus biologic DMARD. We found a single 1-year RCT (N=121) followed by a 2-year open label long-term extension (N=80) that reported no significant differences in functional capacity for patients treated with abatacept combined with etanercept compared with etanercept only (Table 32).80 The study reported greater improvement in quality of life measured by the physical component summary of the SF-36 (data NR), but not the mental component summary. Although the initial RCT dosing of abatacept was lower than currently used clinically, the frequency of serious adverse events was higher in the abatacept combined with etanercept treated patients than the etanercept-only treated patients. The study concluded that abatacept in combination with etanercept should not be used for patients with RA due to limited efficacy findings and safety concerns (more abatacept and etanercept-treated patients experienced serious adverse events).

Table 32 Biologic DMARD plus biologic DMARD versus biologic DMARD studies: functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Etanercept+Abatacept vs. Etanercept
*Weinblatt et al., 2006^80^ | RCT 121 1-year double-blind phase 2-year long term-extension | Patients with active RA despite ETN; mean disease duration 12.8 to 13 years | ETN (25 mg twice weekly)+ABA 2g/kg increased to 10 mg/kg after 1 year) vs. ETN (25 mg twice weekly) | Mean change in mHAQ at 12 months: −0.3 vs. −0.2; P=NR Mean change in mHAQ from 1 year to 2 years: −0.1 vs. 0; P=NR) | Greater improvement in the SF-36 PCS for ETN+ABA group (data NR) Mean change in SF-36 MCS: 3.9 vs.1.06; P=NS | Fair

* New studies since last review.

ABA = abatacept; ETN = etanercept; g/kg = gram/killigram; mg = milligram; mg/kg = milligram/killigram; mHAQ = modified health assessment questionnaire; NR = not reported; NS = not significant; PCS = physical component score; RA = rheumatoid arthritis; RCT = randomized controlled trial; SF-36 = Medical Outcomes Test, Short Form 36; vs. = versus; yr = year

Biologic combinations: biologic DMARD plus oral DMARD versus biologic DMARD. We found five studies, four RCTs76, 85, 86, 201 and one prospective cohort study,68 comparing the combination of a biologic DMARD plus an oral DMARD with approved doses of biologic DMARD monotherapy (Table 33). The majority of these studies compared a combination of a biologic DMARD and MTX with monotherapy of the same biologic DMARD.68, 76, 86, 201 One trial used sulfasalazine as a oral DMARD in combination with a biologic DMARD.85 Three of the studies found no difference between combination therapy and biologic DMARD monotherapy; two reported greater improvement with combination therapy. The two RCTs finding that combination therapy resulted in greater improvement in functional capacity or quality of life enrolled subjects that were MTX-naïve76 or had not been on MTX for at least 6 months prior to enrollment.86 The studies finding no difference enrolled subjects with active RA despite treatment with the same oral DMARD that was used in the combination therapy arm of the trial.

Table 33 Biologic DMARD plus oral DMARD versus biologic DMARD studies: functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Adalimumab +MTX vs. Adalimumab
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (<3 years) | ADA (40 mg biweekly)+MTX (20 mg/week) vs. ADA (40 mg biweekly) | At 1 year, ADA+MTX group had greater improvements in HAQ-DI than ADA alone (mean, −1.1 units vs. −0.8; P=0.002). After 2 years, there was no difference (−1.0 vs. −0.9; P=0.058) After 2 years, more ADA+MTX patients had improvement of ≥0.22 in HAQ-DI than ADA patients (72% vs. 58%; P<0.05); had a greater percentage with HAQ-DI scores of 0 (33% vs. 19%; P<0.001) | NR | Fair
Etanercept+Oral DMARD vs. Etanercept
Combe et al., 2006^85^ *Combe et al., 2009^145^ | RCT 260 24 weeks 2 years | Europe multicenter; active RA despite SSZ treatment; mean disease duration 6.6 years | ETN (25 mg twice weekly)+SSZ (2, 2.5, or 3g/day) vs. ETN (25 mg twice weekly) | Mean percentage improvements in HAQ were similar for ETN+SSZ and ETN alone at 24 weeks (40.2% vs. 35.3%, P=NS). At 2 years, clinically significant improvement in HAQ was seen for 78% vs. 76% (P=NS) | Mean percentage improvements in EuroQOL VAS were similar for ETN+SSZ and ETN alone at 24 weeks (67.6% vs. 64.6%; P=NS) | Fair
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006^137, 138^ TEMPO study | RCT 686(503 for 2-year results) 52 weeks (2 years, 100 weeks) | Europe multinational, multicenter; active RA; had failed at least 2 DMARDs; mean disease duration 6.6 years | ETN (25 mg twice weekly)+MTX (20 mg/week) vs. ETN (25 mg twice weekly) | At 52 weeks ETN+MTX was more likely to attain HAQ-DI scores similar to population norms (<0.5) than ETN alone (P<0.05). Combination group had greater improvement in mean HAQ scores (mean fall from 1.8 to 0.8 vs. 1.7 to 1.0; P<0.001; mean improvement from baseline HAQ 1.0 vs. 0.7; P<0.01) | ETN+MTX patients reported better quality of life than ETN-only patients (mean EQ-5D VAS 72.7 vs. 66.8; P<0.05) | Good
*Van Riel et al., 2008^201^ ADORE trial | Open-label RCT 315 16 weeks | Inadequate control of disease with MTX; mean disease duration 10.9 years | ETN (25 mg twice weekly)+MTX (>12.5 mg/week) vs. ETN (25 mg twice weekly) | Mean change in HAQ DI at 16 weeks: −0.59 vs. −0.59; difference between groups 0.029 (95% CI, −0.115 to 0.172) | Mean change in EQ-5D VAS: 21.00 vs. 19.76; difference between groups −2.593 (95% CI, −7.667 to −2.482) | Fair
Weaver et al., 2006^68^ | Prospective cohort study 3,034 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETN (25 mg twice weekly)+MTX (dose NR) vs. ETN (25 mg twice weekly) | Patients treated with ETN+MTX had similar improvements in functional capacity to those treated with ETN only (mean percentage improvements in HAQ at 12 months: 17% vs. 17%; P=NR) | NR | Fair

* New study added since last review.

ADA = adalimumab; CI = confidence interval; EQ-5D VAS = European Quality of Life-5 Dimensions Visual Analogue Scale; EuroQOL VAS = European Quality of Life Health Status Visual Analogue Scale; ETN = etanercept; HAQ = Health Assessment Questionnaire; HAQ-DI = Health Assessment Questionnaire – Disability Index; MTX = methotrexate; NR = not reported; NS = not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; vs. = versus

Adalimumab plus MTX versus adalimumab. The PREMIER study was conducted in MTX-naive patients with early (<3 years), aggressive RA.76 This 2-year multinational study randomized 799 patients to a combination of adalimumab and MTX, adalimumab monotherapy, or MTX monotherapy. After 1 year, the combination group had greater improvements in HAQ-DI scores than the adalimumab group. After 2 years, the combination group and the adalimumab-only group did not differ significantly for improvements in the HAQ-DI. After 2 years, more patients in the combination group had achieved improvement of ≥0.22 (the clinically relevant threshold) in HAQ-DI than the adalimumab group. In addition, 33 percent of patients in the combination group and 19 percent of those in the adalimumab group had HAQ-DI scores of zero (P<0.001).

Etanercept plus MTX versus etanercept. Two RCTs (four publications)86, 136, 138, 201 and one prospective cohort study68 assessed differences in efficacy between a combination of etanercept and MTX and etanercept monotherapy. One RCT showed greater improvements for functional capacity and quality of life for combination therapy; one RCT found no difference; the cohort study found no difference. The study showing greater improvements for combination therapy enrolled subjects who had not taken MTX during the prior 6 months. The studies that found no difference enrolled subjects with active RA despite current MTX use.

The first RCT, the 52-week TEMPO trial, involved 686 patients with active RA who had failed previous DMARD therapy.86, 136–138 Subjects were included only if they had not taken MTX for the 6 months prior to enrollment. Baseline HAQ scores were similar. At 52 weeks, patients in the combination group were significantly more likely to attain HAQ-DI scores similar to population norms (<0.5) than patients in the monotherapy group (P<0.05) and had greater improvement in HAQ scores. In addition, those receiving combination therapy achieved better quality-of-life scores than etanercept monotherapy.136 Results of year 2 of the TEMPO trial confirmed the long-term sustainability of these findings.138 Improvement in disability (based on HAQ) remained significantly better in the combination group than in the etanercept monotherapy group (P<0.01). However, attrition was 39 percent for year 2, which could compromise the validity of the long-term results.

The second RCT, the ADORE trial,201 randomized subjects (N=315) with active RA despite MTX treatment to 16 weeks of etanercept plus MTX or to etanercept monotherapy. The study reported no difference in change in functional capacity or quality of life between groups. Unlike the TEMPO trial described above, that enrolled subjects who had not been on MTX for the prior 6 months, the ADORE trial enrolled patients with active RA despite MTX use.

The prospective cohort study was based on the RADIUS program68 (see Biologic DMARD versus biologic DMARD above). Mean percentage improvements in HAQ at 12 months did not differ between patients treated with etanercept plus MTX and those treated with etanercept monotherapy.

Etanercept plus sulfasalazine versus etanercept. A 24-week multicenter RCT in Europe assessed the comparative efficacy of etanercept monotherapy, sulfasalazine monotherapy, and an etanercept-sulfasalazine combination in patients with active RA who had failed previous sulfasalazine treatment.85 Two-year outcomes were also published for the trial.145 Results on patient-reported measures of functional status and quality of life (HAQ, EuroQOL VAS) were similar at baseline for patients in the two groups. The mean percentage improvement for HAQ was similar for the combination group and the etanercept group (P=NS). The mean percentage improvement for health-related quality of life measured by the EuroQOL VAS was also similar. After 2 years, a clinically significant improvement in functional capacity (HAQ improvement of ≥0.22) was similar for both groups (Table 34).145

Table 34 Biologic DMARD plus oral DMARD versus oral DMARD studies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Abatacept+MTX vs. MTX
*Westhovens et al., 2009^89^ | RCT 509 2 years | Early RA, MTX-naïve or pervious MTX ≤10 mg/week for 3 weeks or less, with none for prior 3 months | Abatacept (~10 mg/kg)+MTX vs. MTX | Adjusted mean change from baseline in HAQ-DI: −0.96 vs. −0.76, between group difference −0.20, 95% CI −0.31 to −0.08 | Adjusted mean change from baseline in SF-36 PCS: 11.68 vs. 9.18, P=0.005 For SF-36 MCS: 8.15 vs. 6.34, P=0.046 | Good
Adalimumab+MTX vs. MTX
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration <1 year | ADA (40 mg biweekly)+MTX (20 mg/week) vs. MTX (20 mg/week) | At 1 year, mean improvement in HAQ-DI: −1.1 units vs. −0.8; P<0.001. After 2 years: −1.0 vs. −0.9; P<0.058 After 2 years, percentage of subjects with improvement of ≥0.22 in HAQ-DI: 72% vs. 63%; P<0.05 Percentage with HAQ-DI scores of 0: 33% vs. 19%; P<0.001 | NR | Fair
Etanercept+MTX vs. MTX
*Emery et al., 2008;^90^ Kekow, 2010^212^ Emery, 2010^91^ COMET study | RCT 542 52 weeks^†^ 2 years91 | MTX naïve patients; Early RA, mean disease duration 9 months | ETN (50 mg/week)+MTX (7.5–20 mg/week) vs. MTX (7.5 to 20 mg/week) | Percent improvement in HAQ DI: 61% vs. 44%; P<0.0001 Mean improvement in HAQ: −1.02 vs. −0.72; P<0.001 Percent of subjects achieving normal HAQ-DI (score<0.5): 55% vs. 39%; P=0.0004 | Mean improvement in SF-36 PCS: 13.7 vs. 10.7, P=0.003 Mean improvement in SF-36 MCS: 6.8 vs. 6.1, P=NS Mean improvement in EQ-5D VAS: 26.6 vs. 21.7, P=0.003 | Fair
Klareskog et al., 2004;^86^ van der Heijde et al., 2006;^136^ van der Heijde et al., 2006^137, 138^ TEMPO study | RCT 686(503 for 2-year results) 52 weeks (2 years, 100 weeks) | Europe multinational, multicenter; active RA; had failed at least 2 DMARDs; mean disease duration 6.6 years | ETN (25 mg twice weekly)+MTX (20 mg/week) vs. MTX (20 mg/week) | Combination group had greater improvement in mean HAQ scores (mean improvement from baseline HAQ 1.0 vs. 0.65; P<0.01) | ETN+MTX patients reported better quality of life than MTX-only patients (mean EQ-5D VAS 72.7 vs. 63.7; P<0.01) | Good
Weaver et al., 2006^68^ | Prospective cohort study 3,034 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETN (25 mg twice weekly)+MTX (dose NR) vs. MTX | Greater mean percentage improvements in HAQ at 12 months for ETN+MTX than MTX (17% vs. 7%; P<0.01) Similar mean percentage improvements in HAQ at 12 months for INF+MTX and MTX (3% vs. 7%; P=NS) | NR | Fair
Etanercept+SSZ vs. SSZ
Combe et al., 2006^85, *^Combe et al., 2009^145^ | RCT 260 24 weeks 2 years | Active RA despite SSZ treatment; mean disease duration 6.6 years | ETN (25 mg twice weekly)+SSZ (2, 2.5, or 3g/day) vs. SSZ (2, 2.5, or 3g/day) | Percentage of patients who achieved a clinically significant improvement in HAQ at 2 years: 78% vs. 40%; P<0,01 | NR | Fair
Golimumab+MTX vs. MTX
*Emery et al., 2009^92^ GO-BEFORE | RCT 637 24 weeks | MTX-naïve patients with active RA | GOL (50 mg)+MTX vs. GOL (100 mg)+MTX vs. MTX vs. GOL (100 mg) | Median % improvement from baseline in HAQ-DI: 43.65 vs. 48.55 vs. 36.95 vs. 31.05 (P=0.141 for GOL 50+MTX vs. MTX)^‡^ | NR | Fair
Infliximab+MTX vs. MTX
St Clair et al., 2004;^82^ Smolen et al., 2006^83^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX-naive; mean disease duration 0.9 years | INF (3 mg/kg/8 weeks)+MTX (20 mg/week) vs. INF (6 mg/kg/8 weeks)+MTX (20 mg/week) vs. MTX (20 mg/week) | Median decrease in HAQ: 0.78 vs. 0.79 vs. 0.75; P=0.03 for INF 3+MTX vs. MTX and P<0.001 for INF 6+MTX vs. MTX. Combination therapy was more effective for improving HAQ by at least 0.22 units (76.0% and 75.5% vs. 65.2%; P=0.003; P=0.004) | Significantly greater improvement in SF-36 PCS for INF 6 mg+MTX vs. MTX (13.2 vs. 10.1; P=0.003) but not for INF 3 mg+MTX vs. MTX (11.7 vs. 10.1; P=0.10) | Fair

* New study added since last review.

† In COMET, subjects were randomized to one of four treatment groups: (1) ETN+MTX for year 1 followed by the same treatment for year 2, (2) ETN+MTX for year 1 followed by ETN alone for year 2, (3) MTX for year 1 followed by ETN+MTX for year 2, or (4) MTX for year 1 followed by continued MTX for year 2. Thus, all subjects were treated with ETN+MTX or MTX for 1 year and we present the 52 week outcomes in this table.

‡ P=0.006 for GOL 100+MTX vs. MTX, but GOL 100 mg is an unapproved dose.

ADA = adalimumab; ETN = etanercept; EQ-5D VAS = European Quality of Life-5 Dimensions Visual Analogue Scale; GOL = golimumab; HAQ = Health Assessment Questionnaire; HAQ-DI = Health Assessment Questionnaire – Disability Index; INF = infliximab; MTX = methotrexate; NR = not reported; NS = not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial; SF-36 PCS = Medical Outcomes Test, Short Form 36, physical component score; SSZ = sulfasalazine

Golimumab plus MTX versus golimumab. Two RCTs compared golimumab plus MTX with unapproved doses of golimumab (100 mg).92, 169 These two studies are referenced in other sections of this report for study arms using approved doses (e.g., golimumab 50 mg plus MTX compared with MTX section), but we do not include them in Table 34, the overview, our conclusions, or in strength of evidence tables due to the use of unapproved doses in the golimumab plus placebo arms, because it is difficult to draw conclusions about the comparative effectiveness of golimumab plus MTX with the approved use of golimumab (50 mg every 4 weeks).

The GO-BEFORE study was a phase III, multicenter RCT that randomized subjects to subcutaneous placebo injections plus MTX capsules, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 100 mg injections plus MTX capsules.92 The trial reported a median percent improvement in HAQ-DI of 43.65 for golimumab 50 mg plus MTX compared with 48.55 for golimumab 100 mg plus MTX compared with 31.05 for the golimumab 100 mg plus placebo group (P=NR for golimumab plus MTX compared with golimumab).

The GO-FORWARD study was a phase III, multicenter trial that randomized subjects (assigned in a 3:3:2:2 ratio) to receive placebo injections plus MTX, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 50 mg injections plus MTX capsules.169 The golimumab plus placebo arm of the trial used an unapproved dose of golimumab; thus, it is difficult to draw conclusions about the comparative effectiveness of the approved use of golimumab (50 mg every 4 weeks) and combination therapy with golimumab plus MTX.

Infliximab plus MTX versus infliximab. No RCT compared the infliximab-MTX combination to infliximab monotherapy. The only comparative evidence comes from a cohort study from the RADIUS program (see Etanercept plus MTX versus etanercept).68 The mean percentage improvements in the HAQ at 12 months were similar for patients treated with the infliximab-MTX combination and those treated with infliximab monotherapy (3 percent vs. 1 percent; P=NR).

Biologic combinations: biologic DMARD plus oral DMARD versus oral DMARD. We included seven studies comparing a biologic DMARD plus an oral DMARD with oral DMARD monotherapy (Table 34). We found five RCTs76, 82, 89, 90, 92 and one prospective cohort study68 comparing a combination regimen of abatacept plus MTX,89 adalimumab plus MTX,76 golimumab plus MTX,92 infliximab plus MTX,68, 82 or etanercept plus MTX68, 90 with MTX monotherapy. We found one RCT comparing a combination of etanercept plus sulfasalzine with sulfasalazine monotherapy.85, 145 Four RCTs were conducted in subjects with early RA;76, 82, 89, 90 another enrolled a majority of subjects with early RA (about 70 percent of subjects had RA for 3 years or less).92 All of the RCTs found greater improvement in functional capacity with combination therapies than with monotherapy, although findings in two of the studies did not reach both clinical and statistical significance.

Abatacept plus MTX versus MTX. One multinational RCT randomized 509 subjects with early RA to receive abatacept plus MTX or placebo plus MTX.89 The trial enrolled subjects with early RA who were MTX naïve and seropositive for rheumatoid factor, anti-cyclic citrullinated protein type 2, or both, and had radiographic evidence of joint erosions. At 1 year, subjects treated with abatacept plus MTX had statistically significantly greater improvement in measures of functional capacity (HAQ-DI) and quality of life (SF-36 PCS), but neither difference reached the threshold for MCID (Table 34).

Adalimumab plus MTX versus MTX. The PREMIER study was a multinational 2-year RCT of 799 patients with early, aggressive RA who had not previously received MTX; it compared adalimumab monotherapy, MTX monotherapy, and the combination of adalimumab plus MTX76 (see KQ 1 section on Biologic DMARD plus oral DMARD versus biologic DMARD). After 1 year, the combination group had greater improvements in HAQ-DI scores than the MTX group. After 2 years, the combination was superior to MTX. More patients in the combination group had achieved improvement of ≥0.22 in the HAQ-DI than the MTX group. In addition, 33 percent of patients in the combination group and 19 percent of those in the MTX group had HAQ-DI scores of zero (P<0.001).

Etanercept plus MTX versus MTX. The COMET study randomized 542 subjects with active, early, moderate to severe early RA to 52 weeks of MTX monotherapy or a combination of MTX and etanercept.90, 212 Subjects in the combination therapy group had greater improvements in functional capacity and quality of life (Table 34). In addition, among subjects that were working full- or part-time at baseline, fewer patients needed to stop work for at least 1 week in the combination therapy group (9 percent vs. 24 percent, P=0.004). In COMET, although year 1 of the study compared combination therapy with etanercept and MTX with MTX alone, subjects were actually randomized to one of four treatment groups at the outset: (1) etanercept plus MTX for year 1 followed by the same treatment for year 2 (EM/EM), (2) etanercept plus MTX for year 1 followed by etanercept alone for year 2 (EM/E), (3) MTX for year 1 followed by etanercept plus MTX for year 2 (M/EM), or (4) MTX for year 1 followed by continued MTX for year 2 (M/M). After 2 years, a greater proportion of subjects had normal HAQ DI scores in the EM/EM group compared with the M/M group (62 percent vs. 44 percent, P<0.011).91

The 52-week TEMPO trial involved 686 patients with active RA who had failed previous DMARD therapy.86, 136–138 Subjects were included only if they had not taken MTX for the 6 months prior to enrollment. We focus here on results of the etanercept-MTX combination and the MTX monotherapy arms; their baseline HAQ scores were similar. The combination therapy group had better improvement in functional status than the MTX monotherapy group. At 52 weeks, the combination group had greater improvement in functional capacity than the monotherapy group. In addition, those receiving combination therapy achieved better quality-of-life scores than MTX monotherapy (EQ 5-D VAS).136 Results of year 2 of the TEMPO trial confirmed the long-term sustainability of these findings.138 Improvement in disability (based on HAQ) remained significantly better in the combination group. However, attrition was 39 percent for year 2, which could compromise the validity of the long-term results.

A prospective cohort study from the RADIUS program showed that patients treated with the etanercept-MTX combination had statistically significantly greater mean percentage improvements in HAQ scores at 12 months than those treated with MTX alone.68

Etanercept plus sulfasalazine versus sulfasalazine. A 2-year multicenter RCT in Europe assessed the comparative efficacy of etanercept monotherapy, sulfasalazine monotherapy, and an etanercept-sulfasalazine combination in patients with active RA who had failed previous sulfasalazine treatment.85 Two-year outcomes were also published for the trial.145 Results on patient-reported measures of functional status and quality of life (HAQ, EuroQOL VAS) were similar at baseline for patients in the two groups. A greater percentage of subjects treated with combination therapy achieved a clinically significant improvement in functional capacity (HAQ improvement of ≥0.22) at 2 years.145

Golimumab plus MTX versus MTX. The GO-BEFORE study was a phase III, multicenter RCT that randomized subjects to subcutaneous placebo injections plus MTX capsules, golimumab 100 mg injections plus placebo capsules, golimumab 50 mg injections plus MTX capsules, or golimumab 100 mg injections plus MTX capsules.92 The trial reported a median percent improvement in HAQ-DI of 43.65 for golimumab 50 mg plus MTX compared with 48.55 for golimumab 100 mg plus MTX compared with 36.95 for the MTX group. Although the difference was statistically significant for the 100 mg dose of golimumab plus MTX compared with MTX, the difference was not statistically significantly for the approved dose of golimumab (50 mg) plus MTX compared with MTX (P=0.141 for GOL 50+MTX vs. MTX; P=0.006 for golimumab 100 mg plus MTX compared with MTX).

Infliximab plus MTX versus MTX. The ASPIRE trial enrolled 1,049 patients with early RA (disease duration<3 years) who were MTX-naive.82, 83 This study compared the benefits of initiating treatment with MTX alone or with a combination of MTX and infliximab over 52 weeks. HAQ and SF-36 scores improved significantly more in the combination groups than in the MTX-only group. The median decrease in the HAQ score was greater for the combination groups than for the MTX-only group (Table 34). In addition, more patients in the combination groups improved their HAQ scores by at least 0.22 units than in the MTX-only group. The mean increases in SF-36 physical component summary scores were 11.7 and 13.2 for the combination groups and 10.1 for the MTX-only group (P=0.10 and P=0.003, respectively). Patients on the combination treatment also had a higher probability of maintaining their employability than did those on MTX alone (P<0.001).83

One prospective cohort study from the RADIUS program in the United States (described above in the Etanercept plus MTX versus etanercept section) involved patients who were initiating any new DMARD.68 The mean percentage improvements in the HAQ at 12 months were not significantly different between patients treated with the infliximab-MTX combination and those treated with MTX monotherapy.

Biologic combinations: biologic DMARD plus oral DMARD versus biologic DMARD plus oral DMARD. One prospective cohort compared patients taking an anti-TNF plus oral DMARD to patients taking another anti-TNF plus oral DMARD (Table 35).94 The study compared anti-TNF (infliximab, etanercept or adalimumab) plus MTX versus anti-TNF plus leflunomide.94 The study reported no difference in functional capacity between groups (mean improvement in HAQ at 1 year).94

Table 35 Biologic DMARD plus oral DMARD versus biologic DMARD plus oral DMARD studies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Anti-TNF+MTX vs. Anti-TNF+LEF
*Finckh et al., 2008^94^ SCQM cohort | Prospective Cohort 1,218 17 months (mean) | Population-based: Treatment with INF, ETN or ADA; mean disease duration 8.4 to 8.9 years | Anti-TNF (INF or ETN or ADA) (NR)+MTX (NR) vs. Anti-TNF (INF or ETN or ADA) (NR)+LEF | Mean improvement in HAQ at 1 year: 0.12 vs. 0.14; P=0.09 | NR | Fair

* New study added since last review.

ADA = adalimumab; ETN = etanercept; HAQ = Health Assessment Questionnaire; INF = infliximab; LEF = leflunomide; NR = not reported; SCQM = Swiss Clinical Quality Management; TNF = tumor necrosis factor

Strategies in early RA. Functional capacity and health related quality-of-life outcomes are presented in Table 36.

Table 36 Early RA strategies: Functional capacity and health-related quality-of-life outcomes

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Two Oral DMARD+Corticosteroid vs. Oral DMARD
Boers et al., 1997;^95^ Landewe et al., 2002^96^, COBRA study | RCT 155 (148) 56 weeks (5-year followup) | Multicenter; early RA; mean disease duration 4 months | SSZ (2g/day)+MTX (7.5 mg/day stopped after 40 weeks)+PNL (60 mg/day tapered over 28 weeks) vs. SSZ | Mean change in HAQ: SSZ+MTX combination had greater improvements in functional capacity at 28 weeks (mean change in HAQ −1.1 vs. −0.6; P<0.0001) but difference not significant at 56 weeks (−0.8 vs. −0.6; P<0.06) | NR | Good
Two Oral DMARD+Corticosteroid vs. Oral DMARD
Mottonen et al., 1999;^97^ Korpela et al., 2004;^98^ Puolakka et al., 2004^202^, FIN-RACo study | RCT 199 24 months (5-year followup) | Multicenter; early RA; mean disease duration 7.3 to 8.6 months | MTX (7.5 to 10 mg/week)+HCQ (300 mg/day)+SSZ (2g/day)+PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd DMARD) ± PNL | Less work disability for combination group than monotherapy group (median 12.4 days per patient-observation year vs. 32.2; P=0.008) | NR | Fair
Other Combination Strategies
Goekoop-Ruiterman et al., 2005;^100^ *Allaart et al., 2006;^101^ Goekoop-Ruiterman et al., 2007;^102^ van der Kooij et al., 2009;^103^ van der Kooij et al., 2009^196^ BeSt study | RCT 508 12 months 2 years 4 years | Multicenter; early RA; median duration between diagnosis and inclusion 2 weeks (IQR 1 to 5), median duration of symptoms 23 weeks (IQR 14 to 53) | DAS-driven treatment; 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: step-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/d to 7.5 mg/d) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | All groups improved; greater improvement for groups 3 and 4 than groups 1 or 2 at 3 months (improvement in D-HAQ for strategies 1 through 4: 0.4 vs. 0.4 vs. 0.8 vs. 0.8); better functional ability after 12 months for patients in group 3 or 4 than in group 1 (improvement in mean D-HAQ scores for strategies 1 through 4 were 0.7, 0.7, 0.9, and 0.9, respectively; P<0.05 for 1 vs. 3 and 4, NS for other comparisons); No difference between groups at 24 months (0.7, 0.8, 0.9, and 0.9; P=0.26); improvements were maintained at 4 years, with no significant differences between groups (0.8, 0.7, 0.8, 0.8; P=0.64) | SF-36 PCS: Greater improvement at 3 months and 6 months for groups 3 and 4 than groups 1 and 2 (P<0.001); no difference at 1 and 2 years (P=0.10 and 0.95, respectively) difference SF-36 MCS: No differences between groups at 3 months, 6 months, 1 year, or 2 years (P=0.22, 0.17, 0.83, 0.97, respectively) | Good

* New study added since last review.

BeST = Dutch acronym for Behandel Sstrategieen; COBRA = Combinatietherapie Bij Reumatoide Artritis; DAS = disease activity score; D-HAQ = Health Assessment Questionnaire – Disability Index; DMARD = disease modifying antirheumatic drug; ERA = early rheumatoid arthritis; FIN-RACo = Finnish Rheumatoid Arthritis Combination Therapy; g/day = gram per day; HAQ = Health Assessment Questionnaire; HCQ = hydroxychloroquine; INF = infliximab; MCS = mental component score; mg/d = milligram per day; MTX = methotrexate; NR = not reported; NS = not significant; PCS = physical component score; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; SF-36 = Medical Outcomes Test, Short Form 36; SSZ = sulfasalazine

Two oral DMARDs plus corticosteroid versus oral DMARD. The COBRA study assessed differences in efficacy between a combination of sulfasalazine, MTX, and prednisolone and sulfasalazine only.95, 96 This RCT evaluated 155 patients with early RA over 56 weeks. Combination therapy included sulfasalazine, MTX, and prednisolone treatment. Compared with patients treated with sulfasalazine alone, patients treated with combination therapy had greater improvements in functional capacity at 28 weeks. The difference was no longer statistically significant at 56 weeks.

Three oral DMARDs plus corticosteroid versus oral DMARD. The FIN-RACo RCT assessed the efficacy of a combination of MTX, sulfasalazine, hydroxychloroquine, and prednisolone against monotherapy with a DMARD with or without prednisolone.97 This study randomized 199 patients with early RA to combination therapy or monotherapy. Combination therapy included sulfasalazine, MTX, hydroxychloroquine, and prednisolone. Patients on monotherapy were initially started on sulfasalazine (2 g/day to 3 g/day), but they could be changed to MTX (7.5 mg/week to 15 mg/week) or to a third DMARD if needed. The study is described further in the KQ 1 section titled Three oral DMARDs plus corticosteroid versus oral DMARD. The initial publication reported no functional capacity or quality of life outcomes at 2 years. A 5-year follow-up trial reported that patients in the combination therapy group had significantly less work disability than patients in the monotherapy group.202 After 2 years, the drug treatment strategy was no longer restricted and was left to the discretion of individual physicians.

Other combination strategies. The BeSt RCT examined four different treatment strategies over 12 months.100–103, 196 Patients (N=508) with early RA were randomized to one of four strategies: (1) sequential DMARD starting with MTX (15 mg/week); (2) step-up combination therapy of MTX (15 to 30 mg/week) followed by sulfasalazine (2g/day), hydroxychloroquine, and prednisone; (3) initial combination therapy of MTX, and sulfasalazine with tapered high-dose prednisone (60 mg/day to 7.5 mg/day in 7 weeks); and (4) initial combination therapy with infliximab (3 mg/kg) and MTX (25 to 30 mg/week). Adjustments were made in each strategy when the DAS 44 (disease activity score in 44 joints) was greater than 2.4. All groups had similar D-HAQ (Dutch version of the HAQ) scores at baseline (1.4 ± 0.7 or 1.4 ± 0.6). Functional ability, measured by the D-HAQ, was a primary end point. Subjects in groups 3 and 4 had more rapid improvement in functional ability (statistically significant greater improvements at 3, 6, 9, and 12 months). After 12 months of treatment, patients treated with strategy 3 or 4 had statistically significant better functional ability than those treated with strategy 1. By 2 years, improvement was maintained in all groups, but there were no statistically significant differences between groups. Improvements were maintained at 4 years, with no significant differences between groups. Subjects in groups 3 and 4 had more rapid improvement in physical health-related quality of life; with greater improvement at 3 months and 6 months for groups 3 and 4 than groups 1 and 2 on the SF-36 PCS (P<0.001); but all groups had similar improvement by the end of 1 and 2 years (P=0.10 and 0.95, respectively). There were no differences at any point in mental health-related quality of life as measured by the SF-36 MCS.

## Key Question 3 Harms, Tolerability, Adverse Effects, or Adherence

This key question examines whether drug therapies differ in harms, tolerability, or adverse effects in patients with RA. We describe overall tolerability, then specific adverse events for each drug class, followed by studies reporting on adherence. Evidence Tables in Appendix E describe details about these studies, some of which were described for efficacy in KQ 1, above.

### Overview

A total of 66 randomized controlled trials (RCTs), one nonrandomized controlled trial, 99 observational studies, and 18 systematic reviews reported on tolerability, harms, and adherence (see Evidence Tables in Appendix E).

As with earlier KQs, the main drug classes examined are corticosteroids, oral disease-modifying antirheumatic drugs (DMARDs), and biologic DMARDs. Studies often defined comparator groups that were not specific to a particular agent, but instead encompassed any agent in a family of treatments (e.g., an oral DMARD). In cases of biologic DMARDs, studies often required all patients to already be on an oral DMARD such as methotrexate (MTX). In RCTs where the biologic DMARD plus MTX is compared with MTX monotherapy, we discuss these as placebo-controlled trials since the MTX is given to all patients. We differentiate this issue in the text when study designs may not otherwise be clear.

Most studies that examined the comparative efficacy of our drugs of interest also determined their harms. Methods of adverse events assessment, however, differed greatly. Few studies used objective scales such as the UKU-SES (Utvalg for Kliniske Undersogelser Side Effect Scale) or the adverse reaction terminology from the World Health Organization (WHO). Most studies combined patient-reported adverse events with a regular clinical examination by an investigator. Often, determining whether assessment methods were unbiased and adequate was difficult. Rarely were adverse events prespecified and defined. Short study durations and small sample sizes additionally limited the validity of adverse events assessment with respect to rare but serious adverse events.

Because few studies used the term serious adverse events as defined by the International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use,213 we describe serious adverse events as the individual studies identified and reported them.

### Rheumatoid Arthritis: Key Points

Tolerability and adverse events. Corticosteroids. Comparative tolerability and overall adverse events between corticosteroids were similar but comparative data were limited to one 3-month trial.54 The strength of evidence is low (Appendix I).

Mixed results from one RCT and four observational studies suggest that corticosteroids may increase risk of cardiovascular events.64, 214–217 One study showed a protective effect against cardiovascular morbidity with corticosteroids.215 The strength of the evidence is low.

Corticosteroid use significantly predicted the risk of serious infections, with increased risk of infection demonstrated in nine observational studies.218–226 The strength of evidence for risk of infection with corticosteroids is moderate.

Low strength evidence suggests that corticosteroid treatment is associated with an increased risk of septic (infectious) arthritis227 and interstitial lung disease.228

Oral DMARDs and combinations. Three efficacy trials and one meta-analysis indicated similar tolerability and discontinuation rates of leflunomide, MTX, and sulfasalazine in data up to 2 years.55, 56, 104, 105, 107, 108 A retrospective cohort study found improved tolerability with leflunomide.229 In another meta-analysis, the proportion of patients who stayed on MTX was higher than the proportion remaining on sulfasalazine at 5 years based on analysis of 71 RCTs and 88 observational studies (36 percent vs. 22 percent, P=NR [not reported]).230 The strength of evidence for comparisons of monotherapy with oral DMARDs is low (Appendix I).

Seven studies and two meta-analyses involving combinations of two or three DMARDs, including sulfasalazine, MTX, hydroxychloroquine, and etanercept (a biologic DMARD) versus one or two DMARDs have similar withdrawal rates attributable to adverse events.29, 57–59, 61, 62, 95, 110, 231, 232 Although discontinuation rates were similar for these pharmaceuticals, the number of patients with adverse events (nausea, erythema, elevated transaminases) were higher in two studies of sulfasalazine plus MTX than in monotherapy with either drug.57, 58 The strength of evidence comparing combinations of DMARDs with DMARD monotherapy is low.

Three studies of combinations including prednisone with one or more DMARD indicated similar discontinuation rates between groups.65, 98, 100–102, 196 The BeST study compared various strategies of combining corticosteroids with oral and biologic DMARDs and found similar rates of serious adverse events.100–102, 196 A retrospective cohort study of 154 patients found that addition of a glucocorticoid to hydroxychloroquine or MTX increased the mean time until withdrawal of DMARD therapy due to adverse events by approximately 6 months (P<0.05).233 The level of evidence is moderate.

Four observational studies assessed cardiovascular or cerebrovascular outcomes with monotherapy or combinations of oral DMARD treatment.214, 215, 234, 235 All found either a decrease or no difference in risk of these events for patients treated with oral DMARDs. The reduction in risk was largest for leflunomide based on two studies.215, 234 The strength of the evidence is low.

Hepatic events appeared to be similar among patients treated with MTX, leflunomide, hydroxychloroquine, sulfasalazine, infliximab, and etanercept in two retrospective studies over 2 years to 3 years.229, 236 Longer-term evidence is lacking. The level of evidence is low.

Mixed evidence from 12 studies suggests that oral DMARDs do not significantly affect risk of infections.218, 220, 221, 223, 224, 226, 229, 237–240 Evidence is inconclusive for comparing among oral DMARDs. One good-rated nested case-control study showed a lower rate of infection with MTX and hydroxychloroquine. Four other observational studies found no difference in risk with oral DMARDs,218, 220, 221, 239 while five fair-rated observational studies suggest that risk of infection was increased with oral DMARDs. Because of these inconsistencies, the level of evidence is low.

In one 5-year retrospective cohort, interstitial lung disease appeared to be significantly higher with leflunomide use than with use of other DMARDs (relative risk [RR], 1.9; 95% CI, 1.1 to 3.6) but not significantly higher with use of either MTX (RR, 1.4; 95% CI, 0.8 to 2.3) or biologic DMARDs (RR, 0.8; 95% CI, 0.4 to 1.5).217 Overall, the rate of hospitalizations because of interstitial lung disease in the entire cohort was 8.1 per 10,000 patient years. In a second study, the risk of interstitial lung disease was similar for leflunomide and other oral DMARDs. The level of evidence is insufficient.

Estimates of cancer risk were limited to retrospective cohort studies. No risk of lymphoma was found for MTX or sulfasalazine in a 30-year retrospective cohort.241 For the comparison of oral DMARDs, the strength of the evidence is low. Among RA patients, the development of nonmelanoma skin cancer was associated with use of prednisone (hazard ratio [HR], 1.28; P=0.014).242

Additional studies suggest that oral DMARDs increase risk of septic (infectious) arthritis,227 and that leflunomide increases risk of wound healing complications compared with MTX,243 but hydroxychloroquine, leflunomide, MTX, and sulfasalazine do not increase risk of sinus problems244 A good-rated RCT found that combination DMARD therapy did not increase risk of renal failure.245 Evidence is insufficient regarding risks for fertility, pregnancy, and lactation.246 The strength of this evidence is low because only a single study addresses each of these questions.

Biologic DMARDs. Meta-analysis of withdrawal rates from placebo-controlled trials indicate that fewer patients randomized to a biologic DMARD discontinue treatment compared with patients randomized to placebo or MTX monotherapy (oddsratio [OR] of discontinuation, 0.51; 95% CI, 0.40 to 0.65). This difference is largely driven by withdrawals because of lack of efficacy. In a meta-analysis of withdrawals because of lack of efficacy, the patients treated with a biologic DMARD were much less likely to withdraw than placebo- or MTX-treated patients (OR, 0.21; 95% CI, 0.17 to 0.27). Withdrawals because of adverse events were higher among patients treated with a biologic DMARD compared with placebo- or MTX-treated patients (OR, 1.43; 95% CI, 1.18 to 1.74). Because the overall withdrawals rates favored biologic DMARDs over placebo, we concluded that efficacy had a stronger influence on the likelihood of treatment continuation than adverse events. Adjusted indirect comparisons based on the same efficacy trials found no difference in overall withdrawals, with the exception of a more favorable withdrawal profile for certolizumab pegol. Also, etanercept and rituximab had a more favorable overall withdrawal profile than some other biologic DMARDs. Certolizumab pegol had fewer withdrawals due to lack of efficacy than adalimumab, anakinra, and infliximab. All but adalimumab, golimumab, and infliximab had fewer withdrawals than anakinra due to lack of efficacy. Both certolizumab pegol and infliximab had more withdrawals due to adverse events than etanercept and rituximab. These results should be interpreted cautiously because of the relatively small number of contributing studies and the corresponding wide confidence intervals.

Strength of evidence is presented in Appendix I; overall the strength of evidence is low.

Overall tolerability: studies on discontinuation rates not otherwise covered in quantitative analyses. Studies that assessed overall tolerability but were not eligible for inclusion in quantitative analyses are summarized in Table 38. One good-quality RCT compared etanercept with the combination of etanercept and abatacapt.80 Withdrawals due to adverse events occurred more in the combination group (11.8 percent) than in the monotherapy etanercept group (2.8 percent). Additional evidence on comparative discontinuation rates is provided by observational studies.88, 93, 247–251 While some studies did not find clinically or statistically significant differences in drug discontinuation rates,247, 249 others did, generally suggesting higher discontinuation rates with infliximab, adalimumab, and anakinra.73, 88, 210, 248, 250–252 One good-rated meta-analysis reported an elevated risk of withdrawals due to adverse events for infliximab,126 and another good-rated meta-analysis reported higher withdrawals due to adverse events or adalimumab, anakinra, and infliximab compared with etanercept.27, 180

Table 38 Cardiovascular and cerebrovascular events in patients with rheumatoid arthritis treated with corticosteroids

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Cardiovascular and Cerebrovascular Events
*Choy et al., 2008^64^ CARDERA trial | RCT 467 2 years | Pts with early, active RA | MTX+PNL | The number need to harm (NNH) with added PNL for any adverse event leading to withdrawal was 14 (95% CI, 6 to 65). PNL use associated with hypertension (OR, 2.16; 95% CI, 1.07 to 4.36). | Fair
*Nadareishvili et al., 2008^214^ | Nested case-control 269 cases among 7,045 patients 8 years | RA pts in National Data Bank for Rheumatic Diseases | PRED | Association of PRED therapy with ischemic stroke: OR,1.75; 95% CI, 0.87 to 3.53; P=0.114) | Fair
*Naranjo et al., 2008^215^ | Cross-sectional 4,363 Clinician and patient recall | Sample of RA pts across 15 countries | Glucocorticoids | Glucocorticoids associated with reduced risk for CV morbidity (HR, 0.95; 95% CI, 0.92 to 0.98). | Fair
*Solomon et al., 2006^216^ | Nested case-control study 3,501 24 months | Pennsylvania Medicare enrollees with RA | Glucocorticoids | Glucocorticoid monotherapy associated with increased risk for cardiovascular events (OR, 1.5; 95% CI, 1.1 to 2.1). | Fair
*Suissa et al, 2006^234^ | Retrospective cohort 107,908 14 months | RA pts from PharMetrics data (US) | Glucocorticoids | Glucocorticoid use associated with acute MI (RR,1.32; 95% CI, 1.02 to 1.72) | Fair

* New study added since last review.

AE = adverse event; BUD = budesonide; CI = confidence interval; CV = cardiovascular; DMARD = disease-modifying antirheumatic drugs; GI = gastrointestinal; mg = milligram; HR = hazard ratio; MI = myocardial infarction; MTX = methotrexate; NNH = number needed to harm; OR = odds ratio; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial

Two studies compared adverse event rates and serious adverse events with biologic DMARDs; one randomized controlled trial66 and one retrospective cohort study.253 Both studies found more serious adverse events among patients treated with infliximab compared with abatacept, adalimumab, and etanercept. No other studies directly compared one biologic DMARD with another biologic DMARD with regard to tolerability or serious adverse events. The strength of this evidence is low.

Indirect evidence from additional efficacy trials, cohort studies, and meta-analyses suggests that the overall tolerability profiles are similar among biologic and oral DMARDs, or combinations of biologic and oral DMARDs.67, 70, 76, 84, 86, 87, 89, 90, 116, 121, 127, 136, 138, 156, 170, 175, 177, 178, 183, 210, 254–256 However, several studies suggested that adverse events were more common with biologic DMARDs, given alone or in combination with an oral DMARD.120, 145, 164–167, 173 One good-rated126 and one fair-rated183 systematic review and meta-analysis provide indirect evidence that adverse event rates may be more common with infliximab than with adalimumab or etanercept. One prospective cohort study found a slightly lower rate of serious adverse events among patients who had an oral DMARD added to adalimumab, compared with patients who only received adalimumab (5.3 percent vs. 7.3 percent, respectively; P=NR).257 In contrast, in an RCT of MTX-naïve patients that compared golimumab monotherapy, MTX monotherapy, and golimumab plus MTX, serious adverse events were least common among the golimumab monotherapy group (3.2 percent vs. 6.9 percent vs. 6.3 percent, respectively; P=NR).92

Four RCTs were designed to assess adverse events as primary outcomes.121, 155, 258, 259 Overall, adverse event rates were similar for abatacept,258 adalimumab,121 anakinra,259 or infliximab155 and placebo. Other efficacy trials suggested that overall adverse events are higher with biologic DMARDs than with placebo.

Two trials indicated that a combination treatment of two biologic DMARDs can lead to substantially higher rates of severe adverse events than biologic DMARD monotherapy.79, 258 The evidence, however, is limited to combinations of anakinra with etanercept, and abatacept with anakinra, adalimumab, etanercept, or infliximab. The strength of the evidence is moderate.

Five long-term extension studies of adalimumab,124 anakinra,129 etanercept,260 and infliximab149, 261 indicated that the rate of adverse events does not increase over time. The strength of the evidence is moderate. No evidence is available on the long-term tolerability of abatacept and rituximab.

Specific adverse events. The risk for long-term, rare but serious adverse events such as serious infections, malignancies, congestive heart failure, or autoimmunity is a cause of concern for all biologic DMARDs. We could not, however, reliably assess the comparative risk among biologic DMARDs for most serious adverse events because of insufficient evidence. A summary of studies assessing specific events can be found below later on in Table 39.

Table 39 Infection in patients with rheumatoid arthritis treated with corticosteroids

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Bernatsky et al., 2007^218^ | Nested case-control 23,733 Up to 23 years | RA pts registered in claims databases in Quebec | Glucocorticoids | The risk for all infections requiring hospitalization was most elevated with glucocorticoid agents (RR, 2.6; 95% CI, 2.3 to 2.9); Similar effects were seen with pneumonia as the outcome (RR, 2.1; 95% CI, 2.4 to 3.1). | Fair
*Brassard et al., 2006^219^ | Retrospective cohort study 112,300 Up to 5 years | RA pts from PharMetrics data (U.S.) | Several oral DMARDs, biologic DMARDs, corticosteroids | Adjusted rate ratio of developing TB with corticosteroids: 1.7 (95% CI, 1.3 to 2.2). | Fair
Doran et al., 2002^220^ | Retrospective cohort 609 39 years | RA patients | Several oral DMARDs, corticosteroids | In patients hospitalized for infection, corticosteroid use increased risk (HR, 1.56; 95% CI, 1.20 to 2.04) | Fair
*Lacaille et al., 2008^221^ | Retrospective cohort 27,710 162,720 person years | Pts with RA from British Columbia, Canada | Oral DMARDs, corticosteroids | Adjusted Rate Ratio for serious infections: DMARDs+corticosteroids: 1.63 (95% CI, 1.5 to 1.77); corticosteroids alone: 1.9 (95% CI, 1.75 to 2.05) | Fair
*Greenberg et al., 2010^226^ CORRONA | Prospective cohort 7,971 15,047 person-years | Pts with RA enrolled in the Consortium of Rheumatology Researchers of North America (CORRONA) registry | MTX, oral DMARDs, anti-TNF agents, PRED | Adjusted incidence rate ratio of infection and opportunistic infection for PRED compared with oral DMARDs, respectively: IRR 1.05 (0.97–1.15, P=0.251); IRR 1.63 (1.20–2.21, P=0.002) PRED above 10 mg daily associated with risk of infection (IRR 1.30, 95% 1.11–1.53, P=0.001) | Fair
*Schneeweiss et al., 2007^222^ | Retrospective cohort 15,597 Up to 8 years | Medicare beneficiaries ages 65 and older with RA | Glucocorticoids | Compared with MTX use, glucocorticoid use associated with serious bacterial infections (RR, 2.25; 95% CI, 1.57 to 3.22) | Fair
*Smitten et al., 2008^223^ | Retrospective cohort 24,530 26.6 months | RA pts from PharMetrics data (U.S.) | Corticosteroids | Oral corticosteroid use increased risk of hospitalized infection (RR, 1.92; 95% CI, 1.67 to 2.21). Risk increased with dose. | Good
*Smitten et al., 2007^224^ | Retrospective cohort 12,272 (PM)38,621 (GPRD) 12.3 to 38.8 months | RA pts from PM database and UK GPRD | Corticosteroids | Risk of herpes zoster infection with corticosteroids only: (PM: OR, 2.51; 95% CI, 2.05 to 3.06 GPRD: 1.46; 95% CI, 1.24 to 1.70) | Fair
*Strangfeld et al., 2009^225^ | Prospective cohort 5,040 up to 36 months | RA pts initiating biologic therapy or switching to another DMARD | Glucocorticoids | Adjusted HR for herpes zoster. Glucocorticoids 1 mg to 9 mg (HR, 1.86; 95% CI, 0.92 to 3.78); Glucocorticoids 10+mg (HR, 2.52; 95% CI, 1.12 to 5.65) | Good

* New study added since last review.

AE = adverse event; BUD = budesonide; CI = confidence interval; DMARD = disease-modifying antirheumatic drugs; GI = gastrointestinal; GPRD = General Practice Research Database; mg = milligram; HR = hazard ratio; MTX = methotrexate; OR = odds ratio; PM = Pharmetrics; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = relative risk; TB = tuberculosis

Cardiovascular and cerebrovascular events. No studies compared the risk of cardiovascular or cerebrovascular events with one biologic DMARD to another. Studies assessing class effects or individual biologic DMARDs provide mixed results. For example, one observational study reported lower rates of congestive heart failure.262 for RA patients on anti-tumor necrosis factor (TNF) therapy than for those on conventional RA therapies. This study is contrasted by three other cohort studies that found an increased risk of heart failure with adalimumab, etanercept, and infliximab compared with no treatment or oral DMARD.263–265 Three observational studies assessed the risk of broadly defined cardiovascular events.215, 216, 266 One study found no statistically significant association between use of biologic DMARDs and cardiovascular events,216 while two studies reported a decreased risk of cardiovascular events with biologic DMARDs.215, 266 One nested case-control study found a slight decrease in the risk of stroke with adalimumab, etanercept, and infliximab (OR, 0.79; 95% CI, 0.34 to 1.82; P=NS),214 and two cohort studies found no statistically significant differences in the risk of myocardial infarction (MI) (although results trended towards an increased risk of MI for these biologic DMARDs).234, 267

Infection. The best comparative evidence for risk of infection stems from an RCT66 and two prospective cohort studies.268, 269 The trial abatacept plus MTX with infliximab plus MTX and reported that serious infections were more common in the infliximab group than the abatacept group (P=NR).66 One prospective cohort study suggested that risks do not differ for adalimumab, etanercept, and infliximab.268 A second cohort study conducted in the British Society for Rheumatology Biologics Register (BSRBR) reported that anti-TNF drugs as a class increased risk of serious infections (HR, 1.2; 95% CI, 1.1 to 1.5).269 No statistically significant difference in the incidence rate was observed comparing across the individual drugs. Six systematic reviews and meta-analyses have assessed serious adverse events with biologic DMARDs, with some showing elevated risk of infection for biologic DMARDs.126, 183, 255, 270–272 Some of these analyses provide drug-specific effect size estimates that trended to be higher than for some drugs, although none of these analyses provide adjusted indirect comparisons or mixed treatment comparisons to adequately compare risk of infection among biologic DMARDs. Long-term observational studies generally support an increased risk of infection with biologic DMARDs, although not in across all studies.158, 218, 222, 223, 226, 240, 273–279 Numerous studies suggest that biologic DMARDs have increased risk of tuberculosis (TB) or granulomatous infections,219, 279–287 with one study indicating the risk may be higher for adalimumab and infliximab compared with etanercept.279 Two studies indicated that the general risk of biologic DMARDs for serious infections is dose dependent. The evidence, however, is limited to adalimumab271 and infliximab.155 The strength of comparative evidence is low, and the strength of general evidence of infection is moderate.

Infusion and injection site reactions. In efficacy studies, infusion reactions (abatacept, infliximab, rituximab, tocilizumab) and injection site reactions (adalimumab, anakinra, certolizumab, etanercept, golimumab) were the two most commonly and consistently reported adverse events. Overall, 0.5 percent of patients treated with infliximab had severe acute reactions that resembled acute anaphylactic conditions or led to convulsions.273 Fatal infusion reactions have also occurred with rituximab.288 Of existing comparative evidence, reactions with infliximab were reported more commonly than with other biologic DMARDs in an RCT comparing abatacept and infliximab,66 and in a retrospective cohort study comparing adalimumab, etanercept, and infliximab.253 A systematic review reported that the mean, crude incidence rates of injection site reactions in RCTs and observational studies were 17.5 percent (95% CI, 7.1 to 27.9) for adalimumab, 22.4 percent (95% CI, 8.5 to 36.3) for etanercept, and 67.2 percent (95% CI, 38.7 to 95.7) for anakinra.74

Interstitial lung disease. Only one study assessed the risk of interstitial lung disease with biologic DMARDs. This prospective cohort study found that current treatment with etanercept and infliximab was not associated with hospitalization for interstitial lung disease.228 However, past treatment with etanercept (HR, 1.7; 95% CI, 1.0 to 3.0; P=0.056) and infliximab (HR, 2.1; 95% CI, 1.1 to 3.8; P=0.019) was associated with hospitalization for interstitial lung disease.228

Malignancies. Data from controlled trials do not provide sufficient evidence concerning an increase in the risk of cancer attributable to the use of either biologic DMARDs or a combination of biologic and oral DMARDs. In a large prospective cohort study the risk of lymphoma was higher for patients on anti-TNF therapies than for those on oral DMARDs, although not statistically significantly so (standardized incidence ratio: MTX, 1.7 (95% CI, 0.9 to 3.2); infliximab, 2.6 (95% CI, 1.4 to 4.5); and etanercept, 3.8 (95% CI, 1.9 to 7.5).289 An update of this analysis with additional patients and follow-up time confirmed that the risk of lymphoma was not increased among patients taking adalimumab, etanercept, and infliximab.290 Similarly, three retrospective cohort studies did not detect any differences in the risks of lymphoma between patients on anti-TNF treatment and those on oral DMARDs.291–293 The largest study included 4,160 patients treated with anti-TNF drugs.292 Results yielded an adjusted relative risk of 1.1 (95% CI, 0.6 to 2.1) for anti-TNF patients relative to patients on oral DMARDs. Four meta-analyses have evaluated risk of overall malignancy with anti-TNF drugs.183, 255, 271, 294 Effect size estimates were not statistically significant in three of these analyses, but one fair-rated meta-analysis reported a pooled odds ratio for malignancies of 3.3 (95% CI, 1.2 to 9.1). Five large cohort studies do not suggest a statistically significant increase in risk of malignancy.276, 293, 295–297 The strength of the evidence is low.

Other adverse events. Evidence from randomized trials and observational studies is insufficient to draw conclusions regarding the comparative risk of rare but serious adverse events such as demyelination, autoimmunity, pancytopenia, and hepatotoxicity. Reports based on data from the FDA’s Adverse Events Reporting System (AERS) indicated that adalimumab, etanercept, and infliximab might be associated with demyelination.298, 299 Similar cases have been seen in regulatory trials of adalimumab.300 Reports of autoimmunity have not been confirmed in controlled trials and observational studies. However, case reports suggest an association between infliximab and drug-induced lupus and other autoimmune diseases.273, 301–303 Lupus-like syndromes have also been reported for adalimumab.298

Hepatotoxicity has been reported for infliximab.301 One study also reported elevated liver enzymes in patients treated with tocilizumab.174

A prospective cohort study indicated that patients on anti-TNF treatments were more likely to develop dermatological conditions (skin infections, eczema, drug-related eruptions).304 Another retrospective cohort study found no overall association of anti-TNF drugs with risk of psoriasis.305 Among the three biologic DMARDs included, adalimumab had a significantly increased risk of psoriasis compared with those treated with etanercept (incidence rate ratio [IRR], 4.6; 95% CI, 1.7 to 12.1) and infliximab (IRR, 3.5; 95% CI, 1.3 to 9.3).

One cross-sectional analysis of data from 7,243 patients reported a small elevated risk of sinus problems with etanercept (OR, 1.21; 95% CI, 1.02 to 1.42).244 No statistically significant increased risk of sinus problems was observed with adalimumab (OR, 1.09; 95% CI, 0.79 to 1.51) or infliximab (OR, 1.00; 95% CI, 0.88 to 1.15).

Adherence. Few efficacy studies reported rates of adherence. Results of efficacy trials do not indicate any differences in adherence among drug therapies used to treat RA. However, the quality of reporting and assessment of adherence was limited.

Findings from highly controlled efficacy studies may have limited generalizability to “real world” practice, especially because of the overall short duration of these trials. The evidence is insufficient to draw any conclusions about adherence from effectiveness studies.

For the comparison of one biologic DMARD with another, five observational studies provided mixed results. A review of a large, managed care database suggested that infliximab might have greater adherence than etanercept or MTX.306 This finding is supported by a second analysis that found greater adherence with infliximab compared with etanercept and anakinra.307 In contrast, two prospective cohort studies found that etanercept had better adherence than infliximab.69, 73 One of these studies suggested that etanercept had a better response rate than infliximab attributable to greater adherence.69 Another prospective cohort study failed to find any differences in adherence between etanercept and infliximab.81 Overall strength of evidence is low or insufficient for adherence.

### Detailed Analysis

Tables 37 to 56 provide information on harms, divided into separate sections for the three main categories of drugs covered in this review. In each section, we cover overall tolerability and then specific adverse events. When sufficient data are available, we break out specific events by type (e.g., hepatic, infection, etc). The overall tolerability section for biologic DMARDs is divided further to present results of quantitative analyses.

Table 37 Overall tolerability in patients with rheumatoid arthritis treated with corticosteroids

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Kirwan et al., 2004^54^ | RCT 143 12 weeks | Active RA | BUD PNL | Similar in all groups | Fair
Saag et al., 1994^313^ | Retrospective cohort 224 ≥1 year | RA patients on low-dose PRED (15 mg/day or less) | PRED No PRED | PRED 10 mg to 15 mg/day most related to development of AE (OR, 32.3; 95% CI, 4.6 to 220) PRED 5 mg to 10 mg/day (OR, 4.5; 95% CI, 2.1 to 9.6) No increase in AE for PRED<5 mg/day Fracture: OR, 3.9(95% CI, 0.8 to 18.1; P<0.09) First infection: OR, 8.0 (95% CI, 1.0 to 64.0; P<0.05) First GI event: OR, 3.3 (95% CI, 0.9 to 12.1; P<0.07) | Fair

AE = adverse event; BUD = budesonide; CI = confidence interval; DMARD = disease-modifying antirheumatic drugs; GI = gastrointestinal; mg = milligram; HR = hazard ratio; OR = odds ratio; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial

Table 40 Other specific harms in patients with rheumatoid arthritis treated with corticosteroids

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Edwards et al., 2007^227^ | Retrospective cohort 136,997 15 years | RA pts (n=34,250) | Several oral DMARDs, PNL | PNL (adjusted IRR, 2.94; 95% CI, 1.93 to 4.46, P<0.001) was associated with an increased incidence of septic arthritis when compared with those not receiving any DMARD. | Fair
*Michaud and Wolfe, 2006^244^ | Cross-sectional analysis from prospective cohort 7,243 Questionnaire in Dec 2003 related to previous 6 months | RA pts enrolled in the NDB study | PRED | Association of PRED treatment with visits to physician for sinus problems was OR,0.98; 95% CI, 0.86 to 1.11; P=0.776). | Fair
*Wolfe et al., 2007^228^ | Prospective cohort 17,598 Up to 3.5 years | RA pts in the NDB | PRED | Current treatment with PRED associated with hospitalization for interstitial lung disease (HR, 2.5; 95% CI, 1.5 to 4.1, P<0.001). Past treatment with PRED was also associated with hospitalization for interstitial lung disease (HR, 3.0; 95% CI, 1.0 to 8.9, P=0.044) | Fair

* New study added since last review.

AE = adverse event; BUD = budesonide; CI = confidence interval; DMARD = disease-modifying antirheumatic drugs; GI = gastrointestinal; mg = milligram; HR = hazard ratio; NDB = National Data Bank for Rheumatic Diseases; OR = odds ratio; PNL = prednisolone; PRED = prednisone; RA = rheumatoid arthritis; RCT = randomized controlled trial

Table 41 Overall tolerability in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Oral DMARDs
Cannon et al., 2004^229^ | Retrospective cohort 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | AE rates in LEF and LEF+MTX were lower than or similar to AE rates for MTX and other DMARDs | Fair
Emery et al., 2000^105^ | RCT 999 1 year with optional 2nd year | RA 4 months to 10 years | LEF, MTX | Frequency of SAEs similar between groups | Fair
Maetzel et al., 2000^230^ | Meta-analysis (RCT and observational) 159 studies MTX=2,875 SSZ=1,418 5 years | RA pt studies including withdrawal information | MTX, SSZ, HCQ (and gold) | Withdrawals due to toxicity for 5 years: MTX 35%, SSZ 52% Pts treated with SSZ were 1.68 times more likely to fail therapy due to toxicity than MTX (RR, 1.68; P<0.0001) | Fair
*Osiri et al., 2009^55^ | Systematic review and meta-analysis 6 studies 1,220 patients Mixed duration | Active RA | LEF, MTX, SSZ | Withdrawals due to adverse events were 10% (95%CI: 6–15%) greater with leflunomide than placebo. NNH: 10 (7 to 17) Adverse events and withdrawal rates simiar for LEF, SSZ, and MTX | Good
Smolen et al., 1999^107, 108^ | RCT 358 24 weeks | Active RA | LEF, SSZ | Withdrawal due to AEs 14% vs. 19% | Fair
Strand, et al., 1999^56, 104^ | RCT 482 12 months (1 year continuation) | RA for at least 6 months, MTX-naive | LEF, MTX | AEs constant over time for LEF and MTX 12 months: Higher discontinuation rate for LEF (22% vs. 10.4%, P=NR) | Fair
Oral DMARD Combinations
Boer et al., 1997^95^ COBRA study | RCT 155 56 weeks | Early RA, DMARD naive | PNL taper+MTX+SSZ vs. SSZ | Lower withdrawal rate due to AEs (2.6% vs. 7.6%, P=NR) | Fair
Capell et al., 2006^59^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Active RA | SSZ+MTX vs. SSZ or MTX | Similar withdrawal rate due to AEs | Fair
Dougados et al., 1999^57^ | RCT 209 (146) 52 weeks (5-year followup) | DMARD naive, early RA | SSZ +MTX vs. SSZ or MTX | Discontinuation rate due to AEs similar among groups AEs higher in SSZ+MTX vs. SSZ vs. MTX (91% vs. 75% vs. 75%, P=0.025) | Fair
*Goekoop-Ruiterman et al., 2005^100–102, 196^ BeSt study | RCT 508 12 months | Early RA | Sequential monotherapy (starting with MTX) vs. step-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. combination (MTX, SSZ, tapered high-dose PRED) vs. combination with INF (3 mg/kg – could be titrated to 10 mg/kg based on DAS) | No significant differences in serious AEs in all groups | Good
Haagsma et al., 1997^58^ | RCT 105 52 weeks | DMARD naive, early RA | SSZ+MTX vs. SSZ or MTX | No significant difference in number of withdrawals due to AEs | Fair
Korpela et al., 1999^98^ FIN-RACo study | RCT 199 24 months | Early RA | MTX+HCQ+SSZ+PNL vs. DMARD ± PNL | Frequency of serious AEs similar in both groups Discontinuation due to AEs similar in both groups | Fair
*Malysheva et al., 2008^233^ | Retrospective cohort 154 2–62 months | RA Pts | MTX vs. MTX +glucocorticoids vs. HCQ vs. HCQ+glucocorticoids | Use of GC significantly increased the time until withdrawal of DMARD therapy due to AE (18.6 ± 2.3 months; P<0.05) compared with no use of GC (12.5 ± 1.4 months) | Fair
O’Dell et al., 2006^231^ | Prospective cohort 119 48 weeks | Active RA, previous use of DMARDs | ETA +SSZ vs. ETA+HCQ | Similar discontinuation rates due to AEs | Fair
O’Dell et al., 2002^61^ | RCT 171 2 years | RA pts not previously treated with combination drugs | MTX+SSZ+HCQ vs. MTX+HCQ vs. MTX+SSZ | Similar withdrawal rate due to AEs across groups | Good
O’Dell et al., 1996^62^ | RCT 102 2 years | RA and poor response to at least 1 DMARD | MTX+SSZ+ HCQ vs. MTX vs. SSZ+HCQ | Similar withdrawal rate due to AEs across groups | Good
*Osiri et al., 2009^55^ | Systematic review and meta-analysis 6 studies 1,220 patients Mixed duration | Active RA | LEF+ MTX, MTX | Adverse events reported more frequently for LEF+ MTX than MTX. Withdrawal rates similar with LEF+MTX vs. MTX | Good
*Schipper et al., 2009^232^ | Systematic review 515 24 to 52 weeks | Ra pts with insufficient response to SSZ or MTX and SSZ naive | MTX+SSZ vs. MTX vs. SSZ | Pts naïve to MTZ or SSZ on combination therapy experienced significantly more nausea. Those on MTX+SSZ who previously failed SSZ had comparable tolerability | Fair
*Schipper et al., 2009^110^ | Nonrandomized inception cohort 230 52 weeks | RA pts that had failed SSZ treatment | SSZ+MTX vs. MTX switch | Rate of discontinuation significantly lower in MTX vs. SSZ+MTX group (P=0.01) Relative hazard to stop DMARD within 1 year in SSZ+MTX group vs. MTX group: 1.7 (95% CI, 1.11 to 2.46, P<0.01) | Fair
Svensson et al., 2005^65^ | Open-label RCT 250 2 years | Early RA | DMARD+PNL vs. DMARD | Similar number of discontinuations between groups | Fair
Svensson et al., 2003^318^ | Open-label RCT 245 2 years | Early RA | MTX+PRED SSZ+PRED | Lower withdrawal rate due to AEs or inefficacy for PRED+MTX group vs. PRED+SSZ group (11.5% vs. 33.3%, P=0.0005) | Fair

* New study added since last review.

AEs = adverse events; CI = confidence interval; DMARD = disease-modifying antirheumatic drug; GC = glucocorticoids; hydroxychloroquine; HR = hazard ratio; LEF = leflunomide; MTX = methotrexate; OR = odds ratio; PNL = prednisolone; PRED = prednisone; Pts = patients; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = relative risk; SAEs = serious adverse events; SSZ = sulfasalazine

Table 42 Cardiovascular and cerebrovascular events in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Naranjo et al., 2008^215^ | Cross-sectional 4,363 Clinician and patient recall | Sample of RA pts across 15 countries | MTX, LEF, SSZ | MTX, LEF, and SSZ associated with reduced risk for CV morbidity (HR, 0.85; 95% CI, 0.81 to 0.89; HR, 0.59; 95% CI, 0.43 to 0.79; HR, 0.92; 95% CI, 0.87 to 0.98; respectively). | Fair
*Nadareishvili et al., 2008^214^ | Nested case-control 269 cases among 7045 patients 8 years | RA pts in National Data Bank for Rheumatic Diseases | MTX | Association of treatment with ischemic stroke: MTX: OR,0.63; 95% CI, 0.32 to 1.26; P=0.191) | Fair
*Suissa et al, 2006^234^ | Retrospective cohort 107,908 14 months | RA pts in PharMetrics U.S. data | Traditional DMARDs | Traditional DMARD use associated with decreased acute MI: MTX: RR, 0.8; 95% CI, 0.60 to 1.08 LEF: RR, 0.28; 95% CI,0.12 to 0.64 | Fair
*van Halm et al., 2006^235^ | Case-control 613 Eligible diagnosis from 1953–2004 | Pts with RA treated in a single clinic in Netherlands | MTX, HCQ, SSZ, MTX+HCQ, MTX+SSZ, SSZ+HCQ, MTX+HCQ+SSZ | Cardiovascular events compared with no DMARD treatment: MTX OR:0.47 (95% CI, 0.07 to 3.23), SSZ: 0.31 (95% CI, 0.07 to 1.33), HCQ: 0.45 (95% CI, 0.10 to 2.04), MTX+ SSZ: 0.24 (95% CI, 0.07 to 0.85, P<0.05), MTX+HCQ: 0.54 (95% CI, 0.08 to 3.66), SSZ+ HCQ: 0.34 (95% CI, 0.05 to 2.16), MTX+SSZ+HCQ: 0.27 (95% CI, 0.07 to 0.99, P<0.05) | Fair

* New study added since last review

CV = cardiovascular; CI = confidence interval; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; GI = gastrointestinal; HCQ = hydroxychloroquine; HR = hazard ratio; INF = infliximab; LEF = leflunomide; MTX = methotrexate; OR = odds ratio; Pts = patients; RA = rheumatoid arthritis; RR = rate ratio; SSZ = sulfasalazine

Table 43 Hepatic events in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Cannon et al., 2004^229^ | Retrospective cohort 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | Hepatic event: LEF 4.1/1,000 PY, MTX 6.2/1,000 PY, Other 4.2/1,000 PY, LEF+MTX 4.6/1,000 PY | Fair
Suissa et al., 2004^236^ | 2 retrospective cohorts (claims data) 41,885 3 years | RA diagnosis | LEF, biologics, traditional DMARDs, MTX | Serious hepatic events compared with MTX: LEF rate ratio: 0.9 (95% CI, 0.2 to 4.9), traditional DMARD: 2.3 (95% CI, 0.8 to 6.5), biologic DMARD: 5.5 (95% CI, 1.2 to 24.6) | Fair

* New study added since last review.

CI = confidence interval; DMARD = disease-modifying antirheumatic drug; LEF = leflunomide; MTX = methotrexate; Pts = patients; PY = person years; RA = rheumatoid arthritis

Table 44 Infection in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Bernatsky et al., 2007^218^ | Nested case-control 23,733 Up to 23 years | RA pts registered in claims databases in Quebec | Oral DMARDs including: MTX, LEF, HCQ, SSZ | Relative risk for infections requiring hospitalization: MTX 1.10 (95% CI, 0.98 to 1.23); all other DMARDs (includes LEF, SSZ) 0.99 (95% CI, 0.84 to 1.16); Antimalarial (includes HCQ) 1.06 (95% CI, 0.92 to 1.22) | Fair
*Brassard et al., 2009^238^ | Retrospective cohort study 24,282 1980–2003 for cohort and 1992–2003 for TB incidence rates | RA pts from Quebec | Traditional DMARDs including MTX and LEF, corticosteroids | Rate ratio of TB associated with any DMARD use: 3.0 (95% CI, 1.6 to 5.8). | Fair
*Brassard et al., 2006^219^ | Retrospective cohort study 112,300 Up to 5 years | RA pts from the PharMetrics Patient-Centric database | Several oral DMARDs, biologic DMARDs, corticosteroids | Adjusted rate ratio of developing TB with use of traditional DMARDs: 1.2 (95% CI, 1.0 to 1.5). | Fair
Cannon et al., 2004^229^ | Retrospective cohort 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | Respiratory infection: LEF 20/1,000 PY, MTX 38.9/1,000 PY, Other 36.9/1,000 PY | Fair
Doran et al., 2002^220^ | Retrospective cohort 609 39 years | RA pts | Several oral DMARDs, corticosteroids | Compared with oral DMARDs, corticosteroids increased risk of hospitalized infection (HR, 1.56; 95% CI, 1.20 to 2.04) | Fair
*Greenberg et al., 2010^226^ CORRONA | Prospective cohort 7,971 15,047 patient years | Pts with RA enrolled in the Consortium of Rheumatology Researchers of North America (CORRONA) registry | MTX, oral DMARDs, anti-TNF agents, PRED | Adjusted incidence rate ratio (IRR) for infections: MTX (IRR, 1.30; 95% CI, 1.12 to 1.50, P<0.001) Adjusted incidence rate ratio (IRR) for opportunistic infections: MTX (IRR, 0.93; 95% CI, 0.54 to 1.60, P=0.781) | Fair
*Grijalva et al., 2010^240^ | Prospective cohort 28,906 3 years | Tennesee Medicaid-enrolled RA pts initiating DMARD use | MTX, LEF, SSZ, HCQ, biologic DMARDs, glucocorticoids | Compared with MTX; LEF, SSZ or HCQ did not increase risks of hospitalizations due to pneumonia or serious infections | Good
*Lacaille et al., 2008^221^ | Retrospective cohort 27,710 162,720 person years | Pts with RA from British Columbia, Canada | Oral DMARDs, corticosteroids | Adjusted rate ratio for serious infections: DMARDs+corticosteroids: 1.63 (95% CI, 1.5 to 1.77); DMARDs alone: 0.92 (95% CI, 0.85 to 1.0) | Fair
*McDonald et al., 2009^239^ | Retrospective cohort 20,357 7 years | Pts with RA in the Veterans Affairs health care system | Traditional DMARDs | No increased risk of infection with oral DMARDs; SSZ associated with a lower risk of herpes zoster infection (HR, 0.44; 95% CI, 0.21 to 0.91) | Fair
*Smitten et al., 2008^223^ | Retrospective cohort 24,530 26.6 months | Pts with RA from U.S. PharMetrics data | MTX, LEF, HCQ, SSZ | MTX and HCQ decreased risk of hospitalized infection (RR, 0.81; 95% CI, 0.70 to 0.93; RR, 0.74; 95% CI, 0.62 to 0.89; respectively). | Good
*Smitten et al., 2007^224^ | Retrospective cohort 12,272 (PM)38,621 (GPRD) 12.3 to 38.8 months | Pts with RA the PM database and UK GPRD | Corticosteroids, traditional DMARDs, biologic DMARDs | Risk of herpes zoster infection with traditional DMARDs alone (PM: OR,1.37; 95% CI, 1.18 to 1.59; GPRD, 1.27; 95% CI, 1.10 to 1.48) | Fair
Wolfe et al., 2006^237^ | Prospective cohort 16,788 3.5 years | RA diagnosis | PRED, LEF, SSZ, MTX, ETA, INF, ADA | Risk for hospitalization for pneumonia: PRED HR, 1.7 (95% CI, 1.5 to 2.1), LEF HR, 1.3 (95% CI, 1.0 to 1.5). No significant differences for SSZ, MTX | Fair

* New study added since last review.

ADA = adalimumab; AERS = adverse events reporting system; CI = confidence interval; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; GI = gastrointestinal; GPRD = General Practict Research Database; HCQ = hydroxychloroquine; HR = hazard ratio; INF = infliximab; LEF = leflunomide; MTX = methotrexate; N/A = not applicable; NR = not reported; OR = odds ratio; PM = PharMetrics; PNL = prednisolone; PRED = prednisone; Pts = patients; PY = person years; RA = rheumatoid arthritis; RR = rate ratio; SSZ = sulfasalazine; TB = tuberculosis

Table 45 Interstitial lung disease in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Suissa et al., 2006^217^ | Retrospective cohort (claims data) 62,734 5 years | RA diagnosis, on DMARD | MTX, LEF, biologics, traditional DMARDs | Risk of interstitial lung disease in LEF compared with other DMARDs: OR, 1.9 (95% CI, 1.1 to 3.6). No elevation noted in LEF pts with no history of MTX or no history of interstitial lung disease | Fair
*Wolfe et al., 2007^228^ | Prospective cohort 17,598 Up to 3.5 years | RA pts in the National Databank for Rheumatic Diseases | MTX, LEF, HCQ, SSZ | No significant association between current and past MTX, LEF, HCQ, and SSZ use and hospitalization for interstitial lung disease. | Fair

* New study added since last review.

CI =confidence interval; DMARD = disease-modifying antirheumatic drug; HCQ = hydroxychloroquine; LEF = leflunomide; MTX = methotrexate; OR = odds ratio; Pts = patients; RA = rheumatoid arthritis; SSZ = sulfasalazine

Table 46 Malignancies in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Baecklund et al., 2006^241^ | Retrospective cohort 756 30 years | RA pts with diagnosis of lymphoma | MTX, SSZ | No significant risk for lymphoma for MTX or SSZ | Good
Chakravarty et al., 2005^242^ | Retrospective cohort 15,789 (RA) 4 years | RA pts | PRED, LEF, MTX | PRED was associated with increased risk for nonmelanoma skin cancer PRED: HR 1.28 (95% CI, 1.05 to 1.55, P=0.014) | Fair

* New study added since last review.

CI = confidence interval; HR = hazard ratio; LEF = leflunomide; MTX = methotrexate; OR = odds ratio; PRED = prednisone; Pts = patients; RA = rheumatoid arthritis; SSZ = sulfasalazine

Table 47 Other specific adverse events in patients with rheumatoid arthritis treated with oral DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Edwards et al., 2007^227^ | Retrospective case-control 136,997 15 years | RA pts (n=34,250) | Several oral DMARDs, including MTX, LEF, HCQ, SSZ | Incident rate of septic arthritis in RA pts receiving DMARDs: 2.14 (95% CI, 1.64 to 2.78; P<.001) times greater than in patients with RA not receiving DMARDs. | Fair
*Fuerst et al., 2006^243^ | Prospective cohort 201 6 weeks+ | Pts with RA or PsA (n=8) undergoing elective orthopedic surgery | MTX, LEF, both in combination with corticosteroids | LEF+corticosteroids significantly increased the risk for wound healing complications compared with MTX+corticosteroids (40.6% vs. 13.6%, P=0.01). | Fair
*Karstila et al., 2010^245^ | RCT 195 Up to 11 years | Pts with new onset RA naïve to DMARD treatment | Combination therapy with SSZ, MTX, HCQ, or PRED vs. monotherapy with SSZ with or without PRED | Culmulative incidence of abnormal renal findings in combination vs. monotherapy groups were comparable | Good
*Martinez Lopez et al., 2009^246^ | Systematic review 6 studies 366 patients | Studies addressing pregnancy, fertility, and lactation | MTX | Evidence is insufficient for conclusions | Fair
*Michaud and Wolfe, 2006^244^ | Cross-sectional analysis from prospective cohort 7,243 Questionnaire in Dec 2003 related to previous 6 months | RA pts enrolled in the NDB study | MTX, HCQ, LEF, SSZ | Association (OR) of treatment with visits to physician for sinus problems was; - MTX: 1.06 (95% CI, 0.93 to 1.20; P=0.371);; - HCQ: 1.08 (95% CI, 0.93 to 1.25; P=0.313); - LEF: 0.84 (95% CI, 0.70 to 0.99; P=0.041); - SSZ: 0.68 (95% CI, 0.51 to 0.90; P=0.007) | Fair

* New study added since last review.

DMARD, = disease-modifying antirheumatic drug; HCQ = hydroxychloroquine; LEF = leflunomide; MTX = methotrexate; OR = odds ratio; Pts = patients; RA = rheumatoid arthritis; SSZ = sulfasalazine

Table 48 Overall tolerability: randomized controlled trials included in withdrawal quantitative analyses

Author, Year | Duration (weeks) | Comparison | N | Number of Withdrawals by Reason
Author, Year | Duration (weeks) | Comparison | N | Overall | Tolerability | Efficacy
Kremer, 2005^114^ | 52 | Abatacept | 115 | 26^‡^ | 6^‡^ | 13^‡^
Kremer, 2005^114^ | 52 | Placebo | 119 | 48 | 11 | 30
Kremer, 2006^116^ | 52 | Abatacept | 433 | 48^‡^ | 18^‡^ | 13^‡^
Kremer, 2006^116^ | 52 | Placebo | 219 | 57 | 4 | 40
Schiff, 2008^66^ | 26 | Abatacept | 156 | 9^‡^ | 2^‡^ | 2^‡^
Schiff, 2008^66^ | 26 | Placebo | 55 | 3 | 1 | 1
Weinblatt, 2006^258^ | 52 | Abatacept | 959 | 123^‡^ | 52^‡^ | NR
Weinblatt, 2006^258^ | 52 | Placebo | 482 | 87 | 20 | NR
*Westhovens, 2009^89^ | 52 | Abatacept | 256 | 24 | 9 | 0
*Westhovens, 2009^89^ | 52 | Placebo | 253 | 26 | 11 | 8
Breedveld, 2006^76^ | 104 | Adalimumab | 268 | 65^§^ | 32 | 13
Breedveld, 2006^76^ | 104 | Placebo | 257 | 112 | 19 | 46
Furst, 2003^121^ | 24 | Adalimumab | 318 | 28^‡^ | 9^‡^ | 5^‡^
Furst, 2003^121^ | 24 | Placebo | 318 | 30 | 8 | 14
Kim, 2007^127^ | 18 | Adalimumab | 65 | 6^‡^ | 4^‡^ | NR
Kim, 2007^127^ | 18 | Placebo | 63 | 4 | 4 | NR
Keystone, 2004^120^ | 52 | Adalimumab 20 mg | 212 | 44^‡^ | 16^‡^ | 6^‡^
Keystone, 2004^120^ | 52 | Adalimumab 40 mg | 207 | 48^‡^ | 26^‡^ | 6^‡^
Keystone, 2004^120^ | 52 | Placebo | 200 | 60 | 13 | 23
Miyasaka, 2008^125^ | 24 | Adalimumab | 91 | 16^‡^ | 12^‡^ | NR
Miyasaka, 2008^125^ | 24 | Placebo | 87 | 7 | 4 | NR
Van de putte, 2003^119^ | 12 | Adalimumab 20 mg | 72 | 10^‡^ | 0^‡^ | 2^‡^
Van de putte, 2003^119^ | 12 | Adalimumab 40 mg | 70 | 12^‡^ | 3^‡^ | 0^‡^
Van de putte, 2003^119^ | 12 | Placebo | 70 | 24 | 1 | 1
Van de putte, 2004^122^ | 26 | Adalimumab 20 mg | 112 | 33^‡^ | 3^‡^ | 27^‡^
Van de putte, 2004^122^ | 26 | Adalimumab 40 mg biweekly | 113 | 32^‡^ | 6^‡^ | 20^‡^
Van de putte, 2004^122^ | 26 | Adalimumab 40 mg weekly | 103 | 15^‡^ | 3^‡^ | 10^‡^
Van de putte, 2004^122^ | 26 | Placebo | 110 | 62 | 1 | 56
Weinblatt, 2003^123^ | 16 | Adalimumab | 67 | NR | 0^‡^ | NR
Weinblatt, 2003^123^ | 16 | Placebo | 62 | NR | 2^‡^ | NR
Breshnihan, 1998^128^ | 24 | Anakinra 75 mg/day | 116 | 22^‡^ | 7^‡^ | 14^‡^
Breshnihan, 1998^128^ | 24 | Anakinra 150 mg/day | 116 | 28^‡^ | 11^‡^ | 11^‡^
Breshnihan, 1998^128^ | 24 | Placebo | 121 | 32 | 5 | 24
Cohen, 2002^131^ | 24 | Anakinra 1 mg/kg/day | 59 | 13^‡^ | 8^‡^ | 4^‡^
Cohen, 2002^131^ | 24 | Anakinra 2 mg/kg/day | 72 | 19^‡^ | 11^‡^ | 4^‡^
Cohen, 2002^131^ | 24 | Placebo | 74 | 14 | 3 | 5
Cohen, 2004^133^ | 24 | Anakinra | 250 | NR | 14^‡^ | NR
Cohen, 2004^133^ | 24 | Placebo | 251 | NR | 13^‡^ | NR
Fleishmann, 2003^259^ | 24 | Anakinra | 1116 | 241^‡^ | 149^‡^ | NR
Fleishmann, 2003^259^ | 24 | Placebo | 283 | 53^‡^ | 26^‡^ | NR
Fleishmann, 2009^165^ | 24 | Certolizumab | 111 | 35^‡^ | 5^‡^ | 24^†^
Fleishmann, 2009^165^ | 24 | Placebo | 109 | 81 | 2 | 75
Keystone, 2008^168^ | 52 | Certolizumab | 390 | 116^‡^ | 22^‡^ | 68^‡^
Keystone, 2008^168^ | 52 | Placebo | 199 | 156 | 3 | 125
Smolen, 2009^167^ | 24 | Certolizumab | 246 | 65^‡^ | 6^‡^ | 53^‡^
Smolen, 2009^167^ | 24 | Placebo | 127 | 110 | 2 | 107
*Emery, 2008^90^ | 52 | Etanercept | 274 | 53^‡^ | 28^‡^ | 9^‡^
*Emery, 2008^90^ | 52 | Placebo | 268 | 79 | 34 | 24
*Emery, 2010^91^ | 52 | Etanercept | 90 | 16^‡^ | 7^‡^ | 1^‡^
*Emery, 2010^91^ | 52 | Placebo | 99 | 23 | 9 | 7
Klareskog, 2004^86^ | 52 | Etanercept | 231 | 38^‡^ | 24^‡^ | 6^‡^
Klareskog, 2004^86^ | 52 | Placebo | 228 | 69 | 32 | 21
Moreland, 1997^144^ | 12 | Etanercept | 44 | 3^‡^ | NR | 2^‡^
Moreland, 1997^144^ | 12 | Placebo | 44 | 21 | NR | 19
Moreland, 1999^140^ | 26 | Etanercept | 78 | 19^§^ | 2^†^ | 12^§^
Moreland, 1999^140^ | 26 | Placebo | 80 | 54 | 3 | 42
Weinblatt, 1999^142^ | 24 | Etanercept | 59 | 2^‡^ | 2^‡^ | 0^‡^
Weinblatt, 1999^142^ | 24 | Placebo | 30 | 6 | 1 | 4
*Emery, 2009^92^ | 24 | Golimumab | 158 | 8^‡^ | 5^‡^ | 0^‡^
*Emery, 2009^92^ | 24 | Placebo | 160 | 10 | 1 | 1
*Kay, 2008^166^ | 16 | Golimumab | 35 | 4^‡^ | 2^‡^ | 2^‡^
*Kay, 2008^166^ | 16 | Placebo | 35 | 6 | 3 | 3
*Keystone, 2009^169^ | 16 | Golimumab | 89 | 2^‡^ | 2^‡^ | 0^‡^
*Keystone, 2009^169^ | 16 | Placebo | 133 | 6 | 4 | 0
Abe, 2006^153^ | 14 | Infliximab 3 mg/kg | 49 | NR | 1^‡^ | NR
Abe, 2006^153^ | 14 | Infliximab 10 mg/kg | 51 | NR | 4^‡^ | NR
Abe, 2006^153^ | 14 | Placebo | 47 | NR | 1 | NR
Lipsky, 2000^151^ | 54 | Infliximab 3 mg/kg every 8 wks | 86 | 23^‡^ | 5^‡^ | 17^‡^
Lipsky, 2000^151^ | 54 | Infliximab 3 mg/kg every 4 wks | 86 | 20^‡^ | 9^‡^ | 19^‡^
Lipsky, 2000^151^ | 54 | Infliximab 10 mg/kg every 8 wks | 87 | 12^‡^ | 4^‡^ | 6^‡^
Lipsky, 2000^151^ | 54 | Infliximab 10 mg/kg every 4 wks | 81 | 16^‡^ | 8^‡^ | 7^‡^
Lipsky, 2000^151^ | 54 | Placebo | 88 | 44 | 7 | 32
Schiff, 2008^66^ | 26 | Infliximab | 165 | 13^‡^ | 8^‡^ | 2^‡^
Schiff, 2008^66^ | 26 | Placebo | 55 | 2 | 1 | 1
St. Clair, 2004^82^ | 54 | Infliximab 3 mg/kg | 373 | 66^‡^ | 34^‡^ | 7^‡^
St. Clair, 2004^82^ | 54 | Infliximab 6 mg/kg | 375 | 75^‡^ | 35^‡^ | 12^‡^
St. Clair, 2004^82^ | 54 | Placebo | 298 | 60 | 9 | 27
Westhovens, 2006^155^ | 22 | Infliximab 3 mg/kg | 360 | 26^‡^ | 18^‡^ | NR
Westhovens, 2006^155^ | 22 | Infliximab 10 mg/kg | 361 | 32^‡^ | 20^‡^ | NR
Westhovens, 2006^155^ | 22 | Placebo | 363 | 23 | 8 | NR
Zhang, 2006^156^ | 18 | Infliximab | 87 | 9^‡^ | 6^‡^ | NR
Zhang, 2006^156^ | 18 | Placebo | 86 | 15 | 4 | NR
Cohen, 2006^158^ | 24 | Rituximab | 309 | 55^‡^ | 2^‡^ | NR
Cohen, 2006^158^ | 24 | Placebo | 208 | 96 | 8 | NR
Edwards, 2004^84^ | 24 | Rituximab | 40 | 1^‡^ | 1^‡^ | 1^‡^
Edwards, 2004^84^ | 24 | Placebo | 40 | 3 | 0 | 2
Emery, 2006^157^ | 24 | Rituximab | 192 | 27^‡^ | 6^‡^ | 16^‡^
Emery, 2006^157^ | 24 | Placebo | 149 | 52 | 0 | 46
*Emery, 2010^162^ | 24 | Rituximab | 340 | 12^‡^ | 5^‡^ | 1^‡^
*Emery, 2010^162^ | 24 | Placebo | 172 | 13 | 2 | 7
*Emery, 2008^175^ | 24 | Tocilizumab 4 mg/kg | 163 | 24^‡^ | 10^‡^ | 6^‡^
*Emery, 2008^175^ | 24 | Tocilizumab 8 mg/kg | 175 | 23^‡^ | 11^‡^ | 4^‡^
*Emery, 2008^175^ | 24 | Placebo | 160 | 30 | 10 | 19
*Genovese, 2008^176^ | 16 | Tocilizumab | 805 | 53^‡^ | 32^‡^ | NR
*Genovese, 2008^176^ | 16 | Placebo | 415 | 43 | 8 | NR
*Kremer, 2010^178^ | 24 | Tocilizumab | 797 | NR | 61^‡^ | 3^‡^
*Kremer, 2010^178^ | 24 | Placebo | 393 | NR | 11 | 12
Smolen, 2008^164^ | 24 | Tocilizumab 4 mg/kg | 214 | 25^‡^ | 14^‡^ | 2^‡^
Smolen, 2008^164^ | 24 | Tocilizumab 8 mg/kg | 205 | 13^‡^ | 12^‡^ | 0^‡^
Smolen, 2008^164^ | 24 | Placebo | 204 | 12 | 6 | 3

* New studies since last review.

Kg = kilogram; mg = milligram; NR = not reported; NS = not significant

† P=NS

‡ P=NR

§ P<0.01

Table 49 Overall tolerability: discontinuation data not otherwise covered by quantitative analyses

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Alonoso-Ruiz et al. 2008^126^ | Systematic review and meta-analysis 13 trials 7,087 patients At least 6 months | Pts with RA | ADA ETA, INF | Relative risk of withdrawal due to adverse event compared with control group: ADA (RR, 1.4; 95% CI, 1.0 to 2.0); ETA (RR, 0.7; 95% CI, 0.5 to 0.9); INF (RR, 2.0; 95% CI, 1.3 to 3.1) | Good
*Duclos et al., 2006^248^ | Retrospective cohort 770 7 years | Pts with inflammatory rheumatism (mostly RA) that received an anti-TNF agent | ADA, ETA, INF | Trend towards better tolerability with ETA and ADA compared with INF (P=0.06) | Fair
Flendrie et al., 2003^247^ | Retrospective cohort study 230 NR | Pts with RA initiating therapy with biologic DMARDs | ADA, ETA, INF | No significant differences in discontinuation rates among anti-TNF drugs | Fair
*Hetland et al., 2010^73^ DANBIO | Prospective cohort 2,326 48 months | Pts with RA initiating therapy with biologic DMARDs | ADA, ETA, INF | Hazard ratio for drug withdrawal: INF vs. ETA HR 1.98 (95% CI, 1.63 to 2.40); INF vs. ADA 1.35 (95% CI, 1.15 to 1.58); ADA vs. ETA 1.47 (95% CI, 1.20 to 1.80) | Fair
*Hjardem et al., 2007^249^ | Retrospective cohort 235 Varied | RA pts who had received 2+ biologics (INF, ETA, or ADA only) | ADA, ETA, INF | Similar reasons for switching treatments: Lack of efficacy; ADA 54%; ETA 44%; INF 45%. Adverse events: ADA 21%; ETA 22%; INF 34% | Fair
*Hyrich et al., 2007^250^ | Prospective cohort 6,739 Minimum 6 months | Pts with RA in the British Society for Rheumatology Biologics Register | ADA, ETA, INF | Differences in reason for discontinuation (P=NR): Lack of efficacy; ADA 6.7%; ETA 4.8%; INF 10%. Adverse events: ADA 2.9%; ETA 2.6%; INF 8.4% | Fair
*Karanikolas et al., 2008^93^ | Prospective cohort 128 48 weeks | Pts with RA with inadequate response to traditional DMARD | MTX+ ANK LEF+ANK | No statistically significant differences in number of withdrawals due to adverse events | Fair
Kristensen et al., 2006^251^ | Prospective cohort 1,161 Up to 6 years | Pts with RA in southern Sweden | ETA, ETA+MTX, INF, INF+MTX, other DMARDs | Early discontinuation threefold higher for INF than for ETA (P<.001). Addition of MTX improved treatment continuation rates (P<0.01). | Fair
*Marchesoni et al., 2009^252^ LOHREN | Prospective cohort 1,064 23.32 months | Pts with RA treated with at least one dose of an anti-TNF agent | ADA, ETA, INF | Risk of discontinuation due to adverse events higher for ADA than ETA | Fair
*Mertens and Singh, 2009^134^ | Meta-analysis 2,876 5 trials | Pts with RA included in placebo-controlled RCTs | ANK | No difference in total number of withdrawals, adverse events, or serious adverse events for ANK vs. placebo | Fair
*Singh et al., 2009^27, 180^ | Review of Cochrane reviews and network meta-analysis | Pts with RA | ABA, ADA, ANK, ETA, INF, RTX | ADA, ANK, and INF more likely to have withdrawals due to adverse events vs. ETA: (OR, 1.89; 95% CI, 1.18 to 3.04; OR, 2.05; 95% CI, 1.27 to 3.29; OR, 2.70; 95% CI, 1.43 to 5.26, respectively) | Good
*Singh et al., 2010^177^ | Systematic review and meta-analysis 8 studies 3,334 patients 8 to 52 weeks | Pts with RA | TCZ | Fewer overall trial withdrawals with TCZ than placebo; no statistically significant diffence in withdrawals due to adverse events | Fair
*Singh et al., 2010^210^ | Systematic review and meta-analysis 4 studies 1,231 patients 20 to 52 weeks | Pts with RA | GOL+MTX, MTX | Fewer overall withdrawals for GOL+MTX than MTX alone | Good
*Weinblatt et al., 2007^80^ | RCT 121 1 year (LTE: 2 years) | Pts with active RA | ETA, ABA+ETA | Discontinuation due to adverse events occurred more in ABA+ETA group (11.8%) vs. ETA group (2.8%). | Good
Zink et al., 2005^88^ | Retrospective cohort study 1,523 1 year | Pts with RA who had a change in treatment regimen | ANK, ETA, INF, LEF | Significantly higher overall discontinuation rates for ANK than ETA and INF after 12 months; no differences in discontinuation rates due to adverse events | Good

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; ANK = anakinra; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; GOL = golimumab; INF = infliximab; LEF = leflunomide; LOHREN = Italian Lombardi Rheumatology Network; MTX = methotrexate; NR = not reported; Pts = patients; RA = rheumatoid arthritis; RCT = randomized controlled trial; RTX = rituximab; TCZ = tocilizumab; TNF = tumor necrosis factor

Table 50 Comparative harms in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Biologic DMARDs Overall Tolerability
*Alonoso-Ruiz et al., 2008^126^ | Systematic review and meta-analysis 13 trials 7,087 patients at least 6 months | Pts with RA | ADA ETA, INF | Relative risk of serious adverse events compared with control group: ADA (RR, 1.0; 95% CI, 0.7 to .4); ETA (RR, 1.0; 95% CI, 0.5 to 1.6), INF (RR, 1.4; 95% CI, 1.0 to 2.0) | Good
Bathon et al., 2000^77, 188, 189^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Early, aggressive RA; MTX-naive | ETA, MTX | Significantly more patients on MTX than on ETA had nausea (29% vs. 15%; P<0.05) or mouth ulcers (14% vs. 5%; P<0.05) | Fair
Breedveld et al., 2006^76^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive | ADA, MTX, ADA+MTX | No statistically significant differences in adverse events | Fair
*Burmester et al., 2007^257^ ReACT trial | Prospective cohort 6,610 12 weeks | Pts with RA with treatment failure to at least one traditional DMARD | ADA, ADA+DMARDs | Serious adverse events occurred in 7.3% of pts treated with ADA vs. 5.3% treated with ADA+DMARDs | Fair
*Combe et al., 2009^145^ | RCT 260 2 years | Pts with active RA despite treatment with sulfasalazine | ETA, SSZ, ETA+SSZ | Noninfectious serious adverse events were significantly greater in patients receiving ETA (20.8% for the combination and 20.4% for ETA alone) compared with 4% for patients receiving SSZ (P<0.01) | Fair
Edwards et al., 2004^84^ | RCT 161 24 weeks | Active RA despite MTX treatment | RTX, MTX, RTX+MTX, RTX+CYP | No significant differences in adverse events | Fair
*Emery et al., 2008^175^ RADIATE study | RCT 499 24 weeks | Pts with active RA resistant to 1 or more TNF-alpha antagonist agents | MTX, TCZ +MTX | The overall occurrence of adverse events was similar among groups. | Fair
*Emery et al., 2008^90^ COMET trial | RCT 542 52 weeks | Early, moderate to severe RA; MTX-naive | MTX, ETA+MTX | Serious adverse events were similar among groups | Fair
*Emery et al., 2009^92^ | RCT 637 24 weeks | Pts with RA; MTX-naive | MTX, GOL, GOL+ MTX | More adverse events occurred in the GOL+MTX and MTX monotherapy group compared with GOL monotherapy (P=NR) | Fair
Feltelius et al., 2005^260^ | Case series 1,073 2 years | Pts with RA initiating ETA therapy | ETA | Incidence of serious adverse events remained constant over time | Fair
*Fernandez-Nebro et al., 2007^70^ | Prospective cohort 161 6 years | RA pts with no response to DMARDs, including MTX | ADA, ETA, INF | No difference in adverse events among groups | Fair
*Fleischmann et al., 2009^165^ FAST4WARD | RCT 220 24 weeks | Pts with RA treatment resistant to at least one DMARD | CTZ | Overall, adverse events occurred in 75.4% of pts treated with CTZ and 57.8% of placebo pts | Fair
Fleischmann et al., 2003^259^ | RCT 1,414 6 months | Pts with active RA despite MTX treatment | ANK | No statistically significant differences in adverse events (except infusion reactions) | Fair
Fleischmann et al., 2006^319^ | Open-label extension of RCT 1,346 Up to 3 years | Pts with active RA despite MTX treatment | ANK | Incidence of serious adverse events remained constant over time | Fair
Furst et al., 2003^121^ STAR study | RCT 636 6 months | Pts with active RA despite MTX treatment | ADA | No statistically significant differences in adverse events | Fair
Geborek et al., 2002^67^ | Nonrandomized, open-label trial 369 12 months | Population-based; active RA; had failed at least 2 DMARDs | ETA, LEF, INF | No statistically significant differences in adverse events | Fair
Genovese et al., 2002^188^ | Open-label extension of RCT 632 2 years | Pts with early, aggressive RA; MTX-naive | ETA | Incidence of serious adverse events remained constant over time | Fair
Genovese et al., 2004^79^ | RCT 242 24 weeks | Inadequate control of disease with MTX | ETA, ETA+AKA | Significantly higher rates of serious adverse events in combination group | Fair
Genovese et al., 2005^189^ | Uncontrolled extension of RCT 369 5 years | Pts with early, aggressive RA; MTX-naive | ETA | Rates of serious adverse events did not increase with long-term exposure | Fair
*Karanikolas et al., 2008^93^ | Prospective cohort 128 48 weeks | Pts with RA with inadequate response to traditional DMARD | MTX+ANK, LEF+ANK | No statistically significant differences in adverse events | Fair
*Kay et al., 2008^166^ | RCT 172 52 weeks | Pts with active RA despite treatment with MTX | MTX, GOL+MTX, | Serious adverse events occurred in 9% of pts treated with GOL vs. 6% in pts treated with MTX alone | Fair
*Keystone et al., 2004^120^ | RCT 619 52 weeks | Pts with active RA on MTX therapy | MTX, ADA+MTX | Serious adverse events occurred more frequently in ADA pts (3.8%) vs. MTX pts (0.5%; P≤0.02) | Fair
*Kim et al., 2007^127^ | RCT 128 24 weeks | Korean pts with RA with inadequate response to MTX | ADA+MTX, MTX | No statistically significant differences in adverse events | Fair
Klareskog et al., 2004^86, 136, 138^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 2 DMARDs | ETA, MTX, ETA+MTX | No statistically significant differences in adverse events | Good
*Kremer et al., 2011^178^ | RCT 1,196 12 months | Pts with RA with inadequate response to MTX | TCZ+MTX, MTX | Rate of serious adverse events were not statistically significantly different between groups | Fair
Langer et al., 2003^320^ | Postmarketing surveillance 454 6 months | Pts with RA, initiating AKA treatment | AKA | Rate of adverse events was generally similar to those reported in efficacy trials | Fair
*Leombruno et al., 2009^255^ | Meta-analysis 18 trials 8,808 patients Average 0.8 years | RA pts on anti-TNF therapy | ADA, ETA, INF | Anti-TNF treatment did not increase death (OR, 1.39; 95% CI, 0.74 to 2.62) or serious adverse events (OR, 1.11; 95% CI, 0.94 to 1.32) | Fair
Maini et al., 2004^149^ | Open-label extension of RCT 259 2 years | Pts with active RA despite MTX treatment | INF | Incidence of serious adverse events remained constant over time | Fair
*Martin Du Pan et al., 2009^253^ | Retrospective cohort 2,364 9 years | Pts with RA in the Swiss Clinical Quality Management for Rheumatoid Arthritis (SCQM-RA) registry treated with an anti-TNF agent | ADA, ETA, INF | Increased overall risk for adverse events in INF vs. ETA and ADA (HR, 1.4; 99% CI, 1.00–1.96) | Fair
Moreland et al., 2006^261^ | Open-label extension of clinical trials 714 | Pts treated with ETA | ETA | Incidence of serious adverse events remained constant over time | Fair
*Nishimoto et al., 2009^173^ SATORI | RCT 127 24 weeks | Pts with active RA despite MTX treatment | TCZ, MTX | Adverse events occurred in 91.8% of pts treated with TCZ vs. 71.9% of those treated with MTX | Fair
Nuki et al., 2002^129^ | Uncontrolled extension of RCT 309 19 months | Pts with active RA despite MTX treatment | AKA | Incidence of serious adverse events remained constant over time | Fair
O’Dell et al., 2006^231^ | Nonrandomized, open-label trial 119 | Pts with active RA despite treatment with SSZ, HCQ, or gold | ETA+SSZ ETA+HCQ ETA+gold | No differences in adverse event rates among 3 treatment groups | Fair
*Russell et al., 2007^116, 254^ AIM | RCT 652 12 months | Pts with RA despite treatment with MTX | ABA, ABA+MTX | Incidence of serious adverse events similar between groups | Good
*Schiff et al., 2008^66^ | RCT 431 1 year | Pts with RA despite treatment with MTX, anti-TNF therapy naive | ABA +MTX, INF +MTX, MTX | The occurrence of serious adverse events was lower in those treated with ABA (9.6%) vs. INF (18.2%). | Fair
Schiff et al., 2006^298^ | Retrospective data analysis of clinical trials; postmarketing surveillance 10,050 12,506 pt years | Pts treated with ADA | ADA | Incidence of serious adverse events remained constant over time | Fair
*Singh et al., 2010^177^ | Systematic review and meta-analysis 8 studies 3,334 patients 8 to 52 weeks | Pts with RA | TCZ | Occurrence of adverse event in TCZ group compared with placebo (74% vs. 65%); RR, 1.17; 95% CI, 0.83 to 1.64 | Fair
*Singh et al., 2010^210^ | Systematic review and meta-analysis 4 studies 1,231 patients 20 to 52 weeks | Pts with RA | GOL+MTX, MTX | No difference in occurrence of adverse events in GOL+MTX vs. MTX (RR, 1.1; 95% Cl, 0.9 to 1.2; P=0.44). No differences in GOL vs. placebo for serious adverse events | Good
*Smolen et al., 2008^164^ OPTION study | RCT 623 32 weeks | Pts with RA that failed treatment with MTX | MTX, TCZ+MTX | Adverse events occurred more frequently in pts treated with TCZ (71%) vs. MTX monotherapy (63%) | Fair
*Smolen et al., 2009^167^ RAPID 2 study | RCT 619 24 weeks | Pts with RA with prior MTX use for ≥6 months | MTX, CTZ+MTX | Serious adverse events occurred more frequently in CTZ pts vs. pts treated with MTX monotherapy | Fair
*Smolen et al., 2009^170^ | RCT 461 24 weeks | Pts with RA treated with at least one dose of an TNF inhibitor | GOL | No statistically significant differences in adverse events | Fair
Van Riel et al., 2006^87^ | Open-label RCT 315 16 weeks | Inadequate control of disease with MTX | ETA, ETA+MTX | No statistically significant differences in adverse events | Fair
Weinblatt et al., 2006^258^ ASSURE study | RCT 1,456 1 year | Pts with active RA despite background biologic or synthetic DMARD treatment | ABA | Higher incidence of serious adverse events in pts on ABA and a biologic background DMARD | Fair
Weinblatt et al., 2006^124^ | Uncontrolled extension of RCT 162 3.4 years | Pts with active RA despite MTX treatment | ADA | Incidence of serious adverse events remained constant over time | Fair
Westhovens et al., 2006^155^ START study | RCT 1,084 22 weeks | Pts with active RA despite MTX treatment | INF+MTX, MTX | No statistically significant differences in adverse events, except infection (higher in 10 mg/kg) | Good
*Westhovens et al., 2009^89^ | RCT 509 1 year | RA pts naïve to MTX | ABA+ MTX, MTX | No statistically significant differences in adverse events | Fair
*Wiens et al., 2009^256^ | Meta-analysis 2,385 8 weeks to 3 years | Pts with RA with or without concomitant MTX | ETA, MTX | No statistically significant differences in withdrawals due to adverse events, serious adverse events, serious infections, malignancies, or deaths. | Fair
*Wiens et al., 2010^183^ | Meta-analysis 21 studies 6,503 patients 8 weeks to 3 years | Pts with RA with or without concomitant MTX | ADA, ETA, INF | Similar incidence of serious adverse events for ADA, ETA, and INF compared with placebo | Fair
*Zhang et al., 2006^156^ | RCT 173 18 weeks | Pts with active RA despite treatment with MTX | MTX, INF+MTX | Rate of adverse events similar between groups | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; AERS = adverse event reporting system; ANK = anakinra; CTZ = certolizumab; CYP = cyclophosphamide; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; GOL = golimumab; HCQ = hydroxychloroquine; INF = infliximab; IR = incidence rate; IRR = incidence rate ratio; LEF = leflunomide; MTX = methotrexate; NA = not applicable; NR = not reported; OR = odds ratio; Pts = patients; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = rate ratio; RTX = rituximab; SSZ = sulfasalazine; TCZ = tocilizumab; TNF = tumor necrosis factor

Table 51 Cardiovascular and cerebrovascular events in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Curtis et al., 2007^263^ | Retrospective cohort study 2,121 5 years | Pts with RA (Also Crohn’s disease but excluded here) | ETA, INF | Cumulative incidence of heart failure among pts treated with ETA or INF vs. those not: 4.4 cases per 1,000 persons and 1.0 case per 1,000 persons in the unexposed group (RR, 4.3; P=NS). | Fair
*Dixon et al., 2007^267^ BSRBR | Prospective cohort 10,755 1.66 years median followup | Pts with RA in the British Society for Rheumatology Biologics Register (BSRBR) | ADA, ETA, INF, oral DMARDs | IRR, of MI among anti-TNF users compared with oral DMARDs:1.44 (95% CI, 0.56 to 3.67) | Good
Jacobsson et al., 2005^266^ | Retrospective cohort study 983 NR | Pts with RA in daily clinical care in Sweden | ETA, INF | Pts on anti-TNF treatment had a lower rate of cardiovascular events than pts on traditional RA therapy | Fair
*Listing et al., 2008^264^ | Prospective cohort 4,248 5 years | Pts with RA enrolled in the RABBIT German biologics register | ADA, ETA, INF, oral DMARDs | HR for incident HF among those using anti-TNFs vs. conventional DMARDs: 1.66, (95% CI, 0.67 to 4.10;P=0.28); HR for worsening HF among prevalent cases: 1.18, (95% CI, 0.30 to 4.73;P=0.81) | Good
*Nadareishvili et al., 2008^214^ | Nested case-control 269 cases among 7045 patients 8 years | RA pts in National Data Bank for Rheumatic Diseases | ADA, ETA, INF | Association of treatment with ischemic stroke: Anti-TNF: OR, 0.79; 95% CI, 0.34 to 1.82; P=0.584) | Fair
*Naranjo et al., 2008^215^ | Cross-sectional 4,363 Clinician and patient recall | Sample of RA pts across 15 countries | TNF-alpha antagonists (not specified) | Anti-TNF agents associated with reduced risk for CV morbidity (HR, 0.64; 95% CI, 0.49 to 0.83). | Fair
Kwon et al., 2003^321^ | Database analysis AERS 47 cases of CHF NA, AERS data | Pts on ETA or INF therapy | ETA, INF | Most pts with CHF did not have preexisting conditions | Fair
*Setoguchi et al., 2008^265^ | Retrospective cohort 5,593 10 years | Medicare pts with RA from 2 states | ADA, ETA, INF, MTX | Effect of anti-TNFs compared with MTX on heart failure and/or death; HR, 1.70; 95% CI, 1.07 to 2.69 | Good
*Solomon et al., 2006^216^ | Case-control study 3,501 24 months | Pennsylvania Medicare enrollees with RA | Biologic DMARDs | No statistically significant association between use of biologic DMARDs and cardiovascular events | Fair
*Suissa et al, 2006^234^ | Prospective cohort 107,908 14 months | RA pts in U.S. PharMetrics data | ADA, ETA, INF | Biologic DMARD use slightly associated with acute MI (RR, 1.30; 95% CI, 0.92 to 1.83) | Fair
Wolfe et al., 2004^262^ | Retrospective cohort study 13,171 2 years | Pts with RA in daily clinical care in U.S. | ADA, ETA, INF | Pts on anti-TNF treatment had a lower rate of CHF than pts on traditional RA therapy | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; AERS = adverse event reporting system; ANK = anakinra; CHF = congestive heart failure; CV = cardiovascular; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; HF = heart failure; HR = hazard ratio; INF = infliximab; IR = incidence rate; IRR = incidence rate ratio; LEF = leflunomide; MI = myocardial infarction; MTX = methotrexate; NA = not applicable; OR = odds ratio; Pts = patients; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = rate ratio; TCZ = tocilizumab; TNF = tumor necrosis factor; vs. = versus

Table 52 Infections in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Alonoso-Ruiz et al. 2008^126^ | Meta-analysis 13 trials 7,087 patients St least 6 months | Pts with RA | ADA ETA, INF | Relative risk of infections compared with control group: ADA (RR, 1.1; 95% CI, 0.9 to 1,2); ETA (RR, 1.0; 95% CI, 0.9 to 1.0); INF (RR, 1.2; 95% CI, 1.1 to 1.3) | Good
Askling et al., 2005^281^ | Retrospective cohort study 62,321 467,770 person-years | Pts with RA in daily clinical care in Sweden | ETA, INF | Fourfold increase of risk for TB for ETA and INF compared with conventional DMARDs | Good
Bergstrom et al., 2004^325^ | Retrospective cohort study 985 3 years | Pts with inflammatory arthritis in daily clinical care, U.S. | ETA, INF | Pts treated with INF or ETA are more likely to develop symptomatic coccidiomycosis than pts on synthetic DMARDs | Fair
*Bernatsky et al., 2007^218^ | Nested case-control 23,733 Up to 23 years | RA pts registered in claims databases in Quebec | Anti-TNFs (not specified), oral DMARDs, corticosteroids | No statistical association between anti-TNF use and risk for all infections requiring hospitalization (RR, 1.9; 95% CI, 0.7 to 5.3) | Fair
*Bernatsky et al., 2010^270^ | Meta-analysis 7 studies of administrative claims or electronic health records | Studies estimating overall risk of serious infection in RA pts initiating biologic DMARDs | Biologic DMARD use vs. no use | Biologic DMARD use increased risk of serious infection (pooled adjusted RR, 1.37, 95% CI, 1.18 to 1.60) | Fair
Bongartz et al., 2006^271^ | Meta-analysis 5,014 3 to 12 months | Pts with active RA despite MTX treatment | ADA, INF | Statistically significantly higher risk of serious infections for ADA and INF compared with placebo (3.6% vs. 1.7%; OR, 2.0; 95% CI, 1.3 to 3.1) | Fair
*Brassard et al., 2006^219^ | Retrospective cohort 112,300 Up to 5 years | RA pts with ≥1 claim for anti-RA drugs in U.S. database | Several oral DMARDs, ANK, ETA, INF, corticosteroids | Adjusted rate ratio of developing TB: Biologic DMARDs:1.5 (95% CI, 1.1 to 1.9); INF:1.6 (95% CI, 1.0 to 2.6) ETA:1.2 (95% CI, 0.9 to 1.8) ANK:1.3 (95% CI, 0.8 to 2.1) | Fair
*Cohen et al., 2006^158^ REFLEX Trial | RCT 520 24 weeks | Pts with RA with inadequate response to previous or current treatment with anti-TNF agents | RTX+MTX, MTX | The rate of serious infection was 5.2 and 3.7 per 100 pt-yrs in the RTX+MTX and MTX groups, respectively | Fair
Combe et al., 2006^145^ | RCT 260 Up to 2 years | Active RA despite SSZ treatment | ETA, SSZ, ETA+SSZ | Significantly more infections in ETA and ETA+SSZ than in SSZ group (47% vs. 31% vs. 13%; P<0.05) at 6 months; similar pattern at 2 years (P<0.001) | Fair
*Curtis et al., 2007^277, 278^ | Retrospective cohort study 5,326 Up to 67 months | Pts with RA enrolled in a large U.S. health care organization | MTX, TNF-alpha antagonists | Risk of hospitalization with a bacterial infection for those receiving TNF-alpha antagonists was 1.94 (95% CI, 1.32 to 2.83) compared with pts that received MTX only; risk highest in first 6 months – ETA: 1.61, 95% CI, (0.75 to 3.47) INF 2.40, 95% CI, (1.23 to 4.68) | Good
*den Broeder et al., 2007^326^ | Retrospective cohort 1,219 1 year followup | RA pts that were TNF-alpha antagonist naïve | TNF-alpha antagonists | Perioperative continuation of anti-TNFs not associated with increased risk of surgical site infection. Wound dehiscence in patients that continued anti-TNFs compared with patients that temporarily discontinued anti-TNF treatment (OR, 11.2; 95% CI, 1.4 to 90). | Fair
Dixon et al., 2006^268^ | Prospective cohort study 8,973 11,220 pt-years | Pts with active RA despite MTX treatment | ADA, ETA, INF | No differences among anti-TNF drugs for risk of serious infections. Similar risk for serious infections between anti-TNF drugs and oral DMARDs | Fair
*Dixon et al., 2010^279^ BSRBR | Prospective cohort study 13,739 7,345 person-years (DMARD cohort) 34,025 person-years (anti-TNF cohort) | Pts with RA from the British Society for Rheumatology Biologics Register (BSRBR) | ADA, ETA, INF vs. oral DMARDs | Adjusted incidence rate ratio of TB cases compared with ETA: INF 3.1 (95% CI, 1.0 to 9.5) and ADA 4.2 (1.4–12.4) | Fair
*Galloway et al., 2011^269^ BSRBR | Prospective cohort study 15,396 3.9 years (anti-TNF cohort) 2.6 years (DMARD cohort) | Pts with RA from the British Society for Rheumatology Biologics Register (BSRBR) | ADA, ETA, INF vs. oral DMARDs | Adjusted hazard ratio for serious infection in anti-TNF cohort: 1.2 (95% CI, 1.1 to 1.5). No significant difference in serious infection incidence between ADA, ETA, and INF | Fair
Gomez-Reino et al., 2003^282^ | Retrospective cohort study 1,540 1.1 years | Pts with RA in daily clinical care in Spain | ETA, INF | Higher risk of TB for ETA and INF than oral DMARDs | Fair
*Greenberg et al., 2010^226^ CORRONA | Prospective cohort 7,971 15,047 person-years | Pts with RA enrolled in the Consortium of Rheumatology Researchers of North America (CORRONA) registry | MTX, oral DMARDs, anti-TNF agents, PRED | Adjusted incidence rate ratio (IRR) for infections withanti-TNF agents compared with oral DMARDs (IRR, 1.52; 95% CI, 1.30 to 1.78, P<0.001); opportunistic infections (IRR, 1.67; 95% CI, 0.95 to 2.94 P=0.077) | Fair
*Grijalva et al., 2010^240^ | Retrospective cohort 28,906 Up to 180 days | Tennesee Medicaid-enrolled RA pts initiating DMARD use | MTX, LEF, SSZ, HCQ, biologic DMARDs (ADA, ETA, INF), steroids | Compared with MTX biologic DMARDs increased risk of hospitalization due to pneumonia (HR, 1.31; 95% CI, 0.78 to 2.19) or serious infections (HR, 1.65; 95% CI, 0.85 to 3.03) | Good
*Kawakami et al., 2010^327^ | Case-control 128 | Pts with RA that underwent joint surgery | ETN, INF, DMARDs | Higher risk of surgical site infections in anti-TNF group vs. oral DMARD group (OR, 21.80; 95% CI, 1.231 to 386.1, P=0.036) | Fair
Keane et al., 2001^283^ | Database analysis 70 cases of TB NA, AERS data | Pts treated with INF | INF | TB may develop soon after initiation of INF treatment | Fair
*Keystone et al., 2008^168^ RAPID-1 Trial | RCT 982 52 weeks | Pts with RA that received MTX for ≥6 months prior to baseline | MTX, CTZ+MTX | Occurrence of serious infections was higher in pts treated with CTZ than those on MTX alone | Fair
Lee et al., 2002^286^ | Database analysis 10 cases of histoplasmosis NA, AERS data | Pts treated with ETA and INF | ETA, INF | Histoplasmosis infections may be a serious complication of treatment with anti-TNF agents; pts on INF had a higher rate of infections than pts on ETA | Fair
*Leombruno et al., 2009^255^ | Meta-analysis 18 trials 8,808 patients Average 0.8 years | RA pts on anti-TNF therapy | ADA, ETA, INF | Anti-TNF treatment did not increase seirious infection (OR, 1.21; 95% CI, 0.89 to 1.63) | Fair
Listing et al., 2005^274^ | Prospective cohort study 1,529 Up to 12 months | Pts with RA in daily clinical care in Germany | AKA, ETA, INF | Higher risk of infections for AKA, ETA, INF compared with DMARDs | Fair
*Migliore et al., 2009^328^ | Retrospective cohort 138 with RA Followup not specified | Pts 65 years old or more with RA, PsA, or Ankylosing Spondylitis | ETA, ADA, INF | Infection rate: ETN 18.51%, ADA 20.51%, INF 15.55% | Fair
Mohan et al., 2004^284^ | Database analysis 25 cases of TB NA, AERS data | Pts treated with ETA | ETA | Median interval between first dose and diagnosis of TB was 11.5 months | Fair
*Salliot et al., 2009^272^ | Meta-analysis 12 RCTs | RA patients receiving ABA, ANK, or RTX | ABA, ANK, RTX | No increase in risk of serious infection for ABA or RTX; high doses of ANK increased risk of serious infection | Fair
Salliot et al., 2006^275^ | Case series 709 NR | Pts with different rheumatic diseases; primary care-based cohort | ADA, ETA, INF | Rates of serious infections in daily practice were higher than ones reported in efficacy trials | Fair
*Schiff et al., 2008^66^ | RCT 431 1 year | Pts with RA despite treatment with MTX, anti-TNF therapy naive | ABA +MTX, INF +MTX, MTX | Serious infections were reported more with INF (8.5%) than ABA (1.9%) | Fair
*Schneeweiss et al., 2007^222^ | Retrospective cohort 15,597 Up to 8 years | Medicare beneficiaries ages 65 and older with RA | TNF-alpha antagonists (ADA, ETA, INF) | Compared with MTX use, TNF-alpha did not increase risk of serious bacterial infections (RR, 1.04; 95% CI, 0.63 to 1.72) | Fair
Slifman et al., 2003^287^ | Database analysis 15 cases of listeria infection NA, AERS data | Pts treated with ETA and INF | ETA, INF | Pts on INF had a higher rate of infections than pts on ETA | Fair
*Smitten et al., 2008^223^ | Retrospective cohort 24,530 26.6 months | Pts with RA from U.S. PharMetrics data | ADA, ANK, ETA, INF | Biologic DMARDs slightly increased risk of hospitalized infection (RR, 1.21; 95% CI, 1.02 to 1.43). | Good
*Smitten et al., 2007^224^ | Retrospective cohort 12,272 (PM) 38,621 (GPRD) 12.3 to 38.8 months | Pts with RA from the PharMetrics (PM) database and UK General Practice Research database (GPRD) | ANK, ETA, INF | Risk of herpes zoster infection with biologic DMARD: (PM: OR,1.54; 95% CI, 1.04 to 2.29) | Fair
*Smolen et al., 2009^167^ RAPID 2 study | RCT 619 24 weeks | Pts with RA with prior MTX use for ≥6 months | MTX, CTZ+MTX | Serious infection occurred more frequently in CTZ pts vs. pts treated with MTX monotherapy | Fair
St. Clair et al., 2004^82^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX-naive | MTX, INF+ MTX | Significantly more patients in the INF+MTX than in the MTX group had more than one serious infection (5.3 vs. 2.1%; P<0.05) | Fair
*Strangfeld et al., 2009^225^ | Prospective cohort 5,040 up to 36 months | RA pts initiating biologic therapy or switching to another DMARD | ADA, ETA, INF | Adjusted HR for Herpes Zoster. All anti-TNFs: (HR, 1.63; 95% CI, 0.97 to 2.74) ADA or INF (HR, 1.82; 95% CI, 1.05 to 3.15) ETA (HR, 1.36; 95% CI, 0.73 to 2.55) | Good
Wallis et al., 2004^280^ | Database analysis 649 cases of granulomatous infections NA, AERS data | Pts treated with ETA and INF | ETA, INF | Pts on INF had a higher rate of granulomatous infections than pts on ETA | Fair
*Wiens et al., 2010^183^ | Meta-analysis 21 studies 6,503 patients 8 weeks to 3 years | Pts with RA with or without concomitant MTX | ADA, ETA, INF | Effect estimate of serious infections compared with placebo: ADA (2.22, 95% CI, 0.83 to 5.99, P=0.11), ETA (0.89, 95%CI, 0.54 to 1.48, P=0.66), INF (0.96, 95%CI, 0.39 to 2.38, P=0.93) | Fair
Westhovens et al., 2006^155^ START study | RCT 1,084 22 weeks | Pts with active RA despite MTX treatment | INF+MTX, MTX | Risk of serious infections was similar between placebo and 3 mg/kg infliximab. 10 mg/kg infliximab led to increased risk of serious infections | Good
Wolfe et al., 2004^285^ | Prospective cohort study with historic control 17,242 3 years | Pts with RA in daily clinical care in U.S. | INF, oral DMARDs | TB was more common in pts treated with INF than with oral DMARDs | Fair
Wolfe et al., 2006^237^ | Prospective cohort study 16,788 3.5 years | Pts with RA | ADA, ETA, INF | No increased risk for hospitalization for pneumonia for ADA, ETA, and INF compared with a historic control | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; AERS = adverse event reporting system; ANK = anakinra; CI = confidence interval; CTZ = certolizumab; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; HR = hazard ratio; INF = infliximab; kg = kilogram; LEF = leflunomide; mg = milligram; MTX = methotrexate; NA = not applicable; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; RR = rate ratio; RTX = rituximab; SSZ = sulfasalazine; TB = tuberculosis; TCZ = tocilizumab; TNF = tumor necrosis factor

Table 53 Infusion or injection site reactions in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Cohen et al., 2006^158^ REFLEX Trial | RCT 520 24 weeks | Pts with RA with inadequate response to previous or current treatment with anti-TNF agents | RTX+MTX, MTX | Infusion reactions occurred in 23% of RTX+MTX pts vs. 18% in MTX alone | Fair
*Emery et al., 2006^161^ DANCER trial | RCT 465 24 weeks | Pts with RA that failed prior treatment with at least 1 but not more than 5 DMARDs (other than MTX) and/or biologic response modifiers | RTX+MTX, MTX | Acute infusion reaction occurred more frequently in pts treated with RTX (23% and 32% in the 500-mg and 1,000-mg groups, respectively) vs. MTX alone (17%) | Fair
Fleischmann et al., 2003^259^ | RCT 1,414 6 months | Pts with active RA despite MTX treatment | ANK | Higher rates of injection site reactions with ANK than placebo | Fair
Gartlehner et al., 2006^74^ | Meta-analysis 5,248 NA | Patients who have failed MTX treatment; mean disease duration: varied | ADA, ANK, ETA, INF | Higher rates of injection site/infusion reactions for ANK than ADA and ETA (56% vs. 19% vs. 25%) | Good
Langer et al., 2003^320^ | Postmarketing surveillance 454 6 months | Pts with RA, initiating ANK treatment | ANK | Lower rates of injection site reactions than in clinical trials | Fair
*Martin Du Pan et al., 2009^253^ | Retrospective cohort 2,364 9 years | Pts with RA in the Swiss Clinical Quality Management for Rheumatoid Arthritis (SCQM-RA) registry treated with an anti-TNF agent | ADA, ETA, INF | Increased risk for injection site/infusion or systemic allergic reaction in INF vs. ETA and ADA (HR, 2.11; 99% CI, 1.23–3.62; P=0.018) | Fair
*Miyasaka et al., 2008^125^ CHANGE study | RCT 352 24 weeks | Pts with RA that failed 1 DMARD, including MTX | ADA | Injection site reactions occurred more frequently in ADA pts vs. placebo (P<0.05); Placebo 2.3%; ADA 20 mg 31%; ADA 40 mg 30.8%; ADA 80 mg 33.3% | Fair
Schaible et al., 2000^273^ | Retrospective data analysis of clinical trials 913 12 weeks to 3 years | Pts with RA or Crohn’s disease | INF | 17% of pts on INF in clinical trials had acute infusion reactions | Fair
*Schiff et al., 2008^66^ | RCT 431 1 year | Pts with RA despite treatment with MTX, anti-TNF therapy naive | ABA+MTX, INF+MTX, MTX | Acute infusional events occurred in 7.1% of those treated with ABA vs. 24.8% treated with INF. | Fair
Wasserman et al., 2004^329^ | Prospective cohort study 113 15 months | Pts with RA starting INF treatment in a clinical care setting | INF | 53% of pts on INF experienced at least one infusion reaction | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; ANK = anakinra; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; INF = infliximab; MTX = methotrexate; NA = not applicable; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; RTX = rituximab; TNF = tumor necrosis factor

Table 54 Interstitial lung disease in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
*Wolfe et al., 2007^228^ | Prospective cohort 17,598 Up to 3.5 years | Pts with RA in U.S. National Databank for Rheumatic Diseases | ETA, INF | Current treatment with ETA and INF not associated with hospitalization for interstitial lung disease. Past treatment with ETA and INF was associated with hospitalization for interstitial lung disease (HR, 1.7; 95% CI, 1.0 to 3.0; P=0.056; HR, 2.1; 95% CI, 1.1 to 3.8; P=0.019 | Fair

* New study added since last review.

ETA = etanercept; HR = hazard ratio; INF = infliximab

Table 55 Malignancies in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Askling et al., 2005^276^ | Prospective cohort study 60,930 NR | Pts with RA in daily clinical care in Sweden | ADA, ETA, INF, oral DMARDs | No increase in solid cancers for pts treated with anti-TNF drugs | Fair
Askling et al., 2005^292^ | Prospective cohort study 53,067 NR | Pts with RA in daily clinical care in Sweden | ADA, ETA, INF, oral DMARDs | No increase in lymphoma for pts treated with anti-TNF drugs | Fair
*Askling et al., 2009^295^ | Prospective cohort 6,366 25,693 person-years | Pts with RA in Sweden | ADA, ETA, INF | Relative risk of first primary cancer in comparison to biologic-naïve patients: ADA (RR 1.32, 95% CI, 0.87 to 1.98); ETA (RR 0.78, 95% CI, 0.61 to 1.00); INF (RR 1.09, 95% CI, 0.91 to 1.30); P=0.034 | Fair
Bongartz et al., 2006^271^ | Meta-analysis 5,014 3 to 12 months | Pts with active RA despite MTX treatment | ADA, INF | Statistically significantly higher risk of malignancies for ADA and INF compared with placebo (0.8% vs. 0.2%; OR, 3.3; 95% CI, 1.2 to 9.1) | Fair
*Bongartz et al., 2009^294^ | Meta-analysis 9 studies 3,316 patients At least 12 weeks | Pts with RA | ETA | Risk of maliginancy in ETA not statistically significantly higher than placebo: HR 1.84 (95% CI, 0.79 to 4.28) | Good
Brown et al., 2002^333^ | Database analysis AERS 26 cases of lymphoma NA, AERS data | RA or CD pts treated with ETA and INF | INF, ETA | Median interval between initiation of therapy and lymphoma 8 weeks; some spontaneous remissions after discontinuation of therapy reported | Fair
Chakravarty et al., 2005^242^ | Retrospective cohort study 15,789 NR | RA or osteoarthritis pts treated with ETA or INF | ETA, INF | Statistically significant association between anti-TNF (HR, 1.97; 95% CI, NR; P=0.001) and corticosteroid (HR, 1.28; 95% CI, NR; P=0.014) use and nonmelanoma skin cancer | Fair
Geborek et al., 2005^291^ | Retrospective cohort study 1,557 5,551 pt-years | Pts with RA in daily clinical care in Sweden | ETA, INF | Higher risk of lymphoma for anti-TNF drugs than oral DMARDs | Fair
Lebwohl et al., 2005^334^ | Postmarketing database review 1,442 3.7 years | Pts with RA treated with ETA | ETA | No increase in the incidence of cutaneous squamous cell carcinoma for ETA-treated pts | Fair
*Leombruno et al., 2009^255^ | Meta-analysis 18 trials 8,808 patients Average 0.8 years | RA pts on anti-TNF therapy | ADA, ETA, INF | Anti-TNF treatment did not increase lymphoma (OR 1.26 95% CI, 0.52 to 3.06), nonmelanoma skin cancers (OR 1.27, 95% CI, 0.67 to 2.42), or noncutaneuous cancers plus melanomas (OR 1.31, 95% CI, 0.69 to 2.48) | Fair
*Pallavicini et al., 2010^296^ LORHEN | Prospective cohort 1,114 Mean 23.32 months | RA pts that failed to respond to traditional DMARDs | ADA, ETA, INF | Similar cancer incidence rate as general population Hazard ratio of cancer risk compared with ETN: ADA (HR 1.66, 95% CI, 0.50 to 5.52, P=0.407); INF (HR 0.59, 95% CI, 0.17 to 2.09, P=0.412) | Fair
Setoguchi et al., 2006^293^ | Retrospective cohort study 8,458 2,940 person-years (Biologic DMARD) to 30,300 person-years (MTX) | Pts with RA in daily clinical care in U.S. and Canada | ADA, ETA, INF | No increased risk of hematologic and overall malignancies for pts treated with anti-TNF drugs compared with those on oral DMARDs | Good
*Strangfeld et al., 2010^297^ RABBIT | Prospective cohort 5,120 60 months | Pts with RA in Germany that failed at least one other DMARD therapy | ADA, ANK, ETA, INF, oral DMARDs | No statistically significant difference in the overall incidence of new or recurrent malignancies | Fair
*Wiens et al., 2010^183^ | Meta-analysis 21 studies 6,503 patients 8 weeks to 3 years | Pts with RA with or without concomitant MTX | ADA, ETA, INF | Effect estimate of malignancies compared with placebo: ADA (0.55, 95% CI, 0.14 to 2.11, P=0.38), ETA (0.98, 95% CI, 0.32 to 3.02, P=0.97), INF (1.64, 95% CI, 0.30 to 8.89, P=0.57) | Fair
*Wolfe et al., 2007^335^ | Prospective cohort 13,869 4. years (mean) | Pts with RA in U.S. NDB study | ADA, ANK, ETA, INF | Biologics were associated with an increased risk of nonmelanotic skin cancer (OR, 1.5; 95% CI, 1.2 to 1.8) and melanoma (OR, 2.3; 95% CI, 0.9 to 5.4). No other malignancy was associated with biologic use. The overall risk of any cancer was 1.0 (95% CI, 0.8 to 1.2). | Fair
Wolfe et al., 2004^289^ | Prospective cohort study with external control 18,572 Up to 3 years | Pts with RA in daily clinical care in U.S. | INF, ETA | Pts with RA treated with INF or ETA are more likely to develop lymphoma than the general population | Fair
*Wolfe and Michaud, 2007^290^ *Updates Wolfe 2004^289^ | Prospective cohort 19,591 89,710 person-years | Pts with RA in U.S. NDB study | MTX, ADA, ETA, INF | Pts treated with any anti-TNFs did not have an increases risk for lymphoma compared with RA pts who had not received anti-TNFs. | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; AERS = adverse event reporting system; ANK = anakinra; CD = Crohns disease; CI = confidence interval; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; HR = hazard ratio; INF = infliximab; MTX = methotrexate; NA = not applicable; OR = odds ratio; RA = rheumatoid arthritis; TNF = tumor necrosis factor

Table 56 Other specific adverse events in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
De Bandt et al., 2005^302^ | Case series 22 cases with lupus syndrome | Pts with RA in daily clinical care in France | ETA, INF | Similar incidence of lupus syndrome between ETA and INF | Fair
Flendrie et al., 2005^304^ | Prospective cohort study with historic control 578 911 person-years | Pts with RA starting anti-TNF therapy | ADA, ETA, INF | Higher rates of dermatological conditions in pts on anti-TNF drugs compared with DMARDs | Fair
*Harrison et al., 2009^305^ BSRBR | Retrospective cohort study 12,706 1 to 2 years | Pts with severe RA from The British Society for Rheumatology Biologics Register (BSRBR) | ADA, ETA, INF, oral DMARDs | Anti-TNF vs. oral DMARDs: IR 1.04 (95% CI, 0.67 to 1.54); Among anti-TNF: ADA had a significantly increased risk of psoriasis compared with those treated with ETA (IRR, 4.6; 95% CI, 1.7 to 12.1) and INF (IRR, 3.5; 95% CI, 1.3 to 9.3) | Fair
*Harrison et al., 2009^305^ BSRBR | Retrospective cohort study 12,706 1 to 2 years | Pts with severe RA from The British Society for Rheumatology Biologics Register (BSRBR) | ADA, ETA, INF, oral DMARDs | Anti-TNF vs. oral DMARDs: IR 1.04 (95% CI, 0.67 to 1.54); Among anti-TNF: ADA had a significantly increased risk of psoriasis compared with those treated with ETA (IRR, 4.6; 95% CI, 1.7 to 12.1) and INF (IRR, 3.5; 95% CI, 1.3 to 9.3) | Fair
*Kawakami et al., 2010^327^ | Case-control 128 Post-surgery | Pts with RA that underwent joint surgery | ETN, INF, DMARDs | Increased risk of surgical site infection and deep vein thrombosis in anti-TNF group vs. oral DMARD group | Fair
*Maini et al., 2006^174^ CHARISMA | RCT 359 20 weeks | Pts with RA despite MTX treatment | MTX, TCZ+MTX, TCZ | Liver enzymes (AST) increased with TOC use but was highest in TOC+MTX. No change in liver enzymes occurred with MTX alone | Fair
*Michaud and Wolfe, 2006^244^ | Cross-sectional analysis from prospective cohort 7,243 Questionnaire in Dec 2003 related to previous 6 months | RA pts enrolled in the NDB study | ADA, ETA, INF | Association (OR) of treatment with visits to physician for sinus problems:; - ADA: 1.09 (95% CI, 0.79 to 1.51; P=0.600); - ETA: 1.21 (95% CI, 1.02 to 1.42; P=0.025); - INF: 1.00 (95% CI, 0.88 to 1.15; P=0.973) | Fair
Mohan et al., 2001^299^ | Database analysis AERS 19 cases of demyelination NA, AERS data | Pts on anti-TNF therapy | ETA, INF | Discontinuation of therapy led to partial or complete resolution of all cases | Fair
Shin et al., 2006^336^ | Database analysis AERS 15 cases of Guillain-Barre and Miller Fisher syndromes NA, AERS data | Pts on anti-TNF therapy | ADA, ETA, INF | Demyelination is a potential adverse event of anti-TNF therapy | Fair
*Sokolove et al., 2010^337^ CORRONA | Prospective cohort 6861 Mean 17 months | Pts with RA enrolled in the Consortium of Rheumatology Researchers of North America (CORRONA) registry | ADA, ETA, INF, DMARDs | Adjusted odds ratio of elevated liver enzymes (ALT and/or AST>2×ULN) compared with non-biologic DMARD users: ADA (OR, 1.72; 95% CI, 0.99 to 3.01); ETN (OR, 1.10; 95% CI, 0.64 to 1.88); INF (OR, 2.40; 95% CI, 1.53 to 3.76) | Fair

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AE = adverse event; AERS = adverse event reporting system; ANK = anakinra; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; INF = infliximab; IR = incidence rate; IRR = incidence rate ratio; LEF = leflunomide; MTX = methotrexate; NA = not applicable; OR = odds ratio; RA = rheumatoid arthritis; RCT = randomized controlled trial; TCZ = tocilizumab; TNF = tumor necrosis factor

Corticosteroids: overall tolerability. Corticosteroids are associated with several well-known side effects (noted already in Tables 38 to 40). The prescription information for long-term use of corticosteroids highlights precautions including osteoporosis with secondary fractures, infection, glucose intolerance, peptic ulcer disease, gastrointestinal bleeding, cataracts, and glaucoma.308–312

Comparatively, the tolerability for corticosteroids appears to be similar among different corticosteroids, although the information is limited by short study duration and the fact that only one comparative study is available (Table 37). This head-to-head RCT, described more in detail for KQ 1, compared budesonide (3 mg/day), high-dose budesonide (9 mg/day), prednisolone (7.5 mg/day), and placebo over 12 weeks.54 Overall rates of adverse events were similar among groups (89 percent, 3 mg/day budesonide; 94 percent, 9 mg/day budesonide; 85 percent, prednisone; 90 percent, placebo; P=NR). Few adverse events caused patients to discontinue the drug; gastrointestinal symptoms, heart symptoms, and mood swings or insomnia were similar in all patient groups (P=NR).

One retrospective cohort study of 224 RA patients directly assessed the toxicity of low-dose, long-term corticosteroid therapy (mean 4.9 years).313 In three outpatient rheumatology clinics, 112 patients on low-dose prednisone (<15 mg/day) for more than 1 year were matched with 112 patients not using prednisone. Investigators abstracted records from the date of prednisone initiation to the date of a predetermined adverse event (fracture, avascular necrosis of bone, new onset diabetes or diabetes out of control, infection requiring hospital or surgical intervention, herpes zoster, MI, cerebrovascular event, gastrointestinal (GI) bleeding or peptic ulcer disease, cataracts, glaucoma, and death). Low-dose and high-dose long-term prednisone use (>5 mg/day) was correlated with dose-dependent specific adverse events (adverse event at 10 to 15 mg/day: OR, 32.3; 95% CI, 4.6 to 220; P=0.0004; adverse event at 5 to 10 mg/day: OR, 4.5; 95% CI, 2.1 to 9.6; P=0.0001; and adverse event at 0 to 4 mg/day: OR, 1.9; 95% CI, 0.8 to 4.7; P=0.15). Patients on long-term prednisone (any dose) were at higher risk for fracture (OR, 3.9; 95% CI, 0.8 to 18.1; P<0.09), infection (OR, 8.0; 95% CI, 1.0 to 64; P<0.09) and GI event (OR, 3.3; 95% CI, 0.9 to 12.1; P<0.07) than were those on shorter-term prednisone use.

Corticosteroids—specific adverse events. We found no comparative study of corticosteroids directly assessing specific serious adverse events. Sixteen studies assessed single agents or class effects of corticosteroids, and these studies are highlighted here for cardiovascular and cerebrovascular events (Table 38), infection (Table 39), and other specific events (Table 40).

Cardiovascular and cerebrovascular events. Four observational studies214–216, 234 and one RCT64 provide mixed evidence that corticosteroid treatment in patients with RA increases risk of cardiovascular events, and possibly cerebrovascular events (Table 38). Of the studies of cardiovascular outcomes, one fair-rated cross-sectional analysis of 4,363 patients with RA sampled from 15 countries reported a small reduction in risk of cardiovascular morbidity (HR, 0.95; 95% CI, 0.92 to 0.98).215 Three studies reported an increased risk of cardiovascular events.64, 216, 234 A fair-rated RCT of patients with early RA reported that prednisolone was associated with an increased risk of developing hypertension (OR, 2.16; 95% CI, 1.07 to 4.36).64 A fair-rated nested-case control study of Pennsylvania Medicare enrollees with RA found a glucocorticoid-related increased risk of cardiovascular events (OR, 1.5; 95% CI, 1.1 to 2.1),216 and a fair-rated retrospective cohort study of U.S. commercially insured patients found that glucocorticoid use was associated with small increased risk of acute MI (RR, 1.32; 95% CI, 1.02 to 1.72).234 Only one study assessed cerebrovascular outcomes; this nested case-control study from the National Data Bank for Rheumatic Diseases (NDB) study found a statistically nonsignificant increased risk of ischemic stroke with prednisolone treatment (OR, 1.75; 95% CI, 0.87 to 3.53).

Infection. Nine observational studies (Table 39) provide consistent evidence that corticosteroid use in patients with RA is associated with an increased risk of infection, including infections like TB and herpes zoster.218–226 These studies represent large treated populations with RA, varying in setting from U.S. commercially insured populations, Medicare patients in a single U.S. state, a U.S. registry, and populations in the UK and Canada. A risk of serious bacterial infection was shown in five fair-quality studies218, 220–222, 226 and one good-quality study.223 One fair-224 and one good-rated study225 demonstrated an increased risk of herpes zoster infection with corticosteroids, and one fair-rated study219 demonstrated an increased risk of TB with corticosteroids. Across all of these studies of patients with RA (regardless of type of infection), the risk of infection increased by approximately 50 percent to 150 percent with use of corticosteroids.

Other adverse events. Three additional observational studies assessed the risk of specific adverse events with corticosteroid treatment in patients with RA; one of septic (infectious) arthritis;227 one of sinus problems;244 and one of interstitial lung disease (Table 40).228 A large fair-rated retrospective cohort study found that prednisolone was associated with roughly a threefold increased risk of developing septic (infectious) arthritis compared with those not receiving any DMARD (IRR, 2.94; 95% CI, 1.93 to 4.46).227 A cross-sectional analysis of 6-month questionnaires from 7,243 patients enrolled in the NDB study found that prednisone use was not associated with an increased risk of sinus problems.244 Analysis of a larger group of patients from the NDB study (n=17,598) found that current and past prednisone use was associated with hospitalization for interstitial lung disease (respectively, HR, 2.5; 95% CI, 1.5 to 4.1, P<0.001, and HR, 3.0; 95% CI, 1.0 to 8.9, P=0.044).228

Oral DMARDs: overall tolerability. MTX, sulfasalazine, hydroxychloroquine and leflunomide all can produce several well-known, and similar, reactions. Frequently reported adverse reactions for these drugs found in package inserts include the following:

- MTX: ulcerative stomatitis, nausea and abdominal distress, fatigue, chills and fever, dizziness, leukopenia, and decreased resistance to infection;314
- Sulfasalazine: stomatitis, nausea, dyspepsia, rash, headache, abdominal pain or vomiting, fever, dizziness, pruritus, and abnormal liver function tests;315
- Hydroxychloroquine: dizziness, headache, abdominal pain/nausea/vomiting/diarrhea, pruritus, weight loss, hair bleaching, and alopecia;316 and
- Leflunomide: diarrhea, rash, elevated liver enzymes, and alopecia.317

Tables 41 to 47 describe studies providing information on tolerability and various adverse events. Studies reporting overall tolerability of oral DMARDs and oral DMARD combinations are summarized in Table 41. For monotherapy with oral DMARDs, three trials56, 104, 105, 107, 108 and a meta-analysis with up to 2 years of data,55 all described in more detail for KQ 1, indicated similar levels of general tolerability among leflunomide, MTX, and sulfasalazine, including similar discontinuation rates and frequency of serious adverse events. A retrospective cohort study found leflunomide given as monotherapy or in combination with MTX had fewer adverse event reports than MTX alone or other oral DMARDs.229 However, another meta-analysis of withdrawal rates from 71 RCTs and 88 observational studies, which included data up to 5 years, found that patients with RA stayed on MTX significantly longer than on either sulfasalazine or hydroxychloroquine.230 At 5 years, 36 percent of patients had remained on MTX to continue their treatment; 22 percent had remained on sulfasalazine. Patients on sulfasalazine were more likely to have withdrawn from medication because of toxicity than those on MTX (52 percent vs. 35 percent; RR, 1.68; P<0.0001). Withdrawal rates were not found to differ between samples reported in observational studies and RCTs.

For combination therapies, eight studies of DMARD combinations (one up to 5 years57) included MTX, sulfasalazine, hydroxychloroquine, and etanercept (described in detail under KQ 1). They generally had similar withdrawal rates attributed to adverse events.55, 57–59, 61, 62, 110, 231, 232 One nonrandomized inception cohort fournd higher disciontinuation rates for sulfasalazine plus MTX compared with MTX monotherapy (P=0.01).110 In two RCTs, discontinuation rates were similar, but rates of adverse events were higher for sulfasalazine plus MTX vs. MTX monotherapy (adverse events for combination therapy range from 53 percent to 91 percent; adverse events for monotherapy range from 50 percent to 75 percent).57, 58 Side effects included nausea, erythema, and elevated transaminases. One systematic review of leflunomide plus MTX vs. MTX monotherapy found increased frequency of adverse event reports with combination therapy.55 Three RCTs of combination therapy including prednisone with one or more DMARDs (described in detail in KQ 1) showed similar discontinuation rates between groups.65, 98, 100 One open-label RCT of 155 patients comparing a prednisolone taper plus MTX plus sulfasalazine actually had a lower withdrawal rate because of adverse events than sulfasalazine only (2.6 percent vs. 7.6 percent, P=NR).95 Another open-label RCT of 245 patients found the withdrawal rate for adverse events to be lower in the prednisone plus MTX group than in the prednisone plus sulfasalazine group (11.5 percent vs. 33.3 percent, P=0.0005).318 A retrospective cohort study of 154 patients found that addition of a glucocorticoid to hydroxychloroquine or MTX increased the mean time until withdrawal of DMARD therapy due to adverse events by approximately 6 months (P<0.05).233

Oral DMARDs: specific adverse events. Oral DMARDs can produce several serious adverse events. The package inserts for MTX give several warnings.314 It has been reported to cause congenital abnormalities. Severe and sometimes fatal bone marrow suppression and gastrointestinal toxicity have been reported with concomitant administration of MTX and nonsteroidal anti-inflammatory drugs (NSAIDs). MTX-induced lung disease can occur with doses as low as 7.5 mg per week. Malignant lymphoma may also occur in patients on low-dose MTX. Severe, occasionally fatal skin reactions have also been reported.

Less common but severe adverse and potentially fatal events for sulfasalazine include blood dyscrasias, hypersensitivity reactions including Stevens-Johnson syndrome, renal and liver damage, irreversible neuromuscular and central nervous system changes, and fibrosing alveolitis.315 The package insert for hydroxychloroquine describes irreversible retinal damage in some patients on long-term therapy or high dosage. Other serious reactions include blood dyscrasias, seizures, hypersensitivity reactions, and hepatotoxicity.316 Potentially severe adverse reactions for leflunomide include blood dyscrasias, hepatotoxicity, and hypersensitivity reactions including Stevens-Johnson syndrome.317 Studies of adverse events with oral DMARDs are summarized in Tables 42 to 47.

Cardiovascular and cerebrovascular events. Four observational studies assessed cardiovascular or cerebrovascular outcomes with oral DMARD treatment (Table 42).214, 215, 234, 235 All found either a decrease or no difference in risk of these events for patients treated with oral DMARDs compared with no treatment or other comparator treatments.

Two studies found a decreased risk of broadly defined cardiovascular events with oral DMARDs.215, 235 One study, the Quantitative Patient Questionnaires in Standard Monitoring of Patients with Rheumatoid Arthritis (QUEST-RA) project, was a cross-sectional review of 4,363 patient records from 15 countries.215 This fair-rated study reviewed clinical history and surveyed patients for information about cardiovascular events, including MI, angina, coronary disease, coronary bypass surgery, and stroke. Risk of all types of cardiovascular events was reduced among patients taking MTX, leflunomide, and sulfasalazine. The second study was a retrospective chart review of 613 patients from a single rheumatology clinic in the Netherlands.235 Cardiovascular disease was defined as a verified medical history of coronary, cerebral, or peripheral arterial disease. Regression models considered patients treated with oral DMARD monotherapy, as well as combinations of MTX, hydroxychloroquine, and sulfasalazine. All oral DMARD monotherapy and combinations showed a decreased risk of cardiovascular disease (compared with no oral DMARD), although the risk reduction was only statistically significant for patients ever taking MTX and sulfasalazine (OR, 0.24; 95% CI, 0.07 to 0.85, P<0.05) and MTX, sulfasalazine, and hydroxychloroquine (OR, 0.27; 95% CI, 0.07 to 0.99, P<0.05).

One fair-rated retrospective cohort study of 107,908 commercially insured patients with RA found a decreased risk of acute MI among patients taking MTX (RR, 0.81; 95% CI, 0.60 to 1.08) or leflunomide (RR, 0.28; 95% CI, 0.12 to 0.65).234 A decreased risk also was observed among a heterogeneous group of “all other traditional DMARDs” (RR, 0.67; 95% CI, 0.46 to 0.97); this group included hydroxychloroquine and sulfasalazine among numerous other agents.

A fair-rated nested case-control study of 7,045 patients with RA from the NDB study found that while overall patients with RA have a significantly increased risk of stroke (OR, for all strokes 1.64; 95% CI, 1.16 to 2.30; OR, for ischemic strokes 2.66; 95% CI, 1.24 to 5.70), treatment with MTX, hydroxychloroquine, leflunomide, and sulfasalazine does not increase this risk.214

Hepatic events. Two retrospective cohorts examined hepatic events in patients with rheumatoid arthritis.229, 236 Both studies found similar hepatic event rates for leflunomide and MTX (Table 43).

A 2-year retrospective cohort from a U.S. insurance claims database (N=40,594) examined the incidence rates of serious hepatic events in patients treated with leflunomide, MTX, and other DMARDs (including gold, D-penicillamine, hydroxychloroquine, sulfasalazine, infliximab, and etanercept).229 The hepatic event rate for leflunomide was similar to that for other DMARDs (leflunomide, 4.1/1,000 person-years [95% CI, 2.4 to 7.0], MTX, 6.2/1,000 person-years [95% CI, 5.1 to 9.3]; other DMARDs, 4.2/1,000 person-years [95% CI, 3.3 to 5.3], P=NS, NR).

Another group examined data from claims databases for two retrospective cohorts of 41,885 patients over 3 years for serious hepatic events associated with treatment with leflunomide, MTX, traditional DMARDs (hydroxychloroquine, sulfasalazine, gold, minocycline, penicillamine, chlorambucil, cylcophosphamide and cyclosporine), or biologic DMARDs (infliximab, etanercept).236 Overall, the rate of serious hepatic events for all drugs was 4.9 per 10,000 patient years. Using MTX as the reference, they observed no higher rates in serious hepatic events for leflunomide (RR, 0.9; 95% CI, 0.2 to 4.9) or for traditional DMARDs (RR, 2.3; 95% CI, 0.8 to 6.5), but they did report higher rates for biologic DMARDs (RR, 5.5; 95% CI, 1.2 to 24.6).

Infection. Mixed evidence from 12 studies suggests that oral DMARDs do not significantly affect risk of infections (Table 44).218, 220, 221, 223, 224, 226, 229, 237–240 A good-rated retrospective cohort study found that some oral DMARDs may decrease risk of infection.223 In this study, 24,530 U.S. commercially insured patients with RA were evaluated for hospitalized infection. A nested case-control analysis was conducted on 1,993 cases of infection and 9,965 controls. The adjusted rate ratio showed a statistically significantly lower rate of infection for MTX- (RR, 0.81; 95% CI, 0.70 to 0.93) and hydroxychloroquine-treated patients (RR, 0.74; 95% CI, 0.62 to 0.89). Risk of infection was not increased with leflunomide (RR, 1.02; 95% CI, 0.79 to 1.32) or sulfasalazine (RR, 0.82; 95% CI, 0.58 to 1.16). In contrast, a fair-rated cohort study from the Consortium of Rheumatology Research of North America (CORRONA) registry found MTX to be associated with an increased risk of infection (IRR, 1.30; 95% CI, 1.12 to 1.5; P<0.001).226

Four other fair-rated studies showed no difference in infection rates with oral DMARDs.218, 220, 221, 239 A 39-year population-based study of the Rochester, Minnesota, cohort examined potential risk factors for hospitalization for infection in RA patients (N=609).220 The use of corticosteroids increased hospitalization for infection (HR, 1.56; 95% CI, 1.20 to 2.04), but oral DMARDs (including MTX, hydroxychloroquine, sulfasalazine, and leflunomide) had no increased risk of infection-related hospitalizations. This finding was similar in a retrospective cohort study of 27,710 patients with RA from British Columbia,221 where oral DMARDs given in combination with corticosteroids were associated with an increased risk of infection (RR, 1.63; 95% CI, 1.5 to 1.77), but oral DMARDs alone were not associated with an increased risk of infection (RR, 0.92; 95% CI, 0.85 to 1.0). A nested case-control study of 23,733 patients with RA from a Quebec database218 and a retrospective cohort study of 20,357 patients with RA treated at the U.S. Veterans Affairs health care system239 also found no increased risk of infection with oral DMARDs.

Two fair-rated and one good-rated cohort studies examined the risk of hospitalization for pneumonia infection.229, 237, 240 One study examined 16,788 patients from U.S. rheumatology practices and followed up semi-annually with questionnaires for 3.5 years.237 Both prednisone and leflunomide use increased the risk of hospitalization for pneumonia compared with RA patients not on these drugs (HR, 1.7; 95% CI, 1.5 to 2.1; HR 1.3; 95% CI, 1.0 to 1.5); MTX, hydroxychloroquine, sulfasalazine, infliximab, etanercept, or adalimumab did not increase risks. A 2-year retrospective database study examined RA patients to determine the incidence rates of adverse events during treatment with leflunomide, MTX, and other DMARDs (including gold, D-penicillamine, hydroxychloroquine, sulfasalazine, infliximab, and etanercept).229 Respiratory infection rates per person-year were highest in the MTX group (38.9/1,000 person-years), next highest in the other DMARD group (36.9/1,000 person-years), and lowest in the leflunomide group (20/1,000 person-years) (P<0.0001). The good-rated study found that, compared with MTX, hydroxychloroquine, leflunomide, and sulfasalazine do not increase risk of hospitalization due to pneumonia (adjuster HR, 1.61; 95% CI, 0.85 to 3.03).240

Two retrospective cohort studies examined the risk of TB with oral DMARDs.219, 238 Both showed an increased risk of TB with oral DMARD treatment. One study examined 24,282 patients with RA from Quebec, Canada and found the risk of TB to be increased among oral DMARD users (RR, 3.0; 95% CI, 1.6 to 5.8).238 The risk was highest among leflunomide-treated patients (RR, 11.7; 95% CI, 2.1 to 65.1), although the sample size for this group was only 10 patients (3 cases, 7 controls). A similarly designed study using a U.S. claims database identified 112,300 patients with RA and found only a slight increase in risk of developing TB among oral DMARD users (RR, 1.2; 95% CI, 1.0 to 1.5).219 Subgroup analyses from this study illustrate that the risk of developing TB is lower among patients concomitantly receiving corticosteroids (RR, 0.6; 95% CI, 0.4 to 1.0) compared with patients not receiving corticosteroids (RR, 1.4; 95% CI, 1.1 to 1.8).

One fair-rated retrospective cohort study examined the risk of herpes zoster infection with oral DMARDs.224 This study analyzed data from a U.S. commercial claims database as well as data from the UK General Practice Research Database. Analyses from both databases revealed an increased risk of herpes zoster infection with oral DMARDs (U.S. data: OR, 1.37; 95% CI, 1.18 to 1.59; UK data: OR, 1.27; 95% CI, 1.10 to 1.48).

Interstitial lung disease. Two fair-rated observational studies evaluated the risk of interstitial lung disease with oral DMARD treatment (Table 45).217, 228 One 5-year retrospective cohort study examined claims data from 62,734 patients with RA given a DMARD 1 year prior to the date of diagnosis of interstitial lung disease.217 Patients were divided into four categories: leflunomide, MTX, biologic agents (infliximab, etanercept, adalimumab, anakinra), and traditional DMARDs (antimalarials, sulfasalazine, gold salts, minocycline, penicillamine, azathioprine, cyclosporine, other cytotoxic agents). In patients diagnosed with interstitial lung disease, those prescribed leflunomide were at increased risk compared with patients prescribed other DMARDs (RR, 1.9; 95% CI, 1.1 to 3.6) but not significantly higher with use of either MTX (RR, 1.4; 95% CI, 0.8 to 2.3) or biologic DMARDs (RR, 0.8; 95% CI, 0.4 to 1.5).217 The second study analyzed data from 17,598 patients with RA followed prospectively in the NDB study.228 Cases of interstitial lung disease were identified by searching patient descriptive reports, hospital records, physician records, and mortality records. The incidence of hospitalization for interstitial lung disease was 260 per 100,000 patient years. No significant association was observed between current or past treatment with MTX, hydroxychloroquine, leflunomide, or sulfasalazine. Current and past treatment with prednisone, as well as current treatment with infliximab, etanercept, and cyclophosphamide was associated with an increased risk of interstitial lung disease.

Malignancies. Two observational studies assessed the risk of malignancy with oral DMARDs (Table 46). One retrospective study examined 756 patients with RA to determine the risk of lymphoma over a 30-year period.241 This was a matched case-control of consecutive Swedish RA patients in whom lymphoma was diagnosed. Controls were RA patients matched for sex, year of birth, year of RA diagnosis, and county of residence. The investigators found no association between lymphoma and use of DMARDs, including MTX (OR, 0.7; 95% CI, 0.3 to 1.6) or sulfasalazine (OR, 0.6; 95% CI, 0.3 to 1.1).

Another retrospective cohort study examined the risk of nonmelanoma skin cancer in 15,789 U.S. patients with RA who were participating in a registry and returned semiannual questionnaires over a 4-year period in which they reported any current malignancies.242 Among RA patients, the development of nonmelanoma skin cancer was associated with use of prednisone (HR, 1.28; P=0.014). They found no association between this neoplasm and leflunomide plus MTX.

Other adverse events. Five studies provided additional data on oral DMARD-related adverse events (Table 47). One study evaluated the relationship of treatment with the incident rate of septic arthritis;227 one study examined whether MTX and leflunomide increased the risk of wound healing complications (both in combination with corticosteroids) in RA patients undergoing elective orthopedic surgery;243 one study examined evidence of kidney damage from combination therapy compared with monotherapy with suflasalazine or prednisone;245 one systematic review evaluated studies addressing fertility, pregnancy, and laction;246 and one study assessed whether oral DMARDs were related to sinus problems.244

In a retrospective cohort study of 136,977 patients with RA from the UK General Practice Research Database, the incidence rate of septic (infectious) arthritis was increased for patients receiving oral DMARDs compared with patients not receiving oral DMARDs (IR, 2.14; 95% CI, 1.64 to 2.78; P<0.001).227 The increased incidence rate varied by drug, and was highest for penicillamine (IRR, 2.51; 95% CI, 1.29 to 4.89), sulfasalazine (IRR, 1.74; 95% CI, 1.04 to 2.91), and prednisolone (IRR, 2.51; 95% CI, 1.93 to 4.46).

A prospective cohort study of 201 patients with RA undergoing orthopedic surgery assessed whether leflunomide or MTX given in combination with corticosteroids increased the risk of wound healing complications.243 In comparison with patients who received MTX, the risk of postoperative wound healing complications was significantly higher than in patients who received leflunomide (MTX 13.6 percent vs. leflunomide 40.6 percent; P=0.01).

A good-rated RCT compared oral DMARD combination therapy with oral DMARD monotherapy in 195 DMARD-naïve patients with recent onset RA. Over an 11-year follow-up period, no statistically significant difference in renal complications was observed.245

A systematic review of studies addressing safety of MTX during pregnanancy, lactation, and related to fertility concluded that evidence is insufficient to adequately addreass the question.246

A cross-sectional analysis of 7,243 patients followed in the NDB study assessed whether treatment with oral DMARDs was associated with physician visits for sinus problems.244 Treatment with MTX and hydroxychloroquine were not associated with an increased risk of sinus problems, and leflunomide and sulfasalazine had a slight protective effect (respectively, OR, 0.84; 95% CI, 0.70 to 0.99; P=0.041; and OR, 0.68; 95% CI, 0.51 to 0.90; P=0.007).

Biologic DMARDs. This section follows a similar format as the detailed analysis of corticosteroid and oral DMARD sections above, where results for overall tolerability are presented first, followed by general adverse events and then specific adverse events. This section follows a slightly different format to accommodate the presentation of quantitative analyses and detailed adverse event data. Data on tolerability and adverse events for biologic DMARDs are presented as follows: (1) results of quantitative analyses for withdrawal data; and (2) additional discontinuation data not captured by the quantitative analyses, (3) overall adverse event rates and reports of serious adverse events (not otherwise discussed in the specific adverse events section but that are reflective of tolerability profile), and (4) specific adverse events.

Overall tolerability quantitative analyses. RCTs identified by our systematic literature search were screened for inclusion in the meta-analysis of overall tolerability. This included mostly fair-to-good quality efficacy trials, as well as some RCTs otherwise included in a good-quality meta-analysis covered in KQ 1 or KQ 2 of this report. Trials were excluded if they did not meet preestablished eligibility criteria for study design or duration, patient population, interventions, outcomes, and comparisons to medications outside our scope of interest. Eligible studies had to compare one more biologic DMARD with placebo. Concomitant use of MTX was allowed, as long as it was consistently used in the biologic DMARD and placebo groups. The outcome of interest was withdrawal (total, due to adverse events and due to lack of efficacy) of biologic DMARD treatment. These trials were not required to report adverse event data other than withdrawals, and thus not all of the studies are detailed further in other adverse event-related sections of this report. Trials had to be at least 12 weeks in duration. If multiple withdrawal rates were reported for more than one time point, we used the time point identified for the primary outcome measure. We limited included data to FDA-approved dosage ranges to achieve better equivalency across drugs. Note that sample sizes may not match sample sizes reported in individual trials since we excluded dosing arms outside of the FDA recommend range. We identified a total of 42 studies (43 comparisons) that were relevant for nine biologics. These included five studies for abatacept, eight for adalimumab, four for anakinra, three for certolizumab, six for etanercept, three for golimumab, six for infliximab, four for rituximab, and four for tocilizumab. Table 48 lists trials included in the meta-analyses, along with the corresponding withdrawal rates overall and by reason.

Overall tolerability: quantitative analysis of total withdrawals for biologic DMARD versus placebo. Using random effects models, we calculated the pooled odds ratios of total treatment withdrawal for each biologic relative to placebo (Figure 4). Overall, patients on biologics were approximately half as likely to withdraw from the treatment as compared with the patients on placebo. Among the individual biologics, the pooled estimates were statistically significant for abatacept (OR, 0.58; 95% CI, 0.39 to 0.86), certolizumab (OR, 0.10; 95% CI, 0.06 to 0.18), etanercept (OR, 0.32; 95% CI, 0.18 to 0.57) and rituximab (OR, 0.29; 95% CI, 0.22 to 0.39). Patients taking these drugs were less likely to withdraw from a trial than patients taking placebo. The likelihood of withdrawal of adalimumab, anakinra, golimumab, infliximab, and tocilizumab was not statistically significantly different than placebo. We estimated heterogeneity using I2 statistic. I2 was found to be 86.5 percent overall, which suggested a high amount of heterogeneity among the studies. This heterogeneity may be attributed to several reasons. First, real heterogeneity may exist across study designs and patient populations. Second, the withdrawal outcome—which measures a combination of withdrawals due to adverse events and withdrawals due to lack of efficacy—can be a potential source of heterogeneity. These reasons for withdrawal may not be in agreement with each other, and introduce measurement concerns when combining studies. For example, total withdrawal for one drug can be higher because it is less efficacious while for another drug, it might just be because of high adverse events. This can lead to potential heterogeneity concerns when looking across all studies. We assessed publication bias using funnel plots. Visual examination of funnel plots illustrated potential for some publication bias. However, given the small number of component studies, results of these tests must be viewed cautiously.

Figure 4 Meta-analysis of overall withdrawals from randomized controlled trials of biologic DMARDs

Figure 4 displays a forest plot of the findings from a meta-analysis of overall withdrawals from randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The withdrawal rates between drug and placebo are presented as odds ratios and 95 percent confidence intervals. The forest plot is organized alphabetically by biologic DMARD and under each biologic is a list of studies included in the analysis. The studies included are listed in Table 47. Each study is presented with an odds ratio and 95 percent confidence interval, and, in addition, there is a subtotal odds ratio and confidence interval for each biologic and an overall pooled odds ratio and corresponding confidence interval which includes all the biologic DMARDs. A measure of heterogeneity and corresponding test statistic p-value is presented for each subtotal and overall estimate. In the center of the figure, the odds ratios are presented as shaded boxes along the x-axis ranging from a scale of 0.05 to 20. The size of each box corresponds to the relative sample size/precision of each study. Each box has a line running through it representing the width of the confidence interval. The subtotal and overall odds ratios and confidence intervals are presented as diamond shapes centered on the odds ratio and stretched over the width of the confidence interval. A vertical line running the center of the page where the odds ratio is equal to one represents no difference between drug and placebo. For each comparison, if the confidence interval crosses the line of no difference, then a conclusion of no statistically significant difference between drug and placebo is supported. Odds ratios greater than one indicate a higher withdrawal rate for the drug, while ratios less than one indicate a higher withdrawal rate for placebo. Results for each biologic drug are as follows: abatacept pooled odds ratio, 0.58 with 95 percent confidence interval 0.39 to 0.86, I squared statistic of 64.4 percent with p-value 0.024; adalimumab pooled odds ratio, 0.66 with 95 percent confidence interval 0.41 to 1.06, I squared statistic of 79.5 percent with p-value 0.000; anakinra pooled odds ratio, 1.08 with 95 percent confidence interval 0.79 to 1.47, I squared statistic of 23.1 percent with p-value 0.273; certolizumab pooled odds ratio, 0.10 with 95 percent confidence interval 0.06 to 0.18, I squared statistic of 70.5 percent with p-value 0.034; etanercept pooled odds ratio, 0.32 with 95 percent confidence interval 0.18 to 0.57, I squared statistic of 75.3 percent with p-value 0.001; golimumab pooled odds ratio, 0.68 with 95 percent confidence interval 0.34 to 1.38, I squared statistic of 0.0 percent with p-value 0.865; infliximab pooled odds ratio, 0.70 with 95 percent confidence interval 0.38 to 1.30, I squared statistic of 81.0 percent with p-value 0.000; rituximab pooled odds ratio, 0.29 with 95 percent confidence interval 0.22 to 0.39, I squared statistic of 0.0 percent with p-value 0.657; tocilizumab pooled odds ratio, 0.83 with 95 percent confidence interval 0.50 to 1.40, I squared statistic of 66.1 percent with p-value 0.053; and overall pooled odds ratio of 0.51 with 95 percent confidence interval of 0.40 to 0.65 and I squared statistic of 86.5 percent with p-value 0.000.

Overall tolerability: quantitative analysis of withdrawals due to lack of efficacy for biologic DMARD versus placebo. We also calculated the pooled odds ratios of treatment withdrawal because of lack of efficacy for each biologic relative to placebo (Figure 5). Patients randomized to biologic DMARDs were nearly 5 times less likely to withdraw from the treatment due to lack of efficacy as compared with the patients on placebo (OR, 0.21; 95% CI, 0.17 to 0.27). All individual biologics, except golimumab, were less likely to be withdrawn compared with placebo for lack of efficacy. I2 was found to be 52.8 percent, which suggested slightly lower heterogeneity when just looking at lack of efficacy compared with overall withdrawals. This result suggests that some of the heterogeneity with the total withdrawals analysis was probably due to combining withdrawals for all the reasons together. Visual examination of funnel plots did not show evidence of publication bias.

Figure 5 Meta-analysis of withdrawals due to lack of efficacy in randomized controlled trials of biologic DMARDs

Figure 5 displays a forest plot of the findings from a meta-analysis of withdrawals due to lack of efficacy from randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The withdrawal rates between drug and placebo are presented as odds ratios and 95 percent confidence intervals. The forest plot is organized alphabetically by biologic DMARD and under each biologic is a list of studies included in the analysis. The studies included are listed in Table 47. Each study is presented with an odds ratio and 95 percent confidence interval, and, in addition, there is a subtotal odds ratio and confidence interval for each biologic and an overall pooled odds ratio and corresponding confidence interval which includes all the biologic DMARDs. A measure of heterogeneity and corresponding p-value is presented for each subtotal and overall estimate. In the center of the figure, the odds ratios are presented as shaded boxes along the x-axis ranging from a scale of 0.05 to 20. The size of each box corresponds to the relative sample size/precision of each study. Each box has a line running through it representing the width of the confidence interval. The subtotal and overall odds ratios and confidence intervals are presented as diamond shapes centered on the odds ratio and stretched over the width of the confidence interval. A vertical line running the center of the page where the odds ratio is equal to one represents no difference between drug and placebo. For each comparison, if the confidence interval crosses the line of no difference, then a conclusion of no statistically significant difference between drug and placebo is supported. Odds ratios greater than one indicate a higher withdrawal rate for the drug, while odds ratios less than one indicate a higher withdrawal rate in placebo. Results for each biologic drug are as follows: abatacept pooled odds ratio, 0.23 with 95 percent confidence interval 0.10 to 0.52, I squared statistic of 50.0 percent with p-value 0.112; adalimumab pooled odds ratio, 0.23 with 95 percent confidence interval 0.17 to 0.32, I squared statistic of 0.0 percent with p-value 0.684; anakinra pooled odds ratio, 0.56 with 95 percent confidence interval 0.33 to 0.96, I squared statistic of 0.0 percent with p-value 0.361; certolizumab pooled odds ratio, 0.09 with 95 percent confidence interval 0.05 to 0.17, I squared statistic of 72.0 percent with p-value 0.028; etanercept pooled odds ratio, 0.20 with 95 percent confidence interval 0.13 to 0.32, I squared statistic of 10.5 percent with p-value 0.349; golimumab pooled odds ratio, 0.70 with 95 percent confidence interval 0.18 to 2.83, I squared statistic of 0.0 percent with p-value 0.781; infliximab pooled odds ratio, 0.25 with 95 percent confidence interval 0.17 to 0.37, I squared statistic of 0.0 percent with p-value 0.674; rituximab pooled odds ratio, 0.19 with 95 percent confidence interval 0.10 to 0.33, I squared statistic of 0.0 percent with p-value 0.628; tocilizumab pooled odds ratio, 0.20 with 95 percent confidence interval 0.11 to 0.38, I squared statistic of 0.0 percent with p-value 0.609; and overall pooled odds ratio of 0.21 with 95 percent confidence interval of 0.17 to 0.27 and I squared statistic of 52.8 percent with p-value 0.000.

Overall tolerability: quantitative analysis of withdrawals due to adverse events for biologic DMARD versus placebo. We also calculated the pooled odds ratios of treatment withdrawal because of adverse events for each biologic relative to placebo. Patients on biologics were 44 percent more likely to withdraw from the treatment due to adverse events compared with the patients on placebo (OR, 1.43; 95% CI, 1.18 to 1.74). Among individual biologics, the pooled estimates for adalimumab (OR, 1.60; 95% CI, 1.13 to 2.28), anakinra (OR, 1.59; 95% CI, 1.10 to 2.31), certolizumab (OR, 2.73; 95% CI, 1.18 to 6.31), infliximab (OR, 2.09; 95% CI, 1.38 to 3.18), and tocilizumab (OR, 1.94; 95% CI, 1.22 to 3.09) were statistically significant, suggesting that patients on these drugs were more likely to withdraw from the trial due to adverse events than patients on placebo. Heterogeneity I^2^ was found to be 31.3 percent, which suggests relatively low heterogeneity among this outcome in these studies. Visual examination of funnel plots did not show evidence of publication bias.

Overall tolerability: mixed treatment comparisons for overall withdrawals. Indirect comparisons were made using the studies described in Table 49 and shown in meta-analyses (Figures 4 to 6). Thirty-eight studies contributed data to the analysis of overall withdrawals. Results are presented for each possible drug-drug comparison (Figure 7). Odds ratios less than 1 favor the first drug listed in the comparison (Drug A), indicating that there were fewer total withdrawals for this drug in comparison with the second drug listed (Drug B). Odds ratios greater than 1 favor drug B in terms of a more favorable withdrawal rate. Most comparisons suggest no difference in overall withdrawals. A few exceptions were found: certolizumab pegol had a more favorable overall withdrawal profiles than all other biologic DMARDs. Etanercept and rituximab also had fewer overall withdrawals in some comparisons. For etanercept, results were statistically significant for the comparison with adalimumab (OR, 0.51; 95% CI, 0.22 to 0.97), anakinra (OR, 0.32; 95% CI, 0.12 to 0.70), infliximab (OR, 0.38; 95% CI, 0.18 to 0.89), and tocilizumab (OR, 0.33; 95% CI, 0.14 to 0.89). For rituximab, results were statistically significant for only the comparisons with anakinra (OR, 0.33; 95% CI, 0.11 to 0.78), infliximab (OR, 0.45; 95% CI, 0.17 to 1.00), and tocilizumab (OR, 0.32; 95% CI, 0.13 to 0.99). These results should be interpreted cautiously because of the relatively small number of contributing studies and the corresponding wide confidence intervals. Plus, evaluating overall withdrawals provides only a rough proxy for tolerability.

Figure 6 Meta-analysis of withdrawals due to adverse events in randomized controlled trials of biologic DMARDs

Figure 6 displays a forest plot of the findings from a meta-analysis of withdrawals due to adverse events from randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The withdrawal rates between drug and placebo are presented as odds ratios and 95 percent confidence intervals. The forest plot is organized alphabetically by biologic DMARD and under each biologic is a list of studies included in the analysis. The studies included are listed in Table 47. Each study is presented with an odds ratio and 95 percent confidence interval, and, in addition, there is a subtotal odds ratio and confidence interval for each biologic and an overall pooled odds ratio and corresponding confidence interval which includes all the biologic DMARDs. A measure of heterogeneity and corresponding p-value is presented for each subtotal and overall estimate. In the center of the figure, the odds ratios are presented as shaded boxes along the x-axis ranging from a scale of 0.05 to 20. The size of each box corresponds to the relative sample size/precision of each study. Each box has a line running through it representing the width of the confidence interval. The subtotal and overall odds ratios and confidence intervals are presented as diamond shapes centered on the odds ratio and stretched over the width of the confidence interval. A vertical line running the center of the page where the odds ratio is equal to one represents no difference between drug and placebo. For each comparison, if the confidence interval crosses the line of no difference, then a conclusion of no statistically significant difference between drug and placebo is supported. Odds ratios greater than one indicate a higher withdrawal rate for the drug, while ratios less than one indicate a higher withdrawal rate in placebo. Results for each biologic drug are as follows: abatacept pooled odds ratio, 1.06 with 95 percent confidence interval 0.64 to 1.76, I squared statistic of 27.6 percent with p-value 0.238; adalimumab pooled odds ratio, 1.60 with 95 percent confidence interval 1.13 to 2.28, I squared statistic of 0.0 percent with p-value 0.648; anakinra pooled odds ratio, 1.59 with 95 percent confidence interval 1.10 to 2.31, I squared statistic of 7.3 percent with p-value 0.357; certolizumab pooled odds ratio, 2.73 with 95 percent confidence interval 1.18 to 6.31, I squared statistic of 0.0 percent with p-value 0.667; etanercept pooled odds ratio, 0.76 with 95 percent confidence interval 0.54 to 1.08, I squared statistic of 0.0 percent with p-value 0.996; golimumab pooled odds ratio, 1.20 with 95 percent confidence interval 0.35 to 4.11, I squared statistic of 21.6 percent with p-value 0.279; infliximab pooled odds ratio, 2.09 with 95 percent confidence interval 1.38 to 3.18, I squared statistic of 2.8 percent with p-value 0.399; rituximab pooled odds ratio, 0.94 with 95 percent confidence interval 0.18 to 4.97, I squared statistic of 59.7 percent with p-value 0.059; tocilizumab pooled odds ratio, 1.94 with 95 percent confidence interval 1.22 to 3.09, I squared statistic of 31.5 percent with p-value 0.223; and overall pooled odds ratio of 1.43 with 95 percent confidence interval of 1.18 to 1.74 and I squared statistic of 31.3 percent with p-value 0.030.

Figure 7 Mixed treatment comparisons for overall withdrawals in randomized controlled trials of biologic DMARDs

Figure 7 displays a forest plot of the results of the mixed treatment comparisons for overall withdrawals in randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative withdrawal rate of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 72 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents the line of no difference. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one indicate the second drug listed in the comparison has a lower withdrawal rate, while ratios less than one indicate the first drug listed in the comparison has a lower withdrawal rate. Most comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: adalimumab versus etanercept, OR 1.98 and 95 percent credible interval of 1.03 to 4.61; anakinra versus etanercept, OR 3.11 and 95 percent credible interval of 1.42 to 8.67; anakinra versus rituximab, OR 3.05 and 95 percent credible interval of 1.28 to 9.39; certolizumab versus abatacept, OR 0.19 and 95 percent credible interval of 0.07 to 0.41; certolizumab versus adalimumab, OR 0.17 and 95 percent credible interval of 0.06 to 0.35; certolizumab versus anakinra, OR 0.11 and 95 percent credible interval of 0.03 to 0.25; certolizumab versus etanercept, OR 0.29 and 95 percent credible interval of 0.13 to 0.80; certolizumab versus golimumab, OR 0.13 and 95 percent credible interval of 0.05 to 0.53; certolizumab versus infliximab, OR 0.12 and 95 percent credible interval of 0.05 to 0.32; certolizumab versus rituximab, OR 0.28 and 95 percent credible interval of 0.12 to 0.87; certolizumab versus tocilizumab, OR 0.10 and 95 percent credible interval of 0.04 to 0.32; infliximab versus etanercept, OR 2.65 and 95 percent credible interval of 1.12 to 5.54; rituximab versus infliximab, OR 0.45 and 95 percent credible interval of 0.17 to 1.00; rituximab versus tocilizumab, OR 0.32 and 95 percent credible interval of 0.13 to 0.99; and tocilizumab versus etanercept, OR 3.06 and 95 percent credible interval of 1.12 to 6.97.

Overall tolerability: mixed treatment comparisons for withdrawals due to lack of efficacy. Thirty-one studies contributed data to the analysis of withdrawals due to lack of efficacy. Results are presented for each possible drug-drug comparison (Figure 8). Odds ratios less than 1 favor the first drug listed in the comparison (Drug A), indicating that there were fewer withdrawals due to lack of efficacy for this drug in comparison with the second drug listed (Drug B). Odds ratios greater than 1 favor drug B in terms of a more favorable efficacy-related withdrawal rate. Most comparisons suggest no difference in withdrawals due to lack of efficacy. Similar to the analysis of overall withdrawals, certolizumab pegol had lower rates of withdrawals due to lack of efficacy than adalimumab (OR, 0.41; 95% CI, 0.18 to 0.76), anakinra (OR, 0.18; 95% CI, 0.06 to 0.39), and infliximab (OR, 0.33; 95% CI, 0.16 to 0.77). Withdrawals due to lack of efficacy were lower for abatacept (OR, 0.31; 95% CI, 0.13 to 0.93), etanercept (OR, 0.33; 95% CI, 0.11 to 0.74), rituximab (OR, 0.31; 95% CI, 0.08 to 0.78), and tocilizumab (OR, 0.37; 95% CI, 0.11 to 0.93) than for anakinra. These results should be interpreted cautiously because of the relatively small number of contributing studies and the corresponding wide confidence intervals. Plus, evaluation of withdrawals due to lack of efficacy is only a rough proxy for tolerability.

Figure 8 Mixed treatment comparisons for withdrawals due to lack of efficacy in randomized controlled trials of biologic DMARDs

Figure 8 displays a forest plot of the results of the mixed treatment comparisons for withdrawals due to efficacy in randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative withdrawal rate of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 72 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents the line of no difference. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one indicate the second drug listed in the comparison has a lower withdrawal rate, while ratios less than one indicate the first drug listed in the comparison has a lower withdrawal rate. Most comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: abatacept versus anakinra, OR 0.31 and 95 percent credible interval of 0.13 to 0.93; certolizumab versus adalimumab, OR 0.41 and 95 percent credible interval of 0.18 to 0.76; certolizumab versus anakinra, OR 0.18 and 95 percent credible interval of 0.06 to 0.39; certolizumab versus infliximab, OR 0.33 and 95 percent credible interval of 0.16 to 0.77; etanercept versus anakinra, OR 0.33 and 95 percent credible interval of 0.11 to 0.74; rituximab versus anakinra, OR 0.31 and 95 percent credible interval of 0.08 to 0.78; and tocilizumab versus anakinra, OR 0.37 and 95 percent credible interval of 0.11 to 0.93.

Overall tolerability: mixed treatment comparisons for withdrawals due to adverse events. Indirect comparisons were made using the studies described in Table 48 and shown in meta-analyses (Figure ). Forty-one studies contributed data to the analysis of withdrawals due to adverse events. Results are presented for each possible drug-drug comparison (Figure 9). Odds ratios less than 1 favor the first drug listed in the comparison (Drug A), indicating that there were fewer withdrawals due to adverse events for this drug in comparison with the second drug listed (Drug B). Odds ratios greater than 1 favor drug B in terms of a more favorable adverse-event-related withdrawal rate. Most comparisons suggest no difference in withdrawals due to adverse events, with a few exceptions. Both certolizumab pegol and infliximab had more withdrawals due to adverse events than some other drugs. For certolizumab, the likelihood of withdrawal because of an adverse event was greater than for abatacept (OR, 3.28; 95% CI, 1.05 to 8.53), etanercept (OR, 3.48; 95% CI, 1.44 to 11.65) and rituximab (OR, 2.82; 95% CI, 1.01 to 13.26).

Figure 9 Mixed treatment comparisons for withdrawals due to adverse events in randomized controlled trials of biologic DMARDs

Figure 9 displays a forest plot of the results of the mixed treatment comparisons for withdrawals due to adverse events in randomized controlled trials of biologic DMARDs, including: abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative withdrawal rate of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 72 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents the line of no difference. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one indicate the second drug listed in the comparison has a lower withdrawal rate, while ratios less than one indicate the first drug listed in the comparison has a lower withdrawal rate. Most comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: abatacept versus certolizumab, OR 0.30 and 95 percent credible interval of 0.12 to 0.96; abatacept versus infliximab, OR 0.43 and 95 percent credible interval of 0.24 to 0.83; adalimumab versus etanercept, OR 2.00 and 95 percent credible interval of 1.10 to 3.93; anakinra versus etanercept, OR 2.07 and 95 percent credible interval of 1.17 to 4.30; certolizumab versus abatacept, OR 3.28 and 95 percent credible interval of 1.05 to 8.53; certolizumab versus etanercept, OR 3.48 and 95 percent credible interval of 1.44 to 11.65; certolizumab versus rituximab, OR 2.82 and 95 percent credible interval of 1.01 to 13.26; etanercept versus infliximab, OR 0.30 and 95 percent credible interval of 0.16 to 0.62; etanercept versus tocilizumab, OR 0.35 and 95 percent credible interval of 0.20 to 0.73; infliximab versus rituximab, OR 2.40 and 95 percent credible interval of 1.00 to 7.43; and tocilizumab versus abatacept, OR 2.01 and 95 percent credible interval of 1.01 to 3.71.

For infliximab, the likelihood of withdrawal because of an adverse event was greater than for abatacept (OR, 2.35; 95% CI, 1.20 to 4.22), etanercept (OR, 3.31; 95% CI, 1.62 to 6.07), and rituximab (OR, 2.40; 95% CI, 1.00 to 7.43). Withdrawals because of adverse events tended to be lower with abatacept and etanercept when comparing them with some other drugs. For abatacept, statistically significantly fewer withdrawals occurred due to adverse events when compared with certolizumab (OR, 0.30; 95% CI, 0.12 to 0.96), infliximab (OR, 0.43; 95% CI, 0.24 to 0.83), and tocilizumab (OR, 0.50; 95% CI, 0.27 to 1.00), and for etanercept, differences were statistically significant for comparisons with adalimumab (OR, 0.50; 95% CI, 0.25 to 0.91), anakinra (OR, 0.48; 95% CI, 0.23 to 0.85), certolizumab (OR, 0.29; 95% CI, 0.09 to 0.69), infliximab (OR, 0.30; 95% CI, 0.16 to 0.62), and tocilizumab (OR, 0.35; 95% CI, 0.20 to 0.73). All of these results should be interpreted cautiously because of the relatively small number of contributing studies and the very wide confidence intervals.

Biologic DMARDs—overall tolerability: studies on discontinuation rates not otherwise covered in quantitative analyses. Table 49 presents studies providing discontinuation data not otherwise covered by quantitative analyses. One good-quality RCT compared etanercept with the combination of etanercept and abatacapt.80 This RCT was not included in our meta-analysis of withdrawal rates because it compared two biologic DMARDs with a single biologic DMARD. Withdrawals due to adverse events occurred more in the combination group (11.8 percent) than in the monotherapy etanercept group (2.8 percent).

Additional evidence on comparative discontinuation rates is provided by systematic reviews27, 126, 134, 177, 180, 210 and observational studies.73, 88, 93, 247–252 While some studies did not find clinically or statistically significant differences in drug discontinuation rates,247, 249 others did. Consistent with our mixed treatment comparisons analysis, a good-rated meta-analysis found etanercept to have fewer withdrawals due to adverse events than adalimumab, anakinra, and infliximab.27 A second good-rated meta-analysis found the highest rate of withdrawals due to adverse events for infliximab and the lowest rate for adalimumab.126

Observational evidence generally supports these findings.73, 88, 248, 250–252 A Swedish population-based, prospective cohort study reported statistically significantly higher rates of overall discontinuation (HR, 2.92; 95% CI, 2.32 to 3.69; P<0.001) for patients on infliximab than for those on etanercept.251 These differences were not statistically significant for discontinuations due to adverse events or due to lack of efficacy. A German retrospective, population-based cohort study, based on the RABBIT database, reported that overall discontinuation rates among biologics were significantly higher for anakinra-treated patients (41 percent) than for patients on etanercept (31 percent; P=0.004 for anakinra vs. etanercept) or those on infliximab (35 percent; P=0.03 for anakinra vs. infliximab).88 Treatment discontinuations because of adverse events, after 12 months of treatment, were lowest for etanercept (13 percent for etanercept, 16 percent for anakinra, and 19 percent for infliximab; P=NR). This finding is also consistent with a retrospective cohort study of patients treated with adalimumab, etanercept, and infliximab, where there was a trend towards better tolerability with adalimumab and etanercept compared with infliximab (P=0.06).248 Another prospective cohort study reported higher rates of switching treatments with infliximab compared with adalimumab and etanercept (P=NR).250 In the Danish DANBIO registry, the hazard ratios for drug withdrawal were 1.98 for infliximab versus etanercept (95% CI, 1.63 to 2.40), 1.35 for infliximab versus adalimumab (95% CI, 1.15 to 1.58), and 1.47 for adalimumab versus etanercept (95% CI, 1.20 to 1.80).73 In the Italian Lombardi Rheumatology Network (LOHREN) registry, the risk of discontinuation due to adverse events was higher for adalimumab than for etanercept (AHR 2.09; 95% CI, 1.29 to 3.38).252

Biologic DMARDs—overall tolerability: adverse event rates and serious adverse events. Table 50 presents the comparative harms for biologic DMARDs. Only two studies compared adverse event rates and serious adverse events with biologic DMARDs; one RCT66 and one retrospective cohort study.253 Both studies found more serious adverse events among patients treated with infliximab. The RCT included 431 patients with RA who were receiving MTX and were naïve to biologic DMARDs. Patients were randomized to abatacept plus MTX, infliximab plus MTX, or placebo plus MTX. At 6 months, 5.1 percent of the abatacept group reported serious adverse events, but 11.8 percent and 11.5 percent of the placebo and infliximab groups, respectively, reported serious adverse events (P=NR). After 1 year, 18.2 percent of infliximab-treated and 9.6 percent of abatacept-treated reported a serious adverse event (P=NR; placebo arm stopped at 6 months). Acute infusional events were lower with abatacept (7.1 percent) than with infliximab (24.8 percent). The retrospective cohort study followed 2,364 patients with RA newly treated with an anti-TNF agent in the Swiss Clinical Quality Management for Rheumatoid Arthritis (SCQM-RA) registry. There was an increased risk of adverse events in the infliximab compared with adalimumab and etanercept groups (HR, 1.4; 99% CI, 1.0–1.96). More specifically, there was an increased risk of infusion or systemic allergic reactions with infliximab compared with adalimumab and etanercept (P=0.018).

One good-rated126 and one fair-rated183 systematic review and meta-analysis provided indirect evidence regarding comparative differences in adverse events with adalimumab, etanercept, and infliximab. In the good-rated meta-analysis, the relative risk of serious adverse events for biologic DMARDs compared with control was statistically significant only for infliximab (RR, 1.4; 95% CI, 1.0 to 2.0; P=0.048).126 The infliximab-treated patients in this analysis were more likely than control group patients to withdraw from studies because of adverse events, had more severe adverse events, infection, and infusion reactions. In the fair-rated meta-analyis of adalimumab, etanercept, and infliximab compared with placebo, no statistically significant differences were noted in serious adverse events, serious infections, malignancy, or death (P>0.05 for all comparisons).183 Based on unadjusted comparison of risk ratios from meta-analyses, infliximab had the highest rate of withdrawal due to adverse events (RR, 2.05; 95% CI, 1.33 to 3.16).

Indirect evidence from additional efficacy trials, cohort studies, and meta-analyses suggests that the overall tolerability profiles are similar among biologic and oral DMARDs, or combinations of biologic and oral DMARDs.67, 70, 76, 84, 86, 87, 89, 90, 116, 121, 127, 136, 138, 156, 170, 175, 177, 178, 210, 254–256 However, several studies suggested that adverse events were more common with biologic DMARDs, given alone or in combination with an oral DMARD.120, 145, 164–167, 173 One prospective cohort study found a slightly lower rate of serious adverse events among patients who had an oral DMARD added to adalimumab, compared with patients who only received adalimumab (5.3 percent vs. 7.3 percent, respectively; P=NR).257 In one RCT of MTX-naïve patients that compared golimumab monotherapy, MTX monotherapy, and golimumab plus MTX, serious adverse events were least common among the golimumab monotherapy group (3.2 percent vs. 6.9 percent vs. 6.3 percent, respectively; P=NR).92

Four RCTs were designed to assess adverse events as primary outcomes.121, 155, 258, 259 Overall, adverse event rates were similar for abatacept,258 adalimumab,121 anakinra,259 or infliximab155 and placebo. Other efficacy trials suggested that overall adverse events are higher with biologic DMARDs than with placebo.

In placebo-controlled efficacy trials of biologic DMARDs, injection site reactions, abdominal pain, nausea, headache, diarrhea, upper respiratory tract infections, and urinary tract infections were commonly reported adverse events.74 The combination of two biologic DMARDs consistently had more adverse events than monotherapy. A 24-week RCT, described in more detail for KQ 1, assessed a combination treatment of etanercept (25 mg or 50 mg/week) and anakinra (100 mg/day) compared with etanercept monotherapy.79 The frequency of serious adverse events was substantially higher in the combination groups than the etanercept-only group (14.8 percent for 50 mg etanercept plus anakinra; 4.9 percent for 25 mg etanercept plus anakinra; 2.5 percent for etanercept only; P=NR). Furthermore, a study determining the efficacy of abatacept combined with different background treatments found substantially higher rates of serious adverse events in patients on abatacept combined with a biologic background treatment (22.3 percent) than in those not on a combination of two biologic DMARDs (12.5 percent).258

One nonrandomized open-label trial determined the comparative harms among combinations of biologic DMARDs and oral DMARDs other than MTX.231 No differences in adverse events could be detected between a combination of etanercept and either sulfasalazine or hydroxychloroquine. Similar evidence of similarities in adverse events among background oral DMARDs comes from an RCT comparing rituximab, MTX, rituximab plus MTX, and rituximab plus cyclophosphamide,84 and a prospective cohort study comparing anakinra plus MTX with anakinra plus leflunomide.93 Both studies reported no significant differences in adverse events among these combinations of biologic and oral DMARDs.

The ERA study,77 described in more detail in KQ 1, had an open-label extension of up to 2 years,188 and an uncontrolled extension with etanercept (25 mg twice weekly) of up to 5 years.189 The rates of adverse events for etanercept did not rise during long-term treatment compared with rates reported from the short-term RCT. These results are consistent with findings from long-term extension studies of efficacy RCTs on adalimumab,124 anakinra,129, 319 and infliximab.149, 261 Likewise, safety analyses of postmarketing surveillance data showed that the incidence of adverse events did not rise over time in patients treated with adalimumab298 and etanercept.260

Biologic DMARDs—specific adverse events. Biologic DMARDs can produce several serious adverse events (Table 51). Studies of adverse events with biologic DMARDs are summarized in Tables 51 to 56.

Cardiovascular and cerebrovascular events. No direct evidence compared the risk of cardiovascular or cerebrovascular events for one biologic DMARD with another. Eleven observational studies provide evidence for the risk of cardiovascular and cerebrovascular events (Table 51).214, 216, 234, 262–267, 321 These studies use a variety of comparator groups, including oral DMARDs, “conventional” DMARDs, and placebo. In some cases, the comparison group is unclear. Whenever possible, we specify the comparator in the tables and summary text.

One additional RCT conducted in a population with CHF322 is discussed because it provides general evidence for risk of using infliximab in patients with existing heart failure (even though these patients did not have RA).

The evidence on the risk of congestive heart failure (CHF) with anti-TNF therapy is mixed. One observational study reported lower rates of CHF262 for RA patients on anti-TNF therapy than for those on conventional RA therapies. This large retrospective cohort study (N=13,171) reported an absolute risk reduction for CHF of 1.2 percent (95% CI, −1.9 to −0.5; P=NR) for patients treated with anti-TNF therapy compared with those not treated with anti-TNF medications over a 2-year period.262 This study contrasts with three other cohort studies that found an increased risk of heart failure with adalimumab, etanercept, and infliximab compared with no treatment or oral DMARD.263–265 While the increased risk was not statistically significant in two of these studies,263, 264 one good-rated retrospective cohort study of 5,593 Medicare patients with RA from two U.S. states reported statistically significant increases in the risk of heart failure and death (HR, 1.70; 95% CI, 1.07 to 2.69).265

An analysis of the FDA AERS data reported that half of the patients who developed new onset CHF under etanercept or infliximab treatment did not have any identifiable risk factors.321 Indirect evidence comes from three trials, two on etanercept323 and one on infliximab,322 that evaluated the efficacy of these drugs for the treatment of CHF. Study populations did not have any rheumatoid illnesses. One of the two etanercept trials was terminated early because interim analyses indicated higher mortality rates in patients treated with etanercept. Similarly, the infliximab study presented higher mortality rates in the 10 mg/kg arm than in the placebo and 5 mg/kg arm.322 The package insert of infliximab issues a contraindication regarding use in patients with CHF; the package inserts of etanercept and adalimumab emphasize precaution.

Three observational studies assessed the risk of cardiovascular events (broadly defined).215, 216, 266 One case-control study of Medicare patients with RA found no statistically significant association between use of biologic DMARDs and cardiovascular events,216 while two studies reported a decreased risk of cardiovascular events with biologic DMARDs.215, 266 A good-quality Swedish retrospective cohort study (N=983), using data from population-based databases, reported a statistically significantly lower risk of cardiovascular events in patients treated with anti-TNF medications than in those on conventional therapy (age-sex adjusted rate ratio: 0.46/1,000 person-years; 95% CI, 0.25 to 0.85; P=0.013).266 A cross-sectional analysis of patients from 15 countries participating in the QUEST-RA study reported that patients exposed to biologic DMARDs had a reduced risk of cardiovascular morbidity (HR, 0.42; 95% CI, 0.21 to 0.81; P<0.05).215

One nested case-control study assessed the risk of stroke with adalimumab, etanercept, and infliximab,214 and two cohort studies assessed the risk of MI with these same biologic DMARDs.234, 267 The study assessing stroke was conducted in the National Data Bank for Rheumatic Diseases, finding a slight decrease in the risk of stroke with adalimumab, etanercept, and infliximab (OR, 0.79; 95% CI, 0.34 to 1.82; P=NS).214 The two studies assessing risk of MI also found no statistically significant differences in the risk of MI, although results trended towards an increased risk of MI for these biologic DMARDs. In a good-rated analysis of 10,755 patients from the British Society for Rheumatology Biologics Register, the incidence rate ratio was 1.44 (95% CI, 0.56 to 3.67) for biologic DMARDs compared with oral DMARDs. In a larger fair-rated analysis of 107,908 patients from a U.S. claims database, biologic DMARDs were associated with a similar nonstatistically significant increase in the risk of MI (RR, 1.30; 95% CI, 0.92 to 1.83).234

Infections. Because of the immunosuppressive nature of biologic DMARDs, serious infections including TB, pneumonia, osteomyelitis, progressive multifocal leucoencephalopathy (PML), and sepsis are of special concern. The FDA has issued black box warnings about an increased risk of infections for adalimumab and infliximab. The package inserts of anakinra and etanercept also contain bold letter warnings. Recently, the FDA issued an alert for health care professionals highlighting the death of two patients from PML who had been treated with rituximab for systemic lupus erythematosus.324 The available head-to-head evidence is insufficient to draw firm conclusions about the comparative risk of biologic DMARDs.

The best comparative evidence stems from an RCT66 and two prospective cohort studies.268, 269 The trial randomized 431 patients with RA to MTX, abatacept plus MTX, or infliximab plus MTX. Serious infections were reported more often in the infliximab group than the abatacept group (P=NR).66 One cohort study enrolled 8,973 patients with severe RA from the British Society for Rheumatology Biologics Register (BSRBR). Patients were treated with adalimumab (n=1,190), etanercept (n=3,596), infliximab (n=2,878), or oral DMARDs (n=1,354). The overall followup included 11,220 person-years. Results indicated no differences in risks among anti-TNF drugs. Compared with oral DMARDs, anti-TNF drugs did not lead to a higher overall risk for serious infections (IRR, 1.03; 95% CI, 0.68 to 1.57). The frequency of serious skin infections, however, was fourfold higher in patients treated with anti-TNF drugs than with oral DMARDs (IRR, 4.28; 95% CI, 1.06 to 17.17). A second cohort study conducted in BSRBR followed 15,396 patients with RA who were taking adalimumab, etanercept, or infliximab.269 As a class, these anti-TNF drugs increased risk of serious infections (HR, 1.2; 95% CI, 1.1 to 1.5). No statistically significant difference in the incidence rate was observed comparing across the individual drugs.

Although the statistical analysis for the prospective cohort studies controlled for multiple confounding factors, residual confounding in such a study design is likely. Results, therefore, must be interpreted cautiously. Event rates of serious infections in efficacy trials comparing anti-TNF drugs with oral DMARDs were generally too low to draw meaningful conclusions.

The following paragraphs summarize the evidence on the general risk of biologic DMARDs for serious infections (i.e., the risk of biologic DMARDs compared with that of placebo treatment). Table 52 presents studies reporting on infections in those patients treated with biologic DMARDs.

Most studies defined serious infections as those that required antibiotic treatment or led to hospitalization or death. In placebo-controlled safety RCTs, the incidence of serious infections was consistently higher in biologic-treated than in placebo-treated patients.82, 85, 155, 158, 167, 168 Although clinically significant, these differences rarely reached statistical significance because of low power. For example, in one large safety RCT (N=1,414), a trend towards an increased risk of serious infections in anakinra-treated patients was apparent during the 6 months of treatment (2.1 percent vs. 0.4 percent; P=0.068).259 The START (Trial for Rheumatoid Arthritis with Remicade) study, another safety RCT (N=1,084) conducted to assess the risk of serious infections during infliximab treatment for RA, indicated a dose-dependent risk for patients on infliximab.155 After 22 weeks of treatment, patients on 3 mg/kg infliximab had similar rates of serious infections as patients on placebo (1.7 percent vs. 1.7 percent; RR, 1.0; 95% CI, 0.3 to 3.1). Patients treated with 10 mg/kg infliximab had a significantly higher rate of serious infections than patients on placebo (5.0 percent vs. 1.7 percent; RR, 3.1; 95 percent CI, 1.2 to 7.9). The REFLEX (Randomized Evaluation of Long-Term Efficacy of Rituximab) trial randomized 520 patients to 24 weeks of treatment with MTX or rituximab plus MTX.158 The rate of serious infections was slightly higher among rituximab-treated patients (5.2 vs. 3.7 per 100 person-years). In both the RAPID1 and RAPID2 (RA Prevention of Structural Damage) trials,167, 168 two trials assessing the efficacy of certolizumab in RA patients previously treated with MTX, serious infections occurred more frequently among the certolizumab-treated patients.

Six systematic reviews and meta-analyses have assessed serious infections with biologic DMARDs.126, 183, 255, 270–272 Some of these analyses provide drug-specific effect size estimates, although none provide adjusted indirect comparisons or mixed treatment comparisons to adequately compare risk of infection among biologic DMARDs. Effect size estimates generally suggest that infection rates are increased with biologic DMARDs; several analyses found this increase to be statistically nonsignficant.183, 255 In a fair-rate meta-analysis of efficacy studies of adalimumab- and infliximab-treated patients, the pooled odds ratio for serious infections was 2.0 (95% CI, 1.3 to 3.1) relative to placebo.271 A fair-rated meta-analysis of large cohort studies (excluding trials) of anti-TNF drugs also found an increased risk of serious infections (RR, 1.37; 95% CI, 1.18 to 1.60).270 In a good-rated meta-analysis of 13 trials (7,087 patients) of adalimumab, etanercept, and infliximab, a statistically significant increase in risk of infection was observed only among the infliximab group (RR, 1.2; 95% CI, 1.1 to 1.3).126 Another fair meta-analysis of 12 RCTs did not find an increased risk of serious infections with abatacept or rituximab, but found that high doses of anakinra did increase risk.272

Long-term observational studies generally support an increased risk of infection with biologic DMARDs, although not in across all studies.158, 218, 222, 223, 226, 240, 273–279, 328 A large, French case series of 709 patients with various rheumatic diseases treated with adalimumab, etanercept, or infliximab in daily clinical practice reported a substantially higher rate of serious infections (10.5 per 100 person-years) than rates reported in phase 3 efficacy trials (3 to 4 per 100 person-years).275 A prospective cohort study of 7,971 patients (15,047 patient years) with RA in the Consortium of Rheumatology Researchers of North America (CORRONA) registry reported an increased rate of infection for anti-TNF drugs compared with oral DMARDs (IRR, 1.52; 95% CI, 1.30 to 1.78).226 A large good-rated U.S. cohort study (N=5,326) of patients with RA enrolled in a U.S. health care organization found an increased risk of hospitalization with bacterial infection for those treated with adalimumab, etanercept, or infliximab (HR, 1.94; 95% CI, 1.32 to 2.83) compared with patients that only received MTX.277, 278 This finding contrasts with a large retrospective cohort study of 15,597 U.S. Medicare patients receiving adalimumab, etanercept, or infliximab;222 compared with MTX use there was no increased risk of serious infection with these biologic DMARDs. Two additional good-rated cohort studies showed an increased risk of infection hospitalization.223, 240 One retrospective cohort study using U.S. administrative claims data showed a slightly increased risk of hospitalized infection with adalimumab, anakinra, etanercept, and infliximab (RR, 1.21; 95% CI, 1.02 to 1.43).223 Another retrospective cohort study of Tennessee Medicaid patients did not find a statistically significant increase in risk of hospitalization due to pneumonia (HR, 1.31; 95% CI, 0.78 to 2.19) or serious infection (HR, 1.65; 95% CI, 0.85 to 3.03) for patients treated with adalimumab, etanercept, or infliximab compared with MTX.240

In addition to bacterial pathogens, serious infections included cases of TB,283 coccidiomycosis,325 histoplasmosis,286 listeriosis,287 candida,283 and herpes.224, 225

In a fair-rated cohort study of 13,739 patients with RA in the BSRBR the incidence of TB with oral DMARDs was compared with adalimumab, etanercept, and infliximab.279 No cases of TB were observed among oral DMARD users and only 40 cases of TB were observed among the biologic DMARD users, so statistical analyses only compared biologic DMARDs. Compared with etanercept, the incidence rate ratio of TB was higher for infliximab (IRR, 3.1; 95% CI, 1.0 to 9.5) and adalimumab (IRR, 4.2; 95% CI, 1.4- to 12.4).

Six additional cohort studies determined the risk of TB or granulomatous infections during treatment with infliximab or etanercept.219, 280–285 All studies reported a significant increase in risk attributable to biologic DMARDs relative to placebo. For example, in a fair-rated retrospective cohort study of 112,300 U.S. patients with RA, the rate ratio for developing TB was 1.5 with biologic DMARDs (95% CI, 1.1 to 1.9).219 For the individual agents, the rate ratio was highest with infliximab (RR, 1.6; 95% CI, 1.0 to 2.6) compared with etanercept and anakinra (respectively, RR, 1.2; 95% CI, 0.9 to 1.8; and RR, 1.3; 95% CI, 0.8 to 2.1).

Other evidence regarding the risk of TB comes from Spanish, Swedish, and U.S. databases that collected data on patients treated with biologic DMARDs.281, 282, 285 The U.S. study, using data from the National Data Bank of Rheumatic Diseases (NBI), reported an eightfold higher rate of TB in patients treated with infliximab than in patients in a historic control group who had been treated with synthetic DMARDs.285 The analysis yielded rates of 6.2 cases per 100,000 person-years in the control group and 52.5 cases per 100,000 person-years in patients on infliximab. The other two studies were based on the Spanish BIOBADASER (Base de Datos de Productos Biologicos de la Sociedad Espanola de Reumatologia)282 and several Swedish databases.281 Both studies analyzed data on infliximab and etanercept and indicated a substantially higher risk for TB in patients treated with etanercept or infliximab than in those on synthetic RA therapy. The Swedish study reported a fourfold increased risk of TB (RR, 4.0; 95% CI, 1.3 to 12) for patients on anti-TNF treatment compared with the risk for RA patients not exposed to etanercept or infliximab.281 The incidence of TB in patients treated with infliximab was 145 per 100,000 (95% CI, 58 to 299) person years; in patients treated with etanercept, the incidence was 80 (95% CI, 16 to 232) per 100,000 person years.

Three studies based on spontaneously reported adverse events from the FDA AERS database provided similar results.280, 283, 284 These studies reflecte reports of adverse events, but are subject to reporting and other biases. One analysis of AERS data focused on granulomatous infections in general. It indicated a higher rate among patients treated with infliximab (239 cases per 100,000 patients) than with etanercept (74 cases per 100,000 patients).280 The rate of TB in this study was 144 cases per 100,000 patients for infliximab and 35 cases per 100,000 patients for etanercept. However, incidence rates must be compared cautiously because this study reported cases per treated patients and not per patient years.280 Another AERS analysis reported histoplasmosis to be related to treatment with etanercept and infliximab.286

Two observational studies assessed the risk of herpes zoster infection with biologic DMARDs.224, 225 A good-rated prospective cohort study of 5,040 patients with RA initiating treatment with adalimumab, etanercept, or infliximab reported a statistically nonsignificant but potentially clinically significant increase in the risk of herpes zoster infection (HR, 1.63; 95% CI, 0.97 to 2.74).225 This risk was greatest among patients treated with adalimumab or infliximab (HR, 1.82; 95% CI, 1.03 to 3.15) in comparison with those treated with etanercept (HR, 1.36; 95% CI, 0.73 to 2.55). A fair-rated retrospective cohort study of patient in a U.S. claims database and patients from the UK General Practice Research Database found a risk of herpes zoster infection of similar magnitude (OR, 1.54; 95% CI, 1.04 to 2.29).224

One case-control study compared the risk of surgical site infections in patients taking anti-TNF drugs and patients taking oral DMARDs among patients with RA undergoing joint surgery.327 In this relatively small study (N=128) the risk of infection was significantly greater among patients in the anti-TNF drug group (OR, 21.8; 95% CI, 1.2 to 386.1; P=0.036).

Infusion and injections site reactions. Infusion reactions (abatacept, infliximab, rituximab, tocilizumab) and injection site reactions (adalimumab, anakinra, certolizumab, etanercept, golimumab) were the more commonly and consistently reported adverse events. Most infusion reactions were nonspecific symptoms such as headache, dizziness, nausea, pruritus, chills, or fever. Studies reporting infusion or injection site reactions in patients treated with biologic DMARDs are presented in Table 53.

In clinical trials of infliximab for the treatment of RA or Crohn’s disease, 17 percent of patients experienced infusion reactions; 0.5 percent were severe and resembled acute anaphylactic conditions or led to convulsions.273 In these trials, however, less than 2 percent of patients discontinued because of infusion reactions.273 A prospective cohort study of infliximab in a Canadian clinical care setting reported substantially higher rates of reactions than did the clinical trials.329 Specifically, in the community study (113 patients with 1,183 infusions), 53 percent of patients experienced at least one infusion reaction during the course of the therapy (mean 15 months). Reactions with infliximab were reported more commonly than with other biologic DMARDs in an RCT comparing abatacept and infliximab,66 and in a retrospective cohort study comparing adalimumab (injection site reaction), etanercept, and infliximab.253 In the randomized trial, 7.1 percent of those treated with abatacept and 24.8 percent of those treated with infliximab had an infusion reaction.66 In the retrospective cohort study, the risk of infusion reaction (or systemic allergic reaction with adalimumab) was more than twofold greater with infliximab compared with injection site reactions with adalimumab and etanercept (HR, 2.11; 95% CI, 1.23 to 3.62; P=0.018).253 While comparative data on infusion reactions were not available for rituximab and tocilizumab, two RCTs reported similar rates of infusion reactions; 23 percent158 and 28 percent.161

Injection site reactions were mainly erythema, pruritus, rash, and pain of mild to moderate severity, and they were the most common reason for discontinuation blamed on adverse events. A systematic review reported that the mean, crude incidence rates of injection site reactions in RCTs and observational studies were 17.5 percent (95% CI, 7.1 to 27.9) for adalimumab, 22.4 percent (95% CI, 8.5 to 36.3) for etanercept, and 67.2 percent (95% CI, 38.7 to 95.7) for anakinra.49 Injection site reactions for adalimumab were slightly higher than this estimate (31.7 percent) in an RCT of 352 patients with RA.125 The substantially higher incidence of injection site reactions for anakinra than for adalimumab and etanercept is consistent with rates reported in the respective package inserts.300, 330, 331 A German retrospective study based on postmarketing surveillance data, however, reported a lower incidence of injection site reaction for anakinra than was reported in clinical trials (20 percent).320

Interstitial lung disease. The risk of interstitial lung disease with biologic DMARDs was assessed by one fair-quality prospective cohort study conducted in 17,598 patients with RA in the NDB study (Table 54).228 This study found that current treatment with etanercept and infliximab was not associated with hospitalization for interstitial lung disease. However, past treatment with etanercept (HR, 1.7; 95% CI, 1.0 to 3.0; P=0.056) and infliximab (HR, 2.1; 95% CI, 1.1 to 3.8; P=0.019) was associated with hospitalization for interstitial lung disease.

Malignancies. The risk of lymphoma, both Hodgkin and non-Hodgkin lymphoma, is generally increased in patients with RA compared with the general population.332 Data from controlled trials do not provide sufficient evidence concerning a further increase in their risk of cancer attributable to the use of either biologic DMARDs or a combination of biologic and synthetic DMARDs. Findings from retrospective observational studies are mixed (Table 55).

Several cohort studies have assessed risk of lymphoma with anti-TNF drugs. An analysis of spontaneously reported cases of lymphoma associated with etanercept or infliximab suggested a median time of 8 weeks from start of therapy to lymphoma diagnosis, and some cases spontaneously remitted after biologic DMARD discontinuation.333 A large prospective cohort study followed 18,572 RA patients in a registry for up to 3 years.289 The risk of lymphoma was higher for patients on anti-TNF therapies than for those on oral DMARDs, although not statistically significantly so. Confidence intervals for treatment groups overlapped and the results were insufficient to establish a causal relationship between RA treatments and lymphoma or to delineate differences in risks among treatments. The standardized incidence rate (SIR) in the overall cohort was 1.9 cases per 100,000. The SIR for patients not receiving MTX or any biologic agents was 1.0. The SIRs for patients on specific drugs were as follows: MTX, 1.7 (95% CI, 0.9 to 3.2); infliximab, 2.6 (95% CI, 1.4 to 4.5); and etanercept, 3.8 (95% CI, 1.9 to 7.5). An update of this analysis with additional patients and follow-up time confirmed that the risk of lymphoma was not increased among patients taking adalimumab, etanercept, and infliximab.290

Three community-based, retrospective cohort studies from Sweden, Canada, and the United States, however, did not detect any differences in the risks of lymphoma between patients on anti-TNF treatment and those on oral DMARDs.291–293 The largest study included 4,160 patients treated with anti-TNF drugs.292 Results yielded an adjusted relative risk of 1.1 (95% CI, 0.6 to 2.1) for anti-TNF patients relative to patients on oral DMARDs.

Data from observartional studies and meta-analyses are also mixed regarding an increased risk for overall malignancies in patients treated with biologic DMARDs. Four meta-analyses have evaluated risk of malignancy with anti-TNF drugs.183, 255, 271, 294 Effect size estimates were not statistically significant in three of these analyses, but one fair-rated meta-analysis of more than 5,000 RA patients from adalimumab and infliximab efficacy trials reported a pooled odds ratio for malignancies of 3.3 (95% CI, 1.2 to 9.1). The number needed to harm (NNH) was 154 (95% CI, 91 to 500) within a treatment period of 3 months to 12 months.

Five large cohort studies do not suggest a statistically significant increase in risk of malignancy.276, 293, 295–297 For example, the largest of these two studies, based on data on more than 60,000 Swedish patients, found SIRs for solid cancers to be similar for RA patients treated with anti-TNF medications and those on conventional therapy using both a contemporary and a historic control group. In another Swedish analysis of 6,366 patients with RA during 25,693 person years of followup, the risk of first cancer did not differ for patients starting anti-TNF drug therapy and patients starting MTX (RR, 1.00; 95% CI, 0.86 to 1.15).295 In a cohort of 8,458 patients with RA from the U.S. and Canada, no increase in risk of overall malignancies was observed for patients taking anti-TNF drugs relative to patients taking oral DMARDs.293 In a German cohort of 5,120 patients with RA who had failed at least one other DMARD therapy (RABBIT), no statistically significant increase in the adjusted risk of developing malignancy was observed for anti-TNF drugs (HR, 0.7; 95% CI, 0.44 to 1.12; P=0.133) and anakinra (HR, 1.39; 95% CI, 0.56 to 3.48; P=0.48).297 An Italian cohort from the Lombardi Rheumatology Network (LOHREN) registry reported an overall cancer risk for 1,114 RA patients treated with anti-TNF drugs to be similar to the general population, with no statistically significant differences observed among anti-TNF drugs.296

A clinical trial database review did not detect a higher incidence of squamous cell carcinoma in 1,442 RA patients (4,257 person-years) treated with etanercept (crude rate: 2.8 cases/1,000 patients) than for those on placebo;334 the median follow-up time was only 3.7 years. A larger retrospective cohort study (N=15,789), however, reported a statistically significant association of a combination of anti-TNF and MTX treatment and nonmelanoma skin cancer (hazard ratio [HR]: 1.28; 95% CI, NR; P=0.014).242 This finding also was observed in a large prospective cohort study of 13,869 patients in the U.S. NDB study taking adalimumab, anakinra, etanercept, and infliximab.335 These biologic DMARDs were associated with an increased risk of nonmelanotic skin cancer (OR, 1.5; 95% CI, 1.2 to 1.8) and melanoma (OR, 2.3; 95% CI, 0.9 to 5.4).

Other adverse events. Evidence from randomized trials and observational studies is insufficient to draw conclusions regarding the comparative risk of rare but serious adverse events such as demyelination, autoimmunity, pancytopenia, and hepatotoxicity (Table 56). Reports based on data from the FDA’s AERS indicated that adalimumab, etanercept, and infliximab might be associated with demyelination.298, 299, 336 Similar cases have been seen in regulatory trials of adalimumab.300 All neurologic events partially or completely resolved after discontinuation of treatment.

Similarly, reports of autoimmunity have not been confirmed in controlled trials and observational studies. However, case reports suggest an association between infliximab and drug-induced lupus and other autoimmune diseases.273, 301–303 Lupus-like syndromes have also been reported for adalimumab.298 Development of antinuclear, antidouble-stranded DNA, or antihistone antibodies have also been reported in regulatory trials of other anti-TNF-α drugs.300, 330

The infliximab package insert reports that 34 percent of patients treated with infliximab and MTX experienced transient elevations of liver function parameters.301 Severe liver injury, including acute liver failure, has been reported. One study, the Chugai Humanized Anti-Human Recombinant Interleukin-6 Monoclonal Antibody (CHARISMA) trial,174 reported data on liver function tests. This trial compared MTX, tocilizumab plus MTX, and tocilizumab monotherapy over 20 weeks in 359 patients with RA. Both tocilizumab groups had elevated liver enzymes compared with MTX monotherapy. Liver enzymes were most elevated in the tocilizumab plus MTX group. In a prospective cohort of 6,861 patients from the Consortium of Rheumatology Researchers of North America (CORRONA) registry, compared with patients receiving other nonbiologic DMARD treatments, liver enzymes were elevated for adalimumab- (OR, 1.72; 95% CI, 0.99 to 3.01) and infliximab-treated (OR, 2.40; 95% CI, 1.53 to 3.76) patients but not for etanercept-treated patients (OR, 1.10; 95% CI, 0.64 to 1.88).337

A prospective cohort study (N=578) indicated that patients on anti-TNF treatments developed dermatological conditions (skin infections, eczema, drug-related eruptions) statistically significantly more often than anti-TNF-naive patients over a median treatment time of 2.3 years (25 percent vs. 13 percent; P<0.0005).304 Another retrospective cohort study of 12,076 patients with severe RA from the BSRBR failed to find an overall association of anti-TNF drugs with risk of psoriasis.305 Among the three biologic DMARDs included, adalimumab had a significantly increased risk of psoriasis compared with those treated with etanercept (IRR, 4.6; 95% CI, 1.7 to 12.1) and infliximab (IRR, 3.5; 95% CI, 1.3 to 9.3).

One cross-sectional analysis of data from 7,243 patients in the prospective cohort of the NDB study assessed the relationship of treatment with adalimumab, etanercept, and infliximab with physician visits for sinus problems.244 A small elevated risk was observed among patients treated with etanercept (OR, 1.21; 95% CI, 1.02 to 1.42). No statistically significant increased risk of sinus problems was observed with adalimumab (OR, 1.09; 95% CI, 0.79 to 1.51) or infliximab (OR, 1.00; 95% CI, 0.88 to 1.15).

Adherence. The published literature in this area frequently uses the terms compliance and adherence interchangeably. Compliance has traditionally been used to describe a patient’s ability to take medications as prescribed. Some authors argue, however, that adherence better represents the more complex relationship among patients, providers, and medications; it is meant to reflect the fact that following a medication regimen is not necessarily a simple choice.338 Given the lack of a clear definition, we use the term adherence. Table 57 summarizes studies for adherence.

Table 57 Studies assessing adherence in patients with rheumatoid arthritis

Author, Year | Study Type and Interventions | N | Results
Boers et al., 1997^95^ | RCT MTX+SSZ+prednisolone vs. SSZ | 155 | Compliance satisfactory in 85%
Emery et al., 2000^105^ | RCT LEF vs. MTX | 999 | Reason for withdrawal: noncompliance in the 1st year: LEF 11 (2%) vs. MTX 14 (3%) noncompliance in the 2nd year: LEF 6 (2%) vs. MTX 6 (2%)
Fleischmann et al., 2003^259^ | RCT AKA vs. placebo | 1,414 | AKA vs. placebo: 100% adherent with use of study drug: 43.8% vs. 47.8% <70% adherent with use of study drug: 0.8% vs. 1.7% >40% missed no injections >90% received at least 90% of intended doses
Goekoop-Ruiterman et al., 2005^100^ | RCT Four treatment strategies | 508 | 24 (5%) were nonadherent
*Grijalva et al., 2007^339^ | Retrospective cohort study Oral and Biologic DMARDs | 6,018 | SSZ, MTX+HCQ, MTX+INF, MTX+ETN, MTX+ADA, and ANK or ANK+MTX less adherent than MTX (P=0.014; P<0.001; P<0.001; P<0.001; P=0.001; P=0.008; respectively) LEF, INF, ETN, ADA more adherent than MTX (P<0.001; P<0.001; P<0.001; P=0.005; respectively)
Haagsma et al., 1997^58^ | RCT SSZ+MTX vs. SSZ or MTX | 105 | Percentage of tablets taken>90% (pill count)
Harley et al., 2003^306^ | Retrospective database analysis INF vs. ETN vs. MTX | 2,662 | INF more adherent than ETA or MTX (P<0.05)
*Hetland et al., 2010^73^ | Prospective cohort ADA vs. ETA vs. INF | 2,326 | Drug adherence rates at 48 months: ADA, 52% (95% CI, 46 to 57); ETN, 56% (95% CI, 51 to 62); INF, 41% (95% CI, 37 to 44); P<0.0001
Hyrich et al., 2006^81^ | Prospective observational study | 2,711 | Remained on treatment at 6 months: ETN 80% vs. INF 79% ETN subgroups (22% monotherapy, 16% MTX co-therapy, 19% DMARD co-therapy) INF subgroups (30% vs. 21% MTX co-therapy, vs. 22% DMARD co-therapy)
*Li et al., 2010^307^ | Retrospective cohort ANK vs. ETA vs. INF | 5,390 | Adherence rates measured by PDC ≥0.8): ANK: 10.5% (P<0.05) ETA:32% INF:43%
*Kristensen et al., 2006^69^ | Prospective cohort study ETN vs. INF | 949 | Withdrawals due to adverse events (P<0.001) and withdrawals due to lack of efficacy (P=0.018) more common for INF than for ETN
*Kristensen et al., 2006^251^ | Prospective cohort study ETN vs. INF | 1,161 | INF less adherent than ETN for all subgroups (P<0.001). Adherence at 5 years 69% for INF+MTX vs. 89% for ETN+MTX (P<0.001).
Kremer et al., 2002^340^ | RCT LEF+MTX vs. placebo+MTX | 263 | Overall, 98% adherent Adherence rates 80%–120% LEF, 87.7% placebo 90.2%
*Russell et al., 2007^116, 254^ | RCT ABA+MTX vs. placebo+MTX | 652 | ABA+MTX adherence 89% MTX placebo adherence 74%
Strand et al., 1999^104^ | RCT LEF vs. MTX vs. placebo | 402 | Nonadherence as the reason for withdrawal: LEF (1) MTX (1)

* New study added since last review.

ABA = abatacept; ADA = adalimumab; AKA = anakinra; DMARD = disease-modifying antirheumatic drug; ETA = etanercept; HCQ = hydroxychloroquine; INF = infliximab; LEF = leflunomide; MTX = methotrexate; RCT = randomized controlled trial; SSZ = sulfasalazine

The majority of RCTs that reported adherence stated a rate between 85 percent and 100 percent. Seven published studies reported levels of adherence in RCTs.58, 95, 100, 105, 116, 254, 259, 340 Most, however, contained only minimal information, and many did not stratify by treatment. Furthermore, they provided little or no information on the methods of assessment. For example, one study reported that adherence was satisfactory in 85 percent of patients, but the investigators did not describe their method of determining adherence.95 Only four of the seven RCTs reported adherence rates for different treatment arms.105, 116, 254, 259, 340 None of these studies noted a significant difference in adherence (although differences in discontinuation rates were noted in many trials). To what extent results from these highly controlled efficacy trials can be extrapolated to effectiveness settings remains unclear.

A retrospective database analysis used a large U.S. health plan, which included commercial and Medicare insurance, to examine adherence levels in 2,662 patients being treated with infliximab, etanercept, or MTX from November 1999 to December 31, 2001.^306^ The primary outcome measured was the number of drug administrations or prescriptions filled, divided by the expected number during a 365-day period. Their primary finding was that patients on infliximab were significantly more adherent than patients on etanercept or MTX. After controlling for baseline covariates (age, sex, baseline cost, insurance type, health plan region, history of therapy of RA, comorbidities, type of physician), 81 percent of the patients receiving infliximab were adherent compared with 68 percent of the etanercept and 64 percent of the MTX patients (P<0.05 for infliximab vs. both other drugs) over 1 year. This finding was supported by a retrospective cohort study of 5,390 patients taking anakinra, etanercept, or infliximab. In this study, adherence measured by the proportion of days covered was 43 percent for infliximab, but only 32 percent for etanercept and 10.5 percent for anakinra (P<0.05).307 Another observational study reported similar adherence for etanercept and infliximab.81 However, this is contradicted by three additional cohort studies.69, 73, 251 A prospective cohort study of 1,161 patients taking etanercept or infliximab, where infliximab-treated patients were less adherent than etanercept-treated patients (P<0.001).251 Adherence at 5 years was 69 percent for the infliximab group and 89 percent for the etanercept group. In an analysis of 949 patients derived from the same Swedish registry, withdrawals due to adverse events (P<0.001) and withdrawals due to lack of efficacy (P=0.018) were more common for infliximab than for etanercept.69 In a prospective cohort study of 2,326 patients taking adalimumab, etanercept, or infliximab, drug adherenc rates at 48 months were 52 percent for adalimumab, 56 percent for etanercept, and 41 percent for infliximab (P<0.0001).73

A retrospective cohort study of 6,018 patients measured adherence with multiple oral DMARDs, biologic DMARDs, and combinations of DMARDs. Compared with patients on MTX monotherapy, patients taking monotherapy sulfasalazine or anakinra, and patients taking MTX plus hydroxychloroquine, adalimumab, anakinra, etanercept, and infliximab had lower adherence.339 Patients on monotherapy leflunomide, adalimumab, etanercept, or infliximab had better adherence than patients on monotherapy MTX. However, these differences might also be capturing decrements in adherence related to measurement or to behavior with taking more than one treatment at the same time (since combination treatments had lower adherence).

## Key Question 4 Benefits and Harms for Selected Populations

This key question (KQ) addressed the comparative benefits and harms of drug therapies for rheumatoid arthritis (RA) in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities. Early RA as a stage of disease and history of prior therapy were addressed under KQ 1; however, we present one study here that grouped subjects by early RA versus more advanced RA. We did not find studies that exclusively compared MTX-naive RA groups with those with RA who were MTX-experienced.

### Overview

We focused on groups defined by stage of disease, demographics (age, sex, race, or ethnicity), concomitant therapies, and comorbidities (any comorbidity, cardiovascular disease, osteoporosis, and renal disease). We included five good or fair quality studies: two RCTs, one subgroup analysis of multiple RCTs, one database analysis, and one systematic review met the inclusion criteria for this key question.

Stage of disease. One fair quality post-hoc analysis of two RCTs341 compared those treated with MTX or etanercept or a combination of both in patients with moderate RA with those in a severe disease activity state. Generally, patients with moderate RA achieved significantly better DAS28 and HAQ results than those with severe RA; however, those with severe disease activity on etanercept or MTX monotherapies had greater change scores from baseline in DAS28.

Demographics. We found no studies that conducted comparisons by sex, race, or ethnicity, but we did include one fair systematic review that addressed age,342 one pooled analysis of RCTs,298 and a secondary database analysis of Medicare patients.216

One systematic review by the Rheumatoid Arthritis Clinical Trial Archive Group found an inverse relationship between age and major clinical improvement.342 Of the three trials reviewed, the differences between the odds ratios was small.342 One study directly compared the efficacy of etanercept in elderly RA patients (65 years of age or older) with younger RA patients (under 64 years of age and older than 18) and found no significant difference in functional status between age groups.298 The secondary database analysis reported that in the elderly, the risk of cardiovascular events was higher in those who were treated with oral glucocorticoids or cyctotoxic immunosuppressant agents such as leflunomide, whereas biologic agents (abatacept, intanercept, infliximab, anakina) were found to have no beneficial or harmful effect.216

Concomitant therapies. We found no evidence from head-to-head comparisons, placebo-controlled trials, or observational studies on other treatment therapies. Differences based on comparisons of various combinations of RA medications are addressed in KQs 1 through 3. An analysis of data from one placebo-controlled trial involving RA patients receiving anakinra determined that the safety profiles did not differ in subjects receiving antihypertensive, antidiabetic, or statin medication treatments.343

Comorbidities. We identified two studies that addressed outcomes of RA patients with comorbidities. For RA patients with various high-risk conditions, one large placebo-controlled RCT of anakinra reported that there was no difference in serious adverse events or infections between the treated and placebo groups.344 A systematic review of 11 MTX trials of RA patients determined that those with renal impairment were directly at greater risk for experiencing MTX toxicity, and the greater the renal impairment the greater the toxicity effects.342

We present detailed analyses below for the population groups noted above. Details about included studies are presented by subgroup analysis in Tables 64 to 68 (listed alphabetically within outcome sections).

### Detailed Analysis

Stage of disease. A fair quality post-hoc analysis of TEMPO and ERA study data (Table 58)341 looked at response to etanercept or MTX, or a combination of both, in regard to the patient’s stage of RA—moderate (DAS20>3.2 and ≤5.1) or severe (DAS28>5.1). Although there were similarities between the two trial populations, the TEMPO subjects in this analysis had RA longer (6.6 vs. 1 mean years) and greater prior MTX use (43 percent vs. 0 percent) than the ERA group. Both analysis groups were primarily patients with severe RA (94 percent vs. 84.3 percent); however, the percentage of ERA patients with moderate RA was more than twice that in the TEMPO group (15.7 percent vs. 6 percent), making the TEMPO analysis group a more severe population than the ERA group overall. The authors did not report any P values for differences between groups on baseline characteristics.

Table 58 Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis: By stage of disease

Study | Study Design N Duration | Study Population | Interventions | Outcomes | Quality Rating
Keystone et al., 2009^341^ | Post-hoc analysis of two RCTs 1,091 12 months | Adults with moderate vs. severe RA treated with MTX, etanercept monotherapies or combinations | MTX (dose NR), ETN (25 mg twice weekly), MTX+ETN | Significant differences favored those with moderate RA in DAS28 and HAQ scores vs. those with severe stage, but greater gains from baseline scores for DAS28 were seen in the those with severe RA | Fair

ETN = etanercept; MTX = methotrexate; NR = not reported; RA = rheumatoid arthritis; RCT = randomized controlled trial

Investigators reported significant differences in DAS28 remission at 6 months in TEMPO patients with moderate RA treated with MTX or etanercept monotherapies or combination compared with those with severe RA. This significant trend continued for the MTX-only or MTX-etanercept combination groups at 12 months, but not for those treated with etanercept alone (MTX: P=0.0035; MTX plus etanercept: P=0.0006). In the ERA analysis, both those treated with MTX or etanercept monotherapies for moderate RA, achieved significant DAS28 improvements at both 6 months (MTX: P=0.0058; etanercept: P=0.0003) and 12 months (MTX: P=0.0094; etanercept: P<0.0001).341

A significant difference in low disease activity level was achieved by those with moderate RA in both trial groups at both 6 and 12 months in all treatment groups except those treated with etanercept monotherapy in the TEMPO study. Mean DAS28 scores were consistently lower in moderate RA groups in comparison with those with severe RA; however, mean changes in DAS28 scores at 12 months were significantly greater in those with severe RA (ERA trial: MTX only: 1.2 vs. 2.4, P<0.0001; etanercept only: 1.7 vs. 2.4 P<0.0110; TEMPO trial: MTX only: 1.6 vs. 2.6, P<0.0076; etanercept only: 1.5 vs. 2.7, P<0.0268; MTX plus etanercept 2.5 vs. 3.5, P<0.0069).341

Twelve-month changes in HAQ scores from baseline showed significant differences between moderate and severe disease activity in the MTX-only group from the TEMPO trial and the two monotherapies in the ERA trial (TEMPO trial: MTX only 0.29 vs. 0.68, P=0.0138; etanercept only 0.42 vs. 0.74, P=0.1329; MTX plus etanercept 0.74 vs. 1.00, P=0.0895; ERA trial: MTX only 0.44 vs. 0.77, P=0.0107; etanercept only 0.45 vs. 0.75, P=0.0070).341

In regard to radiographic changes, only the MTX monotherapy group in the TEMPO trial showed significant differences in median change of total sharp scores between moderate and severe RA patients (1.00 vs. 2.57, P=0.014).341

Demographics. We identified one study analyzing MTX use in the elderly and one database analysis of various agents of a Medicare population.216, 342 Table 59 presents the studies of adults with RA that conducted comparisons by age groups.

Table 59 Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis: By age

Study | Study Design N Duration | Study Population | Interventions | Outcomes | Quality Rating
Rheumatoid Arthritis Clinical Trial Archive Group 1995^342^ | Systematic review 496 ≥12 weeks | Adults with RA by age subgroups: under 60 years of age; 60 to 64 years; 65 to 69 years; and 70 years or above | MTX | Adjusted analysis demonstrated that as age increases, the odds ratio for major clinical improvement decreases; no effect found on toxicity | Fair
Solomon et al., 2006^216^ | Nested case control database analysis (Medicare and PACE) 946 ≤24 months | Elderly adults with RA | MTX, ADA, ETN, INF, AKA, AZA, CSA, LEF, HCQ, SSZ, gold, and all oral glucocorticoid agents | Oral glucocorticoids and cytotoxic immunosuppressive agents increased risks for cardiovascular events, biologics neither increased risk or decreased risk | Fair

ADA = adalimumab; AERS = adverse events reporting system; AKA = anakinra; AZA = azathioprine; CHF = congestive heart failure; CSA = cyclosporine A; ETN = etanercept; HCQ = hydroxychloroquine; INF = infliximab; LEF = leflunomide; MTX = methotrexate; NA = not applicable; PACE = pharmaceutical assistance contract for the elderly; RA = rheumatoid arthritis; RCT = randomized controlled trial; SSZ = sulfasalazine; TNF = tumor necrosis factor

The Rheumatoid Arthritis Clinical Trial Archive Group 1995 review of 11 MTX trials for adults with RA evaluated the effects of age or renal impairment on adverse events or treatment efficacy.342 Although the authors reported that the odds for major clinical improvement dropped slightly as age increases, among all clinical trial patients, age did not affect MTX efficacy or the rate of side effects. Using the group under age 60 as the referent, the odds of major clinical improvement for those 60 to 64 years of age was 1.4 (95% CI, 0.7 to 2.6), 1.0 (95% CI, 0.5 to 2.2) for those 65 to 69 years of age, and 0.7 (95% CI, 0.3 to 1.7) for those 70 years of age or older (P=NR).

A fair quality nested case control study investigating cardiovascular events in 946 RA patients was conducted using data from Medicare enrollees also receiving benefits from the state of Pennsylvania Pharmaceutical Assistance Contract for the Elderly Program.216 Index dates were established as the first cardiovascular event within patients who had a diagnosis of RA on at least two visits and a prescription of an immunosuppressant agent (MTX, adalimumab, etanercept, infliximab, anakinra, azathioprine, cyclosporine, leflunomide, gold, hydroxychloroquine, sulfasalazine, and all oral glucocorticoid agents) within 90 days of the index event. Using MTX as the reference group, oral glucocorticoids (monotherapy: OR, 1.5; 95% CI, 1.1 to 2.1; combinations: OR, 1.3; 95% CI, 0.8 to 2.0) and cytotoxic immunosuppressive agents: azathioprine, cyclosporine, and leflunomide (OR, 1.8; 95% CI, 1.1 to 3.0) were associated with an increased risk for cardiovascular events. Biologics (adalimumab, etanercept, infliximab), on the other hand, had no effect on risk for developing or preventing a cardiovascular event (monotherapy: OR, 1.0; 95% CI, 0.5 to 1.9; combination with MTX: OR 0.8; 95% CI, 0.3 to 2.0; combination with other immunosuppressive agents OR, 1.2; 95% CI, 0.7 to 2.2).216

Concomitant therapies. One placebo-controlled trial of 1,399 adults with active RA disease examined safety profiles of those treated with 100mg/day anakinra (Table 60). Investigators failed to find any differences in the adverse event profiles of the subjects taking or not taking concomitant antihypertensive, antidiabetic, or statin pharmacotherapies. Even when the analysis compared those treated with anakinra with those on placebo, no differences emerged (P=NR).343

Table 60 Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis: By concomitant therapies

Study | Study Design N Duration | Study Population | Intervention | Outcomes | Quality Rating
Tesser et al., 2004^343^ | RCT 1,399 6 months | Adults with RA taking or not taking antihypertensive, antidiabetic, or statin pharma-cotherapies | ANK, 100mg/day | No significant difference found in safety profiles | Fair

ANK = anakinra; RA = rheumatoid arthritis; RCT = randomized controlled trial

Comorbidities. Table 61 presents three studies identified as addressing comorbidities.

Table 61 Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis by comorbidities

Study | Study Design N Duration | Study Population | Interventions | Outcomes | Quality Rating
Rheumatoid Arthritis Clinical Trial Archive Group, 1995^342^ | Systematic review of 11 RCTs 454 NA | RA patients with impaired renal function treated with MTX | MTX | Severe toxicity (severe upper abdominal pain, renal failure, proteinurea, cytopenias and liver toxicity) and respiratory toxicity (cough, pneumonitis, dyspnea, wheezing) worse with greater renal impairment | Fair
Schiff et al., 2004^344^ | RCT 951 6 months | RA patients with high-risk comorbid conditions | ANK, 100 mg/day | In patients with comorbid conditions, no differences were found between treatment groups in regard to incidence of serious adverse events or overall infectious events | Fair

ANK = anakinra; MTX = methotrexate; NA = not applicable; RA = rheumatoid arthritis; RCT = randomized controlled trial

Any comorbidity. We did not identify any study specifically designed to assess the comparative efficacy and risk of biologic DMARDs (abatacept, adalimumab, anakinra, certolizumab, etanercept, golimumab, infliximab, rituximab, or tocilizumab) in RA patients with common comorbidities. A post-hoc subgroup analysis of a large safety trial determined the safety profile of anakinra in patients with various comorbidities (cardiovascular events, pulmonary events, diabetes, infections, malignancies, renal impairment, and central nervous system-related events).344 Overall, the incidence rates of adverse events were similar regardless of comorbidity status.

Cardiovascular morbidity. No direct evidence exists on the comparative risk of biologic DMARDs in patients with both RA and cardiovascular disease.

Renal function. A systematic review of 11 RCTs of MTX use in 496 adults with RA concluded that toxicity worsened with greater renal impairment. Patients with high renal impairment had a fourfold risk (OR, 4.5; 95% CI, 0.9 to 22.6) for severe toxicity (severe upper abdominal pain, renal failure, proteinurea, cytopenias, and liver toxicity) than those with no renal impairment. Slightly more (4 percent vs. 1 percent) had respiratory toxicity (cough, pneumonitis, dyspnea, wheezing). No effect was found between renal impairment and increased liver toxicity.342 Baseline renal function was found to be a significant predictor of toxicity, with the lower creatinine clearances ending up with greater toxicity (P=0.027).342