# Peer Reviewers

Joan M. Bathon, M.D.

Professor of Medicine

Division of Rheumatology

Department of Medicine

Johns Hopkins University

Director, Johns Hopkins Arthritis Center

Co-Deputy Director, Division of Rheumatology

Bayview Medical Center

Baltimore, MD

Louis Bridges, Jr., M.D., Ph.D.

Professor of Medicine and Microbiology

Director of the Division of Clinical Immunology and Rheumatology

Deputy Director of the Comprehensive Arthritis, Musculoskeletal, and Autoimmunity Center

University of Alabama at Birmingham

Birmingham, AL

Marion McDonagh, Pharm.D.

Assistant Professor

Informatics and Clinical Epidemiology

Oregon Health & Science University

Portland, OR

James O’Dell, M.D.

Professor and Program Director

Department of Internal Medicine

University of Nebraska

Lincoln, NE

Nancy Olsen, M.D.

McGee Foundation Distinguished Professor in Arthritis Research

Internal Medicine – Rheumatic Diseases

UT Southwestern Medical School

Dallas, TX