# Methods

In this chapter, we document the procedures that the RTI International–University of North Carolina Evidence-based Practice Center (RTI–UNC EPC) used to develop this comparative effectiveness review (CER) on pharmacologic treatments for rheumatoid arthritis. We briefly describe the topic development process below. We then document our literature search and retrieval process and describe methods of abstracting relevant information from the eligible articles to generate evidence tables. We also document our criteria for rating the quality of individual studies and for grading the strength of the evidence as a whole.

## Topic Development

This report is an update of a CER completed in 2007.^26^ The topic of the original report and the preliminary Key Questions (KQs) arose through a public process involving the public, the Scientific Resource Center (SRC, at www.effectivehealthcare.ahrq.gov/aboutUs/index.cfm#RC) for the Effective Health Care program of the Agency for Healthcare Research and Quality (AHRQ) (www.effectivehealthcare.ahrq.gov), and various stakeholder groups (www.effectivehealthcare.ahrq.gov/aboutUs/index.cfm#SG). Investigators from the RTI-UNC EPC then refined the original questions into the KQs used for the original report, in consultation with AHRQ, the SRC, and the Technical Expert Panel (TEP) during multiple conference calls. For this update, the original KQs were again refined into the final set of KQs cited in the introduction. No substantive changes to the KQs were made for this update other than adding new medications that have been approved since the previous report. The protocol for the project was posted on the AHRQ Web site (www.effectivehealthcare.ahrq.gov). The original report included both rheumatoid arthritis (RA) and psoriatic arthritis (PsA). When updating the material, the decision was made to divide into the material into two separate reports, one for RA and one for PsA. This report includes only the information related to patients with RA. This report is intended to replace the original report; it includes the information from the original report as well as the new information we identified.

## Literature Search

To identify articles relevant to each KQ, we searched MEDLINE®, Embase, the Cochrane Library, and the International Pharmaceutical Abstracts. The full search strategy is presented in Appendix A. We conducted this review at the same time as a review on PsA; the literature searches and review processes were conducted in parallel, shown in Appendix A. We used either Medical Subject Headings (MeSH or MH) as search terms when available or key words when appropriate. We combined terms for selected indications (RA, PsA), drug interactions, and adverse events with a list of included medications. We included the following medications: corticosteroids (methylprednisolone, prednisone, and prednisolone), four oral disease-modifying antirheumatic drugs (DMARDs) (methotrexate [MTX], leflunomide, sulfasalazine, and hydroxychloroquine), and nine biologic DMARDs (abatacept, adalimumab, anakinra, certolizumab pegol, etanercept, golimumab, infliximab, rituximab and tocilizumab). We limited the electronic searches to “human” and “English language.” For the original report, sources were searched from 1990 to September 2006. For this update, sources were searched from June 2006 to January 2011. We overlapped the update search with the original search to account for delays in indexing. We used the National Library of Medicine publication type tags to identify reviews, randomized controlled trials (RCTs), and meta-analyses. We manually searched reference lists of pertinent review articles and letters to the editor to supplement searches for the original report. We used the Scopus™ abstract and citation database to supplement searches for this update. We imported all citations into an electronic database (EndNote X.0.2). Additionally, we hand-searched the Center for Drug Evaluation and Research (CDER) database to identify unpublished research submitted to the U.S. Food and Drug Administration (FDA). The SRC contacted pharmaceutical manufacturers and invited them to submit dossiers, including citations. We received dossiers from five pharmaceutical companies (Abbott, Amgen, Bristol-Myers Squibb, Centocor, and Genentech) for the original report. We received dossiers from six pharmaceutical companies (Abbott, Amgen, Centocor, Horizon, Genentech, and UCB) for this update. The SRC also searched the following for potentially relevant unpublished and ongoing literature: FDA Web site; Health Canada; Authorized Medicines for EU; ClinicalTrial.gov; Current Controlled Trials, Clinical Study Results, WHO Clinical Trials, Conference Papers Index; Scopus; NIH RePORTER; HSRPROJ; Hayes, Inc. Health Technology Assessment; and the New York Academy of Medicine’s Grey Literature Index.

## Study Selection

We developed eligibility (inclusion and exclusion) criteria with respect to study design or duration, patient population, interventions, outcomes, and comparisons for each KQ, as described in Table 5. For efficacy and effectiveness, we focused on head-to-head trials and prospective cohort studies comparing one drug with another. For biologic DMARDs, we also included placebo-controlled, double-blind RCTs. For harms and tolerability, as well as for efficacy and effectiveness in subgroups, we included head-to-head trials, high-quality systematic reviews, and observational studies.

Table 5 Outcome measures and study eligibility criteria

Key Questions, Outcomes of Interest, and Specific Measures | Study Eligibility Criteria
KQ 1/KQ 2:^a^ Efficacy/effectiveness KQ 1:; - Disease activity^b^; - Radiographic joint damage; - Remission; KQ 2:; - Functional capacity; - Quality of life; - Patient-reported symptoms | Study Design; - Head-to-head double-blind RCTs; - Systematic reviews; - Prospective, controlled cohort studies; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Ages 19 or older; - Patients with RA; Sample Size; - RCT N ≥100; - Observational N ≥100
KQ 3: Harms, tolerability, adherence, adverse effects | Study Design; - Head-to-head double-blind RCTs; - Systematic reviews; - Observational studies, prospective and retrospective; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Ages 19 or older; - Patients with RA; Sample Size; - RCT N ≥100; - Observational N ≥100
KQ 4: Benefits and harms in subgroups based on stage, history of prior therapy, demographics, concomitant therapies, comorbidities | Study Design; - Head-to-head double-blind RCTs; - Systematic reviews; - Observational studies; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Ages 19 or older; - Patients with RA; Sample Size; - RCT N ≥100; - Observational N ≥100

KQ = Key Question; N = number of subjects enrolled (i.e. sample size); RA = rheumatoid arthritis; RCT = randomized controlled trial

a We divided the assessment of efficacy/effectiveness into two KQs based on two groups of outcomes: those addressing disease activity, radiographic measures, and remission (KQ 1) and those addressing functional capacity, quality of life, and other patient reported symptoms (KQ 2). We did this to group measures that are based on more objective measures under KQ 1 and those that are based more on subjective patient reported outcomes under KQ 2.

b Disease activity reflects the overall RA activity. Measures of disease activity, such as the American College of Rheumatology 20 percent response (ACR 20), 50 percent response (ACR 50), 70 percent response (ACR 70), and the Disease Activity Score (DAS), include assessment of some or all of the following: the number of swollen and tender joints, the patient’s global assessment of his/her disease activity, the physician’s global assessment of the patient’s disease activity, patient’s pain score, patient’s physical function score, and acute phase reactants (C-reactive protein). Appendix G provides additional details about these measures.

For this review, results from well-conducted, valid head-to-head trials provide the strongest evidence to compare drugs with respect to efficacy, effectiveness, and harms. We defined head-to-head trials as those comparing one drug of interest with another. RCTs or prospective cohort studies of at least 3 months’ duration were eligible for inclusion. Because multiple large RCTs had been conducted on this topic, we adopted a minimum sample size requirement (N ≥100) to focus on the best available evidence. However, we did not use a sample size cutoff for our meta-analyses (RCTs of any sample size were eligible for our mixed treatment comparisons). For harms (i.e., evidence pertaining to tolerability, adverse effects, and adverse events), we examined data from both experimental and observational studies. We included RCTs and observational studies with sample sizes of at least 100 patients that last at least 3 months, and that reported an outcome of interest.

As equipotency among the reviewed drugs is not well established, we assumed that comparisons made within the recommended dosing ranges in the Introduction chapter are appropriate. Dose comparisons made outside the recommended daily dosing range are not in our report. Doses that that could be considered equivalent to the recommended doses, but were not identical to recommended doses are included in the report. For example, 40 mg every other week is a recommended dose for adalimumab and some studies used a 20 mg weekly dosing (not a recommended dose). We considered the 20 mg weekly dose to be equivalent to 40 mg every other week and included studies using the 20 mg every week dose.

Two individuals independently reviewed abstracts (Appendix B contains review criteria for title/abstract stage). If both reviewers agreed that a study did not meet eligibility criteria, we excluded it. We obtained the full text of all remaining articles and used the same eligibility criteria (Appendix B) to determine which, if any, to exclude at this stage. Appendix C lists our full bibliography and their source database. Appendix D summarizes reasons for excluding studies that were reviewed as full-text articles but did not meet eligibility criteria. We did not include studies that met eligibility criteria but were reported as an abstract only.

We reviewed studies that reported health outcomes for efficacy or effectiveness. For example, these outcomes included clinical response to treatment, remission, functional capacity, and quality of life. In addition, we included radiographic outcomes as intermediate outcome measures. For harms, we looked for both total adverse events and specific adverse events ranging in severity (e.g., serious infections, malignancies, hepatotoxicity, hematological adverse events, infusion and injection reactions, and nausea), withdrawals attributable to adverse events, and drug interactions. We included systematic reviews and meta-analyses in our evidence report if we found them to be relevant for a KQ and of good or fair methodological quality. We did not abstract individual studies if they had been used in an included systematic review or meta-analysis of good quality. However, we reviewed them to determine whether any other outcomes of interest were reported.

## Data Extraction

We designed and used a structured data abstraction form to ensure consistency of appraisal for each study. Trained reviewers abstracted data from each study. A senior reviewer read each abstracted article and evaluated the completeness of the data abstraction.

We abstracted the following data from included articles: study design, eligibility criteria, intervention (drugs, dose, and duration), additional medications allowed, methods of outcome assessment, population characteristics (such as age, sex, race or ethnicity, or mean disease duration), sample size, loss to followup, withdrawals because of adverse events, results, and adverse events reported. We recorded intention-to-treat (ITT) results if available. All data abstraction employed SRS 4.0, Mobius Analytics™. Evidence tables containing all abstracted data of included studies are presented in Appendix E.

## Quality Assessment

To assess the quality (internal validity) of trials, we used predefined criteria based on those developed by the U.S. Preventive Services Task Force (ratings: good, fair, poor)30 and the National Health Service Centre for Reviews and Dissemination.31 Elements of quality assessment included randomization and allocation concealment, similarity of compared groups at baseline, use of ITT analysis (i.e., all patients were analyzed as randomized), adequacy of blinding, and overall and differential loss to followup.

In general terms, a “good” study has a low risk of bias and results are considered to be valid. A “fair” study is susceptible to some risk of bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant risk of bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study’s results.

To assess the quality of observational studies, we used criteria outlined by Deeks et al.32 Items assessed included selection of cases or cohorts and controls, adjustment for confounders, methods of outcomes assessment, length of followup, and statistical analysis. To assess the quality of systematic reviews and meta-analyses, we assessed the following: whether the review was based on a clear question, clear reporting of inclusion criteria, methods used for identifying literature (the search strategy), whether two reviewers independently reviewed publications to determine eligibility, whether authors used a standard method of critical appraisal (or quality rating or validity assessment), assessment of heterogeneity, assessment of publication bias, and statistical analysis. Systematic reviews were categorized as good when all criteria were met.

Two independent reviewers assigned quality ratings. They resolved any disagreements by discussion and consensus or by consulting with a third reviewer. Appendix F details the predefined criteria used for evaluating the quality of all included studies. We gave a good-quality rating to studies that met all criteria. We gave a poor-quality rating to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories and excluded them from our analyses. Poor-quality studies and reasons for that rating are presented in Appendix H.

## Applicability Assessment

We used the parameters for evaluation on guidance provided by AHRQ’s Methods Guide for Comparative Effectiveness Reviews,33 to evaluate the applicability of the included studies. Applicability is similar to generalizability or external validity of the studies included in the evidence base. We evaluated applicability using a qualitative assessment of the population, intervention/treatment, comparator, outcomes measured, timing of followup, and setting. We specifically considered whether populations enrolled in these trials or studies differed from target populations as laid out in the Introduction, whether studied interventions are comparable with those in routine use, whether comparators reflect best alternatives, whether measured outcomes reflect the most important clinical outcomes, whether followup was sufficient, and whether study settings were representative of most settings.

## Grading Strength of Evidence

We evaluated the strength of evidence based on methods guidance for the EPC program.33, 34 For this report, we graded the strength of evidence for the outcomes determined to be most important: measures of disease activity (e.g., ACR 20/50/70, DAS), radiographic changes, functional capacity, quality of life, withdrawals due to adverse events, and specific adverse events if data were available (e.g., injection-site reactions, infections, malignancy). The strength of evidence for each outcome or comparison that we graded incorporates scores on four domains (Table 5): risk of bias, consistency, directness, and precision; it can also reflect ratings for other domains that can be factored in when relevant (e.g., dose-response relationships).

As described in Owens et al., the evaluation of risk of bias includes assessment of study design and aggregate quality of studies.34 We judged good-quality studies to result in evidence with low risk of bias. We graded evidence as consistent when effect sizes across studies were in the same direction. When the evidence linked the interventions directly to health outcomes, we graded the evidence as being direct. We graded evidence as being precise when results had a low degree of uncertainty. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions.34

We dually evaluated the overall strength of evidence for each major outcome based on a qualitative assessment of strength of evidence for each domain and reconciled all disagreements. The levels of strength of evidence are shown in Table 6.

Table 6 Strength of evidence grades and their definitions34

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

## Data Synthesis

A direct comparative effectiveness assessment of two treatments was available if a comparative study of the two treatments has been conducted. Ideally, this would be a randomized controlled trial that directly compares the two treatments. However, many competing treatments have not been compared directly. In such cases, indirect methods that utilize data from common comparators (e.g., placebo) were available. There were very few head-to-head studies of biologic DMARDS, but there were numerous placebo-controlled studies. Using MTC meta-analysis allowed us to incorporate both direct evidence (from head-to-head studies) and indirect evidence (from placebo-controlled studies) to determine how biologic DMARDs compare with each other.”

Throughout this CER, we generally synthesized the literature qualitatively. The exceptions are the meta-analysis comparing the relative efficacy of biologic DMARDs and the meta-analyses comparing withdrawal rates from placebo-controlled trials. Comparisons of the drugs that were not quantitatively analyzed in any of the included meta-analyses were either limited to fewer than three good or fair RCTs or had heterogeneous/noncomparable study populations. Therefore, we did not attempt any quantitative analyses of such comparisons.

To compare the relative efficacy of biologic DMARDs, we used a mixed treatment comparison (MTC) meta-analysis. MTC is a generalization of standard pairwise meta-analysis that allows for simultaneous pairwise comparisons based on a network of evidence.35 One advantage of MTC using a Bayesian framework is that it allows for the combination of both direct head-to-head evidence and indirect evidence (e.g., different treatments with a common comparator) in a way that preserves randomization and minimizes bias.36 Another advantage is that the Bayesian framework allows for a ranking of treatments based on the probability of which treatment is best.37

We conducted the MTC meta-analysis using the methods developed by the Multi-Parameter Evidence Synthesis (MPES) Research Group at the University of Bristol.35, 36, 38 We used a random effects logistic regression model that adjusted for correlations between arms within each study. The analysis was performed using WinBUGS Version 1.4.3, a Bayesian software package that uses Markov chain Monte Carlo (MCMC) techniques.39 We used WinBUGS code developed by the MPES Research Group, which is available from their program Web site.40 For our analysis, study effect and treatment effect parameters were modeled by noninformative (flat) prior distributions that were normal (0, 10,000). For the heterogeneity of the random-effects model, we used a uniform prior distribution centered at zero with sufficiently large variance. The first 20,000 simulations were discarded to allow for model convergence, and then an additional 80,000 simulations were used in estimating the posterior probabilities. Satisfactory convergence was verified by trace plots and calculation of the Monte Carlo error for each parameter.

In conducting any meta-analysis, it is important to consider various sources of heterogeneity and bias. Valid inferences are based on the assumption of studies of similar design, similar patient populations, and a network of evidence with a common comparator. Evidence suggests that adjusted indirect comparisons agree with head-to-head trials if component studies are similar and treatment effects are expected to be consistent in patients included in different trials.41–43

For the MTC meta-analyses for efficacy, we included studies with a good or fair quality rating that compared biologic DMARDs to a placebo- or active-control in patients with active RA despite MTX therapy. Patients could be on a background dose of MTX, but both treatment and placebo arms needed to be on comparable doses. Only studies with durations greater than 3 months were considered. For MTC meta-analyses for efficacy, we excluded trials enrolling either (1) patients who were MTX-naïve, or (2) patients who previously failed treatment with biologic DMARDs. This population reflects a clinically relevant subset, because in general, biologics are prescribed when patients are resistant to MTX and many of the studies were conducted in MTX-resistant patients who are new to biologic therapy. In addition, patients who are MTX-naïve or who have previously failed treatment with biologic DMARDs may have different response to treatments. We felt that an inadequate number of studies examined other populations, such as MTX-naïve patients, to allow us to conduct MTC meta-analyses for efficacy for other populations.

For MTC meta-analyses of withdrawals, we did not exclude studies enrolling patients who were MTX-naïve or patients who previously failed treatment with biologic DMARDs because we did not consider these factors to be significant in evaluating tolerability profiles. Unlike efficacy, we believe that tolerability is more likely to be a function of the specific treatment regimen than it is to be related to how patients previously have responded to other treatments (i.e., MTX naive and anti-TNF failure).

Our outcome measures of choice were American College of Rheumatology (ACR) response rates and withdrawals (overall, due to lack of efficacy, and due to adverse events).44 The primary efficacy outcome of our MTC meta-analysis is the ACR 50; results are reported in the Resultss chapter. The results from the analysis of ACR 20 and ACR 70 are presented in Appendix J. We present the relative efficacies of biologic DMARDs as odds ratios and 95 percent Credible Intervals (CrI).

A total of 34 studies were identified for potential inclusion in the MTC meta-analysis of ACR response rates, and were further reviewed to explore sources of heterogeneity before conducting the MTC. We excluded four studies from the main analysis because of heterogeneity due to study design, whereas other sources of heterogeneity were explored through sensitivity analyses (Appendix K). The four excluded studies had early escape designs, a large number of crossovers from placebo to active treatment, and no ACR outcomes reported prior to the crossover. All potentially eligible studies of certolizumab were among these four studies. A total of 30 studies were included in the final MTC meta-analysis for efficacy, evaluating eight biologic DMARDs: abatacept, adalimumab, anakinra, etanercept, golimumab, infliximab, rituximab, and tocilizumab. Detailed information on the included studies for the efficacy analysis can be found in the Results chapter.

The meta-analysis comparing withdrawal rates from placebo-controlled trials used a random effects model to calculate pooled odds ratios of treatment withdrawals for each biologic DMARD relative to placebo. In these analyses, certolizumab pegol was included (because outcomes were reported prior to, or at the time of, crossover) in addition to the eight biologic DMARDs listed above. The outcomes of interest were rates of overall withdrawals, withdrawals due to lack of efficacy, and withdrawals due to adverse events. For each analysis, we conducted a test of heterogeneity (I^2^ statistic) and assessed publication bias with funnel plots. These analyses were performed using Stata 10. Additional meta-analyses comparing withdrawal rates between the biologic DMARDs were performed using an MTC meta-analysis.

## Peer Review

Individuals who were experts in rheumatology and various stakeholder and user communities (listed in the front matter) performed an external peer review on this CER. The SRC oversaw the peer review process. Peer reviewers were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we had conceptualized and defined the topic and KQs. Our peer reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ and the SRC also requested review from its own staff. In addition, the SRC placed the draft report on the AHRQ Web site (http://effectivehealthcare.ahrq.gov) and compiled the comments for our review.