# Introduction

Arthritis and other rheumatic conditions constitute the leading cause of disability among U.S. adults,1 with more than 46 million Americans reporting doctor-diagnosed arthritis.2 Noninflammatory arthritic conditions (e.g., osteoarthritis) are most common, but inflammatory arthritides such as spondyloarthropathies (e.g., ankylosing spondylitis, psoriatic arthritis [PsA]), and reactive arthritis) and rheumatoid arthritis (RA) can be equally or more disabling.

Among patients with RA, the burden of disease is evidenced by decreased quality of life,3–6 decreased employment rates,7, 8 and increased direct and indirect costs.9–12 In 2003, arthritis and other rheumatic conditions cost the United States $127.8 billion ($80.8 billion in medical care expenditures and $47.0 billion in lost earnings).13 Annually, approximately 9 million physician office visits and more than 250,000 hospitalizations occur as the result of RA. The mean total annual direct cost to patients with RA is estimated to be $9,519 per person,9 and most studies have reported indirect costs to be roughly twofold greater than direct costs.14

## Causes and Diagnosis

RA is an autoimmune disease that affects 1.3 million adults in the United States.2 Disease onset generally occurs between ages 30 and 50 years, and incidence is higher in women and older adults. RA presentations range from mild to severe. Some people are affected for as little as a few months, whereas others are affected for a lifetime and suffer severe joint damage and disability.

The hallmarks of the disease are inflammation of the synovium (a membrane that lines the joint capsule and produces lubricating fluid in the joint) with progressive erosion of bone leading to malalignment of the joint. As the inflamed synovium destroys the joint, the surrounding muscles and tendons become weak, leading to disability in most cases. Unlike osteoarthritis, RA can affect other areas in addition to joints. Most patients develop anemia. Some patients have dry eyes and mouth (sicca syndrome). Rarely, patients develop inflammation in the lining of the lung (pulmonary fibrosis), various layers of the eye wall (episcleritis and scleritis), small vessels (vasculitis), and the outer covering of the heart (pericarditis).

The exact etiology of RA is not completely understood, but genetic susceptibility plays an important role.15, 16 Studies have shown the importance of T cells, B cells, and cytokines in the pathogenesis of RA.17, 18 Cytokines of particular interest are tumor necrosis factor (TNF), interleukin (IL)-1, and IL-6.

TNF plays a central role in the pathobiology of RA. It is an important regulator of other proinflammatory molecules and stimulates the secretion of matrix metalloproteinases. It also exerts a direct effect on the multiple tissues inside the joint including chondrocytes, macrophages, synovial fibroblasts, and osteoclasts. Together, its action leads to inflammation and the formation of pannus, a mass of tissue that causes localized joint destruction.18

The diagnosis of RA is primarily a clinical one, based on multiple patient symptoms. No single laboratory test confirms RA. Constitutional symptoms including low-grade fever, fatigue, or malaise are common before the onset of joint swelling and pain. Joint stiffness is almost always present and is frequently most severe after periods of prolonged rest. The disease tends to affect the small joints of the hands and feet first in a symmetric pattern, but other joint patterns are often seen. A serum rheumatoid factor is present in up to 75 percent of patients with RA but is frequently negative in early disease. A more specific marker, anticyclic citrullinated peptide (CCP) antibody, has recently been described and may be a useful marker in patients with early disease.19, 20 Table 1 presents the 1988 diagnostic criteria for RA developed by the American College of Rheumatology (ACR) and used by many of the studies in this review.21 Patients are said to have RA if they meet four of the seven criteria in the table.21 It should be noted that these criteria are relatively insensitive for early disease and efforts are underway to revise the criteria to address this issue. In 2010, a collaborative work group of the ACR and the European League Against Rheumatism (EULAR) released new classification criteria that are sensitive to the current treatment goals—remission or at least low disease activity in all patients.22 (Further information on these criteria can be found at the end of Appendix G).

Table 1 ACR criteria for the diagnosis of rheumatoid arthritis

Criteria
1. | Morning stiffness lasting greater than 1 hour
2. | Arthritis in three or more joint areas
3. | Arthritis of the hand joints (metacarpophalangeal [MCP], proximal interphalangeal [PIP], wrists)
4. | Symmetric arthritis
5. | Rheumatoid nodules
6. | Serum rheumatoid factor
7. | Radiographic changes: erosions or unequivocal periarticular osteopenia

Source: Arnett et al., The American Rheumatism Association 1987 revised criteria for the classification of rheumatoid arthritis. Arthritis Rheum. 1988 Mar; 31(3):315–24.^21^

## Treatment of Rheumatoid Arthritis

Treatment of patients with RA aims to control pain and inflammation and, ultimately the goal is remission or at least low disease activity for all patients. This review focuses on treatments commonly used for RA in the United States.^a^

a Minocycline, gold cyclosporine, and azathioprine are not included in this review.

Corticosteroids. Corticosteroids—sometimes referred to as glucocorticoids or steroids—are used for many inflammatory and autoimmune conditions. As a class, corticosteroids have been used since the discovery of cortisone in the 1940s. Commonly used oral corticosteroids include methylprednisolone, prednisone, and prednisolone.

Corticosteroids are a synthetic form of cortisol, a hormone produced by the adrenal glands. They produce their anti-inflammatory and immunosuppressive response by interacting with steroid-specific receptors in the cytoplasm of cells, thereby inhibiting the movement of inflammatory cells into the site of inflammation, inhibiting neutrophil function, and inhibiting prostaglandin production. They are widely prescribed as an oral treatment for RA because of their ability to reduce inflammation and subsequent joint pain and swelling.

Oral disease-modifying antirheumatic drugs (DMARDs). Oral DMARDs such as methotrexate (MTX), sulfasalazine, hydroxychloroquine, and leflunomide modify the course of inflammatory conditions, presumably through their effects on the immune system. Most of the oral DMARDs have been used in clinical practice for more than 20 years. MTX was developed in the 1940s as a treatment for leukemia but was not approved for the treatment of arthritis until 1988. Sulfasalazine also has been available since the 1940s; it is a combination salicylate (acetylsalicylic acid) and antibiotic (sulfapyearidine) that originally was used to treat patients with inflammatory bowel disease. Hydroxychloroquine, approved in the 1950s for the treatment of malaria, is believed to work in arthritis by interfering with antigen presentation and the activation of immune response by increasing the pH within macrophage phagolysosomes. Additionally, hydroxychloroquine possibly inhibits toll-like receptors that mediate proinflammatory cytokine production. Only leflunomide, an isoxazole immunomodulatory agent, was specifically developed for treating inflammatory arthritis; the U.S. Food and Drug Administration (FDA) approved its use in 1998.

Oral DMARDs are not members of a single drug family. They are classified together, however, because they all are slow acting with the aim of improving symptoms, reducing or preventing joint damage, and preserving structure and function in patients with inflammatory disease. All the oral DMARDs covered in this review can be given orally, although MTX can also be injected (subcutaneous [SQ] or intramuscular [IM]).

Biologic DMARDs. Biologic DMARDs—commonly referred to as biological response modifiers or simply biologics—are a relatively new injectable category of DMARDs that differ from oral DMARDs in that they target specific components of the immune system. The FDA approved the first of the biologics (infliximab) in 1998; this report covers eight additional agents approved since that time: etanercept (1998), anakinra (2001), adalimumab (2002), abatacept (2005), rituximab (2006), certolizumab pegol (2008), golimumab (2009), and tocilizumab (2010). Of the nine agents, all are currently FDA approved for treating RA.

The biologic DMARDs work by selectively blocking mechanisms involved in the inflammatory and immune response. Adalimumab, certolizumab pegol, etanercept, golimumab, and infliximab are known as TNF inhibitors (i.e., drugs that block specific proinflammatory mediators known as cytokines). They produce their primary effect by blocking TNF from interacting with cell surface TNF receptors. Adalimumab, infliximab, and golimumab are monoclonal antibodies. Adalimumab is a fully human monoclonal antibody that binds specifically to TNF, blocking its interaction with both the p55 and p75 cell surface TNF receptor. Golimumab is also a human monoclonal antibody that binds to TNF alpha with high affinity. Infliximab is a chimeric (i.e., made from human and mouse proteins) monoclonal antibody that binds specifically to human TNF alpha. Etanercept is not a monoclonal antibody, but rather a TNF-soluble receptor protein. More specifically, it is a soluble dimeric form of the p75 TNF receptor linked to the Fc portion of human immunoglobulin G1 (IgG1). Etanercept exerts its action by binding circulating TNF and preventing it from interacting with a cell surface receptor. It does not form neutralizing antibodies or mediate cell lysis in the presence or absence of complement. Certolizumab pegol is a pegylated humanized antibody fragment of TNF monoclonal antibody. The drug binds to the TNF alpha-receptor and blocks TNF alpha actvity. It only possesses the Fab fragment and lacks the Fc region. Hence, it does not induce antibody-dependant cell mediated apoptosis or toxicity.

IL-1, another naturally occurring cytokine, has both immune and proinflammatory actions. Anakinra, an IL-1 receptor antagonist, is a human recombinant protein that competitively blocks the IL-1 receptor, thus blocking various inflammatory and immunological responses.

The immunosuppressant agent abatacept produces its immune response by interfering with T lymphocyte activation. Abatacept is a soluble fusion protein that consists of the extracellular domain of human cytotoxic T lymphocyte-associated antigen (CTLA-4) and the modified Fc portion of IgG1.

Rituximab, a chimeric murine/human monoclonal antibody, works by binding to the CD20 antigen found on the surface of B lymphocytes. Thus, it removes circulating B cells from the pre-B cell stage through the activated B cells. B cells are believed to play a role in autoimmune and inflammatory processes, such as those involved in RA.

IL-6 is a naturally occurring cytokine involved in the regulation of immune responses and inflammation. Tocilizumab is a monoclonal antibody that inhibits interleukin-6 (IL-6) receptors, blocking the action of IL-6, and leading to a reduction in cytokine and inflammatory response. Tables 2 through 4 provide detailed information (names, manufacturers, and available dosage forms) on agents used in the treatment of RA that we have included in this review. Also presented are routes of administration, labeled uses, and usual (recommended) adult doses and frequency for RA.

Table 2 Pharmaceutical treatments for rheumatoid arthritis: Corticosteroids

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | How Supplied | Usual Adult Dose
Cortico-steroids: Methyl-prednisolone | Multiple Medrol®, Depo-Medrol®, Solu-Medrol® | Acetate - Injectable IM—20, 40, and 80 mg/ml Sodium succinate - Injectable: IM—40, 125, and 500 mg, 1 and 2 g vials Oral: Tabs—2, 4, 8, 16, and 32 mg | Acetate: IM—10 to 80 mg every 1 to 2 weeks Intra-articular, intralesional —4 to 80 mg every 1 to 5 weeks Sodium succinate: IM—10 to 80 mg daily IV—10 to 40 mg every 4 to 6 hours; up to 30 mg/kg every 4 to 6 hours Oral: 2 to 60 mg in 1 to 4 divided doses to start, followed by gradual reduction
Prednisone | Multiple Deltasone®, Sterapred®, LiquiPred | Oral Solution—1 and 5 mg/ml Tabs—1, 2.5, 5, 10, 20, and 50 mg | Use lowest effective dose. Usually ≤ 10 mg/day, but doses range from 5–60 mg/day
Prednisolone | Multiple Orapred®, Pediapred®, Prelone®, Delta-Cortef®, Econopred® | Oral Solution/Syrup—5, 15, and 20 mg/5 ml Oral Tabs—5 and 15 mg | Use lowest effective dose (5 to 7.5 mg/day), up to 60 mg/day

IM = intramuscular; IV = intravenous; kg = killigram; mg = milligram; ml = millileter

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

Table 3 Pharmaceutical treatments for rheumatoid arthritis: Oral DMARDs

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | How Supplied | Usual Adult Dose
Hydroxy-chloroquine^b^ | Multiple Plaquenil®^b^ | Oral Tabs—200 mg | 200 to 400^a^ mg/day in 1 or 2 divided doses
Leflunomide^b^ | Multiple Arava®^b^ | Oral Tabs—10 and 20 mg | 10 to 20 mg/day in a single dose. May give loading dose of 100mg/day for 3 days in patients with low risk of hepatic or hematologic toxicity.
Methotrexate^b^ | Multiple Trexall®^b^, Folex®^b^, Rheumatrex®^b^ | Injectable—25 mg/ml, 20 mg and 1 g vials Oral Tabs—2.5, 5, 7.5, 10, and 15 mg | IM, SQ, oral—7.5 to 20 mg/week in a single dose
Sulfasalazine^b^ | Multiple Azulfidine®^b^, EN-tabs®^b^, Sulfazine®^b^ | Oral Suspension—250 mg/5 ml Oral Tabs—500 mg | 500 to 3,000 mg/day in 2 to 4 divided doses

G = gram; IM = intramuscular; mg = milligram; ml = millileter

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

a Initial dose is 400 to 600 mg/day for 4 to 12 weeks.

b Dosed according to the RA dosing recommendations.

Table 4 Pharmaceutical treatments for rheumatoid arthritis: Biologic DMARDs

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | Injectable Supply | Usual Adult Dose
Abatacept | Bristol Myers Squibb Orencia® | 250 mg vial | IV—Dosed according to body weight (< 60 kg = 500 mg; 60–100 kg = 750 mg; > 100 kg = 1,000 mg); dose repeated at 2 weeks and 4 weeks after initial dose, and every 4 weeks thereafter SQ—may give weight-based IV loading dose, then 125 mg SQ once weekly
Adalimumab | Abbott Humira® | 40 mg/0.8 ml, 20 mg/0.4 ml prefilled syringe | SQ—40 mg every other week; may increase to 40 mg per week in patients not taking concomitant MTX
Anakinra^a^ | Amgen Kineret® | 100 mg/0.67 ml syringe | SQ—100 mg/day; dose should be decreased to 100 mg every other day in renal insufficiency
Certolizumab^a^ Pegol | UCB Cimzia® | 200 mg powder for reconstitution, 200 mg/ml solution | SQ—Initial dose of 400 mg (as 2 SQ injections of 200 mg), repeat dose 2 and 4 weeks after initial dose; Maintenance dose is 200 mg every other week (may consider maintenance dose of 400 every 4 weeks)
Etanercept | Amgen Pfizer Immunex Enbrel® | 50 mg/ml in 25 mg or 50 mg single use prefilled syringe | SQ—50 mg once weekly with or without MTX
Golimumab | Centocor Ortho Biotech Simponi® | 50 mg/0.5 ml syringe | SQ—50 mg once per month in combination with MTX
Infliximab | Centocor Ortho Biotech Remicade® | 100 mg in a 20 ml vial | IV—3 mg/kg in combination with MTX at 0, 2, and 6 weeks followed by maintenance every 8 weeks thereafter; may increase to maximum of 10 mg/kg or treat as often as every 4 weeks
Rituximab^a^ | Biogen Idec/Genentech Rituxan® | 100 mg/10 ml and 500 mg/50 ml vial | IV—1,000 mg IV infusion separated by 2 weeks (one course) every 24 weeks or based on clinical evaluation, but not sooner than every 16 weeks
Tocilizumab^a^ | Genentech/Roche Actemra®, RoActemra® | 80 mg/4 ml, 200 mg/10 ml, 400 mg/20 ml vial | IV—4 mg/kg every 4 weeks; increase to 8 mg/kg every 4 weeks based on clinical response

Kg = killigram; mg = milligram; ml = millileter; MTX = methotrexate; IV = intravenously SQ = subcutaneously

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

a Dosed according to the RA dosing recommendations..

## Treatment Strategies

In RA, nonsteroidal anti-inflammatory drugs (NSAIDs) are frequently used in early or mild disease, but they do not have any disease-modifying properties. The oral DMARD MTX is the cornerstone of treatment, as it has demonstrated good disease control. However, MTX toxicity may limit its use, and many patients do not adequately respond to MTX monotherapy. Leflunomide, hydroxychloroquine, and sulfasalazine are alternative oral DMARDs that can be given as monotherapy or in combination; recommendations for their use are largely based on disease duration, degree of disease activity, and prognostic features.23

Combination therapies serve an important role because treatment with a single DMARD often does not adequately control symptoms. Low-dose systemic corticosteroids (prednisone 7.5–10 mg/day) or intra-articular corticosteroids are used as an adjunct to DMARDs. In patients with persistent disease despite aggressive management with standard agents, biologic agents, often in combination with MTX, are now considered the standard of care. Although combination therapies improve response rates in patients initially receiving monotherapy, available evidence does not predict which combination strategy will provide the best outcome.24

There is debate about which types of combination therapy are preferred and how early in the disease process to initiate this intervention. No settled opinion exists as to whether treatment should proceed in a sequential step-up approach (progressing from single therapy to combination therapy) or in a step-down approach (beginning with combination therapy and stepping down treatment when symptoms are under control). Additional uncertainty remains regarding risks and benefits of therapies in patient subgroups.

Recent reports have examined treatment of RA, supporting the overall efficacy of treatments.25–29 However, additional agents have since been introduced on the market, necessitating an update of the evidence. A further examination of the comparative efficacy and effectiveness of various treatments and treatment strategies, as well as long-term outcomes and subpopulations, is warranted.

## Scope and Key Questions

The purpose of this review is to compare the efficacy, effectiveness, and harms of corticosteroids, oral DMARDs, and biologic DMARDs in the treatment of patients with RA. We address the following four Key Questions (KQs):

- KQ 1: For patients with RA, do drug therapies differ in their ability to reduce disease activity, to slow or limit the progression of radiographic joint damage, or to maintain remission?
- KQ 2: For patients with RA, do drug therapies differ in their ability to improve patient-reported symptoms, functional capacity, or quality of life?
- KQ 3: For patients with RA, do drug therapies differ in harms, tolerability, patient adherence, or adverse effects?
- KQ 4: What are the comparative benefits and harms of drug therapies for RA in subgroups of patients based on stage of disease, prior therapy, demographics, concomitant therapies, or comorbidities?

## Organization of the Report

The remainder of this comparative effectiveness review describes our methods to review and synthesize this literature, presents our results by KQ, and discusses the implications of those results for clinical applications and future research. Appendix A describes our search strategy; Appendix B presents our review and abstraction forms; Appendix C lists our articles by database searched; Appendix D lists excluded studies and the reasons for exclusion; Appendix E contains our evidence tables; Appendix F presents the criteria for assessing the quality of individual studies; Appendix G describes clinical assessment scales commonly used in arthritis trials; Appendix H contains our Poor Quality studies; Appendix I, our Strength of Evidence tables; Appendix J, the sensitivity analysis methods for the Mixed Treatment Comparisons; and Appendix K, the ACR 20 and ACR 70 results for the Mixed Treatment Comparisons.