# Executive Summary

## Background

Rheumatoid arthritis (RA), which affects 1.3 million adult Americans, is an autoimmune disease that involves inflammation of the synovium (a thin layer of tissue lining a joint space) with progressive erosion of bone leading in most cases to misalignment of the joint, loss of function, and disability. The disease tends to affect the small joints of the hands and feet in a symmetric pattern, but other joint patterns are often seen. The diagnosis is based primarily on the clinical history and physical examination with support from selected laboratory tests. Treatment of patients with RA aims to control pain and inflammation and, ultimately, the goal is remission or at least low disease activity for all patients. Available therapies for RA include corticosteroids, oral disease-modifying antirheumatic drugs or DMARDs (hydroxychloroquine, leflunomide, methotrexate [MTX], and sulfasalazine), and biologic DMARDs (five anti-tumor necrosis factor drugs [anti-TNF]: adalimumab, certolizumab, etanercept, golimumab, infliximab; and others including abatacept, anakinra, rituximab, and tocilizumab).

Treatment strategies for RA continue to evolve. Early use of DMARDs is considered crucial to avoid persistent and erosive arthritis. Clinicians frequently start treatment regimens with oral DMARD monotherapies and adjust dosages as appropriate to achieve a low disease activity or remission. Clinical experience supports the use of MTX as the oral DMARD of choice unless there are contraindications (e.g., liver impairment, alcohol abuse, pregnancy, lung disease). Experts have not arrived at consensus about the comparative effectiveness of corticosteroids, oral DMARDs, and biologic DMARDs. More importantly, it is unclear how the effectiveness and safety of different types of combination therapy compare, for example, oral DMARDs with corticosteroids, oral DMARDs with biologic DMARDs, or a triple combination of corticosteroids, oral DMARDs, and biologic DMARDs. In addition, there is debate about how early in the disease process combination therapy should be initiated. Many questions remain about the risks of these agents across a spectrum of adverse events, from relatively minor side effects such as injection site reactions to severe and possibly life-threatening problems such as severe infections or infusion reactions. Finally, very little is known about the benefits or risks of these drugs in different patient subgroups, including ethnic minorities, the elderly, pregnant women, and patients with other comorbidities.

## Objectives

This report summarizes the evidence on the comparative efficacy, effectiveness, and harms of corticosteroids, oral DMARDs, and biologic DMARDs in the treatment of patients with RA. This report updates a previous version published in 2007. The Key Questions (KQs) are as follows:

KQ1 For patients with RA, do drug therapies differ in their ability to reduce disease activity, to slow or limit the progression of radiographic joint damage, or to maintain remission?
KQ2 For patients with RA, do drug therapies differ in their ability to improve patient-reported symptoms, functional capacity, or quality of life?
KQ3 For patients with RA, do drug therapies differ in harms, tolerability, patient adherence, or adverse effects?
KQ4 What are the comparative benefits and harms of drug therapies for RA in subgroups of patients based on stage of disease, prior therapy, demographics, concomitant therapies, or comorbidities?

## Analytic Framework

Figure A depicts the analytic framework for rheumatoid arthritis.

Figure A Analytic framework for treatment for rheumatoid arthritis

Figure ES-1: This figure depicts the key questions within the context of population, interventions, comparators, outcomes, timing and setting (PICOTS framework). The figure illustrates how treatment with corticosteroids, biologic DMARDs, or oral DMARDs versus any of these same treatments may result in intermediate outcomes such as symptoms, joint damage, physical functioning and/or long-term outcomes such as quality of life, morbidity, or mortality. Also, adverse events may occur at any point after the treatment is received.

## Methods

A Technical Expert Panel was employed for the finalization of the KQs and review of the planned analysis strategy. Our KQs and protocol were posted on the Agency for Healthcare Research and Quality Web site for public review and comment. Individuals who were experts in rheumatology and various stakeholder and user communities performed an external peer review of the report. The report was also posted for public review. We compiled all comments and addressed each one individually, revising the text as appropriate.

We searched MEDLINE®, Embase, the Cochrane Library, and the International Pharmaceutical Abstracts to identify relevant articles. We limited the electronic searches to “human” and “English language.” For this update, the searches went up to January 2011. Hand searches were conducted on the Center for Drug Evaluation and Research (CDER) database of the U.S. Food and Drug Administration and unpublished literature including dossiers from pharmaceutical companies.

Study eligibility (inclusion and exclusion) criteria were designed in respect to study design or duration, patient population, interventions, outcomes, and comparisons for each KQ. For efficacy and effectiveness, we focused on head-to-head trials and prospective cohort studies comparing one drug with another. For biologic DMARDs, we also included placebo-controlled, double-blind randomized controlled trials (RCTs). For harms and tolerability, as well as for efficacy and effectiveness in subgroups, we included head-to-head trials, high-quality systematic reviews, and observational studies. We included studies with sample sizes of at least 100 and duration of at least 3 months. We only included studies that used doses within the recommended dosing range or that used doses that could be considered equivalent to recommended doses.

Two individuals independently reviewed abstracts identified by searches. If both reviewers agreed that a study did not meet eligibility criteria, we excluded it. We obtained the full text of all remaining articles. Two individuals again independently reviewed the full text of all remaining articles to determine whether they should be included. We designed and used a structured data abstraction form to ensure consistency of appraisal for each included study. Trained reviewers abstracted data from each study. A senior evaluated the completeness of each data abstraction.

We rated the quality of individual studies using the predefined criteria based on those developed by the U.S. Preventive Services Task Force (ratings: good, fair, poor)1 and the National Health Service Centre for Reviews and Dissemination.2 Two independent reviewers assigned quality ratings. They resolved any disagreements by discussion and consensus or by consulting with a third reviewer. We gave a good-quality rating to studies that met all criteria. We gave a poor-quality rating to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories and excluded them from our analyses. We graded the strength of evidence as high, moderate, low, or insufficient based on methods guidance for the Evidence-based Practice Program.3,4 We graded strength of evidence for the outcomes determined to be most important: measures of disease activity (e.g., American College of Rheumatology [ACR] 20/50/70, Disease Activity Score [DAS]), radiographic changes, functional capacity, quality of life, withdrawals due to adverse events, and specific adverse events if data were available (e.g., injection-site reactions, infections, malignancy). We generally synthesized the literature qualitatively, but we did conduct meta-analyses comparing the relative efficacy of biologic DMARDs and comparing withdrawal rates from placebo-controlled trials. To compare the relative efficacy of biologic DMARDs, we conducted a mixed treatment comparison (MTC) meta-analysis using WinBUGS Version 1.4.3, a Bayesian software package that uses Markov chain Monte Carlo (MCMC) techniques. The primary efficacy outcome of our MTC meta-analysis was the ACR 50.

## Results

We identified 3,868 citations from our searches. We included 258 published articles reporting on 211 studies: 31 head-to-head RCTs, 1 head-to-head nonrandomized controlled trial, 44 placebo-controlled trials, 28 meta-analyses or systematic reviews, and 107 observational studies. We identified 30 studies for quantitative synthesis for KQ1 and 42 studies for quantitative syntheses for KQ3. Most studies were of fair quality.

Our major findings are presented in this section by type of drug comparison for benefits and harms (Table A). Subpopulation analyses are described after Table A because the evidence is very limited.

Table A Summary of findings with strength of evidence

Key Comparisons | Efficacy Strength of Evidence | Harms Strength of Evidence
Oral DMARD vs. Oral DMARD
Leflunomide vs. MTX | No differences in ACR 20 or radiographic responses. Low No clinically significant difference for functional capacity. Low Greater improvement in health-related quality of life (SF-36 physical component) for leflunomide. Low | No consistent differences in tolerability and discontinuation rates. Low Mixed results for specific adverse events. Insufficient
Leflunomide vs. sulfasalazine | Mixed ACR response rates. Insufficient No differences in radiographic changes. Low Greater improvement in functional capacity for leflunomide Low | No differences in tolerability and discontinuation rates. Low Mixed results for specific adverse events. Insufficient
Sulfasalazine vs. MTX | No differences in ACR 20 response, disease activity scores and radiographic changes.^†^ Moderate No differences for functional capacity.^†^ Moderate | No differences in tolerability; more patients stayed on MTX long term. Low Mixed results for specific adverse events. Insufficient
Oral DMARD Combinations vs. Oral DMARD
Sulfasalazine plus MTX vs. sulfasalazine or MTX monotherapy | In patients with early RA, no differences in ACR 20 response rates or radiographic changes. Moderate No differences in functional capacity. Moderate | Withdrawal rates attributable to adverse events higher with combination. Low Insufficient evidence for specific adverse events. Insufficient
Oral DMARD plus prednisone vs. oral DMARD | Mixed results for disease activity. Insufficient Less radiographic progression in patients on DMARD plus prednisone. Low In patients with early RA, significantly lower radiographic progression and fewer eroded. joints Low Greater improvement in functional capacity for one oral DMARD plus prednisolone than for oral DMARD monotherapy. Moderate No difference in quality of life. Low | No differences in discontinuation rates; addition of corticosteroid may increase time to discontinuation of treatment. Moderate No differences in specific adverse events, except addition of corticosteroid may increase wound-healing complications. Low
Biologic DMARDs vs. Biologic DMARDs
Abatacept vs. Infliximab | Greater improvement in disease activity for abatacept, but no difference in remission or functional capacity. Statistically significant difference between groups for quality of life (SF-36 PCS) that did not reach the minimal clinically important difference. Low | Discontinuation rates and severe adverse events higher with infliximab. Low
Biologic vs. biologic (Mixed treatment comparisons) | No significant differences in disease activity (ACR 50) in MTC analyses between abatacept, adalimumab, golimumab, infliximab, rituximab, and tocilizumab in patients resistant to MTX. Low Less improvement in disease activity (ACR 50) for anakinra compared with etanercept and compared with adalimumab in MTC analyses in patients resistant to MTX. Comparisons with abatacept, golimumab, infliximab, rituximab, and tocilizumab did not reach statistical significance. Low | Adjusted indirect comparisons found a more favorable withdrawal profile for certolizumab pegol than other biologic DMARDs. Also, etanercept and rituximab had a more favorable overall withdrawal profile than some other biologic DMARDs. Certolizumab pegol had fewer withdrawals due to lack of efficacy than adalimumab, anakinra, and infliximab. All but adalimumab, golimumab, and infliximab had fewer withdrawals than anakinra due to lack of efficacy. Both certolizumab pegol and infliximab had more withdrawals due to adverse events than etanercept and rituximab. Low
Biologic vs. biologic (Mixed treatment comparisons) (continued) | Greater improvement in disease activity (ACR 50) for etanercept compared with abatacept, adalimumab, anakinra, infliximab, rituximab, and tocilizumab in MTC analyses. No significant differences when compared with golimumab. Low | Risk for injection site reactions apparently highest with anakinra. Low Mixed results for specific adverse events. Insufficient
Biologic DMARDs vs. Oral DMARDs
Anti-tumor necrosis factor drugs vs. MTX | In patients with early RA, no clinically significant differences in clinical response between adalimumab or etanercept and MTX; in patients on biologic DMARDs, better radiographic outcomes than in patients on oral DMARDs. Moderate No difference in functional capacity between adalimumab and MTX for MTX-naïve subjects with early RA; mixed results for etanercept vs. MTX. Low; Insufficient Faster improvement in quality of life with etanercept than MTX. Low | No differences in adverse events in efficacy studies. Low Insufficient evidence on differences in the risk for rare but severe adverse events. Insufficient
Biologic DMARD Combinations
Biologic DMARD plus biologic DMARD vs. biologic DMARD | No additional benefit in disease activity or functional capacity from combination of etanercept plus anakinra compared with etanercept monotherapy or combination of etanercept plus abatacept compared with abatacept monotherapy, but greater improvement in quality of life with etanercept plus abatacept vs. etanercept. Low | Substantially higher rates of serious adverse events from combination of two biologic DMARDs than from monotherapy. Moderate
Biologic DMARDs plus MTX vs. biologic DMARDs | Better improvements in disease activity from combination therapy of biologic DMARDs (adalimumab, etanercept, infliximab, rituximab) plus MTX than from monotherapy with biologics. Moderate In MTX-naive patients with early aggressive RA, better ACR 50 response, significantly greater clinical remission, and less radiographic progression in the combination therapy group. Low In MTX-naïve subjects or those not recently on MTX, greater improvement in functional capacity (Moderate) and quality of life (Low) with combination therapy. In subjects with active RA despite treatment with MTX, no difference in functional capacity or quality of life. Low | No differences in adverse events in efficacy studies. Low Insufficient evidence on differences in the risk for rare but severe adverse events. Insufficient
Biologic DMARDs plus oral DMARD other than MTX vs. biologic DMARDs | No difference in clinical response rates, functional capacity, and quality of life between etanercept plus sulfasalazine and etanercept monotherapy. Low | No differences in adverse events in efficacy studies. Low Insufficient evidence on differences in the risk for rare but severe adverse events Insufficient
Biologic DMARD plus MTX vs. MTX | Better clinical response rates, functional capacity, and quality of life from combination therapy of biologic DMARDs and MTX than from MTX monotherapy. High for clinical response and functional capacity, Moderate for quality of life | Better tolerability profile for MTX plus abatacept, adalimumab, certolizumab, etanercept, and rituximab than for MTX monotherapy from meta-analysis. Low Mixed evidence on differences in the risk for rare but severe adverse events. Insufficient
Strategies in Early RA
Two oral DMARDs plus prednisone vs. oral DMARD | In patients on two oral DMARDs, improved ACR 50 response rates, disease activity scores, but no difference at 56 weeks. Low In patients with early RA, significantly lower radiographic progression and fewer eroded joints at 56 weeks. Low More rapid improvement in functional capacity by 28 weeks but no differences by 56 weeks. Low | No differences in discontinuation rates. Moderate
Three oral DMARDs plus prednisone vs. one oral DMARD | In patients on three oral DMARDs, improved ACR 50 response rates, disease activity scores, and less work disability. Low In patients with early RA, significantly lower radiographic progression and fewer eroded joints Low | No differences in discontinuation rates. Moderate
Sequential monotherapy starting with MTX vs. step-up combination therapy vs. combination with tapered high-dose prednisone vs. combination with infliximab | Less radiographic progression, lower disease activity scores, and better functional ability and health-related quality of life from initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone or initial combination therapy with infliximab plus MTX than from sequential DMARD monotherapy or step-up combination therapy. However no differences between groups for functional ability and quality of life by 2 years and no difference in remission at 4 years. Low | No differences in serious adverse events between groups. Low

† at MTX doses ranging from 7.5–25 mg per week

ACR = American College of Rheumatology; DMARD = disease-modifying antirheumatic drug; MTC = mixed treatment comparisons; MTX = methotrexate; RA = rheumatoid arthritis; vs = versus

Subpopulations. Limited good or fair evidence for benefits or harms of subpopulations exists; therefore, the strength of evidence was low and results should be interpreted cautiously. Patients with moderate RA had significant improvements and better overall functional status than those with severe RA, but those with severe RA had the greatest improvements from baseline in disease activity. For MTX, the odds for major clinical improvement dropped slightly as the age of clinical trial patients increased; age did not affect MTX efficacy or the rate of side effects. Biologics neither decreased nor increased cardiovascular risks in the elderly. Those taking anakinra and concomitant diabetic, antihypertensive, or statin medications did not have higher adverse events rates. Toxicity was more likely with MTX in patients with greater renal impairment. Those with high-risk comorbidities (cardiovascular events, diabetes, malignances, renal impairment) and taking anakinra did not experience an increase in serious adverse events or overall infectious events.

## Discussion

Existing comparative evidence did not support the superiority of one oral DMARD over another. Limitations to these trials included the wide range of MTX dosing in the trials. Biologic DMARD comparisons are limited to mostly observational studies and findings from MTC meta-analyses. Our MTC meta-analyses, suggest some differences, such as etanercept having a higher probability of improvement in disease activity than most other biologic DMARDs, but are limited primarily to indirect evidence (low strength of evidence) and therefore should be interpreted with caution. The limited evidence precludes drawing firm conclusions about whether one combination strategy is better than another in early RA. Overall tolerability is similar among biologic and among oral DMARDs; however, several studies suggest that adverse events are more common with biologic DMARDs compared with oral DMARDs. Limited evidence does not suggest an increased risk of severe adverse events, including cardiovascular or cancer, with oral DMARDs. Most studies found no risk of cardiovascular events and malignancy with biologic DMARDs, except for cohort studies, which describe an increased risk of heart failure with adalimumab, etanercept, and infliximab compared with oral DMARDs.

Common problems for RA studies included the lack of effectiveness information, that is, studies and findings with a high level of applicability to community populations. Future investigations need to take into account factors such as varying adherence because of administration schedules, costs, and adverse events. Information is also needed about the performance of these drugs in subgroups of patients defined by health status, sociodemographic, or other variables.

To address problems with current literature, future studies should include using designs of longer duration and followup, enrolling patients representing key subgroups (or reporting on them when they are enrolled), and ensuring that quality of life (or other patient-centered outcomes) is measured, in addition to clinician-centered measures such as joint erosion. Ideally, studies need to mimic clinical decisionmaking, where if a patient is not doing well after a specified time, the protocol gives them something different. Important areas that will influence clinical decisionmaking include three critical topics: (1) specific head-to-head comparisons focusing on different combination strategies and different biologic DMARDs, (2) timing of initiation of therapies, and (3) applicability of combination strategies and biologic DMARD therapy in community practice. The results of the MTC meta-analyses suggested some differences. However, the strength of evidence was low for the MTC findings, and head-to-head studies are needed to confirm or refute these results before any firm clinical recommendations can be made.

Analyses involving subpopulations, specifically those defined by age and coexisting conditions, will be beneficial, given that RA disease onset generally occurs in middle age, when the risk of comorbidities increases. Studies of longer duration and followup will be beneficial, given that RA is a progressive, chronic condition. Such studies will also help to clarify whether early initiation of any regimen can improve the long-term prognosis of RA and, particularly, whether early use of biologic DMARDs is helpful.

## Abbreviations

ACR: American College of Rheumatology
Anti-TNF: Anti-tumor necrosis factor drugs
CDER: Center for Drug Evaluation and Research
DMARD: Disease-modifying antirheumatic drug
MCMC: Markov chain Monte Carlo techniques
MTC: Mixed-treatment comparisons
MTX: Methotrexate
RA: Rheumatoid arthritis
RCT: Randomized controlled trial
SF36: Short Form 36

## References

1 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
2 Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews, CRD Report Number 4. 2nd edition. 2001.
3 Agency for Healthcare Research and Quality. Methods reference guide for effectiveness and comparative effectiveness reviews, version 1.0. Rockville, MD. Agency for Healthcare Research and Quality. October. 2007. (draft). http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
4 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].