# Discussion

This report provides a comprehensive review of the comparative efficacy, effectiveness, and harms of members of the main classes of drugs used to treat adult patients with rheumatoid arthritis (RA). These include oral disease-modifying antirheumatic drugs (DMARDs), and biologic DMARDs. The objective of our report was to evaluate the comparative efficacy, effectiveness, and harms of monotherapies, combination therapies, and different treatment strategies.

Table 62 summarizes our findings and the strength of evidence for three Key Questions (KQs) addressed by this report.

Table 62 Summary of findings with strength of evidence

Key Comparisons | Efficacy Strength of Evidence | Harms Strength of Evidence
Oral DMARD vs. Oral DMARD
Leflunomide vs. MTX | No differences in ACR 20 or radiographic responses Low No clinically significant difference for functional capacity Low Greater improvement in health-related quality of life (SF-36 physical component) for leflunomide Low | No consistent differences in tolerability and discontinuation rates Low Mixed results for specific adverse events Insufficient
Leflunomide vs. sulfasalazine | Mixed ACR response rates Insufficient No differences in radiographic changes Low Greater improvement in functional capacity for leflunomide Low | No differences in tolerability and discontinuation rates Low Mixed results for specific adverse events Insufficient
Sulfasalazine vs. MTX | No differences in ACR 20 response, disease activity scores and radiographic changes* Moderate No differences for functional capacity* Moderate | No differences in tolerability; more patients stayed on MTX long-term Low Mixed results for specific adverse events Insufficient
Oral DMARD Combinations vs. Oral DMARD
Sulfasalazine plus MTX vs. sulfasalazine or MTX monotherapy | In patients with early RA, no differences in ACR 20 response rates or radiographic changes Moderate No differences in functional capacity Moderate | Withdrawal rates attributable to adverse events higher with combination Low Insufficient evidence for specific adverse events Insufficient
Oral DMARD plus prednisone vs. oral DMARD | Mixed results for disease activity Insufficient Less radiographic progression In patients on DMARD plus prednisone Low In patients with early RA, significantly lower radiographic progression and fewer eroded joints Low Greater improvement in functional capacity for one oral DMARD plus prednisolone than for oral DMARD monotherapy Moderate No difference in quality of life Low | No differences in discontinuation rates; addition of corticosteroid may increase time to discontinuation of treatment Moderate No differences in specific adverse events, except addition of corticosteroid may increase wound-healing complications Low
Biologic DMARD vs. Biologic DMARD
Abatacept vs. Infliximab | Greater improvement in disease activity for abatacept, but no difference in remission or functional capacity. Statistically significant difference between groups for quality of life (SF-36 PCS) that did not reach the minimal clinically important difference. Low | Discontinuation rates and severe adverse events higher with infliximab Low
Biologic vs. biologic (Mixed treatment comparisons) | No significant differences in disease activity (ACR 50) in MTC analyses between abatacept, adalimumab, golimumab, infliximab, rituximab, and tocilizumab in patients resistant to MTX Low Less improvement in disease activity (ACR 50) for anakinra compared to etanercept and compared to adalimumab in MTC analyses in patients resistant to MTX. Comparisons with abatacept, golimumab, infliximab, rituximab and tocilizumab did not reach statistical significance. Low Greater improvement in disease activity (ACR 50) for etanercept compared to abatacept, adalimumab, anakinra, infliximab, rituximab, and tocilizumab in MTC analyses. No significant differences when compared with golimumab Low | Adjusted indirect comparisons found a more favorable withdrawal profile for certolizumab pegol than other biologic DMARDs. Also, etanercept and rituximab had a more favorable overall withdrawal profile than some other biologic DMARDs. Certolizumab pegol had fewer withdrawals due to lack of efficacy than adalimumab, anakinra, and infliximab. All but adalimumab and golimumab had fewer withdrawals than anakinra due to lack of efficacy. Both certolizumab pegol and infliximab had more withdrawals due to adverse events than etanercept and rituximab. Low Risk of infusion reactions most common with infliximab Low Risk for injection site reactions apparently highest with anakinra Low Mixed results for specific adverse events Insufficient
Biologic DMARD vs. Oral DMARD
Anti-tumor necrosis factor drugs vs. MTX | In patients with early RA, no clinically significant differences in clinical response between adalimumab or etanercept and MTX; in patients on biologic DMARDs, better radiographic outcomes than in patients on oral DMARDs Moderate No difference in functional capacity between adalimumab and MTX for MTX-naïve subjects with early RA; mixed results for etanercept vs. MTX Low; Insufficient Faster improvement in quality of life with etanercept than MTX Low | No differences in adverse events in efficacy studies Low Insufficient evidence on differences in the risk for rare but severe adverse events Insufficient
Biologic DMARD Combinations
Biologic DMARD plus biologic DMARD vs. biologic DMARD | No additional benefit in disease activity or functional capacity from combination of etanercept plus anakinra compared with etanercept monotherapy or combination of etanercept plus abatacept compared with abatacept monotherapy, but greater improvement in quality of life with etanercept plus abatacept vs. etanercept Low | Substantially higher rates of serious adverse events from combination of two biologic DMARDs than from monotherapy Moderate
Biologic DMARDs plus MTX vs. biologic DMARDs | Better improvements in disease activity from combination therapy of biologic DMARDs (adalimumab, etanercept, infliximab, rituximab) plus MTX than from monotherapy with biologics Moderate In MTX-naive patients with early aggressive RA, better ACR 50 response, significantly greater clinical remission, and less radiographic progression in the combination therapy group Low In MTX-naïve subjects or those not recently on MTX, greater improvement in functional capacity (Moderate) and quality of life (Low) with combination therapy In subjects with active RA despite treatment with MTX, no difference in functional capacity or quality of life Low | No differences in adverse events in efficacy studies Low Insufficient evidence on differences in the risk for rare but severe adverse events Insufficient
Biologic DMARDs plus oral DMARD other than MTX vs. biologic DMARDs | No difference in clinical response rates, functional capacity, and quality of life between etanercept plus sulfasalazine and etanercept monotherapy Low | No differences in adverse events in efficacy studies Low Insufficient evidence on differences in the risk for rare but severe adverse events Insufficient
Biologic DMARD plus MTX vs. MTX | Better clinical response rates, functional capacity, and quality of life from combination therapy of biologic DMARDs and MTX than from MTX monotherapy High for clinical response and functional capacity, Moderate for quality of life | Better tolerability profile for MTX plus abatacept, adalimumab, certolizumab, etanercept, and rituximab than for MTX monotherapy from meta-analysis Low Mixed evidence on differences in the risk for rare but severe adverse events Insufficient
Strategies in Early RA
Two oral DMARDs plus prednisone vs. oral DMARD | In patients on two oral DMARDs, improved ACR 50 response rates, disease activity scores, but no difference at 56 weeks Low In patients with early RA, significantly lower radiographic progression and fewer eroded joints at 56 weeks Low More rapid improvement in functional capacity by 28 weeks but no differences by 56 weeks. Low | No differences in discontinuation rates Moderate
Three oral DMARDs plus prednisone vs. 1 oral DMARD | In patients on three oral DMARDs, improved ACR 50 response rates, disease activity scores, and less, less work disability Low In patients with early RA, significantly lower radiographic progression and fewer eroded joints Low | No differences in discontinuation rates Moderate
Sequential monotherapy starting with MTX vs. step-up combination therapy vs. combination with tapered high-dose prednisone vs. combination with infliximab | Less radiographic progression, lower disease activity scores, and better functional ability and health-related quality of life from initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone or initial combination therapy with infliximab plus MTX than from sequential DMARD monotherapy or step-up combination therapy. However no differences between groups for functional ability and quality of life by 2 years and no difference in remission at 4 years Low | No differences in serious adverse events between groups Low

† at MTX doses ranging from 7.5–25 mg per week

ACR = American College of Rheumatology; DMARD = disease modifying antirheumatic drug; MTC = mixed treatment comparisons; MTX = methotrexate; RA = rheumatoid arthritis; vs. = versus

## Key Findings

Existing comparative evidence permits us to draw some conclusions for monotherapies of oral and biologic DMARDs. Overall, the evidence supports similar efficacy and effectiveness for methotrexate (MTX) and sulfasalazine.57–59 However, it is important to note that MTX dosing for two of these studies ranged in the lower part of the dosing range. The evidence is insufficient to draw conclusions about disease activity for sulfasalazine and leflunomide, but improvement in functional capacity was greater for patients on leflunomide in one study (low strength of evidence).107, 200 All three drugs have similar discontinuation rates attributed to adverse events in short-term efficacy trials up to 2 years.104, 105, 107, 345

Although several biologic DMARDs are available, the head-to-head evidence remains very limited. Current evidence comparing biologic DMARDs is limited to one head-to-head randomized controlled trial (RCT), several observational studies, indirect analyses, and our mixed treatment comparisons (MTC) meta-analyses. Based on one RCT, abatacept lessens disease activity more than infliximab, but remission rates are not significantly different at 1 year (low strength of evidence).66 Discontinuation rates and severe adverse events appear higher with infliximab; these results are also supported by observational studies.158, 248, 250, 251

Our MTC of RCTs of subjects with active RA despite MTX treatment suggest a higher odds of reaching the ACR 50 for etanercept compared to most other biologic DMARDs (low strength of evidence). Similarly, our indirect analyses from randomized trials indicate that patients taking certolizumab or etanercept are less likely to withdraw treatment than patients taking other biologic DMARDs. In contrast prior analyses found no differences among the set of anti-tumor necrosis factor (anti-TNF) drugs (namely, etanercept, infliximab, and adalimumab).28, 74, 75, 179 The differences between our results and those of previous indirect analyses may be attributed to newer studies and drugs (certolizumab, golimumab, and tocilizumab) added to the analyses, which provide additional data. Further, unlike previous indirect analyses, our MTC meta-analysis uses methods that do not rely solely on placebo-controlled trials; it also allows the inclusion of data from head-to-head studies or those with active comparators, thus increasing statistical power. In addition, for efficacy, we limited our MTC inclusion criteria to studies enrolling patient populations who had an inadequate response to MTX and excluded studies with MTX-naïve populations, those with early RA, or those who had failed anti-TNF therapy.

Our MTC meta-analysis indicates that anakinra trended toward lower efficacy. Prior indirect comparisons consistently indicated that anakinra is less efficacious than biologics for patients with RA.74, 75 Adjusted indirect comparisons, in general, have to be interpreted cautiously because the validity of results is based on assumptions that cannot be verified, particularly the similarity of study populations.

The evidence comparing monotherapy using a biologic DMARD with monotherapy using an oral DMARD is mixed. Monotherapies of adalimumab in early RA76 and etanercept in longstanding RA77, 86 generally did not reveal a benefit relative to MTX monotherapy for response rates and had mixed results for functional capacity. There was faster improvement in quality of life for etanercept. Radiographic outcomes were also significantly better in patients on biologic DMARDs than on MTX. Whether such differences are clinically relevant and can alter the long-term progression of the disease remains unclear.

Although a substantial percentage of patients respond well to DMARD monotherapy,76, 77, 86, 136, 138, 345 some patients do not achieve an acceptable treatment response. As the BeSt study (Dutch acronym for Behandel Strategieen, “treatment strategies”), a Dutch effectiveness trial assessing different treatment strategies for RA, has indicated, tight disease control and an individualized treatment approach are paramount in achieving a satisfactory treatment response or remission.100 Therefore, if dose escalation of a monotherapy does not achieve low levels of disease activity, combination therapies have to be taken into consideration. This is supported by multiple efficacy studies that indicate that combinations of biologic and oral DMARDs appear to be more efficacious than monotherapy of either drug in populations failing DMARD therapy.

The existing evidence supports combination strategies of up to three oral DMARDs, including corticosteroids, compared with strategies using one or two drugs. The data are limited, however, by the number of supporting studies for each drug combination. Moderate strength evidence from two efficacy trials reported higher proportions of patients meeting American College of Rheumatology (ACR) 20 criteria at 2 years for the combination of MTX plus sulfasalazine and hydroxychloroquine than for one or two drugs.61, 62

Combination therapy of biologic DMARDs with MTX achieved better results in clinical outcomes, functional capacity, and quality of life than monotherapy with biologic DMARDs in MTX-naïve subjects or those not recently on MTX.76, 86, 87, 136, 138 Whether these results can be extrapolated to combinations of biologic DMARDs with other oral DMARDs is uncertain. In clinical practice, patients often receive biologic DMARDs as an add-on therapy to an existing regimen of various oral DMARDs.

Combinations of two biologic DMARDs did not yield an additional treatment benefit but rather led to substantially higher rates of serious adverse events than with biologic DMARD monotherapies (14.8 percent vs. 2.5 percent; P=NR [not reported]).79, 80, 258

The evidence is limited to draw firm conclusions about whether one combination strategy is better than another in early RA. Current evidence also suggests improved functional capacity65, 95, 97, 202 and less radiographic progression65, 95–98 for combination strategies with corticosteroids and one or more oral DMARDs compared with oral DMARD monotherapy. For most of these comparisons, the evidence is limited to a single study. One effectiveness trial for patients with early RA reported less radiographic progression over 12 months with either (1) combination therapy of MTX, sulfasalazine, and high-dose tapered prednisone or (2) MTX and infliximab versus (3) sequential DMARD therapy or (4) step-up combination therapy.100 At 2 years,102 results of this study reinforced the conclusion that patients on initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone or initial combination therapy with MTX and infliximab had less radiographic progression. They also had more rapid improvement in disease activity functional capacity and quality of life, although the differences between groups were no longer present by 2 years. By 4 years, there was no difference in remission among the groups.196

Evidence of moderate strength suggests that studies of combinations of two or three DMARDs, including MTX, sulfasalazine, hydroxychloroquine, and etanercept versus one or two DMARDs had similar withdrawal rates attributable to adverse events. Studies of combinations including prednisone with one or more DMARDs had similar discontinuation rates between groups.

Similarly, patients on combinations of biologic and oral DMARDs were less likely than patients on oral DMARD monotherapy to withdraw from trials because of lack of efficacy. Combinations of biologic and oral DMARDs had similar rates of adverse events than monotherapies of either drugs However, because biologic DMARDs are relatively new medications, long-term data on safety are generally still missing. Especially rare but severe adverse events such as serious infections, lymphoma, autoimmunity, or congestive heart failure are of concern. One obvious difference among biologic DMARDs that might be clinically useful for choosing a particular drug involves dosing and administration. Abatacept, infliximab, and rituximab require intravenous administration at different intervals and present the danger of rare but severe infusion reactions. Adalimumab, anakinra, and etanercept can be administered subcutaneously by the patient. Administration intervals differ substantially: adalimumab requires an injection once a week or once every other week, anakinra has to be administered daily, and etanercept once or twice per week. The route of administration is also the cause of the main differences in short-term tolerability. Anakinra appears to have a substantially higher rate of injection site reactions than anti-TNF drugs. Abatacept, infliximab, and rituximab carry the risk of severe infusion reactions that cannot occur in drugs administered subcutaneously. Fatal infusion reactions have been reported for infliximab and rituximab.288, 301

The existing evidence remains insufficient to draw firm conclusions on the best treatment regimen for patients with early RA. Studies conducted in patients with early aggressive RA suggested that an early start of a biologic DMARD can improve disease activity, radiographic findings, functional capacity, and quality of life compared to an oral DMARD. Because the studies were of limited duration, however, they do not allow conclusions on whether early initiation of a biologic regimen can improve the long-term prognosis of RA. Currently, clinical practice guidelines recommend that clinicians start biologic DMARDs if patients have suboptimal response to oral DMARDs or only if there is high disease activity. For those patients with longer disease duration, biologics are recommended.23, 346

Furthermore, we did not find any studies directly comparing efficacy, effectiveness, and harms of drug therapies between subgroups.

## Applicability

A considerable limitation of our conclusions is that we have had to derive them primarily from efficacy trials that typically enroll a narrow spectrum of patients and are conducted in ideal settings. However, the direction and effect sizes of findings from effectiveness trials and observational studies were generally consistent with those from efficacy trials. Nonetheless, differences in the incidence of reported adverse events and discontinuation rates were obvious between clinical trials and population-based observational studies.

For example, clinical efficacy trials of infliximab reported infusion reactions, on average, in 17 percent of patients.273 A prospective cohort study in a Canadian clinical care setting, however, reported substantially higher percentages.329 Patients who were enrolled in efficacy trials usually suffered from more severe disease than the average patient in clinical practice.347 For example, only a small proportion of consecutive patients with RA who were under the care of a private practice rheumatologist in Nashville, Tennessee, would have met eligibility criteria of the ERA (Early Rheumatoid Arthritis) trial;77 only 31 percent of patients with early RA who had not taken MTX would have met the ERA criteria. The same pattern was true for the ATTRACT (anti-TNF trial in RA with concomitant therapy) study trials;148, 347 only 5 percent of patients in a long-term RA database would have been eligible for this trial. Therefore, the applicability of results from efficacy trials to the average patient in community practice appears to be limited.

Additionally, some trials comparing MTX started with a lower dosing range than what is commonly given in practice.57, 58, 110 This hinders evaluating some of the comparisons of MTX with other oral DMARDs. Otherwise, the dosing and frequencies of the included studies are directly applicable to community-based populations.

## Conclusions

Despite the limitations of the available literature, this comprehensive review describes similar efficacy, functional capacity, and tolerability among oral DMARDs. Biologic DMARD comparisons are limited to mostly observational studies and findings from MTC meta-analyses. Our MTC meta-analysis, suggest some differences, such as etanercept having a higher probability of improvement in disease activity than most other biologic DMARDs, but are limited primarily to indirect evidence (Low SOE) and, therefore, should be interpreted with caution. The limited evidence precludes drawing firm conclusions about whether one combination strategy is better than another in early RA. Overall tolerability is similar among biologic and among oral DMARDs; however, several studies suggest that adverse events are more common with biologic DMARDs compared with oral DMARDs. Limited evidence does not suggest an increased risk of severe adverse events, including cardiovascular or cancer, with oral DMARDs. Most studies found no risk of cardiovascular events and malignancy with biologic DMARDs, except for cohort studies, which describe an increased risk of heart failure with adalimumab, etanercept, and infliximab compared with oral DMARDs.

## Clinical Relevance

Although the studies comparing oral DMARDs show therapeutic equivalence, the data are sparse and of lower strength, given the range of MTX dosing used in available trials. Vast clinical experience supports the use of MTX as the oral DMARD of choice unless there are contraindications. In addition, MTX is almost universally used as the anchor drug in studies of multidrug regimens. Data on the use of other oral DMARDs in combination with biologic therapy are sparse.

Data suggest that early institution of biologic therapy improves radiographic outcomes and should be considered in patients with poor prognostic features. Clearly, however, many patients can be effectively managed with oral DMARDs alone. There are few direct comparisons that can guide the selection of a specific biologic agent. Most agents have roughly equivalent efficacy using validated RA outcome measures (except anakinra, which is less effective). The apparent superiority of etanercept in MTCs is an unexpected finding and warrants further study.

## Future Research

We have identified several areas that need further research to help clinicians and researchers arrive at stronger conclusions on the comparative efficacy, effectiveness, quality of life, and harms of medications for RA. Important areas that will influence clinical decisionmaking include three critical topics: (1) specific head-to-head comparisons focusing on different combination strategies and different biologic DMARDs, (2) timing of initiation of therapies, and (3) applicability of combination strategies and biologic DMARD therapy in community practice.

Currently, evidence from systematic reviews, placebo-controlled trials, and observational studies does not allow us to draw any firm conclusions for the head-to-head comparisons between biologic DMARDs (i.e., those with greater than low strength of evidence). Although results of the MTC found some differences among biologics, the strength of evidence remains low, and head-to-head studies are needed to confirm or refute these results. Head-to-head RCTs are ideal to establish the comparative effectiveness and safety of biologic DMARDs. However, these types of trials would be costly and may be unrealistic. Although less rigorous, one initial approach could be to collect real data generated in clinical practice; for example, large databases created from electronic medical records. This type of data would be more likely to reflect real practice.

Furthermore, we did not find any studies directly comparing efficacy, effectiveness, and harms of drug therapies between subgroups. Analyses involving subpopulations, specifically those defined by age and coexisting conditions, will be beneficial, given that RA disease onset generally occurs in middle age, when the risk of comorbidities increases.

Timing of initiation of therapies needs to be addressed, including whether aggressive early treatment in RA influences the course and prognosis beneficially. Adequately powered, long-term RCTs must examine different treatment strategies with and without corticosteroids, oral DMARDs, and biologic DMARDs to determine the best therapy to prevent or minimize debilitating joint damage in this population. These trials should be conducted over multiple years to guarantee that results provide a relevant assessment of the long-term prognosis of RA under different treatment strategies. Such trials would also provide insight about whether the long-term benefits of any combination of drugs outweigh the adverse effects.

Given that available long-term data indicate high discontinuation rates for drugs used to treat RA, having backup regimens is crucial. Additional well-conducted research is needed to assess the comparative efficacy and safety of oral DMARDs in patients who currently do not qualify for a treatment with a biologic DMARD. Also still unclear is whether newer oral DMARDs such as leflunomide have a better, long-term adverse events profile than older oral DMARDs such as MTX. Additionally, although combination strategies with oral DMARDs with or without corticosteroids appear more effective, further research examining which combination strategy is more effective would be beneficial for medical treatment decisionmaking.

Further studies need to be designed to mimic clinical decisionmaking. If patients are not doing well after 3 months of a therapy that takes less than 3 months to work, then the protocol needs to give them something different. Additionally, long-term outcomes are potentially more meaningful when protocols attempt to follow what would happen in real life. For example, radiographic progression becomes less meaningful if a clinician would have switched to a different drug due to lack of clinical effect earlier. Biologic DMARDs differ substantially in the route and frequency of administration, which can influence the choice of a biologic agent by patients and physicians. Establishing the comparative effectiveness and safety of biologic DMARDs, therefore, is helpful for balanced, informed decisionmaking.

The risk of rare but serious adverse events such as malignancies, serious infections, demyelinations, severe infusion reactions, or congestive heart failure must be established in well-conducted observational studies, such as large cohort or case-control studies. The balance of risks and benefits of biologic DMARDs can be determined reliably only if good long-term data on such harms are available.

In general, all future studies have to ensure applicability to patients seen in community practices. Future research has to establish the comparative effectiveness, health-related quality of life, and safety of all therapies, but especially biologic DMARDs, in settings that reflect daily clinical care and take into account factors such as varying adherence due to administration schedules, costs, and adverse events. The current evidence indicates that severity of disease and population characteristics may differ substantially between the highly selected populations enrolled in efficacy trials and those treated in daily clinical practice. Future trials must plan subgroup analyses in older patients or patients with comorbidities a priori.