# Mixed Treatment Comparisons Sensitivity Analysis Methods

A total of 34 studies were identified for potential inclusion in the MTC meta-analysis comparing the efficacy of biologic DMARDs. The potential studies were:

- Three studies evaluating abatacept: AIM 2006,^1^ Kremer 2003,^2^ and ATTEST 2008,^3^
- Eight studies evaluating adalimumab: ARMADA 2003,^4^ STAR 2003,^5^ Keystone 2004,^6^ van de Putte 2003,^7^ van de Putte 2004,^8^ Kim 2007,^9^ CHANGE 2008,^10^ and Chen 2008,^11^
- Three studies evaluating anakinra: Cohen 2002,^12^ Cohen 2004,^13^ and Bresnihan 1998,^14^
- Three studies evaluating certolizumab pegol: RAPID-1 2008,^15^ RAPID-2 2009,^16^ and FAST4WARD 2009,^17^
- Four studies evaluating etanercept: Moreland 1999,^18^ Weinblatt 1999,^19^ Lan 2004,^20^ Moreland 1997,^21^
- Two studies evaluating golimumab: GO-FORWARD 2009,^22^ and Kay 2008,^23^
- Six studies evaluating infliximab: ATTRACT 1999,^24^ Abe 2006,^25^ Kavanaugh 2000,^26^ START 2006,^27^ Zhang 2006,^28^ ATTEST 2008,^3^ (listed twice as it included comparisons with both abatacept and infliximab)
- Two studies evaluating rituximab: Edwards 2004,^29^ and SERENE 2010,^30^
- Four studies evaluating tocilizumab: LITHE 2010,^31^ OPTION 2008,^32^ TOWARD 2008,^33^ and CHARISMA 2006,^34^

We reviewed all 34 studies for sources of heterogeneity and to consider whether to remove any studies that we did not feel were appropriate to include in the analyses. We considered factors such as handling of missing data, early escape design, unexpected high or low treatment response, study duration, and use of monotherapy treatment. Table 1 summarizes our approach for addressing the potential sources of heterogeneity. Based on our findings, we decided to exclude four studies, CHANGE 2008,^10^ RAPID-1 2008,^15^ RAPID-2 2009,^16^ and FAST4WARD 2009,^17^ because of heterogeneity due to early escape study design. Other sources of heterogeneity were explored through four sensitivity analyses. The results of these analyses are presented and discussed in Chapter 3.

Table 1 Approach for Addressing Potential Sources of Heterogeneity

Potential Source of Heterogeneity | Description | Approach
Missing Data | Trials were evaluated for their handling of missing data for ACR50. The majority of trials either used a Last Observation Carried Forward (LOCF) approach for the components that comprise ACR50 or imputed missing ACR data at the endpoint as non-responders (NRI). | Use of different imputation approaches could lead to important differences in estimated treatment effects. Studies were reviewed to investigate whether one biologic exclusively used one approach compared to another biologic. Since ACR data for any one biologic included a mix of studies that used both LOCF and NRI, no trials were excluded based on choice of imputation approach alone.
Early escape design | Trials were evaluated for offering rescue therapy or early escape for patients who failed to achieve a minimal ACR response at a pre-specified time point in the trial. | Several trials offered some sort of rescue therapy at a pre-defined timepoint in the study, but only four trials had a mandatory early escape design and did not report outcomes prior to the early escape. There were a large number of crossovers (from placebo to active treatment) in these studies that might lead to inaccurate calculations of treatment effects. As a result, four studies (CHANGE 2008,10 RAPID-1 2008,^15^ RAPID-2 2009,^16^ and FAST4WARD 2009,17) were not included in our main MTC analysis. These four studies included all three potentially eligible studies of certolizumab pegol. We added the four studies back in a sensitivity analysis to gauge potential impact on overall results. As a result of this approach, certolizumab pegol is now only included in the sensitivity analysis results in Chapter 3. A fifth study, GO-FORWARD 2009,^22^ evaluating goliumumab also had a mandatory early escape design, but ACR50 data were available at time of early escape, so this study was kept in the analysis and the outcomes prior to early escape were used.
Monotherapy | Some trials included in the MTC did not have patients in the relevant arms on a background dose of Methotrexate. | In order to separate out the effects that combination therapy may have on the relative treatment effects, monotherapy trials were removed in a sensitivity analysis.
Study Duration | Studies included in the main MTC meta-analysis had durations of three months or more. | In order to evaluate whether study duration influenced our findings, and to compare with other analyses that have used a 6 month cutoff, the ACR50 analysis was rerun with studies of durations of 22 weeks or longer (approximately 6 months).
High or low ACR response | Trials were evaluated for unexpected high treatment response or low placebo response. | Two trials with etanercept, Lan 2004,^20^ and Moreland 1997,^21^ had both a high ACR50 response and low placebo response. Due to the relatively large differences between treatment and placebo response, we removed these two trials in a sensitivity analysis.

## References

1 Kremer JM, Genant HK, Moreland LW, Russell AS, Westhovens R, et al. Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis - A randomized trial. Annals of Internal Medicine (USA). 2006:865-76.
2 Kremer JM, Westhovens R, Leon M, Di Giorgio E, Alten R, Steinfeld S, et al. Treatment of rheumatoid arthritis by selective inhibition of T-cell activation with fusion protein CTLA4Ig. N Engl J Med. 2003:1907-15. [pmid: 14614165].
3 Schiff M, Keiserman M, Codding C, Songcharoen S, Berman A, Nayiager S, et al. Efficacy and safety of abatacept or infliximab vs placebo in ATTEST: a phase III, multi-centre, randomised, double-blind, placebo-controlled study in patients with rheumatoid arthritis and an inadequate response to methotrexate. Ann Rheum Dis. 2008:1096-103. [pmid: 18055472].
4 Weinblatt ME, Keystone EC, Furst DE, Moreland LW, Weisman MH, Birbara CA, et al. Adalimumab, a fully human anti-tumor necrosis factor alpha monoclonal antibody, for the treatment of rheumatoid arthritis in patients taking concomitant methotrexate: the ARMADA trial. Arthritis Rheum. Jan. 2003;48(1):35-45. [pmid: 12528101].
5 Furst DE, Schiff MH, Fleischmann RM, Strand V, Birbara CA, Compagnone D, et al. Adalimumab, a fully human anti tumor necrosis factor-alpha monoclonal antibody, and concomitant standard antirheumatic therapy for the treatment of rheumatoid arthritis: results of STAR (Safety Trial of Adalimumab in Rheumatoid Arthritis). J Rheumatol. Dec. 2003;30(12):2563-71. [pmid: 14719195].
6 Keystone EC, Kavanaugh AF, Sharp JT, Tannenbaum H, Hua Y, Teoh LS, et al. Radiographic, clinical, and functional outcomes of treatment with adalimumab (a human anti-tumor necrosis factor monoclonal antibody) in patients with active rheumatoid arthritis receiving concomitant methotrexate therapy: a randomized, placebo-controlled, 52-week trial. Arthritis Rheum. May. 2004;50(5):1400-11. [pmid: 15146409].
7 van de Putte LB, Rau R, Breedveld FC, Kalden JR, Malaise MG, van Riel PL, et al. Efficacy and safety of the fully human anti-tumour necrosis factor alpha monoclonal antibody adalimumab (D2E7) in DMARD refractory patients with rheumatoid arthritis: a 12 week, phase II study. Ann Rheum Dis. Dec. 2003;62(12):1168-77. [pmid: 14644854].
8 van de Putte LB, Atkins C, Malaise M, Sany J, Russell AS, van Riel PL, et al. Efficacy and safety of adalimumab as monotherapy in patients with rheumatoid arthritis for whom previous disease modifying antirheumatic drug treatment has failed. Ann Rheum Dis. May. 2004;63(5):508-16. [pmid: 15082480].
9 Kim HY, Lee SK, Song YW, Yoo DH, Koh EM, Yoo B, et al. A randomized, double-blind, placebo-controlled, phase III study of the human anti-tumor necrosis factor antibody adalimumab administered as subcutaneous injections in Korean rheumatoid arthritis patients treated with methotrexate. APLAR Journal of Rheumatology. 2007:9-16.
10 Miyasaka N. Clinical investigation in highly disease-affected rheumatoid arthritis patients in Japan with adalimumab applying standard and general evaluation: the CHANGE study. Mod Rheumatol. 2008:252-62. [pmid: 18330677].
11 Chen DY, Chou SJ, Hsieh TY, Chen YH, Chen HH, Hsieh CW, et al. Randomized, double-blind, placebo-controlled, comparative study of human anti-TNF antibody adalimumab in combination with methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis. 2009.
12 Cohen S, Hurd E, Cush J, Schiff M, Weinblatt ME, Moreland LW, et al. Treatment of rheumatoid arthritis with anakinra, a recombinant human interleukin-1 receptor antagonist, in combination with methotrexate: results of a twenty-four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Mar. 2002;46(3):614-24. [pmid: 11920396].
13 Cohen SB, Moreland LW, Cush JJ, Greenwald MW, Block S, Shergy WJ, et al. A multicentre, double blind, randomised, placebo controlled trial of anakinra (Kineret), a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis treated with background methotrexate. Ann Rheum Dis. Sep. 2004;63(9):1062-8. [pmid: 15082469].
14 Bresnihan B, Alvaro-Gracia JM, Cobby M, Doherty M, Domljan Z, Emery P, et al. Treatment of rheumatoid arthritis with recombinant human interleukin-1 receptor antagonist. Arthritis Rheum. 1998:2196-204. [pmid: 9870876].
15 Keystone E, Heijde D, Mason D Jr, Landewe R, Vollenhoven RV, Combe B, et al. Certolizumab pegol plus methotrexate is significantly more effective than placebo plus methotrexate in active rheumatoid arthritis: findings of a fifty-two-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum. 2008:3319-29. [pmid: 18975346].
16 Smolen J, Landewe RB, Mease P, Brzezicki J, Mason D, Luijtens K, et al. Efficacy and safety of certolizumab pegol plus methotrexate in active rheumatoid arthritis: the RAPID 2 study. A randomised controlled trial. Ann Rheum Dis. 2009:797-804. [pmid: 19015207].
17 Fleischmann R, Vencovsky J, van Vollenhoven RF, Borenstein D, Box J, Coteur G, et al. Efficacy and safety of certolizumab pegol monotherapy every 4 weeks in patients with rheumatoid arthritis failing previous disease-modifying antirheumatic therapy: the FAST4WARD study. Ann Rheum Dis. Jun. 2009;68(6):805-11. [pmid: 19015206].
18 Moreland LW, Schiff MH, Baumgartner SW, Tindall EA, Fleischmann RM, Bulpitt KJ, et al. Etanercept therapy in rheumatoid arthritis. A randomized, controlled trial. Ann Intern Med. Mar. 16. 1999;130(6):478-86. [pmid: 10075615].
19 Weinblatt ME, Kremer JM, Bankhurst AD, Bulpitt KJ, Fleischmann RM, Fox RI, et al. A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. N Engl J Med. Jan. 28. 1999;340(4):253-9. [pmid: 9920948].
20 Lan JL, Chou SJ, Chen DY, Chen YH, Hsieh TY, Young M Jr. A comparative study of etanercept plus methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis: a 12-week, double-blind, randomized, placebo-controlled study. J Formos Med Assoc. Aug. 2004;103(8):618-23. [pmid: 15340661].
21 Moreland LW, Baumgartner SW, Schiff MH, Tindall EA, Fleischmann RM, Weaver AL, et al. Treatment of rheumatoid arthritis with a recombinant human tumor necrosis factor receptor (p75)-Fc fusion protein. N Engl J Med. Jul. 17. 1997;337(3):141-7. [pmid: 9219699].
22 Keystone EC, Genovese MC, Klareskog L, Hsia EC, Hall ST, Miranda PC, et al. Golimumab, a human antibody to tumour necrosis factor {alpha} given by monthly subcutaneous injections, in active rheumatoid arthritis despite methotrexate therapy: the GO-FORWARD Study. Ann Rheum Dis. 2009:789-96. [pmid: 19066176].
23 Kay J, Matteson EL, Dasgupta B, Nash P, Durez P, Hall S, et al. Golimumab in patients with active rheumatoid arthritis despite treatment with methotrexate: a randomized, double-blind, placebo-controlled, dose-ranging study. Arthritis Rheum. 2008:964-75. [pmid: 18383539].
24 Maini R, St Clair EW, Breedveld F, Furst D, Kalden J, Weisman M, et al. Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a randomised phase III trial. ATTRACT Study Group. Lancet. Dec. 4. 1999;354(9194):1932-9. [pmid: 10622295].
25 Abe T, Takeuchi T, Miyasaka N, Hashimoto H, Kondo H, Ichikawa Y, et al. A multicenter, double-blind, randomized, placebo controlled trial of infliximab combined with low dose methotrexate in Japanese patients with rheumatoid arthritis. J Rheumatol. Jan. 2006;33(1):37-44. [pmid: 16395748].
26 Kavanaugh A, St Clair EW, McCune WJ, Braakman T, Lipsky P. Chimeric anti-tumor necrosis factor-alpha monoclonal antibody treatment of patients with rheumatoid arthritis receiving methotrexate therapy. J Rheumatol. Apr. 2000;27(4):841-50. [pmid: 10782805].
27 Westhovens R, Yocum D, Han J, Berman A, Strusberg I, Geusens P, et al. The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum. Apr. 2006;54(4):1075-86. [pmid: 16572442].
28 Zhang FC, Hou Y, Huang F, Wu DH, Bao CD, Ni LQ, et al. Infliximab versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: A preliminary study from China. APLAR Journal of Rheumatology. 2006:127-30.
29 Edwards JC, Szczepanski L, Szechinski J, Filipowicz-Sosnowska A, Emery P, Close DR, et al. Efficacy of B-cell-targeted therapy with rituximab in patients with rheumatoid arthritis. N Engl J Med. Jun. 17. 2004;350(25):2572-81. [pmid: 15201414].
30 Emery P, Deodhar A, Rigby WF, Isaacs JD, Combe B, Racewicz AJ, et al. Efficacy and safety of different doses and retreatment of rituximab: a randomised, placebo-controlled trial in patients who are biological naive with active rheumatoid arthritis and an inadequate response to methotrexate (Study Evaluating Rituximab’s Efficacy in MTX iNadequate rEsponders (SERENE)). Ann Rheum Dis. 2010/05/22 ed. 2010:1629-35.
31 Kremer JL, Blanco R, Brzosko M, Burgos-Vargas R, Halland AM, Vernon E, et al. Tocilizumab inhibits structural joint damage in rheumatoid arthritis patients with inadequate responses to methotrexate at 1 year: The LITHE study. Arthritis Rheum. 2010.
32 Smolen JS, Beaulieu A, Rubbert-Roth A, Ramos-Remus C, Rovensky J, Alecock E, et al. Effect of interleukin-6 receptor inhibition with tocilizumab in patients with rheumatoid arthritis (OPTION study): a double-blind, placebo-controlled, randomised trial. Lancet. 2008:987-97. [pmid: 18358926].
33 Genovese MC, McKay JD, Nasonov EL, Mysler EF, Da Silva NA, Alecock E, et al. Interleukin-6 receptor inhibition with tocilizumab reduces disease activity in rheumatoid arthritis with inadequate response to disease-modifying antirheumatic drugs: The tocilizumab in combination with traditional disease-modifying antirheumatic drug therapy study. Arthritis and Rheumatism. 2008:2968-80. [pmid: 18821691].
34 Maini RN, Taylor PC, Szechinski J, Pavelka K, Broll J, Balint G, et al. Double-blind randomized controlled clinical trial of the interleukin-6 receptor antagonist, tocilizumab, in European patients with rheumatoid arthritis who had an incomplete response to methotrexate. Arthritis Rheum. 2006:2817-29. [pmid: 16947782].