# Mixed Treatment Comparisons Results: ACR 20 and ACR 70

Relative Treatment Effect for ACR20 Response

Figure J-1 displays a forest plot of the relative ACR20 treatment effect between eight biologic DMARDs: abatacept, adalimumab, anakinra, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative treatment effect of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 56 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents the line of no difference. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one favor the first drug listed in the comparison, while ratios less than one favor the second drug listed in the comparison. Most ACR20 comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: adalimumab versus anakinra, OR 1.93 and 95 percent credible interval of 1.15 to 3.63; etanercept versus abatacept, OR 4.20 and 95 percent credible interval of 1.88 to 8.23; etanercept versus adalimumab, OR 3.40 and 95 percent credible interval of 1.59 to 6.37; etanercept versus anakinra, OR 6.93 and 95 percent credible interval of 2.99 to 13.90; etanercept versus golimumab, OR 4.54 and 95 percent credible interval of 2.04 to 12.44; etanercept versus infliximab, OR 3.41 and 95 percent credible interval of 1.82 to 7.34; etanercept versus rituximab, OR 3.00 and 95 percent credible interval of 1.38 to 7.84; and etanercept versus tocilizumab, OR 3.34 and 95 percent credible interval of 1.77 to 7.31.

Relative Treatment Effect for ACR70 Response

Figure J1 displays a forest plot of the relative ACR70 treatment effect between eight biologic DMARDs: abatacept, adalimumab, anakinra, etanercept, golimumab, infliximab, rituximab, and tocilizumab. The relative treatment effect of each pairwise comparison is presented as an odds ratio and 95 percent credible interval. The drug comparisons are listed on the left-hand side (e.g. Abatacept vs. Adalimumab) and there are a total of 56 pairwise comparisons presented. In the center of the figure, the odds ratios are presented as boxes along the x-axis ranging from a scale of 0.01 to 100. Each box has a line running through it representing the width of the credible interval. On the right-hand side of the graph the odds ratios and 95 percent credible intervals are listed down the page corresponding to the box and line graphic in the center and the drug comparison on the right-hand side. A vertical line running the center of the page for an odds ratio equal to one represents the line of no difference. For each comparison, if the credible interval crosses the line of no difference, then a conclusion of no statistically significant difference between the two drugs is supported. Odds ratios greater than one favor the first drug listed in the comparison, while ratios less than one favor the second drug listed in the comparison. Most ACR70 comparisons crossed this line of no difference. Differences reaching statistical significance include the following comparisons: etanercept versus abatacept, OR 11.98 and 95 percent credible interval of 1.30 to 54.89; etanercept versus infliximab, OR 4.33 and 95 percent credible interval of 1.23 to 47.82; and etanercept versus rituximab, OR 6.45 and 95 percent credible interval of 1.59 to 95.79.