# Excluded Studies: Characteristics of Studies With Poor Internal Validity

Characteristics of Studies with Poor Internal Validity

Study | Design | Sample Size | Intervention | Reason for Exclusion
Anis et al., 2009^1^ | RCT subanalysis | 205 | Etanercept | High risk of bias due to loss of effect of randomization
Bathon et al., 2006^2^ | Pooled data analysis | 2,402 | Etanercept | Selection bias
Bazzani et al., 2009^3^ | Prospective cohort registry study | 1010 | Etanercept Adalimumab Infliximab corticosteroid | Selection bias
Bejarno et al., 2008^4^ | RCT | 148 | Adalimumab Methotrexate | Very high LTF
‡Burmester et al., 2007^5^ | Prospective cohort open-label study | 6610 | Adalimumab Combo therapy with 1+ DMARD | high risk of bias; confounding by indication
Chopra et al., 2008^6^ | Prospective cohort study | 230 | Leflunomide Methotrexate | High LTF; completers analysis for outcome of interest; selection bias
Cohen et al, 2010^7^ | Post hoc analysis of RCT data | 468 | Rituximab Methotrexate | High risk of bias due to loss of effect of randomization
Cole et al., 2007^8^ | Retrospective cohort study | 303 | Etanercept Adalimumab Infliximab Methylprednisolone | Inadequate control for potential confounders; retrospective study with chart review; groups not similar at baseline; small sample size
De Stefano, 2010^9^ | Non-randomized controlled trial | 120 | Anti-TNF therapy Methotrexate Leflunomide | High LTF; no randomization; non-ITT analysis
de Nijs et al., 2001^10^ | Cross-sectional | 410 | Corticosteroids | Selection bias
Faarvang et al., 1993^11^ | RCT | 91 | Hydroxychloroquine Sulfasalazine | No ITT analysis; high LTF
Fleischmann et al., 2003^12^ | Pooled data analysis | 1128 | Etanercept | Selection bias
Flendrie et al., 2005^13^ | Observational | 162 | Leflunomide infliximab | High LTF; selection bias
Ghosh et al., 2008^14^ | RCT | 110 | Methotrexate Sulfasalazine Hydroxychlorquine | Randomization/allocation not adequately reported; inadequate reporting of baseline measures
Guignard et al., 2008^15^ | Retrospective cohort study | 2707 | Anti-TNF therapy Non anti-TNF therapy | No adjustment for confounders and effect modifiers; small sample size; single center
Hafstrem et al., 2009^16^ | RCT | 150 | Prednisolone | High LTF
Hansen et al., 1999^17^ | RCT | 102 | DMARDs Prednisolone | High attrition; no ITT analysis
Heiberg et al., 2006^18^ | Observational | 183 | Adalimumab Methotrexate | High potential for selection bias and confounding; baseline differences between groups
Iwatani et al., 2006^19^ | Cross-sectional prospective cohort | 313 | Sulfasalazine Methotrexate Bucillamine | Selection bias; high potential for confounding
Jones, et al., 2010^20^ | RCT | 570 | Tocilizumab Methotrexate | Attrition NR; quality of randomization and allocation concealment unclear
Karlsson et al., 2008^21^ | Prospective cohort study | 473 | Second-line anti-TNF therapy Third-line anti-TNF therapy | High LTF; Poor inter-rater reliability
Kimel et al., 2008^22^ | RCT | 525 | Adalimumab Methotrexate | Selection bias; High LTF; no ITT analysis; analyses do not directly compare the two treatment groups
Lee et al., 2008^23^ | Adjusted indirect comparison | N/A | Anti-TNF therapy Methotrexate | High risk of bias due to small number of studies (3) included in indirect comparisons
Mariette et al., 2010^24^ | Case-control study | 111 | Etanercept Infliximab Adalimumab | Small sample size; control for confounding unclear
Mattey et al., 2009^25^ | Observational | 154 | Infliximab Etanercept | No baseline characteristics reported; no adjustments made for different lengths of treatment
Mertz and Blair, 2007^26^ | Retrospective observational Study | 287 | Anti-TNF therapy Methotrexate Azathioprine Leflunomide Prednisone | Confounding by indication; selection bias; groups not similar at baseline
Nagashima et al., 2006^27^ | Prospective cohort | 1358 | Sulfasalazine Methotrexate | No adjustments for confounding; unequal treatment duration; unclear if groups are similar at baseline
Osiri et al., 2006^28^ | Prospective cohort | 152 | Methotrexate Sulfasalazine Leflunomide | High potential for bias due to confounding by indication
Schoels et al., 2007^29^ | Prospective cohort study | 1214 | Methotrexate Sulfasalazine Leflunomide Other unspecified DMARS | Attrition data not reported; not clear if groups are similar at baseline
Seong et al., 2007^30^ | Retrospective cohort study | 1478 | Anti-TNF naïve Infliximab Etanercept | Selection bias; groups not comparable at baseline; high potential for confounding
Soderlin et al., 2007^31^ | Prospective cohort | 357 | Biologics Methotrexate | High LTF; important potential confounders not accounted for
‡Strand et al., 2006 32 | RCT | 161 | Rituximab Methotrexate | Very high LTF
Todoerti et al., 2010^33^ | RCT | 210 | Prednisone | Poor reporting of outcomes; statistical methods or study design to reduce confounding unclear
van der Heijde et al., 2007^34^ | RCT | 414 | Etanercept Methotrexate | High LTF
van Vollenhoven et al., 2010^35^ | Observational | 664 | Adalimumab Methotrexate | High LTF; important baseline differences between groups; high risk of selection bias
Weisman et al., 2007^36^ | RCT | 564 | Etanercept Placebo | High LTF; not powered to detect a difference in these rare outcomes; some baseline differences in cardiovascular risk factors

NR, not reported; ITT, intention to treat; LTF, loss to followup; RCT, randomized controlled trial.

‡ Rated fair for adverse events or included in adverse events meta-analysis

## References

1 Anis A, Zhang W, Emery P, et al. The effect of etanercept on work productivity in patients with early active rheumatoid arthritis: results from the COMET study. Rheumatology (Oxford). 2009;48(10):1283-9. [pmid: 19690125].
2 Bathon JM, Fleischmann RM, Van der Heijde D, et al. Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. J Rheumatol. Feb. 2006;33(2):234-43. [pmid: 16465653].
3 Bazzani C, Filippini M, Caporali R, et al. Anti-TNFalpha therapy in a cohort of rheumatoid arthritis patients: Clinical outcomes. Autoimmunity Reviews. 2009;8(3):260-5. [pmid: 19027090].
4 Bejarano V, Quinn M, Conaghan PG, et al. Effect of the early use of the anti-tumor necrosis factor adalimumab on the prevention of job loss in patients with early rheumatoid arthritis. Arthritis Rheum. 2008;59(10):1467-74. [pmid: 18821658].
5 Burmester GR, Mariette X, Montecucco C, et al. Adalimumab alone and in combination with disease-modifying antirheumatic drugs for the treatment of rheumatoid arthritis in clinical practice: the Research in Active Rheumatoid Arthritis (ReAct) trial. Ann Rheum Dis. 2007;66(6):732-9. [pmid: 17329305].
6 Chopra A, Saluja M, Lagu-Joshi V, et al. Leflunomide (Arava) is a useful DMARD in Indian (Asian) patients: a clinic-based observational study of 1-year treatment. Clin Rheumatol. 2008;27(8):1039-44. [pmid: 18470473].
7 Cohen SB, Keystone E, Genovese MC, et al. Continued inhibition of structural damage over 2 years in patients with rheumatoid arthritis treated with rituximab in combination with methotrexate. Ann Rheum Dis. 2010;69(6):1158-61. [pmid: 20439295].
8 Cole J, Busti A, Kazi S. The incidence of new onset congestive heart failure and heart failure exacerbation in Veteran’s Affairs patients receiving tumor necrosis factor alpha antagonists. Rheumatol Int. 2007;27(4):369-73. [pmid: 17028862].
9 De Stefano R, Frati E, Nargi F, et al. Comparison of combination therapies in the treatment of rheumatoid arthritis: leflunomide-anti-TNF-alpha versus methotrexate-anti-TNF-alpha. Clin Rheumatol. 2010;29(5):517-24. [pmid: 20082236].
10 de Nijs RN, Jacobs JW, Bijlsma JW, et al. Prevalence of vertebral deformities and symptomatic vertebral fractures in corticosteroid treated patients with rheumatoid arthritis. Rheumatology (Oxford). Dec. 2001;40(12):1375-83. [pmid: 11752508].
11 Faarvang K, Egsmose C, Kryger P, et al. Hydroxychloroquine and Sulphasalazine Alone and in Combination in Rheumatoid Arthritis: a Randomised Double Blind Trial. Annals of the rheumatic diseases. 1993;52(10):711-5. [pmid: 7903034].
12 Fleischmann RM, Baumgartner SW, Tindall EA, et al. Response to etanercept (Enbrel) in elderly patients with rheumatoid arthritis: a retrospective analysis of clinical trial results. J Rheumatol. Apr. 2003;30(4):691-6. [pmid: 12672185].
13 Flendrie M, Creemers MC, Welsing PM, et al. The influence of previous and concomitant leflunomide on the efficacy and safety of infliximab therapy in patients with rheumatoid arthritis; a longitudinal observational study. Rheumatology (Oxford). Apr. 2005;44(4):472-8. [pmid: 15598707].
14 Ghosh B, Halder S, Ghosh A, et al. Early rheumatoid arthritis: Clinical and therapeutic evaluation in a tertiary care centre in India. Indian Journal of Rheumatology. 2008;3(2):48-51.
15 Guignard S, Gossec L, Bandinelli F, et al. Comparison of the clinical characteristics of vasculitis occurring during anti-tumor necrosis factor treatment or not in rheumatoid arthritis patients. A systematic review of 2707 patients, 18 vasculitis. Clin Exp Rheumatol. 2008;26(3 Suppl 49):S23-9. [pmid: 18799049].
16 Hafstrem I, Albertsson K, Boonen A, et al. Remission achieved after 2 years treatment with low-dose prednisolone in addition to diseasemodifying anti-rheumatic drugs in early rheumatoid arthritis is associated with reduced joint destruction still present after 4 years: An open 2-year continuation study. 2009.
17 Hansen M, Podenphant J, Florescu A, et al. A Randomised Trial of Differentiated Prednisolone Treatment in Active Rheumatoid Arthritis. Clinical Benefits and Skeletal Side Effects. Annals of the rheumatic diseases. 1999;58(11):713-8. [pmid: 10531077].
18 Heiberg MS, RÃ¸devand E, Mikkelsen K, et al. Adalimumab and methotrexate is more effective than adalimumab alone in patients with established rheumatoid arthritis: Results from a 6-month longitudinal, observational, multicentre study. Annals of the rheumatic diseases. 2006;65(10):1379-83. [pmid: 16679432].
19 Iwatani M, Inoue E, Nakamura T, et al. Efficacy profile of bucillamine in rheumatoid arthritis patients in a large observational cohort study, IORRA. Mod Rheumatol. 2006;16(6):376-80. [pmid: 17165000].
20 Jones G. The AMBITION trial: tocilizumab monotherapy for rheumatoid arthritis. Expert Rev Clin Immunol. 2010;6(2):189-95. [pmid: 20402381].
21 Karlsson JA, Kristensen LE, Kapetanovic MC, et al. Treatment response to a second or third TNF-inhibitor in RA: results from the South Swedish Arthritis Treatment Group Register. Rheumatology (Oxford). 2008;47(4):507-13. [pmid: 18304941].
22 Kimel M, Cifaldi M, Chen N, et al. Adalimumab plus methotrexate improved SF-36 scores and reduced the effect of rheumatoid arthritis (RA) on work activity for patients with early RA. J Rheumatol. 2008;35(2):206-15. [pmid: 18085743].
23 Lee YH, Woo JH, Rho YH, et al. Meta-analysis of the combination of TNF inhibitors plus MTX compared to MTX monotherapy, and the adjusted indirect comparison of TNF inhibitors in patients suffering from active rheumatoid arthritis. Rheumatology international. 2008;28(6):553-9. [pmid: 17943257].
24 Mariette X, Tubach F, Bagheri H, et al. Lymphoma in patients treated with anti-TNF: Results of the 3-year prospective French RATIO registry. Annals of the rheumatic diseases. 2010;69(2):400-8. [pmid: 19828563].
25 Mattey DL, Brownfield A, Dawes PT. Relationship between pack-year history of smoking and response to tumor necrosis factor antagonists in patients with rheumatoid arthritis. J Rheumatol. 2009;36(6):1180-7. [pmid: 19447930].
26 Mertz LE, Blair JE. Coccidioidomycosis in rheumatology patients: incidence and potential risk factors. Ann N Y Acad Sci. 2007:1111343-57.
27 Nagashima M, Matsuoka T, Saitoh K, et al. Treatment continuation rate in relation to efficacy and toxicity in long-term therapy with low-dose methotrexate, sulfasalazine, and bucillamine in 1,358 Japanese patients with rheumatoid arthritis. Clin Exp Rheumatol. 2006;24(3):260-7. [pmid: 16870092].
28 Osiri M, Deesomchok U, Tugwell P. Disease activity and functional changes of RA patients receiving different DMARDs in clinical practice. Clin Rheumatol. 2006;25(5):721-7. [pmid: 16365685].
29 Schoels M, Kapral T, Stamm T, et al. Step-up combination versus switching of non-biological disease-modifying antirheumatic drugs in rheumatoid arthritis: results from a retrospective observational study. Ann Rheum Dis. 2007;66(8):1059-65. [pmid: 17307765].
30 Seong SS, Choi CB, Woo JH, et al. Incidence of tuberculosis in Korean patients with rheumatoid arthritis (RA): effects of RA itself and of tumor necrosis factor blockers. J Rheumatol. Apr. 2007;34(4):706-11. [pmid: 17309133].
31 Soderlin MK, Lindroth Y, Jacobsson LT. Trends in medication and health-related quality of life in a population-based rheumatoid arthritis register in Malmo, Sweden. Rheumatology (Oxford). 2007;46(8):1355-8. [pmid: 17567634].
32 Strand V, Balbir-Gurman A, Pavelka K, et al. Sustained benefit in rheumatoid arthritis following one course of rituximab: improvements in physical function over 2 years. Rheumatology (Oxford). 2006;45(12):1505-13. [pmid: 17062648].
33 Todoerti M, Scire CA, Boffini N, et al. Early disease control by low-dose prednisone comedication may affect the quality of remission in patients with early rheumatoid arthritis. Ann N Y Acad Sci. 2010;1193(1):139-45. [pmid: 20398020].
34 van der Heijde D, Klareskog L, Landewe R, et al. Disease remission and sustained halting of radiographic progression with combination etanercept and methotrexate in patients with rheumatoid arthritis. Arthritis Rheum. 2007;56(12):3928-39. [pmid: 18050208].
35 van Vollenhoven RF, Cifaldi MA, Ray S, et al. Improvement in work place and household productivity for patients with early rheumatoid arthritis treated with adalimumab plus methotrexate: work outcomes and their correlations with clinical and radiographic measures from a randomized controlled trial companion study. Arthritis Care Res (Hoboken). 2010;62(2):226-34. [pmid: 20191522].
36 Weisman MH, Paulus HE, Burch FX, et al. A placebo-controlled, randomized, double-blinded study evaluating the safety of etanercept in patients with rheumatoid arthritis and concomitant comorbid diseases. Rheumatology (Oxford). 2007;46(7):1122-5. [pmid: 17470434].