# Evidence Tables

## Index of Studies by Key Question

### KQ1

#### RCTs and other studies found in Evidence Table 1

- Allaart, 2006 – found under Goekoop-Ruiterman, 2005
- Bathon, 2000
- Boers, 1997
- Breedveld, 2006
- Capell, 2006
- Choy, 2008
- Cohen, 2001 – found under Strand 1999
- Cohen, 2006
- Combe, 2006
- Dougados, 1999
- Emery, 2000
- Emery, 2006
- Emery, 2008
- Emery, 2008
- Emery, 2009
- Emery, 2010
- Emery, 2010
- Fernandez-Nebro, 2007
- Finckh, 2007
- Finckh, 2009
- Fleischmann, 2009
- Furst, 2003
- Geborek, 2002
- Genovese, 2002 – found under Bathon 2000
- Genovese, 2004
- Genovese, 2005 – found under Bathon 2000
- Genovese, 2008
- Goekoop-Ruiterman, 2005
- Goekoop-Ruiterman, 2007 – found under Goekoop-Ruiterman 2005
- Haagsma, 1997
- Hetland, 2010
- Hoff, 2009
- Hyrich, 2006
- Hyrich, 2006 [Change ET to say 2006] in 2003 file
- Karanikola, 2008
- Kavanaugh, 2008 – found under Klareskog 2004
- Kay, 2008
- Keystone, 2008
- Keystone, 2008 – found under Cohen 2006
- Keystone, 2009
- Keystone, 2009 – found under Cohen 2006
- Keystone, 2010
- Kievit, 2008
- Kim, 2007
- Kirwan, 2004
- Klareskog, 2004
- Korpela, 2004 – found under Mottonen 1999
- Kremer, 2006
- Kremer, 2010
- kristensen, 2006
- Kristensen, 2007
- Larsen, 2001 – found under Smolen 1999
- Lee, 2008
- Listing, 2006
- Maillefert, 2003 – found under Dougados 1999
- Maini, 2006
- Miyasaka, 2008
- Mottonen, 1999
- Mottonen, 2002 – found under Mottonen 1999
- Nishimoto, 2009
- O’Dell, 1996
- O’Dell, 2002
- Osiri, 2002
- Schiff, 2008
- Schipper, 2009
- Sharp, 2000 – found under Smolen 1999
- Smolen, 1999
- Smolen, 1999
- Smolen, 2005 – found under Breedveld 2004
- Smolen, 2006 – found under St. Clair 2004
- Smolen, 2008
- Smolen, 2009
- Smolen, 2009
- St. Clair, 2004
- Strand, 1999
- Svensson, 2005
- van der Heijde, 2005 – found under Klareskog 2004
- van der Heijde, 20062005 – found under Klareskog 2004
- van der Heijde, 20062005 – found under Klareskog 2004
- van der Kooij, 2008
- van der Kooij, 2009 – found under Goekoop-Ruiterman 2005
- van der Kooij, 2009 – found under Goekoop-Ruiterman 2005
- van Riel, 2006
- van Vollenhoven, 2009
- Weaver, 2006
- Weinblatt, 1999
- Weinblatt, 2007
- Westhovens, 2006
- Westhovens, 2009
- Zhang, 2006
- Zink, 2005

#### Systematic Reviews and Meta-analyses found in Evidence Table 2

- Alonso-Ruiz, 2008
- Bergman, 2010
- Clark, 2004
- Devine, 2011
- Gartlehner, 2006
- Gaujoux-Viala, 2010
- Hochberg, 2003
- Kirwan, 2009
- Kuriya, 2010
- Nam, 2010
- Osiri, 2002/9
- Singh, 2009
- Singh, 2009
- Singh, 2010
- Singh, 2010
- Wailoo, 2006
- Wiens, 2010

Does not have Schipper

### KQ2

#### RCTs and other studies found in Evidence Table 1

- Allaart, 2006 – found under Goekoop-Ruiterman 2005
- Bathon, 2000
- Boers, 1997
- Breedveld, 2006
- Capell, 2006
- Choy, 2008
- Cohen, 2001 – found under Strand 1999
- Combe, 2006
- Combe, 2009
- Dougados, 1999
- Emery, 2000
- Emery, 2006
- Emery, 2006
- Emery, 2008
- Emery, 2008
- Emery, 2009
- Emery, 2010
- Fernandez-Nebro, 2007
- Finckh, 2009
- Genovese, 2002 – found under Bathon 2000
- Genovese, 2005 – found under Bathon 2000
- Goekoop-Ruiterman, 2005
- Goekoop-Ruiterman, 2007 – found under Goekoop-Ruiterman 2005
- Haagsma, 1997
- Hassett, 2008
- Kekow, 2010
- Keystone, 2008 – found under Cohen 2006
- Kievit, 2008
- Kirwan, 2004
- Klareskog, 2004
- Korpela, 2004 – found under Mottonen 1999
- Kosinski, 2002 – found under Bathon 2000
- Kremer, 2010
- Landewe, 2002 – found under Boers 1997
- Li, 2008
- Listing, 2006
- Maillefert, 2003 – found under Dougados 1999
- Mease, 2008
- Mottonen, 1999
- Nishimoto, 2009
- Osiri, 2002
- Puolakka, 1487 – found under Mottonen 1999
- Schiff, 2008
- Scott, 2000 – found under Smolen 1999
- Smolen, 1999
- Smolen, 2005 – found under Breedveld 1004
- Smolen, 2006 – found under St. Clair 2004
- St. Clair, 2004
- Strand, 1999
- Svensson, 2005
- van der Heijde, 2005 – found under Klareskog 2004
- van der Heijde, 2006 – found under Klareskog 2004
- van der Heijde, 2006 – found under Klareskog 2004
- van der Kooij, 2009 – found under Goekoop-Ruiterman 2005
- van der Kooij, 2009 – found under Goekoop-Ruiterman 2005
- van Riel, 2008
- Weaver, 2006
- Weinblatt, 2007
- Wells, 2008 – found under Westhovens 2006
- Westhovens, 2006
- Westhovens, 2009

#### Systematic Reviews and Meta-analyses found in Evidence Table 2

- Gaujoux-Viala, 2010
- Mertens, 2009
- Osiri, 2002/9
- Singh, 2010
- Singh, 2010

### KQ3

#### RCTs and other studies found in Evidence Table 1

- Allaart, 2006 – found under Goekoop-Ruiterman 2005
- Askling, 2005
- Askling, 2005
- Askling, 2005
- Askling, 2009
- Baecklund, 2006
- Bathon, 2000
- Bergstrom, 2004
- Bernatsky, 2007
- Boers, 1997
- Brassard, 2006
- Brassard, 2009
- Breedveld, 2006
- Brown, 2002
- Burmester
- Cannon, 2004
- Capell, 2006
- Chakravarty, 2005
- Choy, 2008
- Chung, 2003
- Cohen, 2001 – found under Strand 1999
- Cohen, 2006
- Combe, 2006
- Combe, 2009
- Curtis, 2007
- Curtis, 2007
- Curtis, 2007
- DeBandt, 2005
- den Broeder, 2007
- Dixon, 2006
- Dixon, 2007
- Dixon, 2010
- Doran, 2002
- Dougados, 1999
- Duclos, 2006
- Edwards, 2007
- Emery, 2000
- Emery, 2006
- Emery, 2008
- Emery, 2008
- Emery, 2009
- Emery, 2010
- Emery, 2010
- Feltelius, 2005
- Fernandez-Nebro, 2007
- Fleischmann, 2003
- Fleischmann, 2006 – found under Fleischmann 2003
- Fleischmann, 2009
- Flendrie, 2003
- Flendrie, 2005
- Fuerst, 2006
- Furst, 2003
- Galloway, 2011
- Geborek, 2002
- Geborek, 2005
- Genovese, 2002 – found under Bathon 2000
- Genovese, 2004
- Genovese, 2005 – found under Bathon 2000
- Genovese, 2008
- Goekoop-Ruiterman, 2005
- Goekoop-Ruiterman, 2007 – found under Goekoop-Ruiterman 2005
- Gomez-Reino, 2003
- Greenberg, 2010
- Grijalva, 2007
- Grijalva, 2010
- Haagsma, 1997
- Harley, 2003
- Harrison, 2009
- Hetland, 2010
- Hjardem, 2007
- Hyrich, 2006 [Change ET to say 2006] in 2003 file
- Hyrich, 2007
- Jacobsson, 2005
- Karanikola, 2008
- Karstila, 2010
- Kawakami, 2010
- Kay, 2008
- Keane, 2001
- Keystone, 2008
- Keystone, 2009
- Kim, 2007
- Kirwan, 2004
- Klareskog, 2004
- Korpela, 2004 – found under Mottonen 1999
- Kremer, 2002
- Kremer, 2006
- Kremer, 2010
- kristensen, 2006
- kristensen, 2006
- Kwon, 2003
- Lacaille, 2008
- Langer, 2003
- Lebwohl, 2005
- Lee, 2002
- Lee, 2008
- Li, 2010
- Listing, 2005
- Listing, 2008
- Maini, 2004 – found under Breedveld 2004
- Malyshev, 2008
- Marchesoni, 2009
- McDonald, 2009
- Michaud, 2006
- Migliore, 2009
- Miyasaka, 2008
- Mohan, 2001
- Mohan, 2004
- Nadareishvili, 2008
- Naranjo, 2008
- Nishimoto, 2009
- Nuki, 2002
- O’Dell, 1996
- O’Dell, 2002
- O’Dell, 2006
- Osiri, 2002
- Pallavicini, 2010
- Pan, 2009
- Russell, 2007
- Saag, 1994
- Salliot, 2006
- Schaible, 2000
- Schiff, 2006
- Schiff, 2008
- Schipper, 2009
- Schneeweiss, 2007
- Setoguchi, 2006
- Setoguchi, 2008
- Shin, 2006
- Slifman, 2003
- Smitten, 2007
- Smitten, 2008
- Smolen, 1999
- Smolen, 1999
- Smolen, 2008
- Smolen, 2009
- Sokolove, 2010
- Solomon, 2006
- St. Clair, 2004
- Strand, 1999
- Strand, 2006
- Strangfeld, 2009
- Strangfeld, 2010
- Suissa, 2004
- Suissa, 2006
- Suissa, 2006
- Svensson, 2003
- Svensson, 2005
- van der Heijde, 2006 –f ound under Klareskog 2004
- van der Heijde, 2006 – found under Klareskog 2004
- van der Kooij, 2009 – found under Goekoop-Ruiterman 2005
- van Halm, 2006
- van Riel, 2006
- van Vollenhoven, 2009
- Wallis, 2004
- Wasserman, 2004
- Weinblatt, 1999
- Weinblatt, 2006
- Weinblatt, 2006
- Weinblatt, 2007
- Westhovens, 2006
- Westhovens, 2009
- Wolfe, 2004
- Wolfe, 2004
- Wolfe, 2004
- Wolfe, 2006
- Wolfe, 2007
- Wolfe, 2007
- Wolfe, 2007
- Zhang, 2006
- Zink, 2005

#### Systematic Reviews and Meta-analyses found in Evidence Table 2

- Alonso-Ruiz, 2008
- Bernatsky, 2010
- Bongartz, 2006
- Bongartz, 2009
- Gartlehner, 2006
- Leombruno, 2009
- Maetzel, 2000
- Martinez Lopez, 2009
- Mertens, 2009
- Osiri, 2002, 2009
- Salliot, 2009
- Schipper, 2009
- Singh, 2009
- Singh, 2009
- Singh, 2010
- Singh, 2010
- Wiens, 2009
- Wiens, 2010

### KQ4

#### RCTs and other studies found in Evidence Table 1

- Keystone, 2009
- Schiff, 2004
- Schiff, 2006 – found under Fleischmann 2003
- Solomon, 2006
- Tesser, 2004 – found under Fleischmann 2003

#### Systematic Reviews and Meta-analyses found in Evidence Table 2

- Rheumatoid Arthritis Clinical Trial Archive Group, 1995

## Abbreviations used in the evidence tables

ACR: American College of Rheumatology
ADA: adalimumab
AEs: adverse events
AIDS: acquired immunodeficiency syndrome
AIMS: Arthritis Impact Measurement Scales
ANA: anakinra
ARA: American Rheumatism Association criteria (pre-1987)
AS: ankylosing spondylitis
ASHI: Arthritis-Specific Health Index (Medical Outcomes Study Short Form SF-36 Arthritis-specific Health Index)
AUC: area under the curve
BUD: budesonide
Ccs: corticosteroids
CFS: chronic fatigue syndrome
CHF: coronary heart failure
Cm: centimeters
Combo: combination therapy
CI: confidence interval
CHD: coronary heart disease
COPD: Chronic Obstructive Pulmonary Disease
CRP: C-reactive protein
CVD: cardiovascular disease
CXT: cyclophosamide
CYP: cyclosporine
Ds: days
DM: diabetes mellitus
DAS: Disease Activity Score
DMARD: disease modifying antirheumatic drug
D-HAQ: Dutch version of the Health Assessment Questionnaire (HAQ)
EQ-5D–: Quality of Life Questionnaire
ESR: erythrocyte sedimentation rate
ETA: etanercept
EULAR: European League against Rheumatism
EuroQol EQ-5D: European Quality of Life Questionnaire
EuroQOL VAS: European Quality of Life Visual Analogue Scale
GI: gastrointestinal
HAQ: Health Assessment Questionnaire
HAQ-DI: Disability Index of the Heath Assessment Questionnaire (HAQ)
HIV: Human immunodeficiency virus
HLA-DR4: Human immune-response, D-related antigen encoded by the D locus on chromosome 6
HR: hazard ratio
HRQOL: health related quality of life
ICD: International Classification of Diseases
INF: infliximab
ISRs: injection site reactions
ITT: intention to treat
JRA: juvenile rheumatoid arthritis
HCQ: hydroxychloroquine
JSN: joint space narrowing
LEF: leflunomide
MTX: methotrexate
Mg: milligrams
mSharp Scale: Modified Sharp Method for Scoring Radiographs
mos: months
MHAQ: Modified Health Assessment Questionnaire
NSAIDs: non-steroidal anti-inflammatory drugs
NSFHS: National Survey of Functional Health Status
NA: not applicable
NMSC: non-melanoma skin cancer
NR: not reported
NS: not significant
NYHA: New York Heart Association
OA: osteoarthritis
OR: odds ratio
OMERACT: Outcome Measures in Rheumatology Clinical Trials
PASI: Psoriasis Area and Severity Index
PNL: prednisolone
PRED: prednisone
PsA: psoriatic arthritis
PsARC: Psoriatic Arthritis Response Scale
Pt: patient
PY: person-year
QOL: quality of life
RCT: randomized controlled trial
RAI: Ritchie Articular Index
RA: rheumatoid arthritis
RDS: radiological damage score
RF: rheumatoid factor
RIT: rituximab
RR: risk ratio
SAEs: serious adverse events
SAARDs: slow-acting anti-rheumatic drugs
SCC: squamous cell carcinoma
SD: standard deviation
SF-36: Medical Outcomes Study Short Form 36 Health Survey
SJC: swollen joint count
SHS: Sharp/van der Heijde Method (SHS) for Scoring Radiographs
SIR: standardized incidence ratio
SLE: Systemic Lupus Erythematosus
SMR: standardized morbidity ratio
SSZ: sulfasalazine
SSTG: South Swedish Arthritis Treatment Group
TB: Tuberculosis
TIM: targeted immune modulator
TJC: tender joint count
TNF: tumor necrosis factor
Txt: treatment
URTI: upper respiratory tract infection
UTI: urinary tract infection
vs.: versus
yrs: years
w/: with
w/in: with in
w/o: with out

## Evidence Tables

Evidence Table 1 Randomized controlled trials and observational studies

Evidence Table 2 Systematic reviews and meta-analyses

## References

1 Askling J, Fored CM, Brandt L, et al. Risk and case characteristics of tuberculosis in rheumatoid arthritis associated with tumor necrosis factor antagonists in Sweden. Arthritis Rheum. Jul. 2005;52(7):1986-92. [pmid: 15986370].
2 Askling J, Fored CM, Brandt L, et al. Risks of solid cancers in patients with rheumatoid arthritis and after treatment with tumour necrosis factor antagonists. Ann Rheum Dis. Oct. 2005;64(10):1421-6. [pmid: 15829572].
3 Askling J, Fored CM, Baecklund E, et al. Haematopoietic malignancies in rheumatoid arthritis: lymphoma risk and characteristics after exposure to tumour necrosis factor antagonists. Ann Rheum Dis. Oct. 2005;64(10):1414-20. [pmid: 15843454].
4 Askling J, van Vollenhoven RF, Granath F, et al. Cancer risk in patients with rheumatoid arthritis treated with anti-tumor necrosis factor alpha therapies: does the risk change with the time since start of treatment?. Arthritis Rheum. 2009;60(11):3180-9. [pmid: 19877027].
5 Baecklund E, Iliadou A, Askling J, et al. Association of chronic inflammation, not its treatment, with increased lymphoma risk in rheumatoid arthritis. Arthritis Rheum. Mar. 2006;54(3):692-701. [pmid: 16508929].
6 Bathon JM, Martin RW, Fleischmann RM, et al. A comparison of etanercept and methotrexate in patients with early rheumatoid arthritis. N Engl J Med. Nov. 30. 2000;343(22):1586-93. [pmid: 11096165].
7 Genovese MC, Bathon JM, Martin RW, et al. Etanercept versus methotrexate in patients with early rheumatoid arthritis: two-year radiographic and clinical outcomes. Arthritis Rheum. Jun. 2002;46(6):1443-50. [pmid: 12115173].
8 Kosinski M, Kujawski SC, Martin R, et al. Health-related quality of life in early rheumatoid arthritis: impact of disease and treatment response. Am J Manag Care. Mar. 2002;8(3):231-40. [pmid: 11915973].
9 Genovese MC, Bathon JM, Fleischmann RM, et al. Longterm safety, efficacy, and radiographic outcome with etanercept treatment in patients with early rheumatoid arthritis. J Rheumatol. Jul. 2005;32(7):1232-42. [pmid: 15996057].
10 Bergstrom L, Yocum DE, Ampel NM, et al. Increased risk of coccidioidomycosis in patients treated with tumor necrosis factor alpha antagonists. Arthritis Rheum. Jun. 2004;50(6):1959-66. [pmid: 15188373].
11 Bernatsky S, Hudson M, Suissa S. Anti-rheumatic drug use and risk of serious infections in rheumatoid arthritis. Rheumatology (Oxford). 2007;46(7):1157-60. [pmid: 17478469].
12 Boers M, Verhoeven AC, Markusse HM, et al. Randomised comparison of combined step-down prednisolone, methotrexate and sulphasalazine with sulphasalazine alone in early rheumatoid arthritis. Lancet. Aug. 2. 1997;350(9074):309-18. [pmid: 9251634].
13 Landewe RB, Boers M, Verhoeven AC, et al. COBRA combination therapy in patients with early rheumatoid arthritis: long-term structural benefits of a brief intervention. Arthritis Rheum. Feb. 2002;46(2):347-56. [pmid: 11840436].
14 Brassard P, Lowe AM, Bernatsky S, et al. Rheumatoid arthritis, its treatments, and the risk of tuberculosis in Quebec, Canada. Arthritis Rheum. 2009;61(3):300-4. [pmid: 19248128].
15 Brassard P, Kezouh A, Suissa S. Antirheumatic drugs and the risk of tuberculosis. Clin Infect Dis. 2006;43(6):717-22. [pmid: 16912945].
16 Breedveld FC, Weisman MH, Kavanaugh AF, et al. The PREMIER study: A multicenter, randomized, double-blind clinical trial of combination therapy with adalimumab plus methotrexate versus methotrexate alone or adalimumab alone in patients with early, aggressive rheumatoid arthritis who had not had previous methotrexate treatment. Arthritis Rheum. Jan. 2006;54(1):26-37. [pmid: 16385520].
17 Breedveld FC, Emery P, Keystone E, et al. Infliximab in active early rheumatoid arthritis. Ann Rheum Dis. 2004;63(2):149-55. [pmid: 14722203].
18 Maini RN, Breedveld FC, Kalden JR, et al. Sustained improvement over two years in physical function, structural damage, and signs and symptoms among patients with rheumatoid arthritis treated with infliximab and methotrexate. Arthritis Rheum. Apr. 2004;50(4):1051-65. [pmid: 15077287].
19 Smolen JS, Han C, Bala M, et al. Evidence of radiographic benefit of treatment with infliximab plus methotrexate in rheumatoid arthritis patients who had no clinical improvement: a detailed subanalysis of data from the anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study. Arthritis Rheum. 2005;52(4):1020-30. [pmid: 15818697].
20 Brown SL, Greene MH, Gershon SK, et al. Tumor necrosis factor antagonist therapy and lymphoma development: twenty-six cases reported to the Food and Drug Administration. Arthritis Rheum. Dec. 2002;46(12):3151-8. [pmid: 12483718].
21 Burmester GR, Mariette X, Montecucco C, et al. Adalimumab alone and in combination with disease-modifying antirheumatic drugs for the treatment of rheumatoid arthritis in clinical practice: the Research in Active Rheumatoid Arthritis (ReAct) trial. Ann Rheum Dis. 2007;66(6):732-9. [pmid: 17329305].
22 Cannon GW, Holden WL, Juhaeri J, et al. Adverse events with disease modifying antirheumatic drugs (DMARD): a cohort study of leflunomide compared with other DMARD. J Rheumatol. Oct. 2004;31(10):1906-11. [pmid: 15468352].
23 Capell H, Madhok R, Porter D, et al. Combination therapy with sulphasalazine and methotrexate is more effective than either drug alone in rheumatoid arthritis (ra) patients with a suboptimal response to sulphasalazine: Results from the double blind placebo controlled mascot study. Ann Rheum Dis. Feb. 2007;66(2):235-41. [pmid: 16926184].
24 Chakravarty EF, Michaud K, Wolfe F. Skin cancer, rheumatoid arthritis, and tumor necrosis factor inhibitors. J Rheumatol. Nov. 2005;32(11):2130-5. [pmid: 16265690].
25 Choy EH, Smith CM, Farewell V, et al. Factorial randomised controlled trial of glucocorticoids and combination disease modifying drugs in early rheumatoid arthritis. Ann Rheum Dis. 2008;67(5):656-63. [pmid: 17768173].
26 Chung ES, Packer M, Lo KH, et al. Randomized, double-blind, placebo-controlled, pilot trial of infliximab, a chimeric monoclonal antibody to tumor necrosis factor-alpha, in patients with moderate-to-severe heart failure: results of the anti-TNF Therapy Against Congestive Heart Failure (ATTACH) trial. Circulation. Jul. 1. 2003;107(25):3133-40. [pmid: 12796126].
27 Cohen SB, Emery P, Greenwald MW, et al. Rituximab for rheumatoid arthritis refractory to anti-tumor necrosis factor therapy: results of a multicenter, randomized, double-blind, placebo-controlled, phase III trial evaluating primary efficacy and safety at twenty-four weeks. Arthritis Rheum. 2006;54(9):2793-806. [pmid: 16947627].
28 Keystone E, Burmester GR, Furie R, et al. Improvement in patient-reported outcomes in a rituximab trial in patients with severe rheumatoid arthritis refractory to anti-tumor necrosis factor therapy. Arthritis Rheum. 2008;59(6):785-93. [pmid: 18512710].
29 Keystone E, Emery P, Peterfy CG, et al. Rituximab inhibits structural joint damage in patients with rheumatoid arthritis with an inadequate response to tumour necrosis factor inhibitor therapies. Ann Rheum Dis. 2009;68(2):216-21. [pmid: 18388156].
30 Combe BG, Codreanu C, Fiocco U, et al. Double-blind comparison of Etanercept and Sulphasalazine, alone and combined, in patients with active rheumatoid arthritis despite receiving Sulphasalazine. Ann Rheum Dis. 2006. Apr. 10.
31 Combe B, Codreanu C, Fiocco U, et al. Efficacy, safety and patient-reported outcomes of combination etanercept and sulfasalazine versus etanercept alone in patients with rheumatoid arthritis: a double-blind randomised 2-year study. Ann Rheum Dis. 2009;68(7):1146-52. [pmid: 18794178].
32 Curtis JR, Patkar N, Xie A, et al. Risk of serious bacterial infections among rheumatoid arthritis patients exposed to tumor necrosis factor alpha antagonists. Arthritis Rheum. 2007;56(4):1125-33. [pmid: 17393394].
33 Curtis JR, Xi J, Patkar N, et al. Drug-specific and time-dependent risks of bacterial infection among patients with rheumatoid arthritis who were exposed to tumor necrosis factor alpha antagonists. Arthritis Rheum. 2007;56(12):4226-7. [pmid: 18050253].
34 Curtis JR, Kramer JM, Martin C, et al. Heart failure among younger rheumatoid arthritis and Crohn’s patients exposed to TNF-alpha antagonists. Rheumatology (Oxford). 2007;46(11):1688-93. [pmid: 17938138].
35 De Bandt M, Sibilia J, Le Loet X, et al. Systemic lupus erythematosus induced by anti-tumour necrosis factor alpha therapy: a French national survey. Arthritis Res Ther. 2005;7(3):R545-51. [pmid: 15899041].
36 den Broeder AA, Creemers MC, Fransen J, et al. Risk factors for surgical site infections and other complications in elective surgery in patients with rheumatoid arthritis with special attention for anti-tumor necrosis factor: a large retrospective study. J Rheumatol. 2007;34(4):689-95. [pmid: 17117492].
37 Dixon WG, Watson K, Lunt M, et al. Rates of serious infection, including site-specific and bacterial intracellular infection, in rheumatoid arthritis patients receiving anti-tumor necrosis factor therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum. Jul. 25. 2006;54(8):2368-76. [pmid: 16868999].
38 Dixon WG, Watson KD, Lunt M, et al. Reduction in the incidence of myocardial infarction in patients with rheumatoid arthritis who respond to anti-tumor necrosis factor alpha therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis and Rheumatism. 2007;56(9):2905-12. [pmid: 17763428].
39 Dixon WG, Hyrich KL, Watson KD, et al. Drug-specific risk of tuberculosis in patients with rheumatoid arthritis treated with anti-TNF therapy: results from the British Society for Rheumatology Biologics Register (BSRBR). Ann Rheum Dis. 2010;69(3):522-8. [pmid: 19854715].
40 Doran MF, Crowson CS, Pond GR, et al. Predictors of infection in rheumatoid arthritis. Arthritis Rheum. Sep. 2002;46(9):2294-300. [pmid: 12355476].
41 Dougados M, Combe B, Cantagrel A, et al. Combination therapy in early rheumatoid arthritis: a randomised, controlled, double blind 52 week clinical trial of sulphasalazine and methotrexate compared with the single components. Ann Rheum Dis. 1999;58(4):220-5. [pmid: 10364900].
42 Maillefert JF, Combe B, Goupille P, et al. Long term structural effects of combination therapy in patients with early rheumatoid arthritis: five year follow up of a prospective double blind controlled study. Ann Rheum Dis. 2003;62(8):764-6. [pmid: 12860733].
43 Duclos M, Gossec L, Ruyssen-Witrand A, et al. Retention rates of tumor necrosis factor blockers in daily practice in 770 rheumatic patients. J Rheumatol. 2006;33(12):2433-8. [pmid: 17014004].
44 Edwards CJ, Cooper C, Fisher D, et al. The importance of the disease process and disease-modifying antirheumatic drug treatment in the development of septic arthritis in patients with rheumatoid arthritis. Arthritis Rheum. 2007;57(7):1151-7. [pmid: 17907232].
45 Emery P, Breedveld FC, Lemmel EM, et al. A comparison of the efficacy and safety of leflunomide and methotrexate for the treatment of rheumatoid arthritis. Rheumatology (Oxford). 2000;39(6):655-65. [pmid: 10888712].
46 Emery P, Fleischmann R, Filipowicz-Sosnowska A, et al. The efficacy and safety of rituximab in patients with active rheumatoid arthritis despite methotrexate treatment - results of a phase IIb randomized, double-blind, placebo-controlled, dose-ranging trial. Arthritis Rheum. May. 1. 2006;54(May):1390-400. [pmid: 16649186].
47 Emery P, Kosinski M, Li T, et al. Treatment of rheumatoid arthritis patients with abatacept and methotrexate significantly improved health-related quality of life. J Rheumatol. 04. 01. 2006;33(Apr):681-9. [pmid: 16568505].
48 Emery P, Breedveld FC, Hall S, et al. Comparison of methotrexate monotherapy with a combination of methotrexate and etanercept in active, early, moderate to severe rheumatoid arthritis (COMET): a randomised, double-blind, parallel treatment trial. Lancet. 2008;372(9636):375-82. [pmid: 18635256].
49 Emery P, Keystone E, Tony HP, et al. IL-6 receptor inhibition with tocilizumab improves treatment outcomes in patients with rheumatoid arthritis refractory to anti-tumour necrosis factor biologicals: results from a 24-week multicentre randomised placebo-controlled trial. Ann Rheum Dis. 2008;67(11):1516-23. [pmid: 18625622].
50 Emery P, Fleischmann RM, Moreland LW, et al. Golimumab, a human anti-tumor necrosis factor alpha monoclonal antibody, injected subcutaneously every four weeks in methotrexate-naive patients with active rheumatoid arthritis: twenty-four-week results of a phase III, multicenter, randomized, double-blind, placebo-controlled study of golimumab before methotrexate as first-line therapy for early-onset rheumatoid arthritis. Arthritis Rheum. 2009;60(8):2272-83. [pmid: 19644849].
51 Emery P, Breedveld F, van der Heijde D, et al. Two-year clinical and radiographic results with combination etanercept-methotrexate therapy versus monotherapy in early rheumatoid arthritis: a two-year, double-blind, randomized study. Arthritis Rheum. 2010;62(3):674-82. [pmid: 20187135].
52 Emery P, Deodhar A, Rigby WF, et al. Efficacy and safety of different doses and retreatment of rituximab: a randomised, placebo-controlled trial in patients who are biological naive with active rheumatoid arthritis and an inadequate response to methotrexate (Study Evaluating Rituximab’s Efficacy in MTX iNadequate rEsponders (SERENE)). Ann Rheum Dis. 2010;69(9):1629-35. [pmid: 20488885].
53 Feltelius N, Fored CM, Blomqvist P, et al. Results from a nationwide postmarketing cohort study of patients in Sweden treated with etanercept. Ann Rheum Dis. Feb. 2005;64(2):246-52. [pmid: 15208177].
54 Fernandez-Nebro A, Irigoyen MV, Urena I, et al. Effectiveness, predictive response factors, and safety of anti-tumor necrosis factor (TNF) therapies in anti-TNF-naive rheumatoid arthritis. J Rheumatol. 2007;34(12):2334-42. [pmid: 17985409].
55 Finckh A, Ciurea A, Brulhart L, et al. B cell depletion may be more effective than switching to an alternative anti-tumor necrosis factor agent in rheumatoid arthritis patients with inadequate response to anti-tumor necrosis factor agents. Arthritis Rheum. 2007;56(5):1417-23. [pmid: 17469098].
56 Finckh A, Dehler S, Gabay C. The effectiveness of leflunomide as a co-therapy of tumour necrosis factor inhibitors in rheumatoid arthritis: a population-based study. Ann Rheum Dis. 2009;68(1):33-9. [pmid: 18230627].
57 Fleischmann RM, Schechtman J, Bennett R, et al. Anakinra, a recombinant human interleukin-1 receptor antagonist (r-metHuIL-1ra), in patients with rheumatoid arthritis: A large, international, multicenter, placebo-controlled trial. Arthritis Rheum. Apr. 2003;48(4):927-34. [pmid: 12687534].
58 Tesser J, Fleischmann R, Dore R, et al. Concomitant medication use in a large, international, multicenter, placebo controlled trial of anakinra, a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis. J Rheumatol. 2004;31(4):649-54. [pmid: 15088288].
59 Schiff MH, DiVittorio G, Tesser J, et al. The safety of anakinra in high-risk patients with active rheumatoid arthritis: six-month observations of patients with comorbid conditions. Arthritis Rheum. Jun. 2004;50(6):1752-60. [pmid: 15188350].
60 Fleischmann RM, Tesser J, Schiff MH, et al. Safety of extended treatment with anakinra in patients with rheumatoid arthritis. Ann Rheum Dis. Aug. 2006;65(8):1006-12. [pmid: 16396977].
61 Fleischmann R, Vencovsky J, van Vollenhoven RF, et al. Efficacy and safety of certolizumab pegol monotherapy every 4 weeks in patients with rheumatoid arthritis failing previous disease-modifying antirheumatic therapy: the FAST4WARD study. Ann Rheum Dis. Jun. 2009;68(6):805-11. [pmid: 19015206].
62 Flendrie M, Creemers MC, Welsing PM, et al. Survival during treatment with tumour necrosis factor blocking agents in rheumatoid arthritis. Ann Rheum Dis. Nov. Suppl 2. 2003;62:ii30-3. [pmid: 14532145].
63 Flendrie M, Vissers WH, Creemers MC, et al. Dermatological conditions during TNF-alpha-blocking therapy in patients with rheumatoid arthritis: a prospective study. Arthritis Res Ther. 2005;7(3):R666-76. [pmid: 15899052].
64 Fuerst M, Mohl H, Baumgartel K, et al. Leflunomide increases the risk of early healing complications in patients with rheumatoid arthritis undergoing elective orthopedic surgery. Rheumatol Int. 2006;26(12):1138-42. [pmid: 16736164].
65 Furst DE, Schiff MH, Fleischmann RM, et al. Adalimumab, a fully human anti tumor necrosis factor-alpha monoclonal antibody, and concomitant standard antirheumatic therapy for the treatment of rheumatoid arthritis: results of STAR (Safety Trial of Adalimumab in Rheumatoid Arthritis). J Rheumatol. Dec. 2003;30(12):2563-71. [pmid: 14719195].
66 Galloway JB, Hyrich KL, Mercer LK, et al. Anti-TNF therapy is associated with an increased risk of serious infections in patients with rheumatoid arthritis especially in the first 6 months of treatment: updated results from the British Society for Rheumatology Biologics Register with special emphasis on risks in the elderly. Rheumatology (Oxford, England). 2011;50(1):124-31.
67 Geborek P, Crnkic M, Petersson IF, et al. Etanercept, infliximab, and leflunomide in established rheumatoid arthritis: clinical experience using a structured follow up programme in southern Sweden. Ann Rheum Dis. Sep. 2002;61(9):793-8. [pmid: 12176803].
68 Geborek P, Bladstrom A, Turesson C, et al. Tumour necrosis factor blockers do not increase overall tumour risk in patients with rheumatoid arthritis, but may be associated with an increased risk of lymphomas. Ann Rheum Dis. May. 2005;64(5):699-703. [pmid: 15695534].
69 Genovese MC, Cohen S, Moreland L, et al. Combination therapy with etanercept and anakinra in the treatment of patients with rheumatoid arthritis who have been treated unsuccessfully with methotrexate. Arthritis Rheum. May. 2004;50(5):1412-9. [pmid: 15146410].
70 Genovese MC, McKay JD, Nasonov EL, et al. Interleukin-6 receptor inhibition with tocilizumab reduces disease activity in rheumatoid arthritis with inadequate response to disease-modifying antirheumatic drugs: the tocilizumab in combination with traditional disease-modifying antirheumatic drug therapy study. Arthritis and Rheumatism. 2008;58(10):2968-80. [pmid: 18821691].
71 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, et al. Clinical and radiographic outcomes of four different treatment strategies in patients with early rheumatoid arthritis (the BeSt study): a randomized, controlled trial. Arthritis Rheum. Nov. 2005;52(11):3381-90. [pmid: 16258899].
72 Allaart CF, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. Aiming at low disease activity in rheumatoid arthritis with initial combination therapy or initial monotherapy strategies: the BeSt study. Clin Exp Rheumatol. Nov–Dec. 2006;24(6 Suppl 43):S-77-82.
73 Goekoop-Ruiterman YPM, De Vries-Bouwstra JK, Allaart CF, et al. Comparison of treatment strategies in early rheumatoid arthritis: a randomized trial. Ann Intern Med. 2007;146(6):406-15. [pmid: 17371885].
74 van der Kooij SM, de Vries-Bouwstra JK, Goekoop-Ruiterman YP, et al. Patient-reported outcomes in a randomized trial comparing four different treatment strategies in recent-onset rheumatoid arthritis. Arthritis Rheum. Jan. 15. 2009;61(1):4-12. [pmid: 19116965].
75 van der Kooij SM, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. Drug-free remission, functioning and radiographic damage after 4 years of response-driven treatment in patients with recent-onset rheumatoid arthritis. Ann Rheum Dis. 2009;68(6):914-21. [pmid: 18662933].
76 Gomez-Reino JJ, Carmona L, Valverde VR, et al. Treatment of rheumatoid arthritis with tumor necrosis factor inhibitors may predispose to significant increase in tuberculosis risk: a multicenter active-surveillance report. Arthritis Rheum. Aug. 2003;48(8):2122-7. [pmid: 12905464].
77 Greenberg JD, Reed G, Kremer JM, et al. Association of methotrexate and tumour necrosis factor antagonists with risk of infectious outcomes including opportunistic infections in the CORRONA registry. Ann Rheum Dis. 2010;69(2):380-6. [pmid: 19359261].
78 Grijalva CG, Chung CP, Arbogast PG, et al. Assessment of adherence to and persistence on disease-modifying antirheumatic drugs (DMARDs) in patients with rheumatoid arthritis. Med Care. 2007;45(10 Supl 2):S66-76. [pmid: 17909386].
79 Grijalva CG, Kaltenbach L, Arbogast PG, et al. Initiation of rheumatoid arthritis treatments and the risk of serious infections. Rheumatology (Oxford). 2010:4982-90.
80 Haagsma CJ, van Riel PL, de Jong AJ, et al. Combination of sulphasalazine and methotrexate versus the single components in early rheumatoid arthritis: a randomized, controlled, double-blind, 52 week clinical trial. Br J Rheumatol. 1997;36(10):1082-8. [pmid: 9374925].
81 Harley CR, Frytak JR, Tandon N. Treatment compliance and dosage administration among rheumatoid arthritis patients receiving infliximab, etanercept, or methotrexate. Am J Manag Care. Oct. 2003;9(6 Suppl):S136-43. [pmid: 14577718].
82 Harrison MJ, Dixon WG, Watson KD, et al. Rates of new-onset psoriasis in patients with rheumatoid arthritis receiving anti-tumour necrosis factor alpha therapy: results from the British Society for Rheumatology Biologics Register. Ann Rheum Dis. 2009;68(2):209-15. [pmid: 18385277].
83 Hetland ML, Christensen IJ, Tarp U, et al. Direct comparison of treatment responses, remission rates, and drug adherence in patients with rheumatoid arthritis treated with adalimumab, etanercept, or infliximab results from eight years of surveillance of clinical practice in the Nationwide Danish DANBIO Registry. Arthritis Rheum. 2010;62(1):22-32. [pmid: 20039405].
84 Hjardem E, Ostergaard M, Podenphant J, et al. Do rheumatoid arthritis patients in clinical practice benefit from switching from infliximab to a second tumor necrosis factor alpha inhibitor?. Ann Rheum Dis. 2007;66(9):1184-9. [pmid: 17389656].
85 Hoff M, Kvien TK, Kalvesten J, et al. Adalimumab therapy reduces hand bone loss in early rheumatoid arthritis: explorative analyses from the PREMIER study. Ann Rheum Dis. 2009;68(7):1171-6. [pmid: 18801760].
86 Hyrich KL, Symmons DP, Watson KD, et al. Comparison of the response to infliximab or etanercept monotherapy with the response to cotherapy with methotrexate or another disease-modifying antirheumatic drug in patients with rheumatoid arthritis: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum. May. 30. 2006;54(6):1786-94. [pmid: 16736520].
87 Hyrich KL, Watson KD, Silman AJ, et al. Predictors of response to anti-TNF-alpha therapy among patients with rheumatoid arthritis: results from the British Society for Rheumatology Biologics Register. Rheumatology. 2006;45(Dec):1558-65. [pmid: 16705046].
88 Hyrich KL, Lunt M, Watson KD, et al. Outcomes after switching from one anti-tumor necrosis factor alpha agent to a second anti-tumor necrosis factor alpha agent in patients with rheumatoid arthritis: results from a large UK national cohort study. Arthritis Rheum. 2007;56(1):13-20. [pmid: 17195186].
89 Jacobsson LT, Turesson C, Gulfe A, et al. Treatment with tumor necrosis factor blockers is associated with a lower incidence of first cardiovascular events in patients with rheumatoid arthritis. J Rheumatol. Jul. 2005;32(7):1213-8. [pmid: 15996054].
90 Karanikolas G, Charalambopoulos D, Vaiopoulos G, et al. Adjunctive anakinra in patients with active rheumatoid arthritis despite methotrexate, or leflunomide, or cyclosporin-A monotherapy: a 48-week, comparative, prospective study. Rheumatology (Oxford). 2008;47(9):1384-8. [pmid: 18603660].
91 Kavanaugh A, Klareskog L, van der Heijde D, et al. Improvements in clinical response between 12 and 24 weeks in patients with rheumatoid arthritis on etanercept therapy with or without methotrexate. Ann Rheum Dis. 2008;67(10):1444-7. [pmid: 18535115].
92 Klareskog L, van der Heijde D, de Jager JP, et al. Therapeutic effect of the combination of etanercept and methotrexate compared with each treatment alone in patients with rheumatoid arthritis: double-blind randomised controlled trial. Lancet. Feb. 28. 2004;363(9410):675-81. [pmid: 15001324].
93 Kay J, Matteson EL, Dasgupta B, et al. Golimumab in patients with active rheumatoid arthritis despite treatment with methotrexate: a randomized, double-blind, placebo-controlled, dose-ranging study. Arthritis Rheum. 2008;58(4):964-75. [pmid: 18383539].
94 Keane J, Gershon S, Wise RP, et al. Tuberculosis associated with infliximab, a tumor necrosis factor alpha-neutralizing agent. N Engl J Med. Oct. 11. 2001;345(15):1098-104. [pmid: 11596589].
95 Keystone E, Heijde D, Mason D Jr, et al. Certolizumab pegol plus methotrexate is significantly more effective than placebo plus methotrexate in active rheumatoid arthritis: findings of a fifty-two-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum. 2008;58(11):3319-29. [pmid: 18975346].
96 Keystone E, Freundlich B, Schiff M, et al. Patients with moderate rheumatoid arthritis (RA) achieve better disease activity states with etanercept treatment than patients with severe RA. J Rheumatol. 2009;36(3):522-31. [pmid: 19228659].
97 Keystone EC, Genovese MC, Klareskog L, et al. Golimumab, a human antibody to tumour necrosis factor {alpha} given by monthly subcutaneous injections, in active rheumatoid arthritis despite methotrexate therapy: the GO-FORWARD Study. Ann Rheum Dis. 2009;68(6):789-96. [pmid: 19066176].
98 Keystone E, Genovese MC, Klareskog L, et al. Golimumab in patients with active rheumatoid arthritis despite methotrexate therapy: 52-week results of the GO-FORWARD study. Annals of the rheumatic diseases. 2010;(6):1129-35. [pmid: 20444749].
99 Kievit W, Adang EM, Fransen J, et al. The effectiveness and medication costs of three anti-tumour necrosis factor alpha agents in the treatment of rheumatoid arthritis from prospective clinical practice data. Ann Rheum Dis. 2008;67(9):1229-34. [pmid: 18174220].
100 Kim HY, Lee SK, Song YW, et al. A randomized, double-blind, placebo-controlled, phase III study of the human anti-tumor necrosis factor antibody adalimumab administered as subcutaneous injections in Korean rheumatoid arthritis patients treated with methotrexate. APLAR J Rheumatol. 2007;10(1):9-16.
101 Kirwan JR, Hallgren R, Mielants H, et al. A randomised placebo controlled 12 week trial of budesonide and prednisolone in rheumatoid arthritis. Ann Rheum Dis. 2004;63(6):688-95. [pmid: 15140776].
102 van der Heijde D, Klareskog L, Boers M, et al. Comparison of different definitions to classify remission and sustained remission: 1 year TEMPO results. Ann Rheum Dis. Nov. 2005;64(11):1582-7. [pmid: 15860509].
103 van der Heijde D, Klareskog L, Singh A, et al. Patient reported outcomes in a trial of combination therapy with etanercept and methotrexate for rheumatoid arthritis: the TEMPO trial. Ann Rheum Dis. Mar. 2006;65(3):328-34. [pmid: 16079172].
104 van der Heijde D, Klareskog L, Rodriguez-Valverde V, et al. Comparison of etanercept and methotrexate, alone and combined, in the treatment of rheumatoid arthritis: two-year clinical and radiographic results from the TEMPO study, a double-blind, randomized trial. Arthritis Rheum. Apr. 2006;54(4):1063-74. [pmid: 16572441].
105 Kremer JM, Genovese MC, Cannon GW, et al. Concomitant leflunomide therapy in patients with active rheumatoid arthritis despite stable doses of methotrexate. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2002;137(9):726-33. [pmid: 12416946].
106 Kremer JL, Blanco R, Brzosko M, et al. Tocilizumab inhibits structural joint damage in rheumatoid arthritis patients with inadequate responses to methotrexate at 1 year: The LITHE study. Arthritis Rheum. 2010.
107 Kristensen LE, Saxne T, Geborek P. The LUNDEX, a new index of drug efficacy in clinical practice: results of a five-year observational study of treatment with infliximab and etanercept among rheumatoid arthritis patients in southern Sweden. Arthritis Rheum. Feb. 2006;54(2):600-6. [pmid: 16447237].
108 Kristensen LE, Saxne T, Nilsson JA, et al. Impact of concomitant DMARD therapy on adherence to treatment with etanercept and infliximab in rheumatoid arthritis. Results from a six-year observational study in southern Sweden. Arthritis Res Ther. 2006;8(6):R174. [pmid: 17121678].
109 Kristensen LE, Christensen R, Bliddal H, et al. The number needed to treat for adalimumab, etanercept, and infliximab based on ACR50 response in three randomized controlled trials on established rheumatoid arthritis: A systematic literature review. Scandinavian Journal of Rheumatology. 2007;36(6):411-7. [pmid: 18092260].
110 Lacaille D, Guh DP, Abrahamowicz M, et al. Use of nonbiologic disease-modifying antirheumatic drugs and risk of infection in patients with rheumatoid arthritis. Arthritis Rheum. 2008;59(8):1074-81. [pmid: 18668604].
111 Langer HE, Missler-Karger B. Kineret: efficacy and safety in daily clinical practice: an interim analysis of the Kineret response assessment initiative (kreative) protocol. Int J Clin Pharmacol Res. 2003;23(4):119-28. [pmid: 15224501].
112 Lebwohl M, Blum R, Berkowitz E, et al. No evidence for increased risk of cutaneous squamous cell carcinoma in patients with rheumatoid arthritis receiving etanercept for up to 5 years. Arch Dermatol. Jul. 2005;141(7):861-4. [pmid: 16027301].
113 Lee JH, Slifman NR, Gershon SK, et al. Life-threatening histoplasmosis complicating immunotherapy with tumor necrosis factor alpha antagonists infliximab and etanercept. Arthritis Rheum. Oct. 2002;46(10):2565-70. [pmid: 12384912].
114 Lee YH, Woo JH, Rho YH, et al. Meta-analysis of the combination of TNF inhibitors plus MTX compared to MTX monotherapy, and the adjusted indirect comparison of TNF inhibitors in patients suffering from active rheumatoid arthritis. Rheumatology international. 2008;28(6):553-9. [pmid: 17943257].
115 Li T, Gignac M, Wells G, et al. Decreased external home help use with improved clinical status in rheumatoid arthritis: an exploratory analysis of the Abatacept in Inadequate responders to Methotrexate (AIM) trial. Clin Ther. 2008;30(4):734-48. [pmid: 18498922].
116 Kremer JM, Genant HK, Moreland LW, et al. Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis - a randomized trial. Ann Intern Med. Dec. 2006;144:865-76. [pmid: 16785475].
117 Li P, Blum MA, Von Feldt J, et al. Adherence, discontinuation, and switching of biologic therapies in medicaid enrollees with rheumatoid arthritis. Value Health. 2010;13(6):805-12. [pmid: 21054657].
118 Listing J, Strangfeld A, Kary S, et al. Infections in patients with rheumatoid arthritis treated with biologic agents. Arthritis Rheum. Nov. 2005;52(11):3403-12. [pmid: 16255017].
119 Listing J, Strangfeld A, Rau R, et al. Clinical and functional remission: even though biologics are superior to conventional DMARDs overall success rates remain low--results from RABBIT, the German biologics register. Arthritis Res Ther. 2006;8(3):R66. [pmid: 16600016].
120 Listing J, Strangfeld A, Kekow J, et al. Does tumor necrosis factor alpha inhibition promote or prevent heart failure in patients with rheumatoid arthritis?. Arthritis Rheum. 2008;58(3):667-77. [pmid: 18311816].
121 Maini RN, Taylor PC, Szechinski J, et al. Double-blind randomized controlled clinical trial of the interleukin-6 receptor antagonist, tocilizumab, in European patients with rheumatoid arthritis who had an incomplete response to methotrexate. Arthritis Rheum. 2006;54(9):2817-29. [pmid: 16947782].
122 Malysheva OA, Wahle M, Wagner U, et al. Low-dose prednisolone in rheumatoid arthritis: adverse effects of various disease modifying antirheumatic drugs. J Rheumatol. 2008;35(6):979-85. [pmid: 18412314].
123 Marchesoni A, Zaccara E, Gorla R, et al. TNF-alpha antagonist survival rate in a cohort of rheumatoid arthritis patients observed under conditions of standard clinical practice. Ann N Y Acad Sci. 2009:1173837-46.
124 McDonald JR, Zeringue AL, Caplan L, et al. Herpes zoster risk factors in a national cohort of veterans with rheumatoid arthritis. Clin Infect Dis. 2009;48(10):1364-71. [pmid: 19368499].
125 Mease PJ, Revicki DA, Szechinski J, et al. Improved health-related quality of life for patients with active rheumatoid arthritis receiving rituximab: results of the Dose-Ranging Assessment: International Clinical Evaluation of Rituximab in Rheumatoid Arthritis (DANCER) Trial. J Rheumatol. 2008;35(1):20-30. [pmid: 18050385].
126 Michaud K, Wolfe F. The association of rheumatoid arthritis and its treatment with sinus disease. J Rheumatol. 2006;33(12):2412-5. [pmid: 17143978].
127 Migliore A, Bizzi E, Lagana B, et al. The safety of anti-TNF agents in the elderly. Int J Immunopathol Pharmacol. 2009;22(2):415-26. [pmid: 19505394].
128 Miyasaka N. Clinical investigation in highly disease-affected rheumatoid arthritis patients in Japan with adalimumab applying standard and general evaluation: the CHANGE study. Mod Rheumatol. 2008;18(3):252-62. [pmid: 18330677].
129 Mohan N, Edwards ET, Cupps TR, et al. Demyelination occurring during anti-tumor necrosis factor alpha therapy for inflammatory arthritides. Arthritis Rheum. Dec. 2001;44(12):2862-9. [pmid: 11762947].
130 Mohan AK, Cote TR, Block JA, et al. Tuberculosis following the use of etanercept, a tumor necrosis factor inhibitor. Clin Infect Dis. Aug. 1. 2004;39(3):295-9. [pmid: 15306993].
131 Mottonen T, Hannonen P, Leirisalo-Repo M, et al. Comparison of Combination Therapy With Single-Drug Therapy in Early Rheumatoid Arthritis: a Randomised Trial. Lancet. 1999;353(9164):1568-73. [pmid: 10334255].
132 Korpela M, Laasonen L, Hannonen P, et al. Retardation of joint damage in patients with early rheumatoid arthritis by initial aggressive treatment with disease-modifying antirheumatic drugs: five-year experience from the Fin-Raco Study. Arthritis Rheum. 2004;50(7):2072-81. [pmid: 15248204].
133 Puolakka K, Kautiainen H, Mottonen T, et al. Impact of initial aggressive drug treatment with a combination of disease-modifying antirheumatic drugs on the development of work disability in early rheumatoid arthritis: a five-year randomized followup trial. Arthritis Rheum. 2004;50(1):55-62. [pmid: 14730599].
134 Mottonen T, Hannonen P, Korpela M, et al. Delay to Institution of Therapy and Induction of Remission Using Single-Drug or Combination-Disease-Modifying Antirheumatic Drug Therapy in Early Rheumatoid Arthritis. Arthritis Rheum. 2002;46(4):894-8. [pmid: 11953964].
135 Nadareishvili Z, Michaud K, Hallenbeck JM, et al. Cardiovascular, rheumatologic, and pharmacologic predictors of stroke in patients with rheumatoid arthritis: a nested, case-control study. Arthritis Rheum. 2008;59(8):1090-6. [pmid: 18668583].
136 Naranjo A, Sokka T, Descalzo MA, et al. Cardiovascular disease in patients with rheumatoid arthritis: results from the QUEST-RA study. Arthritis Res Ther. 2008;10(2):R30. [pmid: 18325087].
137 Nishimoto N, Miyasaka N, Yamamoto K, et al. Study of active controlled tocilizumab monotherapy for rheumatoid arthritis patients with an inadequate response to methotrexate (SATORI): significant reduction in disease activity and serum vascular endothelial growth factor by IL-6 receptor inhibition therapy. Mod Rheumatol. 2009;19(1):12-9. [pmid: 18979150].
138 Nuki G, Bresnihan B, Bear MB, et al. Long-term safety and maintenance of clinical improvement following treatment with anakinra (recombinant human interleukin-1 receptor antagonist) in patients with rheumatoid arthritis: extension phase of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Nov. 2002;46(11):2838-46. [pmid: 12428223].
139 O’Dell JR, Haire CE, Erikson N, et al. Treatment of rheumatoid arthritis with methotrexate alone, sulfasalazine and hydroxychloroquine, or a combination of all three medications. N Engl J Med. May. 16. 1996;334(20):1287-91. [pmid: 8609945].
140 O’Dell JR, Leff R, Paulsen G, et al. Treatment of rheumatoid arthritis with methotrexate and hydroxychloroquine, methotrexate and sulfasalazine, or a combination of the three medications: results of a two-year, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. 2002;46(5):1164-70. [pmid: 12115219].
141 O’Dell JR, Petersen K, Leff R, et al. Etanercept in combination with sulfasalazine, hydroxychloroquine, or gold in the treatment of rheumatoid arthritis. J Rheumatol. Feb. 2006;33(2):213-8. [pmid: 16358366].
142 Osiri M, Shea B, Robinson V, et al. Leflunomide for treating rheumatoid arthritis. Cochrane Database Syst Rev. 2002;(3):CD002047.
143 Pallavicini FB, Caporali R, Sarzi-Puttini P, et al. Tumour necrosis factor antagonist therapy and cancer development: analysis of the LORHEN registry. Autoimmun Rev. 2010;9(3):175-80. [pmid: 19647103].
144 Pan SM, Dehler S, Ciurea A, et al. Comparison of drug retention rates and causes of drug discontinuation between anti-tumor necrosis factor agents in rheumatoid arthritis. Arthritis Rheum. 2009;61(5):560-8. [pmid: 19405000].
145 Russell AS, Wallenstein GV, Li T, et al. Abatacept improves both the physical and mental health of patients with rheumatoid arthritis who have inadequate response to methotrexate treatment. Ann Rheum Dis. Feb. 2007;66(2):189-94. [pmid: 16984942].
146 Saag KG, Koehnke R, Caldwell JR, et al. Low dose long-term corticosteroid therapy in rheumatoid arthritis: an analysis of serious adverse events. Am J Med. Feb. 1994;96(2):115-23. [pmid: 8109596].
147 Salliot C, Gossec L, Ruyssen-Witrand A, et al. Infections during tumour necrosis factor-{alpha} blocker therapy for rheumatic diseases in daily practice: a systematic retrospective study of 709 patients. Rheumatology (Oxford). July. 31. 2006. 2007;46(2):327-34. [pmid: 16880188].
148 Schaible TF. Long term safety of infliximab. Can J Gastroenterol. Sep. 2000;14(Suppl C):29C-32C.
149 Schiff MH, Burmester GR, Kent JD, et al. Safety analyses of adalimumab (HUMIRA) in global clinical trials and US postmarketing surveillance of patients with rheumatoid arthritis. Ann Rheum Dis. Jul. 2006;65(7):889-94. [pmid: 16439435].
150 Schiff M, Keiserman M, Codding C, et al. Efficacy and safety of abatacept or infliximab vs placebo in ATTEST: a phase III, multi-centre, randomised, double-blind, placebo-controlled study in patients with rheumatoid arthritis and an inadequate response to methotrexate. Ann Rheum Dis. 2008;67(8):1096-103. [pmid: 18055472].
151 Schipper LG, Fransen J, Barrera P, et al. Methotrexate therapy in rheumatoid arthritis after failure to sulphasalazine: to switch or to add?. Rheumatology (Oxford). 2009;48(10):1247-53. [pmid: 19638454].
152 Schneeweiss S, Setoguchi S, Weinblatt ME, et al. Anti-tumor necrosis factor alpha therapy and the risk of serious bacterial infections in elderly patients with rheumatoid arthritis. Arthritis Rheum. 2007;56(6):1754-64. [pmid: 17530704].
153 Setoguchi S, Solomon DH, Weinblatt ME, et al. Tumor necrosis factor alpha antagonist use and cancer in patients with rheumatoid arthritis. Arthritis Rheum. Sep. 2006;54(9):2757-64. [pmid: 16947774].
154 Setoguchi S, Schneeweiss S, Avorn J, et al. Tumor necrosis factor-alpha antagonist use and heart failure in elderly patients with rheumatoid arthritis. Am Heart J. 2008;156(2):336-41. [pmid: 18657665].
155 Shin IS, Baer AN, Kwon HJ, et al. Guillain-Barre and Miller Fisher syndromes occurring with tumor necrosis factor alpha antagonist therapy. Arthritis Rheum. May. 2006;54(5):1429-34. [pmid: 16645971].
156 Slifman NR, Gershon SK, Lee JH, et al. Listeria monocytogenes infection as a complication of treatment with tumor necrosis factor alpha-neutralizing agents. Arthritis Rheum. Feb. 2003;48(2):319-24. [pmid: 12571839].
157 Smitten AL, Choi HK, Hochberg MC, et al. The risk of herpes zoster in patients with rheumatoid arthritis in the United States and the United Kingdom. Arthritis Rheum. 2007;57(8):1431-8. [pmid: 18050184].
158 Smitten AL, Choi HK, Hochberg MC, et al. The risk of hospitalized infection in patients with rheumatoid arthritis. J Rheumatol. 2008;35(3):387-93. [pmid: 18260176].
159 Smolen JS, Kalden JR, Scott DL, et al. Efficacy and safety of leflunomide compared with placebo and sulphasalazine in active rheumatoid arthritis: a double-blind, randomised, multicentre trial. Lancet. 1999;353(9149):259-66. [pmid: 9929017].
160 Smolen JS. Efficacy and safety of the new DMARD leflunomide: comparison to placebo and sulfasalazine in active rheumatoid arthritis. Scand J Rheumatol. 1999;112(Supplement):15-21.
161 Sharp JT, Strand V, Leung H, et al. Treatment with leflunomide slows radiographic progression of rheumatoid arthritis: results from three randomized controlled trials of leflunomide in patients with active rheumatoid arthritis. Arthritis Rheum. 2000;43(3):495-505. [pmid: 10728741].
162 Larsen A, Kvien TK, Schattenkirchner M, et al. Slowing of disease progression in rheumatoid arthritis patients during long-term treatment with leflunomide or sulfasalazine. Scand J Rheumatol. 2001;30(3):135-42. [pmid: 11469522].
163 Scott DL, Smolen JS, Kalden JR, et al. Treatment of active rheumatoid arthritis with leflunomide: two year follow up of a double blind, placebo controlled trial versus sulfasalazine. Ann Rheum Dis. 2001;60(10):913-23. [pmid: 11557646].
164 Smolen JS, Beaulieu A, Rubbert-Roth A, et al. Effect of interleukin-6 receptor inhibition with tocilizumab in patients with rheumatoid arthritis (OPTION study): a double-blind, placebo-controlled, randomised trial. Lancet. 2008;371(9617):987-97. [pmid: 18358926].
165 Smolen J, Landewe RB, Mease P, et al. Efficacy and safety of certolizumab pegol plus methotrexate in active rheumatoid arthritis: the RAPID 2 study. A randomised controlled trial. Ann Rheum Dis. 2009;68(6):797-804. [pmid: 19015207].
166 Smolen JS, Han C, van der Heijde DM, et al. Radiographic changes in rheumatoid arthritis patients attaining different disease activity states with methotrexate monotherapy and infliximab plus methotrexate: the impacts of remission and tumour necrosis factor blockade. Ann Rheum Dis. 2009;68(6):823-7. [pmid: 18593759].
167 Smolen JS, Kay J, Doyle MK, et al. Golimumab in patients with active rheumatoid arthritis after treatment with tumour necrosis factor alpha inhibitors (GO-AFTER study): a multicentre, randomised, double-blind, placebo-controlled, phase III trial. Lancet. 2009;374(9685):210-21. [pmid: 19560810].
168 Sokolove J, Strand V, Greenberg JD, et al. Risk of elevated liver enzymes associated with TNF inhibitor utilisation in patients with rheumatoid arthritis. Ann Rheum Dis. 2010;69(9):1612-7. [pmid: 20448284].
169 Solomon DH, Avorn J, Katz JN, et al. Immunosuppressive medications and hospitalization for cardiovascular events in patients with rheumatoid arthritis. Arthritis Rheum. 12. 01. 2006;54(Dec):3790-8. [pmid: 17136752].
170 St Clair EW, van der Heijde DM, Smolen JS, et al. Combination of infliximab and methotrexate therapy for early rheumatoid arthritis: a randomized, controlled trial. Arthritis Rheum. Nov. 2004;50(11):3432-43. [pmid: 15529377].
171 Smolen JS, Han C, van der Heijde D, et al. Infliximab treatment maintains employability in patients with early rheumatoid arthritis. Arthritis Rheum. Mar. 2006;54(3):716-22. [pmid: 16508932].
172 Strand V, Cohen S, Schiff M, et al. Treatment of active rheumatoid arthritis with leflunomide compared with placebo and methotrexate. Arch Intern Med. 1999;159(21):2542-50. [pmid: 10573044].
173 Strand V, Tugwell P, Bombardier C, et al. Function and health-related quality of life: results from a randomized controlled trial of leflunomide versus methotrexate or placebo in patients with active rheumatoid arthritis. Leflunomide Rheumatoid Arthritis Investigators Group. Arthritis Rheum. Sep. 1999;42(9):1870-8. [pmid: 10513801].
174 Cohen S, Cannon G, Schiff M, et al. Two-year, blinded, randomized, controlled trial of treatment of active rheumatoid arthritis with leflunomide compared with methotrexate. Utilization of leflunomide in the treatment of rheumatoid arthritis. Arthritis Rheum. 2001;44(9):1984-92. [pmid: 11592358].
175 Strand V, Balbir-Gurman A, Pavelka K, et al. Sustained benefit in rheumatoid arthritis following one course of rituximab: improvements in physical function over 2 years. Rheumatology (Oxford). 2006;45(12):1505-13. [pmid: 17062648].
176 Strangfeld A, Listing J, Herzer P, et al. Risk of herpes zoster in patients with rheumatoid arthritis treated with anti-TNF-alpha agents. Jama. 2009;301(7):737-44. [pmid: 19224750].
177 Strangfeld A, Hierse F, Rau R, et al. Risk of incident or recurrent malignancies among patients with rheumatoid arthritis exposed to biologic therapy in the German biologics register RABBIT. Arthritis Res Ther. 2010;12(1):R5. [pmid: 20064207].
178 Suissa S, Ernst P, Hudson M, et al. Newer disease-modifying antirheumatic drugs and the risk of serious hepatic adverse events in patients with rheumatoid arthritis. Am J Med. Jul. 15. 2004;117(2):87-92. [pmid: 15234643].
179 Suissa S, Hudson M, Ernst P. Leflunomide use and the risk of interstitial lung disease in rheumatoid arthritis. Arthritis Rheum. May. 2006;54(5):1435-9. [pmid: 16645972].
180 Suissa S, Bernatsky S, Hudson M. Antirheumatic drug use and the risk of acute myocardial infarction. Arthritis Rheum. 2006;55(4):531-6. [pmid: 16874796].
181 Svensson B, Ahlmen M, Forslind K. Treatment of early RA in clinical practice: a comparative study of two different DMARD/corticosteroid options. Clin Exp Rheumatol. May–Jun. 2003;21(3):327-32. [pmid: 12846051].
182 Svensson B, Boonen A, Albertsson K, et al. Low-dose prednisolone in addition to the initial disease-modifying antirheumatic drug in patients with early active rheumatoid arthritis reduces joint destruction and increases the remission rate: a two-year randomized trial. Arthritis Rheum. 2005;52(11):3360-70. [pmid: 16255010].
183 van Halm VP, Nurmohamed MT, Twisk JW, et al. Disease-modifying antirheumatic drugs are associated with a reduced risk for cardiovascular disease in patients with rheumatoid arthritis: a case control study. Arthritis Res Ther. 2006;8(5):R151. [pmid: 16984661].
184 van Riel PL, Taggart AJ, Sany J, et al. Efficacy and safety of combination etanercept and methotrexate versus etanercept alone in patients with rheumatoid arthritis with an inadequate response to methotrexate: The ADORE study. Ann Rheum Dis. 2006. Feb. 7.
185 Van Riel PLCM, Freundlich B, MacPeek D, et al. Patient-reported health outcomes in a trial of etanercept monotherapy versus combination therapy with etanercept and methotrexate for rheumatoid arthritis: The ADORE trial. Ann Rheum Dis. 2008;67(8):1104-10. [pmid: 17666447].
186 van Vollenhoven RF, Ernestam S, Geborek P, et al. Addition of infliximab compared with addition of sulfasalazine and hydroxychloroquine to methotrexate in patients with early rheumatoid arthritis (Swefot trial): 1-year results of a randomised trial. Lancet. 2009;374(9688):459-66. [pmid: 19665644].
187 Wallis RS, Broder MS, Wong JY, et al. Granulomatous infectious diseases associated with tumor necrosis factor antagonists. Clin Infect Dis. May. 1. 2004;38(9):1261-5. [pmid: 15127338].
188 Wasserman MJ, Weber DA, Guthrie JA, et al. Infusion-related reactions to infliximab in patients with rheumatoid arthritis in a clinical practice setting: relationship to dose, antihistamine pretreatment, and infusion number. J Rheumatol. Oct. 2004;31(10):1912-7. [pmid: 15468353].
189 Weaver AL, Lautzenheiser RL, Schiff MH, et al. Real-world effectiveness of select biologic and DMARD monotherapy and combination therapy in the treatment of rheumatoid arthritis: results from the RADIUS observational registry. Curr Med Res Opin. Jan. 2006;22(1):185-98. [pmid: 16393444].
190 Weinblatt M, Combe B, Covucci A, et al. Safety of the selective costimulation modulator abatacept in rheumatoid arthritis patients receiving background biologic and nonbiologic disease-modifying antirheumatic drugs: A one-year randomized, placebo-controlled study. Arthritis Rheum. Aug. 31. 2006;54(9):2807-16. [pmid: 16947384].
191 Weinblatt M, Schiff M, Goldman A, et al. Selective costimulation modulation using abatacept in patients with active rheumatoid arthritis while receiving etanercept: a randomised clinical trial. Ann Rheum Dis. Feb. 2007;66(2):228-34. [pmid: 16935912].
192 Wells G, Li T, Maxwell L, et al. Responsiveness of patient reported outcomes including fatigue, sleep quality, activity limitation, and quality of life following treatment with abatacept for rheumatoid arthritis. Ann Rheum Dis. 2008;67(2):260-5. [pmid: 17846044].
193 Westhovens R, Cole JC, Li T, et al. Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology. 2006;45(Oct):1238-46. [pmid: 16567357].
194 Hassett AL, Li T, Buyske S, et al. The multi-faceted assessment of independence in patients with rheumatoid arthritis: preliminary validation from the ATTAIN study. Curr Med Res Opin. 2008;24(5):1443-53. [pmid: 18402714].
195 Westhovens R, Yocum D, Han J, et al. The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum. Apr. 2006;54(4):1075-86. [pmid: 16572442].
196 Westhovens R, Robles M, Ximenes AC, et al. Clinical efficacy and safety of abatacept in methotrexate-naive patients with early rheumatoid arthritis and poor prognostic factors. Ann Rheum Dis. Dec. 2009;68(12):1870-7. [pmid: 19124524].
197 Wolfe F, Michaud K. Lymphoma in rheumatoid arthritis: the effect of methotrexate and anti-tumor necrosis factor therapy in 18,572 patients. Arthritis Rheum. Jun. 2004;50(6):1740-51. [pmid: 15188349].
198 Wolfe F, Michaud K. Heart failure in rheumatoid arthritis: rates, predictors, and the effect of anti-tumor necrosis factor therapy. Am J Med. Mar. 1. 2004;116(5):305-11. [pmid: 14984815].
199 Wolfe F, Caplan L, Michaud K. Treatment for rheumatoid arthritis and the risk of hospitalization for pneumonia: associations with prednisone, disease-modifying antirheumatic drugs, and anti-tumor necrosis factor therapy. Arthritis Rheum. Feb. 2006;54(2):628-34. [pmid: 16447241].
200 Wolfe F, Caplan L, Michaud K. Rheumatoid arthritis treatment and the risk of severe interstitial lung disease. Scand J Rheumatol. 2007;36(3):172-8. [pmid: 17657669].
201 Wolfe F, Michaud K. The effect of methotrexate and anti-tumor necrosis factor therapy on the risk of lymphoma in rheumatoid arthritis in 19,562 patients during 89,710 person-years of observation. Arthritis Rheum. 2007;56(5):1433-9. [pmid: 17469100].
202 Wolfe F, Michaud K. Biologic treatment of rheumatoid arthritis and the risk of malignancy: Analyses from a large US observational study. Arthritis Rheum. 2007;56(9):2886-95. [pmid: 17729297].
203 Zhang FC, Hou Y, Huang F, et al. Infliximab versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a preliminary study from China. APLAR J Rheumatol. 2006;9(2):127-30.
204 Zink A, Listing J, Kary S, et al. Treatment continuation in patients receiving biological agents or conventional DMARD therapy. Ann Rheum Dis. Sep. 2005;64(9):1274-9. [pmid: 15708884].
205 Alonso-Ruiz A, Pijoan JI, Ansuategui E, et al. Tumor necrosis factor alpha drugs in rheumatoid arthritis: Systematic review and metaanalysis of efficacy and safety. BMC Musculoskeletal Disorders. 2008;9.
206 Bergman GJ, Hochberg MC, Boers M, et al. Indirect comparison of tocilizumab and other biologic agents in patients with rheumatoid arthritis and inadequate response to disease-modifying antirheumatic drugs. Semin Arthritis Rheum. 2010;39(6):425-41. [pmid: 20223500].
207 Bernatsky S, Habel Y, Rahme E. Observational studies of infections in rheumatoid arthritis: a metaanalysis of tumor necrosis factor antagonists. J Rheumatol. 2010;37:928-31. [pmid: 20360181].
208 Bongartz T, Sutton AJ, Sweeting MJ, et al. Anti-TNF antibody therapy in rheumatoid arthritis and the risk of serious infections and malignancies: systematic review and meta-analysis of rare harmful effects in randomized controlled trials. JAMA. May. 17. 2006;295(19):2275-85. [pmid: 16705109].
209 Bongartz T, Warren FC, Mines D, et al. Etanercept therapy in rheumatoid arthritis and the risk of malignancies: a systematic review and individual patient data meta-analysis of randomised controlled trials. Ann Rheum Dis. 2009;68(7):1177-83. [pmid: 19019889].
210 Clark W, Jobanputra P, Barton P, et al. The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis. Health Technol Assess. May. 2004;8(18):iii-iv. ix. x. 1. 105.
211 Devine EB, Alfonso-Cristancho R, Sullivan SD. Effectiveness of biologic therapies for rheumatoid arthritis: an indirect comparisons approach. Pharmacotherapy. 2011;31(1):39-51. [pmid: 21182357].
212 Gartlehner G, Hansen RA, Jonas BL, et al. The comparative efficacy and safety of biologics for the treatment of rheumatoid arthritis: a systematic review and metaanalysis. J Rheumatol. Dec. 2006;33(12):2398-408. [pmid: 17225293].
213 Gaujoux-Viala C, Smolen JS, Landewe R, et al. Current evidence for the management of rheumatoid arthritis with synthetic disease-modifying antirheumatic drugs: a systematic literature review informing the EULAR recommendations for the management of rheumatoid arthritis. Ann Rheum Dis. Jun. 2010;69(6):1004-9. [pmid: 20447954].
214 Hochberg MC, Tracy JK, Hawkins-Holt M, et al. Comparison of the efficacy of the tumour necrosis factor alpha blocking agents adalimumab, etanercept, and infliximab when added to methotrexate in patients with active rheumatoid arthritis. Ann Rheum Dis. 2003. Suppl 2. 2003;62:ii13-6. [pmid: 14532140].
215 Kirwan JR, Bijlsma JW, Boers M, et al. Effects of glucocorticoids on radiological progression in rheumatoid arthritis. Cochrane Database Syst Rev. 2007;(1):CD006356. [pmid: 17253590].
216 Kuriya B, Arkema EV, Bykerk VP, et al. Efficacy of initial methotrexate monotherapy versus combination therapy with a biological agent in early rheumatoid arthritis: a meta-analysis of clinical and radiographic remission. Ann Rheum Dis. 2010;69(7):1298-304. [pmid: 20421343].
217 Leombruno JP, Einarson TR, Keystone EC. The safety of anti-tumour necrosis factor treatments in rheumatoid arthritis: meta and exposure-adjusted pooled analyses of serious adverse events. Ann Rheum Dis. 2009;68(7):1136-45. [pmid: 18753157].
218 Maetzel A, Wong A, Strand V, et al. Meta-analysis of treatment termination rates among rheumatoid arthritis patients receiving disease-modifying anti-rheumatic drugs. Rheumatology (Oxford). Sep. 2000;39(9):975-81. [pmid: 10986302].
219 Martinez Lopez JA, Loza E, Carmona L. Systematic review on the safety of methotrexate in rheumatoid arthritis regarding the reproductive system (fertility, pregnancy, and breastfeeding). Clin Exp Rheumatol. 2009;27(4):678-84. [pmid: 19772806].
220 Mertens M, Singh JA. Anakinra for rheumatoid arthritis. Cochrane Database Syst Rev. 2009;(1):CD005121. [pmid: 19160248].
221 Nam JL, Winthrop KL, van Vollenhoven RF, et al. Current evidence for the management of rheumatoid arthritis with biological disease-modifying antirheumatic drugs: a systematic literature review informing the EULAR recommendations for the management of RA. Ann Rheum Dis. 2010;69(6):976-86. [pmid: 20447957].
222 Osiri M, Shea B, Welch V, et al. Leflunomide for the treatment of rheumatoid arthritis. Cochrane Database Syst Rev. 2003;1. Art. No.: CD002047.
223 Rheumatoid Arthritis Clinical Trial Archive Group. The effect of age and renal function on the efficacy and toxicity of methotrexate in rheumatoid arthritis. J Rheumatol. 1995;22(2):218-23. [pmid: 7738941].
224 Salliot C, Dougados M, Gossec L. Risk of serious infections during rituximab, abatacept and anakinra treatments for rheumatoid arthritis: meta-analyses of randomised placebo-controlled trials. Ann Rheum Dis. 2009;68(1):25-32. [pmid: 18203761].
225 Schipper LG, Fransen J, Barrera P, et al. Methotrexate in combination with sulfasalazine is more effective in rheumatoid arthritis patients who failed sulfasalazine than in patients naive to both drugs. Rheumatology (Oxford). 2009;48(7):828-33. [pmid: 19458163].
226 Singh JA, Christensen R, Wells GA, et al. A network meta-analysis of randomized controlled trials of biologics for rheumatoid arthritis: a Cochrane overview. Can Med Assoc J. 2009;181:787. [pmid: 19884297].
227 Singh Jasvinder A, Christensen R, Wells George A, et al. Biologics for rheumatoid arthritis: an overview of Cochrane reviews. Cochrane Database of Systematic Reviews. 2009;(4).
228 Singh JA, Noorbaloochi S, Singh G. Golimumab for rheumatoid arthritis. Cochrane Database Syst Rev. 2010;(1):CD008341. [pmid: 20091667].
229 Singh Jasvinder A, Beg S, Lopez-Olivo Maria A. Tocilizumab for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2010;(7).
230 Wailoo A, Brennan A, Bansback N, et al. Modeling the cost effectiveness of etanercept, adalimumab and anakinra compared to infliximab in the treatment of patients with rheumatoid arthritis in the Medicare program. AHRQ Technology Assessment Program. 2006.
231 Wiens A, Correr CJ, Pontarolo R, et al. A systematic review and meta-analysis of the efficacy and safety of etanercept for treating rheumatoid arthritis. Scand J Immunol. 2009;70(4):337-44. [pmid: 19751268].
232 Wiens A, Venson R, Correr CJ, et al. Meta-analysis of the efficacy and safety of adalimumab, etanercept, and infliximab for the treatment of rheumatoid arthritis. Pharmacotherapy. 2010;30(4):339-53. [pmid: 20334454].