# Review and Abstraction Forms

Abstract Review Questions

Original research (no review articles, editorials, letters to the editor) published in English after 1990 in adult patients with rheumatoid or psoriatic arthritis AND is not a case report or case series? | Yes
| No
| Cannot determine
| No, but article will be used for background
Study includes one or more of the following pharmaceutical interventions (check all that apply): | Corticosteroids
Study includes one or more of the following pharmaceutical interventions (check all that apply): | Oral DMARDs including methotrexate, leflunomide, sulfasalazine, cyclosporine, hydroxychloroquine
Study includes one or more of the following pharmaceutical interventions (check all that apply): | Biologic DMARDs including anakinra, etanercept, infliximab, adalimumab, abatacept, certolizumab, golimumab, tocilizumab, rituximab
Study includes one or more of the following pharmaceutical interventions (check all that apply): | Cannot determine
Study includes one or more of the following pharmaceutical interventions (check all that apply): | Comparison is not of interest
Study compares: | Two of the included drugs
Study compares: | Biological DMARD (TIM) versus placebo
Study compares: | One of the included drugs versus placebo but is of interest because of specific outcomes such as adverse events
Study compares: | Nothing of interest and article should not be included
Study compares: | Cannot determine
Addresses one or more of the following key questions (check all that apply): | KQ1 For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in their ability to reduce patient-reported symptoms, to slow or limit progression of radiographic joint damage, or to maintain remission (reduce the incidence flareups?
Addresses one or more of the following key questions (check all that apply): | KQ2- For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in their ability to improve functional capacity or quality of life?
Addresses one or more of the following key questions (check all that apply): | KQ3 For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in harms, tolerability, adherence, or adverse effects?
Addresses one or more of the following key questions (check all that apply): | KQ4 What are the comparative benefits and harms of drug therapies for rheumatoid arthritis and psoriatic arthritis in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities?
Addresses one or more of the following key questions (check all that apply): | Cannot determine by the title or abstract
Addresses one or more of the following key questions (check all that apply): | None of the above
Study design is one of the following: | RCT 3 months or longer
Study design is one of the following: | Meta-analysis or systematic review
Study design is one of the following: | Observational Study (N is greater or equal to 100) 3 months or longer
Study design is one of the following: | Case series
Study design is one of the following: | Case report
Study design is one of the following: | None of the above – so exclude
Study design is one of the following: | None of the above – but include
Study design is one of the following: | Cannot determine

Abstraction Forms