# References

1 Bolen J, Helmick CG, Sacks JJ, et al. Prevalence of self-reported arthritis or chronic joint symptoms among adults--United States, 2001. MMWR Morb Mortal Wkly Rep. Oct. 25. 2002;51(42):948-50. [pmid: 12437034].
2 Helmick CG, Felson DT, Lawrence RC, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part. I. Arthritis Rheum. Jan. 2008;58(1):15-25. [pmid: 18163481].
3 Bruce TO. Comorbid depression in rheumatoid arthritis: pathophysiology and clinical implications. Curr Psychiatry Rep. Jun. 2008;10(3):258-64. [pmid: 18652795].
4 Husted JA, Gladman DD, Farewell VT, et al. Health-related quality of life of patients with psoriatic arthritis: a comparison with patients with rheumatoid arthritis. Arthritis Rheum. Apr. 2001;45(2):151-8. [pmid: 11324779].
5 Sokoll KB, Helliwell PS. Comparison of disability and quality of life in rheumatoid and psoriatic arthritis. J Rheumatol. Aug. 2001;28(8):1842-6. [pmid: 11508587].
6 Borman P, Toy GG, Babaoğlu S, et al. A comparative evaluation of quality of life and life satisfaction in patients with psoriatic and rheumatoid arthritis. Clin Rheumatol. Apr. 19. 2006;26(3):330-4. [pmid: 16622591].
7 Li X, Gignac MA, Anis AH. The indirect costs of arthritis resulting from unemployment, reduced performance, and occupational changes while at work. Med Care. Apr. 2006;44(4):304-10. [pmid: 16565630].
8 Mau W, Listing J, Huscher D, et al. Employment across chronic inflammatory rheumatic diseases and comparison with the general population. J Rheumatol. Apr. 2005;32(4):721-8. [pmid: 15801031].
9 Michaud K, Messer J, Choi HK, et al. Direct medical costs and their predictors in patients with rheumatoid arthritis: a three-year study of 7,527 patients. Arthritis Rheum. Oct. 2003;48(10):2750-62. [pmid: 14558079].
10 Hallert E, Husberg M, Skogh T. Costs and course of disease and function in early rheumatoid arthritis: a 3-year follow-up (the Swedish TIRA project). Rheumatology (Oxford). Mar. 2006;45(3):325-31. [pmid: 16287927].
11 Huscher D, Merkesdal S, Thiele K, et al. Cost of illness in rheumatoid arthritis, ankylosing spondylitis, psoriatic arthritis and systemic lupus erythematosus in Germany. Ann Rheum Dis. Sep. 2006;65(9):1175-83. [pmid: 16540552].
12 Ozminkowski RJ, Burton WN, Goetzel RZ, et al. The impact of rheumatoid arthritis on medical expenditures, absenteeism, and short-term disability benefits. J Occup Environ Med. Feb. 2006;48(2):135-48. [pmid: 16474262].
13 National and state medical expenditures and lost earnings attributable to arthritis and other rheumatic conditions--United States, 2003. MMWR Morb Mortal Wkly Rep. Jan. 12. 2007;56(1):4-7. [pmid: 17218935].
14 Ackermann C, Kavanaugh A. Economic burden of psoriatic arthritis. Pharmacoeconomics. 2008;26(2):121-9. [pmid: 18198932].
15 Olivieri I, Mantovani LG, D’Angelo S, et al. Psoriatic arthritis: pharmacoeconomic considerations. Curr Rheumatol Rep. Aug. 2009;11(4):263-9. [pmid: 19691929].
16 Gladman DD, Antoni C, Mease P, et al. Psoriatic arthritis: epidemiology, clinical features, course, and outcome. Ann Rheum Dis. Mar. 2005;64(Suppl 2):ii14-7. [pmid: 15708927].
17 Gelfand JM, Gladman DD, Mease PJ, et al. Epidemiology of psoriatic arthritis in the population of the United States. J Am Acad Dermatol. Oct. 2005;53(4):573. [pmid: 16198775].
18 Anandarajah AP, Ritchlin CT. Pathogenesis of psoriatic arthritis. Curr Opin Rheumatol. Jul. 2004;16(4):338-43. [pmid: 15201594].
19 Helliwell PS, Taylor WJ. Classification and diagnostic criteria for psoriatic arthritis. Ann Rheum Dis. Mar. 2005;64(Suppl 2):ii3-8. [pmid: 15708931].
20 Taylor W, Gladman D, Helliwell P, et al. Classification criteria for psoriatic arthritis: development of new criteria from a large international study. Arthritis Rheum. Aug. 2006;54(8):2665-73. [pmid: 16871531].
21 Ritchlin CT, Kavanaugh A, Gladman DD, et al. Treatment recommendations for psoriatic arthritis. Ann Rheum Dis. Sep. 2009;68(9):1387-94. [pmid: 18952643].
22 Donahue KE, Gartlehner G, Jonas DE, et al. Comparative effectiveness of drug therapy for rheumatoid arthritis and psoriatic arthritis in adults, Comparative Effectiveness Review No. 11. (Prepared by RTI-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016.) AHRQ Pub. No. 08-EHC004-1. Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
23 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
24 Undertaking systematic reviews of research on effectiveness: CRD’s guidance for those carrying out or commissioning reviews, CRD Report Number 4. 2nd edition. 2001.
25 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
26 Agency for Healthcare Research and Quality. Methods reference guide for effectiveness and comparative effectiveness reviews, version 1.0. [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
27 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
28 van Tuyl LH, Vlad SC, Felson DT, et al. Defining remission in rheumatoid arthritis: results of an initial American College of Rheumatology/European League Against Rheumatism consensus conference. Arthritis Rheum. May. 15. 2009;61(5):704-10. [pmid: 19405006].
29 Prevoo ML, van Gestel AM, van T, Hof MA, et al. Remission in a prospective study of patients with rheumatoid arthritis. American Rheumatism Association preliminary remission criteria in relation to the disease activity score. Br J Rheumatol. Nov. 1996;35(11):1101-5. [pmid: 8948296].
30 Landewe R, van der Heijde D, van der Linden S, et al. Twenty-eight-joint counts invalidate the DAS28 remission definition owing to the omission of the lower extremity joints: a comparison with the original DAS remission. Ann Rheum Dis. May. 2006;65(5):637-41. [pmid: 16219709].
31 Wells GA, Tugwell P, Kraag GR, et al. Minimum important difference between patients with rheumatoid arthritis: the patient’s perspective. J Rheumatol. Mar. 1993;20(3):557-60. [pmid: 8478873].
32 Carlin CS, Feldman SR, Krueger JG, et al. A 50% reduction in the Psoriasis Area and Severity Index (PASI 50) is a clinically significant endpoint in the assessment of psoriasis. J Am Acad Dermatol. Jun. 2004;50(6):859-66. [pmid: 15153885].
33 Reddy SM, Bingham CO III. Outcome measures in psoriatic arthritis clinical trials. Curr Rheumatol Rep. Aug. 2005;7(4):299-305. [pmid: 16045833].
34 Kosinski M, Zhao SZ, Dedhiya S, et al. Determining minimally important changes in generic and disease-specific health-related quality of life questionnaires in clinical trials of rheumatoid arthritis. Arthritis Rheum. Jul. 2000;43(7):1478-87. [pmid: 10902749].
35 Walters SJ, Brazier JE. What is the relationship between the minimally important difference and health state utility values? The case of the SF-6. D Health Qual Life Outcomes. 2003;1:4. [pmid: 12737635].
36 Ware JE, Snow KK, Kosinski M, et al. SF-36^®^ Health Survey Manual and Interpretation Guide. Boston, MA. New England Medical Center, The Health Institute. 1993.
37 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. Aug. 2001;45(4):384-91. [pmid: 11501727].
38 Bruynesteyn K, van der Heijde D, Boers M, et al. Determination of the minimal clinically important difference in rheumatoid arthritis joint damage of the Sharp/van der Heijde and Larsen/Scott scoring methods by clinical experts and comparison with the smallest detectable difference. Arthritis Rheum. Apr. 2002;46(4):913-20. [pmid: 11953967].
39 Willkens RF, Williams HJ, Ward JR, et al. Randomized, double-blind, placebo controlled trial of low-dose pulse methotrexate in psoriatic arthritis. Arthritis Rheum. Apr. 1984;27(4):376-81. [pmid: 6712754].
40 Jones G, Crotty M, Brooks P. Interventions for treating psoriatic arthritis. Cochrane Database Syst Rev. 2000;(3):CD000212. [pmid: 10908464].
41 Kaltwasser J, Nash P, Gladman D, et al. Efficacy and Safety of Leflunomide in the Treatment of Psoriatic Arthritis and Psoriasis: a Multinational, Double-Blind, Randomized, Placebo-Controlled Clinical Trial. Arthritis and rheumatism. 2004;50(6):1393-50.
42 Nash P, Thaci D, Behrens F, et al. Leflunomide improves psoriasis in patients with psoriatic arthritis: an in-depth analysis of data from the TOPAS study. Dermatology. 2006;212(3):238-49. [pmid: 16549920].
43 Kristensen LE, Gulfe A, Saxne T, et al. Efficacy and tolerability of anti-tumour necrosis factor therapy in psoriatic arthritis patients: results from the South Swedish Arthritis Treatment Group register. Ann Rheum Dis. Mar. 2008;67(3):364-9. [pmid: 17644547].
44 Saad AA, Ashcroft DM, Watson KD, et al. Efficacy and safety of anti-TNF therapies in psoriatic arthritis: an observational study from the British Society for Rheumatology Biologics Register. Rheumatology. (Oxford). 2010;49(4):697-705. [pmid: 20056769].
45 Ravindran V, Scott DL, Choy EH. A systematic review and meta-analysis of efficacy and toxicity of disease modifying anti-rheumatic drugs and biological agents for psoriatic arthritis. Ann Rheum Dis. Jun. 2008;67(6):855-9. [pmid: 17827183].
46 Mease PJ, Gladman DD, Ritchlin CT, et al. Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. Oct. 2005;52(10):3279-89. [pmid: 16200601].
47 Mease PJ, Goffe BS, Metz J, et al. Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet. Jul. 29. 2000;356(9227):385-90. [pmid: 10972371].
48 Mease PJ, Kivitz AJ, Burch FX, et al. Etanercept treatment of psoriatic arthritis: safety, efficacy, and effect on disease progression. Arthritis Rheum. Jul. 2004;50(7):2264-72. [pmid: 15248226].
49 Mease PJ, Kivitz AJ, Burch FX, et al. Continued inhibition of radiographic progression in patients with psoriatic arthritis following 2 years of treatment with etanercept. J Rheumatol. Apr. 2006;33(4):712-21. [pmid: 16463435].
50 Antoni CE, Kavanaugh A, Kirkham B, et al. Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum. Apr. 2005;52(4):1227-36. [pmid: 15818699].
51 Kavanaugh A, Antoni CE, Gladman D, et al. The Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT): results of radiographic analyses after 1 year. Ann Rheum Dis. Aug. 2006;65(8):1038-43. [pmid: 16439444].
52 Antoni C, Krueger GG, de Vlam K, et al. Infliximab improves signs and symptoms of psoriatic arthritis: results of the IMPACT 2 trial. Ann Rheum Dis. Aug. 2005;64(8):1150-7. [pmid: 15677701].
53 Kavanaugh A, Antoni C, Krueger GG, et al. Infliximab improves health related quality of life and physical function in patients with psoriatic arthritis. Ann Rheum Dis. Apr. 2006;65(4):471-7. [pmid: 16096330].
54 Kavanaugh A, McInnes I, Mease P, et al. Golimumab, a new human tumor necrosis factor alpha antibody, administered every four weeks as a subcutaneous injection in psoriatic arthritis: twenty-four-week efficacy and safety results of a randomized, placebo-controlled study. Arthritis Rheum. Apr. 2009;60(4):976-86. [pmid: 19333944].
55 Woolacott N, Bravo Vergel Y, Hawkins N, et al. Etanercept and infliximab for the treatment of psoriatic arthritis: a systematic review and economic evaluation. Health Technol Assess. Sep. 2006;10(31):1-258. [pmid: 17083854].
56 Genovese MC, Mease PJ, Thomson GT, et al. Safety and efficacy of adalimumab in treatment of patients with psoriatic arthritis who had failed disease modifying antirheumatic drug therapy. J Rheumatol. May. 2007;34(5):1040-50. [pmid: 17444593].
57 van der Heijde D, Kavanaugh A, Gladman DD, et al. Infliximab inhibits progression of radiographic damage in patients with active psoriatic arthritis through one year of treatment: results from the induction and maintenance psoriatic arthritis clinical trial 2. Arthritis Rheum. Aug. 2007;56(8):2698-707. [pmid: 17665424].
58 Samsa G, Edelman D, Rothman ML, et al. Determining clinically important differences in health status measures: a general approach with illustration to the Health Utilities Index Mark II. Pharmacoeconomics. Feb. 1999;15(2):141-55. [pmid: 10351188].
59 Gladman DD, Mease PJ, Cifaldi MA, et al. Adalimumab improves joint-related and skin-related functional impairment in patients with psoriatic arthritis: patient-reported outcomes of the Adalimumab Effectiveness in Psoriatic Arthritis Trial. Ann Rheum Dis. Feb. 2007;66(2):163-8. [pmid: 17046964].
60 Mease PJ, Woolley JM, Singh A, et al. Patient-reported outcomes in a randomized trial of etanercept in psoriatic arthritis. J Rheumatol. Jun. 2010;37(6):1221-7. [pmid: 20395648].
61 Kavanaugh A, Antoni C, Mease P, et al. Effect of infliximab therapy on employment, time lost from work, and productivity in patients with psoriatic arthritis. J Rheumatol. Nov. 2006;33(11):2254-9. [pmid: 16960923].
62 Mease PJ. Adalimumab: an anti-TNF agent for the treatment of psoriatic arthritis. Expert Opin Biol Ther. Nov. 2005;5(11):1491-504. [pmid: 16255652].
63 Saad AA, Ashcroft DM, Watson KD, et al. Persistence with anti-tumour necrosis factor therapies in patients with psoriatic arthritis: observational study from the British Society of Rheumatology Biologics Register. Arthritis Res Ther. 2009;11(2):R52. [pmid: 19356232].