# Peer Reviewers

Marion McDonagh, Pharm.D.

Assistant Professor

Informatics and Clinical Epidemiology

Oregon Health & Science University

Portland OR

Christopher T. Ritchlin, M.D., M.P.H.

Internal Medicine, Rheumatology

School of Medicine and Dentistry

University of Rochester

Rochester, NY