# Introduction

## Background

Arthritis and other rheumatic conditions constitute the leading cause of disability among United States (U.S.) adults,1 with more than 46 million Americans reporting doctor-diagnosed arthritis.2 Noninflammatory arthritic conditions (e.g., osteoarthritis) are most common, but inflammatory arthritides such as spondyloarthropathies (e.g., ankylosing spondylitis, psoriatic arthritis [PsA]), and reactive arthritis) and rheumatoid arthritis (RA) can be equally or more disabling.

Among patients with arthritis, the burden of disease is evidenced by decreased quality of life,3–6 decreased employment rates,7, 8 and increased direct and indirect costs.9–12 In 2003, arthritis and other rheumatic conditions cost the United States $127.8 billion ($80.8 billion in medical care expenditures and $47.0 billion in lost earnings).13

Costs associated with PsA are not as well studied as costs associated with other arthritic conditions, although they are believed to be just slightly lower than those associated with RA.11 Indirect costs are believed to increase over time because as the disease progresses so does the loss of function and inability to work. Based on 1997 estimates for psoriasis and PsA, annual direct costs are approximately $650 million.14 Of these costs, hospitalizations accounted for $31 million, outpatient physician visits for $87 million, photochemotherapy for $27 million, dermatologic prescription drugs for $148 million, and over-the-counter medications for $357 million.14, 15 These estimates do not include indirect costs, and the specific direct costs of PsA are not known.

### Causes and Diagnosis

Psoriasis, a skin disease, affects 2.2 percent of U.S. adults; approximately 6 percent to 42 percent of patients with psoriasis develop PsA.16 Approximately 520,000 adults in the United States have PsA.17 PsA can develop at any age but most often appears between 30 and 50 years of age. Unlike RA, PsA appears to affect men slightly more often than women.

Clinically PsA is a multifaceted disease and may have skin presentations that help with its diagnosis. The presentation is highly variable. Patients with PsA can have moderate to severe involvement of skin and joints, and this combination can have profound effects on function and quality of life. In most cases, the psoriasis predates the onset of the PsA, although arthritis has been described as the initial manifestation of psoriatic disease. Common presentations include a symmetric small-joint polyarthritis (RA-like) and an axial arthritis with involvement of the sacroiliac joints, axial skeleton (spine), and large joints. In all cases, symptoms include pain and stiffness in the affected joint, enthesial areas (where tendons insert into bone) with joint line tenderness, swelling, and often loss of range of motion. Pitting of the fingernails often correlates with the extent and severity of the disease. Dactylitis—swelling of a whole digit—is a characteristic clinical finding, and inflammatory eye disease (iritis, uveitis) may occur. More than one-third of patients with PsA will develop dactylitis and enthesopathy (a disease process at the site where muscle tendons or ligaments insert into bones or joints).

The etiology and pathogenesis of psoriasis and PsA are not completely understood, but genetic, immunologic, and environmental factors are all likely to play a role.18 Several classification systems have been proposed for the diagnosis of PsA,19 but which one best represents true PsA remains unclear.

Table 1 presents the CASPAR (ClASsification of Psoriatic ARthritis) as an example of one classification.20

Table 1 CASPAR criteria for the diagnosis of psoriatic arthritis

Inflammatory articular disease (joint, spine, or enthesial areas) with ≥ 3 points from the following:
1. Evidence of current psoriasis, a personal history of psoriasis, or a family history of psoriasis
2. Typical psoriatic nail dystrophy, including onycholysis, pitting, or hyperkeratosis
3. Negative test result for the presence of rheumatoid factor
4. Current dactylitis or history of dactylitis
5. Radiographic evidence of juxtaarticular new bone formation

Source: Taylor W, Gladman D, Helliwell P, Marchesoni A, Mease P, Mielants H. Classification criteria for psoriatic arthritis: development of new criteria from a large international study. Arthritis Rheum. 2006 Aug;54(8):2665–73.^20^

### Treatment of Psoriatic Arthritis

Treatment of patients with PsA is aimed primarily at controlling pain and inflammation and, ultimately, at slowing or arresting the progression of joint destruction. Historically, few trials have been conducted in patients with PsA, with only minimal research before biologic agents were introduced; management options tended to be adapted from RA trial evidence. Like in RA trials, many questions remain about the risks of these agents across a spectrum of adverse events from relatively minor side effects such as injection-site reactions to severe and possibly life-threatening problems such as severe infections or infusion reactions. Unlike RA, there is no diagnostic marker for PsA, which can lead to misdiagnosis. Additionally, studies performed before the CASPAR criteria were used included patients that are not explicitly defined.

#### Corticosteroids

Corticosteroids—sometimes referred to as glucocorticoids or steroids—are used for many inflammatory and autoimmune conditions. As a class, corticosteroids have been used since the discovery of cortisone in the 1940s. Commonly used oral corticosteroids include methylprednisolone, prednisone, and prednisolone.

Corticosteroids are a synthetic form of cortisol, a hormone produced by the adrenal glands. They produce their anti-inflammatory and immunosuppressive response by interacting with steroid-specific receptors in the cytoplasm of cells, thereby inhibiting the movement of inflammatory cells into the site of inflammation, inhibiting neutrophil function, and inhibiting prostaglandin production. When used to treat PsA, corticosteroids are most often given as a joint injection rather than orally. Although they can be very effective in controlling joint inflammation, oral steroids are generally avoided in treating PsA, because a flare of skin disease has been described when steroids are tapered or withdrawn.

#### Oral Disease-Modifying Antirheumatic Drugs (DMARDs)

Oral DMARDs such as methotrexate (MTX), sulfasalazine, hydroxychloroquine, and leflunomide modify the course of inflammatory conditions, presumably through their effects on the immune system. Most of the oral DMARDs have been used in clinical practice for more than 20 years. MTX was developed in the 1940s as a treatment for leukemia but was not approved for the treatment of arthritis until 1988. Sulfasalazine also has been available since the 1940s; it is a combination salicylate (acetylsalicylic acid) and antibiotic (sulfapyearidine) that originally was used to treat patients with inflammatory bowel disease. Hydroxychloroquine, approved in the 1950s for the treatment of malaria, is believed to work in treating arthritis by interfering with antigen presentation and the activation of immune response by increasing the pH within macrophage phagolysosomes. Additionally, hydroxychloroquine possibly inhibits toll-like receptors that mediate proinflammatory cytokine production. Only leflunomide, an isoxazole immunomodulatory agent, was specifically developed for treating inflammatory arthritis; the U.S. Food and Drug Administration (FDA) approved its use in 1998.

Oral DMARDs are not members of a single drug family. They are classified together, however, because they all are slow acting with the aim of improving symptoms, reducing or preventing joint damage, and preserving structure and function in patients with inflammatory disease. All the oral DMARDs covered in this review can be given orally, although MTX can also be injected (subcutaneous [SQ] or intramuscular [IM]).

#### Biologic DMARDs

Biologic DMARDs—commonly referred to as biological response modifiers or simply biologics—are a relatively new category of DMARDs that differ from oral DMARDs in that they target specific components of the immune system. FDA approved the first of the biologics (infliximab) in 1998; this report covers eight additional agents approved since that time: etanercept (1998), anakinra (2001), adalimumab (2002), abatacept (2005), rituximab (2006), certolizumab pegol (2008), golimumab (2009), and tocilizumab (2010). Of the nine agents, all are currently FDA approved for treating RA, but only adalimumab, etanercept, golimumab, and infliximab are approved for treating PsA. Even though anakinra, abatacept, certolixumab pegol, rituximab, and tocilizumab are not FDA approved for PsA, this report reviews the evidence for all of these agents.

The biologic DMARDs work by selectively blocking mechanisms involved in the inflammatory and immune response. Adalimumab, certolizumab pegol, etanercept, golimumab, and infliximab are known as tumor necrosis factor (TNF) inhibitors (i.e., drugs that block specific proinflammatory mediators known as cytokines). They produce their primary effect by blocking TNF from interacting with cell surface TNF receptors. Adalimumab, golimumab, and infliximab are monoclonal antibodies. Adalimumab is a fully human monoclonal antibody that binds specifically to TNF, blocking its interaction with both the p55 and p75 cell surface TNF receptor. Golimumab is also a human monoclonal antibody that binds to TNF alpha with high affinity. Infliximab is a chimeric (i.e., made from human and mouse proteins) monoclonal antibody that binds specifically to human TNF-alpha. Certolizumab pegol is a pegylated humanized antibody fragment of tumor necrosis factor monoclonal antibody. The drug binds to the TNF alpha-receptor and blocks TNF alpha activity. It only possesses the Fab fragment and lacks the Fc region. Hence, it does not induce antibody-dependant cell-mediated apoptosis or toxicity. Etanercept is not a monoclonal antibody, but rather a TNF-soluble receptor protein. More specifically, it is a soluble dimeric form of the p75 TNF receptor linked to the Fc portion of human immunoglobulin G1 (IgG1). Etanercept exerts its action by binding circulating TNF and preventing it from interacting with a cell surface receptor. It does not form neutralizaing antibodies or mediate cell lysis in the presence or absence of complement.

Interleukin-1 (IL-1), another naturally occurring cytokine, has both immune and proinflammatory actions. Anakinra is a human recombinant protein that competitively blocks the IL-1 receptor, thus blocking various inflammatory and immunological responses.

The immunosuppressant agent abatacept produces its immune response by interfering with T lymphocyte activation. Abatacept is a soluble fusion protein that consists of the extracellular domain of human cytotoxic T lymphocyte-associated antigen (CTLA-4) and the modified Fc portion of IgG1.

Rituximab, a chimeric murine/human monoclonal antibody, works by binding to the CD20 antigen found on the surface of B lymphocytes. Thus, it in effect removes circulating B cells from the pre-B cell stage through the activated B cells. B cells are believed to play a role in autoimmune and inflammatory processes.

Interleukin-6 (IL-6) is a naturally occurring cytokine involved in regulating immune responses and inflammation. Tocilizumab is a monoclonal antibody that inhibits IL-6 receptors, blocking the action of IL-6 and leading to a reduction in cytokine and inflammatory response.

Tables 2 through 4 provide detailed information (names, manufacturers, and available dosage forms) on agents used in the treatment of RA that we have included in this review. Also presented are routs of administration, labeled uses, and usual (recommended) adult doses and frequency for PsA.

Table 2 Pharmaceutical treatments for psoriatic arthritis: corticosteroids

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | How Supplied | Usual Adult Dose
Methyl-prednisolone | Multiple Medrol^®^, Depo-Medrol^®^, Solu-Medrol^®^ | Acetate - Injectable IM—20, 40, and 80 mg/ml Sodium succinate - Injectable: IM—40, 125, and 500 mg, 1 and 2 g vials Oral: Tabs—2, 4, 8, 16, and 32 mg | Acetate:; - IM—10 to 80 mg every 1 to 2 weeks; - Intra-articular, intralesional —4 to 80 mg every 1 to 5 weeks; Sodium succinate:; - IM—10 to 80 mg daily; - IV—10 to 40 mg every 4 to 6 hours; up to 30 mg/kg every 4 to 6 hours; Oral:; - 2 to 60 mg in 1 to 4 divided doses to start, followed by gradual reduction
Prednisone | Multiple Deltasone^®^, Sterapred^®^, LiquiPred^®^ | Oral Solution—1 and 5 mg/ml Tabs—1, 2.5, 5, 10, 20, and 50 mg | Use lowest effective dose (5–60 mg/day)
Prednisolone | Multiple Orapred^®^, Pediapred^®^, Prelone^®^, Delta-Cortef^®^, Econopred^®^ | Oral Solution/Syrup—5, 15, and 20 mg/5 ml Oral Tabs—5 and 15 mg | Use lowest effective dose (5 to 7.5 mg/day)

IM = intramuscular; IV = intravenous; kg = killigram; mg = milligram; ml = millileter

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

Table 3 Pharmaceutical treatments for psoriatic arthritis: oral DMARDs

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | How Supplied | Usual Adult Dose
Hydroxy-chloroquine^b^ | Multiple Plaquenil^®^ | Oral Tabs—200 mg | 200 to 400^a^ mg/day in 1 or 2 divided doses
Leflunomide^b^ | Multiple Arava^®^ | Oral Tabs—10 and 20 mg | 10 to 20 mg/day in a single dose
Methotrexate^b^ | Multiple Trexall^®^, Folex^®^, Rheumatrex^®^ | Injectable—25 mg/ml, 20 mg and 1 g vials Oral Tabs—2.5, 5, 7.5, 10, and 15 mg | IM, SQ, oral—7.5 to 20 mg/week in a single dose
Sulfasalazine^b^ | Multiple Azulfidine^®^, EN-tabs^®^, Sulfazine^®^ | Oral Suspension—250 mg/5 ml Oral Tabs—500 mg | 500 to 3,000 mg/day in 2 to 4 divided doses

g = gram; IM = intramuscular; mg = milligram; ml = millileter

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

a Initial dose is 400 to 600 mg/day for 4 to 12 weeks.

b Dosed according to the RA dosing recommendations.

Table 4 Pharmaceutical treatments for psoriatic arthritis: biologic DMARDs

Generic Name | Manufacturer U.S. Trade Name(s)^*^ | Injectable Supply | Usual Adult Dose
Biologic DMARDs
Abatacept | Bristol Myers Squibb Orencia^®^ | 250 mg vial | IV—Dosed according to body weight (<60 kg=500 mg; 60–100 kg=750 mg; >100 kg=1,000 mg); dose repeated at 2 weeks and 4 weeks after initial dose, and every 4 weeks thereafter SQ—may give weight-based IV loading dose, then 125 mg SQ once weekly
Adalimumab | Abbott Humira^®^ | 40 mg/0.8 ml, 20 mg/0.4 ml prefilled syringe | SQ—40 mg every other week alone or in combination with other DMARDs
Anakinra^a^ | Amgen Kineret^®^ | 100 mg/0.67 ml syringe | SQ—100 mg/day; dose should be decreased to 100 mg every other day in renal insufficiency
Certolizumab Pegol^a^ | UCB Cimzia^®^ | 200 mg powder for reconstitution, 200 mg/ml solution | SQ—initial dose of 400 mg (as 2 SQ injections of 200 mg), repeat dose 2 and 4 weeks after initial dose; Maintenance dose is 200 mg every other week (may consider maintenance dose of 400 every 4 weeks)
Etanercept | Amgen Pfizer Immunex Enbrel^®^ | 50 mg/ml in 25 mg or 50 mg single use prefilled syringe | SQ—50 mg once weekly with or without MTX
Golimumab | Centocor Ortho Biotech Simponi^®^ | 50 mg/0.5 ml syringe | SQ—50 mg once per month, alone or in combination with MTX
Infliximab | Centocor Ortho Biotech Remicade^®^ | 100 mg in a 20 ml vial | IV—5 mg/kg at 0, 2 and 6 weeks followed by maintenance every 8 weeks thereafter; may be given with or without MTX
Rituximab^a^ | Biogen Idec / Genentech Rituxan^®^ | 100 mg/10 ml and 500 mg/50 ml vial | IV—1,000 mg IV infusion separated by 2 weeks (one course) every 24 weeks or based on clinical evaluation, but not sooner than every 16 weeks
Tocilizumab^a^ | Genentech / Roche Actemra^®^, RoActemra^®^ | 80 mg/4 ml, 200 mg/10 ml, 400 mg/20 ml vial | IV—4 mg/kg every 4 weeks; increase to 8 mg/kg every 4 weeks based on clinical response

kg = killigram; mg = milligram; ml = millileter; MTX = methotrexate; IV = intravenousl SQ = subcutaneously

* Listed trade names are limited to commonly prescribed U.S. products w hen multiple trade names are available.

a Dosed according to the RA dosing recommendations.

### Treatment Strategies

The first line of treatment of PsA is nonsteroidal anti-inflammatory drugs (NSAIDs), although in most cases DMARDs are necessary. MTX is particularly useful because it treats the psoriasis in addition to the arthropathy. Corticosteroids may be used to control inflammation, but they do not have much of a role in chronic disease management in psoriatic disease. The tapering or withdrawal of steroids in PsA has been associated with severe flares of skin disease. When chronic disease continues to be active despite the use of MTX, biologics are indicated. Biologics most often are given in combination with oral DMARDs (e.g., MTX).21

Historically, few PsA trials have been conducted, and management has been adapted from RA trial data. Since the introduction of biologic therapy, however, dedicated PsA trials have demonstrated efficacy in this distinct disease. Detailed and comparative examination of the efficacy, effectiveness, and harms of treatments for PsA is needed.

## Scope and Key Questions

The purpose of this review is to compare the efficacy, effectiveness, and harms of corticosteroids, oral DMARDS, and biologic DMARDs in the treatment of patients’ PsA. We address the following four Key Questions (KQs):

KQ 1 For patients with PsA, do drug therapies differ in their ability to reduce disease activity, to slow or limit progression of radiographic joint damage, or to maintain remission?
KQ 2 For patients with PsA, do drug therapies differ in their ability to improve patient-reported symptoms, functional capacity, or quality of life?
KQ 3 For patients with PsA, do drug therapies differ in harms, tolerability, adherence, or adverse effects?
KQ 4 What are the comparative benefits and harms of drug therapies for PsA in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities?

Appendix A presents our search strategy; Appendix B contains our review criteria and abstraction forms; Appendix C lists our full bibliography and the source retrieved from; Appendix D lists excluded studies; Appendix E presents evidence tables; Appendix F presents the criteria for assessing the quality of individual studies; Appendix G describes clinical assessment scales commonly used in arthritis trials; Appendix H presents the poor quality studies; and Appendix I contains our strength of evidence tables.