# Discussion

This report provides a comprehensive review of the comparative efficacy, effectiveness, and harms of members of three main classes of drugs used to treat adult patients with psoriatic arthritis (PsA). These drugs include corticosteroids, oral disease-modifying antirheumatic drugs (DMARDs), and biologic DMARDs. The objective of this report is to evaluate the comparative efficacy, effectiveness, and harms of monotherapies, combination therapies, and different treatment strategies.

Table 16 summarizes our findings and the strength of evidence for the Key Questions (KQs) addressed by this report. In brief, the KQs addressed benefits of these drugs, alone or in combination, in terms of slowing or limiting the progression of radiographic joint damage and maintaining remission (KQ 1); reduction of patient-reported symptoms and improved functional capacity and quality of life (KQ 2); harms and risks of these drugs (KQ 3); and the benefits or harms in various patient subpopulations defined by sociodemographic characteristics or health states (KQ 4).

Table 16 Summary of findings

Key Comparisons | Efficacy and Effectiveness Strength of Evidence Grade | Harms Strength of Evidence Grade
Oral DMARDs
Leflunomide | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative efficacy of leflunomide and other treatments. INSUFFICIENT Compared with placebo in one study, leflunomide produced better improvement in health-related quality of life and statistically significant, but not clinically significant, improvement in disease activity and functional capacity. LOW | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative harms of leflunomide and other treatments. INSUFFICIENT Current evidence was limited to placebo-controlled trials. Compared with placebo, leflunomide led to higher rates of withdrawals because of adverse events, diarrhea, and clinically significant increases in alanine aminotransferase. INSUFFICIENT
Methotrexate | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative efficacy of MTX and other treatments. INSUFFICIENT Current evidence was limited to placebo-controlled trials. Compared with placebo in one fair study, MTX resulted in greater improvement in physician assessment of disease activity than placebo. LOW | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative harms of MTX and other treatments. INSUFFICIENT
Sulfasalazine | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative efficacy of sulfasalazine and other treatments. INSUFFICIENT Current evidence was limited to placebo-controlled trials. Compared with placebo in one good systematic review study, sulfasalazine reduced disease activity. MODERATE | No head-to-head studies met inclusion criteria; unable to draw conclusions on the comparative harms of sulfasalazine and other treatments. INSUFFICIENT
Biologic DMARDs
Biologic DMARD + Oral DMARD vs. Biologic DMARD or Oral DMARD | The current evidence was limited to two cohort studies. Compared to anti-TNF monotherapy (adalimumab, etanercept, or infliximab), MTX plus anti-TNF produced similar disease activity response rates. LOW One systematic review of TNF inhibitors found that both TNF inhibitors and sulfasalazine are effective (similar withdrawals due to lack of efficacy); however, the data were insufficient to determine if the effect reached MCID. INSUFFICIENT | No head-to-head evidence met inclusion criteria; unable to draw conclusions on the comparative harms of biologic DMARD + oral DMARD and other treatments. INSUFFICIENT
Biologic | No head-to-head trials met inclusion criteria; unable to draw conclusions on the comparative efficacy of biologics and other treatments. INSUFFICIENT Compared with placebo, adalimumab, etanercept, golimumab, and infliximab led to greater improvement in disease activity, functional capacity^*^ and health-related quality of life.^†^ LOW to MODERATE^‡^ | Etanercept had a lower rate of withdrawals because of adverse events than infliximab in a prospective cohort study. LOW Additional evidence was limited to placebo-controlled trials, where adverse events were not the primary outcome. Overall adverse event profiles appeared to be similar for biologic DMARDs and placebo. However, compared with placebo, we noted the following: adalimumab and etanercept had more injection-site reactions and adalimumab had fewer events of aggravated psoriasis than placebo LOW Golimumab was associated with more malignancies than placebo in one RCT INSUFFICIENT

ADA = adalimumab; DMARD = disease-modifying antirheumatic drug; ETN = etanercept; INF = infliximab; LEF = leflunomide; MCID = minimal clinically important difference; MTX = methotrexate; PCS = physical component score; SF-36 = Medical Outcomes Study Short Form 36; SSZ = sulfasalazine; TNF = tumor necrosis factor

* Of seven studies reporting outcomes for the Health Assessment Questionnaire (HAQ), the magnitude of benefit in functional capacity compared with placebo reached the MCID (HAQ change of ≥ 0.22) for all but one study of adalimumab (which found a between-group difference of 0.2).^a^ The magnitude of benefit for functional capacity (between-group difference for improvement in HAQ) ranged from 0.2 to 0.3 for adalimumab, 0.5 to 1.1 for etanercept, 0.34 to 0.4 for golimumab, and 0.4 to 0.6 for infliximab.

a Genovese MC, Mease PJ, Thomson GT, et al. Safety and efficacy of adalimumab in treatment of patients with psoriatic arthritis who had failed disease modifying antirheumatic drug therapy. J Rheumatol 2007;34(5):1040–50.

† The magntude of benefit in quality of life reached the MCID for the SF-36 PCS for all five studies that reported the PCS and ranged from 2.9 to 7.9 for adalimumab, 8.6 for etanercept, 5.9 to 7.2 for golimumab, and 6.4 to 8 for infliximab.

‡ Low for golimumab and moderate for adalimumab, etanercept and infliximab.

Data are quite limited for PsA patients, and the evidence is insufficient to draw firm conclusions on comparative efficacy, effectiveness, and harms of either oral or biologic DMARDs in this condition.

## Key Findings

No head-to-head controlled trials meeting inclusion criteria exist for any drugs in this review for treating patients with PsA. Two cohort studies with low evidence indicated that the combination of an anti-tumor necrosis factor (TNF) (adalimumab, etanercept, or infliximab) with methotrexate (MTX) only was not different in treatment response43, 44 than treatment with anti-TNF only.

Table 17 gives a range for effect sizes for commonly reported measures, including American College of Rheumatology 20 percent improvement from baseline to endpoint (ACR 20), Health Assessment Questionnaire (HAQ), and Short Form 36 Physical Component Score (SF-36 PCS). For the oral DMARDs, including sulfasalazine and methotrexate, sparse data are available. Parenteral high-dose MTX and sulfasalazine improved physician assessment of disease activity compared with placebo.40 For both of these comparisons, minimally clinically important differences (MCIDs) cannot be determined. Additionally, patients taking leflunomide had higher response rates and better quality-of-life outcomes than those taking placebo, however these reached MCID by ACR 20, but not by the Psoriasis Area and Severity Index (PASI) or by the HAQ scales.41, 42

Table 17 Comparison of effect sizes^*^ from placebo-controlled trials for ACR 20, HAQ, and SF-36 PCS by Drug

Drug | Studies/Participants | ACR 20 (% of Subjects Achieving) | HAQ (Mean Improvement) | SF-36 PCS (Mean Improvement)
Oral DMARDs
Leflunomide | 1 RCT/190 | 36 | 0.14 | NR
Methotrexate | 1 RCT/37 | NR | NR | NR
Sulfasalazine | 1 SER/1,022 | NR | NR | NR
Biologic DMARDS
Adalimumab | 2 RCTs/415 | 39 to 57 | 0.2 to 0.3 | 2.9 to 7.9
Etanercept | 3 RCTs/633 | 59 to 65 | 0.5 to 1.1 | 8.6
Golimumab | 1 RCT/405 | 45 to 51 | 0.34 to 0.4 | 5.9 to 7.2
Infliximab | 2RCTs,1SER/673 | 58 to 62 | 0.4 to 0.6 | 6.4 to 8

ACR 20 = American College of Rheumatology 20 percent improvement from baseline to endpoint; HAQ = Health Assessment Questionnaire; PCS = physical component score; SF-36 = Medical Outcomes Study Short Form 36; RCT = Randomized controlled trial; SER = systematic evidence review

* Effect sizes represent the range of point estimates from individual studies for the absolute difference between drug and placebo. Minimally Clinically Important Differences (MCIDs): ACR 20 is 20% minimal improvement; ACR 50/70 considered more clinically significant; HAQ >=0.22 change, SF36 PCS>= 2 standard error of the mean (SEM).

Evidence supports the efficacy of adalimumab, etanercept, golimumab, and infliximab for the treatment of PsA.46–56 However, evidence is insufficient to draw firm conclusions about the comparative efficacy, effectiveness, functional status, health-related quality of life, or tolerability of abatacept, adalimumab, anakinra, certolizumab, golimumab, etanercept, infliximab, rituximab, and tocilizumab for treating PsA.

As noted in Table 17, DMARDs, including adalimumab, etanercept, golimumab, and infliximab, appear to achieve similar ACR 20, HAQ, and SF-36 PCS scores when compared with placebo.

Information is generally insufficient to compare drugs for PsA with respect to harms, tolerability, adverse events, and adherence. The available studies include two relatively small prospective cohort studies and placebo-controlled studies; no head-to-head studies meeting inclusion criteria have been published.

In terms of applicability to patient subgroups, the studies are generally multicenter involving adults with diagnosed PsA. Prior medications tried before these studies were variable, but, in general, patients had failed a DMARD prior to starting any of the biologic agents. It is also important to note that the diagnostic criteria for PsA before the publication of the CASPAR criteria were not validated, which could lead to enrollment of patients that were not explicitly defined.

This report’s findings did not reveal any differences with current standard of care. DMARDs are needed in most cases for PsA treatment. MTX is commonly used and useful treating psoriasis in addition to arthropathy. However, when chronic disease continues to be active despite use of MTX, biologics are indicated and most often given in combination with oral DMARDs (e.g., MTX).21 Comparative effectiveness remains lacking among and between oral and biologic DMARDs.

## Future Research

We have identified several areas needing further research to help clinicians and researchers arrive at stronger conclusions on the comparative efficacy, effectiveness, quality of life, and harms of medications for PsA. For this condition, the available evidence is limited to two head-to-head cohort studies and placebo-controlled trials. The quality of studies on oral DMARDs is sparse and fraught with methodological issues. Head-to-head RCTs are required to establish the comparative efficacy and safety of different treatment strategies to determine the best therapy to prevent or minimize debilitating joint damage. Specifically, we need better studies that include head-to-head comparisons particularly between oral DMARDS and biologics versus DMARDS and with combination therapies of different types. Furthermore, head-to-head RCTs have to determine the comparative effectiveness and safety of biologic DMARDs for the treatment of PsA. More generally, the issues of effectiveness, subgroups, and use in ordinary clinical settings highlighted for RA warrant attention for PsA as well. Future studies should also include outcome measures for axial disease, enthesitis, and dactylitis along with more traditional joint counts. An organized effort to identify diagnostic markers and surrogate endpoints for PsA is also a major unmet need and will help better define and treat this population.