# Strength of Evidence Tables

Table I-1 Strength of evidence for disease activity and radiographic progression

Table I-2 Strength of evidence for functional capacity and quality of life outcomes

Table I-3 Strength of evidence for adverse events