# Characteristics of Studies with Poor Internal Validity

Study | Design | Sample Size | Intervention | Reason for Exclusion
Atteno et al., 2010^1^ | Open-label RCT | 100 | Adalimumab Etanercept Infliximab | No blinding; no ITT analysis; high risk of selection bias and measurement bias
Saad et al., 2010^2^ | Observational | 596 | Adalimumab Etanercept Infliximab | High LTF
Virkki et al., 2010^3^ | Observational | 127 | Etanercept Infliximab | High LTF; completers analysis

ITT = intention to treat; LTF = loss to followup; RCT = randomized controlled trial

## References

1 Atteno M, Peluso R, Costa L, et al. Comparison of effectiveness and safety of infliximab, etanercept, and adalimumab in psoriatic arthritis patients who experienced an inadequate response to previous disease-modifying antirheumatic drugs. Clin Rheumatol. 2010/01/13 ed. 2010:399-403.
2 Saad AA, Ashcroft DM, Watson KD, et al. Improvements in quality of life and functional status in patients with psoriatic arthritis receiving anti-tumor necrosis factor therapies. Arthritis Care Res (Hoboken). 2010/04/15 ed. 2010:345-53.
3 Virkki LM, Sumathikutty BC, Aarnio M, et al. Biological Therapy for Psoriatic Arthritis in Clinical Practice: Outcomes Up to 2 Years. Journal of Rheumatology. 2010:2362-8. [pmid: 20716655].