# Evidence Tables

## Index of Studies Included by Key Question

### Key Question 1

#### RCTs and other studies (Evidence Table 1)

- Antoni, 2005 (IMPACT 2)1
- Antoni, 2005 (IMPACT)2
- Genovese, 2007^3^
- Kaltwasser, 2004^4^
- Kavanaugh, 2006 (IMPACT)5 – found under Antoni, 2005
- Kavanaugh, 2006 (IMPACT2)6
- Kavanaugh, 2009^7^
- Kristensen, 2008^8^
- Mease, 2000^9^
- Mease, 2004^10^
- Mease, 2005 (ADEPT) 11
- Mease, 2006^12^–found under Mease 2004
- Nash, 2006^13^–found under Kaltwasser 2004
- Saad, 2010^14^
- Van der Heijde, 2007^15^–found under Kavanaugh, 2006
- Willkens, 1984^16^

#### Systematic Reviews and Meta-analyses (Evidence Table 2)

- Jones, 2000^17^
- Ravindran, 2008^18^
- Woolacott, 2006^19^

### Key Question 2

#### RCTs and other studies (Evidence Table 1)

- Antoni, 2005 (IMPACT) 2
- Antoni, 2005 (IMPACT 2)1
- Genovese, 2007^3^
- Gladman, 2007(ADEPT) 20
- Kaltwasser, 2004^4^
- Kavanaugh, 2006 5 – found under Antoni, 2005
- Kavanaugh, 2006^6^
- Kavanaugh, 2006 21
- Kavanaugh, 2009^7^
- Kristensen, 2008^8^
- Mease, 2000^9^
- Mease, 2004^10^
- Mease, 2005^22^
- Mease, 2005 (ADEPT) 11
- Mease, 2006^12^ – found under Mease 2004
- Mease, 2010^23^
- Nash, 2006^13^ – found under Kaltwasser 2004
- Saad, 2009^24^
- Saad, 2010^14^
- Van der Heijde, 2007^15^ – found under Kavanaugh, 2006
- Willkens, 1984^16^

#### Systematic Reviews and Meta-analyses (Evidence Table 2)

- Ravindran, 2008

### Key Question 3

#### RCTs and other studies (Evidence Table 1)

- Antoni, 2005 (IMPACT 2)
- Antoni, 2005 (IMPACT) 2
- Genovese, 2007^3^
- Kaltwasser, 2004^4^
- Kavanaugh, 2009^7^
- Kristensen, 2008^8^
- Mease, 2000^9^
- Mease, 2005^22^
- Mease, 2006 – found under Mease 2004
- Saad, 2009^24^

#### Systematic Reviews and Meta-analyses (Evidence Table 2)

- Ravindran, 2008^18^

## Evidence Tables

Evidence Table 1 Randomized controlled trials and observational studies

Evidence Table 2 Systematic reviews and meta-analyses

## Abbreviations

ACR: American College of Rheumatology
ADA: adalimumab
AEs: adverse events
AIDS: acquired immunodeficiency syndrome
AIMS: Arthritis Impact Measurement Scales
ANA: anakinra
ARA: American Rheumatism Association criteria (pre-1987)
AS: ankylosing spondylitis
ASHI: Arthritis-Specific Health Index (Medical Outcomes Study Short Form SF-36 Arthritis-specific Health Index)
AUC: area under the curve
BUD: budesonide
Ccs: corticosteroids
CFS: chronic fatigue syndrome
CHF: coronary heart failure
Cm: centimeters
Combo: combination therapy
CI: confidence interval
CHD: coronary heart disease
COPD: Chronic Obstructive Pulmonary Disease
CRP: C-reactive protein
CVD: cardiovascular disease
CXT: cyclophosamide
CYP: cyclosporine
Ds: days
DM: diabetes mellitus
DAS: Disease Activity Score
DMARD: disease modifying antirheumatic drug
D-HAQ: Dutch version of the Health Assessment Questionnaire (HAQ)
EQ-5D–: Quality of Life Questionnaire
ESR: erythrocyte sedimentation rate
ETA: etanercept
EULAR: European League against Rheumatism
EuroQol EQ-5D: European Quality of Life Questionnaire
EuroQOL VAS: European Quality of Life Visual Analogue Scale
GI: gastrointestinal
HAQ: Health Assessment Questionnaire
HAQ-DI: Disability Index of the Heath Assessment Questionnaire (HAQ)
HIV: Human immunodeficiency virus
HLA-DR4: Human immune-response, D-related antigen encoded by the D locus on chromosome 6
HR: hazard ratio
HRQOL: health related quality of life
ICD: International Classification of Diseases
INF: infliximab
ISRs: injection site reactions
ITT: intention to treat
JRA: juvenile rheumatoid arthritis
HCQ: hydroxychloroquine
JSN: joint space narrowing
LEF: leflunomide
MTX: methotrexate
Mg: milligrams
mSharp Scale: Modified Sharp Method for Scoring Radiographs
mos: months
MHAQ: Modified Health Assessment Questionnaire
NSAIDs: non-steroidal anti-inflammatory drugs
NSFHS: National Survey of Functional Health Status
NA: not applicable
NMSC: non-melanoma skin cancer
NR: not reported
NS: not significant
NYHA: New York Heart Association
OA: osteoarthritis
OR: odds ratio
OMERACT: Outcome Measures in Rheumatology Clinical Trials
PASI: Psoriasis Area and Severity Index
PNL: prednisolone
PRED: prednisone
PsA: psoriatic arthritis
PsARC: Psoriatic Arthritis Response Scale
Pt: patient
PY: person-year
QOL: quality of life
RCT: randomized controlled trial
RAI: Ritchie Articular Index
RA: rheumatoid arthritis
RDS: radiological damage score
RF: rheumatoid factor
RIT: rituximab
RR: risk ratio
SAEs: serious adverse events
SAARDs: slow-acting anti-rheumatic drugs
SCC: squamous cell carcinoma
SD: standard deviation
SF-36: Medical Outcomes Study Short Form 36 Health Survey
SJC: swollen joint count
SHS: Sharp/van der Heijde Method (SHS) for Scoring Radiographs
SIR: standardized incidence ratio
SLE: Systemic Lupus Erythematosus
SMR: standardized morbidity ratio
SSZ: sulfasalazine
SSTG: South Swedish Arthritis Treatment Group
TB: Tuberculosis
TIM: targeted immune modulator
TJC: tender joint count
TNF: tumor necrosis factor
Txt: treatment
URTI: upper respiratory tract infection
UTI: urinary tract infection
vs.: versus
yrs: years
w/: with
w/in: with in
w/o: with out

## References

1 Antoni C, Krueger GG, de Vlam K, et al. Infliximab improves signs and symptoms of psoriatic arthritis: results of the IMPACT 2 trial. Ann Rheum Dis. Aug. 2005;64(8):1150-7. [pmid: 15677701].
2 Antoni CE, Kavanaugh A, Kirkham B, et al. Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum. Apr. 2005;52(4):1227-36. [pmid: 15818699].
3 Genovese MC, Mease PJ, Thomson GT, et al. Safety and efficacy of adalimumab in treatment of patients with psoriatic arthritis who had failed disease modifying antirheumatic drug therapy. J Rheumatol. 2007:1040-50. [pmid: 17444593].
4 Kaltwasser J, Nash P, Gladman D, et al. Efficacy and Safety of Leflunomide in the Treatment of Psoriatic Arthritis and Psoriasis: a Multinational, Double-Blind, Randomized, Placebo-Controlled Clinical Trial. Arthritis and rheumatism. 2004;50(6):1393-50.
5 Kavanaugh A, Antoni CE, Gladman D, et al. The Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT): results of radiographic analyses after 1 year. Ann Rheum Dis. Aug. 2006;65(8):1038-43. [pmid: 16439444].
6 Kavanaugh A, Antoni C, Krueger GG, et al. Infliximab improves health related quality of life and physical function in patients with psoriatic arthritis. Ann Rheum Dis. Apr. 2006;65(4):471-7. [pmid: 16096330].
7 Kavanaugh A, McInnes I, Mease P, et al. Golimumab, a new human tumor necrosis factor alpha antibody, administered every four weeks as a subcutaneous injection in psoriatic arthritis: Twenty-four-week efficacy and safety results of a randomized, placebo-controlled study. Arthritis Rheum. 2009:976-86. [pmid: 19333944].
8 Kristensen LE, Gulfe A, Saxne T, et al. Efficacy and tolerability of anti-tumour necrosis factor therapy in psoriatic arthritis patients: results from the South Swedish Arthritis Treatment Group register. Ann Rheum Dis. 2008:364-9. [pmid: 17644547].
9 Mease PJ, Goffe BS, Metz J, et al. Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet. Jul. 29. 2000;356(9227):385-90. [pmid: 10972371].
10 Mease PJ, Kivitz AJ, Burch FX, et al. Etanercept treatment of psoriatic arthritis: safety, efficacy, and effect on disease progression. Arthritis Rheum. 2004:2264-72. [pmid: 15248226].
11 Mease PJ, Gladman DD, Ritchlin CT, et al. Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. 2005:3279-89. [pmid: 16200601].
12 Mease PJ, Kivitz AJ, Burch FX, et al. Continued inhibition of radiographic progression in patients with psoriatic arthritis following 2 years of treatment with etanercept. J Rheumatol. 2006:712-21. [pmid: 16463435].
13 Nash P, Thaci D, Behrens F, et al. Leflunomide improves psoriasis in patients with psoriatic arthritis: an in-depth analysis of data from the TOPAS study. Dermatology. 2006;212(3):238-49. [pmid: 16549920].
14 Saad AA, Ashcroft DM, Watson KD, et al. Efficacy and safety of anti-TNF therapies in psoriatic arthritis: an observational study from the British Society for Rheumatology Biologics Register. Rheumatology. (Oxford). 2010:697-705.
15 van der Heijde D, Kavanaugh A, Gladman DD, et al. Infliximab inhibits progression of radiographic damage in patients with active psoriatic arthritis through one year of treatment: Results from the induction and maintenance psoriatic arthritis clinical trial 2. Arthritis Rheum. 2007:2698-707. [pmid: 17665424].
16 Willkens RF, Williams HJ, Ward JR, et al. Randomized, double-blind, placebo controlled trial of low-dose pulse methotrexate in psoriatic arthritis. Arthritis Rheum. 1984/04/01 ed. 1984:376-81.
17 Jones G, Crotty M, Brooks P. Interventions for treating psoriatic arthritis. Cochrane Database Syst Rev. 2000;(3):CD000212.
18 Ravindran V, Scott DL, Choy EH. A systematic review and meta-analysis of efficacy and toxicity of disease modifying anti-rheumatic drugs and biological agents for psoriatic arthritis. Ann Rheum Dis. 2008:855-9. [pmid: 17827183].
19 Woolacott N, Bravo Vergel Y, Hawkins N, et al. Etanercept and infliximab for the treatment of psoriatic arthritis: a systematic review and economic evaluation. Health Technol Assess. Sep. 2006;10(31):1-258. [pmid: 17083854].
20 Gladman DD, Mease PJ, Cifaldi MA, et al. Adalimumab improves joint-related and skin-related functional impairment in patients with psoriatic arthritis: patient-reported outcomes of the Adalimumab Effectiveness in Psoriatic Arthritis Trial. Ann Rheum Dis. 2007:163-8. [pmid: 17046964].
21 Kavanaugh A, Antoni C, Mease P, et al. Effect of infliximab therapy on employment, time lost from work, and productivity in patients with psoriatic arthritis. J Rheumatol. 2006;2254:9.
22 Mease PJ. Adalimumab: an anti-TNF agent for the treatment of psoriatic arthritis. Expert Opin Biol Ther. 2005:1491-504. [pmid: 16255652].
23 Mease PJ, Woolley JM, Singh A, et al. Patient-reported outcomes in a randomized trial of etanercept in psoriatic arthritis. J Rheumatol. 2010/04/17 ed. 2010:1221-7.
24 Saad AA, Ashcroft DM, Watson KD, et al. Persistence with anti-tumour necrosis factor therapies in patients with psoriatic arthritis: observational study from the British Society of Rheumatology Biologics Register. Arthritis Res Ther. 2009/04/10 ed. 2009:R52.