# Articles by Database Searched

## Reference Source: PubMed

1 Juvenile and adult systemic-onset Still’s disease. Lancet. Jul. 14. 1990;336(8707):92. [pmid: 1975330].
2 Double blind controlled phase III multicenter clinical trial with interferon gamma in rheumatoid arthritis. German Lymphokine Study Group. Rheumatol Int. 1992;12(5):175-85. [pmid: 1290019].
3 A randomized trial of hydroxychloroquine in early rheumatoid arthritis: the HERA Study. Am J Med. Feb. 1995;98(2):156-68. [pmid: 7847432].
4 Treatment methods. Nonsurgical treatment methods for diseases in multiple joints (polyarthritis). Scand J Rheumatol Suppl. 1999;110:7-14. [pmid: 10422546].
5 Etanercept and infliximab for rheumatoid arthritis. Drug Ther Bull. Jul. 2001;39(7):49-52. [pmid: 11471515].
6 One million U.S. adults may suffer from psoriatic arthritis. Dermatol Nurs. Jun. 2002;14(3):207-8.
7 Anakinra (Kineret) for rheumatoid arthritis. Med Lett Drugs Ther. Feb. 18. 2002;44(1124):18-9. [pmid: 11856953].
8 Summaries for patients. Tumor necrosis factor antagonists and heart failure. Ann Intern Med. May. 20. 2003;138(10):I48.
9 Is it true that vaccines may not be safe for people with rheumatoid arthritis (which I have)? Does that mean I shouldn’t get a flu shot?. Johns Hopkins Med Lett Health After. Oct. 17. 2004;50(8):8.
10 Summaries for patients. Abatacept for people with active rheumatoid arthritis. Ann Intern Med. Jun. 20. 2006;144(12):I18.
11 Rituximab and abatacept for rheumatoid arthritis. Drug Ther Bull. Aug. 2008;46(8):57-61. [pmid: 18687584].
12 The Chinese herbal remedy Tripterygium wilfordii Hook F in the treatment of rheumatoid arthritis. Ann Intern Med. Aug. 18. 2009;151(4):I-36.
13 New drug information: Simponi. Jaapa. Aug. 2009;22(8):13.
14 Abarca J, Malone DC, Armstrong EP, et al. Longitudinal analysis of the use of etanercept versus infliximab determined from medical chart audit. J Manag Care Pharm. Nov–Dec. 2004;10(6):538-42. [pmid: 15548126].
15 Abe K, Mitsuka T, Kanamori S, et al. Gynecomastia associated with low-dose methotrexate therapy for rheumatoid arthritis. Mod Rheumatol. 2007;17(6):511-3. [pmid: 18084706].
16 Abe T, Takeuchi T, Miyasaka N, et al. A multicenter, double-blind, randomized, placebo controlled trial of infliximab combined with low dose methotrexate in Japanese patients with rheumatoid arthritis. J Rheumatol. Jan. 2006;33(1):37-44. [pmid: 16395748].
17 Abedin M, Scheurich D, Reimold SC, et al. Acute coronary syndrome after infliximab infusion. Cardiol Rev. Jan–Feb. 2006;14(1):50-2. [pmid: 16371767].
18 Ablin JN, Boguslavski V, Aloush V, et al. Effect of anti-TNFalpha treatment on circulating endothelial progenitor cells (EPCs) in rheumatoid arthritis. Life Sci. Nov. 17. 2006;79(25):2364-9. [pmid: 16962143].
19 Aboulafia DM, Bundow D, Wilske K, et al. Etanercept for the treatment of human immunodeficiency virus-associated psoriatic arthritis. Mayo Clin Proc. Oct. 2000;75(10):1093-8. [pmid: 11040859].
20 Abramovits W, Arrazola P, Gupta AK. Enbrel (etanercept). Skinmed. Nov–Dec. 2004;3(6):333-5. [pmid: 15538082].
21 Acero J, Navarro-Cuellar C, Menarguez J, et al. Naso-maxillary non-Hodgkin lymphoma associated with methotrexate treatment in a patient with rheumatoid arthritis. J Oral Maxillofac Surg. Apr. 2006;64(4):708-11. [pmid: 16546655].
22 Adachi J, Cranney A, Goldsmith CH, et al. Intermittent cyclic therapy with etidronate in the prevention of corticosteroid induced bone loss. J Rheumatol. Oct. 1994;21(10):1922-6. [pmid: 7837160].
23 Adam DJ, Nawroz I, Petrie PW. Pyoderma gangrenosum severely affecting both hands. J Hand Surg [Br]. Dec. 1996;21(6):792-4.
24 Adebayo D, Popat R, Thjodleifsson B, et al. Granulomatous ileitis in a patient with ankylosing spondylitis. Nat Clin Pract Gastroenterol Hepatol. Jun. 2007;4(6):347-51. [pmid: 17541448].
25 Adhikesavan LG, Newman ED, Diehl MP, et al. American College of Rheumatology quality indicators for rheumatoid arthritis: benchmarking, variability, and opportunities to improve quality of care using the electronic health record. Arthritis Rheum. Dec. 15. 2008;59(12):1705-12. [pmid: 19035412].
26 Adisen E, Karaca F, Gurer MA. When there is no single best biological agent: psoriasis and psoriatic arthritis in the same patient responding to two different biological agents. Clin Exp Dermatol. Mar. 2008;33(2):164-6. [pmid: 18257837].
27 Adzic TN, Stojsic JM, Radosavljevic-Asic GD, et al. Multinodular pulmonary amyloidosis in primary Sjogren’s syndrome. Eur J Intern Med. Dec. 2008;19(8):e97-8. [pmid: 19046717].
28 Aeberli D, Oertle S, Mauron H, et al. Inhibition of the TNF-pathway: use of infliximab and etanercept as remission-inducing agents in cases of therapy-resistant chronic inflammatory disorders. Swiss Med Wkly. Jul. 27. 2002;132(29–30):414-22. [pmid: 12428187].
29 Aeberli D, Seitz M, Juni P, et al. Increase of peripheral CXCR3 positive T lymphocytes upon treatment of RA patients with TNF-alpha inhibitors. Rheumatology (Oxford). Feb. 2005;44(2):172-5. [pmid: 15509629].
30 Aerts NE, Ebo DG, Bridts CH, et al. Flow cytometric analysis of phospho-p38 mitogen-activated kinase (MAPK): p38 MAPK does not mediate the effect of adalimumab on peripheral T cell cytokine production in rheumatoid arthritis. Cytokine. Sep. 2009;47(3):178-84. [pmid: 19616965].
31 Agarwal PK, Gallaghar M, Murphy E, et al. Endogenous endophthalmitis in a rheumatoid patient on tumor necrosis factor alpha blocker. Indian J Ophthalmol. May–Jun. 2007;55(3):230-2. [pmid: 17456948].
32 Agarwal S, Zaman T, Handa R. Retention rates of disease-modifying anti-rheumatic drugs in patients with rheumatoid arthritis. Singapore Med J. 2009;50(7):686-92. [pmid: 19644623].
33 Agarwal SK, Maier AL, Chibnik LB, et al. Pattern of infliximab utilization in rheumatoid arthritis patients at an academic medical center. Arthritis Rheum. Dec. 15. 2005;53(6):872-8. [pmid: 16342095].
34 Aggarwal A, Panda S, Misra R. Effect of etanercept on matrix metalloproteinases and angiogenic vascular endothelial growth factor: a time kinetic study. Ann Rheum Dis. Jul. 2004;63(7):891-2. [pmid: 15194595].
35 Aggarwal P, Naik S, Mishra KP, et al. Correlation between methotrexate efficacy & toxicity with C677T polymorphism of the methylenetetrahydrofolate gene in rheumatoid arthritis patients on folate supplementation. Indian J Med Res. Nov. 2006;124(5):521-6. [pmid: 17213520].
36 Agirbasli M, Inanc N, Baykan OA, et al. The effects of TNF alpha inhibition on plasma fibrinolytic balance in patients with chronic inflammatory rheumatical disorders. Clin Exp Rheumatol. Sep–Oct. 2006;24(5):580-3. [pmid: 17181930].
37 Ahmadi-Simab K, Lamprecht P, Nolle B, et al. Successful treatment of refractory anterior scleritis in primary Sjogren’s syndrome with rituximab. Ann Rheum Dis. Jul. 2005;64(7):1087-8. [pmid: 15958765].
38 Ahmed M, Luggen M, Herman JH, et al. Hypertrophic pachymeningitis in rheumatoid arthritis after adalimumab administration. J Rheumatol. Nov. 2006;33(11):2344-6. [pmid: 16981287].
39 Ahmed MM, Mubashir E, Wolf RE, et al. Impact of treatment with infliximab on anticyclic citrullinated peptide antibody and rheumatoid factor in patients with rheumatoid arthritis. South Med J. Nov. 2006;99(11):1209-15. [pmid: 17195414].
40 Aida S, Okawa-Takatsuji M, Aotsuka S, et al. Calcitonin inhibits production of immunoglobulins, rheumatoid factor and interleukin-1 by mononuclear cells from patients with rheumatoid arthritis. Ann Rheum Dis. Apr. 1994;53(4):247-9. [pmid: 8203953].
41 Akai M, Ohno T, Kamura S, et al. Epidural abscess following septic arthritis in a rheumatoid patient. A case report. Spine. Jun. 1990;15(6):603-5. [pmid: 2402704].
42 Akay OM, Korkmaz C, Gulbas Z. Development of acute inflammatory arthritis by granulocyte-macrophage colony-stimulating factor during autologous stem cell transplantation for cryoglobulinemia. Rheumatol Int. Oct. 2007;27(12):1167-9. [pmid: 17429637].
43 Akritidis N, Papadopoulos A, Pappas G. Long-term follow-up of patients with adult-onset Still’s disease. Scand J Rheumatol. Sep–Oct. 2006;35(5):395-7. [pmid: 17062441].
44 Alarcon GS. Early rheumatoid arthritis: combination therapy of doxycycline plus methotrexate versus methotrexate monotherapy. Nat Clin Pract Rheumatol. Jun. 2006;2(6):296-7. [pmid: 16932705].
45 Al-Arfaj AS, Al-Saleh S. Adult-Onset Still’s disease in Saudi Arabia. Clin Rheumatol. 2001;20(3):197-200. [pmid: 11434473].
46 Alegre-Sancho JJ, Juanola X, Narvaez FJ, et al. Septic arthiritis due to Prevotella bivia in a patient with rheumatoid arthritis. Joint Bone Spine. 2000;67(3):228-9. [pmid: 10875323].
47 Alessandri C, Bombardieri M, Papa N, et al. Decrease of anti-cyclic citrullinated peptide antibodies and rheumatoid factor following anti-TNFalpha therapy (infliximab) in rheumatoid arthritis is associated with clinical improvement. Ann Rheum Dis. Oct. 2004;63(10):1218-21. [pmid: 15361374].
48 Aletaha D, Funovits J, Keystone EC, et al. Disease activity early in the course of treatment predicts response to therapy after one year in rheumatoid arthritis patients. Arthritis Rheum. Oct. 2007;56(10):3226-35. [pmid: 17907167].
49 Alex P, Szodoray P, Arthur E, et al. Influence of intraarticular corticosteroid administration on serum cytokines in rheumatoid arthritis. Clin Rheumatol. May. 2007;26(5):845-8. [pmid: 17021669].
50 Alex P, Szodoray P, Knowlton N, et al. Multiplex serum cytokine monitoring as a prognostic tool in rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2007;25(4):584-92. [pmid: 17888215].
51 Alexander D, Friedrich B, Abruzzese T, et al. The active form of leflunomide, HMR1726, facilitates TNF-alpha and IL-17 induced MMP-1 and MMP-3 expression. Cell Physiol Biochem. 2006;17(1–2):69-78. [pmid: 16543723].
52 Ali AA, Moatter T, Baig JA, et al. Polymorphism of HLA-DR and HLA-DQ in rheumatoid arthritis patients and clinical response to methotrexate--a hospital-based study. J Pak Med Assoc. Oct. 2006;56(10):452-6. [pmid: 17144392].
53 Alivernini S, Mazzotta D, Zoli A, et al. Leflunomide treatment in elderly patients with rheumatoid or psoriatic arthritis: retrospective analysis of safety and adherence to treatment. Drugs Aging. 2009;26(5):395-402. [pmid: 19552491].
54 Alkassab F. Overlap of systemic sclerosis and rheumatoid arthritis. J Rheumatol. Jul. 2007;34(7):1593-4. [pmid: 17611965].
55 Allanore Y, Bremont C, Kahan A, et al. Transient hyperthyroidism in a patient with rheumatoid arthritis treated by etanercept. Clin Exp Rheumatol. May–Jun. 2001;19(3):356-7. [pmid: 11407100].
56 Allanore Y, Sellam J, Batteux F, et al. Induction of autoantibodies in refractory rheumatoid arthritis treated by infliximab. Clin Exp Rheumatol. Nov–Dec. 2004;22(6):756-8. [pmid: 15638051].
57 Allantaz F, Chaussabel D, Stichweh D, et al. Blood leukocyte microarrays to diagnose systemic onset juvenile idiopathic arthritis and follow the response to IL-1 blockade. J Exp Med. Sep. 3. 2007;204(9):2131-44. [pmid: 17724127].
58 Almodovar R, Izquierdo M, Zarco P, et al. Pulmonary sarcoidosis in a patient with ankylosing spondylitis treated with infliximab. Clin Exp Rheumatol. Jan–Feb. 2007;25(1):99-101. [pmid: 17417999].
59 Almodovar R, Zarco P, Quiros FJ, et al. Infliximab treatment efficacy in lymphoedema associated with ankylosing spondylitis. Rheumatology (Oxford). Nov. 2004;43(11):1456. [pmid: 15502003].
60 al-Mughales J, Blyth TH, Hunter JA, et al. The chemoattractant activity of rheumatoid synovial fluid for human lymphocytes is due to multiple cytokines. Clin Exp Immunol. Nov. 1996;106(2):230-6. [pmid: 8918567].
61 Alonso-Bartolome P, Martinez-Taboada VM, Blanco R, et al. Insufficiency fractures of the tibia and fibula. Semin Arthritis Rheum. Jun. 1999;28(6):413-20. [pmid: 10406409].
62 Alshekhlee A, Basiri K, Miles JD, et al. Chronic inflammatory demyelinating polyneuropathy associated with tumor necrosis factor-alpha antagonists. Muscle Nerve. May. 2010;41(5):723-7. [pmid: 20405504].
63 Alstergren P, Larsson PT, Kopp S. Successful treatment with multiple intra-articular injections of infliximab in a patient with psoriatic arthritis. Scand J Rheumatol. Mar–Apr. 2008;37(2):155-7. [pmid: 18415775].
64 Altintop L, Cakar B, Hokelek M, et al. Strongyloides stercoralis hyperinfection in a patient with rheumatoid arthritis and bronchial asthma: a case report. Ann Clin Microbiol Antimicrob. 2010;9:27. [pmid: 20849666].
65 Alvarez-Rodriguez L, Carrasco-Marin E, Lopez-Hoyos M, et al. Interleukin-1RN gene polymorphisms in elderly patients with rheumatic inflammatory chronic conditions: Association of IL-1RN*2/2 genotype with polymyalgia rheumatica. Hum Immunol. Jan. 2009;70(1):49-54. [pmid: 19026700].
66 Aman S, Hakala M, Silvennoinen J, et al. Low incidence of osteoporosis in a two year follow-up of early community based patients with rheumatoid arthritis. Scand J Rheumatol. 1998;27(3):188-93. [pmid: 9645413].
67 Amenomori M, Migita K, Miyashita T, et al. Cytomegalovirus-associated hemophagocytic syndrome in a patient with adult onset Still’s disease. Clin Exp Rheumatol. Jan–Feb. 2005;23(1):100-2. [pmid: 15789896].
68 Amichai B, Gat A, Grunwald MH. Cutaneous hyperpigmentation during therapy with hydroxychloroquine. J Clin Rheumatol. Apr. 2007;13(2):113. [pmid: 17414546].
69 Amital H, Aamar S, Rubinow A. Bilateral septic arthritis of the hip: does etanercept play a role? A case report. J Bone Joint Surg Am. Nov. 2003;85-A(11):2205-6. [pmid: 14630854].
70 Amital H, Arnson Y, Chodick G, et al. Hepatotoxicity rates do not differ in patients with rheumatoid arthritis and psoriasis treated with methotrexate. Rheumatology (Oxford). Sep. 2009;48(9):1107-10. [pmid: 19578136].
71 Anandacoomarasamy A, Kannangara S, Barnsley L. Cutaneous vasculitis associated with infliximab in the treatment of rheumatoid arthritis. Intern Med J. Oct. 2005;35(10):638-40. [pmid: 16207269].
72 Anandarajah AP, Schwarz EM, Totterman S, et al. The effect of etanercept on osteoclast precursor frequency and enhancing bone marrow oedema in patients with psoriatic arthritis. Ann Rheum Dis. Mar. 2008;67(3):296-301. [pmid: 17967829].
73 Ancuta C, Ancuta E, Miu S, et al. Adalimumab therapy in patients with active rheumatoid arthritis. Rev Med Chir Soc Med Nat Iasi. Jul–Sep. 2009;113(3):710-5. [pmid: 20191820].
74 Andonopoulos AP, Meimaris N, Daoussis D, et al. Intra-articular anti-tumor necrosis factor alpha antibody in recalcitrant arthritis of Behcet’s disease. Clin Exp Rheumatol. Jul–Aug. 2003;21(4 Suppl 30):S57-8. [pmid: 14727465].
75 Andres E, Limbach FX, Goichot B, et al. Silent thyroiditis associated with etanercept in rheumatoid arthritis. Ann Rheum Dis. Jun. 2002;61(6):565. [pmid: 12006340].
76 Anelli MG, Torres DD, Manno C, et al. Improvement of renal function and disappearance of hepatitis B virus DNA in a patient with rheumatoid arthritis and renal amyloidosis following treatment with infliximab. Arthritis Rheum. Aug. 2005;52(8):2519-20. [pmid: 16052569].
77 Ang HT, Helfgott S. Do the clinical responses and complications following etanercept or infliximab therapy predict similar outcomes with the other tumor necrosis factor-alpha antagonists in patients with rheumatoid arthritis?. J Rheumatol. Nov. 2003;30(11):2315-8. [pmid: 14677170].
78 Anis A, Zhang W, Emery P, et al. The effect of etanercept on work productivity in patients with early active rheumatoid arthritis: results from the COMET study. Rheumatology (Oxford). 2009;48(10):1283-9. [pmid: 19690125].
79 Anolik JH, Ravikumar R, Barnard J, et al. Cutting edge: anti-tumor necrosis factor therapy in rheumatoid arthritis inhibits memory B lymphocytes via effects on lymphoid germinal centers and follicular dendritic cell networks. J Immunol. Jan. 15. 2008;180(2):688-92. [pmid: 18178805].
80 Antolin J, Azahara M, Hernandez C, et al. Tuberculous peritonitis after treatment with adalimumab. Scand J Infect Dis. 2008;40(8):677-8. [pmid: 18979608].
81 Antoni C, Dechant C, Hanns-Martin Lorenz PD, et al. Open-label study of infliximab treatment for psoriatic arthritis: clinical and magnetic resonance imaging measurements of reduction of inflammation. Arthritis Rheum. Oct. 15. 2002;47(5):506-12. [pmid: 12382299].
82 Antoni C, Krueger GG, de Vlam K, et al. Infliximab improves signs and symptoms of psoriatic arthritis: results of the IMPACT 2 trial. Ann Rheum Dis. Aug. 2005;64(8):1150-7. [pmid: 15677701].
83 Antoni CE, Kavanaugh A, Kirkham B, et al. Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum. Apr. 2005;52(4):1227-36. [pmid: 15818699].
84 Antoni CE, Kavanaugh A, van der Heijde D, et al. Two-year efficacy and safety of infliximab treatment in patients with active psoriatic arthritis: findings of the Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT). J Rheumatol. May. 2008;35(5):869-76. [pmid: 18381786].
85 Antoniou KM, Mamoulaki M, Malagari K, et al. Infliximab therapy in pulmonary fibrosis associated with collagen vascular disease. Clin Exp Rheumatol. Jan–Feb. 2007;25(1):23-8. [pmid: 17417986].
86 Antony T, Jose VM, Paul BJ, et al. Efficacy and safety of leflunomide alone and in combination with methotrexate in the treatment of refractory rheumatoid arthritis. Indian J Med Sci. Aug. 2006;60(8):318-26. [pmid: 16864918].
87 Aouba A, De Bandt M, Aslangul E, et al. Haemophagocytic syndrome in a rheumatoid arthritis patient treated with infliximab. Rheumatology (Oxford). Jun. 2003;42(6):800-2. [pmid: 12771439].
88 Aparicio AG, Munoz-Fernandez S, Bonilla G, et al. Report of an additional case of anti-tumor necrosis factor therapy and Listeria monocytogenes infection: comment on the letter by Gluck et al. Arthritis Rheum. Jun. 2003;48(6):1764-5. author reply 5–6. [pmid: 12794847].
89 Appel da Silva F, Appel da Silva MC, Romagna ES. Clinical images: Psoriatic arthritis mutilans. Arthritis Rheum. Jul. 2010;62(7):2159. [pmid: 20506494].
90 Appenzeller S, Castro GR, Costallat LT, et al. Adult-onset Still disease in southeast Brazil. J Clin Rheumatol. Apr. 2005;11(2):76-80. [pmid: 16357707].
91 Arabelovic S, Sam G, Dallal GE, et al. Preliminary evidence shows that folic acid fortification of the food supply is associated with higher methotrexate dosing in patients with rheumatoid arthritis. J Am Coll Nutr. Oct. 2007;26(5):453-5. [pmid: 17914133].
92 Aramaki T, Kawakami A, Iwamoto N, et al. Prediction of DAS28-CRP remission in patients with rheumatoid arthritis treated with tacrolimus at 6 months by baseline variables. Mod Rheumatol. 2009;19(6):652-6. [pmid: 19787419].
93 Ardalan MR, Shoja MM. Multiple myeloma presented as acute interstitial nephritis and rheumatoid arthritis-like polyarthritis. Am J Hematol. Apr. 2007;82(4):309-13. [pmid: 17022047].
94 Arend SM, Kuijper EJ, Allaart CF, et al. Cavitating pneumonia after treatment with infliximab and prednisone. Eur J Clin Microbiol Infect Dis. Aug. 2004;23(8):638-41. [pmid: 15278730].
95 Argyropoulou MI, Glatzouni A, Voulgari PV, et al. Magnetic resonance imaging quantification of hand synovitis in patients with rheumatoid arthritis treated with infliximab. Joint Bone Spine. Dec. 2005;72(6):557-61. [pmid: 16376805].
96 Arif S, Cox P, Afzali B, et al. Anti-TNFalpha therapy--killing two birds with one stone?. Lancet. 2010;375(9733):2278. [pmid: 20609973].
97 Arkachaisri T, Lehman TJ. Use of biologics in the treatment of childhood rheumatic diseases. Curr Rheumatol Rep. Aug. 2000;2(4):330-6. [pmid: 11123079].
98 Arman A, Yilmaz B, Coker A, et al. Interleukin-1 receptor antagonist (IL-1RN) and interleukin-1B gene polymorphisms in Turkish patients with rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2006;24(6):643-8. [pmid: 17207379].
99 Armstrong DJ, McCarron MT, Wright GD. Successful treatment of rheumatoid vasculitis-associated foot-drop with infliximab. J Rheumatol. Apr. 2005;32(4):759. author reply - 60. [pmid: 15801041].
100 Arnold EL, Khanna D, Paulus H, et al. Acute injection site reaction to intraarticular etanercept administration. Arthritis Rheum. Jul. 2003;48(7):2078-9. [pmid: 12847708].
101 Arvidson NG, Larsen A, Aaseth J, et al. Short-term effects of the TNFalpha antagonist infliximab on the acute phase reaction and activities of daily life in patients with rheumatoid arthritis. Scand J Clin Lab Invest. 2007;67(3):337-42. [pmid: 17454848].
102 Asanuma Y, Chung CP, Oeser A, et al. Serum osteoprotegerin is increased and independently associated with coronary-artery atherosclerosis in patients with rheumatoid arthritis. Atherosclerosis. Dec. 2007;195(2):e135-41. [pmid: 17570371].
103 Asherson RA, Pascoe L. Adult onset Still’s disease: response to Enbrel. Ann Rheum Dis. Sep. 2002;61(9):859-60. author reply 60. [pmid: 12176823].
104 Ashok D, Ayliffe WH, Kiely PD. Necrotizing scleritis associated with rheumatoid arthritis: long-term remission with high-dose infliximab therapy. Rheumatology (Oxford). Jul. 2005;44(7):950-1. [pmid: 15827040].
105 Ashok D, Dubey S, Tomlinson I. C-ANCA positive systemic vasculitis in a patient with rheumatoid arthritis treated with infliximab. Clin Rheumatol. Feb. 2008;27(2):261-4. [pmid: 17712519].
106 Askling J, Fored CM, Brandt L, et al. Risk and case characteristics of tuberculosis in rheumatoid arthritis associated with tumor necrosis factor antagonists in Sweden. Arthritis Rheum. Jul. 2005;52(7):1986-92. [pmid: 15986370].
107 Askling J, van Vollenhoven RF, Granath F, et al. Cancer risk in patients with rheumatoid arthritis treated with anti-tumor necrosis factor alpha therapies: does the risk change with the time since start of treatment?. Arthritis Rheum. 2009;60(11):3180-9. [pmid: 19877027].
108 Aslangul E, Perrot S, Durand E, et al. Successful etanercept treatment of constrictive pericarditis complicating rheumatoid arthritis. Rheumatology (Oxford). Dec. 2005;44(12):1581-3. [pmid: 16204377].
109 Aslanidis S, Pyrpasopoulou A, Douma S, et al. Is it safe to readminister tumor necrosis factor alpha antagonists following tuberculosis flare?. Arthritis Rheum. Jan. 2008;58(1):327-8. [pmid: 18163500].
110 Aslanidis S, Vassiliadis T, Pyrpasopoulou A, et al. Inhibition of TNFalpha does not induce viral reactivation in patients with chronic hepatitis C infection: two cases. Clin Rheumatol. Feb. 2007;26(2):261-4. [pmid: 16924392].
111 Asli B, Wechsler B, Lemaitre C. Inhibition of tumor necrosis factor alpha and ankylosing spondylitis. N Engl J Med. Jan. 23. 2003;348(4):359-61. author reply - 61. [pmid: 12540654].
112 Asplund MS, Hagberg H, Holmstrom M. Chemotherapy in severe nasal polyposis--a possible beneficial effect? A report of three cases. Rhinology. Sep. 2010;48(3):374-6. [pmid: 21038033].
113 Assimakopoulos SF, Michalopoulou S, Melachrinou M, et al. Primary Sjogren syndrome complicated by autoimmune hemolytic anemia and pure red cell aplasia. Am J Med Sci. Dec. 2007;334(6):493-6. [pmid: 18091373].
114 Assmann G, Pfreundschuh M, Voswinkel J. Rituximab in patients with rheumatoid arthritis and vasculitis-associated cutaneous ulcers. Clin Exp Rheumatol. Jan–Feb. 2010;28(1 Suppl 57):81-3. [pmid: 20412708].
115 Assous N, Gossec L, Dieude P, et al. Rituximab therapy in rheumatoid arthritis in daily practice. J Rheumatol. Jan. 2008;35(1):31-4. [pmid: 18176989].
116 Atchia II, Kidd CE, Bell RW. Rheumatoid arthritis-associated necrotizing scleritis and peripheral ulcerative keratitis treated successfully with infliximab. J Clin Rheumatol. Dec. 2006;12(6):291-3. [pmid: 17149060].
117 Atteno M, Peluso R, Costa L, et al. Comparison of effectiveness and safety of infliximab, etanercept, and adalimumab in psoriatic arthritis patients who experienced an inadequate response to previous disease-modifying antirheumatic drugs. Clin Rheumatol. 2010;29(4):399-403. [pmid: 20066450].
118 Atzeni F, Doria A, Ghirardello A, et al. Organ-specific autoantibodies in patients with rheumatoid arthritis treated with adalimumab: a prospective long-term follow-up. Autoimmunity. Feb. 2008;41(1):87-91. [pmid: 18176869].
119 Atzeni F, Sarzi-Puttini P, DePortu S, et al. In etanercept-treated psoriatic arthritis patients clinical improvement correlated with an increase of serum cortisol relative to other adrenal hormones. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):103-8. [pmid: 18328154].
120 Augustsson J, Eksborg S, Ernestam S, et al. Low-dose glucocorticoid therapy decreases risk for treatment-limiting infusion reaction to infliximab in patients with rheumatoid arthritis. Ann Rheum Dis. Nov. 2007;66(11):1462-6. [pmid: 17502359].
121 Augustsson J, Neovius M, Cullinane-Carli C, et al. Patients with rheumatoid arthritis treated with tumour necrosis factor antagonists increase their participation in the workforce: potential for significant long-term indirect cost gains (data from a population-based registry). Ann Rheum Dis. 2010;69(1):126-31. [pmid: 19470527].
122 Avancini-Dobrovic V, Vrbanic TS, Kukuljan M, et al. Spontaneous serial fractures of metatarsal bones in female patient with rheumatoid arthritis on long-term steroid therapy. Coll Antropol. Sep. 2010;34(3):1123-6. [pmid: 20977115].
123 Avriel A, Zeller L, Flusser D, et al. Coexistence of psoriatic arthritis and systemic lupus erythematosus. Isr Med Assoc J. Jan. 2007;9(1):48-9. [pmid: 17274359].
124 Ayaz NA, Demirkaya E, Bilginer Y, et al. Preventing tuberculosis in children receiving anti-TNF treatment. Clin Rheumatol. Apr. 2010;29(4):389-92. [pmid: 20084445].
125 Aydin T, Karacan I, Demir SE, et al. Bone loss in males with ankylosing spondylitis: its relation to sex hormone levels. Clin Endocrinol (Oxf). Oct. 2005;63(4):467-9. [pmid: 16181241].
126 Aydintug AO, D’Cruz D, Cervera R, et al. Low dose methotrexate treatment in adult Still’s disease. J Rheumatol. Mar. 1992;19(3):431-5. [pmid: 1578459].
127 Aydog E, Yesilli O, Sever A, et al. Dermatitis herpetiformis and rheumatoid arthritis. Saudi Med J. Jun. 2006;27(6):881-4. [pmid: 16758056].
128 Azuma T, Ishimaru H, Hatta K, et al. Improved response to infliximab after leukocytapheresis in a patent with rheumatoid arthritis. Mod Rheumatol. 2007;17(3):253-5. [pmid: 17564785].
129 Babacan T, Onat AM, Pehlivan Y, et al. Successful treatment of refractory adult Still’s disease and membranous glomerulonephritis with infliximab. Clin Rheumatol. Apr. 2010;29(4):423-6. [pmid: 20101429].
130 Bacquet-Deschryver H, Jouen F, Quillard M, et al. Impact of three anti-TNFalpha biologics on existing and emergent autoimmunity in rheumatoid arthritis and spondylarthropathy patients. J Clin Immunol. Sep. 2008;28(5):445-55. [pmid: 18587633].
131 Bae SC, Corzillius M, Kuntz KM, et al. Cost-effectiveness of low dose corticosteroids versus non-steroidal anti-inflammatory drugs and COX-2 specific inhibitors in the long-term treatment of rheumatoid arthritis. Rheumatology (Oxford). Jan. 2003;42(1):46-53. [pmid: 12509612].
132 Baer AN, Dessypris EN, Krantz SB. The pathogenesis of anemia in rheumatoid arthritis: a clinical and laboratory analysis. Semin Arthritis Rheum. Feb. 1990;19(4):209-23. [pmid: 2181669].
133 Baeten D, De Keyser F, Veys EM, et al. Tumour necrosis factor alpha independent disease mechanisms in rheumatoid arthritis: a histopathological study on the effect of infliximab on rheumatoid nodules. Ann Rheum Dis. May. 2004;63(5):489-93. [pmid: 15082477].
134 Baeten D, Van Damme N, Van den Bosch F, et al. Impaired Th1 cytokine production in spondyloarthropathy is restored by anti-TNFalpha. Ann Rheum Dis. Aug. 2001;60(8):750-5. [pmid: 11454638].
135 Bagalas V, Kioumis I, Argyropoulou P, et al. Visceral leishmaniasis infection in a patient with rheumatoid arthritis treated with etanercept. Clin Rheumatol. Aug. 2007;26(8):1344-5. [pmid: 16865310].
136 Baghai M, Osmon DR, Wolk DM, et al. Fatal sepsis in a patient with rheumatoid arthritis treated with etanercept. Mayo Clin Proc. Jun. 2001;76(6):653-6. [pmid: 11393506].
137 Baig MA, Aksoy T, McClain D, et al. Calciphylaxis in a hemodialysis patient on corticosteroids and etanercept for psoriatic arthritis. J Clin Rheumatol. Mar. 2010;16(2):92-3. [pmid: 20130476].
138 Bakewell C, Dugowson C. Images in clinical medicine. Baker’s cyst in a patient with rheumatoid arthritis. N Engl J Med. Sep. 10. 2009;361(11):1098. [pmid: 19741231].
139 Bakland G, Nossent H. Acute myelogenous leukaemia following etanercept therapy. Rheumatology (Oxford). Jul. 2003;42(7):900-1. [pmid: 12826706].
140 Balandraud N, Guis S, Baptiste Meynard J, et al. Long-term treatment with methotrexate or tumor necrosis factor alpha inhibitors does not increase epstein-barr virus load in patients with rheumatoid arthritis. Arthritis Rheum. Jun. 15. 2007;57(5):762-7. [pmid: 17530675].
141 Balanescu A, Radu E, Nat R, et al. Early and late effect of infliximab on circulating dendritic cells phenotype in rheumatoid arthritis patients. Int J Clin Pharmacol Res. 2005;25(1):9-18. [pmid: 15864873].
142 Balbir-Gurman A, Guralnik L, Best LA, et al. Accelerated pulmonary nodulosis and sterile pleural effusion in a patient with psoriatic arthropathy during methotrexate therapy: a case report. J Clin Rheumatol. Feb. 2009;15(1):29-30. [pmid: 18679135].
143 Bambery P, Thomas RJ, Malhotra HS, et al. Adult onset Still’s disease: clinical experience with 18 patients over 15 years in northern India. Ann Rheum Dis. Apr. 1992;51(4):529-32. [pmid: 1586255].
144 Bandelier C, Guerne PA, Genevay S, et al. Clinical experience with mycophenolate mofetil in systemic autoimmune conditions refractory to common immunosuppressive therapies. Swiss Med Wkly. Jan. 24. 2009;139(3–4):41-6. [pmid: 19169902].
145 Bang LM, Keating GM. Adalimumab: a review of its use in rheumatoid arthritis. BioDrugs. 2004;18(2):121-39. [pmid: 15046527].
146 Bankhurst AD. Etanercept and methotrexate combination therapy. Clin Exp Rheumatol. Nov–Dec. 1999;17(6 Suppl 18):S69-72. [pmid: 10589361].
147 Baraliakos X, Brandt J, Listing J, et al. Outcome of patients with active ankylosing spondylitis after two years of therapy with etanercept: clinical and magnetic resonance imaging data. Arthritis Rheum. Dec. 15. 2005;53(6):856-63. [pmid: 16342093].
148 Baraliakos X, Davis J, Tsuji W, et al. Magnetic resonance imaging examinations of the spine in patients with ankylosing spondylitis before and after therapy with the tumor necrosis factor alpha receptor fusion protein etanercept. Arthritis Rheum. Apr. 2005;52(4):1216-23. [pmid: 15818694].
149 Baraliakos X, Listing J, Rudwaleit M, et al. Radiographic progression in patients with ankylosing spondylitis after 2 years of treatment with the tumour necrosis factor alpha antibody infliximab. Ann Rheum Dis. Oct. 2005;64(10):1462-6. [pmid: 15778240].
150 Barber J, Sheeran T, Mulherin D. Anti-tumour necrosis factor treatment in a patient with anorexia nervosa and juvenile idiopathic arthritis. Ann Rheum Dis. May. 2003;62(5):490-1. [pmid: 12695170].
151 Bargagli E, Galeazzi M, Rottoli P. Infliximab treatment in a patient with rheumatoid arthritis and pulmonary fibrosis. Eur Respir J. Oct. 2004;24(4):708. [pmid: 15459153].
152 Barra L, Pope JE, Payne M. Real-world anti-tumor necrosis factor treatment in rheumatoid arthritis, psoriatic arthritis, and ankylosing spondylitis: cost-effectiveness based on number needed to treat to improve health assessment questionnaire. J Rheumatol. Jul. 2009;36(7):1421-8. [pmid: 19487267].
153 Barrera P, Oyen WJ, Boerman OC, et al. Scintigraphic detection of tumour necrosis factor in patients with rheumatoid arthritis. Ann Rheum Dis. Sep. 2003;62(9):825-8. [pmid: 12922953].
154 Barrera P, van der Laken CJ, Boerman OC, et al. Radiolabelled interleukin-1 receptor antagonist for detection of synovitis in patients with rheumatoid arthritis. Rheumatology (Oxford). Aug. 2000;39(8):870-4. [pmid: 10952741].
155 Bartelds GM, Wijbrandts CA, Nurmohamed MT, et al. Clinical response to adalimumab: relationship to anti-adalimumab antibodies and serum adalimumab concentrations in rheumatoid arthritis. Ann Rheum Dis. Jul. 2007;66(7):921-6. [pmid: 17301106].
156 Barthel HR. Rapid remission of treatment-resistant ankylosing spondylitis with etanercept--a drug for refractory ankylosing spondylitis?. Arthritis Rheum. Aug. 2001;45(4):404. [pmid: 11501730].
157 Bartke U, Venten I, Kreuter A, et al. Human immunodeficiency virus-associated psoriasis and psoriatic arthritis treated with infliximab. Br J Dermatol. Apr. 2004;150(4):784-6. [pmid: 15099388].
158 Bartolucci P, Ramanoelina J, Cohen P, et al. Efficacy of the anti-TNF-alpha antibody infliximab against refractory systemic vasculitides: an open pilot study on 10 patients. Rheumatology (Oxford). Oct. 2002;41(10):1126-32. [pmid: 12364631].
159 Barton A, Myerscough A, John S, et al. A single nucleotide polymorphism in exon 1 of cytotoxic T-lymphocyte-associated-4 (CTLA-4) is not associated with rheumatoid arthritis. Rheumatology (Oxford). Jan. 2000;39(1):63-6. [pmid: 10662875].
160 Barton P, Jobanputra P, Wilson J, et al. The use of modelling to evaluate new drugs for patients with a chronic condition: the case of antibodies against tumour necrosis factor in rheumatoid arthritis. Health Technol Assess. Mar. 1. 2004;8(11):iii-91.
161 Bartram D, Sheeran T, Price T, et al. Anti-tumour necrosis factor therapy in the West Midlands. Rheumatology (Oxford). Mar. 2004;43(3):400. author reply -1. [pmid: 14963219].
162 Bas S, Gauthier BR, Spenato U, et al. CD14 is an acute-phase protein. J Immunol. Apr. 1. 2004;172(7):4470-9. [pmid: 15034063].
163 Baskan BM, Sivas F, Alemdaroglu E, et al. Association of bone mineral density and vertebral deformity in patients with rheumatoid arthritis. Rheumatol Int. Apr. 2007;27(6):579-84. [pmid: 17287933].
164 Bassetti S, Wasmer S, Hasler P, et al. Staphylococcus aureus in patients with rheumatoid arthritis under conventional and anti-tumor necrosis factor-alpha treatment. J Rheumatol. Nov. 2005;32(11):2125-9. [pmid: 16265689].
165 Bathon JM, Fleischmann RM, Van der Heijde D, et al. Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. J Rheumatol. Feb. 2006;33(2):234-43. [pmid: 16465653].
166 Bathon JM, Martin RW, Fleischmann RM, et al. A comparison of etanercept and methotrexate in patients with early rheumatoid arthritis. N Engl J Med. Nov. 30. 2000;343(22):1586-93. [pmid: 11096165].
167 Batsis JA, Phy MP. West Nile virus meningitis in a chronic immunosuppressed patient with rheumatoid arthritis. Clin Rheumatol. Sep. 2005;24(5):548-50. [pmid: 15856365].
168 Bauer AS, Blazar PE, Earp BE, et al. Mycobacterial hand infections occurring postoperatively in patients treated with tumor necrosis factor-alpha inhibitors for inflammatory arthritis: report of three cases. J Hand Surg Am. Jan. 2010;35(1):104-8. [pmid: 20117311].
169 Baumgartner SW, Fleischmann RM, Moreland LW, et al. Etanercept (Enbrel) in patients with rheumatoid arthritis with recent onset versus established disease: improvement in disability. J Rheumatol. Aug. 2004;31(8):1532-7. [pmid: 15290731].
170 Bayer M, Stepan J, Nemcova D, et al. Juvenile chronic arthritis--bone mineral density in relation to corticosteroid therapy. Acta Univ Carol [Med] (Praha). 1994;40(1–4):33-5.
171 Bejarano V, Quinn M, Conaghan PG, et al. Effect of the early use of the anti-tumor necrosis factor adalimumab on the prevention of job loss in patients with early rheumatoid arthritis. Arthritis Rheum. 2008;59(10):1467-74. [pmid: 18821658].
172 Bejot Y, Osseby GV, Ben Salem D, et al. Bilateral optic neuropathy revealing Sjogren’s syndrome. Rev Neurol (Paris). Dec. 2008;164(12):1044-7. [pmid: 18808771].
173 Belknap R, Reves R, Burman W. Immune reconstitution to Mycobacterium tuberculosis after discontinuing infliximab. Int J Tuberc Lung Dis. Sep. 2005;9(9):1057-8. [pmid: 16158902].
174 Bellisai F, Giannitti C, Donvito A, et al. Combination therapy with cyclosporine A and anti-TNF-alpha agents in the treatment of rheumatoid arthritis and concomitant hepatitis C virus infection. Clin Rheumatol. Jul. 2007;26(7):1127-9. [pmid: 17143590].
175 Belostocki K, Pricop L, Redecha PB, et al. Infliximab treatment shifts the balance between stimulatory and inhibitory Fcgamma receptor type II isoforms on neutrophils in patients with rheumatoid arthritis. Arthritis Rheum. Feb. 2008;58(2):384-8. [pmid: 18240208].
176 Bender NK, Heilig CE, Droll B, et al. Immunogenicity, efficacy and adverse events of adalimumab in RA patients. Rheumatol Int. Jan. 2007;27(3):269-74. [pmid: 17006705].
177 Ben-Horin S, Goldstein I, Koltakov A, et al. The effect of blockade of tumor necrosis factor alpha on VLA-1+ T-cells in rheumatoid arthritis patients. J Clin Immunol. Nov. 2007;27(6):580-8. [pmid: 17891451].
178 Benito-Garcia E, Heller JE, Chibnik LB, et al. Dietary caffeine intake does not affect methotrexate efficacy in patients with rheumatoid arthritis. J Rheumatol. Jul. 2006;33(7):1275-81. [pmid: 16821266].
179 Bennett AN, Peterson P, Zain A, et al. Adalimumab in clinical practice. Outcome in 70 rheumatoid arthritis patients, including comparison of patients with and without previous anti-TNF exposure. Rheumatology (Oxford). Aug. 2005;44(8):1026-31. [pmid: 15870150].
180 Bennett AN, Wong M, Zain A, et al. Adalimumab-induced asthma. Rheumatology (Oxford). Sep. 2005;44(9):1199-200. [pmid: 15870147].
181 Benucci M, Li GF, Del Rosso A, et al. Adalimumab (anti-TNF-alpha) therapy to improve the clinical course of adult-onset Still’s disease: the first case report. Clin Exp Rheumatol. Sep–Oct. 2005;23(5):733. [pmid: 16173267].
182 Benucci M, Li Gobbi F, Fossi F, et al. Drug-induced lupus after treatment with infliximab in rheumatoid arthritis. J Clin Rheumatol. Feb. 2005;11(1):47-9. [pmid: 16357696].
183 Benucci M, Li Gobbi F, Saviola G, et al. Improved rheumatoid digital vasculitis in a patient treated with TNFalpha agent blocking (infliximab). Rheumatol Int. Oct. 2008;28(12):1253-5. [pmid: 18493770].
184 Benucci M, Manfredi M, Mecocci L. Effect of etanercept plus lamivudine in a patient with rheumatoid arthritis and viral hepatitis B. J Clin Rheumatol. Aug. 2008;14(4):245-6. [pmid: 18766129].
185 Benucci M, Saviola G, Baiardi P, et al. Anti-nucleosome antibodies as prediction factor of development of autoantibodies during therapy with three different TNFalpha blocking agents in rheumatoid arthritis. Clin Rheumatol. Jan. 2008;27(1):91-5. [pmid: 17929076].
186 Berard A, Solomon DH, Avorn J. Patterns of drug use in rheumatoid arthritis. J Rheumatol. Jul. 2000;27(7):1648-55. [pmid: 10914846].
187 Berg L, Lampa J, Rogberg S, et al. Increased peripheral T cell reactivity to microbial antigens and collagen type II in rheumatoid arthritis after treatment with soluble TNFalpha receptors. Ann Rheum Dis. Feb. 2001;60(2):133-9. [pmid: 11156546].
188 Berger A, Edelsberg J, Li TT, et al. Dose intensification with infliximab in patients with rheumatoid arthritis. Ann Pharmacother. Dec. 2005;39(12):2021-5. [pmid: 16288073].
189 Bergman J, Schjott J. Hepatitis caused by Lotus-f3?. Basic Clin Pharmacol Toxicol. May. 2009;104(5):414-6. [pmid: 19413662].
190 Bergstrom L, Yocum DE, Ampel NM, et al. Increased risk of coccidioidomycosis in patients treated with tumor necrosis factor alpha antagonists. Arthritis Rheum. Jun. 2004;50(6):1959-66. [pmid: 15188373].
191 Berkun Y, Abou Atta I, Rubinow A, et al. 2756GG genotype of methionine synthase reductase gene is more prevalent in rheumatoid arthritis patients treated with methotrexate and is associated with methotrexate-induced nodulosis. J Rheumatol. Aug. 2007;34(8):1664-9. [pmid: 17611986].
192 Bernatsky S, Ehrmann Feldman D. Discontinuation of methotrexate therapy in older patients with newly diagnosed rheumatoid arthritis: analysis of administrative health databases in Quebec, Canada. Drugs Aging. 2008;25(10):879-84. [pmid: 18808212].
193 Bernatsky S, Hudson M, Suissa S. Anti-rheumatic drug use and risk of serious infections in rheumatoid arthritis. Rheumatology (Oxford). 2007;46(7):1157-60. [pmid: 17478469].
194 Berookhim B, Fischer HD, Weinberg JM. Treatment of recalcitrant pemphigus vulgaris with the tumor necrosis factor alpha antagonist etanercept. Cutis. Oct. 2004;74(4):245-7. [pmid: 15551718].
195 Berthelot C, Cather J, Jones D, et al. Atypical CD8+ cutaneous T-cell lymphoma after immunomodulatory therapy. Clin Lymphoma Myeloma. Jan. 2006;6(4):329-32. [pmid: 16507211].
196 Berthelot JM, De Bandt M, Goupille P, et al. Exposition to anti-TNF drugs during pregnancy: outcome of 15 cases and review of the literature. Joint Bone Spine. Jan. 2009;76(1):28-34. [pmid: 19059799].
197 Berthelot JM, Glemarec J, Maugars Y, et al. Lethal medium-vessel panarteritis mimicking deep sepsis following etanercept and minocycline therapy in a patient with severe rheumatoid arthritis. Rheumatology (Oxford). Jun. 2002;41(6):703-5. [pmid: 12048303].
198 Berthelot JM, Varin S, Cormier G, et al. 25 mg etanercept once weekly in rheumatoid arthritis and spondylarthropathy. Joint Bone Spine. Mar. 2007;74(2):144-7. [pmid: 17337351].
199 Bertoli AM, Strusberg I, Baravalle M, et al. Rate and causes of infliximab discontinuation in patients with rheumatoid arthritis in a private clinical practice. J Clin Rheumatol. Dec. 2008;14(6):313-7. [pmid: 18690164].
200 Beuthien W, Mellinghoff HU, von Kempis J. Skin reaction to adalimumab. Arthritis Rheum. May. 2004;50(5):1690-2. [pmid: 15146441].
201 Beyeler C, Frey BM, Bird HA. Urinary 6 beta-hydroxycortisol excretion in rheumatoid arthritis. Br J Rheumatol. Jan. 1997;36(1):54-8. [pmid: 9117175].
202 Bhagat S, Ostor AJ. Diagnosing joint pain in the older people. Practitioner. Jan. 2010;254(1725):17-21. 2. [pmid: 20198931].
203 Bibbo C, Goldberg JW. Infectious and healing complications after elective orthopaedic foot and ankle surgery during tumor necrosis factor-alpha inhibition therapy. Foot Ankle Int. May. 2004;25(5):331-5. [pmid: 15134615].
204 Bicer A, Tursen U, Cimen OB, et al. Prevalence of dermatophytosis in patients with rheumatoid arthritis. Rheumatol Int. Jan. 2003;23(1):37-40. [pmid: 12548440].
205 Biester S, Deuter C, Michels H, et al. Adalimumab in the therapy of uveitis in childhood. Br J Ophthalmol. Mar. 2007;91(3):319-24. [pmid: 17035274].
206 Bilsborough W, Keen H, Taylor A, et al. Anti-tumour necrosis factor-alpha therapy over conventional therapy improves endothelial function in adults with rheumatoid arthritis. Rheumatol Int. Oct. 2006;26(12):1125-31. [pmid: 16799778].
207 Biro T, Griger Z, Kiss E, et al. Abnormal cell-specific expressions of certain protein kinase C isoenzymes in peripheral mononuclear cells of patients with systemic lupus erythematosus: effect of corticosteroid application. Scand J Immunol. Oct. 2004;60(4):421-8. [pmid: 15379867].
208 Biyikoglu B, Buduneli N, Kardesler L, et al. Evaluation of t-PA, PAI-2, IL-1beta and PGE(2) in gingival crevicular fluid of rheumatoid arthritis patients with periodontal disease. J Clin Periodontol. Sep. 2006;33(9):605-11. [pmid: 16856901].
209 Biyikoglu B, Buduneli N, Kardesler L, et al. Gingival crevicular fluid MMP-8 and -13 and TIMP-1 levels in patients with rheumatoid arthritis and inflammatory periodontal disease. J Periodontol. Aug. 2009;80(8):1307-14. [pmid: 19656031].
210 Blackman MR, Muniyappa R, Wilson M, et al. Diurnal secretion of growth hormone, cortisol, and dehydroepiandrosterone in pre- and perimenopausal women with active rheumatoid arthritis: a pilot case-control study. Arthritis Res Ther. 2007;9(4):R73. [pmid: 17662149].
211 Blanco R, Martinez-Taboada VM, Rodriguez-Valverde V, et al. Successful therapy with danazol in refractory autoimmune thrombocytopenia associated with rheumatic diseases. Br J Rheumatol. Oct. 1997;36(10):1095-9. [pmid: 9374927].
212 Bleumink GS, ter Borg EJ, Ramselaar CG, et al. Etanercept-induced subacute cutaneous lupus erythematosus. Rheumatology (Oxford). Nov. 2001;40(11):1317-9. [pmid: 11709621].
213 Blom M, Kievit W, Fransen J, et al. The reason for discontinuation of the first tumor necrosis factor (TNF) blocking agent does not influence the effect of a second TNF blocking agent in patients with rheumatoid arthritis. J Rheumatol. Oct. 2009;36(10):2171-7. [pmid: 19723902].
214 Blom M, Kievit W, Kuper HH, et al. Frequency and effectiveness of dose increase of adalimumab, etanercept, and infliximab in daily clinical practice. Arthritis Care Res (Hoboken). Sep. 2010;62(9):1335-41. [pmid: 20506128].
215 Blumberg SN, Fox DA. Rheumatoid arthritis: guidelines for emerging therapies. Am J Manag Care. Jun. 2001;7(6):617-26. [pmid: 11439735].
216 Blyth T, Hunter JA, Stirling A. Pain relief in the rheumatoid knee after steroid injection. A single-blind comparison of hydrocortisone succinate, and triamcinolone acetonide or hexacetonide. Br J Rheumatol. May. 1994;33(5):461-3. [pmid: 8173851].
217 Boatright MD, Wang BW. Clinical infection with Strongyloides sterocoralis following etanercept use for rheumatoid arthritis. Arthritis Rheum. Apr. 2005;52(4):1336-7. [pmid: 15818680].
218 Bobbio-Pallavicini F, Alpini C, Caporali R, et al. Autoantibody profile in rheumatoid arthritis during long-term infliximab treatment. Arthritis Res Ther. 2004;6(3):R264-72. [pmid: 15142273].
219 Bobbio-Pallavicini F, Caporali R, Alpini C, et al. High IgA rheumatoid factor levels are associated with poor clinical response to tumour necrosis factor alpha inhibitors in rheumatoid arthritis. Ann Rheum Dis. Mar. 2007;66(3):302-7. [pmid: 17079248].
220 Bodur H, Ataman S, Akbulut L, et al. Characteristics and medical management of patients with rheumatoid arthritis and ankylosing spondylitis. Clin Rheumatol. Sep. 2008;27(9):1119-25. [pmid: 18357499].
221 Bodur H, Seckin U, Eser F, et al. Coexistence of familial Mediterranean fever and psoriasis in a patient with seronegative spondyloarthropathy. Rheumatol Int. Nov. 2008;29(1):107-10. [pmid: 18500460].
222 Boeger CA, Wittwer H, Schattenkirchner M, et al. Treatment of ankylosing spondylitis with infliximab. Ann Rheum Dis. Dec. 2001;60(12):1159-60. [pmid: 11760727].
223 Boers M, Verhoeven AC, Markusse HM, et al. Randomised comparison of combined step-down prednisolone, methotrexate and sulphasalazine with sulphasalazine alone in early rheumatoid arthritis. Lancet. Aug. 2. 1997;350(9074):309-18. [pmid: 9251634].
224 Boesen M, Boesen L, Jensen KE, et al. Clinical outcome and imaging changes after intraarticular (IA) application of etanercept or methylprednisolone in rheumatoid arthritis: magnetic resonance imaging and ultrasound-Doppler show no effect of IA injections in the wrist after 4 weeks. J Rheumatol. Apr. 2008;35(4):584-91. [pmid: 18322991].
225 Boesen M, Jensen KE, Torp-Pedersen S, et al. Intra-articular distribution pattern after ultrasound-guided injections in wrist joints of patients with rheumatoid arthritis. Eur J Radiol. Feb. 2009;69(2):331-8. [pmid: 17935920].
226 Boey O, Van Hooland S, Woestenburg A, et al. Methotrexate should not be used for patients with end-stage kidney disease. Acta Clin Belg. Jul–Aug. 2006;61(4):166-9. [pmid: 17091912].
227 Bogoch E, Ouellette G, Hastings D. Failure of internal fixation of displaced femoral neck fractures in rheumatoid patients. J Bone Joint Surg Br. Jan. 1991;73(1):7-10. [pmid: 1991779].
228 Bogoch ER, Ouellette G, Hastings DE. Intertrochanteric fractures of the femur in rheumatoid arthritis patients. Clin Orthop Relat Res. Sep. 1993;(294):181-6. [pmid: 8358912].
229 Bohanec Grabar P, Grabnar I, Rozman B, et al. Investigation of the influence of CYP1A2 and CYP2C19 genetic polymorphism on 2-Cyano-3-hydroxy-N-[4-(trifluoromethyl)phenyl]-2-butenamide (A77 1726) pharmacokinetics in leflunomide-treated patients with rheumatoid arthritis. Drug Metab Dispos. Oct. 2009;37(10):2061-8. [pmid: 19581389].
230 Bohanec Grabar P, Logar D, Lestan B, et al. Genetic determinants of methotrexate toxicity in rheumatoid arthritis patients: a study of polymorphisms affecting methotrexate transport and folate metabolism. Eur J Clin Pharmacol. Nov. 2008;64(11):1057-68. [pmid: 18607581].
231 Bohanec Grabar P, Rozman B, Tomsic M, et al. Genetic polymorphism of CYP1A2 and the toxicity of leflunomide treatment in rheumatoid arthritis patients. Eur J Clin Pharmacol. Sep. 2008;64(9):871-6. [pmid: 18496682].
232 Bolla G, Disdier P, Harle JR, et al. Concurrent acute megaloblastic anaemia and pneumonitis: a severe side-effect of low-dose methotrexate therapy during rheumatoid arthritis. Clin Rheumatol. Dec. 1993;12(4):535-7. [pmid: 8124920].
233 Bollow M, Braun J, Taupitz M, et al. CT-guided intraarticular corticosteroid injection into the sacroiliac joints in patients with spondyloarthropathy: indication and follow-up with contrast-enhanced MRI. J Comput Assist Tomogr. Jul–Aug. 1996;20(4):512-21. [pmid: 8708047].
234 Bologna C, Jorgensen C, Sany J. Association of methotrexate and corticosteroids in the treatment of patients with rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 1996;14(4):401-6. [pmid: 8871839].
235 Bolstad AI, Eiken HG, Rosenlund B, et al. Increased salivary gland tissue expression of Fas, Fas ligand, cytotoxic T lymphocyte-associated antigen 4, and programmed cell death 1 in primary Sjogren’s syndrome. Arthritis Rheum. Jan. 2003;48(1):174-85. [pmid: 12528117].
236 Bombardieri S, Ruiz AA, Fardellone P, et al. Effectiveness of adalimumab for rheumatoid arthritis in patients with a history of TNF-antagonist therapy in clinical practice. Rheumatology (Oxford). Jul. 2007;46(7):1191-9. [pmid: 17504821].
237 Bongartz T, Harle P, Friedrich S, et al. Successful treatment of psoriatic onycho-pachydermo periostitis (POPP) with adalimumab. Arthritis Rheum. Jan. 2005;52(1):280-2. [pmid: 15641098].
238 Bongiorno MR, Pistone G, Doukaki S, et al. Adalimumab for treatment of moderate to severe psoriasis and psoriatic arthritis. Dermatol Ther. Oct. 2008;21(Suppl 2):S15-20.
239 Book C, Karlsson M, Akesson K, et al. Disease activity and disability but probably not glucocorticoid treatment predicts loss in bone mineral density in women with early rheumatoid arthritis. Scand J Rheumatol. Jul–Aug. 2008;37(4):248-54. [pmid: 18612924].
240 Book C, Karlsson MK, Akesson K, et al. Early rheumatoid arthritis and body composition. Rheumatology (Oxford). Sep. 2009;48(9):1128-32. [pmid: 19602478].
241 Book C, Saxne T, Jacobsson LT. Prediction of mortality in rheumatoid arthritis based on disease activity markers. J Rheumatol. Mar. 2005;32(3):430-4. [pmid: 15742433].
242 Boonen A, van der Heijde D, Severens JL, et al. Markov model into the cost-utility over five years of etanercept and infliximab compared with usual care in patients with active ankylosing spondylitis. Ann Rheum Dis. Feb. 2006;65(2):201-8. [pmid: 16014677].
243 Borowski LC, Lopes RP, Gonzalez TP, et al. Is steroid resistance related to multidrug resistance-I (MDR-I) in rheumatoid arthritis?. Int Immunopharmacol. Jun. 2007;7(6):836-44. [pmid: 17466917].
244 Borras-Blasco J, Gracia-Perez A, Nunez-Cornejo C, et al. Exacerbation of psoriatic skin lesions in a patient with psoriatic arthritis receiving adalimumab. J Clin Pharm Ther. Jun. 2008;33(3):321-5. [pmid: 18452420].
245 Borras-Blasco J, Gracia-Perez A, Rosique-Robles JD, et al. Urticaria due to etanercept in a patient with psoriatic arthritis. South Med J. Mar. 2009;102(3):304-5. [pmid: 19204628].
246 Borras-Blasco J, Nunez-Cornejo C, Gracia-Perez A, et al. Parapharyngeal abscess in a patient receiving etanercept. Ann Pharmacother. Feb. 2007;41(2):341-4. [pmid: 17227824].
247 Bos WH, Bartelds GM, Vis M, et al. Preferential decrease in IgG4 anti-citrullinated protein antibodies during treatment with tumour necrosis factor blocking agents in patients with rheumatoid arthritis. Ann Rheum Dis. Apr. 2009;68(4):558-63. [pmid: 18445623].
248 Bos WH, Bartelds GM, Wolbink GJ, et al. Differential response of the rheumatoid factor and anticitrullinated protein antibodies during adalimumab treatment in patients with rheumatoid arthritis. J Rheumatol. Oct. 2008;35(10):1972-7. [pmid: 18785316].
249 Boscarino JA. Posttraumatic stress disorder and physical illness: results from clinical and epidemiologic studies. Ann N Y Acad Sci. Dec. 2004;1032:141-53. [pmid: 15677401].
250 Bosello S, Santoliquido A, Zoli A, et al. TNF-alpha blockade induces a reversible but transient effect on endothelial dysfunction in patients with long-standing severe rheumatoid arthritis. Clin Rheumatol. Jul. 2008;27(7):833-9. [pmid: 18075712].
251 Boss B, Neeck G, Engelhardt B, et al. Influence of corticosteroids on neutrophils, lymphocytes, their subsets, and T-cell activity markers in patients with active rheumatoid arthritis, compared to healthy controls. Ann N Y Acad Sci. Jun. 22. 1999;876:198-200. [pmid: 10415610].
252 Bostrom EA, d’Elia HF, Dahlgren U, et al. Salivary resistin reflects local inflammation in Sjogren’s syndrome. J Rheumatol. Oct. 2008;35(10):2005-11. [pmid: 18709689].
253 Botez SA, Herrmann DN. Prolonged remission of a demyelinating neuropathy in a patient with lymphoma and Sjogren’s syndrome after Rituximab therapy. J Clin Neuromuscul Dis. Mar. 2010;11(3):127-31. [pmid: 20215986].
254 Bourgeois E, Caulier MT, Rose C, et al. Role of splenectomy in the treatment of myelodysplastic syndromes with peripheral thrombocytopenia: a report on six cases. Leukemia. Jun. 2001;15(6):950-3. [pmid: 11417482].
255 Boveri E, Castagnola C, Castello A, et al. Aberrant phenotype of plasmacytoid monocytes in acute myeloid leukemia. Am J Hematol. May. 2008;83(5):428-9. [pmid: 17617786].
256 Bowie VL, Snella KA, Gopalachar AS, et al. Listeria meningitis associated with infliximab. Ann Pharmacother. Jan. 2004;38(1):58-61. [pmid: 14742795].
257 Bozkurt FY, Berker E, Akkus S, et al. Relationship between interleukin-6 levels in gingival crevicular fluid and periodontal status in patients with rheumatoid arthritis and adult periodontitis. J Periodontol. Nov. 2000;71(11):1756-60. [pmid: 11128925].
258 Bramlage CP, Kaps C, Ungethum U, et al. Modulatory effects of inflammation and therapy on GDF-5 expression in rheumatoid arthritis synovium. Scand J Rheumatol. Nov–Dec. 2008;37(6):401-9. [pmid: 18830904].
259 Brandt J, Haibel H, Cornely D, et al. Successful treatment of active ankylosing spondylitis with the anti-tumor necrosis factor alpha monoclonal antibody infliximab. Arthritis Rheum. Jun. 2000;43(6):1346-52. [pmid: 10857793].
260 Brandt J, Khariouzov A, Listing J, et al. Six-month results of a double-blind, placebo-controlled trial of etanercept treatment in patients with active ankylosing spondylitis. Arthritis Rheum. Jun. 2003;48(6):1667-75. [pmid: 12794835].
261 Brandt J, Listing J, Haibel H, et al. Long-term efficacy and safety of etanercept after readministration in patients with active ankylosing spondylitis. Rheumatology (Oxford). Mar. 2005;44(3):342-8. [pmid: 15561737].
262 Brandt J, Listing J, Sieper J, et al. Development and preselection of criteria for short term improvement after anti-TNF alpha treatment in ankylosing spondylitis. Ann Rheum Dis. Nov. 2004;63(11):1438-44. [pmid: 15044211].
263 Brassard P, Kezouh A, Suissa S. Antirheumatic drugs and the risk of tuberculosis. Clin Infect Dis. 2006;43(6):717-22. [pmid: 16912945].
264 Brassard P, Lowe AM, Bernatsky S, et al. Rheumatoid arthritis, its treatments, and the risk of tuberculosis in Quebec, Canada. Arthritis Rheum. 2009;61(3):300-4. [pmid: 19248128].
265 Braun J, Baraliakos X, Brandt J, et al. Persistent clinical response to the anti-TNF-alpha antibody infliximab in patients with ankylosing spondylitis over 3 years. Rheumatology (Oxford). May. 2005;44(5):670-6. [pmid: 15757965].
266 Braun J, Baraliakos X, Golder W, et al. Magnetic resonance imaging examinations of the spine in patients with ankylosing spondylitis, before and after successful therapy with infliximab: evaluation of a new scoring system. Arthritis Rheum. Apr. 2003;48(4):1126-36. [pmid: 12687557].
267 Braun J, Bollow M, Seyrekbasan F, et al. Computed tomography guided corticosteroid injection of the sacroiliac joint in patients with spondyloarthropathy with sacroiliitis: clinical outcome and followup by dynamic magnetic resonance imaging. J Rheumatol. Apr. 1996;23(4):659-64. [pmid: 8730123].
268 Braun J, Brandt J, Listing J, et al. Long-term efficacy and safety of infliximab in the treatment of ankylosing spondylitis: an open, observational, extension study of a three-month, randomized, placebo-controlled trial. Arthritis Rheum. Aug. 2003;48(8):2224-33. [pmid: 12905476].
269 Braun J, Brandt J, Listing J, et al. Two year maintenance of efficacy and safety of infliximab in the treatment of ankylosing spondylitis. Ann Rheum Dis. Feb. 2005;64(2):229-34. [pmid: 15388511].
270 Braun J, Brandt J, Listing J, et al. Treatment of active ankylosing spondylitis with infliximab: a randomised controlled multicentre trial. Lancet. Apr. 6. 2002;359(9313):1187-93. [pmid: 11955536].
271 Braun J, Kastner P, Flaxenberg P, et al. Comparison of the clinical efficacy and safety of subcutaneous versus oral administration of methotrexate in patients with active rheumatoid arthritis: results of a six-month, multicenter, randomized, double-blind, controlled, phase IV trial. Arthritis Rheum. Jan. 2008;58(1):73-81. [pmid: 18163521].
272 Braun J, Landewe R, Hermann KG, et al. Major reduction in spinal inflammation in patients with ankylosing spondylitis after treatment with infliximab: results of a multicenter, randomized, double-blind, placebo-controlled magnetic resonance imaging study. Arthritis Rheum. May. 2006;54(5):1646-52. [pmid: 16646033].
273 Braun J, Sieper J, Breban M, et al. Anti-tumour necrosis factor alpha therapy for ankylosing spondylitis: international experience. Ann Rheum Dis. Dec. 51. 2002;61(Suppl 3):iii-60.
274 Braun J, van der Heijde D. Imaging and scoring in ankylosing spondylitis. Best Pract Res Clin Rheumatol. Sep. 2002;16(4):573-604. [pmid: 12406428].
275 Braun-Moscovici Y, Markovits D, Rozin A, et al. Anti-tumor necrosis factor therapy: 6 year experience of a single center in northern Israel and possible impact of health policy on results. Isr Med Assoc J. Apr. 2008;10(4):277-81. [pmid: 18548981].
276 Bravo Vergel Y, Hawkins NS, Claxton K, et al. The cost-effectiveness of etanercept and infliximab for the treatment of patients with psoriatic arthritis. Rheumatology (Oxford). Nov. 2007;46(11):1729-35. [pmid: 17956918].
277 Breban M, Vignon E, Claudepierre P, et al. Efficacy of infliximab in refractory ankylosing spondylitis: results of a six-month open-label study. Rheumatology (Oxford). Nov. 2002;41(11):1280-5. [pmid: 12422001].
278 Breedveld F, Agarwal S, Yin M, et al. Rituximab pharmacokinetics in patients with rheumatoid arthritis: B-cell levels do not correlate with clinical response. J Clin Pharmacol. Sep. 2007;47(9):1119-28. [pmid: 17766699].
279 Breedveld FC, Emery P, Keystone E, et al. Infliximab in active early rheumatoid arthritis. Ann Rheum Dis. 2004;63(2):149-55. [pmid: 14722203].
280 Breedveld FC, Weisman MH, Kavanaugh AF, et al. The PREMIER study: A multicenter, randomized, double-blind clinical trial of combination therapy with adalimumab plus methotrexate versus methotrexate alone or adalimumab alone in patients with early, aggressive rheumatoid arthritis who had not had previous methotrexate treatment. Arthritis Rheum. Jan. 2006;54(1):26-37. [pmid: 16385520].
281 Breglia MD, Carter JD. Atypical insufficiency fracture of the tibia associated with long-term bisphosphonate therapy. J Clin Rheumatol. Mar. 2010;16(2):76-8. [pmid: 20130483].
282 Bremner R, Simpson E, White CR, et al. Palisaded neutrophilic and granulomatous dermatitis: an unusual cutaneous manifestation of immune-mediated disorders. Semin Arthritis Rheum. Dec. 2004;34(3):610-6. [pmid: 15609265].
283 Brennan A, Bansback N, Nixon R, et al. Modelling the cost effectiveness of TNF-alpha antagonists in the management of rheumatoid arthritis: results from the British Society for Rheumatology Biologics Registry. Rheumatology (Oxford). Aug. 2007;46(8):1345-54. [pmid: 17562686].
284 Brennan MT, Sankar V, Leakan RA, et al. Sex steroid hormones in primary Sjogren’s syndrome. J Rheumatol. Jun. 2003;30(6):1267-71. [pmid: 12784401].
285 Bresnihan B. Treating early rheumatoid arthritis in the younger patient. J Rheumatol Suppl. Jun. 2001;62:4-9. [pmid: 11409156].
286 Bresnihan B, Alvaro-Gracia JM, Cobby M, et al. Treatment of rheumatoid arthritis with recombinant human interleukin-1 receptor antagonist. Arthritis Rheum. 1998;41(12):2196-204. [pmid: 9870876].
287 Bresnihan B, Newmark R, Robbins S, et al. Effects of anakinra monotherapy on joint damage in patients with rheumatoid arthritis. Extension of a 24-week randomized, placebo-controlled trial. J Rheumatol. Jun. 2004;31(6):1103-11. [pmid: 15170922].
288 Brocq O, Albert C, Roux C, et al. Adalimumab in rheumatoid arthritis after failed infliximab and/or etanercept therapy: experience with 18 patients. Joint Bone Spine. Nov. 2004;71(6):601-3. [pmid: 15589452].
289 Brocq O, Roux CH, Albert C, et al. TNFalpha antagonist continuation rates in 442 patients with inflammatory joint disease. Joint Bone Spine. 2007;74(2):148-54. [pmid: 17368068].
290 Brooks H, Taylor HG, Nichol FE. The three week sulphasalazine syndrome. Clin Rheumatol. Dec. 1992;11(4):566-8. [pmid: 1362531].
291 Brophy RH, MacKenzie CR, Gamradt SC, et al. The diagnosis and management of psoriatic arthritis in a professional football player presenting with a knee effusion: a case report. Clin J Sport Med. Jul. 2008;18(4):369-71. [pmid: 18614892].
292 Broussais F, Kawashima M, Marotte H, et al. Chronic myeloid leukaemia and tuberculosis in a patient with rheumatoid arthritis treated with infliximab. Ann Rheum Dis. Mar. 2005;64(3):509-10. [pmid: 15708911].
293 Broussard JS Jr. Derangement, osteoarthritis, and rheumatoid arthritis of the temporomandibular joint: implications, diagnosis, and management. Dent Clin North Am. Apr. 2005;49(2):327-42. [pmid: 15755408].
294 Brown A, Grubbs P, Mongey AB. Infection of total hip prosthesis by Mycobacterium tuberculosis and Mycobacterium chelonae in a patient with rheumatoid arthritis. Clin Rheumatol. Apr. 2008;27(4):543-5. [pmid: 18034202].
295 Brown ES, Frol A, Bobadilla L, et al. Effect of lamotrigine on mood and cognition in patients receiving chronic exogenous corticosteroids. Psychosomatics. May–Jun. 2003;44(3):204-8. [pmid: 12724501].
296 Brown ES, Woolston DJ, Frol AB. Amygdala volume in patients receiving chronic corticosteroid therapy. Biol Psychiatry. Apr. 1. 2008;63(7):705-9. [pmid: 17981265].
297 Brown GT, Wright FV, Lang BA, et al. Clinical responsiveness of self-report functional assessment measures for children with juvenile idiopathic arthritis undergoing intraarticular corticosteroid injections. Arthritis Rheum. Dec. 15. 2005;53(6):897-904. [pmid: 16342103].
298 Brown SL, Greene MH, Gershon SK, et al. Tumor necrosis factor antagonist therapy and lymphoma development: twenty-six cases reported to the Food and Drug Administration. Arthritis Rheum. Dec. 2002;46(12):3151-8. [pmid: 12483718].
299 Bruckle W, Eisenhut C, Goebel FD. Cerebral involvement in adult onset Still’s disease. Clin Rheumatol. Jun. 1992;11(2):276-9. [pmid: 1617905].
300 Brunasso AM, Massone C. Thrombocytopenia associated with the use of anti-tumor necrosis factor-alpha agents for psoriasis. J Am Acad Dermatol. May. 2009;60(5):781-5. [pmid: 19217692].
301 Bruns A, Nicaise-Roland P, Hayem G, et al. Prospective cohort study of effects of infliximab on rheumatoid factor, anti-cyclic citrullinated peptide antibodies and antinuclear antibodies in patients with long-standing rheumatoid arthritis. Joint Bone Spine. May. 2009;76(3):248-53. [pmid: 19208451].
302 Bruns H, Meinken C, Schauenberg P, et al. Anti-TNF immunotherapy reduces CD8+ T cell-mediated antimicrobial activity against Mycobacterium tuberculosis in humans. J Clin Invest. May. 2009;119(5):1167-77. [pmid: 19381021].
303 Bruyn GA, Tate G, Caeiro F, et al. Everolimus in patients with rheumatoid arthritis receiving concomitant methotrexate: a 3-month, double-blind, randomised, placebo-controlled, parallel-group, proof-of-concept study. Ann Rheum Dis. Aug. 2008;67(8):1090-5. [pmid: 18037627].
304 Bryl E, Vallejo AN, Matteson EL, et al. Modulation of CD28 expression with anti-tumor necrosis factor alpha therapy in rheumatoid arthritis. Arthritis Rheum. Oct. 2005;52(10):2996-3003. [pmid: 16200579].
305 Buccoliero G, Lonero G, Romanelli C, et al. Varicella zoster virus encephalitis during treatment with anti-tumor necrosis factor-alpha agent in a psoriatic arthritis patient. New Microbiol. Jul. 2010;33(3):271-4. [pmid: 20954448].
306 Buccoliero R, Gambelli S, Sicurelli F, et al. Leukoencephalopathy as a rare complication of hepatitis C infection. Neurol Sci. Nov. 2006;27(5):360-3. [pmid: 17122948].
307 Buch MH, Bingham SJ, Bryer D, et al. Long-term infliximab treatment in rheumatoid arthritis: subsequent outcome of initial responders. Rheumatology (Oxford). Jul. 2007;46(7):1153-6. [pmid: 17478470].
308 Buch MH, Bingham SJ, Seto Y, et al. Lack of response to anakinra in rheumatoid arthritis following failure of tumor necrosis factor alpha blockade. Arthritis Rheum. Mar. 2004;50(3):725-8. [pmid: 15022311].
309 Buch MH, Boyle DL, Rosengren S, et al. Mode of action of abatacept in rheumatoid arthritis patients having failed tumour necrosis factor blockade: a histological, gene expression and dynamic magnetic resonance imaging pilot study. Ann Rheum Dis. Jul. 2009;68(7):1220-7. [pmid: 18772191].
310 Buch MH, Conaghan PG, Quinn MA, et al. True infliximab resistance in rheumatoid arthritis: a role for lymphotoxin alpha?. Ann Rheum Dis. Oct. 2004;63(10):1344-6. [pmid: 15033655].
311 Buch MH, Reece RJ, Quinn MA, et al. The value of synovial cytokine expression in predicting the clinical response to TNF antagonist therapy (infliximab). Rheumatology (Oxford). Oct. 2008;47(10):1469-75. [pmid: 18660510].
312 Buch MH, Seto Y, Bingham SJ, et al. C-reactive protein as a predictor of infliximab treatment outcome in patients with rheumatoid arthritis: defining subtypes of nonresponse and subsequent response to etanercept. Arthritis Rheum. Jan. 2005;52(1):42-8. [pmid: 15641046].
313 Buchbinder R, Barber M, Heuzenroeder L, et al. Incidence of melanoma and other malignancies among rheumatoid arthritis patients treated with methotrexate. Arthritis Rheum. Jun. 15. 2008;59(6):794-9. [pmid: 18512713].
314 Buchs N, Silvestri T, di Giovine FS, et al. IL-4 VNTR gene polymorphism in chronic polyarthritis. The rare allele is associated with protection against destruction. Rheumatology (Oxford). Oct. 2000;39(10):1126-31. [pmid: 11035134].
315 Buckland GT 3rd, Carlson JA, Meyer DR. Persistent periorbital and facial lymphedema associated with Group A beta-hemolytic streptococcal infection (erysipelas). Ophthal Plast Reconstr Surg. Mar–Apr. 2007;23(2):161-3.
316 Buckley LM, Leib ES, Cartularo KS, et al. Effects of low dose corticosteroids on the bone mineral density of patients with rheumatoid arthritis. J Rheumatol. Jun. 1995;22(6):1055-9. [pmid: 7674230].
317 Buckley LM, Leib ES, Cartularo KS, et al. Calcium and vitamin D3 supplementation prevents bone loss in the spine secondary to low-dose corticosteroids in patients with rheumatoid arthritis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. Dec. 15. 1996;125(12):961-8. [pmid: 8967706].
318 Buckley LM, Leib ES, Cartularo KS, et al. Effects of low dose methotrexate on the bone mineral density of patients with rheumatoid arthritis. J Rheumatol. Aug. 1997;24(8):1489-94. [pmid: 9263140].
319 Buda-Okreglak EM, Drabick JJ, Delaney NR. Proinflammatory syndrome mimicking acute rheumatoid arthritis in a patient with Waldenstrom’s macroglobulinemia treated with rituximab. Ann Hematol. Feb. 2004;83(2):117-9. [pmid: 14513285].
320 Bunescu A, Seideman P, Lenkei R, et al. Enhanced Fcgamma receptor I, alphaMbeta2 integrin receptor expression by monocytes and neutrophils in rheumatoid arthritis: interaction with platelets. J Rheumatol. Dec. 2004;31(12):2347-55. [pmid: 15570633].
321 Burge DJ, Bookbinder SA, Kivitz AJ, et al. Pharmacokinetic and pharmacodynamic properties of TRU-015, a CD20-directed small modular immunopharmaceutical protein therapeutic, in patients with rheumatoid arthritis: a Phase I, open-label, dose-escalation clinical study. Clin Ther. Oct. 2008;30(10):1806-16. [pmid: 19014836].
322 Burgos RA, Hancke JL, Bertoglio JC, et al. Efficacy of an Andrographis paniculata composition for the relief of rheumatoid arthritis symptoms: a prospective randomized placebo-controlled trial. Clin Rheumatol. Aug. 2009;28(8):931-46. [pmid: 19408036].
323 Burmester GR, Ferraccioli G, Flipo RM, et al. Clinical remission and/or minimal disease activity in patients receiving adalimumab treatment in a multinational, open-label, twelve-week study. Arthritis Rheum. Jan. 15. 2008;59(1):32-41. [pmid: 18163417].
324 Burmester GR, Mariette X, Montecucco C, et al. Adalimumab alone and in combination with disease-modifying antirheumatic drugs for the treatment of rheumatoid arthritis in clinical practice: the Research in Active Rheumatoid Arthritis (ReAct) trial. Ann Rheum Dis. 2007;66(6):732-9. [pmid: 17329305].
325 Burnham JM, Shults J, Dubner SE, et al. Bone density, structure, and strength in juvenile idiopathic arthritis: importance of disease severity and muscle deficits. Arthritis Rheum. Aug. 2008;58(8):2518-27. [pmid: 18668565].
326 Buttgereit F, Doering G, Schaeffler A, et al. Efficacy of modified-release versus standard prednisone to reduce duration of morning stiffness of the joints in rheumatoid arthritis (CAPRA-1): a double-blind, randomised controlled trial. Lancet. Jan. 19. 2008;371(9608):205-14. [pmid: 18207016].
327 Buttgereit F, Doering G, Schaeffler A, et al. Targeting pathophysiological rhythms: prednisone chronotherapy shows sustained efficacy in rheumatoid arthritis. Ann Rheum Dis. Jul. 2010;69(7):1275-80. [pmid: 20542963].
328 Caballol Pons N, Montala N, Valverde J, et al. Isolated cerebral vasculitis associated with rheumatoid arthritis. Joint Bone Spine. Jul. 2010;77(4):361-3. [pmid: 20471884].
329 Cairns AP, Duncan MK, Hinder AE, et al. New onset systemic lupus erythematosus in a patient receiving etanercept for rheumatoid arthritis. Ann Rheum Dis. Nov. 2002;61(11):1031-2. [pmid: 12379532].
330 Cairns AP, Taggart AJ. Anti-tumour necrosis factor therapy for severe inflammatory arthritis: two years of experience in Northern Ireland. Ulster Med J. Nov. 2002;71(2):101-5. [pmid: 12513005].
331 Calabrese LH. Rheumatoid arthritis and primary care: the case for early diagnosis and treatment. J Am Osteopath Assoc. Jun. 1999;99(6):313-21. [pmid: 10405518].
332 Calin A, Dijkmans BA, Emery P, et al. Outcomes of a multicentre randomised clinical trial of etanercept to treat ankylosing spondylitis. Ann Rheum Dis. Dec. 2004;63(12):1594-600. [pmid: 15345498].
333 Callaly EL, FitzGerald O, Rogers S. Hydroxychloroquine-associated, photo-induced toxic epidermal necrolysis. Clin Exp Dermatol. Aug. 2008;33(5):572-4. [pmid: 18477009].
334 Cambridge G, Leandro MJ, Edwards JC, et al. Serologic changes following B lymphocyte depletion therapy for rheumatoid arthritis. Arthritis Rheum. Aug. 2003;48(8):2146-54. [pmid: 12905467].
335 Cambridge G, Stohl W, Leandro MJ, et al. Circulating levels of B lymphocyte stimulator in patients with rheumatoid arthritis following rituximab treatment: relationships with B cell depletion, circulating antibodies, and clinical relapse. Arthritis Rheum. Mar. 2006;54(3):723-32. [pmid: 16508933].
336 Campion GV, Lebsack ME, Lookabaugh J, et al. Dose-range and dose-frequency study of recombinant human interleukin-1 receptor antagonist in patients with rheumatoid arthritis. The IL-1Ra Arthritis Study Group. Arthritis Rheum. Jul. 1996;39(7):1092-101. [pmid: 8670316].
337 Campione E, Mazzotta A, Paterno EJ, et al. Effect of calcipotriol on etanercept partial responder psoriasis vulgaris and psoriatic arthritis patients. Acta Derm Venereol. 2009;89(3):288-91. [pmid: 19479128].
338 Cankaya H, Alpoz E, Karabulut G, et al. Effects of hydroxychloroquine on salivary flow rates and oral complaints of Sjogren patients: a prospective sample study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jul. 2010;110(1):62-7. [pmid: 20610299].
339 Cannon GW, Holden WL, Juhaeri J, et al. Adverse events with disease modifying antirheumatic drugs (DMARD): a cohort study of leflunomide compared with other DMARD. J Rheumatol. Oct. 2004;31(10):1906-11. [pmid: 15468352].
340 Cansu DU, Kalifoglu T, Korkmaz C. Short-term course of chronic hepatitis B and C under treatment with etanercept associated with different disease modifying antirheumatic drugs without antiviral prophylaxis. J Rheumatol. Mar. 2008;35(3):421-4. [pmid: 18203328].
341 Cantarini L, Tinazzi I, Biasi D, et al. Sulfasalazine-induced immune thrombocytopenia. Postgrad Med J. Jun. 2007;83(980):e1. [pmid: 17551063].
342 Cantini F, Niccoli L, Benucci M, et al. Switching from infliximab to once-weekly administration of 50 mg etanercept in resistant or intolerant patients with ankylosing spondylitis: results of a fifty-four-week study. Arthritis Rheum. Oct. 15. 2006;55(5):812-6. [pmid: 17013842].
343 Cantini F, Niccoli L, Nannini C, et al. Frequency and duration of clinical remission in patients with peripheral psoriatic arthritis requiring second-line drugs. Rheumatology (Oxford). 2008;47(6):872-6. [pmid: 18400836].
344 Capell H. Longterm maintenance therapy with disease modifying antirheumatic drugs. J Rheumatol Suppl. Nov. 2002;66:38-43. [pmid: 12435167].
345 Capell HA, Madhok R, Hunter JA, et al. Lack of radiological and clinical benefit over two years of low dose prednisolone for rheumatoid arthritis: results of a randomised controlled trial. Ann Rheum Dis. Jul. 2004;63(7):797-803. [pmid: 15194574].
346 Capell HA, Murphy EA, Hunter JA. Rheumatoid arthritis: workload and outcome over 10 years. Q J Med. Jun. 1991;79(290):461-76. [pmid: 1946927].
347 Caplan L, Wolfe F, Russell AS, et al. Corticosteroid use in rheumatoid arthritis: prevalence, predictors, correlates, and outcomes. J Rheumatol. Apr. 2007;34(4):696-705. [pmid: 17299838].
348 Capria A, De Nardo D, Baffetti FR, et al. Long-term anti-TNF-alpha treatments reverse the endothelial dysfunction in rheumatoid arthritis: the biological coherence between synovial and endothelial inflammation. Int J Immunopathol Pharmacol. Jan–Mar. 2010;23(1):255-62. [pmid: 20378011].
349 Capsoni F, Sarzi-Puttini P, Atzeni F, et al. Effect of adalimumab on neutrophil function in patients with rheumatoid arthritis. Arthritis Res Ther. 2005;7(2):R250-5. [pmid: 15743471].
350 Caramaschi P, Biasi D, Carletto A, et al. A case of adult onset Still’s disease treated with infliximab. Clin Exp Rheumatol. Jan–Feb. 2002;20(1):113. [pmid: 11892694].
351 Caramaschi P, Biasi D, Carletto A, et al. Orbital myositis in a rheumatoid arthritis patient during etanercept treatment. Clin Exp Rheumatol. Jan–Feb. 2003;21(1):136-7. [pmid: 12673906].
352 Caramaschi P, Ruzzenente O, Pieropan S, et al. Determination of ANA specificity using multiplexed fluorescent microsphere immunoassay in patients with ANA positivity at high titres after infliximab treatment: preliminary results. Rheumatol Int. May. 2007;27(7):649-54. [pmid: 17136355].
353 Caramella C, Avouac J, Sogni P, et al. Association between rheumatoid arthritis and primary biliary cirrhosis. Joint Bone Spine. May. 2007;74(3):279-81. [pmid: 17369071].
354 Cardillo C, Schinzari F, Mores N, et al. Intravascular tumor necrosis factor alpha blockade reverses endothelial dysfunction in rheumatoid arthritis. Clin Pharmacol Ther. Sep. 2006;80(3):275-81. [pmid: 16952494].
355 Carloni A, Piciucchi S, Giannakakis K, et al. Diffuse alveolar hemorrhage after leflunomide therapy in a patient with rheumatoid arthritis. J Thorac Imaging. Feb. 2008;23(1):57-9. [pmid: 18347524].
356 Carlson E, Rothfield N. Etanercept-induced lupus-like syndrome in a patient with rheumatoid arthritis. Arthritis Rheum. Apr. 2003;48(4):1165-6. author reply 6. [pmid: 12687569].
357 Carmona L, Gomez-Reino JJ, Rodriguez-Valverde V, et al. Effectiveness of recommendations to prevent reactivation of latent tuberculosis infection in patients treated with tumor necrosis factor antagonists. Arthritis Rheum. Jun. 2005;52(6):1766-72. [pmid: 15934089].
358 Caroyer JM, Manto MU, Steinfeld SD. Severe sensory neuronopathy responsive to infliximab in primary Sjogren’s syndrome. Neurology. Oct. 8. 2002;59(7):1113-4. [pmid: 12370480].
359 Carrasco R, Smith JA, Lovell D. Biologic agents for the treatment of juvenile rheumatoid arthritis: current status. Paediatr Drugs. 2004;6(3):137-46. [pmid: 15170361].
360 Carreira PE, Gonzalez-Crespo MR, Ciruelo E, et al. Polymorphism of the interleukin-1 receptor antagonist gene: a factor in susceptibility to rheumatoid arthritis in a Spanish population. Arthritis Rheum. Oct. 2005;52(10):3015-9. [pmid: 16200608].
361 Carrera C, Mascaro JM Jr, Moreno-Romero JA, et al. Pyoderma vegetans associated with severe psoriatic arthritis: good response to etanercept. Dermatology. 2007;214(1):77-81. [pmid: 17191052].
362 Carroll MB, Bond MI. Use of tumor necrosis factor-alpha inhibitors in patients with chronic hepatitis B infection. Semin Arthritis Rheum. Dec. 2008;38(3):208-17. [pmid: 18221983].
363 Carter JD, Gerard HC, Hudson AP. Psoriasiform lesions induced by tumour necrosis factor antagonists: a skin-deep medical conundrum. Ann Rheum Dis. Aug. 2008;67(8):1181-3. [pmid: 18299302].
364 Carter JD, Valeriano J, Vasey FB. Tumor necrosis factor-alpha inhibition and VATER association: a causal relationship. J Rheumatol. May. 2006;33(5):1014-7. [pmid: 16652431].
365 Caselli RJ, Scheithauer BW, Bowles CA, et al. The treatable dementia of Sjogren’s syndrome. Ann Neurol. Jul. 1991;30(1):98-101. [pmid: 1929232].
366 Caselli RJ, Scheithauer BW, O’Duffy JD, et al. Chronic inflammatory meningoencephalitis should not be mistaken for Alzheimer’s disease. Mayo Clin Proc. Sep. 1993;68(9):846-53. [pmid: 8371602].
367 Cash JM, Crofford LJ, Gallucci WT, et al. Pituitary-adrenal axis responsiveness to ovine corticotropin releasing hormone in patients with rheumatoid arthritis treated with low dose prednisone. J Rheumatol. Nov. 1992;19(11):1692-6. [pmid: 1337108].
368 Casoli P, Tumiati B. Rheumatoid arthritis, corticosteroid therapy and Kaposi’s sarcoma: a coincidence? A case and review of literature. Clin Rheumatol. Sep. 1992;11(3):432-5. [pmid: 1458798].
369 Caspi D, Elkayam O, Eisinger M, et al. Clinical significance of low titer anti-nuclear antibodies in early rheumatoid arthritis: implications on the presentation and long-term course of the disease. Rheumatol Int. Feb. 2001;20(2):43-7. [pmid: 11269531].
370 Cassano N, Galluccio A, De Simone C, et al. Influence of body mass index, comorbidities and prior systemic therapies on the response of psoriasis to adalimumab: an exploratory analysis from the APHRODITE data. J Biol Regul Homeost Agents. Oct–Dec. 2008;22(4):233-7. [pmid: 19036225].
371 Cassano N, Loconsole F, Amoruso A, et al. Infliximab monotherapy for refractory psoriasis: preliminary results. Int J Immunopathol Pharmacol. Sep–Dec. 2004;17(3):373-80. [pmid: 15461871].
372 Castagnetta LA, Carruba G, Granata OM, et al. Increased estrogen formation and estrogen to androgen ratio in the synovial fluid of patients with rheumatoid arthritis. J Rheumatol. Dec. 2003;30(12):2597-605. [pmid: 14719200].
373 Castaneda O, Nair MG. Controlled trial of methotrexate versus CH-1504 in the treatment of rheumatoid arthritis. J Rheumatol. May. 2006;33(5):862-4. [pmid: 16652417].
374 Catananti C, Mastropaolo S, Calabrese C, et al. A case of normal-pressure hydrocephalus associated with rheumatoid arthritis. Aging Clin Exp Res. Apr. 2010;22(2):189-91. [pmid: 20440105].
375 Catley D, Kaell AT, Kirschbaum C, et al. A naturalistic evaluation of cortisol secretion in persons with fibromyalgia and rheumatoid arthritis. Arthritis Care Res. Feb. 2000;13(1):51-61. [pmid: 11094926].
376 Catrina AI, af Klint E, Ernestam S, et al. Anti-tumor necrosis factor therapy increases synovial osteoprotegerin expression in rheumatoid arthritis. Arthritis Rheum. Jan. 2006;54(1):76-81. [pmid: 16385498].
377 Catrina AI, Lampa J, Ernestam S, et al. Anti-tumour necrosis factor (TNF)-alpha therapy (etanercept) down-regulates serum matrix metalloproteinase (MMP)-3 and MMP-1 in rheumatoid arthritis. Rheumatology (Oxford). May. 2002;41(5):484-9. [pmid: 12011369].
378 Catrina AI, Trollmo C, af Klint E, et al. Evidence that anti-tumor necrosis factor therapy with both etanercept and infliximab induces apoptosis in macrophages, but not lymphocytes, in rheumatoid arthritis joints: extended report. Arthritis Rheum. Jan. 2005;52(1):61-72. [pmid: 15641091].
379 Catrina AI, Ulfgren AK, Lindblad S, et al. Low levels of apoptosis and high FLIP expression in early rheumatoid arthritis synovium. Ann Rheum Dis. Oct. 2002;61(10):934-6. [pmid: 12228167].
380 Cattalini M, Maduskuie V, Fawcett PT, et al. Predicting duration of beneficial effect of joint injection among children with chronic arthritis by measuring biomarkers concentration in synovial fluid at the time of injection. Clin Exp Rheumatol. Nov–Dec. 2008;26(6):1153-60. [pmid: 19210889].
381 Cauli A, Yanni G, Panayi GS. Interleukin-1, interleukin-1 receptor antagonist and macrophage populations in rheumatoid arthritis synovial membrane. Br J Rheumatol. Sep. 1997;36(9):935-40. [pmid: 9376987].
382 Cauza E, Cauza K, Hanusch-Enserer U, et al. Intravenous anti TNF-alpha antibody therapy leads to elevated triglyceride and reduced HDL-cholesterol levels in patients with rheumatoid and psoriatic arthritis. Wien Klin Wochenschr. Dec. 30. 2002;114(23–24):1004-7. [pmid: 12635469].
383 Cauza E, Hanusch-Enserer U, Frischmuth K, et al. Short-term infliximab therapy improves symptoms of psoriatic arthritis and decreases concentrations of cartilage oligomeric matrix protein. J Clin Pharm Ther. Apr. 2006;31(2):149-52. [pmid: 16635048].
384 Cauza E, Spak M, Cauza K, et al. Treatment of psoriatic arthritis and psoriasis vulgaris with the tumor necrosis factor inhibitor infliximab. Rheumatol Int. Nov. 2002;22(6):227-32. [pmid: 12426660].
385 Cavagna L, Caporali R, Epis O, et al. Infliximab in the treatment of adult Still’s disease refractory to conventional therapy. Clin Exp Rheumatol. May–Jun. 2001;19(3):329-32. [pmid: 11407090].
386 Cavallasca JA, Caubet M, Helling CA, et al. Cryptogenic organizing pneumonia (COP), as presentation of rheumatoid arthritis. Rheumatol Int. Nov. 2008;29(1):99-101. [pmid: 18500458].
387 Cavazzana I, Bobbio-Pallavicini F, Franceschini F, et al. Anti-TNF-alpha treatment in rheumatoid arthritis with anti-Ro/SSA antibodies. Analysis of 17 cases among a cohort of 322 treated patients. Clin Exp Rheumatol. Sep–Oct. 2007;25(5):676-83. [pmid: 18078613].
388 Cay HF, Gungor HA, Sezer I, et al. Adverse effect of TNF-alpha blocker? Demyelination in an ankylosing spondylitis patient: a case report. J Clin Pharm Ther. Dec. 2006;31(6):645-8. [pmid: 17176371].
389 Cefle A. Leflunomide and azathioprine combination in refractory adult-onset Still’s disease. Ann Pharmacother. Apr. 2005;39(4):764-7. [pmid: 15741418].
390 Cepeda EJ, Williams FM, Ishimori ML, et al. The use of anti-tumour necrosis factor therapy in HIV-positive individuals with rheumatic disease. Ann Rheum Dis. May. 2008;67(5):710-2. [pmid: 18079191].
391 Chakraborty PP, Achar A. Spontaneous bleeding in a patient of rheumatoid arthritis: a complication after accidental overdose of methotrexate. J Assoc Physicians India. Jul. 2007;55:501. [pmid: 17907499].
392 Chakravarty EF, Sanchez-Yamamoto D, Bush TM. The use of disease modifying antirheumatic drugs in women with rheumatoid arthritis of childbearing age: a survey of practice patterns and pregnancy outcomes. J Rheumatol. Feb. 2003;30(2):241-6. [pmid: 12563675].
393 Chambers CD, Johnson DL, Robinson LK, et al. Birth outcomes in women who have taken leflunomide during pregnancy. Arthritis Rheum. 2010;62(5):1494-503. [pmid: 20131283].
394 Chan AT, Cleeve V, Daymond TJ. Necrotising fasciitis in a patient receiving infliximab for rheumatoid arthritis. Postgrad Med J. Jan. 2002;78(915):47-8. [pmid: 11796874].
395 Chan JL, Davis-Reed L, Kimball AB. Counter-regulatory balance: atopic dermatitis in patients undergoing infliximab infusion therapy. J Drugs Dermatol. May–Jun. 2004;3(3):315-8. [pmid: 15176169].
396 Chandra PA, Margulis Y, Schiff C. Rituximab is useful in the treatment of Felty’s syndrome. Am J Ther. Jul–Aug. 2008;15(4):321-2. [pmid: 18645332].
397 Chandran V, Schentag CT, Gladman DD. Reappraisal of the effectiveness of methotrexate in psoriatic arthritis: results from a longitudinal observational cohort. J Rheumatol. Mar. 2008;35(3):469-71. [pmid: 18085735].
398 Chandran V, Siannis F, Rahman P, et al. Folate pathway enzyme gene polymorphisms and the efficacy and toxicity of methotrexate in psoriatic arthritis. J Rheumatol. Jul. 2010;37(7):1508-12. [pmid: 20472929].
399 Chang DM, Chang SY, Yeh MK, et al. The pharmacokinetics of interleukin-1 receptor antagonist in Chinese subjects with rheumatoid arthritis. Pharmacol Res. Sep. 2004;50(3):371-6. [pmid: 15225683].
400 Chang DM, Weinblatt ME, Schur PH. The effects of methotrexate on interleukin 1 in patients with rheumatoid arthritis. J Rheumatol. Nov. 1992;19(11):1678-82. [pmid: 1491385].
401 Chang HK, Park W, Ryu DS. Successful treatment of progressive rheumatoid interstitial lung disease with cyclosporine: a case report. J Korean Med Sci. Apr. 2002;17(2):270-3. [pmid: 11961317].
402 Chang J, Girgis L. Clinical use of anti-TNF-alpha biological agents--a guide for GPs. Aust Fam Physician. Dec. 2007;36(12):1035-8. [pmid: 18075630].
403 Chang WH, Katz BJ, Warner JE, et al. A novel method for screening the multifocal electroretonogram in patients using hydroxychloroquine. Retina. Nov–Dec. 2008;28(10):1478-86. [pmid: 18997610].
404 Chantler IW, Davie MW, Evans SF, et al. Oral corticosteroid prescribing in women over 50, use of fracture prevention therapy, and bone densitometry service. Ann Rheum Dis. Apr. 2003;62(4):350-2. [pmid: 12634236].
405 Chapman PT, O’Donnell JL, Moller PW. Rheumatoid pleural effusion: response to intrapleural corticosteroid. J Rheumatol. Mar. 1992;19(3):478-80. [pmid: 1578466].
406 Charabaty S, Shanmugam V. A 65-year-old man with longstanding seropositive rheumatoid arthritis and lower extremity ulceration. Arthritis Rheum. Sep. 15. 2009;61(9):1275-80. [pmid: 19714596].
407 Charles PJ, Smeenk RJ, De Jong J, et al. Assessment of antibodies to double-stranded DNA induced in rheumatoid arthritis patients following treatment with infliximab, a monoclonal antibody to tumor necrosis factor alpha: findings in open-label and randomized placebo-controlled trials. Arthritis Rheum. Nov. 2000;43(11):2383-90. [pmid: 11083258].
408 Charles-Schoeman C, Watanabe J, Lee YY, et al. Abnormal function of high-density lipoprotein is associated with poor disease control and an altered protein cargo in rheumatoid arthritis. Arthritis Rheum. Oct. 2009;60(10):2870-9. [pmid: 19790070].
409 Chatterjee S. Severe interstitial pneumonitis associated with infliximab therapy. Scand J Rheumatol. 2004;33(4):276-7. [pmid: 15370726].
410 Chatzikyriakidou A, Georgiou I, Voulgari PV, et al. Transcription regulatory polymorphism -43T>C in the 5′-flanking region of SLC19A1 gene could affect rheumatoid arthritis patient response to methotrexate therapy. Rheumatol Int. Sep. 2007;27(11):1057-61. [pmid: 17404734].
411 Chauhan A, Mikulik Z, Hackshaw KV. Multicentric reticulohistiocytosis with positive anticyclic citrullinated antibodies. J Natl Med Assoc. Jun. 2007;99(6):678-80. [pmid: 17595939].
412 Chaveiro MA, Vieira R, Cardoso J, et al. Cutaneous infection due to Scedosporium apiospermum in an immunosuppressed patient. J Eur Acad Dermatol Venereol. Jan. 2003;17(1):47-9. [pmid: 12602968].
413 Chavez-Lopez MA, Delgado-Villafana J, Gallaga A, et al. Severe anaphylactic reaction during the second infusion of infliximab in a patient with psoriatic arthritis. Allergol Immunopathol (Madr). Sep–Oct. 2005;33(5):291-2. [pmid: 16287551].
414 Cheema GS, Quismorio FP Jr. Pulmonary involvement in adult-onset Still’s disease. Curr Opin Pulm Med. Sep. 1999;5(5):305-9. [pmid: 10461535].
415 Chen DY, Shen GH, Hsieh TY, et al. Effectiveness of the combination of a whole-blood interferon-gamma assay and the tuberculin skin test in detecting latent tuberculosis infection in rheumatoid arthritis patients receiving adalimumab therapy. Arthritis Rheum. Jun. 15. 2008;59(6):800-6. [pmid: 18512714].
416 Chen HA, Lin KC, Chen CH, et al. The effect of etanercept on anti-cyclic citrullinated peptide antibodies and rheumatoid factor in patients with rheumatoid arthritis. Ann Rheum Dis. Jan. 2006;65(1):35-9. [pmid: 15975966].
417 Chen YC, Hsu SW. Tuberculous arthritis mimic arthritis of the Sjogren’s syndrome: findings from sonography, computed tomography and magnetic resonance images. Eur J Radiol. Dec. 2001;40(3):232-5. [pmid: 11731212].
418 Chen YC, Yang WC, Yang AH, et al. Primary Sjogren’s syndrome associated with Gitelman’s syndrome presenting with muscular paralysis. Am J Kidney Dis. Sep. 2003;42(3):586-90. [pmid: 12955689].
419 Cheung KK, Chow KM, Szeto CC, et al. Fatal pancytopenia in a hemodialysis patient after treatment with low-dose methotrexate. J Clin Rheumatol. Jun. 2009;15(4):177-80. [pmid: 19502905].
420 Chevillotte-Maillard H, Ornetti P, Mistrih R, et al. Survival and safety of treatment with infliximab in the elderly population. Rheumatology (Oxford). May. 2005;44(5):695-6. [pmid: 15705631].
421 Chew AL, Bennett A, Smith CH, et al. Successful treatment of severe psoriasis and psoriatic arthritis with adalimumab. Br J Dermatol. Aug. 2004;151(2):492-6. [pmid: 15327561].
422 Chikanza IC, Petrou P, Kingsley G, et al. Defective hypothalamic response to immune and inflammatory stimuli in patients with rheumatoid arthritis. Arthritis Rheum. Nov. 1992;35(11):1281-8. [pmid: 1445443].
423 Chikanza IC, Roux-Lombard P, Dayer JM, et al. Dysregulation of the in vivo production of interleukin-1 receptor antagonist in patients with rheumatoid arthritis. Pathogenetic implications. Arthritis Rheum. May. 1995;38(5):642-8. [pmid: 7748221].
424 Chikkamuniyappa S. Streptococcal toxic shock syndrome and sepsis manifesting in a patient with chronic rheumatoid arthritis. Dermatol Online J. 2004;10(1):7. [pmid: 15347489].
425 Chikura B, Sathi N, Lane S, et al. Variation of immunological response in methotrexate-induced pneumonitis. Rheumatology (Oxford). Nov. 2008;47(11):1647-50. [pmid: 18812430].
426 Chilton F, Collett RA. Treatment choices, preferences and decision-making by patients with rheumatoid arthritis. Musculoskeletal Care. Mar. 2008;6(1):1-14. [pmid: 17726671].
427 Chim CS, Pang YY, Ooi GC, et al. EBV-associated synovial lymphoma in a chronically inflamed joint in rheumatoid arthritis receiving prolonged methotrexate treatment. Haematologica. Aug. 2006;91(8 Suppl):ECR31. [pmid: 16923515].
428 Chiou CF, Sherbourne CD, Cornelio I, et al. Revalidation of the original Cedars-Sinai health-related quality of life in rheumatoid arthritis questionnaire. J Rheumatol. Feb. 2006;33(2):256-62. [pmid: 16465655].
429 Cho I, Mori S, Imamura F, et al. Methotrexate pneumonia lacking dyspnea and radiographic interstitial patterns during treatment for early rheumatoid arthritis: bronchoalveolar lavage and transbronchial lung biopsy in a differential diagnosis. Mod Rheumatol. 2007;17(3):256-61. [pmid: 17564786].
430 Choi SW, Ahn JJ, Hwang YT, et al. A case of tuberculous arthritis following the use of etanercept. Korean J Intern Med. Dec. 2009;24(4):397-401. [pmid: 19949742].
431 Chomarat P, Vannier E, Dechanet J, et al. Balance of IL-1 receptor antagonist/IL-1 beta in rheumatoid synovium and its regulation by IL-4 and IL-10. J Immunol. Feb. 1. 1995;154(3):1432-9. [pmid: 7822808].
432 Chopin F, Garnero P, le Henanff A, et al. Long-term effects of infliximab on bone and cartilage turnover markers in patients with rheumatoid arthritis. Ann Rheum Dis. Mar. 2008;67(3):353-7. [pmid: 17644538].
433 Chopra A, Saluja M, Lagu-Joshi V, et al. Leflunomide (Arava) is a useful DMARD in Indian (Asian) patients: a clinic-based observational study of 1-year treatment. Clin Rheumatol. 2008;27(8):1039-44. [pmid: 18470473].
434 Chou CT. The clinical application of etanercept in Chinese patients with rheumatic diseases. Mod Rheumatol. 2006;16(4):206-13. [pmid: 16906369].
435 Choy EH, Isenberg DA, Garrood T, et al. Therapeutic benefit of blocking interleukin-6 activity with an anti-interleukin-6 receptor monoclonal antibody in rheumatoid arthritis: a randomized, double-blind, placebo-controlled, dose-escalation trial. Arthritis Rheum. Dec. 2002;46(12):3143-50. [pmid: 12483717].
436 Choy EH, Smith CM, Farewell V, et al. Factorial randomised controlled trial of glucocorticoids and combination disease modifying drugs in early rheumatoid arthritis. Ann Rheum Dis. 2008;67(5):656-63. [pmid: 17768173].
437 Chung CP, Oeser A, Solus JF, et al. Inflammation-associated insulin resistance: differential effects in rheumatoid arthritis and systemic lupus erythematosus define potential mechanisms. Arthritis Rheum. Jul. 2008;58(7):2105-12. [pmid: 18576352].
438 Chung CP, Russell AS, Segami MI, et al. The effect of low-dose prednisone on bone mineral density in Peruvian rheumatoid arthritis patients. Rheumatol Int. Mar. 2005;25(2):114-7. [pmid: 14628151].
439 Ciboddo G, Idone C. Treatment of renal amyloidosis in rheumatoid arthritis requires further investigation: comment on the case report by Elkayam et al. Arthritis Rheum. Nov. 2003;48(11):3299. author reply - 300. [pmid: 14613302].
440 Cisternas M, Gutierrez M, Jacobelli S. Successful rechallenge with anti-tumor necrosis factor alpha for psoriatic arthritis after development of demyelinating nervous system disease during initial treatment: comment on the article by Mohan et al. Arthritis Rheum. Nov. 2002;46(11):3107-8. author reply 8–9. [pmid: 12428265].
441 Clark W, Jobanputra P, Barton P, et al. The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis. Health Technol Assess. May. 2004;8(18):iii-iv. ix. x. 1. 105.
442 Clarke LE, Junkins-Hopkins J, Seykora JT, et al. Methotrexate-associated lymphoproliferative disorder in a patient with rheumatoid arthritis presenting in the skin. J Am Acad Dermatol. Apr. 2007;56(4):686-90. [pmid: 17141365].
443 Cleland LG, Caughey GE, James MJ, et al. Reduction of cardiovascular risk factors with longterm fish oil treatment in early rheumatoid arthritis. J Rheumatol. Oct. 2006;33(10):1973-9. [pmid: 16881100].
444 Clelland S, Hunek JR. Etanercept injection site reaction. Dermatol Nurs. Oct. 2005;17(5):375. [pmid: 16294944].
445 Clementine RR, Lyman J, Zakem J, et al. Tumor necrosis factor-alpha antagonist-induced sarcoidosis. J Clin Rheumatol. Sep. 2010;16(6):274-9. [pmid: 20808167].
446 Clifford LJ, Rossiter JD. Peripheral visual field loss following treatment with etanercept. Br J Ophthalmol. Jun. 2004;88(6):842. [pmid: 15148232].
447 Clunie G, Voules S, Watts R. Dose reduction of etanercept--can we treat more patients using a fixed budget?. Rheumatology (Oxford). Apr. 2003;42(4):600-1. [pmid: 12649411].
448 Coates LC, Cawkwell LS, Ng NW, et al. Sustained response to long-term biologics and switching in psoriatic arthritis: results from real life experience. Ann Rheum Dis. May. 2008;67(5):717-9. [pmid: 18055476].
449 Cobo Ibanez T, Yehia Tayel M, Balsa Criado A, et al. Safety and efficacy of leflunomide and infliximab versus methotrexate and infliximab combination therapy in rheumatoid arthritis. Rheumatology (Oxford). Nov. 2005;44(11):1467-8. [pmid: 16174647].
450 Coca A, Sanz I. B cell depletion in lupus and Sjogren’s syndrome: an update. Curr Opin Rheumatol. Sep. 2009;21(5):483-8. [pmid: 19644378].
451 Cocito D, Bergamasco B, Tavella A, et al. Multifocal motor neuropathy during treatment with infliximab. J Peripher Nerv Syst. Dec. 2005;10(4):386-7. [pmid: 16279990].
452 Cohen CD, Horster S, Sander CA, et al. Kaposi’s sarcoma associated with tumour necrosis factor alpha neutralising therapy. Ann Rheum Dis. Jul. 2003;62(7):684. [pmid: 12810439].
453 Cohen G, Courvoisier N, Cohen JD, et al. The efficiency of switching from infliximab to etanercept and vice-versa in patients with rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2005;23(6):795-800. [pmid: 16396697].
454 Cohen J. Still looking for the cause of fever?. Crit Care Resusc. Jun. 2006;8(2):155-6. [pmid: 16749886].
455 Cohen JD, Bournerias I, Buffard V, et al. Psoriasis induced by tumor necrosis factor-alpha antagonist therapy: a case series. J Rheumatol. Feb. 2007;34(2):380-5. [pmid: 17013997].
456 Cohen JD, Zaltni S, Kaiser MJ, et al. Secondary addition of methotrexate to partial responders to etanercept alone is effective in severe rheumatoid arthritis. Ann Rheum Dis. Feb. 2004;63(2):209-10. [pmid: 14722213].
457 Cohen MD, Conn DL. Benefits of low-dose corticosteroids in rheumatoid arthritis. Bull Rheum Dis. Jun. 1997;46(4):4-7. [pmid: 9188203].
458 Cohen S, Hurd E, Cush J, et al. Treatment of rheumatoid arthritis with anakinra, a recombinant human interleukin-1 receptor antagonist, in combination with methotrexate: results of a twenty-four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Mar. 2002;46(3):614-24. [pmid: 11920396].
459 Cohen SB, Cheng TT, Chindalore V, et al. Evaluation of the efficacy and safety of pamapimod, a p38 MAP kinase inhibitor, in a double-blind, methotrexate-controlled study of patients with active rheumatoid arthritis. Arthritis Rheum. Feb. 2009;60(2):335-44. [pmid: 19180516].
460 Cohen SB, Dore RK, Lane NE, et al. Denosumab treatment effects on structural damage, bone mineral density, and bone turnover in rheumatoid arthritis: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, phase II clinical trial. Arthritis Rheum. May. 2008;58(5):1299-309. [pmid: 18438830].
461 Cohen SB, Keystone E, Genovese MC, et al. Continued inhibition of structural damage over 2 years in patients with rheumatoid arthritis treated with rituximab in combination with methotrexate. Ann Rheum Dis. 2010;69(6):1158-61. [pmid: 20439295].
462 Cohen SB, Moreland LW, Cush JJ, et al. A multicentre, double blind, randomised, placebo controlled trial of anakinra (Kineret), a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis treated with background methotrexate. Ann Rheum Dis. Sep. 2004;63(9):1062-8. [pmid: 15082469].
463 Cohen SB, Strand V, Aguilar D, et al. Patient- versus physician-reported outcomes in rheumatoid arthritis patients treated with recombinant interleukin-1 receptor antagonist (anakinra) therapy. Rheumatology (Oxford). Jun. 2004;43(6):704-11. [pmid: 14997006].
464 Cohen SB, Woolley JM, Chan W. Interleukin 1 receptor antagonist anakinra improves functional status in patients with rheumatoid arthritis. J Rheumatol. Feb. 2003;30(2):225-31. [pmid: 12563672].
465 Cole J, Busti A, Kazi S. The incidence of new onset congestive heart failure and heart failure exacerbation in Veteran’s Affairs patients receiving tumor necrosis factor alpha antagonists. Rheumatol Int. 2007;27(4):369-73. [pmid: 17028862].
466 Cole JC, Li T, Lin P, et al. Treatment impact on estimated medical expenditure and job loss likelihood in rheumatoid arthritis: re-examining quality of life outcomes from a randomized placebo-controlled clinical trial with abatacept. Rheumatology (Oxford). Jul. 2008;47(7):1044-50. [pmid: 18487628].
467 Coluccia D, Wolf OT, Kollias S, et al. Glucocorticoid therapy-induced memory deficits: acute versus chronic effects. J Neurosci. Mar. 26. 2008;28(13):3474-8. [pmid: 18367613].
468 Colwell CW Jr, Robinson CA, Stevenson DD, et al. Osteonecrosis of the femoral head in patients with inflammatory arthritis or asthma receiving corticosteroid therapy. Orthopedics. Nov. 1996;19(11):941-6. [pmid: 8936529].
469 Combe B, Codreanu C, Fiocco U, et al. Efficacy, safety and patient-reported outcomes of combination etanercept and sulfasalazine versus etanercept alone in patients with rheumatoid arthritis: a double-blind randomised 2-year study. Ann Rheum Dis. 2009;68(7):1146-52. [pmid: 18794178].
470 Comby E, Tanaff P, Mariotte D, et al. Evolution of antinuclear antibodies and clinical patterns in patients with active rheumatoid arthritis with longterm infliximab therapy. J Rheumatol. Jan. 2006;33(1):24-30. [pmid: 16395746].
471 Conaghan PG, O’Connor P, McGonagle D, et al. Elucidation of the relationship between synovitis and bone damage: a randomized magnetic resonance imaging study of individual joints in patients with early rheumatoid arthritis. Arthritis Rheum. Jan. 2003;48(1):64-71. [pmid: 12528105].
472 Constantinescu F, Goucher S, Weinstein A, et al. Racial disparities in treatment preferences for rheumatoid arthritis. Med Care. Mar. 2009;47(3):350-5. [pmid: 19165120].
473 Constantinou M, Jhanji V, Tao LW, et al. Clinical review of corneal ulcers resulting in evisceration and enucleation in elderly population. Graefes Arch Clin Exp Ophthalmol. Oct. 2009;247(10):1389-93. [pmid: 19475415].
474 Conti A, Sartorio A, Ferrero S, et al. Modifications of biochemical markers of bone and collagen turnover during corticosteroid therapy. J Endocrinol Invest. Feb. 1996;19(2):127-30. [pmid: 8778165].
475 Conti F, Ceccarelli F, Marocchi E, et al. Switching tumour necrosis factor alpha antagonists in patients with ankylosing spondylitis and psoriatic arthritis: an observational study over a 5-year period. Ann Rheum Dis. Oct. 2007;66(10):1393-7. [pmid: 17613555].
476 Conti F, Priori R, Chimenti MS, et al. Successful treatment with intraarticular infliximab for resistant knee monarthritis in a patient with spondylarthropathy: a role for scintigraphy with 99mTc-infliximab. Arthritis Rheum. Apr. 2005;52(4):1224-6. [pmid: 15818709].
477 Contreras-Yanez I, Ponce De Leon S, Cabiedes J, et al. Inadequate therapy behavior is associated to disease flares in patients with rheumatoid arthritis who have achieved remission with disease-modifying antirheumatic drugs. Am J Med Sci. Oct. 2010;340(4):282-90. [pmid: 20881757].
478 Cooper C, Coupland C, Mitchell M. Rheumatoid arthritis, corticosteroid therapy and hip fracture. Ann Rheum Dis. Jan. 1995;54(1):49-52. [pmid: 7880122].
479 Cordero-Coma M, Anzaar F, Sobrin L, et al. Systemic immunomodulatory therapy in severe dry eye secondary to inflammation. Ocul Immunol Inflamm. Mar–Apr. 2007;15(2):99-104. [pmid: 17558834].
480 Cordiali-Fei P, Trento E, D’Agosto G, et al. Effective therapy with anti-TNF-alpha in patients with psoriatic arthritis is associated with decreased levels of metalloproteinases and angiogenic cytokines in the sera and skin lesions. Ann N Y Acad Sci. Sep. 2007;1110:578-89. [pmid: 17911474].
481 Corrao S, Pistone G, Arnone S, et al. Safety of etanercept therapy in rheumatoid patients undergoing surgery: preliminary report. Clin Rheumatol. Sep. 2007;26(9):1513-5. [pmid: 17225928].
482 Corsi F, Previde P, Colombo F, et al. Two cases of intestinal perforation in patients on anti-rheumatic treatment with etanercept. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):113. [pmid: 16539834].
483 Cortet B, Flipo RM, Pigny P, et al. How useful are bone turnover markers in rheumatoid arthritis? Influence of disease activity and corticosteroid therapy. Rev Rhum Engl Ed. Mar. 1997;64(3):153-9. [pmid: 9090763].
484 Cortet B, Guyot MH, Solau E, et al. Factors influencing bone loss in rheumatoid arthritis: a longitudinal study. Clin Exp Rheumatol. Nov–Dec. 2000;18(6):683-90. [pmid: 11138329].
485 Cortot AB, Cottin V, Miossec P, et al. Improvement of refractory rheumatoid arthritis-associated constrictive bronchiolitis with etanercept. Respir Med. Apr. 2005;99(4):511-4. [pmid: 15763460].
486 Courtney PA, Alderdice J, Whitehead EM. Comment on methotrexate pneumonitis after initiation of infliximab therapy for rheumatoid arthritis. Arthritis Rheum. Aug. 15. 2003;49(4):617. author reply -8. [pmid: 12910574].
487 Coury F, Ferraro-Peyret C, Le Cam S, et al. Peripheral blood lymphocytes from patients with rheumatoid arthritis are differentially sensitive to apoptosis induced by anti-tumour necrosis factor-alpha therapy. Clin Exp Rheumatol. Mar–Apr. 2008;26(2):234-9. [pmid: 18565243].
488 Covelli M, Scioscia C, Iannone F, et al. Repeated infusions of low-dose infliximab plus methotrexate in psoriatic arthritis: immediate benefits are not maintained after discontinuation of infliximab. Clin Exp Rheumatol. Mar–Apr. 2005;23(2):145-51. [pmid: 15895882].
489 Coyle CM, Weiss LM, Rhodes LV 3rd, et al. Fatal myositis due to the microsporidian Brachiola algerae, a mosquito pathogen. N Engl J Med. Jul. 1. 2004;351(1):42-7. [pmid: 15229306].
490 Cracchiolo A 3rd, Severt R, Moreland J. Uncemented total hip arthroplasty in rheumatoid arthritis diseases. A two- to six-year follow-up study. Clin Orthop Relat Res. Apr. 1992;(277):166-74. [pmid: 1555338].
491 Creamer P, Keen M, Zananiri F, et al. Quantitative magnetic resonance imaging of the knee: a method of measuring response to intra-articular treatments. Ann Rheum Dis. Jun. 1997;56(6):378-81. [pmid: 9227168].
492 Creemers MC, Franssen MJ, van de Putte LB, et al. Methotrexate in severe ankylosing spondylitis: an open study. J Rheumatol. Jun. 1995;22(6):1104-7. [pmid: 7674237].
493 Crellin AM, Shareef DS, Maher EJ. Opportunistic Listeria pericardial effusion. Postgrad Med J. Mar. 1990;66(773):203-4. [pmid: 2362887].
494 Crilly A, Maiden N, Capell HA, et al. Predictive value of interleukin 1 gene polymorphisms for surgery. Ann Rheum Dis. Sep. 2000;59(9):695-9. [pmid: 10976082].
495 Criswell LA, Lum RF, Turner KN, et al. The influence of genetic variation in the HLA-DRB1 and LTA-TNF regions on the response to treatment of early rheumatoid arthritis with methotrexate or etanercept. Arthritis Rheum. Sep. 2004;50(9):2750-6. [pmid: 15457442].
496 Crnkic M, Mansson B, Larsson L, et al. Serum cartilage oligomeric matrix protein (COMP) decreases in rheumatoid arthritis patients treated with infliximab or etanercept. Arthritis Res Ther. 2003;5(4):R181-5. [pmid: 12823852].
497 Croce A, Firuzi O, Altieri F, et al. Effect of infliximab on the glycosylation of IgG of patients with rheumatoid arthritis. J Clin Lab Anal. 2007;21(5):303-14. [pmid: 17847113].
498 Crofford LJ, Kalogeras KT, Mastorakos G, et al. Circadian relationships between interleukin (IL)-6 and hypothalamic-pituitary-adrenal axis hormones: failure of IL-6 to cause sustained hypercortisolism in patients with early untreated rheumatoid arthritis. J Clin Endocrinol Metab. Apr. 1997;82(4):1279-83. [pmid: 9100607].
499 Crowson CS, Rahman MU, Matteson EL. Which measure of inflammation to use? A comparison of erythrocyte sedimentation rate and C-reactive protein measurements from randomized clinical trials of golimumab in rheumatoid arthritis. J Rheumatol. Aug. 2009;36(8):1606-10. [pmid: 19531760].
500 Cruse LM, Valeriano J, Vasey FB, et al. Prevalence of evaluation and treatment of glucocorticoid-induced osteoporosis in men. J Clin Rheumatol. Oct. 2006;12(5):221-5. [pmid: 17023807].
501 Cuchacovich M, Catalan D, Wainstein E, et al. Basal anti-cyclic citrullinated peptide (anti-CCP) antibody levels and a decrease in anti-CCP titres are associated with clinical response to adalimumab in rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2008;26(6):1067-73. [pmid: 19210871].
502 Cuchacovich M, Ferreira L, Aliste M, et al. Tumour necrosis factor-alpha (TNF-alpha) levels and influence of -308 TNF-alpha promoter polymorphism on the responsiveness to infliximab in patients with rheumatoid arthritis. Scand J Rheumatol. 2004;33(4):228-32. [pmid: 15370717].
503 Cuchacovich M, Soto L, Edwardes M, et al. Tumour necrosis factor (TNF)alpha -308 G/G promoter polymorphism and TNFalpha levels correlate with a better response to adalimumab in patients with rheumatoid arthritis. Scand J Rheumatol. Nov–Dec. 2006;35(6):435-40. [pmid: 17343250].
504 Cuchacovich R, Espinoza CG, Virk Z, et al. Biologic therapy (TNF-alpha antagonists)-induced psoriasis: a cytokine imbalance between TNF-alpha and IFN-alpha?. J Clin Rheumatol. Dec. 2008;14(6):353-6. [pmid: 19033869].
505 Cuchacovich R, Espinoza LR. Does TNF-alpha blockade play any role in cardiovascular risk among rheumatoid arthritis (RA) patients?. Clin Rheumatol. Oct. 2009;28(10):1217-20. [pmid: 19517156].
506 Cui J, Saevarsdottir S, Thomson B, et al. Rheumatoid arthritis risk allele PTPRC is also associated with response to anti-tumor necrosis factor alpha therapy. Arthritis Rheum. 2010;62(7):1849-61. [pmid: 20309874].
507 Culy CR, Keating GM. Etanercept: an updated review of its use in rheumatoid arthritis, psoriatic arthritis and juvenile rheumatoid arthritis. Drugs. 2002;62(17):2493-537. [pmid: 12421111].
508 Cunnane G, Madigan A, Murphy E, et al. The effects of treatment with interleukin-1 receptor antagonist on the inflamed synovial membrane in rheumatoid arthritis. Rheumatology (Oxford). Jan. 2001;40(1):62-9. [pmid: 11157143].
509 Cunnane G, Warnock M, Fye KH, et al. Accelerated nodulosis and vasculitis following etanercept therapy for rheumatoid arthritis. Arthritis Rheum. Aug. 2002;47(4):445-9. [pmid: 12209493].
510 Curkendall S, Patel V, Gleeson M, et al. Compliance with biologic therapies for rheumatoid arthritis: do patient out-of-pocket payments matter?. Arthritis Rheum. Oct. 15. 2008;59(10):1519-26. [pmid: 18821651].
511 Cursiefen C, Grunke M, Dechant C, et al. Multiple bilateral eyelid molluscum contagiosum lesions associated with TNFalpha-antibody and methotrexate therapy. Am J Ophthalmol. Aug. 2002;134(2):270-1. [pmid: 12140038].
512 Curtis JR, Kramer JM, Martin C, et al. Heart failure among younger rheumatoid arthritis and Crohn’s patients exposed to TNF-alpha antagonists. Rheumatology (Oxford). 2007;46(11):1688-93. [pmid: 17938138].
513 Curtis JR, Martin C, Saag KG, et al. Confirmation of administrative claims-identified opportunistic infections and other serious potential adverse events associated with tumor necrosis factor alpha antagonists and disease-modifying antirheumatic drugs. Arthritis Rheum. Mar. 15. 2007;57(2):343-6. [pmid: 17330283].
514 Curtis JR, Patkar N, Xie A, et al. Risk of serious bacterial infections among rheumatoid arthritis patients exposed to tumor necrosis factor alpha antagonists. Arthritis Rheum. 2007;56(4):1125-33. [pmid: 17393394].
515 Curtis JR, Xi J, Patkar N, et al. Drug-specific and time-dependent risks of bacterial infection among patients with rheumatoid arthritis who were exposed to tumor necrosis factor alpha antagonists. Arthritis Rheum. 2007;56(12):4226-7. [pmid: 18050253].
516 Cutolo M, Balleari E, Giusti M, et al. Androgen replacement therapy in male patients with rheumatoid arthritis. Arthritis Rheum. Jan. 1991;34(1):1-5. [pmid: 1824615].
517 Cutolo M, Bisso A, Sulli A, et al. Antiproliferative and antiinflammatory effects of methotrexate on cultured differentiating myeloid monocytic cells (THP-1) but not on synovial macrophages from patients with rheumatoid arthritis. J Rheumatol. Nov. 2000;27(11):2551-7. [pmid: 11093433].
518 Cutolo M, Foppiani L, Minuto F. Hypothalamic-pituitary-adrenal axis impairment in the pathogenesis of rheumatoid arthritis and polymyalgia rheumatica. J Endocrinol Invest. 2002;25(10 Suppl):19-23. [pmid: 12508908].
519 Cutolo M, Foppiani L, Prete C, et al. Hypothalamic-pituitary-adrenocortical axis function in premenopausal women with rheumatoid arthritis not treated with glucocorticoids. J Rheumatol. Feb. 1999;26(2):282-8. [pmid: 9972959].
520 Cutolo M, Maestroni GJ, Otsa K, et al. Circadian melatonin and cortisol levels in rheumatoid arthritis patients in winter time: a north and south Europe comparison. Ann Rheum Dis. Feb. 2005;64(2):212-6. [pmid: 15647428].
521 Cutolo M, Villaggio B, Pizzorni C, et al. Inflammatory gene profile in early rheumatoid arthritis and modulation by leflunomide and prednisone treatment. Ann N Y Acad Sci. Apr. 2010;1193(1):15-21. [pmid: 20398002].
522 Cvetkovic JT, Wallberg-Jonsson S, Stegmayr B, et al. Susceptibility for and clinical manifestations of rheumatoid arthritis are associated with polymorphisms of the TNF-alpha, IL-1beta, and IL-1Ra genes. J Rheumatol. Feb. 2002;29(2):212-9. [pmid: 11838837].
523 Cypiene A, Laucevicius A, Venalis A, et al. Non-invasive assessment of arterial stiffness indices by applanation tonometry and pulse wave analysis in patients with rheumatoid arthritis treated with TNF-alpha blocker remicade (infliximab). Proc West Pharmacol Soc. 2007;50:119-22. [pmid: 18605247].
524 D’Acquisto F, Paschalidis N, Raza K, et al. Glucocorticoid treatment inhibits annexin-1 expression in rheumatoid arthritis CD4+ T cells. Rheumatology (Oxford). May. 2008;47(5):636-9. [pmid: 18390587].
525 Dagci H, Zeyrek F, Gerzile YK, et al. A case of myiasis in a patient with psoriasis from Turkey. Parasitol Int. Jun. 2008;57(2):239-41. [pmid: 18243777].
526 Dahlqvist SR, Engstrand S, Berglin E, et al. Conversion towards an atherogenic lipid profile in rheumatoid arthritis patients during long-term infliximab therapy. Scand J Rheumatol. Mar–Apr. 2006;35(2):107-11. [pmid: 16641043].
527 Dahlqvist SR, Olsson T. Interference with the cortisol axis by the microtubule antagonist, CPH82. Br J Rheumatol. Sep. 1993;32(9):804-6. [pmid: 8396491].
528 Dain L, Braun-Moscovici Y, Baum E, et al. Modification of neutrophil function by plasma of rheumatoid arthritis patients treated with infliximab. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):38-44. [pmid: 16539817].
529 Dalrymple JM, Stamp LK, O’Donnell JL, et al. Pharmacokinetics of oral methotrexate in patients with rheumatoid arthritis. Arthritis Rheum. Nov. 2008;58(11):3299-308. [pmid: 18975321].
530 Damjanov N, Kauffman RS, Spencer-Green GT. Efficacy, pharmacodynamics, and safety of VX-702, a novel p38 MAPK inhibitor, in rheumatoid arthritis: results of two randomized, double-blind, placebo-controlled clinical studies. Arthritis Rheum. May. 2009;60(5):1232-41. [pmid: 19404957].
531 Danko JR, Gilliland WR, Miller RS, et al. Disseminated Mycobacterium marinum infection in a patient with rheumatoid arthritis receiving infliximab therapy. Scand J Infect Dis. 2009;41(4):252-5. [pmid: 19266397].
532 Dans M, Hivnor C, van Voorhees AS. Psoriatic onychopachydermoperiostitis: improvement with etanercept. Br J Dermatol. Oct. 2005;153(4):858-9. [pmid: 16181482].
533 Darabi K, Jaiswal R, Hostetler S, et al. Infectious complications in patients with psoriasis and rheumatoid arthritis treated with antitumor necrosis factor agents and methotrexate. J Drugs Dermatol. Feb. 2009;8(2):175-8. [pmid: 19213235].
534 Darmawan J, Muirden KD, Valkenburg HA, et al. The epidemiology of rheumatoid arthritis in Indonesia. Br J Rheumatol. Jul. 1993;32(7):537-40. [pmid: 8339121].
535 Das P, Raghu P, Amit Kumar D, et al. Strongyloides hyperinfection in rheumatoid arthritis. Int J Surg Pathol. Oct. 2007;15(4):391-2. [pmid: 17913948].
536 Das SK, Pareek A, Mathur DS, et al. Efficacy and safety of hydroxychloroquine sulphate in rheumatoid arthritis: a randomized, double-blind, placebo controlled clinical trial--an Indian experience. Curr Med Res Opin. Sep. 2007;23(9):2227-34. [pmid: 17692155].
537 Dascalu C, Mrejen-Shakin K, Bandagi S. Adalimumab-induced acute pneumonitis in a patient with rheumatoid arthritis. J Clin Rheumatol. Jun. 2010;16(4):172-4. [pmid: 20511978].
538 Dass S, Bowman SJ, Vital EM, et al. Reduction of fatigue in Sjogren syndrome with rituximab: results of a randomised, double-blind, placebo-controlled pilot study. Ann Rheum Dis. Nov. 2008;67(11):1541-4. [pmid: 18276741].
539 Dauendorffer JN, Rivet J, Allard A, et al. Sezary syndrome in a patient receiving infliximab for ankylosing spondylitis. Br J Dermatol. Apr. 2007;156(4):742-3. [pmid: 17263820].
540 D’Auria F, Rovere-Querini P, Giazzon M, et al. Accumulation of plasma nucleosomes upon treatment with anti-tumour necrosis factor-alpha antibodies. J Intern Med. Mar. 2004;255(3):409-18. [pmid: 14871466].
541 Davaine AC, Saraux A, Prigent S, et al. Cutaneous events during treatment of chronic inflammatory joint disorders with anti-tumour necrosis factor alpha: a cross-sectional study. J Eur Acad Dermatol Venereol. Dec. 2008;22(12):1471-7. [pmid: 18713230].
542 Davey M, Buchbinder R. Glucocorticoids in early rheumatoid arthritis. Aust Fam Physician. Jan–Feb. 1. 2008:37-2. 31. 2.
543 Davies K, Stiehm ER, Woo P, et al. Juvenile idiopathic polyarticular arthritis and IgA deficiency in the 22q11 deletion syndrome. J Rheumatol. Oct. 2001;28(10):2326-34. [pmid: 11669177].
544 Davis JC Jr. The role of etanercept in ankylosing spondylitis. Clin Exp Rheumatol. Nov–Dec. 2002;20(6 Suppl 28):S111-5. [pmid: 12463459].
545 Davis JC Jr, Van Der Heijde D, Braun J, et al. Recombinant human tumor necrosis factor receptor (etanercept) for treating ankylosing spondylitis: a randomized, controlled trial. Arthritis Rheum. Nov. 2003;48(11):3230-6. [pmid: 14613288].
546 Davis JC, van der Heijde D, Dougados M, et al. Reductions in health-related quality of life in patients with ankylosing spondylitis and improvements with etanercept therapy. Arthritis Rheum. Aug. 15. 2005;53(4):494-501. [pmid: 16082640].
547 Davis JC, van der Heijde DM, Braun J, et al. Sustained durability and tolerability of etanercept in ankylosing spondylitis for 96 weeks. Ann Rheum Dis. Nov. 2005;64(11):1557-62. [pmid: 15843448].
548 Davis JC Jr, Van der Heijde DM, Dougados M, et al. Baseline factors that influence ASAS 20 response in patients with ankylosing spondylitis treated with etanercept. J Rheumatol. Sep. 2005;32(9):1751-4. [pmid: 16142873].
549 Davis JM 3rd, Maradit Kremers H, Crowson CS, et al. Glucocorticoids and cardiovascular events in rheumatoid arthritis: a population-based cohort study. Arthritis Rheum. Mar. 2007;56(3):820-30. [pmid: 17330254].
550 Davis MC, Zautra AJ, Younger J, et al. Chronic stress and regulation of cellular markers of inflammation in rheumatoid arthritis: implications for fatigue. Brain Behav Immun. Jan. 2008;22(1):24-32. [pmid: 17706915].
551 Day R. Adverse reactions to TNF-alpha inhibitors in rheumatoid arthritis. Lancet. Feb. 16. 2002;359(9306):540-1. [pmid: 11867103].
552 Daza L, Martin-Jimenez R, De la Torre PX, et al. Improvement of ACTH response to insulin tolerance test in female patients with rheumatoid arthritis due to tumor necrosis factor inhibition. Eur J Endocrinol. Jul. 2007;157(1):47-51. [pmid: 17609401].
553 De A, Blotta HM, Mamoni RL, et al. Effects of dexamethasone on lymphocyte proliferation and cytokine production in rheumatoid arthritis. J Rheumatol. Jan. 2002;29(1):46-51. [pmid: 11824970].
554 De Bandt M, Kahn MF. Takayasu’s arteritis associated with Still’s disease in an adult. Clin Exp Rheumatol. Nov–Dec. 1991;9(6):639-40. [pmid: 1684922].
555 De Bandt M, Sibilia J, Le Loet X, et al. Systemic lupus erythematosus induced by anti-tumour necrosis factor alpha therapy: a French national survey. Arthritis Res Ther. 2005;7(3):R545-51. [pmid: 15899041].
556 De Bandt M, Vittecoq O, Descamps V, et al. Anti-TNF-alpha-induced systemic lupus syndrome. Clin Rheumatol. Feb. 2003;22(1):56-61. [pmid: 12605321].
557 De Benedetti F. Targeting interleukin-6 in pediatric rheumatic diseases. Curr Opin Rheumatol. Sep. 2009;21(5):533-7. [pmid: 19593141].
558 De Benedetti F, Pignatti P, Gerloni V, et al. Differences in synovial fluid cytokine levels between juvenile and adult rheumatoid arthritis. J Rheumatol. Jul. 1997;24(7):1403-9. [pmid: 9228145].
559 de’ Clari F, Salani I, Safwan E, et al. Sudden death in a patient without heart failure after a single infusion of 200 mg infliximab: does TNF-alpha have protective effects on the failing heart, or does infliximab have direct harmful cardiovascular effects?. Circulation. May. 28. 2002;105(21):E183. [pmid: 12034672].
560 De Felice C, Mazzotta A, Esposito M, et al. High-dose initiation of etanercept in psoriatic arthritis and plaque psoriasis: efficacy, safety and impact on patients’ quality of life. J Dermatolog Treat. 2006;17(6):355-8. [pmid: 17853309].
561 de Jong JW, van Altena R. Non-respiratory tuberculosis with Mycobacterium tuberculosis after penetrating lesions of the skin: five case histories. Int J Tuberc Lung Dis. Dec. 2000;4(12):1184-7. [pmid: 11144464].
562 de la Torre B, Hedman M, Nilsson E, et al. Relationship between blood and joint tissue DHEAS levels in rheumatoid arthritis and osteoarthritis. Clin Exp Rheumatol. Nov–Dec. 1993;11(6):597-601. [pmid: 8299250].
563 De Leonardis F, Govoni M, Lo Monaco A, et al. Visceral leishmaniasis and anti-TNF-alpha therapy: case report and review of the literature. Clin Exp Rheumatol. May–Jun. 2009;27(3):503-6. [pmid: 19604446].
564 De Miguel S, Jover JA, Vadillo C, et al. B cell activation in rheumatoid arthritis patients under infliximab treatment. Clin Exp Rheumatol. Nov–Dec. 2003;21(6):726-32. [pmid: 14740451].
565 de Nijs RN, Jacobs JW, Bijlsma JW, et al. Prevalence of vertebral deformities and symptomatic vertebral fractures in corticosteroid treated patients with rheumatoid arthritis. Rheumatology (Oxford). Dec. 2001;40(12):1375-83. [pmid: 11752508].
566 de Paz B, Alperi-Lopez M, Ballina-Garcia FJ, et al. Interleukin 10 and tumor necrosis factor-alpha genotypes in rheumatoid arthritis--association with clinical response to glucocorticoids. J Rheumatol. Mar. 2010;37(3):503-11. [pmid: 20080912].
567 De Rosa FG, Shaz D, Campagna AC, et al. Invasive pulmonary aspergillosis soon after therapy with infliximab, a tumor necrosis factor-alpha-neutralizing antibody: a possible healthcare-associated case?. Infect Control Hosp Epidemiol. Jul. 2003;24(7):477-82. [pmid: 12887234].
568 De Rycke L, Baeten D, Foell D, et al. Differential expression and response to anti-TNFalpha treatment of infiltrating versus resident tissue macrophage subsets in autoimmune arthritis. J Pathol. May. 2005;206(1):17-27. [pmid: 15809977].
569 De Rycke L, Baeten D, Kruithof E, et al. Infliximab, but not etanercept, induces IgM anti-double-stranded DNA autoantibodies as main antinuclear reactivity: biologic and clinical implications in autoimmune arthritis. Arthritis Rheum. Jul. 2005;52(7):2192-201. [pmid: 15986349].
570 De Rycke L, Kruithof E, Van Damme N, et al. Antinuclear antibodies following infliximab treatment in patients with rheumatoid arthritis or spondylarthropathy. Arthritis Rheum. Apr. 2003;48(4):1015-23. [pmid: 12687543].
571 De Rycke L, Vandooren B, Kruithof E, et al. Tumor necrosis factor alpha blockade treatment down-modulates the increased systemic and local expression of Toll-like receptor 2 and Toll-like receptor 4 in spondylarthropathy. Arthritis Rheum. Jul. 2005;52(7):2146-58. [pmid: 15986373].
572 De Rycke L, Verhelst X, Kruithof E, et al. Rheumatoid factor, but not anti-cyclic citrullinated peptide antibodies, is modulated by infliximab treatment in rheumatoid arthritis. Ann Rheum Dis. Feb. 2005;64(2):299-302. [pmid: 15166003].
573 de Seze J, Delalande S, Fauchais AL, et al. Myelopathies secondary to Sjogren’s syndrome: treatment with monthly intravenous cyclophosphamide associated with corticosteroids. J Rheumatol. Apr. 2006;33(4):709-11. [pmid: 16583474].
574 De Stefano R, Frati E, Nargi F, et al. Comparison of combination therapies in the treatment of rheumatoid arthritis: leflunomide-anti-TNF-alpha versus methotrexate-anti-TNF-alpha. Clin Rheumatol. 2010;29(5):517-24. [pmid: 20082236].
575 de Thurah A, Norgaard M, Johansen M, et al. Time to methotrexate treatment in patients with rheumatoid arthritis referred to hospital. Scand J Rheumatol. 2010;39(1):19-25. [pmid: 20132066].
576 de Thurah A, Norgaard M, Johansen MB, et al. Methotrexate compliance among patients with rheumatoid arthritis: the influence of disease activity, disease duration, and co-morbidity in a 10-year longitudinal study. Scand J Rheumatol. May. 2010;39(3):197-205. [pmid: 20085505].
577 De Vita S, Zaja F, Sacco S, et al. Efficacy of selective B cell blockade in the treatment of rheumatoid arthritis: evidence for a pathogenetic role of B cells. Arthritis Rheum. Aug. 2002;46(8):2029-33. [pmid: 12209504].
578 de Vries-Bouwstra JK, Goekoop-Ruiterman YP, Verpoort KN, et al. Progression of joint damage in early rheumatoid arthritis: association with HLA-DRB1, rheumatoid factor, and anti-citrullinated protein antibodies in relation to different treatment strategies. Arthritis Rheum. May. 2008;58(5):1293-8. [pmid: 18438829].
579 de Vries-Bouwstra JK, Goekoop-Ruiterman YP, Wesoly J, et al. Ex vivo interleukin 1 receptor antagonist production on lipopolysaccharide stimulation is associated with rheumatoid arthritis and with joint damage. Ann Rheum Dis. Aug. 2007;66(8):1033-7. [pmid: 17223662].
580 de Winter S, van Buchem MA, Vermeer MH. Annular erythema of Sjogren’s syndrome. Lancet. May. 13. 2006;367(9522):1604. [pmid: 16698414].
581 Debiais S, Maillot F, Luca L, et al. Efficacy of anakinra in a case of refractory Still disease. J Clin Rheumatol. Dec. 2008;14(6):357-8. [pmid: 19033875].
582 Deighton CM, Watson MJ, Walker DJ. Sex hormones in postmenopausal HLA-identical rheumatoid arthritis discordant sibling pairs. J Rheumatol. Nov. 1992;19(11):1663-7. [pmid: 1491383].
583 Dekkers JC, Geenen R, Godaert GL, et al. Experimentally challenged reactivity of the hypothalamic pituitary adrenal axis in patients with recently diagnosed rheumatoid arthritis. J Rheumatol. Jul. 2001;28(7):1496-504. [pmid: 11469453].
584 del Porto F, Aloe L, Lagana B, et al. Nerve growth factor and brain-derived neurotrophic factor levels in patients with rheumatoid arthritis treated with TNF-alpha blockers. Ann N Y Acad Sci. Jun. 2006;1069:438-43. [pmid: 16855171].
585 Del Porto F, Lagana B, Lai S, et al. Response to anti-tumour necrosis factor alpha blockade is associated with reduction of carotid intima-media thickness in patients with active rheumatoid arthritis. Rheumatology (Oxford). Jul. 2007;46(7):1111-5. [pmid: 17449484].
586 Delabaye I, De Keyser F. 74-week follow-up of safety of infliximab in patients with refractory rheumatoid arthritis. Arthritis Res Ther. 2010;12(3):R121. [pmid: 20569501].
587 Delaunay C, Farrenq V, Marini-Portugal A, et al. Infliximab to etanercept switch in patients with spondyloarthropathies and psoriatic arthritis: preliminary data. J Rheumatol. Nov. 2005;32(11):2183-5. [pmid: 16265699].
588 Delmez JA, Dusso AS, Slatopolsky E, et al. Modulation of renal osteodystrophy by extrarenal production of calcitriol. Am J Nephrol. 1995;15(1):85-9. [pmid: 7872371].
589 Demir H, Kelestimur F, Tunc M, et al. Hypothalamo-pituitary-adrenal axis and growth hormone axis in patients with rheumatoid arthritis. Scand J Rheumatol. 1999;28(1):41-6. [pmid: 10092164].
590 den Broeder A, van de Putte L, Rau R, et al. A single dose, placebo controlled study of the fully human anti-tumor necrosis factor-alpha antibody adalimumab (D2E7) in patients with rheumatoid arthritis. J Rheumatol. Nov. 2002;29(11):2288-98. [pmid: 12415583].
591 den Broeder AA, Assmann KJ, van Riel PL, et al. Nephrotic syndrome as a complication of anti-TNFalpha in a patient with rheumatoid arthritis. Neth J Med. Apr. 2003;61(4):137-41. [pmid: 12852723].
592 den Broeder AA, Creemers MC, Fransen J, et al. Risk factors for surgical site infections and other complications in elective surgery in patients with rheumatoid arthritis with special attention for anti-tumor necrosis factor: a large retrospective study. J Rheumatol. 2007;34(4):689-95. [pmid: 17117492].
593 Den Broeder AA, Creemers MC, van Gestel AM, et al. Dose titration using the Disease Activity Score (DAS28) in rheumatoid arthritis patients treated with anti-TNF-alpha. Rheumatology (Oxford). Jun. 2002;41(6):638-42. [pmid: 12048289].
594 den Broeder AA, Joosten LA, Saxne T, et al. Long term anti-tumour necrosis factor alpha monotherapy in rheumatoid arthritis: effect on radiological course and prognostic value of markers of cartilage turnover and endothelial activation. Ann Rheum Dis. Apr. 2002;61(4):311-8. [pmid: 11874832].
595 den Broeder AA, Wanten GJ, Oyen WJ, et al. Neutrophil migration and production of reactive oxygen species during treatment with a fully human anti-tumor necrosis factor-alpha monoclonal antibody in patients with rheumatoid arthritis. J Rheumatol. Feb. 2003;30(2):232-7. [pmid: 12563673].
596 Denault A, Dimopoulos MA, Fitzcharles MA. Meningoencephalitis and peripheral neuropathy complicating adult Still’s disease. J Rheumatol. May. 1990;17(5):698-700. [pmid: 2162962].
597 Deng A, Harvey V, Sina B, et al. Interstitial granulomatous dermatitis associated with the use of tumor necrosis factor alpha inhibitors. Arch Dermatol. Feb. 2006;142(2):198-202. [pmid: 16490847].
598 Denis B, Lefort A, Flipo RM, et al. Long-term follow-up of patients with tuberculosis as a complication of tumour necrosis factor (TNF)-alpha antagonist therapy: safe re-initiation of TNF-alpha blockers after appropriate anti-tuberculous treatment. Clin Microbiol Infect. Feb. 2008;14(2):183-6. [pmid: 18076664].
599 Deodhar A, Allen E, Daoud K, et al. Vasculitis secondary to staphylococcal Protein A immunoadsorption (Prosorba column) treatment in rheumatoid arthritis. Semin Arthritis Rheum. Aug. 2002;32(1):3-9. [pmid: 12219317].
600 Dequeker J, Borghs H, Van Cleemput J, et al. Transplantation osteoporosis and corticosteroid-induced osteoporosis in autoimmune diseases: experience with alfacalcidol. Z Rheumatol. 2000;59(Suppl 1):53-7. [pmid: 10769438].
601 Dereure O, Guillot B, Jorgensen C, et al. Psoriatic lesions induced by antitumour necrosis factor-alpha treatment: two cases. Br J Dermatol. Aug. 2004;151(2):506-7. [pmid: 15327565].
602 Derot G, Marini-Portugal A, Maitre B, et al. Marked regression of pulmonary rheumatoid nodules under etanercept therapy. J Rheumatol. Feb. 2009;36(2):437-9. [pmid: 19208569].
603 Dervieux T, Greenstein N, Kremer J. Pharmacogenomic and metabolic biomarkers in the folate pathway and their association with methotrexate effects during dosage escalation in rheumatoid arthritis. Arthritis Rheum. Oct. 2006;54(10):3095-103. [pmid: 17009228].
604 Desai D, Goldbach-Mansky R, Milner JD, et al. Anaphylactic reaction to anakinra in a rheumatoid arthritis patient intolerant to multiple nonbiologic and biologic disease-modifying antirheumatic drugs. Ann Pharmacother. May. 2009;43(5):967-72. [pmid: 19417117].
605 Despaux J, Manzoni P, Toussirot E, et al. Prospective study of the prevalence of bronchiectasis in rheumatoid arthritis using high-resolution computed tomography. Rev Rhum Engl Ed. Jul–Sep. 1998;65(7–9):453-61. [pmid: 9785391].
606 Dessein PH, Joffe BI. Suppression of circulating interleukin-6 concentrations is associated with decreased endothelial activation in rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 2006;24(2):161-7. [pmid: 16762151].
607 Dessein PH, Joffe BI, Stanwix AE, et al. Hyposecretion of the adrenal androgen dehydroepiandrosterone sulfate and its relation to clinical variables in inflammatory arthritis. Arthritis Res. 2001;3(3):183-8. [pmid: 11299059].
608 Dessein PH, Woodiwiss AJ, Joffe BI, et al. Aminotransferases are associated with insulin resistance and atherosclerosis in rheumatoid arthritis. BMC Cardiovasc Disord. 2007;7:31. [pmid: 17967187].
609 Devauchelle-Pensec V, Pennec Y, Morvan J, et al. Improvement of Sjogren’s syndrome after two infusions of rituximab (anti-CD20). Arthritis Rheum. Mar. 15. 2007;57(2):310-7. [pmid: 17330280].
610 Devos SA, Van Den Bossche N, De Vos M, et al. Adverse skin reactions to anti-TNF-alpha monoclonal antibody therapy. Dermatology. 2003;206(4):388-90. [pmid: 12771494].
611 Dhaille F, Viseux V, Caudron A, et al. Cutaneous sarcoidosis occurring during anti-TNF-alpha treatment: report of two cases. Dermatology. 2010;220(3):234-7. [pmid: 20185892].
612 di Comite G, Marinosci A, Di Matteo P, et al. Neuroendocrine modulation induced by selective blockade of TNF-alpha in rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2006;1069:428-37. [pmid: 16855170].
613 Di Poi E, Perin A, Morassi MP, et al. Switching to etanercept in patients with rheumatoid arthritis with no response to infliximab. Clin Exp Rheumatol. Jan–Feb. 2007;25(1):85-7. [pmid: 17417995].
614 Dichamp I, Bourgeois A, Dirand C, et al. Increased nuclear factor-kappaB activation in peripheral blood monocytes of patients with rheumatoid arthritis is mediated primarily by tumor necrosis factor-alpha. J Rheumatol. Oct. 2007;34(10):1976-83. [pmid: 17896809].
615 Dilek K, Ali I, Goksal K, et al. The effects of sulphasalazine on urinary excretion of the hydroxypyridinium crosslinks of collagen in patients with rheumatoid arthritis. Yonsei Med J. Aug. 2002;43(4):435-40. [pmid: 12205730].
616 Dilhuydy MS, Vatan R, Etienne G, et al. Prolonged efficacy of infliximab for refractory adult-onset Still’s disease. Clin Exp Rheumatol. Jan–Feb. 2005;23(1):121-2. [pmid: 15789901].
617 Dimakou K, Papaioannides D, Latsi P, et al. Disseminated tuberculosis complicating anti-TNF-alpha treatment. Int J Clin Pract. Nov. 2004;58(11):1052-5. [pmid: 15605672].
618 Diskin CJ, Stokes TJ, Dansby LM, et al. Removal of methotrexate by peritoneal dialysis and hemodialysis in a single patient with end-stage renal disease. Am J Med Sci. Sep. 2006;332(3):156-8. [pmid: 16969149].
619 Dockery KM, Sismanis A, Abedi E. Rheumatoid arthritis of the larynx: the importance of early diagnosis and corticosteroid therapy. South Med J. Jan. 1991;84(1):95-6. [pmid: 1986436].
620 Doggrell SA. Triamcinolone: new and old indications. Expert Opin Pharmacother. Jul. 2001;2(7):1177-86. [pmid: 11583068].
621 Doggrell SA. Is tocilizumab an option for the treatment of arthritis?. Expert Opin Pharmacother. Aug. 2008;9(11):2009-13. [pmid: 18627338].
622 Dohn UM, Skjodt H, Hetland ML, et al. No erosive progression revealed by MRI in rheumatoid arthritis patients treated with etanercept, even in patients with persistent MRI and clinical signs of joint inflammation. Clin Rheumatol. Nov. 2007;26(11):1857-61. [pmid: 17332974].
623 Dombrecht EJ, Aerts NE, Schuerwegh AJ, et al. Influence of anti-tumor necrosis factor therapy (Adalimumab) on regulatory T cells and dendritic cells in rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):31-7. [pmid: 16539816].
624 Domiciano DS, de Carvalho JF, Macedo AR, et al. Central diabetes insipidus induced by tuberculosis in a rheumatoid arthritis patient. Acta Reumatol Port. Apr–Jun. 2010;35(2):232-5. [pmid: 20711095].
625 Domm A. A patient’s reaction to infliximab. Ann Allergy Asthma Immunol. Mar. 2003;90(3):298-301. [pmid: 12669892].
626 Donahue KE, Gartlehner G, Jonas DE, et al. Systematic review: comparative effectiveness and harms of disease-modifying medications for rheumatoid arthritis. Ann Intern Med. Jan. 15. 2008;148(2):124-34. [pmid: 18025440].
627 Doran MF, Crowson CS, Pond GR, et al. Predictors of infection in rheumatoid arthritis. Arthritis Rheum. Sep. 2002;46(9):2294-300. [pmid: 12355476].
628 Doran MF, Crowson CS, Pond GR, et al. Frequency of infection in patients with rheumatoid arthritis compared with controls: a population-based study. Arthritis Rheum. Sep. 2002;46(9):2287-93. [pmid: 12355475].
629 Dore RK, Mathews S, Schechtman J, et al. The immunogenicity, safety, and efficacy of etanercept liquid administered once weekly in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2007;25(1):40-6. [pmid: 17417989].
630 Doria AS, Kiss MH, Sallum AM, et al. Correlation between osteochondral changes depicted by magnetic resonance imaging and disease progression. Rev Hosp Clin Fac Med Sao Paulo. Jul–Aug. 2001;56(4):107-14. [pmid: 11717717].
631 Doshi JA, Li P, Puig A. Impact of the Medicare Modernization Act of 2003 on utilization and spending for medicare part B-covered biologics in rheumatoid arthritis. Arthritis Care Res (Hoboken). Mar. 2010;62(3):354-61. [pmid: 20391481].
632 Douglas G, Bird K, Flume P, et al. Wegener’s granulomatosis in patients with rheumatoid arthritis. J Rheumatol. Sep. 2003;30(9):2064-9. [pmid: 12966617].
633 Doulton TW, Tucker B, Reardon J, et al. Antineutrophil cytoplasmic antibody-associated necrotizing crescentic glomerulonephritis in a patient receiving treatment with etanercept for severe rheumatoid arthritis. Clin Nephrol. Sep. 2004;62(3):234-8. [pmid: 15481857].
634 Drosos A. Methotrexate intolerance in elderly patients with rheumatoid arthritis: what are the alternatives?. Drugs Aging. 2003;20(10):723-36. [pmid: 12875609].
635 Drouin J, Haraoui B. Predictors of clinical response and radiographic progression in patients with rheumatoid arthritis treated with methotrexate monotherapy. J Rheumatol. Jul. 2010;37(7):1405-10. [pmid: 20436076].
636 Drozdzik M, Rudas T, Pawlik A, et al. Reduced folate carrier-1 80G>A polymorphism affects methotrexate treatment outcome in rheumatoid arthritis. Pharmacogenomics J. Dec. 2007;7(6):404-7. [pmid: 17325736].
637 Drozdzik M, Rudas T, Pawlik A, et al. The effect of 3435C>T MDR1 gene polymorphism on rheumatoid arthritis treatment with disease-modifying antirheumatic drugs. Eur J Clin Pharmacol. Nov. 2006;62(11):933-7. [pmid: 16932953].
638 Drynda S, Kuhne C, Kekow J. Soluble tumour necrosis factor receptor treatment does not affect raised transforming growth factor beta levels in rheumatoid arthritis. Ann Rheum Dis. Mar. 2002;61(3):254-6. [pmid: 11830433].
639 Dubois T, Bisagni-Faure A, Coste J, et al. High levels of antibodies to annexins V and VI in patients with rheumatoid arthritis. J Rheumatol. Jul. 1995;22(7):1230-4. [pmid: 7562750].
640 Ducharme J, Pelletier C, Zacharias R. The safety of infliximab infusions in the community setting. Can J Gastroenterol. 2010;24(5):307-11. [pmid: 20485705].
641 Duclos M, Gossec L, Ruyssen-Witrand A, et al. Retention rates of tumor necrosis factor blockers in daily practice in 770 rheumatic patients. J Rheumatol. 2006;33(12):2433-8. [pmid: 17014004].
642 Ducoulombier V, Solau E, Coquerelle P, et al. Long-term results of infliximab therapy in rheumatoid arthritis: experience acquired by the North-Pas-de-Calais hospital network. Joint Bone Spine. Jan. 2007;74(1):56-9. [pmid: 17182267].
643 Duftner C, Dejaco C, Larcher H, et al. Biologicals in rheumatology: Austrian experiences from a rheumatic outpatient clinic. Rheumatol Int. Nov. 2008;29(1):69-73. [pmid: 18504584].
644 Dumont-Berset M, Laffitte E, Gerber C, et al. Eczematous drug eruption after infliximab. Br J Dermatol. Dec. 2004;151(6):1272-3. [pmid: 15606528].
645 Dunne CA, Moran CJ, Thompson PW. The effect of regular intramuscular corticosteroid therapy on bone mineral density in rheumatoid patients. Scand J Rheumatol. 1995;24(1):48-9. [pmid: 7863279].
646 Durez P, Malghem J, Nzeusseu Toukap A, et al. Treatment of early rheumatoid arthritis: a randomized magnetic resonance imaging study comparing the effects of methotrexate alone, methotrexate in combination with infliximab, and methotrexate in combination with intravenous pulse methylprednisolone. Arthritis Rheum. 2007;56(12):3919-27. [pmid: 18050189].
647 Durez P, Nzeusseu Toukap A, Lauwerys BR, et al. A randomised comparative study of the short term clinical and biological effects of intravenous pulse methylprednisolone and infliximab in patients with active rheumatoid arthritis despite methotrexate treatment. Ann Rheum Dis. Sep. 2004;63(9):1069-74. [pmid: 15308515].
648 Durez P, Van den Bosch F, Corluy L, et al. A dose adjustment in patients with rheumatoid arthritis not optimally responding to a standard dose of infliximab of 3 mg/kg every 8 weeks can be effective: a Belgian prospective study. Rheumatology (Oxford). Apr. 2005;44(4):465-8. [pmid: 15695306].
649 Dursun AB, Kalac N, Ozkan B, et al. Pulmonary tuberculosis in patients with rheumatoid arthritis (four case reports). Rheumatol Int. Jan. 2002;21(4):153-7. [pmid: 11843171].
650 Dweik M, Baethge BA, Duarte AG. Coccidioidomycosis pneumonia in a nonendemic area associated with infliximab. South Med J. May. 2007;100(5):517-8. [pmid: 17534091].
651 Eberhardt K, Rydgren L, Fex E, et al. D-penicillamine in early rheumatoid arthritis: experience from a 2-year double blind placebo controlled study. Clin Exp Rheumatol. Nov–Dec. 1996;14(6):625-31. [pmid: 8978957].
652 Eberhardt K, Sandqvist G, Geborek P. Hand function tests are important and sensitive tools for assessment of treatment response in patients with rheumatoid arthritis. Scand J Rheumatol. Mar–Apr. 2008;37(2):109-12. [pmid: 18415767].
653 Eberhardt R, Kruger K, Reiter W, et al. Long-term therapy with the new glucocorticosteroid deflazacort in rheumatoid arthritis. Double-blind controlled randomized 12-months study against prednisone. Arzneimittelforschung. May. 1994;44(5):642-7. [pmid: 8024639].
654 Eder L, Chandran V, Gladman DD. From ankylosis to pencil-in-cup deformity in psoriatic arthritis: a case report. Clin Exp Rheumatol. Jul–Aug. 2009;27(4):661-3. [pmid: 19772803].
655 Edwards CJ, Cooper C, Fisher D, et al. The importance of the disease process and disease-modifying antirheumatic drug treatment in the development of septic arthritis in patients with rheumatoid arthritis. Arthritis Rheum. 2007;57(7):1151-7. [pmid: 17907232].
656 Edwards JC, Szczepanski L, Szechinski J, et al. Efficacy of B-cell-targeted therapy with rituximab in patients with rheumatoid arthritis. N Engl J Med. Jun. 17. 2004;350(25):2572-81. [pmid: 15201414].
657 Edwards KR, Mowad CM, Tyler WB. Worsening injection site reactions with continued use of etanercept. J Drugs Dermatol. Apr. 2003;2(2):184-7. [pmid: 12852371].
658 Efde MN, Houtman PM, Spoorenberg JP, et al. Tonsillar tuberculosis in a rheumatoid arthritis patient receiving anti-TNFalpha (adalimumab) treatment. Neth J Med. Mar. 2005;63(3):112-4. [pmid: 15813424].
659 Efthimiou P, Georgy S. Pathogenesis and management of adult-onset Still’s disease. Semin Arthritis Rheum. Dec. 2006;36(3):144-52. [pmid: 16949136].
660 Eggert M, Kluter A, Rusch D, et al. Expression analysis of the glucocorticoid receptor and the nuclear factor-kB subunit p50 in lymphocytes from patients with rheumatoid arthritis. J Rheumatol. Dec. 2002;29(12):2500-6. [pmid: 12465142].
661 Egnatios G, Warthan MM, Pariser R, et al. Pustular psoriasis following treatment of rheumatoid arthritis with TNF-alpha inhibitors. J Drugs Dermatol. Oct. 2008;7(10):975-7. [pmid: 19112764].
662 Eijsbouts AM, van den Hoogen FH, Laan RF, et al. Hypothalamic-pituitary-adrenal axis activity in patients with rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 2005;23(5):658-64. [pmid: 16173242].
663 Eklow C, Makrygiannakis D, Backdahl L, et al. Cellular distribution of the C-type II lectin dendritic cell immunoreceptor (DCIR) and its expression in the rheumatic joint: identification of a subpopulation of DCIR+ T cells. Ann Rheum Dis. Dec. 2008;67(12):1742-9. [pmid: 18250113].
664 Eklund KK, Leirisalo-Repo M, Ranta P, et al. Serum IL-1beta levels are associated with the presence of erosions in recent onset rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 2007;25(5):684-9. [pmid: 18078614].
665 Eklund KK, Peltomaa R, Leirisalo-Repo M. Occurrence of pulmonary thromboembolism during infliximab therapy. Clin Exp Rheumatol. Sep–Oct. 2003;21(5):679. [pmid: 14611130].
666 El Maghraoui A, Do Santos Zounon AA, Jroundi I, et al. Reproducibility of bone mineral density measurements using dual X-ray absorptiometry in daily clinical practice. Osteoporos Int. Dec. 2005;16(12):1742-8. [pmid: 15937633].
667 Elkayam O, Burke M, Vardinon N, et al. Autoantibodies profile of rheumatoid arthritis patients during treatment with infliximab. Autoimmunity. Mar. 2005;38(2):155-60. [pmid: 16040336].
668 Elkayam O, Caspi D. Infliximab induced lupus in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2004;22(4):502-3. [pmid: 15301255].
669 Elkayam O, Caspi D, Reitblatt T, et al. The effect of tumor necrosis factor blockade on the response to pneumococcal vaccination in patients with rheumatoid arthritis and ankylosing spondylitis. Semin Arthritis Rheum. Feb. 2004;33(4):283-8. [pmid: 14978666].
670 Elkayam O, Hawkins PN, Lachmann H, et al. Rapid and complete resolution of proteinuria due to renal amyloidosis in a patient with rheumatoid arthritis treated with infliximab. Arthritis Rheum. Oct. 2002;46(10):2571-3. [pmid: 12384913].
671 Elkayam O, Paran D, Flusser G, et al. Insufficiency fractures in rheumatic patients: misdiagnosis and underlying characteristics. Clin Exp Rheumatol. May–Jun. 2000;18(3):369-74. [pmid: 10895375].
672 Elkayam O, Yaron I, Shirazi I, et al. Serum levels of IL-10, IL-6, IL-1ra, and sIL-2R in patients with psoriatic arthritis. Rheumatol Int. 2000;19(3):101-5. [pmid: 10776688].
673 ElKayam O, Yaron M, Caspi D. From wheels to feet: a dramatic response of severe chronic psoriatic arthritis to etanercept. Ann Rheum Dis. Oct. 2000;59(10):839. [pmid: 11203155].
674 Ellerton ML. When parents and children disagree about care. Can Nurse. Aug. 2000;96(7):35-6. [pmid: 11865523].
675 Ellingsen T, Hornung N, Moller BK, et al. In active chronic rheumatoid arthritis, dipeptidyl peptidase IV density is increased on monocytes and CD4(+) T lymphocytes. Scand J Immunol. Oct. 2007;66(4):451-7. [pmid: 17850590].
676 Ellingsen T, Hornung N, Moller BK, et al. Differential effect of methotrexate on the increased CCR2 density on circulating CD4 T lymphocytes and monocytes in active chronic rheumatoid arthritis, with a down regulation only on monocytes in responders. Ann Rheum Dis. Feb. 2007;66(2):151-7. [pmid: 16905577].
677 Elliott MJ, Maini RN, Feldmann M, et al. Randomised double-blind comparison of chimeric monoclonal antibody to tumour necrosis factor alpha (cA2) versus placebo in rheumatoid arthritis. Lancet. Oct. 22. 1994;344(8930):1105-10. [pmid: 7934491].
678 Emery P, Breedveld F, van der Heijde D, et al. Two-year clinical and radiographic results with combination etanercept-methotrexate therapy versus monotherapy in early rheumatoid arthritis: a two-year, double-blind, randomized study. Arthritis Rheum. 2010;62(3):674-82. [pmid: 20187135].
679 Emery P, Breedveld FC, Hall S, et al. Comparison of methotrexate monotherapy with a combination of methotrexate and etanercept in active, early, moderate to severe rheumatoid arthritis (COMET): a randomised, double-blind, parallel treatment trial. Lancet. 2008;372(9636):375-82. [pmid: 18635256].
680 Emery P, Deodhar A, Rigby WF, et al. Efficacy and safety of different doses and retreatment of rituximab: a randomised, placebo-controlled trial in patients who are biological naive with active rheumatoid arthritis and an inadequate response to methotrexate (Study Evaluating Rituximab’s Efficacy in MTX iNadequate rEsponders (SERENE)). Ann Rheum Dis. 2010;69(9):1629-35. [pmid: 20488885].
681 Emery P, Fleischmann RM, Moreland LW, et al. Golimumab, a human anti-tumor necrosis factor alpha monoclonal antibody, injected subcutaneously every four weeks in methotrexate-naive patients with active rheumatoid arthritis: twenty-four-week results of a phase III, multicenter, randomized, double-blind, placebo-controlled study of golimumab before methotrexate as first-line therapy for early-onset rheumatoid arthritis. Arthritis Rheum. 2009;60(8):2272-83. [pmid: 19644849].
682 Emery P, Keystone E, Tony HP, et al. IL-6 receptor inhibition with tocilizumab improves treatment outcomes in patients with rheumatoid arthritis refractory to anti-tumour necrosis factor biologicals: results from a 24-week multicentre randomised placebo-controlled trial. Ann Rheum Dis. 2008;67(11):1516-23. [pmid: 18625622].
683 Emery P, Kosinski M, Li T, et al. Treatment of rheumatoid arthritis patients with abatacept and methotrexate significantly improved health-related quality of life. J Rheumatol. Apr. 2006;33(4):681-9. [pmid: 16568505].
684 Emkey RD, Lindsay R, Lyssy J, et al. The systemic effect of intraarticular administration of corticosteroid on markers of bone formation and bone resorption in patients with rheumatoid arthritis. Arthritis Rheum. Feb. 1996;39(2):277-82. [pmid: 8849379].
685 Emlen W, Niebur J, Kadera R. Accelerated in vitro apoptosis of lymphocytes from patients with systemic lupus erythematosus. J Immunol. Apr. 1. 1994;152(7):3685-92. [pmid: 8144943].
686 Engels EA, Cerhan JR, Linet MS, et al. Immune-related conditions and immune-modulating medications as risk factors for non-Hodgkin’s lymphoma: a case-control study. Am J Epidemiol. Dec. 15. 2005;162(12):1153-61. [pmid: 16251389].
687 Epler GR. Bronchiolitis obliterans organizing pneumonia. Semin Respir Infect. Jun. 1995;10(2):65-77. [pmid: 7569401].
688 Eriksson C, Engstrand S, Sundqvist KG, et al. Autoantibody formation in patients with rheumatoid arthritis treated with anti-TNF alpha. Ann Rheum Dis. Mar. 2005;64(3):403-7. [pmid: 15297281].
689 Eriksson C, Rantapaa-Dahlqvist S, Sundqvist KG. T-cell expression of CD91 - a marker of unresponsiveness to anti-TNF therapy in rheumatoid arthritis. APMIS. Nov. 2010;118(11):837-45. [pmid: 20955456].
690 Ernestam S, Hafstrom I, Werner S, et al. Increased DHEAS levels in patients with rheumatoid arthritis after treatment with tumor necrosis factor antagonists: evidence for improved adrenal function. J Rheumatol. Jul. 2007;34(7):1451-8. [pmid: 17477470].
691 Escalante A, Kaufman RL, Quismorio FP Jr, et al. Cardiac compression in rheumatoid pericarditis. Semin Arthritis Rheum. Dec. 1990;20(3):148-63. [pmid: 2287940].
692 Esmailzadeh A, Yousefi P, Farhi D, et al. Predictive factors of eczema-like eruptions among patients without cutaneous psoriasis receiving infliximab: a cohort study of 92 patients. Dermatology. 2009;219(3):263-7. [pmid: 19684381].
693 Esser AC, Abril A, Fayne S, et al. Acute development of multiple keratoacanthomas and squamous cell carcinomas after treatment with infliximab. J Am Acad Dermatol. May. 2004;50(5 Suppl):S75-7. [pmid: 15097933].
694 Estradas J, Pascual-Ramos V, Martinez B, et al. Autoimmune hepatitis with giant-cell transformation. Ann Hepatol. Jan–Mar. 2009;8(1):68-70. [pmid: 19221538].
695 Etemad L, Yu EB, Wanke LA. Dose adjustment over time of etanercept and infliximab in patients with rheumatoid arthritis. Manag Care Interface. Apr. 2005;18(4):21-7. [pmid: 15889759].
696 Ettefagh L, Nedorost S, Mirmirani P. Alopecia areata in a patient using infliximab: new insights into the role of tumor necrosis factor on human hair follicles. Arch Dermatol. Aug. 2004;140(8):1012. [pmid: 15313825].
697 Evans CH, Robbins PD, Ghivizzani SC, et al. Gene transfer to human joints: progress toward a gene therapy of arthritis. Proc Natl Acad Sci U S A. Jun. 14. 2005;102(24):8698-703. [pmid: 15939878].
698 Eyigor S, Karapolat H, Kirazli Y. Efficacy of etanercept and complete decongestive physical therapy in bilateral lower-limb lymphoedema associated with rheumatoid arthritis: a case report. Adv Ther. Jan. 2008;25(1):23-8. [pmid: 18227980].
699 Fabre S, Dupuy AM, Dossat N, et al. Protein biochip array technology for cytokine profiling predicts etanercept responsiveness in rheumatoid arthritis. Clin Exp Immunol. Aug. 2008;153(2):188-95. [pmid: 18549443].
700 Fabre S, Gibert C, Lechiche C, et al. Visceral leishmaniasis infection in a rheumatoid arthritis patient treated with infliximab. Clin Exp Rheumatol. Nov–Dec. 2005;23(6):891-2. [pmid: 16396712].
701 Fabre S, Gibert C, Lechiche C, et al. Primary cutaneous Nocardia otitidiscaviarum infection in a patient with rheumatoid arthritis treated with infliximab. J Rheumatol. Dec. 2005;32(12):2432-3. [pmid: 16331777].
702 Fabre S, Guisset C, Tatem L, et al. Protein biochip array technology to monitor rituximab in rheumatoid arthritis. Clin Exp Immunol. Mar. 2009;155(3):395-402. [pmid: 19220830].
703 Familian A, Voskuyl AE, van Mierlo GJ, et al. Infliximab treatment reduces complement activation in patients with rheumatoid arthritis. Ann Rheum Dis. Jul. 2005;64(7):1003-8. [pmid: 15958758].
704 Fantasia JE. Bisphosphonates--what the dentist needs to know: practical considerations. J Oral Maxillofac Surg. May. 2009;67(5 Suppl):53-60. [pmid: 19371815].
705 Fantini F, Gallazzi M, Gattinara M, et al. Monitoring bone mineralization in chronic rheumatic children on steroid treatment. Acta Univ Carol [Med] (Praha). 1994;40(1–4):17-22.
706 Fantini F, Gallazzi M, Gattinara M, et al. Monitoring osteopenia by dual-photon absorptiometry in chronically ill children treated with steroids. Acta Univ Carol [Med] (Praha). 1991;37(1–2):68-72.
707 Farah RE, Shay MD. Pulmonary sarcoidosis associated with etanercept therapy. Pharmacotherapy. Oct. 2007;27(10):1446-8. [pmid: 17896899].
708 Farahani P, Levine M, Gaebel K, et al. Clinical data gap between phase III clinical trials (pre-marketing) and phase IV (post-marketing) studies: evaluation of etanercept in rheumatoid arthritis. Can J Clin Pharmacol. Fall. 2005;12(3):e254-63. [pmid: 16278497].
709 Farahani P, Levine M, Gaebel K, et al. Community-based evaluation of etanercept in patients with rheumatoid arthritis. J Rheumatol. Apr. 2006;33(4):665-70. [pmid: 16568506].
710 Farukhi FI, Bollinger K, Ruggieri P, et al. Infliximab-associated third nerve palsy. Arch Ophthalmol. Jul. 2006;124(7):1055-7. [pmid: 16832034].
711 Fautrel B, Borget C, Rozenberg S, et al. Corticosteroid sparing effect of low dose methotrexate treatment in adult Still’s disease. J Rheumatol. Feb. 1999;26(2):373-8. [pmid: 9972972].
712 Fautrel B, Flipo RM, Saraux A. Eligibility of rheumatoid arthritis patients for anti-TNF-alpha therapy according to the 2005 recommendations of the French and British Societies for Rheumatology. Rheumatology (Oxford). Nov. 2008;47(11):1698-703. [pmid: 18794185].
713 Fautrel B, Foltz V, Frances C, et al. Regression of subacute cutaneous lupus erythematosus in a patient with rheumatoid arthritis treated with a biologic tumor necrosis factor alpha-blocking agent: comment on the article by Pisetsky and the letter from Aringer et al. Arthritis Rheum. May. 2002;46(5):1408-9. author reply 9. [pmid: 12115253].
714 Fautrel B, Sibilia J, Mariette X, et al. Tumour necrosis factor alpha blocking agents in refractory adult Still’s disease: an observational study of 20 cases. Ann Rheum Dis. Feb. 2005;64(2):262-6. [pmid: 15184196].
715 Fautrel B, Woronoff-Lemsi MC, Ethgen M, et al. Impact of medical practices on the costs of management of rheumatoid arthritis by anti-TNFalpha biological therapy in France. Joint Bone Spine. Dec. 2005;72(6):550-6. [pmid: 15996504].
716 Favalli EG, Arreghini M, Arnoldi C, et al. Anti-tumor necrosis factor alpha switching in rheumatoid arthritis and juvenile chronic arthritis. Arthritis Rheum. Apr. 15. 2004;51(2):301-2. [pmid: 15077278].
717 Favalli EG, Marchesoni A, Colombo GL, et al. Pattern of use, economic burden and vial optimization of infliximab for rheumatoid arthritis in Italy. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):45-51. [pmid: 18328146].
718 Favalli EG, Sinigaglia L, Varenna M, et al. Drug-induced lupus following treatment with infliximab in rheumatoid arthritis. Lupus. 2002;11(11):753-5. [pmid: 12475006].
719 Favero M, Schiavon F, Riato L, et al. Rheumatoid arthritis is the major risk factor for septic arthritis in rheumatological settings. Autoimmun Rev. Oct. 2008;8(1):59-61. [pmid: 18706527].
720 Feijoo M, Tunez I, Tasset I, et al. Infliximab reduces myeloperoxidase concentration in chronic inflammatory joint diseases. Pharmacology. 2009;83(4):211-6. [pmid: 19204412].
721 Felder M, Ruegsegger P. Bone loss in patients with rheumatoid arthritis--effect of steroids measured by low dose quantitative computed tomography. Rheumatol Int. 1991;11(1):41-4. [pmid: 1866572].
722 Feldman SR, Gottlieb AB, Bala M, et al. Infliximab improves health-related quality of life in the presence of comorbidities among patients with moderate-to-severe psoriasis. Br J Dermatol. Sep. 2008;159(3):704-10. [pmid: 18627375].
723 Feldstein AC, Elmer PJ, Nichols GA, et al. Practice patterns in patients at risk for glucocorticoid-induced osteoporosis. Osteoporos Int. Dec. 2005;16(12):2168-74. [pmid: 16142501].
724 Feletar M, Brockbank JE, Schentag CT, et al. Treatment of refractory psoriatic arthritis with infliximab: a 12 month observational study of 16 patients. Ann Rheum Dis. Feb. 2004;63(2):156-61. [pmid: 14722204].
725 Feltelius N, Fored CM, Blomqvist P, et al. Results from a nationwide postmarketing cohort study of patients in Sweden treated with etanercept. Ann Rheum Dis. Feb. 2005;64(2):246-52. [pmid: 15208177].
726 Fernandes M, Vemuganti GK, Rao GN. Bilateral periocular psoriasis: an initial manifestation of acute generalized pustular psoriasis with coexistent Sjogren’s syndrome. Clin Experiment Ophthalmol. Nov. 2007;35(8):763-6. [pmid: 17997783].
727 Fernandes NF, Martin RR, Schenker S. Trazodone-induced hepatotoxicity: a case report with comments on drug-induced hepatotoxicity. Am J Gastroenterol. Feb. 2000;95(2):532-5. [pmid: 10685763].
728 Fernandez-Castro M, Andreu JL, Munoz P, et al. Sepsis of a prosthetic joint and biological therapies. Rheumatology (Oxford). Aug. 2005;44(8):1076-7. author reply 5. [pmid: 15840593].
729 Fernandez-Nebro A, Irigoyen MV, Urena I, et al. Effectiveness, predictive response factors, and safety of anti-tumor necrosis factor (TNF) therapies in anti-TNF-naive rheumatoid arthritis. J Rheumatol. 2007;34(12):2334-42. [pmid: 17985409].
730 Fernandez-Nebro A, Tomero E, Ortiz-Santamaria V, et al. Treatment of rheumatic inflammatory disease in 25 patients with secondary amyloidosis using tumor necrosis factor alpha antagonists. Am J Med. May. 2005;118(5):552-6. [pmid: 15866260].
731 Ferraccioli G, Casatta L, Bartoli E. Increase of bone mineral density and anabolic variables in patients with rheumatoid arthritis resistant to methotrexate after cyclosporin A therapy. J Rheumatol. Sep. 1996;23(9):1539-42. [pmid: 8877921].
732 Ferraccioli G, Guerra P, Rizzi V, et al. Cyclosporin A increases somatomedin C insulin-like growth factor I levels in chronic rheumatic diseases. J Rheumatol. Jun. 1995;22(6):1060-4. [pmid: 7674231].
733 Ferraccioli G, Mecchia F, Di Poi E, et al. Anticardiolipin antibodies in rheumatoid patients treated with etanercept or conventional combination therapy: direct and indirect evidence for a possible association with infections. Ann Rheum Dis. Apr. 2002;61(4):358-61. [pmid: 11874843].
734 Ferraccioli G, Zoli A, Alivernini S, et al. Lupus anticoagulant and ischemic myocardial microangiopathy in rheumatoid arthritis. Nat Clin Pract Cardiovasc Med. Jun. 2006;3(6):339-43. quiz following 43. [pmid: 16729012].
735 Ferraccioli GF, Assaloni R, Di Poi E, et al. Rescue of combination therapy failures using infliximab, while maintaining the combination or monotherapy with methotrexate: results of an open trial. Rheumatology (Oxford). Oct. 2002;41(10):1109-12. [pmid: 12364628].
736 Ferri C, Ferraccioli G, Ferrari D, et al. Safety of anti-tumor necrosis factor-alpha therapy in patients with rheumatoid arthritis and chronic hepatitis C virus infection. J Rheumatol. Oct. 2008;35(10):1944-9. [pmid: 18688917].
737 Fidalgo A, Baptista J, Rocha Paris F, et al. Etanercept for psoriasis: two case reports. Int J Clin Pharmacol Res. 2005;25(4):159-63. [pmid: 16402631].
738 Fiedorczyk M, Klimiuk PA, Sierakowski S, et al. Serum matrix metalloproteinases and tissue inhibitors of metalloproteinases in patients with early rheumatoid arthritis. J Rheumatol. Aug. 2006;33(8):1523-9. [pmid: 16881109].
739 Fiehn C, Andrassy K. Case number 29: hitting three with one strike: rapid improvement of psoriatic arthritis, psoriatic erythroderma, and secondary renal amyloidosis by treatment with infliximab (Remicade). Ann Rheum Dis. Mar. 2004;63(3):232. [pmid: 14962954].
740 Fiehn C, Jacki S, Heilig B, et al. Eight versus 16-week re-evaluation period in rheumatoid arthritis patients treated with leflunomide or methotrexate accompanied by moderate dose prednisone. Rheumatol Int. Aug. 2007;27(10):975-9. [pmid: 17429636].
741 Figueiredo IT, Morel J, Sany J, et al. Maintenance and tolerability of infliximab in a cohort of 152 patients with rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):18-23. [pmid: 18328142].
742 Finckh A, Ciurea A, Brulhart L, et al. B cell depletion may be more effective than switching to an alternative anti-tumor necrosis factor agent in rheumatoid arthritis patients with inadequate response to anti-tumor necrosis factor agents. Arthritis Rheum. 2007;56(5):1417-23. [pmid: 17469098].
743 Finckh A, Ciurea A, Brulhart L, et al. Which subgroup of patients with rheumatoid arthritis benefits from switching to rituximab versus alternative anti-tumour necrosis factor (TNF) agents after previous failure of an anti-TNF agent?. Ann Rheum Dis. 2010;69(2):387-93. [pmid: 19416802].
744 Finckh A, Dehler S, Gabay C. The effectiveness of leflunomide as a co-therapy of tumour necrosis factor inhibitors in rheumatoid arthritis: a population-based study. Ann Rheum Dis. 2009;68(1):33-9. [pmid: 18230627].
745 Finckh A, Dudler J, Wermelinger F, et al. Influence of anti-infliximab antibodies and residual infliximab concentrations on the occurrence of acquired drug resistance to infliximab in rheumatoid arthritis patients. Joint Bone Spine. Jul. 2010;77(4):313-8. [pmid: 20471890].
746 Finckh A, Simard JF, Duryea J, et al. The effectiveness of anti-tumor necrosis factor therapy in preventing progressive radiographic joint damage in rheumatoid arthritis: a population-based study. Arthritis Rheum. Jan. 2006;54(1):54-9. [pmid: 16385495].
747 Finlay DG, Szauter K, Raju GS, et al. Tuberculous peritonitis. Am J Gastroenterol. Jul. 2005;100(7):1624-5. [pmid: 15984997].
748 Fiocco U, Ferro F, Vezzu M, et al. Rheumatoid and psoriatic knee synovitis: clinical, grey scale, and power Doppler ultrasound assessment of the response to etanercept. Ann Rheum Dis. Jun. 2005;64(6):899-905. [pmid: 15567814].
749 Firestein GS, Paine MM, Littman BH. Gene expression (collagenase, tissue inhibitor of metalloproteinases, complement, and HLA-DR) in rheumatoid arthritis and osteoarthritis synovium. Quantitative analysis and effect of intraarticular corticosteroids. Arthritis Rheum. Sep. 1991;34(9):1094-105. [pmid: 1657009].
750 Firth J, Helliwell P, Hale C, et al. The predictors of foot ulceration in patients with rheumatoid arthritis: a preliminary investigation. Clin Rheumatol. Nov. 2008;27(11):1423-8. [pmid: 18543055].
751 Fischer P. Resolution of treatment-related arthralgias and serologic findings with a switch of TNF antagonist therapies in a patient with psoriatic arthritis. J Clin Rheumatol. Oct. 2007;13(5):294-5. [pmid: 17921804].
752 Fiter J, Nolla JM, Navarro MA, et al. Weak androgen levels, glucocorticoid therapy, and bone mineral density in postmenopausal women with rheumatoid arthritis. Joint Bone Spine. 2000;67(3):199-203. [pmid: 10875318].
753 Fitzgerald AA, Leclercq SA, Yan A, et al. Rapid responses to anakinra in patients with refractory adult-onset Still’s disease. Arthritis Rheum. Jun. 2005;52(6):1794-803. [pmid: 15934079].
754 Flaisler F, Hedon B, Sany J, et al. A study of ovarian function in rheumatoid arthritis. Rev Rhum Engl Ed. Oct. 1995;62(9):549-54. [pmid: 8574626].
755 Fleischmann R. The clinical efficacy and safety of certolizumab pegol in rheumatoid arthritis. Expert Opin Biol Ther. May. 2010;10(5):773-86. [pmid: 20230188].
756 Fleischmann R, Baumgartner SW, Weisman MH, et al. Long term safety of etanercept in elderly subjects with rheumatic diseases. Ann Rheum Dis. 2006;65(3):379-84. [pmid: 16150792].
757 Fleischmann R, Stern R, Iqbal I. Anakinra: an inhibitor of IL-1 for the treatment of rheumatoid arthritis. Expert Opin Biol Ther. Aug. 2004;4(8):1333-44. [pmid: 15268666].
758 Fleischmann R, Vencovsky J, van Vollenhoven RF, et al. Efficacy and safety of certolizumab pegol monotherapy every 4 weeks in patients with rheumatoid arthritis failing previous disease-modifying antirheumatic therapy: the FAST4WARD study. Ann Rheum Dis. Jun. 2009;68(6):805-11. [pmid: 19015206].
759 Fleischmann RM. Safety of anakinra, a recombinant interleukin-1 receptor antagonist (r-metHuIL-1ra), in patients with rheumatoid arthritis and comparison to anti-TNF-alpha agents. Clin Exp Rheumatol. Sep–Oct. 2002;20(5 Suppl 27):S35-41.
760 Fleischmann RM. Addressing the safety of anakinra in patients with rheumatoid arthritis. Rheumatology (Oxford). May. 29. 2003;42(Suppl 2):ii-35.
761 Fleischmann RM. Progressive multifocal leukoencephalopathy following rituximab treatment in a patient with rheumatoid arthritis. Arthritis Rheum. Nov. 2009;60(11):3225-8. [pmid: 19877057].
762 Fleischmann RM, Cohen SB, Moreland LW, et al. Methotrexate dosage reduction in patients with rheumatoid arthritis beginning therapy with infliximab: the Infliximab Rheumatoid Arthritis Methotrexate Tapering (iRAMT) trial. Curr Med Res Opin. Aug. 2005;21(8):1181-90. [pmid: 16083527].
763 Fleischmann RM, Schechtman J, Bennett R, et al. Anakinra, a recombinant human interleukin-1 receptor antagonist (r-metHuIL-1ra), in patients with rheumatoid arthritis: A large, international, multicenter, placebo-controlled trial. Arthritis Rheum. Apr. 2003;48(4):927-34. [pmid: 12687534].
764 Flenaugh EL, Kolawole FO, Allen R. Dyspnea and dry cough in a patient with rheumatoid arthritis. Am Fam Physician. Jan. 1. 2007;75(1):103-5. [pmid: 17225711].
765 Flendrie M, Creemers MC, van Riel PL. Titration of infliximab treatment in rheumatoid arthritis patients based on response patterns. Rheumatology (Oxford). Jan. 2007;46(1):146-9. [pmid: 16782732].
766 Flendrie M, Creemers MC, Welsing PM, et al. Survival during treatment with tumour necrosis factor blocking agents in rheumatoid arthritis. Ann Rheum Dis. Nov. 2003;62(Suppl 2):ii30-3. [pmid: 14532145].
767 Flendrie M, Creemers MC, Welsing PM, et al. The influence of previous and concomitant leflunomide on the efficacy and safety of infliximab therapy in patients with rheumatoid arthritis; a longitudinal observational study. Rheumatology (Oxford). Apr. 2005;44(4):472-8. [pmid: 15598707].
768 Foell D, Wittkowski H, Hammerschmidt I, et al. Monitoring neutrophil activation in juvenile rheumatoid arthritis by S100A12 serum concentrations. Arthritis Rheum. Apr. 2004;50(4):1286-95. [pmid: 15077313].
769 Fomin I, Caspi D, Levy V, et al. Vaccination against influenza in rheumatoid arthritis: the effect of disease modifying drugs, including TNF alpha blockers. Ann Rheum Dis. Feb. 2006;65(2):191-4. [pmid: 16014674].
770 Fonollosa A, Segura A, Giralt J, et al. Tuberculous uveitis after treatment with etanercept. Graefes Arch Clin Exp Ophthalmol. Sep. 2007;245(9):1397-9. [pmid: 17364199].
771 Fonseca A, Wagner J, Yamaga LI, et al. (18) F-FDG PET imaging of rheumatoid articular and extraarticular synovitis. J Clin Rheumatol. Oct. 2008;14(5):307. [pmid: 18838912].
772 Fonseca JE, Canhao H, Tavares NJ, et al. Persistent low grade synovitis without erosive progression in magnetic resonance imaging of rheumatoid arthritis patients treated with infliximab over 1 year. Clin Rheumatol. Oct. 2009;28(10):1213-6. [pmid: 19504146].
773 Fonseca JE, Carvalho T, Cruz M, et al. Polymorphism at position -308 of the tumour necrosis factor alpha gene and rheumatoid arthritis pharmacogenetics. Ann Rheum Dis. May. 2005;64(5):793-4. [pmid: 15834068].
774 Font J, Ramos-Casals M, de la Red G, et al. Pure sensory neuropathy in primary Sjogren’s syndrome. Longterm prospective followup and review of the literature. J Rheumatol. Jul. 2003;30(7):1552-7. [pmid: 12858457].
775 Foppiani L, Cutolo M, Sessarego P, et al. Desmopressin and low-dose ACTH test in rheumatoid arthritis. Eur J Endocrinol. Mar. 1998;138(3):294-301. [pmid: 9539304].
776 Forsblad d’Elia H, Pullerits R, Carlsten H, et al. Resistin in serum is associated with higher levels of IL-1Ra in post-menopausal women with rheumatoid arthritis. Rheumatology (Oxford). Jul. 2008;47(7):1082-7. [pmid: 18511473].
777 Forsblad-d’Elia H, Carlsten H, Labrie F, et al. Low serum levels of sex steroids are associated with disease characteristics in primary Sjogren’s syndrome; supplementation with dehydroepiandrosterone restores the concentrations. J Clin Endocrinol Metab. Jun. 2009;94(6):2044-51. [pmid: 19318446].
778 Forslind K, Boonen A, Albertsson K, et al. Hand bone loss measured by digital X-ray radiogrammetry is a predictor of joint damage in early rheumatoid arthritis. Scand J Rheumatol. Nov–Dec. 2009;38(6):431-8. [pmid: 19922017].
779 Forslind K, Hafstrom I, Ahlmen M, et al. Sex: a major predictor of remission in early rheumatoid arthritis?. Ann Rheum Dis. Jan. 2007;66(1):46-52. [pmid: 17158139].
780 Forslund T, Hannonen P, Reitamo S, et al. Hypertension in cyclosporin A-treated patients is independent of circulating endothelin levels. J Intern Med. Jul. 1995;238(1):71-5. [pmid: 7608649].
781 Fortna RR, Gudjonsson JE, Seidel G, et al. Persistent pruritic papules and plaques: a characteristic histopathologic presentation seen in a subset of patients with adult-onset and juvenile Still’s disease. J Cutan Pathol. Sep. 2010;37(9):932-7. [pmid: 20546088].
782 Fossaluzza V, De Vita S. Clinical differences between ANA/anti-ENA positive or negative primary Sjogren’s syndrome. Clin Rheumatol. Sep. 1992;11(3):385-7. [pmid: 1458787].
783 Foster CS, Barrett F. Cataract development and cataract surgery in patients with juvenile rheumatoid arthritis-associated iridocyclitis. Ophthalmology. Jun. 1993;100(6):809-17. [pmid: 8510892].
784 Foster EN, Nguyen KK, Sheikh RA, et al. Crohn’s disease associated with Sweet’s syndrome and Sjogren’s syndrome treated with infliximab. Clin Dev Immunol. Jun. 2005;12(2):145-9. [pmid: 16050146].
785 Fox RI, Stern M, Michelson P. Update in Sjogren syndrome. Curr Opin Rheumatol. Sep. 2000;12(5):391-8. [pmid: 10990175].
786 Fraenkel L, Bogardus ST, Concato J, et al. Patient preferences for treatment of rheumatoid arthritis. Ann Rheum Dis. Nov. 2004;63(11):1372-8. [pmid: 15020312].
787 Franchini S, Dagna L, Salvo F, et al. Efficacy of traditional and biologic agents in different clinical phenotypes of adult-onset Still’s disease. Arthritis Rheum. Aug. 2010;62(8):2530-5. [pmid: 20506370].
788 Franck H, Gottwalt J. Peripheral bone density in patients with rheumatoid arthritis. Clin Rheumatol. Oct. 2009;28(10):1141-5. [pmid: 19529880].
789 Franklin CM. Clinical experience with soluble TNF p75 receptor in rheumatoid arthritis. Semin Arthritis Rheum. Dec. 1999;29(3):172-81. [pmid: 10622681].
790 Franklin J, Lunt M, Bunn D, et al. Risk and predictors of infection leading to hospitalisation in a large primary-care-derived cohort of patients with inflammatory polyarthritis. Ann Rheum Dis. Mar. 2007;66(3):308-12. [pmid: 16984941].
791 Fransen J, Moens HB, Speyer I, et al. Effectiveness of systematic monitoring of rheumatoid arthritis disease activity in daily practice: a multicentre, cluster randomised controlled trial. Ann Rheum Dis. Sep. 2005;64(9):1294-8. [pmid: 15829574].
792 Fransen J, Stucki G, Twisk J, et al. Effectiveness of a measurement feedback system on outcome in rheumatoid arthritis: a controlled clinical trial. Ann Rheum Dis. Jul. 2003;62(7):624-9. [pmid: 12810423].
793 Fraser DA, Thoen J, Djoseland O, et al. Serum levels of interleukin-6 and dehydroepiandrosterone sulphate in response to either fasting or a ketogenic diet in rheumatoid arthritis patients. Clin Exp Rheumatol. May–Jun. 2000;18(3):357-62. [pmid: 10895373].
794 Fraser DA, Thoen J, Selvaag AM, et al. A preliminary study of circadian serum cortisol concentrations in response to a 72-hour fast in rheumatoid arthritis patients not previously treated with corticosteroids. Clin Rheumatol. 2001;20(2):85-7. [pmid: 11346236].
795 Frediani B, Falsetti P, Baldi F, et al. Effects of 4-year treatment with once-weekly clodronate on prevention of corticosteroid-induced bone loss and fractures in patients with arthritis: evaluation with dual-energy X-ray absorptiometry and quantitative ultrasound. Bone. Oct. 2003;33(4):575-81. [pmid: 14555261].
796 Frediani B, Falsetti P, Bisogno S, et al. Effects of high dose methylprednisolone pulse therapy on bone mass and biochemical markers of bone metabolism in patients with active rheumatoid arthritis: a 12-month randomized prospective controlled study. J Rheumatol. Jun. 2004;31(6):1083-7. [pmid: 15170918].
797 Fries JF, Bruce B. Rates of serious gastrointestinal events from low dose use of acetylsalicylic acid, acetaminophen, and ibuprofen in patients with osteoarthritis and rheumatoid arthritis. J Rheumatol. Oct. 2003;30(10):2226-33. [pmid: 14528521].
798 Fries JF, Miller SR, Spitz PW, et al. Identification of patients at risk for gastropathy associated with NSAID use. J Rheumatol Suppl. Feb. 1990;20:12-9. [pmid: 2325051].
799 Fries W, Giofre MR, Catanoso M, et al. Treatment of acute uveitis associated with Crohn’s disease and sacroileitis with infliximab. Am J Gastroenterol. Feb. 2002;97(2):499-500. [pmid: 11866306].
800 Fu A, Bertouch JV, McNeil HP. Disseminated Salmonella typhimurium infection secondary to infliximab treatment. Arthritis Rheum. Sep. 2004;50(9):3049. [pmid: 15457476].
801 Fucci JC, Nightengale ML. Primary esophageal histoplasmosis. Am J Gastroenterol. Mar. 1997;92(3):530-1. [pmid: 9068491].
802 Fuchs I, Avnon L, Freud T, et al. Repeated tuberculin skin testing following therapy with TNF-alpha inhibitors. Clin Rheumatol. Feb. 2009;28(2):167-72. [pmid: 18795393].
803 Fuerst M, Mohl H, Baumgartel K, et al. Leflunomide increases the risk of early healing complications in patients with rheumatoid arthritis undergoing elective orthopedic surgery. Rheumatol Int. 2006;26(12):1138-42. [pmid: 16736164].
804 Fujikawa S. Non-steroidal anti-inflammatory drugs and slow-acting anti-rheumatic drugs in juvenile rheumatoid arthritis. Acta Paediatr Jpn. Oct. 1993;35(5):447-53. [pmid: 8256630].
805 Fujita K, Tanaka E, Hatta K, et al. An autopsy case of Mycobacterium abscessus pulmonary infection complicated with rheumatoid arthritis. Intern Med. 2008;47(13):1273-6. [pmid: 18591855].
806 Fujita Y, Fujii T, Takeda N, et al. Successful treatment of primary Sjogren’s syndrome with chronic natural killer lymphocytosis by high-dose prednisolone and indomethacin farnesil. Intern Med. 2007;46(5):251-4. [pmid: 17329922].
807 Fujiwara H, Nishimoto N, Hamano Y, et al. Masked early symptoms of pneumonia in patients with rheumatoid arthritis during tocilizumab treatment: a report of two cases. Mod Rheumatol. 2009;19(1):64-8. [pmid: 18758893].
808 Fukino K, Kawashima T, Suzuki M, et al. Methylenetetrahydrofolate reductase and reduced folate carrier-1 genotypes and methotrexate serum concentrations in patients with rheumatoid arthritis. J Toxicol Sci. Oct. 2007;32(4):449-52. [pmid: 17965559].
809 Fukuchi M, Mizushima Y, Hori T, et al. Cryptococcal pleural effusion in a patient with chronic renal failure receiving long-term corticosteroid therapy for rheumatoid arthritis. Intern Med. Jun. 1998;37(6):534-7. [pmid: 9678688].
810 Fulchiero GJ Jr, Salvaggio H, Drabick JJ, et al. Eruptive latent metastatic melanomas after initiation of antitumor necrosis factor therapies. J Am Acad Dermatol. May. 2007;56(5 Suppl):S65-7. [pmid: 17434043].
811 Fumagalli M, Incorvaia C, Nitti F, et al. The assessment of quality of life as a measure of gold salts treatment efficacy in rheumatoid arthritis. Minerva Med. Jun. 2002;93(3):199-202. [pmid: 12094150].
812 Funahashi K, Koyano S, Miura T, et al. Efficacy of tocilizumab and evaluation of clinical remission as determined by CDAI and MMP-3 level. Mod Rheumatol. 2009;19(5):507-12. [pmid: 19609487].
813 Funovits J, Aletaha D, Bykerk V, et al. The 2010 American College of Rheumatology/European League Against Rheumatism classification criteria for rheumatoid arthritis: methodological report phase I. Ann Rheum Dis. Sep. 2010;69(9):1589-95. [pmid: 20699242].
814 Furfaro N, Mease PJ. Nursing considerations for infusion therapy in rheumatoid arthritis versus malignancy. J Infus Nurs. Nov–Dec. 2008;31(6):350-60. [pmid: 19018189].
815 Furse RK, Rossetti RG, Seiler CM, et al. Oral administration of gammalinolenic acid, an unsaturated fatty acid with anti-inflammatory properties, modulates interleukin-1beta production by human monocytes. J Clin Immunol. Mar. 2002;22(2):83-91. [pmid: 11998897].
816 Furst DE. Anakinra: review of recombinant human interleukin-I receptor antagonist in the treatment of rheumatoid arthritis. Clin Ther. Dec. 2004;26(12):1960-75. [pmid: 15823761].
817 Furst DE, Gaylis N, Bray V, et al. Open-label, pilot protocol of patients with rheumatoid arthritis who switch to infliximab after an incomplete response to etanercept: the opposite study. Ann Rheum Dis. 2007;66(7):893-9. [pmid: 17412737].
818 Furst DE, Schiff MH, Fleischmann RM, et al. Adalimumab, a fully human anti tumor necrosis factor-alpha monoclonal antibody, and concomitant standard antirheumatic therapy for the treatment of rheumatoid arthritis: results of STAR (Safety Trial of Adalimumab in Rheumatoid Arthritis). J Rheumatol. Dec. 2003;30(12):2563-71. [pmid: 14719195].
819 Furtado RN, Oliveira LM, Natour J. Polyarticular corticosteroid injection versus systemic administration in treatment of rheumatoid arthritis patients: a randomized controlled study. J Rheumatol. Sep. 2005;32(9):1691-8. [pmid: 16142862].
820 Furukawa K, Ohtani T, Furukawa F, et al. Infectious mononucleosis-like syndrome induced by salazosulfapyridine in a patient with rheumatoid arthritis. Mod Rheumatol. 2007;17(6):492-5. [pmid: 18084702].
821 Gadadhar H, Hawkins S, Huffstutter JE, et al. Cutaneous mucormycosis complicating methotrexate, prednisone, and infliximab therapy. J Clin Rheumatol. Dec. 2007;13(6):361-2. [pmid: 18176152].
822 Gadsby K, Deighton C. Characteristics and treatment responses of patients satisfying the BSR guidelines for anti-TNF in ankylosing spondylitis. Rheumatology (Oxford). Mar. 2007;46(3):439-41. [pmid: 17255137].
823 Gal I, Toth L, Szegedi L, et al. Gastric bleeding in a patient with rheumatoid arthritis complicated by immune thrombocytopenic purpura. Joint Bone Spine. May. 2008;75(3):350-2. [pmid: 18314370].
824 Galaria NA, Werth VP, Schumacher HR. Leukocytoclastic vasculitis due to etanercept. J Rheumatol. Aug. 2000;27(8):2041-4. [pmid: 10955351].
825 Galarraga B, Belch JJ, Pullar T, et al. Clinical improvement in rheumatoid arthritis is associated with healthier microvascular function in patients who respond to antirheumatic therapy. J Rheumatol. Mar. 2010;37(3):521-8. [pmid: 20080919].
826 Galarraga B, Khan F, Kumar P, et al. Etanercept improves inflammation-associated arterial stiffness in rheumatoid arthritis. Rheumatology (Oxford). Nov. 2009;48(11):1418-23. [pmid: 19734293].
827 Galindo M, Pablos JL, Gomez-Reino JJ. Internuclear ophthalmoplegia in systemic lupus erythematosus. Semin Arthritis Rheum. Dec. 1998;28(3):179-86. [pmid: 9872478].
828 Ganeshan A, Quen L, Smith D. Occurrence of vesicocolic fistula with a use of etanercept: a cautionary tale. J Clin Rheumatol. Oct. 2005;11(5):290-1. [pmid: 16357782].
829 Garcia-Gomez C, Nolla JM, Valverde J, et al. High HDL-cholesterol in women with rheumatoid arthritis on low-dose glucocorticoid therapy. Eur J Clin Invest. Sep. 2008;38(9):686-92. [pmid: 18837746].
830 Garcia-Porrua C, Gonzalez-Gay MA. Successful treatment of refractory mononeuritis multiplex secondary to rheumatoid arthritis with the anti-tumour necrosis factor alpha monoclonal antibody infliximab. Rheumatology (Oxford). Feb. 2002;41(2):234-5. [pmid: 11886980].
831 Garcia-Porrua C, Gonzalez-Gay MA, Quevedo V. Should anti-tumor necrosis factor-alpha be the first therapy for rheumatoid vasculitis?. J Rheumatol. Feb. 2006;33(2):433. author reply -4. [pmid: 16465676].
832 Gardiner PV, Bell AL, Taggart AJ, et al. A potential pitfall in the use of the Disease Activity Score (DAS28) as the main response criterion in treatment guidelines for patients with rheumatoid arthritis. Ann Rheum Dis. Mar. 2005;64(3):506-7. [pmid: 15708909].
833 Garfield BE, Krahl T, Appel S, et al. Regulation of p38 MAP kinase in CD4+ lymphocytes by infliximab therapy in patients with rheumatoid arthritis. Clin Immunol. Aug. 2005;116(2):101-7. [pmid: 15914087].
834 Garnero P, Gineyts E, Christgau S, et al. Association of baseline levels of urinary glucosyl-galactosyl-pyridinoline and type II collagen C-telopeptide with progression of joint destruction in patients with early rheumatoid arthritis. Arthritis Rheum. Jan. 2002;46(1):21-30. [pmid: 11817593].
835 Garnero P, Tabassi NC, Voorzanger-Rousselot N. Circulating dickkopf-1 and radiological progression in patients with early rheumatoid arthritis treated with etanercept. J Rheumatol. Dec. 2008;35(12):2313-5. [pmid: 18843784].
836 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J of Clinical Epidemiology. Aug. 4. 2006;59(10):1040-8.
837 Garton MJ, Reid DM. Bone mineral density of the hip and of the anteroposterior and lateral dimensions of the spine in men with rheumatoid arthritis. Effects of low-dose corticosteroids. Arthritis Rheum. Feb. 1993;36(2):222-8. [pmid: 8431212].
838 Gaujoux-Viala C, Smolen JS, Landewe R, et al. Current evidence for the management of rheumatoid arthritis with synthetic disease-modifying antirheumatic drugs: a systematic literature review informing the EULAR recommendations for the management of rheumatoid arthritis. Ann Rheum Dis. Jun. 2010;69(6):1004-9. [pmid: 20447954].
839 Gaylis NB, Needell SD, Rudensky D. Comparison of in-office magnetic resonance imaging versus conventional radiography in detecting changes in erosions after one year of infliximab therapy in patients with rheumatoid arthritis. Mod Rheumatol. 2007;17(4):273-8. [pmid: 17694258].
840 Geborek P, Bladstrom A, Turesson C, et al. Tumour necrosis factor blockers do not increase overall tumour risk in patients with rheumatoid arthritis, but may be associated with an increased risk of lymphomas. Ann Rheum Dis. May. 2005;64(5):699-703. [pmid: 15695534].
841 Geborek P, Crnkic M, Petersson IF, et al. Etanercept, infliximab, and leflunomide in established rheumatoid arthritis: clinical experience using a structured follow up programme in southern Sweden. Ann Rheum Dis. Sep. 2002;61(9):793-8. [pmid: 12176803].
842 Geborek P, Mansson B, Wollheim FA, et al. Intraarticular corticosteroid injection into rheumatoid arthritis knees improves extensor muscles strength. Rheumatol Int. 1990;9(6):265-70. [pmid: 2315606].
843 Geenen R, Godaert GL, Heijnen CJ, et al. Experimentally induced stress in rheumatoid arthritis of recent onset: effects on peripheral blood lymphocytes. Clin Exp Rheumatol. Sep–Oct. 1998;16(5):553-9. [pmid: 9779302].
844 Gelinck LB, van der Bijl AE, Beyer WE, et al. The effect of anti-tumour necrosis factor alpha treatment on the antibody response to influenza vaccination. Ann Rheum Dis. May. 2008;67(5):713-6. [pmid: 17965123].
845 Genc H, Duyur Cakit B, Nacir B, et al. The effects of sulfasalazine treatment on enthesal abnormalities of inflammatory rheumatic diseases. Clin Rheumatol. Jul. 2007;26(7):1104-10. [pmid: 17086383].
846 Gengenbacher M, Sebald HJ, Villiger PM, et al. Infliximab inhibits bone resorption by circulating osteoclast precursor cells in patients with rheumatoid arthritis and ankylosing spondylitis. Ann Rheum Dis. May. 2008;67(5):620-4. [pmid: 17720725].
847 Genovese MC, Bathon JM, Fleischmann RM, et al. Longterm safety, efficacy, and radiographic outcome with etanercept treatment in patients with early rheumatoid arthritis. J Rheumatol. Jul. 2005;32(7):1232-42. [pmid: 15996057].
848 Genovese MC, Bathon JM, Martin RW, et al. Etanercept versus methotrexate in patients with early rheumatoid arthritis: two-year radiographic and clinical outcomes. Arthritis Rheum. Jun. 2002;46(6):1443-50. [pmid: 12115173].
849 Genovese MC, Becker JC, Schiff M, et al. Abatacept for rheumatoid arthritis refractory to tumor necrosis factor alpha inhibition. N Engl J Med. Sep. 15. 2005;353(11):1114-23. [pmid: 16162882].
850 Genovese MC, Cohen S, Moreland L, et al. Combination therapy with etanercept and anakinra in the treatment of patients with rheumatoid arthritis who have been treated unsuccessfully with methotrexate. Arthritis Rheum. May. 2004;50(5):1412-9. [pmid: 15146410].
851 Genovese MC, Schiff M, Luggen M, et al. Efficacy and safety of the selective co-stimulation modulator abatacept following 2 years of treatment in patients with rheumatoid arthritis and an inadequate response to anti-tumour necrosis factor therapy. Ann Rheum Dis. Apr. 2008;67(4):547-54. [pmid: 17921185].
852 Genovese MC, Van den Bosch F, Roberson SA, et al. LY2439821, a humanized anti-interleukin-17 monoclonal antibody, in the treatment of patients with rheumatoid arthritis: A phase I randomized, double-blind, placebo-controlled, proof-of-concept study. Arthritis Rheum. Apr. 2010;62(4):929-39. [pmid: 20131262].
853 Geoghegan JM, Clark DI, Bainbridge LC, et al. Risk factors in carpal tunnel syndrome. J Hand Surg [Br]. Aug. 2004;29(4):315-20.
854 George D, Kadlubek P, Batra D, et al. Infliximab dose and charge escalation patterns in managed care. Manag Care Interface. 2004;(Suppl A):5-8. [pmid: 15198423].
855 Georgescu C. Sulphasalazine therapy in rheumatoid arthritis. A two-year study and follow-up of clinical results. Rom J Intern Med. Apr–Jun. 1992;30(2):127-32. [pmid: 1353901].
856 Georgiadis AN, Papavasiliou EC, Lourida ES, et al. Atherogenic lipid profile is a feature characteristic of patients with early rheumatoid arthritis: effect of early treatment--a prospective, controlled study. Arthritis Res Ther. 2006;8(3):R82. [pmid: 16646989].
857 Georgiadis AN, Voulgari PV, Argyropoulou MI, et al. Early treatment reduces the cardiovascular risk factors in newly diagnosed rheumatoid arthritis patients. Semin Arthritis Rheum. Aug. 2008;38(1):13-9. [pmid: 18191989].
858 Geraghty EM, Ristow B, Gordon SM, et al. Overwhelming parasitemia with Plasmodium falciparum infection in a patient receiving infliximab therapy for rheumatoid arthritis. Clin Infect Dis. May. 15. 2007;44(10):e82-4. [pmid: 17443458].
859 Gergely P Jr, Blazsek A, Danko K, et al. Detection of TT virus in patients with idiopathic inflammatory myopathies. Ann N Y Acad Sci. Jun. 2005;1050:304-13. [pmid: 16014546].
860 Gerlag DM, Boyle DL, Rosengren S, et al. Real-time quantitative PCR to detect changes in synovial gene expression in rheumatoid arthritis after corticosteroid treatment. Ann Rheum Dis. Apr. 2007;66(4):545-7. [pmid: 16984938].
861 Gerli R, Bertotto A, Agea E, et al. Basis for defective proliferation of peripheral blood T cells to anti-CD2 antibodies in primary Sjogren’s syndrome. J Clin Invest. Dec. 1990;86(6):1870-7. [pmid: 1979333].
862 Gerli R, Lunardi C, Bocci EB, et al. Anti-tumor necrosis factor-alpha response in rheumatoid arthritis is associated with an increase in serum soluble CD30. J Rheumatol. Jan. 2008;35(1):14-9. [pmid: 18061981].
863 Gerli R, Schillaci G, Giordano A, et al. CD4+CD28- T lymphocytes contribute to early atherosclerotic damage in rheumatoid arthritis patients. Circulation. Jun. 8. 2004;109(22):2744-8. [pmid: 15159291].
864 Gerloni V, Pontikaki I, Gattinara M, et al. Focus on adverse events of tumour necrosis factor alpha blockade in juvenile idiopathic arthritis in an open monocentric long-term prospective study of 163 patients. Ann Rheum Dis. Aug. 2008;67(8):1145-52. [pmid: 17981916].
865 Germano V, Picchianti Diamanti A, Baccano G, et al. Autoimmune hepatitis associated with infliximab in a patient with psoriatic arthritis. Ann Rheum Dis. Oct. 2005;64(10):1519-20. [pmid: 16162908].
866 Gerster JC, Dudler J. Cellulitis caused by Capnocytophaga cynodegmi associated with etanercept treatment in a patient with rheumatoid arthritis. Clin Rheumatol. Dec. 2004;23(6):570-1. [pmid: 15278747].
867 Geusens P, Dequeker J, Vanhoof J, et al. Cyclical etidronate increases bone density in the spine and hip of postmenopausal women receiving long term corticosteroid treatment. A double blind, randomised placebo controlled study. Ann Rheum Dis. Dec. 1998;57(12):724-7. [pmid: 10070271].
868 Gevers G, Dequeker J, van Holsbeeck M, et al. A high dose (up to 200 mg) tolerance and efficacy study of intra-articular rimexolone (Org 6216) in rheumatoid synovitis of the knee. Clin Rheumatol. Mar. 1994;13(1):103-9. [pmid: 8187428].
869 Ghavami A, Genevay S, Fulpius T, et al. Etanercept in treatment of Felty’s syndrome. Ann Rheum Dis. Jul. 2005;64(7):1090-1. [pmid: 15958767].
870 Giagounidis AA, Haase S, Germing U, et al. Autoimmune disorders in two patients with myelodysplastic syndrome and 5q deletion. Acta Haematol. 2005;113(2):146-9. [pmid: 15802895].
871 Gianella S, Schaer DJ, Schwarz U, et al. Retinal microangiopathy and rapidly fatal cerebral edema in a patient with adult-onset Still’s disease and concurrent macrophage activation syndrome. Am J Hematol. May. 2008;83(5):424-7. [pmid: 18183612].
872 Giannelli G, Iannone F, Marinosci F, et al. Infliximab therapy does not modify MMP-2 and MMP-9 serum concentrations in chronic arthritis. Clin Exp Rheumatol. Nov–Dec. 2005;23(6):867-72. [pmid: 16396706].
873 Giardina AR, Accardo-Palumbo A, Ciccia F, et al. Blocking TNF in vitro with infliximab determines the inhibition of expansion and interferon gamma production of Vgamma9/Vdelta2 T lymphocytes from patients with active rheumatoid arthritis. A role in the susceptibility to tuberculosis?. Reumatismo. Jan-Mar. 2009;61(1):21-6. [pmid: 19370184].
874 Gibofsky A, Palmer WR, Goldman JA, et al. Real-world utilization of DMARDs and biologics in rheumatoid arthritis: the RADIUS (Rheumatoid Arthritis Disease-Modifying Anti-Rheumatic Drug Intervention and Utilization Study) study. Curr Med Res Opin. Jan. 2006;22(1):169-83. [pmid: 16393443].
875 Gibson JN, Poyser NL, Morrison WL, et al. Muscle protein synthesis in patients with rheumatoid arthritis: effect of chronic corticosteroid therapy on prostaglandin F2 alpha availability. Eur J Clin Invest. Aug. 1991;21(4):406-12. [pmid: 1936108].
876 Gilbert ME, Savino PJ. Missing the bull’s eye. Surv Ophthalmol. Jul–Aug. 2007;52(4):440-2. [pmid: 17574068].
877 Gilbert TD Jr, Smith D, Ollendorf DA. Patterns of use, dosing, and economic impact of biologic agent use in patients with rheumatoid arthritis: a retrospective cohort study. BMC Musculoskelet Disord. Oct. 14. 2004;5(1):36. [pmid: 15485582].
878 Gilboe IM, Kvien TK, Haugeberg G, et al. Bone mineral density in systemic lupus erythematosus: comparison with rheumatoid arthritis and healthy controls. Ann Rheum Dis. Feb. 2000;59(2):110-5. [pmid: 10666165].
879 Giles JT, Bartlett SJ, Gelber AC, et al. Tumor necrosis factor inhibitor therapy and risk of serious postoperative orthopedic infection in rheumatoid arthritis. Arthritis Rheum. Apr. 15. 2006;55(2):333-7. [pmid: 16583385].
880 Giles JT, Fernandes V, Lima JA, et al. Myocardial dysfunction in rheumatoid arthritis: epidemiology and pathogenesis. Arthritis Res Ther. 2005;7(5):195-207. [pmid: 16207349].
881 Gill JB. Fat suppression imaging in epidural lipomatosis: case report. J Surg Orthop Adv. Fall. 2007;16(3):144-7. [pmid: 17963658].
882 Giltay EJ, Popp-Snijders C, van Schaardenburg D, et al. Serum testosterone levels are not elevated in patients with ankylosing spondylitis. J Rheumatol. Dec. 1998;25(12):2389-94. [pmid: 9858435].
883 Gladman DD, Mease PJ, Choy EH, et al. Risk factors for radiographic progression in psoriatic arthritis: subanalysis of the randomized controlled trial ADEPT. Arthritis Res Ther. 2010;12(3):R113. [pmid: 20537151].
884 Glass GE, Greig AV, Weir J, et al. Nasal tip necrosis--an unusual presentation of rheumatoid vasculitis. Clin Rheumatol. Nov. 2007;26(11):1943-5. [pmid: 17318275].
885 Gleissner C, Willershausen B, Kaesser U, et al. The role of risk factors for periodontal disease in patients with rheumatoid arthritis. Eur J Med Res. Aug. 18. 1998;3(8):387-92. [pmid: 9707521].
886 Gluck T, Linde HJ, Scholmerich J, et al. Anti-tumor necrosis factor therapy and Listeria monocytogenes infection: report of two cases. Arthritis Rheum. Aug. 2002;46(8):2255-7. author reply 7. [pmid: 12209538].
887 Go RS, Li CY, Tefferi A, et al. Acquired pure red cell aplasia associated with lymphoproliferative disease of granular T lymphocytes. Blood. Jul. 15. 2001;98(2):483-5. [pmid: 11435321].
888 Godaert GL, Hartkamp A, Geenen R, et al. Fatigue in daily life in patients with primary Sjogren’s syndrome and systemic lupus erythematosus. Ann N Y Acad Sci. Jun. 2002;966:320-6. [pmid: 12114289].
889 Godinho F, Godfrin B, El Mahou S, et al. Safety of leflunomide plus infliximab combination therapy in rheumatoid arthritis. Clin Exp Rheumatol. May–Jun. 2004;22(3):328-30. [pmid: 15144127].
890 Goeb V, Buch MH, Vital EM, et al. Costimulation blockade in rheumatic diseases: where we are?. Curr Opin Rheumatol. May. 2009;21(3):244-50. [pmid: 19342956].
891 Goedkoop AY, Kraan MC, Picavet DI, et al. Deactivation of endothelium and reduction in angiogenesis in psoriatic skin and synovium by low dose infliximab therapy in combination with stable methotrexate therapy: a prospective single-centre study. Arthritis Res Ther. 2004;6(4):R326-34. [pmid: 15225368].
892 Goedkoop AY, Kraan MC, Teunissen MB, et al. Early effects of tumour necrosis factor alpha blockade on skin and synovial tissue in patients with active psoriasis and psoriatic arthritis. Ann Rheum Dis. Jul. 2004;63(7):769-73. [pmid: 15194570].
893 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, et al. Patient preferences for treatment: report from a randomised comparison of treatment strategies in early rheumatoid arthritis (BeSt trial). Ann Rheum Dis. Sep. 2007;66(9):1227-32. [pmid: 17405834].
894 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, et al. Clinical and radiographic outcomes of four different treatment strategies in patients with early rheumatoid arthritis (the BeSt study): a randomized, controlled trial. Arthritis Rheum. Nov. 2005;52(11):3381-90. [pmid: 16258899].
895 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, et al. Clinical and radiographic outcomes of four different treatment strategies in patients with early rheumatoid arthritis (the BeSt study): A randomized, controlled trial. Arthritis Rheum. Feb. 2008;58(2 Suppl):S126-35. [pmid: 18240203].
896 Goerres GW, Forster A, Uebelhart D, et al. F-18 FDG whole-body PET for the assessment of disease activity in patients with rheumatoid arthritis. Clin Nucl Med. Jul. 2006;31(7):386-90. [pmid: 16785804].
897 Goerttler E, Kutzner H, Peter HH, et al. Methotrexate-induced papular eruption in patients with rheumatic diseases: a distinctive adverse cutaneous reaction produced by methotrexate in patients with collagen vascular diseases. J Am Acad Dermatol. May. 1999;40(5 Pt 1):702-7. [pmid: 10321597].
898 Goksugur N, Yilmaz F. Medical image. Extensive oral ulcerations. N Z Med J. 2006;119(1242):U2236. [pmid: 16998578].
899 Golan TD, Keren D, Elias N, et al. Severe reversible cardiomyopathy associated with systemic vasculitis in primary Sjogren’s syndrome. Lupus. 1997;6(6):505-8. [pmid: 9256307].
900 Golda N, Feldman M. Histoplasmosis clinically imitating cutaneous malignancy. J Cutan Pathol. Oct. 2008;35(Suppl 1):26-8. [pmid: 18544059].
901 Goldbach-Mansky R, Wilson M, Fleischmann R, et al. Comparison of Tripterygium wilfordii Hook F versus sulfasalazine in the treatment of rheumatoid arthritis: a randomized trial. Ann Intern Med. Aug. 18. 2009;151(4):229-40. W49. 51. [pmid: 19687490].
902 Goldberger C, Dulak J, Duftner C, et al. Vascular endothelial growth factor (VEGF) in ankylosing spondylitis--a pilot study. Wien Med Wochenschr. 2002;152(9–10):223-5. [pmid: 12094393].
903 Goldenberg MM. Etanercept, a novel drug for the treatment of patients with severe, active rheumatoid arthritis. Clin Ther. Jan. 1999;21(1):75-87. discussion 1–2. [pmid: 10090426].
904 Gomez-Reino JJ, Carmona L, Valverde VR, et al. Treatment of rheumatoid arthritis with tumor necrosis factor inhibitors may predispose to significant increase in tuberculosis risk: a multicenter active-surveillance report. Arthritis Rheum. Aug. 2003;48(8):2122-7. [pmid: 12905464].
905 Gonnet-Gracia C, Barnetche T, Richez C, et al. Anti-nuclear antibodies, anti-DNA and C4 complement evolution in rheumatoid arthritis and ankylosing spondylitis treated with TNF-alpha blockers. Clin Exp Rheumatol. May–Jun. 2008;26(3):401-7. [pmid: 18578960].
906 Gonzalez-Alvaro I, Ortiz AM, Tomero EG, et al. Baseline serum RANKL levels may serve to predict remission in rheumatoid arthritis patients treated with TNF antagonists. Ann Rheum Dis. Dec. 2007;66(12):1675-8. [pmid: 17666448].
907 Gonzalez-Chavez JR, Berlingeri-Ramos AC, Sanchez Casiano MA. Puerto Rico psoriasis study group: efficacy and safety of etanercept. J Drugs Dermatol. Nov–Dec. 2005;4(6):735-9. [pmid: 16302559].
908 Gonzalez-Gay MA, De Matias JM, Gonzalez-Juanatey C, et al. Anti-tumor necrosis factor-alpha blockade improves insulin resistance in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):83-6. [pmid: 16539824].
909 Gonzalez-Gay MA, Garcia-Unzueta MT, Berja A, et al. Anti-TNF-alpha therapy does not modulate leptin in patients with severe rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 2009;27(2):222-8. [pmid: 19473561].
910 Gonzalez-Gay MA, Garcia-Unzueta MT, Berja A, et al. Short-term effect of anti-TNF-alpha therapy on nitric oxide production in patients with severe rheumatoid arthritis. Clin Exp Rheumatol. May-Jun. 2009;27(3):452-8. [pmid: 19604438].
911 Gonzalez-Gay MA, Garcia-Unzueta MT, De Matias JM, et al. Influence of anti-TNF-alpha infliximab therapy on adhesion molecules associated with atherogenesis in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2006;24(4):373-9. [pmid: 16956426].
912 Gonzalez-Gay MA, Garcia-Unzueta MT, Gonzalez-Juanatey C, et al. Anti-TNF-alpha therapy modulates resistin in patients with rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 2008;26(2):311-6. [pmid: 18565254].
913 Gonzalez-Gay MA, Llorca J, Garcia-Unzueta MT, et al. High-grade inflammation, circulating adiponectin concentrations and cardiovascular risk factors in severe rheumatoid arthritis. Clin Exp Rheumatol. Jul-Aug. 2008;26(4):596-603. [pmid: 18799090].
914 Gonzalez-Gay MA, Vazquez-Rodriguez TR, Garcia-Unzueta MT, et al. Visfatin is not associated with inflammation or metabolic syndrome in patients with severe rheumatoid arthritis undergoing anti-TNF-alpha therapy. Clin Exp Rheumatol. Jan–Feb. 2010;28(1):56-62. [pmid: 20346239].
915 Gonzalez-Juanatey C, Llorca J, Sanchez-Andrade A, et al. Short-term adalimumab therapy improves endo-thelial function in patients with rheumatoid arthritis refractory to infliximab. Clin Exp Rheumatol. May–Jun. 2006;24(3):309-12. [pmid: 16870100].
916 Gonzalez-Juanatey C, Llorca J, Vazquez-Rodriguez TR, et al. Short-term improvement of endothelial function in rituximab-treated rheumatoid arthritis patients refractory to tumor necrosis factor alpha blocker therapy. Arthritis Rheum. Dec. 15. 2008;59(12):1821-4. [pmid: 19035415].
917 Gonzalez-Juanatey C, Testa A, Garcia-Castelo A, et al. Active but transient improvement of endothelial function in rheumatoid arthritis patients undergoing long-term treatment with anti-tumor necrosis factor alpha antibody. Arthritis Rheum. Jun. 15. 2004;51(3):447-50. [pmid: 15188332].
918 Gonzalez-Lopez MA, Martinez-Taboada VM, Gonzalez-Vela MC, et al. Recall injection-site reactions associated with etanercept therapy: report of two new cases with immunohistochemical analysis. Clin Exp Dermatol. Nov. 2007;32(6):672-4. [pmid: 17953638].
919 Goossens PH, Heemskerk B, van Tongeren J, et al. Reliability and sensitivity to change of various measures of hand function in relation to treatment of synovitis of the metacarpophalangeal joint in rheumatoid arthritis. Rheumatology (Oxford). Aug. 2000;39(8):909-13. [pmid: 10952748].
920 Gorman JD, Sack KE, Davis JC Jr. Treatment of ankylosing spondylitis by inhibition of tumor necrosis factor alpha. N Engl J Med. May. 2. 2002;346(18):1349-56. [pmid: 11986408].
921 Gosset P, Perez T, Lassalle P, et al. Increased TNF-alpha secretion by alveolar macrophages from patients with rheumatoid arthritis. Am Rev Respir Dis. Mar. 1991;143(3):593-7. [pmid: 2001072].
922 Gottenberg JE, Guillevin L, Lambotte O, et al. Tolerance and short term efficacy of rituximab in 43 patients with systemic autoimmune diseases. Ann Rheum Dis. Jun. 2005;64(6):913-20. [pmid: 15550531].
923 Gottenberg JE, Miceli-Richard C, Ducot B, et al. Markers of B-lymphocyte activation are elevated in patients with early rheumatoid arthritis and correlated with disease activity in the ESPOIR cohort. Arthritis Res Ther. 2009;11(4):R114. [pmid: 19627580].
924 Gottenberg JE, Ravaud P, Bardin T, et al. Risk factors for severe infections in patients with rheumatoid arthritis treated with rituximab in the autoimmunity and rituximab registry. Arthritis Rheum. Sep. 2010;62(9):2625-32. [pmid: 20506353].
925 Gottlieb AB, Kircik L, Eisen D, et al. Use of etanercept for psoriatic arthritis in the dermatology clinic: the Experience Diagnosing, Understanding Care, and Treatment with Etanercept (EDUCATE) study. J Dermatolog Treat. 2006;17(6):343-52. [pmid: 17853307].
926 Gottlieb AB, Mease PJ, Mark Jackson J, et al. Clinical characteristics of psoriatic arthritis and psoriasis in dermatologists’ offices. J Dermatolog Treat. 2006;17(5):279-87. [pmid: 17092858].
927 Gough A, Sheeran T, Arthur V, et al. Adverse interaction between intramuscular methylprednisolone and sulphasalazine in patients with early rheumatoid arthritis. A pilot study. Scand J Rheumatol. 1994;23(1):46-8. [pmid: 7906428].
928 Graf C, Cardoso G, Silva MB, et al. Intra ocular pressure in chronic users of oral glucocorticoids for rheumatoid arthritis. Acta Reumatol Port. Apr–Jun. 2006;31(2):151-5. 83. [pmid: 17058361].
929 Gran JT, Myklebust G. Toxicity of sulphasalazine in rheumatoid arthritis. Possible protective effect of rheumatoid factors and corticosteroids. Scand J Rheumatol. 1993;22(5):229-32. [pmid: 7901898].
930 Grange L, Nissen MJ, Garambois K, et al. Infliximab-induced cerebral thrombophlebitis. Rheumatology (Oxford). Feb. 2005;44(2):260-1. [pmid: 15637045].
931 Granjo E, Lima M, Correia T, et al. Cd8(+)/V beta 5.1(+) large granular lymphocyte leukemia associated with autoimmune cytopenias, rheumatoid arthritis and vascular mammary skin lesions: successful response to 2-deoxycoformycin. Hematol Oncol. Jun. 2002;20(2):87-93. [pmid: 12111871].
932 Grassi W, De Angelis R, Cervini C. Corticosteroid prescribing in rheumatoid arthritis and psoriatic arthritis. Clin Rheumatol. 1998;17(3):223-6. [pmid: 9694057].
933 Grassi W, Lamanna G, Farina A, et al. Synovitis of small joints: sonographic guided diagnostic and therapeutic approach. Ann Rheum Dis. Oct. 1999;58(10):595-7. [pmid: 10491357].
934 Gratacos J, Casado E, Real J, et al. Prediction of major clinical response (ACR50) to infliximab in psoriatic arthritis refractory to methotrexate. Ann Rheum Dis. Apr. 2007;66(4):493-7. [pmid: 17179176].
935 Gray RE, Doherty SM, Galloway J, et al. A double-blind study of deflazacort and prednisone in patients with chronic inflammatory disorders. Arthritis Rheum. Mar. 1991;34(3):287-95. [pmid: 2003854].
936 Greenberg JD, Kishimoto M, Strand V, et al. Tumor necrosis factor antagonist responsiveness in a United States rheumatoid arthritis cohort. Am J Med. Jun. 2008;121(6):532-8. [pmid: 18501236].
937 Greenwood MC, Hakim AJ, Doyle DV. A simple extension to the Rheumatoid Arthritis Quality of Life Questionnaire (RAQol) to explore individual patient concerns and monitor group outcome in clinical practice. Rheumatology (Oxford). Jan. 2006;45(1):61-5. [pmid: 16263783].
938 Grijalva CG, Chung CP, Arbogast PG, et al. Assessment of adherence to and persistence on disease-modifying antirheumatic drugs (DMARDs) in patients with rheumatoid arthritis. Med Care. 2007;45(10 Supl 2):S66-76. [pmid: 17909386].
939 Grijalva CG, Chung CP, Stein CM, et al. Changing patterns of medication use in patients with rheumatoid arthritis in a Medicaid population. Rheumatology (Oxford). Jul. 2008;47(7):1061-4. [pmid: 18499716].
940 Grijalva CG, Kaltenbach L, Arbogast PG, et al. Adherence to disease-modifying antirheumatic drugs and the effects of exposure misclassification on the risk of hospital admission. Arthritis Care Res (Hoboken). 2010;62(5):730-4. [pmid: 20191470].
941 Grinblat B, Scheinberg M. Unexpected onset of psoriasis during infliximab treatment: comment on the article by Beuthien et al. Arthritis Rheum. Apr. 2005;52(4):1333-4. author reply 4. [pmid: 15818679].
942 Grinblat B, Scheinberg M. The enigmatic development of psoriasis and psoriasiform lesions during anti-TNF therapy: a review. Semin Arthritis Rheum. Feb. 2008;37(4):251-5. [pmid: 17640718].
943 Grisar J, Aletaha D, Steiner CW, et al. Endothelial progenitor cells in active rheumatoid arthritis: effects of tumour necrosis factor and glucocorticoid therapy. Ann Rheum Dis. Oct. 2007;66(10):1284-8. [pmid: 17293363].
944 Guarneri C, Polimeni G. Nicolau syndrome following etanercept administration. Am J Clin Dermatol. 2010;11(Suppl 1):51-2. [pmid: 20586511].
945 Guarneri C, Polimeni G, Nunnari G. Pityriasis rosea during etanercept therapy. Eur Rev Med Pharmacol Sci. Sep–Oct. 2009;13(5):383-7. [pmid: 19961045].
946 Guarnieri MV, Rosenberg L, Scheinberg MA. Intractable pain in a rheumatoid wrist. J Rheumatol. Dec. 2003;30(12):2718-9. [pmid: 14719221].
947 Gubinelli E, Angelo C, Pacifico V. A case of dystrophic epidermolysis bullosa improved with etanercept for concomitant psoriatic arthritis. Am J Clin Dermatol. 2010;11(Suppl 1):53-4. [pmid: 20586512].
948 Gudbjornsson B, Skogseid B, Oberg K, et al. Intact adrenocorticotropic hormone secretion but impaired cortisol response in patients with active rheumatoid arthritis. Effect of glucocorticoids. J Rheumatol. Apr. 1996;23(4):596-602. [pmid: 8730111].
949 Gudbrandsdottir S, Bliddal H, Petri A, et al. Plasma TNF binding capacity profiles during treatment with etanercept in rheumatoid arthritis. Scand J Rheumatol. 2004;33(6):385-8. [pmid: 15794196].
950 Guignard S, Dien G, Dougados M. Severe systemic inflammatory response syndrome in a patient with adult onset Still’s disease treated with the anti-IL1 drug anakinra: a case report. Clin Exp Rheumatol. Sep–Oct. 2007;25(5):758-9. [pmid: 18078628].
951 Guignard S, Gossec L, Bandinelli F, et al. Comparison of the clinical characteristics of vasculitis occurring during anti-tumor necrosis factor treatment or not in rheumatoid arthritis patients. A systematic review of 2707 patients, 18 vasculitis. Clin Exp Rheumatol. 2008;26(3 Suppl 49):S23-9. [pmid: 18799049].
952 Guillot X, Solau-Gervais E, Coulon A, et al. Sjogren’s syndrome with ANCA-associated crescentic extramembranous glomerulonephritis. Joint Bone Spine. Mar. 2009;76(2):188-9. [pmid: 19196532].
953 Guion TL, Sculco TP. Pasteurella multocida infection in total knee arthroplasty. Case report and literature review. J Arthroplasty. Jun. 1992;7(2):157-60. [pmid: 1613522].
954 Guis S, Balandraud N, Bouvenot J, et al. Influence of -308 A/G polymorphism in the tumor necrosis factor alpha gene on etanercept treatment in rheumatoid arthritis. Arthritis Rheum. Dec. 15. 2007;57(8):1426-30. [pmid: 18050183].
955 Gul U, Gonul M, Kilic A, et al. Treatment of psoriatic arthritis with etanercept, methotrexate, and cyclosporin A. Clin Ther. Feb. 2006;28(2):251-4. [pmid: 16678646].
956 Guler-Yuksel M, Allaart CF, Goekoop-Ruiterman YP, et al. Changes in hand and generalised bone mineral density in patients with recent-onset rheumatoid arthritis. Ann Rheum Dis. Mar. 2009;68(3):330-6. [pmid: 18375540].
957 Guler-Yuksel M, Bijsterbosch J, Goekoop-Ruiterman YP, et al. Changes in bone mineral density in patients with recent onset, active rheumatoid arthritis. Ann Rheum Dis. Jun. 2008;67(6):823-8. [pmid: 17644545].
958 Guler-Yuksel M, Bijsterbosch J, Goekoop-Ruiterman YP, et al. Bone mineral density in patients with recently diagnosed, active rheumatoid arthritis. Ann Rheum Dis. Nov. 2007;66(11):1508-12. [pmid: 17456523].
959 Guler-Yuksel M, Klarenbeek NB, Goekoop-Ruiterman YP, et al. Accelerated hand bone mineral density loss is associated with progressive joint damage in hands and feet in recent-onset rheumatoid arthritis. Arthritis Res Ther. 2010;12(3):R96. [pmid: 20482894].
960 Gupta A, Bansal RK, Bambery P. Posterior scleritis related fundal mass in a patient with rheumatoid arthritis. Scand J Rheumatol. 1992;21(5):254-6. [pmid: 1439634].
961 Gupta N, Fox CM, Grisolano SW. Disseminated histoplasmosis with colonic ulcers in a patient receiving infliximab. Gastrointest Endosc. Sep. 2009;70(3):597-8. [pmid: 19573865].
962 Gutierrez MA, Garcia ME, Rodriguez JA, et al. Hypothalamic-pituitary-adrenal axis function in patients with active rheumatoid arthritis: a controlled study using insulin hypoglycemia stress test and prolactin stimulation. J Rheumatol. Feb. 1999;26(2):277-81. [pmid: 9972958].
963 Guzman-Clark JR, Fang MA, Sehl ME, et al. Barriers in the management of glucocorticoid-induced osteoporosis. Arthritis Rheum. Feb. 15. 2007;57(1):140-6. [pmid: 17266078].
964 Gwak GY, Koh KC, Kim HY. Fatal hepatic failure associated with hepatitis B virus reactivation in a hepatitis B surface antigen-negative patient with rheumatoid arthritis receiving low dose methotrexate. Clin Exp Rheumatol. Nov–Dec. 2007;25(6):888-9. [pmid: 18173926].
965 Habib GS, Haj S. Bone mineral density in patients with early rheumatoid arthritis treated with corticosteroids. Clin Rheumatol. Apr. 2005;24(2):129-33. [pmid: 15372317].
966 Hadi A, Hickling P, Brown M, et al. Scintigraphic evidence of effect of infliximab on disease activity in ankylosing spondylitis. Rheumatology (Oxford). Jan. 2002;41(1):114-6. [pmid: 11792894].
967 Hadj Kacem H, Kaddour N, Adyel FZ, et al. HLA-DQB1 CAR1/CAR2, TNFa IR2/IR4 and CTLA-4 polymorphisms in Tunisian patients with rheumatoid arthritis and Sjogren’s syndrome. Rheumatology (Oxford). Dec. 2001;40(12):1370-4. [pmid: 11752507].
968 Haerden J, Coolen L, Dequeker J. The effect of D-penicillamine on lung function parameters (diffusion capacity) in rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 1993;11(5):509-13. [pmid: 8275586].
969 Hafstrom I, Albertsson K, Boonen A, et al. Remission achieved after 2 years treatment with low-dose prednisolone in addition to disease-modifying anti-rheumatic drugs in early rheumatoid arthritis is associated with reduced joint destruction still present after 4 years: an open 2-year continuation study. Ann Rheum Dis. Apr. 2009;68(4):508-13. [pmid: 18420939].
970 Hafstrom I, Rohani M, Deneberg S, et al. Effects of low-dose prednisolone on endothelial function, atherosclerosis, and traditional risk factors for atherosclerosis in patients with rheumatoid arthritis--a randomized study. J Rheumatol. Sep. 2007;34(9):1810-6. [pmid: 17696277].
971 Hage CA, Wood KL, Winer-Muram HT, et al. Pulmonary cryptococcosis after initiation of anti-tumor necrosis factor-alpha therapy. Chest. Dec. 2003;124(6):2395-7. [pmid: 14665529].
972 Hagiwara K, Sato T, Takagi-Kobayashi S, et al. Acute exacerbation of preexisting interstitial lung disease after administration of etanercept for rheumatoid arthritis. J Rheumatol. May. 2007;34(5):1151-4. [pmid: 17444583].
973 Hahtola PA, Jarvenpaa RE, Lounatmaa K, et al. Hard metal alveolitis accompanied by rheumatoid arthritis. Respiration. 2000;67(2):209-12. [pmid: 10773796].
974 Haibel H, Rudwaleit M, Brandt HC, et al. Adalimumab reduces spinal symptoms in active ankylosing spondylitis: clinical and magnetic resonance imaging results of a fifty-two-week open-label trial. Arthritis Rheum. Feb. 2006;54(2):678-81. [pmid: 16447247].
975 Haibel H, Rudwaleit M, Listing J, et al. Open label trial of anakinra in active ankylosing spondylitis over 24 weeks. Ann Rheum Dis. Feb. 2005;64(2):296-8. [pmid: 15208175].
976 Haigh RC, McCabe CS, Halligan PW, et al. Joint stiffness in a phantom limb: evidence of central nervous system involvement in rheumatoid arthritis. Rheumatology (Oxford). Jul. 2003;42(7):888-92. [pmid: 12730550].
977 Hall GM, Daniels M, Doyle DV, et al. Effect of hormone replacement therapy on bone mass in rheumatoid arthritis patients treated with and without steroids. Arthritis Rheum. Oct. 1994;37(10):1499-505. [pmid: 7945476].
978 Hall GM, Peerbhoy D, Shenkin A, et al. Hip and knee arthroplasty: a comparison and the endocrine, metabolic and inflammatory responses. Clin Sci (Lond). Jan. 2000;98(1):71-9. [pmid: 10600661].
979 Hall GM, Perry LA, Spector TD. Depressed levels of dehydroepiandrosterone sulphate in postmenopausal women with rheumatoid arthritis but no relation with axial bone density. Ann Rheum Dis. Mar. 1993;52(3):211-4. [pmid: 8484674].
980 Hall GM, Spector TD, Delmas PD. Markers of bone metabolism in postmenopausal women with rheumatoid arthritis. Effects of corticosteroids and hormone replacement therapy. Arthritis Rheum. Jul. 1995;38(7):902-6. [pmid: 7612039].
981 Hall GM, Spector TD, Griffin AJ, et al. The effect of rheumatoid arthritis and steroid therapy on bone density in postmenopausal women. Arthritis Rheum. Nov. 1993;36(11):1510-6. [pmid: 8240428].
982 Hall HA, Zimmermann B. Evolution of dermatomyositis during therapy with a tumor necrosis factor alpha inhibitor. Arthritis Rheum. Dec. 15. 2006;55(6):982-4. [pmid: 17139649].
983 Hall J, Morand EF, Medbak S, et al. Abnormal hypothalamic-pituitary-adrenal axis function in rheumatoid arthritis. Effects of nonsteroidal antiinflammatory drugs and water immersion. Arthritis Rheum. Aug. 1994;37(8):1132-7. [pmid: 8053951].
984 Hall SJ, Hickling P. Failure of etanercept to control extra-articular manifestations of rheumatoid arthritis. J Clin Rheumatol. Feb. 2007;13(1):54. [pmid: 17278957].
985 Halpern MT, Cifaldi MA, Kvien TK. Impact of adalimumab on work participation in rheumatoid arthritis: comparison of an open-label extension study and a registry-based control group. Ann Rheum Dis. Jun. 2009;68(6):930-7. [pmid: 18829616].
986 Halvorsen EH, Haavardsholm EA, Pollmann S, et al. Serum IgG antibodies to peptidylarginine deiminase 4 predict radiographic progression in patients with rheumatoid arthritis treated with tumour necrosis factor-alpha blocking agents. Ann Rheum Dis. Feb. 2009;68(2):249-52. [pmid: 18723564].
987 Hamada H, Kohno N, Yokoyama A, et al. KL-6 as a serologic indicator of Pneumocystis carinii pneumonia in immunocompromised hosts. Intern Med. Mar. 1998;37(3):307-10. [pmid: 9617869].
988 Hamadeh MA, Atkinson J, Smith LJ. Sulfasalazine-induced pulmonary disease. Chest. Apr. 1992;101(4):1033-7. [pmid: 1348220].
989 Hamalainen H, Arkela-Kautiainen M, Kautiainen H, et al. Bone mineral content in young adults with active or inactive juvenile idiopathic arthritis and in controls. Scand J Rheumatol. May. 2010;39(3):219-22. [pmid: 20059447].
990 Hamilton TK. Treatment of psoriatic arthritis and recalcitrant skin disease with combination therapy. J Drugs Dermatol. Nov. 2008;7(11):1089-93. [pmid: 19110745].
991 Hammer HB, Sveinsson M, Kongtorp AK, et al. A 78-joints ultrasonographic assessment is associated with clinical assessments and is highly responsive to improvement in a longitudinal study of patients with rheumatoid arthritis starting adalimumab treatment. Ann Rheum Dis. Jul. 2010;69(7):1349-51. [pmid: 20472599].
992 Hammoudeh M. Infliximab treatment in a patient with rheumatoid arthritis on haemodialysis. Rheumatology (Oxford). Mar. 2006;45(3):357-9. [pmid: 16368727].
993 Hammoudeh M. Recurrent postpartum episodic rheumatoid arthritis. J Clin Rheumatol. Aug. 2006;12(4):196-8. [pmid: 16891925].
994 Han C, Rahman MU, Doyle MK, et al. Association of anemia and physical disability among patients with rheumatoid arthritis. J Rheumatol. Nov. 2007;34(11):2177-82. [pmid: 17937474].
995 Han C, Smolen J, Kavanaugh A, et al. Comparison of employability outcomes among patients with early or long-standing rheumatoid arthritis. Arthritis Rheum. Apr. 15. 2008;59(4):510-4. [pmid: 18383415].
996 Hanauer SB. Review article: safety of infliximab in clinical trials. Aliment Pharmacol Ther. Sep. 1999;13(Suppl 4):16-22. discussion 38. [pmid: 10597335].
997 Hanna B, Holdeman NR, Tang RA, et al. Retinal toxicity secondary to Plaquenil therapy. Optometry. Feb. 2008;79(2):90-4. [pmid: 18215798].
998 Hansel S, Lassig G, Pistrosch F, et al. Endothelial dysfunction in young patients with long-term rheumatoid arthritis and low disease activity. Atherosclerosis. Sep. 2003;170(1):177-80. [pmid: 12957697].
999 Hansen IB, Ellingsen T, Hornung N, et al. Plasma level of CXC-chemokine CXCL12 is increased in rheumatoid arthritis and is independent of disease activity and methotrexate treatment. J Rheumatol. Sep. 2006;33(9):1754-9. [pmid: 16960937].
1000 Hansen KE, Cush J, Singhal A, et al. The safety and efficacy of leflunomide in combination with infliximab in rheumatoid arthritis. Arthritis Rheum. Apr. 15. 2004;51(2):228-32. [pmid: 15077264].
1001 Hansen KE, Hildebrand JP, Genovese MC, et al. The efficacy of switching from etanercept to infliximab in patients with rheumatoid arthritis. J Rheumatol. Jun. 2004;31(6):1098-102. [pmid: 15170921].
1002 Hansen M, Florescu A, Stoltenberg M, et al. Bone loss in rheumatoid arthritis. Influence of disease activity, duration of the disease, functional capacity, and corticosteroid treatment. Scand J Rheumatol. 1996;25(6):367-76. [pmid: 8996471].
1003 Harada K, Akai Y, Koyama S, et al. A case of autoimmune hepatitis exacerbated by the administration of etanercept in the patient with rheumatoid arthritis. Clin Rheumatol. Aug. 2008;27(8):1063-6. [pmid: 18563514].
1004 Harada S, Mitsunobu F, Kodama F, et al. Giant cell arteritis associated with rheumatoid arthritis monitored by magnetic resonance angiography. Intern Med. Aug. 1999;38(8):675-8. [pmid: 10440507].
1005 Haraoui B, Cameron L, Ouellet M, et al. Anti-infliximab antibodies in patients with rheumatoid arthritis who require higher doses of infliximab to achieve or maintain a clinical response. J Rheumatol. Jan. 2006;33(1):31-6. [pmid: 16395747].
1006 Haraoui B, Keystone EC, Thorne JC, et al. Clinical outcomes of patients with rheumatoid arthritis after switching from infliximab to etanercept. J Rheumatol. Dec. 2004;31(12):2356-9. [pmid: 15570634].
1007 Harboe E, Tjensvoll AB, Vefring HK, et al. Fatigue in primary Sjogren’s syndrome--a link to sickness behaviour in animals?. Brain Behav Immun. Nov. 2009;23(8):1104-8. [pmid: 19560535].
1008 Harbuz MS, Korendowych E, Jessop DS, et al. Hypothalamo-pituitary-adrenal axis dysregulation in patients with rheumatoid arthritis after the dexamethasone/corticotrophin releasing factor test. J Endocrinol. Jul. 2003;178(1):55-60. [pmid: 12844336].
1009 Hardy R, Rabbitt EH, Filer A, et al. Local and systemic glucocorticoid metabolism in inflammatory arthritis. Ann Rheum Dis. Sep. 2008;67(9):1204-10. [pmid: 18420938].
1010 Hargreaves MR, Mowat AG, Benson MK. Acute pneumonitis associated with low dose methotrexate treatment for rheumatoid arthritis: report of five cases and review of published reports. Thorax. Aug. 1992;47(8):628-33. [pmid: 1412121].
1011 Harle P, Pongratz G, Weidler C, et al. Possible role of leptin in hypoandrogenicity in patients with systemic lupus erythematosus and rheumatoid arthritis. Ann Rheum Dis. Jul. 2004;63(7):809-16. [pmid: 15194576].
1012 Harle P, Straub RH, Wiest R, et al. Increase of sympathetic outflow measured by neuropeptide Y and decrease of the hypothalamic-pituitary-adrenal axis tone in patients with systemic lupus erythematosus and rheumatoid arthritis: another example of uncoupling of response systems. Ann Rheum Dis. Jan. 2006;65(1):51-6. [pmid: 15941834].
1013 Harley CR, Frytak JR, Tandon N. Treatment compliance and dosage administration among rheumatoid arthritis patients receiving infliximab, etanercept, or methotrexate. Am J Manag Care. Oct. 2003;9(6 Suppl):S136-43. [pmid: 14577718].
1014 Harner KC, Jackson LW, Drabick JJ. Normalization of anticardiolipin antibodies following rituximab therapy for marginal zone lymphoma in a patient with Sjogren’s syndrome. Rheumatology (Oxford). Oct. 2004;43(10):1309-10. [pmid: 15448217].
1015 Harney S, O’Shea FD, FitzGerald O. Peptostreptococcal pericarditis complicating anti-tumour necrosis factor alpha treatment in rheumatoid arthritis. Ann Rheum Dis. Jul. 2002;61(7):653-4. [pmid: 12079913].
1016 Haroon M, Bond U, Phelan M. Sinusitis: a possible link with adalimumab. Clin Rheumatol. Sep. 2008;27(9):1189-90. [pmid: 18581158].
1017 Haroon N, Srivastava R, Misra R, et al. A novel predictor of clinical response to methotrexate in patients with rheumatoid arthritis: a pilot study of in vitro T cell cytokine suppression. J Rheumatol. Jun. 2008;35(6):975-8. [pmid: 18464312].
1018 Harrison DJ, Huang X, Globe D. Dosing patterns and costs of tumor necrosis factor inhibitor use for rheumatoid arthritis. Am J Health Syst Pharm. Aug. 2010;67(15):1281-7. [pmid: 20651319].
1019 Harrison MJ, Dixon WG, Watson KD, et al. Rates of new-onset psoriasis in patients with rheumatoid arthritis receiving anti-tumour necrosis factor alpha therapy: results from the British Society for Rheumatology Biologics Register. Ann Rheum Dis. 2009;68(2):209-15. [pmid: 18385277].
1020 Harrison MJ, Kim CA, Silverberg M, et al. Does age bias the aggressive treatment of elderly patients with rheumatoid arthritis?. J Rheumatol. Jul. 2005;32(7):1243-8. [pmid: 15996058].
1021 Hartkamp A, Geenen R, Godaert GL, et al. Effect of dehydroepiandrosterone administration on fatigue, well-being, and functioning in women with primary Sjogren syndrome: a randomised controlled trial. Ann Rheum Dis. Jan. 2008;67(1):91-7. [pmid: 17545193].
1022 Hashiramoto A, Shiozawa K, Tanaka Y, et al. Prospective study of methotrexate treatment for rheumatoid arthritis treated legitimately according to the government recommended 8 mg/week dose. Mod Rheumatol. 2009;19(6):637-42. [pmid: 19626390].
1023 Hassell AB, Davis MJ, Fowler PD, et al. The relationship between serial measures of disease activity and outcome in rheumatoid arthritis. Q J Med. Sep. 1993;86(9):601-7. [pmid: 8255975].
1024 Hassett AL, Li T, Buyske S, et al. The multi-faceted assessment of independence in patients with rheumatoid arthritis: preliminary validation from the ATTAIN study. Curr Med Res Opin. 2008;24(5):1443-53. [pmid: 18402714].
1025 Hassikou H, El Haouri M, Tabache F, et al. Leflunomide-induced toxic epidermal necrolysis in a patient with rheumatoid arthritis. Joint Bone Spine. Oct. 2008;75(5):597-9. [pmid: 18805724].
1026 Hatemi G, Melikoglu M, Fresko I, et al. Infliximab does not suppress the tuberculin skin test (purified protein derivative). J Rheumatol. Mar. 2007;34(3):474-80. [pmid: 17299840].
1027 Hau M, Kneitz C, Tony HP, et al. High resolution ultrasound detects a decrease in pannus vascularisation of small finger joints in patients with rheumatoid arthritis receiving treatment with soluble tumour necrosis factor alpha receptor (etanercept). Ann Rheum Dis. Jan. 2002;61(1):55-8. [pmid: 11779760].
1028 Haugeberg G, Orstavik RE, Uhlig T, et al. Clinical decision rules in rheumatoid arthritis: do they identify patients at high risk for osteoporosis? Testing clinical criteria in a population based cohort of patients with rheumatoid arthritis recruited from the Oslo Rheumatoid Arthritis Register. Ann Rheum Dis. Dec. 2002;61(12):1085-9. [pmid: 12429540].
1029 Haugeberg G, Orstavik RE, Uhlig T, et al. Bone loss in patients with rheumatoid arthritis: results from a population-based cohort of 366 patients followed up for two years. Arthritis Rheum. Jul. 2002;46(7):1720-8. [pmid: 12124854].
1030 Haugeberg G, Orstavik RE, Uhlig T, et al. Comparison of ultrasound and X-ray absorptiometry bone measurements in a case control study of female rheumatoid arthritis patients and randomly selected subjects in the population. Osteoporos Int. Jun. 2003;14(4):312-9. [pmid: 12730749].
1031 Haugeberg G, Uhlig T, Falch JA, et al. Bone mineral density and frequency of osteoporosis in female patients with rheumatoid arthritis: results from 394 patients in the Oslo County Rheumatoid Arthritis register. Arthritis Rheum. Mar. 2000;43(3):522-30. [pmid: 10728744].
1032 Haugen M, Lien G, Flato B, et al. Young adults with juvenile arthritis in remission attain normal peak bone mass at the lumbar spine and forearm. Arthritis Rheum. Jul. 2000;43(7):1504-10. [pmid: 10902752].
1033 Haugen MA, Lien G, Flato B, et al. Minor impact of juvenile arthritis on nutritional status in young adult patients. Arthritis Rheum. Dec. 15. 2002;47(6):623-9. [pmid: 12522836].
1034 Hauselmann HJ, Caravatti M, Seifert B, et al. Can collagen type II sustain a methotrexate-induced therapeutic effect in patients with long-standing rheumatoid arthritis? A double-blind, randomized trial. Br J Rheumatol. Oct. 1998;37(10):1110-7. [pmid: 9825751].
1035 Havel J, Aboutalebi S, Doughty L, et al. Development of systemic lupus erythematosus in a patient with rheumatoid arthritis following treatment conversion of infliximab to adalimumab. J Drugs Dermatol. Aug. 2008;7(8):796-8. [pmid: 18720701].
1036 Havelka S, Vavrincova P, Stepan J. Metabolic bone status in young women with juvenile chronic arthritis. J Rheumatol Suppl. Apr. 1993;37:14-6. [pmid: 8501744].
1037 Havelka S, Vavrincova P, Stepan J, et al. Metabolic bone status in young women with JCA. Acta Univ Carol [Med] (Praha). 1994;40(1–4):65-7.
1038 Hawboldt J, Bader M. Intramuscular methotrexate-induced aseptic meningitis. Ann Pharmacother. Nov. 2007;41(11):1906-11. [pmid: 17878395].
1039 Hayashi H, Fujimaki C, Daimon T, et al. Genetic polymorphisms in folate pathway enzymes as a possible marker for predicting the outcome of methotrexate therapy in Japanese patients with rheumatoid arthritis. J Clin Pharm Ther. Jun. 2009;34(3):355-61. [pmid: 19827168].
1040 He Y, Lu A, Zha Y, et al. Differential effect on symptoms treated with traditional Chinese medicine and western combination therapy in RA patients. Complement Ther Med. Aug. 2008;16(4):206-11. [pmid: 18638711].
1041 He Y, Lu A, Zha Y, et al. Correlations between symptoms as assessed in traditional chinese medicine (TCM) and ACR20 efficacy response: a comparison study in 396 patients with rheumatoid arthritis treated with TCM or Western medicine. J Clin Rheumatol. Dec. 2007;13(6):317-21. [pmid: 18176139].
1042 Healy PJ, Groves C, Chandramohan M, et al. MRI changes in psoriatic dactylitis--extent of pathology, relationship to tenderness and correlation with clinical indices. Rheumatology (Oxford). Jan. 2008;47(1):92-5. [pmid: 18077498].
1043 Healy PJ, Helliwell PS. Measuring dactylitis in clinical trials: which is the best instrument to use?. J Rheumatol. Jun. 2007;34(6):1302-6. [pmid: 17309128].
1044 Healy PJ, Helliwell PS. Measuring clinical enthesitis in psoriatic arthritis: assessment of existing measures and development of an instrument specific to psoriatic arthritis. Arthritis Rheum. May. 15. 2008;59(5):686-91. [pmid: 18438903].
1045 Hebbar M, Hebbar-Savean K, Hachulla E, et al. Participation of cryoglobulinaemia in the severe peripheral neuropathies of primary Sjogren’s syndrome. Ann Med Interne (Paris). 1995;146(4):235-8. [pmid: 7653942].
1046 Hedman M, Nilsson E, de la Torre B. Low blood and synovial fluid levels of sulpho-conjugated steroids in rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 1992;10(1):25-30. [pmid: 1532354].
1047 Heiberg MS, Koldingsnes W, Mikkelsen K, et al. The comparative one-year performance of anti-tumor necrosis factor alpha drugs in patients with rheumatoid arthritis, psoriatic arthritis, and ankylosing spondylitis: results from a longitudinal, observational, multicenter study. Arthritis Rheum. Feb. 15. 2008;59(2):234-40. [pmid: 18240258].
1048 Heiberg MS, Nordvag BY, Mikkelsen K, et al. The comparative effectiveness of tumor necrosis factor-blocking agents in patients with rheumatoid arthritis and patients with ankylosing spondylitis: a six-month, longitudinal, observational, multicenter study. Arthritis Rheum. Aug. 2005;52(8):2506-12. [pmid: 16052584].
1049 Heikkila R, Aho K, Heliovaara M, et al. Serum androgen-anabolic hormones and the risk of rheumatoid arthritis. Ann Rheum Dis. May. 1998;57(5):281-5. [pmid: 9741311].
1050 Helliwell PS, Taylor WJ. Treatment of psoriatic arthritis and rheumatoid arthritis with disease modifying drugs -- comparison of drugs and adverse reactions. J Rheumatol. Mar. 2008;35(3):472-6. [pmid: 18203324].
1051 Henke PK, Sukheepod P, Proctor MC, et al. Clinical relevance of peripheral vascular occlusive disease in patients with rheumatoid arthritis and systemic lupus erythematosus. J Vasc Surg. Jul. 2003;38(1):111-5. [pmid: 12844099].
1052 Henrickson M, Reiff A. Prolonged efficacy of etanercept in refractory enthesitis-related arthritis. J Rheumatol. Oct. 2004;31(10):2055-61. [pmid: 15468375].
1053 Hepburn AL, Mason JC, Davies KA. Expression of Fcgamma and complement receptors on peripheral blood monocytes in systemic lupus erythematosus and rheumatoid arthritis. Rheumatology (Oxford). May. 2004;43(5):547-54. [pmid: 14747618].
1054 Herenius MM, Hoving JL, Sluiter JK, et al. Improvement of work ability, quality of life, and fatigue in patients with rheumatoid arthritis treated with adalimumab. J Occup Environ Med. Jun. 2010;52(6):618-21. [pmid: 20523240].
1055 Hermann J, Mueller T, Fahrleitner A, et al. Early onset and effective inhibition of bone resorption in patients with rheumatoid arthritis treated with the tumour necrosis factor alpha antibody infliximab. Clin Exp Rheumatol. Jul–Aug. 2003;21(4):473-6. [pmid: 12942699].
1056 Herrera-Esparza R, Avalos-Diaz E. Infliximab treatment in a case of rheumatoid scleromalacia perforans. Reumatismo. Jul–Sep. 2009;61(3):212-5. [pmid: 19888506].
1057 Hetland ML, Stengaard-Pedersen K, Junker P, et al. Combination treatment with methotrexate, cyclosporine, and intraarticular betamethasone compared with methotrexate and intraarticular betamethasone in early active rheumatoid arthritis: an investigator-initiated, multicenter, randomized, double-blind, parallel-group, placebo-controlled study. Arthritis Rheum. May. 2006;54(5):1401-9. [pmid: 16645967].
1058 Hetland ML, Stengaard-Pedersen K, Junker P, et al. Aggressive combination therapy with intra-articular glucocorticoid injections and conventional disease-modifying anti-rheumatic drugs in early rheumatoid arthritis: second-year clinical and radiographic results from the CIMESTRA study. Ann Rheum Dis. Jun. 2008;67(6):815-22. [pmid: 17878209].
1059 Hetland ML, Stengaard-Pedersen K, Junker P, et al. Radiographic progression and remission rates in early rheumatoid arthritis - MRI bone oedema and anti-CCP predicted radiographic progression in the 5-year extension of the double-blind randomised CIMESTRA trial. Ann Rheum Dis. Oct. 2010;69(10):1789-95. [pmid: 20444751].
1060 Heytman M, Ahern MJ, Smith MD, et al. The longterm effect of pulsed corticosteroids on the efficacy and toxicity of chrysotherapy in rheumatoid arthritis. J Rheumatol. Mar. 1994;21(3):435-41. [pmid: 8006886].
1061 Hider SL, Thomson W, Mack LF, et al. Polymorphisms within the adenosine receptor 2a gene are associated with adverse events in RA patients treated with MTX. Rheumatology (Oxford). Aug. 2008;47(8):1156-9. [pmid: 18539621].
1062 Higashida J, Wun T, Schmidt S, et al. Safety and efficacy of rituximab in patients with rheumatoid arthritis refractory to disease modifying antirheumatic drugs and anti-tumor necrosis factor-alpha treatment. J Rheumatol. Nov. 2005;32(11):2109-15. [pmid: 16265687].
1063 High WA, Muldrow ME, Fitzpatrick JE. Cutaneous lupus erythematosus induced by infliximab. J Am Acad Dermatol. Apr. 2005;52(4):E5. [pmid: 15793503].
1064 Hilliquin P, Houbaba H, Aissa J, et al. Correlations between PAF-acether and tumor necrosis factor in rheumatoid arthritis. Influence of parenteral corticosteroids. Scand J Rheumatol. 1995;24(3):169-73. [pmid: 7777830].
1065 Hirabayashi Y, Shimizu H, Kobayashi N, et al. Leflunomide-induced pneumonitis in a patient with rheumatoid arthritis. Intern Med. 2006;45(10):689-91. [pmid: 16778342].
1066 Hirano D, Nagashima M, Ogawa R, et al. Serum levels of interleukin 6 and stress related substances indicate mental stress condition in patients with rheumatoid arthritis. J Rheumatol. Mar. 2001;28(3):490-5. [pmid: 11296947].
1067 Hirano Y, Kishimoto H, Hagino H, et al. The change of bone mineral density in secondary osteoporosis and vertebral fracture incidence. J Bone Miner Metab. 1999;17(2):119-24. [pmid: 10340639].
1068 Hirano Y, Kojima T, Kanayama Y, et al. Influences of anti-tumour necrosis factor agents on postoperative recovery in patients with rheumatoid arthritis. Clin Rheumatol. 2010;29(5):495-500. [pmid: 20069328].
1069 Hirayama T, Danks L, Sabokbar A, et al. Osteoclast formation and activity in the pathogenesis of osteoporosis in rheumatoid arthritis. Rheumatology (Oxford). Nov. 2002;41(11):1232-9. [pmid: 12421995].
1070 Hirche D, Rubbert A, Lunau L, et al. Successful treatment of refractory rheumatoid arthritis-associated leg ulcerations with adalimumab. Br J Dermatol. May. 2005;152(5):1062-4. [pmid: 15888173].
1071 Hirohata M, Yasukawa Y, Ishida C, et al. Reversible cortical lesions in primary Sjogren’s syndrome presenting with meningoencephalitis as an initial manifestation. J Neurol Sci. May. 15. 2005;232(1–2):111-3. [pmid: 15850591].
1072 Hirohata S, Yanagida T, Tomita T, et al. Differential influences of bucillamine and methotrexate on the generation of fibroblast-like cells from bone marrow CD34+ cells of rheumatoid arthritis patients. Int Immunopharmacol. Jan. 2009;9(1):86-90. [pmid: 19000788].
1073 Hirose W, Nishikawa K, Hirose M, et al. Response of early active rheumatoid arthritis to tumor necrosis factor inhibitors: evaluation by magnetic resonance imaging. Mod Rheumatol. 2009;19(1):20-6. [pmid: 18762862].
1074 Hjardem E, Ostergaard M, Podenphant J, et al. Do rheumatoid arthritis patients in clinical practice benefit from switching from infliximab to a second tumor necrosis factor alpha inhibitor?. Ann Rheum Dis. 2007;66(9):1184-9. [pmid: 17389656].
1075 Ho YV, Briganti EM, Duan Y, et al. Polymorphism of the vitamin D receptor gene and corticosteroid-related osteoporosis. Osteoporos Int. 1999;9(2):134-8. [pmid: 10367040].
1076 Hochberg MC, Johnston SS, John AK. The incidence and prevalence of extra-articular and systemic manifestations in a cohort of newly-diagnosed patients with rheumatoid arthritis between 1999 and 2006. Curr Med Res Opin. Feb. 2008;24(2):469-80. [pmid: 18179735].
1077 Hoff M, Kvien TK, Kalvesten J, et al. Adalimumab therapy reduces hand bone loss in early rheumatoid arthritis: explorative analyses from the PREMIER study. Ann Rheum Dis. 2009;68(7):1171-6. [pmid: 18801760].
1078 Holman AJ, Ng E. Heart rate variability predicts anti-tumor necrosis factor therapy response for inflammatory arthritis. Auton Neurosci. Dec. 5. 2008;143(1–2):58-67. [pmid: 18632310].
1079 Homsi S, Alexandrescu DT, Milojkovic N, et al. Diffuse large B-cell lymphoma with lung involvement in a psoriatic arthritis patient treated with methotrexate. Dermatol Online J. 2010;16(5):1. [pmid: 20492818].
1080 Hong BK, Kumar C, Marottoli RA. “MAC” attack. Am J Med”. Dec. 2009;122(12):1096-8. [pmid: 19958886].
1081 Hong S, Kim T, Chung SH, et al. Recurrence after topical nonpreserved methylprednisolone therapy for keratoconjunctivitis sicca in Sjogren’s syndrome. J Ocul Pharmacol Ther. Feb. 2007;23(1):78-82. [pmid: 17341155].
1082 Hooper DR, Tarnopolsky MA, Baker SK. Lewis-Sumner syndrome associated with infliximab therapy in rheumatoid arthritis. Muscle Nerve. Oct. 2008;38(4):1318-25. [pmid: 18671292].
1083 Hoppe E, Masson C, Audran M, et al. Whipple’s disease diagnosed during biological treatment for joint disease. Joint Bone Spine. Jul. 2010;77(4):335-9. [pmid: 20471891].
1084 Hornung N, Ellingsen T, Attermann J, et al. Patients with rheumatoid arthritis treated with methotrexate (MTX): concentrations of steady-state erythrocyte MTX correlate to plasma concentrations and clinical efficacy. J Rheumatol. Sep. 2008;35(9):1709-15. [pmid: 18634162].
1085 Hosaka K, Ryu J, Saitoh S, et al. The combined effects of anti-TNFalpha antibody and IL-1 receptor antagonist in human rheumatoid arthritis synovial membrane. Cytokine. Dec. 21. 2005;32(6):263-9. [pmid: 16406555].
1086 Hoshida Y, Xu JX, Fujita S, et al. Lymphoproliferative disorders in rheumatoid arthritis: clinicopathological analysis of 76 cases in relation to methotrexate medication. J Rheumatol. Feb. 2007;34(2):322-31. [pmid: 17117491].
1087 Hoshida Y, Yamamoto S, Wada N, et al. Infliximab-associated lymphoproliferative disorders. Int J Hematol. May. 2005;81(4):356-7. [pmid: 15914370].
1088 Hot A, Toh ML, Coppere B, et al. Reactive hemophagocytic syndrome in adult-onset Still disease: clinical features and long-term outcome: a case-control study of 8 patients. Medicine (Baltimore). Jan. 2010;89(1):37-46. [pmid: 20075703].
1089 Housden MM, Bell G, Heycock CR, et al. How to reduce morbidity and mortality from chest infections in rheumatoid arthritis. Clin Med. Aug. 2010;10(4):326-9. [pmid: 20849003].
1090 Houtman PM. Septic monarthritis due to Pasteurella multocida after a cat scratch in a patient with rheumatoid arthritis. Neth J Med. Apr. 1990;36(3–4):207-8. [pmid: 2355999].
1091 Hrycaj P, Korczowska I, Lacki JK. Severe Parkinson’s disease in rheumatoid arthritis patient treated with infliximab. Rheumatology (Oxford). May. 2003;42(5):702-3. [pmid: 12709557].
1092 Hrycaj P, Lacki JK. Treatment resistant ankylosing spondylitis with peripheral joint involvement - a case for infliximab?. J Rheumatol. Jan. 2003;30(1):204-6. author reply 6. [pmid: 12508417].
1093 Hsieh TY, Lan JL, Chen DY. Primary Sjogren’s syndrome with protein-losing gastroenteropathy: report of two cases. J Formos Med Assoc. Jul. 2002;101(7):519-22. [pmid: 12353347].
1094 Hsu CT, Lin YT, Yang YH, et al. Factors affecting clinical and therapeutic outcomes of patients with juvenile rheumatoid arthritis. Scand J Rheumatol. 2004;33(5):312-7. [pmid: 15513679].
1095 Hsu PC, Lan JL, Hsieh TY, et al. Methotrexate pneumonitis in a patient with rheumatoid arthritis. J Microbiol Immunol Infect. Jun. 2003;36(2):137-40. [pmid: 12886966].
1096 Hu D, Bao C, Chen S, et al. A comparison study of a recombinant tumor necrosis factor receptor:Fc fusion protein (rhTNFR:Fc) and methotrexate in treatment of patients with active rheumatoid arthritis in China. Rheumatol Int. Jan. 2009;29(3):297-303. [pmid: 18704426].
1097 Hu S, Cohen D, Murphy G, et al. Interstitial granulomatous dermatitis in a patient with rheumatoid arthritis on etanercept. Cutis. Apr. 2008;81(4):336-8. [pmid: 18491481].
1098 Huang F, Zhu J, Zhang L, et al. Response to one infusion predicts subsequent improvement as well as the rate of relapse of ankylosing spondylitis infused with three pulses of infliximab. Clin Rheumatol. Jun. 2007;26(6):920-6. [pmid: 17021665].
1099 Huang X, Gu NY, Fox KM, et al. Comparison of methods for measuring dose escalation of the subcutaneous TNF antagonists for rheumatoid arthritis patients treated in routine clinical practice. Curr Med Res Opin. Jul. 2010;26(7):1637-45. [pmid: 20429830].
1100 Hubscher O, Re R, Iotti R. Pulmonary rheumatoid nodules in an etanercept-treated patient. Arthritis Rheum. Jul. 2003;48(7):2077-8. [pmid: 12847707].
1101 Hughes LB, Criswell LA, Beasley TM, et al. Genetic risk factors for infection in patients with early rheumatoid arthritis. Genes Immun. Dec. 2004;5(8):641-7. [pmid: 15526004].
1102 Hurlimann D, Forster A, Noll G, et al. Anti-tumor necrosis factor-alpha treatment improves endothelial function in patients with rheumatoid arthritis. Circulation. Oct. 22. 2002;106(17):2184-7. [pmid: 12390945].
1103 Huscher D, Thiele K, Gromnica-Ihle E, et al. Dose-related patterns of glucocorticoid-induced side effects. Ann Rheum Dis. Jul. 2009;68(7):1119-24. [pmid: 18684744].
1104 Husni ME, Maier AL, Mease PJ, et al. Etanercept in the treatment of adult patients with Still’s disease. Arthritis Rheum. May. 2002;46(5):1171-6. [pmid: 12115220].
1105 Hussar DA. New drugs: abatacept, sorafenib, and nelarabine. J Am Pharm Assoc (Wash DC). Mar–Apr. 2006;46(2):300-3.
1106 Hutas G. Golimumab, a fully human monoclonal antibody against TNFalpha. Curr Opin Mol Ther. Aug. 2008;10(4):393-406. [pmid: 18683105].
1107 Huwait H, Wang B, Shustik C, et al. Composite cutaneous lymphoma in a patient with rheumatoid arthritis treated with methotrexate. Am J Dermatopathol. Feb. 2010;32(1):65-70. [pmid: 20098085].
1108 Hyon JY, Lee YJ, Yun PY. Management of ocular surface inflammation in Sjogren syndrome. Cornea. Oct. 2007;26(9 Suppl 1):S13-5. [pmid: 17881909].
1109 Hyrich KL, Deighton C, Watson KD, et al. Benefit of anti-TNF therapy in rheumatoid arthritis patients with moderate disease activity. Rheumatology (Oxford). 2009;48(10):1323-7. [pmid: 19706737].
1110 Hyrich KL, Lunt M, Dixon WG, et al. Effects of switching between anti-TNF therapies on HAQ response in patients who do not respond to their first anti-TNF drug. Rheumatology (Oxford). Jul. 2008;47(7):1000-5. [pmid: 18420660].
1111 Hyrich KL, Lunt M, Watson KD, et al. Outcomes after switching from one anti-tumor necrosis factor alpha agent to a second anti-tumor necrosis factor alpha agent in patients with rheumatoid arthritis: results from a large UK national cohort study. Arthritis Rheum. 2007;56(1):13-20. [pmid: 17195186].
1112 Iagnocco A, Filippucci E, Perella C, et al. Clinical and ultrasonographic monitoring of response to adalimumab treatment in rheumatoid arthritis. J Rheumatol. Jan. 2008;35(1):35-40. [pmid: 18050384].
1113 Iagnocco A, Perella C, Naredo E, et al. Etanercept in the treatment of rheumatoid arthritis: clinical follow-up over one year by ultrasonography. Clin Rheumatol. Apr. 2008;27(4):491-6. [pmid: 17952483].
1114 Iannone F, Trotta F, Montecucco C, et al. Etanercept maintains the clinical benefit achieved by infliximab in patients with rheumatoid arthritis who discontinued infliximab because of side effects. Ann Rheum Dis. Feb. 2007;66(2):249-52. [pmid: 16837489].
1115 Ichikawa T, Kageyama Y, Kobayashi H, et al. Etanercept treatment reduces the serum levels of interleukin-15 and interferon-gamma inducible protein-10 in patients with rheumatoid arthritis. Rheumatol Int. Apr. 2010;30(6):725-30. [pmid: 20062995].
1116 Ideguchi H, Ohno S, Ishigatsubo Y. Risk factors associated with the cumulative survival of low-dose methotrexate in 273 Japanese patients with rheumatoid arthritis. J Clin Rheumatol. Apr. 2007;13(2):73-8. [pmid: 17414533].
1117 Iglesias J, Sathiraju S, Marik PE. Severe systemic inflammatory response syndrome with shock and ARDS resulting from Still’s disease: clinical response with high-dose pulse methylprednisolone therapy. Chest. Jun. 1999;115(6):1738-40. [pmid: 10378576].
1118 Iikuni N, Inoue E, Tanaka E, et al. Low disease activity state with corticosteroid may not represent ‘true’ low disease activity state in patients with rheumatoid arthritis. Rheumatology (Oxford). Apr. 2008;47(4):519-21. [pmid: 18356177].
1119 Ikegawa S, Urano F, Suzuki S, et al. Three cases of pustulotic arthro-osteitis associated with episcleritis. J Am Acad Dermatol. Nov. 1999;41(5 Pt 2):845-6. [pmid: 10534666].
1120 Ikonomidis I, Lekakis JP, Nikolaou M, et al. Inhibition of interleukin-1 by anakinra improves vascular and left ventricular function in patients with rheumatoid arthritis. Circulation. May. 20. 2008;117(20):2662-9. [pmid: 18474811].
1121 Ikonomidis I, Tzortzis S, Lekakis J, et al. Lowering interleukin-1 activity with anakinra improves myocardial deformation in rheumatoid arthritis. Heart. Sep. 2009;95(18):1502-7. [pmid: 19482847].
1122 Ilias I, Mastorakos G, Mavrikakis M, et al. Thyroid disease associated with rheumatoid arthritis is not adequately screened with a sensitive chemiluminescence thyrotrophin assay. Acta Med Austriaca. 1999;26(1):26-8. [pmid: 10230473].
1123 Imaizumi K, Sugishita M, Usui M, et al. Pulmonary infectious complications associated with anti-TNFalpha therapy (infliximab) for rheumatoid arthritis. Intern Med. 2006;45(10):685-8. [pmid: 16778341].
1124 Imrich R, Rovensky J, Malis F, et al. Low levels of dehydroepiandrosterone sulphate in plasma, and reduced sympathoadrenal response to hypoglycaemia in premenopausal women with rheumatoid arthritis. Ann Rheum Dis. Feb. 2005;64(2):202-6. [pmid: 15647427].
1125 Imrich R, Rovensky J, Zlnay M, et al. Hypothalamic-pituitary-adrenal axis function in ankylosing spondylitis. Ann Rheum Dis. Jun. 2004;63(6):671-4. [pmid: 15140773].
1126 Imrich R, Vigas M, Rovensky J, et al. Adrenal plasma steroid relations in glucocorticoid-naive premenopausal rheumatoid arthritis patients during insulin-induced hypoglycemia test compared to matched normal control females. Endocr Regul. Apr. 2009;43(2):65-73. [pmid: 19856711].
1127 Imrich R, Vlcek M, Aldag JC, et al. An endocrinologist’s view on relative adrenocortical insufficiency in rheumatoid arthritis. Ann N Y Acad Sci. Apr. 2010;1193(1):134-8. [pmid: 20398019].
1128 Inanc N, Direskeneli H. Serious infections under treatment with TNF-alpha antagonists compared to traditional DMARDs in patients with rheumatoid arthritis. Rheumatol Int. Nov. 2006;27(1):67-71. [pmid: 16896990].
1129 Infante R, Lahita RG. Rheumatoid arthritis. New disease-modifying and anti-inflammatory drugs. Geriatrics. Mar. 2000;55(3):30-2. 5. 6. 9. 40. [pmid: 10732003].
1130 Ingegnoli F, Fantini F, Favalli EG, et al. Inflammatory and prothrombotic biomarkers in patients with rheumatoid arthritis: effects of tumor necrosis factor-alpha blockade. J Autoimmun. Sep. 2008;31(2):175-9. [pmid: 18707846].
1131 Ingegnoli F, Fantini F, Griffini S, et al. Anti-tumor necrosis factor alpha therapy normalizes fibrinolysis impairment in patients with active rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 2010;28(2):254-7. [pmid: 20483049].
1132 Ingegnoli F, Sciascera A, Galbiati V, et al. Bronchus-associated lymphoid tissue lymphoma in a patient with primary Sjogren’s syndrome. Rheumatol Int. Dec. 2008;29(2):207-9. [pmid: 18592243].
1133 Inokuma S, Sato T, Sagawa A, et al. Proposals for leflunomide use to avoid lung injury in patients with rheumatoid arthritis. Mod Rheumatol. 2008;18(5):442-6. [pmid: 18551351].
1134 Inoue K, Takano H, Yanagisawa R, et al. Effects of tumor necrosis factor-alpha inhibitors on lung lesions with rheumatoid arthritis. Chest. Jul. 2003;124(1):413-4. author reply 4. [pmid: 12853558].
1135 Inoue S, Hashiguchi M, Kawai S, et al. Erythrocyte methotrexate-polyglutamate assay using fluorescence polarization immunoassay technique: application to the monitoring of patients with rheumatoid arthritis. Yakugaku Zasshi. Aug. 2009;129(8):1001-5. [pmid: 19652507].
1136 Inoue S, Hashiguchi M, Takagi K, et al. Preliminary study to identify the predictive factors for the response to methotrexate therapy in patients with rheumatoid arthritis. Yakugaku Zasshi. Jul. 2009;129(7):843-9. [pmid: 19571519].
1137 Iobst W, Ingraham K. Sneddon-Wilkinson disease in a patient with rheumatoid arthritis. Arthritis Rheum. Dec. 2005;52(12):3771. [pmid: 16329105].
1138 Ippolito JA, Palmer L, Spector S, et al. Bronchiolitis obliterans organizing pneumonia and rheumatoid arthritis. Semin Arthritis Rheum. Aug. 1993;23(1):70-8. [pmid: 8235666].
1139 Irwin LR, Beckett R, Suman RK. Steroid injection for carpal tunnel syndrome. J Hand Surg [Br]. Jun. 1996;21(3):355-7.
1140 Ishiguro T, Takayanagi N, Kurashima K, et al. Development of sarcoidosis during etanercept therapy. Intern Med. 2008;47(11):1021-5. [pmid: 18520114].
1141 Ishii H, Nagashima M, Tanno M, et al. Does being easily moved to tears as a response to psychological stress reflect response to treatment and the general prognosis in patients with rheumatoid arthritis?. Clin Exp Rheumatol. Sep–Oct. 2003;21(5):611-6. [pmid: 14611110].
1142 Ishikawa Y, Yukawa N, Ohmura K, et al. Etanercept-induced anti-Jo-1-antibody-positive polymyositis in a patient with rheumatoid arthritis: a case report and review of the literature. Clin Rheumatol. May. 2010;29(5):563-6. [pmid: 20143116].
1143 Itonaga I, Fujikawa Y, Sabokbar A, et al. Rheumatoid arthritis synovial macrophage-osteoclast differentiation is osteoprotegerin ligand-dependent. J Pathol. Sep. 2000;192(1):97-104. [pmid: 10951406].
1144 Iwamoto N, Kawakami A, Fujikawa K, et al. Prediction of DAS28-ESR remission at 6 months by baseline variables in patients with rheumatoid arthritis treated with etanercept in Japanese population. Mod Rheumatol. 2009;19(5):488-92. [pmid: 19578932].
1145 Iwatani M, Inoue E, Nakamura T, et al. Efficacy profile of bucillamine in rheumatoid arthritis patients in a large observational cohort study, IORRA. Mod Rheumatol. 2006;16(6):376-80. [pmid: 17165000].
1146 Iyer S, Yamauchi P, Lowe NJ. Etanercept for severe psoriasis and psoriatic arthritis: observations on combination therapy. Br J Dermatol. Jan. 2002;146(1):118-21. [pmid: 11841377].
1147 Izumi A. Varicella zoster virus infection in patients taking the TNF-alpha inhibitor, etanercept: coincidence or causal?. Hawaii Med J. Dec. 2009;68(11):277-8. [pmid: 20034255].
1148 Izumi M, Eguchi K, Nakamura H, et al. Corticosteroid irrigation of parotid gland for treatment of xerostomia in patients with Sjogren’s syndrome. Ann Rheum Dis. Aug. 1998;57(8):464-9. [pmid: 9797551].
1149 Jacobs JW, Geenen R, Evers AW, et al. Short term effects of corticosteroid pulse treatment on disease activity and the wellbeing of patients with active rheumatoid arthritis. Ann Rheum Dis. Jan. 2001;60(1):61-4. [pmid: 11114284].
1150 Jacobsson LT, Turesson C, Gulfe A, et al. Treatment with tumor necrosis factor blockers is associated with a lower incidence of first cardiovascular events in patients with rheumatoid arthritis. J Rheumatol. Jul. 2005;32(7):1213-8. [pmid: 15996054].
1151 James HM, Gillis D, Hissaria P, et al. Common polymorphisms in the folate pathway predict efficacy of combination regimens containing methotrexate and sulfasalazine in early rheumatoid arthritis. J Rheumatol. Apr. 2008;35(4):562-71. [pmid: 18322994].
1152 Jamnitski A, Visman IM, Peters MJ, et al. Beneficial effect of 1-year etanercept treatment on the lipid profile in responding patients with rheumatoid arthritis: the ETRA study. Ann Rheum Dis. Nov. 2010;69(11):1929-33. [pmid: 20498216].
1153 Jarrett SJ, Cunnane G, Conaghan PG, et al. Anti-tumor necrosis factor-alpha therapy-induced vasculitis: case series. J Rheumatol. Oct. 2003;30(10):2287-91. [pmid: 14528531].
1154 Jenkins EA, Walker-Bone KE, Wood A, et al. The prevention of corticosteroid-induced bone loss with intermittent cyclical etidronate. Scand J Rheumatol. 1999;28(3):152-6. [pmid: 10380836].
1155 Jenks KA, Stamp LK, O’Donnell JL, et al. Leflunomide-associated infections in rheumatoid arthritis. J Rheumatol. Nov. 2007;34(11):2201-3. [pmid: 17937473].
1156 Jeurissen ME, Boerbooms AM, van de Putte LB, et al. Methotrexate versus azathioprine in the treatment of rheumatoid arthritis. A forty-eight-week randomized, double-blind trial. Arthritis Rheum. Aug. 1991;34(8):961-72. [pmid: 1859490].
1157 Jia J, Wang Q, Zhang T, et al. Treatment of ankylosing spondylitis with medicated moxibustion plus salicylazosulfapyridine and methotrexate--a report of 30 cases. J Tradit Chin Med. Mar. 2006;26(1):26-8. [pmid: 16705849].
1158 Jian X, Guo G, Ruan Y, et al. Severe cutaneous adverse drug reaction to leflunomide: a report of two cases. Cutan Ocul Toxicol. 2008;27(1):5-9. [pmid: 18330828].
1159 Jiang Y, Genant HK, Watt I, et al. A multicenter, double-blind, dose-ranging, randomized, placebo-controlled study of recombinant human interleukin-1 receptor antagonist in patients with rheumatoid arthritis: radiologic progression and correlation of Genant and Larsen scores. Arthritis Rheum. May. 2000;43(5):1001-9. [pmid: 10817552].
1160 Jimenez FG, Colmenero JD, Irigoyen MV. Reactivation of brucellosis after treatment with infliximab in a patient with rheumatoid arthritis. J Infect. May. 2005;50(4):370-1. [pmid: 15845443].
1161 Jin T, Bokarewa M, Amu S, et al. Impact of short-term therapies with biologics on prothrombotic biomarkers in rheumatoid arthritis. Clin Exp Rheumatol. May–Jun. 2009;27(3):491-4. [pmid: 19604443].
1162 Jinno S, Pulido S, Pien BC. First reported United States case of Legionella pneumophila serogroup 1 pneumonia in a patient receiving anti-tumor necrosis factor-alpha therapy. Hawaii Med J. Jun. 2009;68(5):109-12. [pmid: 19583105].
1163 Jo SJ, Park JY, Yoon HS, et al. Case of acrodermatitis continua accompanied by psoriatic arthritis. J Dermatol. Nov. 2006;33(11):787-91. [pmid: 17073995].
1164 Jobanputra P, Amarasena R, Maggs F, et al. Hepatotoxicity associated with sulfasalazine in inflammatory arthritis: A case series from a local surveillance of serious adverse events. BMC Musculoskelet Disord. 2008;9:48. [pmid: 18405372].
1165 Johns KR, Littlejohn GO. The safety and efficacy of cyclosporine (Neoral) in rheumatoid arthritis. J Rheumatol. Oct. 1999;26(10):2110-3. [pmid: 10529125].
1166 Johnsen AK, Schiff MH, Mease PJ, et al. Comparison of 2 doses of etanercept (50 vs 100 mg) in active rheumatoid arthritis: a randomized double blind study. J Rheumatol. Apr. 2006;33(4):659-64. [pmid: 16482646].
1167 Johnson EO, Vlachoyiannopoulos PG, Skopouli FN, et al. Hypofunction of the stress axis in Sjogren’s syndrome. J Rheumatol. Aug. 1998;25(8):1508-14. [pmid: 9712092].
1168 Jois RN, Masding A, Somerville M, et al. Rituximab therapy in patients with resistant rheumatoid arthritis: real-life experience. Rheumatology (Oxford). Jun. 2007;46(6):980-2. [pmid: 17384180].
1169 Jones G. The AMBITION trial: tocilizumab monotherapy for rheumatoid arthritis. Expert Rev Clin Immunol. 2010;6(2):189-95. [pmid: 20402381].
1170 Jones SM, Bhalla AK. Osteoporosis in rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 1993;11(5):557-62. [pmid: 8275594].
1171 Jonsdottir T, Forslid J, van Vollenhoven A, et al. Treatment with tumour necrosis factor alpha antagonists in patients with rheumatoid arthritis induces anticardiolipin antibodies. Ann Rheum Dis. Sep. 2004;63(9):1075-8. [pmid: 15066863].
1172 Jorgensen C, Bressot N, Bologna C, et al. Dysregulation of the hypothalamo-pituitary axis in rheumatoid arthritis. J Rheumatol. Oct. 1995;22(10):1829-33. [pmid: 8991978].
1173 Josefina M, Ana CJ, Ariel V, et al. Development of pseudogout during etanercept treatment. J Clin Rheumatol. Jun. 2007;13(3):177. [pmid: 17551392].
1174 Josipovic B. Levels of dehydroepiandrosterone sulfate in female patients with early stage of rheumatoid arthritis. Ann N Y Acad Sci. Jun. 22. 1999;876:145-7. [pmid: 10415602].
1175 Josipovic B. Adrenal secretion of cortisol in patients with short-lasting rheumatoid arthritis. Z Rheumatol. 2000;59(Suppl 2):II/136. [pmid: 11155796].
1176 Ju JH, Kim SI, Lee JH, et al. Risk of interstitial lung disease associated with leflunomide treatment in Korean patients with rheumatoid arthritis. Arthritis Rheum. 2007;56(6):2094-6. [pmid: 17530652].
1177 Juillard-Condat B, Constantin A, Cambon-Thomsen A, et al. Impact of etanercept on the costs of rheumatoid arthritis (RA): results from a French observational study. Joint Bone Spine. Jan. 2008;75(1):25-8. [pmid: 17913554].
1178 Julkunen H. Hormone replacement therapy in women with rheumatic diseases. Scand J Rheumatol. 2000;29(3):146-53. [pmid: 10898065].
1179 Jung N, Hellmann M, Hoheisel R, et al. An open-label pilot study of the efficacy and safety of anakinra in patients with psoriatic arthritis refractory to or intolerant of methotrexate (MTX). Clin Rheumatol. Oct. 2010;29(10):1169-73. [pmid: 20532937].
1180 Kaaja R, Julkunen H, Ammala P, et al. Congenital heart block: successful prophylactic treatment with intravenous gamma globulin and corticosteroid therapy. Am J Obstet Gynecol. Nov. 1991;165(5 Pt 1):1333-4. [pmid: 1720280].
1181 Kadar J, Petrovicz E. Adult-onset Still’s disease. Best Pract Res Clin Rheumatol. Oct. 2004;18(5):663-76. [pmid: 15454125].
1182 Kadota J, Kusano S, Kawakami K, et al. Usual interstitial pneumonia associated with primary Sjogren’s syndrome. Chest. Dec. 1995;108(6):1756-8. [pmid: 7497800].
1183 Kageyama Y, Kobayashi H, Kato N. Infliximab treatment reduces the serum levels of interleukin-23 in patients with rheumatoid arthritis. Mod Rheumatol. 2009;19(6):657-62. [pmid: 19685204].
1184 Kageyama Y, Kobayashi H, Kato N, et al. Etanercept reduces the serum levels of macrophage chemotactic protein-1 in patients with rheumatoid arthritis. Mod Rheumatol. 2009;19(4):372-8. [pmid: 19458908].
1185 Kageyama Y, Takahashi M, Ichikawa T, et al. Reduction of oxidative stress marker levels by anti-TNF-alpha antibody, infliximab, in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):73-80. [pmid: 18328150].
1186 Kageyama Y, Torikai E, Nagano A. Anti-tumor necrosis factor-alpha antibody treatment reduces serum CXCL16 levels in patients with rheumatoid arthritis. Rheumatol Int. Mar. 2007;27(5):467-72. [pmid: 17051360].
1187 Kahan A, Modder G, Menkes CJ, et al. 169Erbium-citrate synoviorthesis after failure of local corticosteroid injections to treat rheumatoid arthritis-affected finger joints. Clin Exp Rheumatol. Nov–Dec. 2004;22(6):722-6. [pmid: 15638046].
1188 Kahn KL, MacLean CH, Liu H, et al. Application of explicit process of care measurement to rheumatoid arthritis: Moving from evidence to practice. Arthritis Rheum. Dec. 15. 2006;55(6):884-91. [pmid: 17139665].
1189 Kahn P, Weiss M, Imundo LF, et al. Favorable response to high-dose infliximab for refractory childhood uveitis. Ophthalmology. May. 2006;113(5):864 e1-2.
1190 Kaipiainen-Seppanen O, Leino M. Recurrent uveitis in a patient with juvenile spondyloarthropathy associated with tumour necrosis factor alpha inhibitors. Ann Rheum Dis. Jan. 2003;62(1):88-9. [pmid: 12480683].
1191 Kaiser J. Clinical trials. Gene transfer an unlikely contributor to patient’s death. Science. Dec. 7. 2007;318(5856):1535. [pmid: 18063761].
1192 Kaiser J. Gene therapy. Questions remain on cause of death in arthritis trial. Science. Sep. 21. 2007;317(5845):1665. [pmid: 17885103].
1193 Kaiser MJ, Bozonnat MC, Jorgensen C, et al. Effect of etanercept on tenosynovitis and nodules in rheumatoid arthritis. Arthritis Rheum. Feb. 2002;46(2):559-60. [pmid: 11840464].
1194 Kaiser MJ, Sany J. Efficacy of infliximab (Remicade) in the treatment of spondyloarthropathies. two case reports. Joint Bone Spine. Dec. 2001;68(6):525-7. [pmid: 11808993].
1195 Kakkassery V, Mergler S, Pleyer U. Anti-TNF-alpha treatment: a possible promoter in endogenous uveitis? observational report on six patients: occurrence of uveitis following etanercept treatment. Curr Eye Res. Aug. 2010;35(8):751-6. [pmid: 20673052].
1196 Kalden JR, Nusslein HG, Wollenhaupt J, et al. Combination treatment with infliximab and leflunomide in patients with active rheumatoid arthritis: safety and efficacy in an open-label clinical trial. Clin Exp Rheumatol. Sep–Oct. 2008;26(5):834-40. [pmid: 19032816].
1197 Kalla AA, Bewerunge L, Langley A, et al. Trabecular bone density in premenopausal rheumatoid arthritis patients. S Afr Med J. Jan. 2002;92(1):62-8. [pmid: 11936021].
1198 Kalla AA, Brown GM, Meyers OL. Nutritional status in rheumatoid arthritis. Effects of disease activity, corticosteroid therapy and functional impairment. S Afr Med J. Dec. 1992;82(6):411-4. [pmid: 1465690].
1199 Kalla AA, Meyers OL, Kotze TJ, et al. Corticosteroid therapy and bone mass--comparison of rheumatoid arthritis and systemic lupus erythematosus. S Afr Med J. Jul. 1994;84(7):404-9. [pmid: 7709304].
1200 Kalyoncu U, Karadag O, Akdogan A, et al. Pneumocystis carinii pneumonia in a rheumatoid arthritis patient treated with adalimumab. Scand J Infect Dis. 2007;39(5):475-8. [pmid: 17464877].
1201 Kamal KM, Madhavan SS, Hornsby JA, et al. Use of tumor necrosis factor inhibitors in rheumatoid arthritis: a national survey of practicing United States rheumatologists. Joint Bone Spine. Dec. 2006;73(6):718-24. [pmid: 16997599].
1202 Kamarashev J, Lor P, Forster A, et al. Generalised pustular psoriasis induced by cyclosporin a withdrawal responding to the tumour necrosis factor alpha inhibitor etanercept. Dermatology. 2002;205(2):213-6. [pmid: 12218252].
1203 Kameda H, Okuyama A, Tamaru J, et al. Lymphomatoid granulomatosis and diffuse alveolar damage associated with methotrexate therapy in a patient with rheumatoid arthritis. Clin Rheumatol. Sep. 2007;26(9):1585-9. [pmid: 17200802].
1204 Kameda T, Dobashi H, Kittaka K, et al. A case of rheumatoid arthritis complicated by demyelination in both cerebral cortex and spinal cord during etanercept therapy. Mod Rheumatol. 2008;18(4):399-402. [pmid: 18414783].
1205 Kamili QA, Menter A. Atypical presentation of histoplasmosis in a patient with psoriasis and psoriatic arthritis on infliximab therapy. J Drugs Dermatol. Jan. 2010;9(1):57-60. [pmid: 20120426].
1206 Kamper AM, Malbrain M, Zachee P, et al. Parvovirus infection causing red cell aplasia and leukopenia in rheumatoid arthritis. Clin Rheumatol. Mar. 1994;13(1):129-31. [pmid: 8187436].
1207 Kanakoudi-Tsakalidou F, Tzimouli V, Pratsidou-Gertsi P, et al. The significance of persistent newly developed autoantibodies in JIA patients under long-term anti-TNF treatment. Cytokine. Jun. 2008;42(3):293-7. [pmid: 18445529].
1208 Kanbe K, Inoue K, Inoue Y, et al. Histological analysis of synovium in cases of effect attenuation associated with infliximab therapy in rheumatoid arthritis. Clin Rheumatol. Jun. 2008;27(6):777-81. [pmid: 18256870].
1209 Kanbe K, Inoue K, Inoue Y, et al. Histological changes in bone marrow after treatment of infliximab for rheumatoid arthritis. Clin Rheumatol. Apr. 2008;27(4):497-501. [pmid: 18060342].
1210 Kaneko K, Nonomura Y, Watanabe K, et al. Infected abdominal aortic aneurysm caused by nontyphoid Salmonella in an immunocompromised patient with rheumatoid arthritis. J Infect Chemother. Oct. 2009;15(5):312-5. [pmid: 19856069].
1211 Kaneko Y, Suwa A, Ikeda Y, et al. Pneumocystis jiroveci pneumonia associated with low-dose methotrexate treatment for rheumatoid arthritis: report of two cases and review of the literature. Mod Rheumatol. 2006;16(1):36-8. [pmid: 16622722].
1212 Kanekura T, Terasaki K, Higashi Y, et al. Improvement of adult Still’s disease with granulocyte and monocyte adsorption apheresis. Clin Exp Dermatol. Jul. 2004;29(4):410-2. [pmid: 15245543].
1213 Kang CP, Lee KW, Yoo DH, et al. The influence of a polymorphism at position -857 of the tumour necrosis factor alpha gene on clinical response to etanercept therapy in rheumatoid arthritis. Rheumatology (Oxford). Apr. 2005;44(4):547-52. [pmid: 15695296].
1214 Kang MJ, Kim MS, Choi EH, et al. Adenoviral pneumonia during etanercept treatment in a patient with rheumatoid arthritis. Korean J Intern Med. Mar. 2007;22(1):63-6. [pmid: 17427651].
1215 Kang MJ, Lee YH, Lee J. Etanercept-induced systemic lupus erythematosus in a patient with rheumatoid arthritis. J Korean Med Sci. Oct. 2006;21(5):946-9. [pmid: 17043436].
1216 Kanik KS, Chrousos GP, Schumacher HR, et al. Adrenocorticotropin, glucocorticoid, and androgen secretion in patients with new onset synovitis/rheumatoid arthritis: relations with indices of inflammation. J Clin Endocrinol Metab. Apr. 2000;85(4):1461-6. [pmid: 10770182].
1217 Kanis JA, Borgstrom F, De Laet C, et al. Assessment of fracture risk. Osteoporos Int. Jun. 2005;16(6):581-9. [pmid: 15616758].
1218 Kao CD, Liao KK. A flow chart proposed for early diagnosis of cryptococcal infection as a cause of stroke. Acta Neurol Taiwan. Mar. 2009;18(1):30-3. [pmid: 19537572].
1219 Kapetanovic MC, Larsson L, Truedsson L, et al. Predictors of infusion reactions during infliximab treatment in patients with arthritis. Arthritis Res Ther. 2006;8(4):R131. [pmid: 16869978].
1220 Kapetanovic MC, Saxne T, Sjoholm A, et al. Influence of methotrexate, TNF blockers and prednisolone on antibody responses to pneumococcal polysaccharide vaccine in patients with rheumatoid arthritis. Rheumatology (Oxford). Jan. 2006;45(1):106-11. [pmid: 16287919].
1221 Kaplan MJ. Do tumor-necrosis-factor inhibitors prevent first cardiovascular events in patients with rheumatoid arthritis?. Nat Clin Pract Rheumatol. Dec. 2005;1(2):74-5. [pmid: 16932633].
1222 Kaplan RM, Groessl EJ, Sengupta N, et al. Comparison of measured utility scores and imputed scores from the SF-36 in patients with rheumatoid arthritis. Med Care. Jan. 2005;43(1):79-87. [pmid: 15626937].
1223 Karabacakoglu A, Karakose S, Ozerbil OM, et al. Fluoroscopy-guided intraarticular corticosteroid injection into the sacroiliac joints in patients with ankylosing spondylitis. Acta Radiol. Jul. 2002;43(4):425-7. [pmid: 12225487].
1224 Karaca-Mandic P, Joyce GF, Goldman DP, et al. Cost sharing, family health care burden, and the use of specialty drugs for rheumatoid arthritis. Health Serv Res. Oct. 2010;45(5 Pt 1):1227-50. [pmid: 20831715].
1225 Karagiannis S, Papaioannou D, Goulas S, et al. Intestinal tuberculosis in a patient on infliximab treatment. Gastrointest Endosc. Jun. 2008;67(7):1178-9. discussion 9. [pmid: 18329027].
1226 Karanikolas G, Charalambopoulos D, Vaiopoulos G, et al. Adjunctive anakinra in patients with active rheumatoid arthritis despite methotrexate, or leflunomide, or cyclosporin-A monotherapy: a 48-week, comparative, prospective study. Rheumatology (Oxford). 2008;47(9):1384-8. [pmid: 18603660].
1227 Karie S, Gandjbakhch F, Janus N, et al. Kidney disease in RA patients: prevalence and implication on RA-related drugs management: the MATRIX study. Rheumatology (Oxford). Mar. 2008;47(3):350-4. [pmid: 18238787].
1228 Karlsson JA, Kristensen LE, Kapetanovic MC, et al. Treatment response to a second or third TNF-inhibitor in RA: results from the South Swedish Arthritis Treatment Group Register. Rheumatology (Oxford). 2008;47(4):507-13. [pmid: 18304941].
1229 Karstila KL, Rantalaiho VM, Mustonen JT, et al. Renal safety of initial combination versus single DMARD therapy in patients with early rheumatoid arthritis: an 11-year experience from the FIN-RACo Trial. Clin Exp Rheumatol. 2010;28(1):73-8. [pmid: 20346242].
1230 Kary S, Worm M, Audring H, et al. New onset or exacerbation of psoriatic skin lesions in patients with definite rheumatoid arthritis receiving tumour necrosis factor alpha antagonists. Ann Rheum Dis. Mar. 2006;65(3):405-7. [pmid: 16150791].
1231 Kasama T, Wakabayashi K, Odai T, et al. Effects of low-dose mizoribine pulse therapy in combination with methotrexate in rheumatoid arthritis patients with an insufficient response to methotrexate. Mod Rheumatol. 2009;19(4):395-400. [pmid: 19440813].
1232 Kasser UR, Gleissner C, Dehne F, et al. Risk for periodontal disease in patients with longstanding rheumatoid arthritis. Arthritis Rheum. Dec. 1997;40(12):2248-51. [pmid: 9416864].
1233 Kassimos D, Choy EH, Grossman AB, et al. Endogenous opioid tone in patients with rheumatoid arthritis. Br J Rheumatol. May. 1996;35(5):436-40. [pmid: 8646433].
1234 Kastanek L. Using anakinra for adult rheumatoid arthritis. Nurse Pract. Apr. 2002;27(4):62-5. [pmid: 11984420].
1235 Kastbom A, Bratt J, Ernestam S, et al. Fcgamma receptor type IIIA genotype and response to tumor necrosis factor alpha-blocking agents in patients with rheumatoid arthritis. Arthritis Rheum. Feb. 2007;56(2):448-52. [pmid: 17265480].
1236 Kastrinaki MC, Sidiropoulos P, Roche S, et al. Functional, molecular and proteomic characterisation of bone marrow mesenchymal stem cells in rheumatoid arthritis. Ann Rheum Dis. Jun. 2008;67(6):741-9. [pmid: 17921184].
1237 Kasukawa R, Shio K, Kanno Y, et al. Doppler ultrasound measurements of knee joint synovitis in rheumatoid arthritis patients treated with infliximab. Mod Rheumatol. 2007;17(5):376-9. [pmid: 17929128].
1238 Katayama K, Matsuno T. Effects of bisphosphonates on fracture incidence and bone metabolism in rheumatoid arthritis patients in general practice taking long-term corticosteroid therapy: a retrospective study. Clin Drug Investig. 2008;28(3):149-58.
1239 Katayama K, Matsuno T. Long-term efficacy of leflunomide on disease activity and inhibition of joint damage: retrospective comparison with methotrexate for Japanese rheumatoid arthritis patients. Mod Rheumatol. 2009;19(5):513-21. [pmid: 19603251].
1240 Katayama Y, Kohriyama K, Kirizuka K, et al. Sjogren’s syndrome complicated with autoimmune hepatitis and antiphospholipid antibody syndrome. Intern Med. Jan. 2000;39(1):73-6. [pmid: 10674855].
1241 Katchamart W, Trudeau J, Phumethum V, et al. Methotrexate monotherapy versus methotrexate combination therapy with non-biologic disease modifying anti-rheumatic drugs for rheumatoid arthritis. Cochrane Database Syst Rev. 2010;4:CD008495. [pmid: 20393970].
1242 Kato T, Hoshi K, Sekijima Y, et al. Rheumatoid meningitis: an autopsy report and review of the literature. Clin Rheumatol. Dec. 2003;22(6):475-80. [pmid: 14677033].
1243 Kato T, Kiire A, Yamagata H, et al. Hypersensitivity reaction against influenza vaccine in a patient with rheumatoid arthritis after the initiation of etanercept injections. Mod Rheumatol. 2006;16(5):327-9. [pmid: 17039318].
1244 Katoulis AC, Kanelleas A, Zambacos G, et al. Development of two primary malignant melanomas after treatment with adalimumab: a case report and review of the possible link between biological therapy with TNF-alpha antagonists and melanocytic proliferation. Dermatology. Aug. 2010;221(1):9-12. [pmid: 20484878].
1245 Katz JA, Antoni C, Keenan GF, et al. Outcome of pregnancy in women receiving infliximab for the treatment of Crohn’s disease and rheumatoid arthritis. Am J Gastroenterol. Dec. 2004;99(12):2385-92. [pmid: 15571587].
1246 Katz P, Yelin E, Patel V, et al. Patient-reported outcomes following biologic therapy in a sample of adults with rheumatoid arthritis recruited from community-based rheumatologists. Arthritis Rheum. May. 15. 2009;61(5):593-9. [pmid: 19405018].
1247 Kaufman I, Schwartz D, Caspi D, et al. Sjogren’s syndrome - not just Sicca: renal involvement in Sjogren’s syndrome. Scand J Rheumatol. May–Jun. 2008;37(3):213-8. [pmid: 18465457].
1248 Kaufman KR. Etanercept, anticytokines and mania. Int Clin Psychopharmacol. Jul. 2005;20(4):239-41. [pmid: 15933486].
1249 Kaur N, Mahl TC. Pneumocystis jiroveci (carinii) pneumonia after infliximab therapy: a review of 84 cases. Dig Dis Sci. Jun. 2007;52(6):1481-4. [pmid: 17429728].
1250 Kaur PP, Chan VC, Berney SN. Successful etanercept use in an HIV-positive patient with rheumatoid arthritis. J Clin Rheumatol. Apr. 2007;13(2):79-80. [pmid: 17414534].
1251 Kaur PP, Chan VC, Berney SN. Histological evaluation of liver in two rheumatoid arthritis patients with chronic hepatitis B and C treated with TNF-alpha blockade: case reports. Clin Rheumatol. Aug. 2008;27(8):1069-71. [pmid: 18521652].
1252 Kaur PP, Derk CT, Chatterji M, et al. Septic arthritis caused by Actinobacillus ureae in a patient with rheumatoid arthritis receiving anti-tumor necrosis factor-alpha therapy. J Rheumatol. Aug. 2004;31(8):1663-5. [pmid: 15290751].
1253 Kaushik P, Cooper ES, Banda VR, et al. Bronchiolitis obliterans with organizing pneumonia in rheumatoid arthritis--a fatal case and short review of literature. Rheumatol Int. Jun. 2005;25(5):391-3. [pmid: 15378265].
1254 Kavalar R, Skok P, Kramberger KG. Phlegmonous gastritis in a patient with rheumatoid arthritis. Wien Klin Wochenschr. May. 2005;117(9–10):364-8. [pmid: 15989117].
1255 Kavanaugh A, Antoni C, Krueger GG, et al. Infliximab improves health related quality of life and physical function in patients with psoriatic arthritis. Ann Rheum Dis. Apr. 2006;65(4):471-7. [pmid: 16096330].
1256 Kavanaugh A, Klareskog L, van der Heijde D, et al. Improvements in clinical response between 12 and 24 weeks in patients with rheumatoid arthritis on etanercept therapy with or without methotrexate. Ann Rheum Dis. 2008;67(10):1444-7. [pmid: 18535115].
1257 Kavanaugh A, Lee SJ, Weng HH, et al. Patient-derived joint counts are a potential alternative for determining Disease Activity Score. J Rheumatol. 2010;37(5):1035-41. [pmid: 20156946].
1258 Kavanaugh A, McInnes I, Mease P, et al. Golimumab, a new human tumor necrosis factor alpha antibody, administered every four weeks as a subcutaneous injection in psoriatic arthritis: Twenty-four-week efficacy and safety results of a randomized, placebo-controlled study. Arthritis Rheum. 2009;60(4):976-86. [pmid: 19333944].
1259 Kavanaugh A, Rosengren S, Lee SJ, et al. Assessment of rituximab’s immunomodulatory synovial effects (ARISE trial). 1: clinical and synovial biomarker results. Ann Rheum Dis. Mar. 2008;67(3):402-8. [pmid: 17644541].
1260 Kavanaugh A, Smolen JS, Emery P, et al. Effect of certolizumab pegol with methotrexate on home and work place productivity and social activities in patients with active rheumatoid arthritis. Arthritis Rheum. 2009;61(11):1592-600. [pmid: 19877104].
1261 Kavanaugh A, St Clair EW, McCune WJ, et al. Chimeric anti-tumor necrosis factor-alpha monoclonal antibody treatment of patients with rheumatoid arthritis receiving methotrexate therapy. J Rheumatol. Apr. 2000;27(4):841-50. [pmid: 10782805].
1262 Kawano M, Okada K, Muramoto H, et al. Simultaneous, clonally identical T cell expansion in tonsil and synovium in a patient with rheumatoid arthritis and chronic tonsillitis. Arthritis Rheum. Sep. 2003;48(9):2483-8. [pmid: 13130467].
1263 Kawano M, Seya T, Koni I, et al. Elevated serum levels of soluble membrane cofactor protein (CD46, MCP) in patients with systemic lupus erythematosus (SLE). Clin Exp Immunol. Jun. 1999;116(3):542-6. [pmid: 10361248].
1264 Kawashima M, Miossec P. Effect of treatment of rheumatoid arthritis with infliximab on IFN gamma, IL4, T-bet, and GATA-3 expression: link with improvement of systemic inflammation and disease activity. Ann Rheum Dis. Mar. 2005;64(3):415-8. [pmid: 15286007].
1265 Kawashima N, Shindo R, Kohno M. Primary Sjogren’s syndrome with subcortical dementia. Intern Med. Jul. 1993;32(7):561-4. [pmid: 8286835].
1266 Kawashiri SY, Kawakami A, Iwamoto N, et al. Proinflammatory cytokines synergistically enhance the production of chemokine ligand 20 (CCL20) from rheumatoid fibroblast-like synovial cells in vitro and serum CCL20 is reduced in vivo by biologic disease-modifying antirheumatic drugs. J Rheumatol. Nov. 2009;36(11):2397-402. [pmid: 19797510].
1267 Kay J, Matteson EL, Dasgupta B, et al. Golimumab in patients with active rheumatoid arthritis despite treatment with methotrexate: a randomized, double-blind, placebo-controlled, dose-ranging study. Arthritis Rheum. 2008;58(4):964-75. [pmid: 18383539].
1268 Kay LJ, Holland TM, Platt PN. Stress fractures in rheumatoid arthritis: a case series and case-control study. Ann Rheum Dis. Dec. 2004;63(12):1690-2. [pmid: 15547098].
1269 Kaya S, Kaptanoglu E, Elden H, et al. Coexistence of familial Mediterranean fever and juvenile idiopathic arthritis with osteoporosis successfully treated with etanercept. Intern Med. 2010;49(6):619-22. [pmid: 20228604].
1270 Kazkaz L, Marotte H, Hamwi M, et al. Rheumatoid arthritis and genetic markers in Syrian and French populations: different effect of the shared epitope. Ann Rheum Dis. Feb. 2007;66(2):195-201. [pmid: 17068065].
1271 Keane J, Gershon S, Wise RP, et al. Tuberculosis associated with infliximab, a tumor necrosis factor alpha-neutralizing agent. N Engl J Med. Oct. 11. 2001;345(15):1098-104. [pmid: 11596589].
1272 Kedzia A, Boldys A, Krysiak R, et al. Potential benefit of paracetamol administration in adult-onset Still’s disease. Pol Arch Med Wewn. Sep. 2009;119(9):595-8. [pmid: 19776706].
1273 Kekow J, Welte T, Kellner U, et al. Development of rheumatoid nodules during anti-tumor necrosis factor alpha therapy with etanercept. Arthritis Rheum. Mar. 2002;46(3):843-4. [pmid: 11920425].
1274 Kelaidi C, Tulliez M, Lecoq-Lafon C, et al. Long-term remission of an EBV-positive B cell lymphoproliferative disorder associated with rheumatoid arthritis under methotrexate with anti-CD20 monoclonal antibody (Rituximab) monotherapy. Leukemia. Oct. 2002;16(10):2173-4. [pmid: 12357380].
1275 Kelesidis T, Salhotra A, Fleisher J, et al. Listeria endocarditis in a patient with psoriatic arthritis on infliximab: are biologic agents as treatment for inflammatory arthritis increasing the incidence of Listeria infections?. J Infect. May. 2010;60(5):386-96. [pmid: 20176052].
1276 Kellner H, Bornholdt K, Hein G. Leflunomide in the treatment of patients with early rheumatoid arthritis--results of a prospective non-interventional study. Clin Rheumatol. Aug. 2010;29(8):913-20. [pmid: 20496042].
1277 Kelsey JL, Lamster IB. Influence of musculoskeletal conditions on oral health among older adults. Am J Public Health. Jul. 2008;98(7):1177-83. [pmid: 18511715].
1278 Kemp E, Nielsen H, Petersen LJ, et al. Newer immunomodulating drugs in rheumatoid arthritis may precipitate glomerulonephritis. Clin Nephrol. Jan. 2001;55(1):87-8. [pmid: 11200876].
1279 Kennedy JW, Wong LK, Kalantarian B, et al. An unusual presentation of methotrexate-induced B-cell lymphoma of the metacarpophalangeal joint: a case report and literature review. J Hand Surg Am. Sep. 2006;31(7):1193-6. [pmid: 16945726].
1280 Kent PD, Davis JM 3rd, Davis MD, et al. Bullous skin lesions following infliximab infusion in a patient with rheumatoid arthritis. Arthritis Rheum. Aug. 2002;46(8):2257-8. author reply 9. [pmid: 12209539].
1281 Keren Z, Braun-Moscovici Y, Markovits D, et al. Depletion of B lymphocytes in rheumatoid arthritis patients modifies IL-8-anti-IL-8 autoantibody network. Clin Immunol. Oct. 2009;133(1):108-16. [pmid: 19632157].
1282 Kesteman T, Yombi JC, Gigi J, et al. Listeria infections associated with infliximab: case reports. Clin Rheumatol. Dec. 2007;26(12):2173-5. [pmid: 17579802].
1283 Keystone E, Burmester GR, Furie R, et al. Improvement in patient-reported outcomes in a rituximab trial in patients with severe rheumatoid arthritis refractory to anti-tumor necrosis factor therapy. Arthritis Rheum. 2008;59(6):785-93. [pmid: 18512710].
1284 Keystone E, Emery P, Peterfy CG, et al. Rituximab inhibits structural joint damage in patients with rheumatoid arthritis with an inadequate response to tumour necrosis factor inhibitor therapies. Ann Rheum Dis. 2009;68(2):216-21. [pmid: 18388156].
1285 Keystone E, Fleischmann R, Emery P, et al. Safety and efficacy of additional courses of rituximab in patients with active rheumatoid arthritis: an open-label extension analysis. Arthritis Rheum. Dec. 2007;56(12):3896-908. [pmid: 18050221].
1286 Keystone E, Freundlich B, Schiff M, et al. Patients with moderate rheumatoid arthritis (RA) achieve better disease activity states with etanercept treatment than patients with severe RA. J Rheumatol. 2009;36(3):522-31. [pmid: 19228659].
1287 Keystone E, Heijde D, Mason D Jr, et al. Certolizumab pegol plus methotrexate is significantly more effective than placebo plus methotrexate in active rheumatoid arthritis: findings of a fifty-two-week, phase III, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum. 2008;58(11):3319-29. [pmid: 18975346].
1288 Keystone EC, Genovese MC, Klareskog L, et al. Golimumab, a human antibody to tumour necrosis factor {alpha} given by monthly subcutaneous injections, in active rheumatoid arthritis despite methotrexate therapy: the GO-FORWARD Study. Ann Rheum Dis. 2009;68(6):789-96. [pmid: 19066176].
1289 Keystone EC, Kavanaugh AF, Sharp JT, et al. Radiographic, clinical, and functional outcomes of treatment with adalimumab (a human anti-tumor necrosis factor monoclonal antibody) in patients with active rheumatoid arthritis receiving concomitant methotrexate therapy: a randomized, placebo-controlled, 52-week trial. Arthritis Rheum. May. 2004;50(5):1400-11. [pmid: 15146409].
1290 Keystone EC, Schiff MH, Kremer JM, et al. Once-weekly administration of 50 mg etanercept in patients with active rheumatoid arthritis: results of a multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Feb. 2004;50(2):353-63. [pmid: 14872476].
1291 Khan IH, Krishnan VV, Ziman M, et al. A comparison of multiplex suspension array large-panel kits for profiling cytokines and chemokines in rheumatoid arthritis patients. Cytometry B Clin Cytom. May. 2009;76(3):159-68. [pmid: 18823005].
1292 Khanna M, Shirodkar MA, Gottlieb AB. Etanercept therapy in patients with autoimmunity and hepatitis C. J Dermatolog Treat. Dec. 2003;14(4):229-32. [pmid: 14660270].
1293 Kho LK, Kermode AG. Leflunomide-induced peripheral neuropathy. J Clin Neurosci. Feb. 2007;14(2):179-81. [pmid: 17107800].
1294 Khosla P, Aroaa N, Jain S. Tubercular pyomyositis in a case of rheumatoid arthritis being treated with infliximab. Int J Rheum Dis. Feb. 1. 2010;13(1):82-5. [pmid: 20374389].
1295 Kielhorn A, Porter D, Diamantopoulos A, et al. UK cost-utility analysis of rituximab in patients with rheumatoid arthritis that failed to respond adequately to a biologic disease-modifying antirheumatic drug. Curr Med Res Opin. Sep. 2008;24(9):2639-50. [pmid: 18687164].
1296 Kiely PD, Johnson DM. Infliximab and leflunomide combination therapy in rheumatoid arthritis: an open-label study. Rheumatology (Oxford). Jun. 2002;41(6):631-7. [pmid: 12048288].
1297 Kietz DA, Pepmueller PH, Moore TL. Clinical response to etanercept in polyarticular course juvenile rheumatoid arthritis. J Rheumatol. Feb. 2001;28(2):360-2. [pmid: 11246677].
1298 Kietz DA, Pepmueller PH, Moore TL. Therapeutic use of etanercept in polyarticular course juvenile idiopathic arthritis over a two year period. Ann Rheum Dis. Feb. 2002;61(2):171-3. [pmid: 11796406].
1299 Kievit W, Adang EM, Fransen J, et al. The effectiveness and medication costs of three anti-tumour necrosis factor alpha agents in the treatment of rheumatoid arthritis from prospective clinical practice data. Ann Rheum Dis. 2008;67(9):1229-34. [pmid: 18174220].
1300 Kievit W, Fransen J, Oerlemans AJ, et al. The efficacy of anti-TNF in rheumatoid arthritis, a comparison between randomised controlled trials and clinical practice. Ann Rheum Dis. Nov. 2007;66(11):1473-8. [pmid: 17426065].
1301 Kim SK, Jun JB, El-Sohemy A, et al. Cost-effectiveness analysis of MTHFR polymorphism screening by polymerase chain reaction in Korean patients with rheumatoid arthritis receiving methotrexate. J Rheumatol. Jul. 2006;33(7):1266-74. [pmid: 16758511].
1302 Kim TH, Stone M, Payne U, et al. Cartilage biomarkers in ankylosing spondylitis: relationship to clinical variables and treatment response. Arthritis Rheum. Mar. 2005;52(3):885-91. [pmid: 15751093].
1303 Kimball AB, Jackson JM, Sobell JM, et al. Reductions in healthcare resource utilization in psoriatic arthritis patients receiving etanercept therapy: results from the educate trial. J Drugs Dermatol. Mar. 2007;6(3):299-306. [pmid: 17373192].
1304 Kimel M, Cifaldi M, Chen N, et al. Adalimumab plus methotrexate improved SF-36 scores and reduced the effect of rheumatoid arthritis (RA) on work activity for patients with early RA. J Rheumatol. 2008;35(2):206-15. [pmid: 18085743].
1305 Kimura E, Oga S, Pereira RM. Comparative study of the pharmacokinetics of MTX in juvenile idiopathic arthritis patients receiving long-term MTX monotherapy or MTX plus chloroquine. J Clin Pharm Ther. Dec. 2007;32(6):579-84. [pmid: 18021335].
1306 Kimura Y, Fieldston E, Devries-Vandervlugt B, et al. High dose, alternate day corticosteroids for systemic onset juvenile rheumatoid arthritis. J Rheumatol. Aug. 2000;27(8):2018-24. [pmid: 10955346].
1307 Kimura Y, Pinho P, Walco G, et al. Etanercept treatment in patients with refractory systemic onset juvenile rheumatoid arthritis. J Rheumatol. May. 2005;32(5):935-42. [pmid: 15868633].
1308 Kinder A, Stephens S, Mortimer N, et al. Severe herpes zoster after infliximab infusion. Postgrad Med J. Jan. 2004;80(939):26. [pmid: 14760175].
1309 Kinder AJ, Edwards J, Samanta A, et al. Pregnancy in a rheumatoid arthritis patient on infliximab and methotrexate. Rheumatology (Oxford). Sep. 2004;43(9):1195-6. [pmid: 15317958].
1310 Kinjo M, Setoguchi S, Solomon DH. Bone mineral density in older adult patients with rheumatoid arthritis: an analysis of NHANES III. J Rheumatol. Oct. 2007;34(10):1971-5. [pmid: 17896806].
1311 Kiortsis DN, Mavridis AK, Vasakos S, et al. Effects of infliximab treatment on insulin resistance in patients with rheumatoid arthritis and ankylosing spondylitis. Ann Rheum Dis. May. 2005;64(5):765-6. [pmid: 15458960].
1312 Kiortsis DN, Mavridis AK, Vasakos S, et al. Effects of infliximab treatment on lipoprotein profile in patients with rheumatoid arthritis and ankylosing spondylitis. J Rheumatol. May. 2006;33(5):921-3. [pmid: 16541480].
1313 Kirchgatterer A, Weber T, Hinterreiter M, et al. Haemorrhagic colitis due to Escherichia coli O103:H2 associated with infliximab therapy in a patient with rheumatoid arthritis. Rheumatology (Oxford). Mar. 2002;41(3):355-6. [pmid: 11934982].
1314 Kirino Y, Takeno M, Murakami S, et al. Tumor necrosis factor alpha acceleration of inflammatory responses by down-regulating heme oxygenase 1 in human peripheral monocytes. Arthritis Rheum. Feb. 2007;56(2):464-75. [pmid: 17265482].
1315 Kirshen C, Kanigsberg N. Alopecia areata following adalimumab. J Cutan Med Surg. Jan–Feb. 2009;13(1):48-50. [pmid: 19298772].
1316 Kirwan J. Early rheumatoid arthritis: combination therapy with disease-modifying antirheumatic drugs and low-dose glucocorticoids?. Nat Clin Pract Rheumatol. Apr. 2006;2(4):182-3. [pmid: 16932680].
1317 Kirwan JR. The effect of glucocorticoids on joint destruction in rheumatoid arthritis. The Arthritis and Rheumatism Council Low-Dose Glucocorticoid Study Group. N Engl J Med. Jul. 20. 1995;333(3):142-6. [pmid: 7791815].
1318 Klaasen R, Thurlings RM, Wijbrandts CA, et al. The relationship between synovial lymphocyte aggregates and the clinical response to infliximab in rheumatoid arthritis: a prospective study. Arthritis Rheum. Nov. 2009;60(11):3217-24. [pmid: 19877042].
1319 Klareskog L, van der Heijde D, de Jager JP, et al. Therapeutic effect of the combination of etanercept and methotrexate compared with each treatment alone in patients with rheumatoid arthritis: double-blind randomised controlled trial. Lancet. Feb. 28. 2004;363(9410):675-81. [pmid: 15001324].
1320 Klein A, Buskila D, Gladman D, et al. Cortisol catabolism by lymphocytes of patients with systemic lupus erythematosus and rheumatoid arthritis. J Rheumatol. Jan. 1990;17(1):30-3. [pmid: 2313669].
1321 Klein R, Rosenbach M, Kim EJ, et al. Tumor necrosis factor inhibitor-associated dermatomyositis. Arch Dermatol. Jul. 2010;146(7):780-4. [pmid: 20644041].
1322 Klimiuk PA, Kita J, Chwiecko J, et al. The changes in serum chemokines following leflunomide therapy in patients with rheumatoid arthritis. Clin Rheumatol. Jan. 2009;28(1):17-21. [pmid: 18663553].
1323 Klimiuk PA, Sierakowski S, Domyslawska I, et al. Effect of repeated infliximab therapy on serum matrix metalloproteinases and tissue inhibitors of metalloproteinases in patients with rheumatoid arthritis. J Rheumatol. Feb. 2004;31(2):238-42. [pmid: 14760791].
1324 Klimiuk PA, Sierakowski S, Domyslawska I, et al. Regulation of serum chemokines following infliximab therapy in patients with rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 2006;24(5):529-33. [pmid: 17181921].
1325 Klimiuk PA, Sierakowski S, Domyslawska I, et al. Effect of etanercept on serum levels of soluble cell adhesion molecules (sICAM-1, sVCAM-1, and sE-selectin) and vascular endothelial growth factor in patients with rheumatoid arthritis. Scand J Rheumatol. Nov–Dec. 2009;38(6):439-44. [pmid: 19922018].
1326 Kneitz C, Suerbaum S, Beer M, et al. Exacerbation of Whipple’s disease associated with infliximab treatment. Scand J Rheumatol. Mar–Apr. 2005;34(2):148-51. [pmid: 16095013].
1327 Kneitz C, Wilhelm M, Tony HP. Improvement of refractory rheumatoid arthritis after depletion of B cells. Scand J Rheumatol. 2004;33(2):82-6. [pmid: 15163108].
1328 Kobak S. Osteonecrosis and monoarticular rheumatoid arthritis treated with intra-articular adalimumab. Mod Rheumatol. 2008;18(3):290-2. [pmid: 18286352].
1329 Kobak S, Deveci H. Retinopathy due to antimalarial drugs in patients with connective tissue diseases: are they so innocent? A single center retrospective study. Int J Rheum Dis. Aug. 2010;13(3):e11-5. [pmid: 20704603].
1330 Kobayashi K, Okamoto Y, Inoue H, et al. Leukoencephalopathy with cognitive impairment following tocilizumab for the treatment of rheumatoid arthritis (RA). Intern Med. 2009;48(15):1307-9. [pmid: 19652436].
1331 Kobelt G, Andlin-Sobocki P, Brophy S, et al. The burden of ankylosing spondylitis and the cost-effectiveness of treatment with infliximab (Remicade). Rheumatology (Oxford). Sep. 2004;43(9):1158-66. [pmid: 15226514].
1332 Kobelt G, Eberhardt K, Geborek P. TNF inhibitors in the treatment of rheumatoid arthritis in clinical practice: costs and outcomes in a follow up study of patients with RA treated with etanercept or infliximab in southern Sweden. Ann Rheum Dis. Jan. 2004;63(1):4-10. [pmid: 14672883].
1333 Kobelt G, Jonsson L, Young A, et al. The cost-effectiveness of infliximab (Remicade) in the treatment of rheumatoid arthritis in Sweden and the United Kingdom based on the ATTRACT study. Rheumatology (Oxford). Feb. 2003;42(2):326-35. [pmid: 12595631].
1334 Kobelt G, Lindgren P, Singh A, et al. Cost effectiveness of etanercept (Enbrel) in combination with methotrexate in the treatment of active rheumatoid arthritis based on the TEMPO trial. Ann Rheum Dis. Aug. 2005;64(8):1174-9. [pmid: 15708879].
1335 Kobelt G, Sobocki P, Sieper J, et al. Comparison of the cost-effectiveness of infliximab in the treatment of ankylosing spondylitis in the United Kingdom based on two different clinical trials. Int J Technol Assess Health Care. Summer. 2007;23(3):368-75. [pmid: 17579941].
1336 Koch AE, Kunkel SL, Chensue SW, et al. Expression of interleukin-1 and interleukin-1 receptor antagonist by human rheumatoid synovial tissue macrophages. Clin Immunol Immunopathol. Oct. 1992;65(1):23-9. [pmid: 1395121].
1337 Kocharla L, Taylor J, Weiler T, et al. Monitoring methotrexate toxicity in juvenile idiopathic arthritis. J Rheumatol. Dec. 2009;36(12):2813-8. [pmid: 19918032].
1338 Koczan D, Drynda S, Hecker M, et al. Molecular discrimination of responders and nonresponders to anti-TNF alpha therapy in rheumatoid arthritis by etanercept. Arthritis Res Ther. 2008;10(3):R50. [pmid: 18454843].
1339 Koffeman EC, Genovese M, Amox D, et al. Epitope-specific immunotherapy of rheumatoid arthritis: clinical responsiveness occurs with immune deviation and relies on the expression of a cluster of molecules associated with T cell tolerance in a double-blind, placebo-controlled, pilot phase II trial. Arthritis Rheum. Nov. 2009;60(11):3207-16. [pmid: 19877047].
1340 Kogure T, Tatsumi T, Sato H, et al. Traditional herbal medicines (Kampo) for patients with rheumatoid arthritis receiving concomitant methotrexate: a preliminary study. Altern Ther Health Med. Jan–Feb. 2010;16(1):46-51. [pmid: 20085177].
1341 Koh ET. New disease modifying agents in adult rheumatoid arthritis. Ann Acad Med Singapore. Mar. 2001;30(2):170-3. [pmid: 11379415].
1342 Koh MS, Leng PH, Eng P, et al. An unusual cause of pulmonary haemorrhage in a patient with rheumatoid arthritis. Ann Acad Med Singapore. May. 2004;33(3):365-7. [pmid: 15175782].
1343 Kohno M, Tsutsumi A, Matsui H, et al. Interleukin-17 gene expression in patients with rheumatoid arthritis. Mod Rheumatol. 2008;18(1):15-22. [pmid: 18092129].
1344 Koide R, Isoo A, Ishii K, et al. Rheumatoid leptomeningitis: rare complication of rheumatoid arthritis. Clin Rheumatol. Sep. 2009;28(9):1117-9. [pmid: 19415375].
1345 Koike T, Harigai M, Inokuma S, et al. Postmarketing surveillance of the safety and effectiveness of etanercept in Japan. J Rheumatol. May. 2009;36(5):898-906. [pmid: 19332630].
1346 Kojima M, Itoh H, Hirabayashi K, et al. Methtrexate-associated lymphoproliferative disorders. A clinicopathological study of 13 Japanese cases. Pathol Res Pract. 2006;202(9):679-85. [pmid: 16859835].
1347 Kokkinos A, Iliopoulos A, Greka P, et al. Successful treatment of refractory adult-onset Still’s disease with infliximab. A prospective, non-comparative series of four patients. Clin Rheumatol. Feb. 2004;23(1):45-9. [pmid: 14749983].
1348 Kolokotronis A, Avramidou E, Zaraboukas T, et al. Oral tuberculosis associated with a treatment with anti-rheumatic drugs. J Oral Pathol Med. Feb. 2006;35(2):123-5. [pmid: 16430744].
1349 Komai N, Morita Y, Sakuta T, et al. Anti-tumor necrosis factor therapy increases serum adiponectin levels with the improvement of endothelial dysfunction in patients with rheumatoid arthritis. Mod Rheumatol. 2007;17(5):385-90. [pmid: 17929130].
1350 Komano Y, Harigai M, Koike R, et al. Pneumocystis jiroveci pneumonia in patients with rheumatoid arthritis treated with infliximab: a retrospective review and case-control study of 21 patients. Arthritis Rheum. Mar. 15. 2009;61(3):305-12. [pmid: 19248121].
1351 Komatsuda A, Okamoto Y, Hatakeyama T, et al. Sulfasalazine-induced hypersensitivity syndrome and hemophagocytic syndrome associated with reactivation of Epstein-Barr virus. Clin Rheumatol. Mar. 2008;27(3):395-7. [pmid: 17952482].
1352 Komatsuda A, Wakui H, Nimura T, et al. Reversible infliximab-related lymphoproliferative disorder associated with Epstein-Barr virus in a patient with rheumatoid arthritis. Mod Rheumatol. 2008;18(3):315-8. [pmid: 18368468].
1353 Konai MS, Vilar Furtado RN, Dos Santos MF, et al. Monoarticular corticosteroid injection versus systemic administration in the treatment of rheumatoid arthritis patients: a randomized double-blind controlled study. Clin Exp Rheumatol. Mar–Apr. 2009;27(2):214-21. [pmid: 19473560].
1354 Kong XD, Xu D, Zhang W, et al. Clinical features and prognosis in adult-onset Still’s disease: a study of 104 cases. Clin Rheumatol. Sep. 2010;29(9):1015-9. [pmid: 20549276].
1355 Kononoff A, Heiskanen J, Lumiaho J, et al. Intensifying treatment of rheumatoid arthritis with combinations of traditional disease-modifying anti-rheumatic drugs among patients with persistent disease did not reduce the need for large joint surgery. Scand J Rheumatol. Nov–Dec. 2007;36(6):424-7. [pmid: 18092262].
1356 Konttinen YT, Ramsay H, Hietanen J, et al. Otitis externa sicca/fibrotising external otitis (FEO) as a complication of Sjogren’s syndrome. Clin Exp Rheumatol. Nov–Dec. 2000;18(6):746-8. [pmid: 11138341].
1357 Kontzias A, Efthimiou P. Adult-onset Still’s disease: pathogenesis, clinical manifestations and therapeutic advances. Drugs. 2008;68(3):319-37. [pmid: 18257609].
1358 Kopp S, Alstergren P, Ernestam S, et al. Interleukin-1beta influences the effect of infliximab on temporomandibular joint pain in rheumatoid arthritis. Scand J Rheumatol. May–Jun. 2006;35(3):182-8. [pmid: 16766364].
1359 Kopp S, Alstergren P, Ernestam S, et al. Reduction of temporomandibular joint pain after treatment with a combination of methotrexate and infliximab is associated with changes in synovial fluid and plasma cytokines in rheumatoid arthritis. Cells Tissues Organs. 2005;180(1):22-30. [pmid: 16088130].
1360 Korah S, Kuriakose T. Optical coherence tomography in a patient with chloroquine-induced maculopathy. Indian J Ophthalmol. Nov–Dec. 2008;56(6):511-3. [pmid: 18974527].
1361 Korczowska I, Olewicz-Gawlik A, Trefler J, et al. Does low-dose and short-term glucocorticoids treatment increase the risk of osteoporosis in rheumatoid arthritis female patients?. Clin Rheumatol. May. 2008;27(5):565-72. [pmid: 17909741].
1362 Korkmaz C, Kasifoglu T, Yasar B. Acceleration of left-ventricular diastolic dysfunction and pulmonary hypertension after TNF-alpha blocker. Ann Pharmacother. Jun. 2005;39(6):1138-9. [pmid: 15870136].
1363 Kosinski M, Kujawski SC, Martin R, et al. Health-related quality of life in early rheumatoid arthritis: impact of disease and treatment response. Am J Manag Care. Mar. 2002;8(3):231-40. [pmid: 11915973].
1364 Kotaniemi K, Penttila H. Intraocular lens implantation in patients with juvenile idiopathic arthritis-associated uveitis. Ophthalmic Res. 2006;38(6):318-23. [pmid: 17047403].
1365 Kotha P, McGreevy MJ, Kotha A, et al. Early deaths with thrombolytic therapy for acute myocardial infarction in corticosteroid-dependent rheumatoid arthritis. Clin Cardiol. Nov. 1998;21(11):853-6. [pmid: 9825203].
1366 Kothapalli R, Nyland SB, Kusmartseva I, et al. Constitutive production of proinflammatory cytokines RANTES, MIP-1beta and IL-18 characterizes LGL leukemia. Int J Oncol. Feb. 2005;26(2):529-35. [pmid: 15645140].
1367 Kotter I, Wacker A, Koch S, et al. Anakinra in patients with treatment-resistant adult-onset Still’s disease: four case reports with serial cytokine measurements and a review of the literature. Semin Arthritis Rheum. Dec. 2007;37(3):189-97. [pmid: 17583775].
1368 Kovacs A, Szekeres E, Berek L, et al. Relationship between the occurrence of anti-SSA, anti-SSB autoantibodies and HLA class II alleles from the aspect of in vitro inhibitory effect of glucocorticosteroid on the antibody-dependent cellular cytotoxicity in patients with primary Sjogren’s syndrome. Acta Microbiol Immunol Hung. 2000;47(4):421-31. [pmid: 11056762].
1369 Kozaci DL, Chernajovsky Y, Chikanza IC. The differential expression of corticosteroid receptor isoforms in corticosteroid-resistant and -sensitive patients with rheumatoid arthritis. Rheumatology (Oxford). Apr. 2007;46(4):579-85. [pmid: 17043048].
1370 Kozora E, Laudenslager M, Lemieux A, et al. Inflammatory and hormonal measures predict neuropsychological functioning in systemic lupus erythematosus and rheumatoid arthritis patients. J Int Neuropsychol Soc. Sep. 2001;7(6):745-54. [pmid: 11575596].
1371 Kraetsch HG, Antoni C, Kalden JR, et al. Successful treatment of a small cohort of patients with adult onset of Still’s disease with infliximab: first experiences. Ann Rheum Dis. Nov. 55. 2001;60(Suppl 3):iii-7.
1372 Kramer N, Chuzhin Y, Kaufman LD, et al. Methotrexate pneumonitis after initiation of infliximab therapy for rheumatoid arthritis. Arthritis Rheum. Dec. 15. 2002;47(6):670-1. [pmid: 12522843].
1373 Kreitzer T, Saoud A. Bacillary angiomatosis following the use of long-term methotrexate therapy: a case report. W V Med J. Jan–Feb. 2006;102(1):317-8. [pmid: 16706324].
1374 Kremer J, Ritchlin C, Mendelsohn A, et al. Golimumab, a new human anti-tumor necrosis factor alpha antibody, administered intravenously in patients with active rheumatoid arthritis: Forty-eight-week efficacy and safety results of a phase III randomized, double-blind, placebo-controlled study. Arthritis Rheum. 2010;62(4):917-28. [pmid: 20131276].
1375 Kremer JM, Bloom BJ, Breedveld FC, et al. The safety and efficacy of a JAK inhibitor in patients with active rheumatoid arthritis: Results of a double-blind, placebo-controlled phase IIa trial of three dosage levels of CP-690,550 versus placebo. Arthritis Rheum. Jul. 2009;60(7):1895-905. [pmid: 19565475].
1376 Kremer JM, Genant HK, Moreland LW, et al. Results of a two-year followup study of patients with rheumatoid arthritis who received a combination of abatacept and methotrexate. Arthritis Rheum. Apr. 2008;58(4):953-63. [pmid: 18383390].
1377 Kremer JM, Habros JS, Kolba KS, et al. Tacrolimus in rheumatoid arthritis patients receiving concomitant methotrexate: a six-month, open-label study. Arthritis Rheum. Oct. 2003;48(10):2763-8. [pmid: 14558080].
1378 Kremer JM, Weinblatt ME, Bankhurst AD, et al. Etanercept added to background methotrexate therapy in patients with rheumatoid arthritis: continued observations. Arthritis Rheum. Jun. 2003;48(6):1493-9. [pmid: 12794815].
1379 Kremer JM, Westhovens R, Leon M, et al. Treatment of rheumatoid arthritis by selective inhibition of T-cell activation with fusion protein CTLA4Ig. N Engl J Med. 2003;349(20):1907-15. [pmid: 14614165].
1380 Kremers HM, Nicola P, Crowson CS, et al. Therapeutic strategies in rheumatoid arthritis over a 40-year period. J Rheumatol. Dec. 2004;31(12):2366-73. [pmid: 15570636].
1381 Kreuter A, Rose C, Zillikens D, et al. Bullous rheumatoid neutrophilic dermatosis. J Am Acad Dermatol. May. 2005;52(5):916-8. [pmid: 15858492].
1382 Krishnamurthy R, Dincer HE, Whittemore D. Strongyloides stercoralis hyperinfection in a patient with rheumatoid arthritis after anti-TNF-alpha therapy. J Clin Rheumatol. Jun. 2007;13(3):150-2. [pmid: 17551383].
1383 Kriss TC, Kriss VM. Neck pain. Primary care work-up of acute and chronic symptoms. Geriatrics. Jan. 2000;55(1):47-8. 51. 4. 7. [pmid: 10659073].
1384 Kristensen LE, Gulfe A, Saxne T, et al. Efficacy and tolerability of anti-tumour necrosis factor therapy in psoriatic arthritis patients: results from the South Swedish Arthritis Treatment Group register. Ann Rheum Dis. 2008;67(3):364-9. [pmid: 17644547].
1385 Kristensen LE, Kapetanovic MC, Gulfe A, et al. Predictors of response to anti-TNF therapy according to ACR and EULAR criteria in patients with established RA: results from the South Swedish Arthritis Treatment Group Register. Rheumatology (Oxford). Apr. 2008;47(4):495-9. [pmid: 18316338].
1386 Kristensen LE, Saxne T, Geborek P. The LUNDEX, a new index of drug efficacy in clinical practice: results of a five-year observational study of treatment with infliximab and etanercept among rheumatoid arthritis patients in southern Sweden. Arthritis Rheum. Feb. 2006;54(2):600-6. [pmid: 16447237].
1387 Kristensen LE, Saxne T, Nilsson JA, et al. Impact of concomitant DMARD therapy on adherence to treatment with etanercept and infliximab in rheumatoid arthritis. Results from a six-year observational study in southern Sweden. Arthritis Res Ther. 2006;8(6):R174. [pmid: 17121678].
1388 Kritikos K, Haritatos E, Tsigkos S, et al. An atypical presentation of visceral leishmaniasis infection in a patient with rheumatoid arthritis treated with infliximab. J Clin Rheumatol. Jan. 2010;16(1):38-9. [pmid: 20051756].
1389 Kroesen S, Widmer AF, Tyndall A, et al. Serious bacterial infections in patients with rheumatoid arthritis under anti-TNF-alpha therapy. Rheumatology (Oxford). May. 2003;42(5):617-21. [pmid: 12709536].
1390 Kroger H, Honkanen R, Saarikoski S, et al. Decreased axial bone mineral density in perimenopausal women with rheumatoid arthritis--a population based study. Ann Rheum Dis. Jan. 1994;53(1):18-23. [pmid: 8311549].
1391 Kroot EJ, van Gestel AM, Swinkels HL, et al. Chronic comorbidity in patients with early rheumatoid arthritis: a descriptive study. J Rheumatol. Jul. 2001;28(7):1511-7. [pmid: 11469455].
1392 Kruithof E, Baeten D, De Rycke L, et al. Synovial histopathology of psoriatic arthritis, both oligo- and polyarticular, resembles spondyloarthropathy more than it does rheumatoid arthritis. Arthritis Res Ther. 2005;7(3):R569-80. [pmid: 15899044].
1393 Kruize AA, Hene RJ, van der Heide A, et al. Long-term followup of patients with Sjogren’s syndrome. Arthritis Rheum. Feb. 1996;39(2):297-303. [pmid: 8849383].
1394 Kucharekova M, Winnepenninckx V, Frank J, et al. Generalized pustulosis induced by adalimumab in a patient with rheumatoid arthritis - a therapeutic challenge. Int J Dermatol. Nov. 2008;47(Suppl 1):25-8. [pmid: 18986481].
1395 Kucharz EJ, Gozdzik J, Kopec M, et al. A single infusion of infliximab increases the serum endostatin level in patients with rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 2003;21(2):273-4. [pmid: 12747296].
1396 Kuek A, Hazleman BL, Gaston JH, et al. Successful treatment of refractory polyarticular juvenile idiopathic arthritis with rituximab. Rheumatology (Oxford). Nov. 2006;45(11):1448-9. [pmid: 16920752].
1397 Kumar D, Bouldin TW, Berger RG. A case of progressive multifocal leukoencephalopathy in a patient treated with infliximab. Arthritis Rheum. Nov. 2010;62(11):3191-5. [pmid: 20722036].
1398 Kumar N, Sandroni P, Steensma DP, et al. Polyradiculopathy due to methotrexate-induced ebv-associated lymphoproliferative disorder. Neurology. Nov. 11. 2008;71(20):1644-5. [pmid: 19001256].
1399 Kumar S, Gupta N, Jhamb R, et al. Celiac disease: association with adult-onset Still’s disease: apropos of a clinical case. Indian J Med Sci. Jul. 2007;61(7):414-7. [pmid: 17611347].
1400 Kumari R, Uppal SS. Prolonged remission in adult-onset Still’s disease with etanercept. Clin Rheumatol. Feb. 2006;25(1):106-8. [pmid: 15856368].
1401 Kumeda Y, Inaba M, Goto H, et al. Increased thickness of the arterial intima-media detected by ultrasonography in patients with rheumatoid arthritis. Arthritis Rheum. Jun. 2002;46(6):1489-97. [pmid: 12115178].
1402 Kumon Y, Kakigi A, Sugiura T. Clinical images: Otalgia, an unusual complication of Sjogren’s syndrome. Arthritis Rheum. Aug. 2009;60(8):2542. [pmid: 19644861].
1403 Kurasawa M, Kotani K, Kurasawa G, et al. Adult-onset Still’s disease in a patient over 80 years old successfully treated with low-dose methotrexate therapy. Age Ageing. Jan. 2007;36(1):104-6. [pmid: 17158115].
1404 Kuriya B, Arkema EV, Bykerk VP, et al. Efficacy of initial methotrexate monotherapy versus combination therapy with a biological agent in early rheumatoid arthritis: a meta-analysis of clinical and radiographic remission. Ann Rheum Dis. 2010;69(7):1298-304. [pmid: 20421343].
1405 Kurmann PT, Van Linthoudt D, So AK. Miller-Fisher syndrome in a patient with rheumatoid arthritis treated with adalimumab. Clin Rheumatol. Jan. 2009;28(1):93-4. [pmid: 18818868].
1406 Kuroda T, Otaki Y, Sato H, et al. A case of AA amyloidosis associated with rheumatoid arthritis effectively treated with Infliximab. Rheumatol Int. Sep. 2008;28(11):1155-9. [pmid: 18496698].
1407 Kuroda T, Wada Y, Kobayashi D, et al. Effective anti-TNF-alpha therapy can induce rapid resolution and sustained decrease of gastroduodenal mucosal amyloid deposits in reactive amyloidosis associated with rheumatoid arthritis. J Rheumatol. Nov. 2009;36(11):2409-15. [pmid: 19797512].
1408 Kurschat P, Rubbert A, Poswig A, et al. Treatment of psoriatic arthritis with etanercept. J Am Acad Dermatol. Jun. 2001;44(6):1052. [pmid: 11369924].
1409 Kurtais Y, Tur BS, Elhan AH, et al. Hypothalamic-pituitary-adrenal hormonal responses to exercise stress test in patients with rheumatoid arthritis compared to healthy controls. J Rheumatol. Aug. 2006;33(8):1530-7. [pmid: 16881110].
1410 Kuruvilla J, Leitch HA, Vickars LM, et al. Aplastic anemia following administration of a tumor necrosis factor-alpha inhibitor. Eur J Haematol. Nov. 2003;71(5):396-8. [pmid: 14667206].
1411 Kur-Zalewska J, Swarowska-Knap J, Tlustochowicz W. Neurological disorders with demyelinating brain white matter lesions in a patient with rheumatoid arthritis treated with etanercept. Pol Arch Med Wewn. Apr. 2008;118(4):234-7. [pmid: 18575424].
1412 Kurzawski M, Pawlik A, Safranow K, et al. 677C>T and 1298A>C MTHFR polymorphisms affect methotrexate treatment outcome in rheumatoid arthritis. Pharmacogenomics. Nov. 2007;8(11):1551-9. [pmid: 18034620].
1413 Kusabe T, Waguri-Nagaya Y, Tanikawa T, et al. The inhibitory effect of disease-modifying anti-rheumatic drugs and steroids on gliostatin/platelet-derived endothelial cell growth factor production in human fibroblast-like synoviocytes. Rheumatol Int. Oct. 2005;25(8):625-30. [pmid: 15990992].
1414 Kuuliala A, Nissinen R, Kautiainen H, et al. Low circulating soluble interleukin 2 receptor level predicts rapid response in patients with refractory rheumatoid arthritis treated with infliximab. Ann Rheum Dis. Jan. 2006;65(1):26-9. [pmid: 15941839].
1415 Kuzmanova SI. Arthroscopic treatment of rheumatoid synovitis. Folia Med (Plovdiv). 2003;45(3):48-54. [pmid: 15366666].
1416 Kvalvik AG, Aadland HA, Hoyeraal HM, et al. Were the patterns of treatment for rheumatoid arthritis during 1977–1992 consistent with modern clinical guidelines?. Scand J Rheumatol. 2001;30(2):61-8. [pmid: 11324791].
1417 Kvalvik AG, Lefsaker L, Dyvik S, et al. Anti-tumor necrosis factor-alpha therapy in the ordinary clinical setting: Three-year effectiveness in patients with rheumatoid arthritis. Joint Bone Spine. Dec. 2007;74(6):606-11. [pmid: 17900958].
1418 Kvien TK, Haugeberg G, Uhlig T, et al. Data driven attempt to create a clinical algorithm for identification of women with rheumatoid arthritis at high risk of osteoporosis. Ann Rheum Dis. Oct. 2000;59(10):805-11. [pmid: 11005782].
1419 Kwak JJ, Chang JE, Lee J, et al. Chronic eosinophilic pneumonia associated with an initiation of rheumatoid arthritis. Clin Rheumatol. Sep. 2003;22(3):240-3. [pmid: 14505220].
1420 Kwon HH, Baek SH, Park SH. Miliary tuberculosis and necrotizing tuberculous fasciitis--an unusual coexistence in a rheumatoid arthritis patient. Int J Rheum Dis. May. 2010;13(2):171-4. [pmid: 20536603].
1421 Kwon HJ, Cote TR, Cuffe MS, et al. Case reports of heart failure after therapy with a tumor necrosis factor antagonist. Ann Intern Med. May. 20. 2003;138(10):807-11. [pmid: 12755552].
1422 La Montagna G, Cacciapuoti F, Buono R, et al. Insulin resistance is an independent risk factor for atherosclerosis in rheumatoid arthritis. Diab Vasc Dis Res. Jun. 2007;4(2):130-5. [pmid: 17654447].
1423 La Montagna G, Valentini G. Listeria monocytogenes meningitis in a patient receiving etanercept for Still’s disease. Clin Exp Rheumatol. Jan–Feb. 2005;23(1):121. [pmid: 15789900].
1424 Laas K, Peltomaa R, Kautiainen H, et al. Clinical impact of switching from infliximab to etanercept in patients with rheumatoid arthritis. Clin Rheumatol. Jul. 2008;27(7):927-32. [pmid: 18414967].
1425 Labbe P, Hardouin P. Epidemiology and optimal management of polymyalgia rheumatica. Drugs Aging. Aug. 1998;13(2):109-18. [pmid: 9739500].
1426 Lacaille D, Guh DP, Abrahamowicz M, et al. Use of nonbiologic disease-modifying antirheumatic drugs and risk of infection in patients with rheumatoid arthritis. Arthritis Rheum. 2008;59(8):1074-81. [pmid: 18668604].
1427 Lacroix BD, Lovern MR, Stockis A, et al. A pharmacodynamic Markov mixed-effects model for determining the effect of exposure to certolizumab pegol on the ACR20 score in patients with rheumatoid arthritis. Clin Pharmacol Ther. Oct. 2009;86(4):387-95. [pmid: 19626001].
1428 Lafforgue P, Monjanel-Mouterde S, Durand A, et al. Is there an interaction between low doses of corticosteroids and methotrexate in patients with rheumatoid arthritis? A pharmacokinetic study in 33 patients. J Rheumatol. Feb. 1993;20(2):263-7. [pmid: 8474062].
1429 Lafforgue P, Toussirot E, Bille F, et al. Astasia-abasia revealing a primary Sjogren’s syndrome. Clin Rheumatol. Jun. 1993;12(2):261-4. [pmid: 8358991].
1430 Lagana B, Picchianti Diamanti A, Ferlito C, et al. Imaging progression despite clinical remission in early rheumatoid arthritis patients after etanercept interruption. Int J Immunopathol Pharmacol. Apr–Jun. 2009;22(2):447-54. [pmid: 19505397].
1431 Lahiff C, Khiaron OB, Nolan N, et al. Pneumocystis carinii pneumonia in a patient on etanercept for psoriatic arthritis. Ir J Med Sci. Dec. 2007;176(4):309-11. [pmid: 17906888].
1432 Lahiri M, Teng GG. A case of refractory adult-onset Still’s disease treated with anakinra. Int J Rheum Dis. Aug. 2010;13(3):e36-41. [pmid: 20704609].
1433 Lahners WJ, Hardten DR, Lindstrom RL. Peripheral keratitis following laser in situ keratomileusis. J Refract Surg. Nov–Dec. 2003;19(6):671-5. [pmid: 14640433].
1434 Lai TY, Ngai JW, Chan WM, et al. Visual field and multifocal electroretinography and their correlations in patients on hydroxychloroquine therapy. Doc Ophthalmol. May. 2006;112(3):177-87. [pmid: 16804707].
1435 Laine L, Bombardier C, Hawkey CJ, et al. Stratifying the risk of NSAID-related upper gastrointestinal clinical events: results of a double-blind outcomes study in patients with rheumatoid arthritis. Gastroenterology. Oct. 2002;123(4):1006-12. [pmid: 12360461].
1436 Laine L, Connors LG, Reicin A, et al. Serious lower gastrointestinal clinical events with nonselective NSAID or coxib use. Gastroenterology. Feb. 2003;124(2):288-92. [pmid: 12557133].
1437 Laine M, Porola P, Udby L, et al. Low salivary dehydroepiandrosterone and androgen-regulated cysteine-rich secretory protein 3 levels in Sjogren’s syndrome. Arthritis Rheum. Aug. 2007;56(8):2575-84. [pmid: 17665393].
1438 Lainez B, Fernandez-Real JM, Romero X, et al. Identification and characterization of a novel spliced variant that encodes human soluble tumor necrosis factor receptor 2. Int Immunol. Jan. 2004;16(1):169-77. [pmid: 14688072].
1439 Lakatos P, Nagy Z, Kiss L, et al. Prevention of corticosteroid-induced osteoporosis by alfacalcidol. Z Rheumatol. 2000;59(Suppl 1):48-52. [pmid: 10769437].
1440 Lam A, Toma W, Schlesinger N. Mycobacterium marinum arthritis mimicking rheumatoid arthritis. J Rheumatol. Apr. 2006;33(4):817-9. [pmid: 16583484].
1441 Lamazza L, Guerra F, Pezza M, et al. The use of etanercept as a non-surgical treatment for temporomandibular joint psoriatric arthritis: a case report. Aust Dent J. Jun. 2009;54(2):161-5. [pmid: 19473159].
1442 Lan JL, Chou SJ, Chen DY, et al. A comparative study of etanercept plus methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis: a 12-week, double-blind, randomized, placebo-controlled study. J Formos Med Assoc. Aug. 2004;103(8):618-23. [pmid: 15340661].
1443 Landewe RB, Boers M, Verhoeven AC, et al. COBRA combination therapy in patients with early rheumatoid arthritis: long-term structural benefits of a brief intervention. Arthritis Rheum. Feb. 2002;46(2):347-56. [pmid: 11840436].
1444 Lane NE, Pressman AR, Star VL, et al. Rheumatoid arthritis and bone mineral density in elderly women. The Study of Osteoporotic Fractures Research Group. J Bone Miner Res. Feb. 1995;10(2):257-63. [pmid: 7754805].
1445 Lange U, Boss B, Teichmann J, et al. Bone mineral density and biochemical markers of bone metabolism in late onset rheumatoid arthritis and polymyalgia rheumatica--a prospective study on the influence of glucocorticoid therapy. Z Rheumatol. 2000;59(Suppl 2):II/137-41.
1446 Lange U, Teichmann J, Muller-Ladner U, et al. Increase in bone mineral density of patients with rheumatoid arthritis treated with anti-TNF-alpha antibody: a prospective open-label pilot study. Rheumatology (Oxford). Dec. 2005;44(12):1546-8. [pmid: 16263785].
1447 Langer HE, Missler-Karger B. Kineret: efficacy and safety in daily clinical practice: an interim analysis of the Kineret response assessment initiative (kreative) protocol. Int J Clin Pharmacol Res. 2003;23(4):119-28. [pmid: 15224501].
1448 Lassoued S, Sire S, Farny M, et al. Pulmonary aspergillosis in a patient with rheumatoid arthritis treated by etanercept. Clin Exp Rheumatol. Mar–Apr. 2004;22(2):267-8. [pmid: 15083902].
1449 Lassoued S, Zabraniecki L, Marin F, et al. Toxoplasmic chorioretinitis and antitumor necrosis factor treatment in rheumatoid arthritis. Semin Arthritis Rheum. Feb. 2007;36(4):262-3. [pmid: 17067660].
1450 Laurberg TB, Frystyk J, Ellingsen T, et al. Plasma adiponectin in patients with active, early, and chronic rheumatoid arthritis who are steroid- and disease-modifying antirheumatic drug-naive compared with patients with osteoarthritis and controls. J Rheumatol. Sep. 2009;36(9):1885-91. [pmid: 19684150].
1451 Lavie F, Miceli-Richard C, Ittah M, et al. Increase of B cell-activating factor of the TNF family (BAFF) after rituximab treatment: insights into a new regulating system of BAFF production. Ann Rheum Dis. May. 2007;66(5):700-3. [pmid: 17040963].
1452 Lazzerini PE, Acampa M, Hammoud M, et al. Arrhythmic risk during acute infusion of infliximab: a prospective, single-blind, placebo-controlled, crossover study in patients with chronic arthritis. J Rheumatol. Oct. 2008;35(10):1958-65. [pmid: 18709695].
1453 Le Loet X, Nordstrom D, Rodriguez M, et al. Effect of anakinra on functional status in patients with active rheumatoid arthritis receiving concomitant therapy with traditional disease modifying antirheumatic drugs: evidence from the OMEGA Trial. J Rheumatol. Aug. 2008;35(8):1538-44. [pmid: 18634163].
1454 Leandro MJ, Cambridge G, Ehrenstein MR, et al. Reconstitution of peripheral blood B cells after depletion with rituximab in patients with rheumatoid arthritis. Arthritis Rheum. Feb. 2006;54(2):613-20. [pmid: 16447239].
1455 Leandro MJ, Cooper N, Cambridge G, et al. Bone marrow B-lineage cells in patients with rheumatoid arthritis following rituximab therapy. Rheumatology (Oxford). Jan. 2007;46(1):29-36. [pmid: 16735454].
1456 Leandro MJ, Edwards JC, Cambridge G. Clinical outcome in 22 patients with rheumatoid arthritis treated with B lymphocyte depletion. Ann Rheum Dis. Oct. 2002;61(10):883-8. [pmid: 12228157].
1457 Lebwohl M, Blum R, Berkowitz E, et al. No evidence for increased risk of cutaneous squamous cell carcinoma in patients with rheumatoid arthritis receiving etanercept for up to 5 years. Arch Dermatol. Jul. 2005;141(7):861-4. [pmid: 16027301].
1458 Ledingham J, Deighton C. Update on the British Society for Rheumatology guidelines for prescribing TNFalpha blockers in adults with rheumatoid arthritis (update of previous guidelines of April 2001). Rheumatology (Oxford). Feb. 2005;44(2):157-63. [pmid: 15637039].
1459 Ledwich LJ, Clarke K. Screening and treatment of glucocorticoid-induced osteoporosis in rheumatoid arthritis patients in an urban multispecialty practice. J Clin Rheumatol. Mar. 2009;15(2):61-4. [pmid: 19265346].
1460 Lee CK, Lee EY, Cho YS, et al. Increased expression of glucocorticoid receptor beta messenger RNA in patients with ankylosing spondylitis. Korean J Intern Med. Jun. 2005;20(2):146-51. [pmid: 16134770].
1461 Lee EB, Shin KC, Lee YJ, et al. 188Re-tin-colloid as a new therapeutic agent for rheumatoid arthritis. Nucl Med Commun. Jun. 2003;24(6):689-96. [pmid: 12766606].
1462 Lee H, Kimko HC, Rogge M, et al. Population pharmacokinetic and pharmacodynamic modeling of etanercept using logistic regression analysis. Clin Pharmacol Ther. Apr. 2003;73(4):348-65. [pmid: 12709725].
1463 Lee HJ, Waller RD, Stebbings S, et al. The effects of an orally administered probiotic on sulfasalazine metabolism in individuals with rheumatoid arthritis: a preliminary study. Int J Rheum Dis. Feb. 1. 2010;13(1):48-54. [pmid: 20374384].
1464 Lee J, Noh JW, Hwang JW, et al. Extended dosing of etanercept 25 mg can be effective in patients with ankylosing spondylitis: a retrospective analysis. Clin Rheumatol. Oct. 2010;29(10):1149-54. [pmid: 20683738].
1465 Lee JH, Slifman NR, Gershon SK, et al. Life-threatening histoplasmosis complicating immunotherapy with tumor necrosis factor alpha antagonists infliximab and etanercept. Arthritis Rheum. Oct. 2002;46(10):2565-70. [pmid: 12384912].
1466 Lee SS, Park YW, Park JJ, et al. Combination treatment with leflunomide and methotrexate for patients with active rheumatoid arthritis. Scand J Rheumatol. Jan–Feb. 2009;38(1):11-4. [pmid: 19191187].
1467 Lee YC, Cui J, Costenbader KH, et al. Investigation of candidate polymorphisms and disease activity in rheumatoid arthritis patients on methotrexate. Rheumatology (Oxford). Jun. 2009;48(6):613-7. [pmid: 19193698].
1468 Lee YH, Choi SJ, Ji JD, et al. No association of polymorphisms of the CTLA-4 exon 1(+49) and promoter(−318) genes with rheumatoid arthritis in the Korean population. Scand J Rheumatol. 2002;31(5):266-70. [pmid: 12455815].
1469 Lee YH, Kim HJ, Rho YH, et al. Interleukin-1 receptor antagonist gene polymorphism and rheumatoid arthritis. Rheumatol Int. May. 2004;24(3):133-6. [pmid: 14872281].
1470 Lehman TJ. Clinical trials for the treatment of systemic onset juvenile rheumatoid arthritis-juvenile idiopathic arthritis. Curr Rheumatol Rep. Aug. 2000;2(4):313-5. [pmid: 11123076].
1471 Lehnen M, Franckson T, Knab J, et al. Successful infliximab therapy of psoriasis vulgaris and psoriatic arthritis in a patient with cirrhosis. Br J Dermatol. Jul. 2005;153(1):212-4. [pmid: 16029357].
1472 Lehnen M, Franckson T, Korber A, et al. Etanercept therapy of psoriatic arthritis in a patient with liver cirrhosis. Acta Derm Venereol. 2005;85(4):351-2. [pmid: 16191861].
1473 Leitch R, Walker SE, Hillard AE. The rheumatoid knee before and after arthrocentesis and prednisolone injection: evaluation by Gd-enhanced MRI. Clin Rheumatol. Jul. 1996;15(4):358-66. [pmid: 8853169].
1474 Lems WF, Gerrits MI, Jacobs JW, et al. Changes in (markers of) bone metabolism during high dose corticosteroid pulse treatment in patients with rheumatoid arthritis. Ann Rheum Dis. May. 1996;55(5):288-93. [pmid: 8660101].
1475 Lems WF, Jacobs JW, van den Brink HR, et al. Transient decrease in osteocalcin and markers of type 1 collagen turnover during high-dose corticosteroid pulse therapy in rheumatoid arthritis. Br J Rheumatol. Sep. 1993;32(9):787-9. [pmid: 8369888].
1476 Lems WF, Jahangier ZN, Jacobs JW, et al. Vertebral fractures in patients with rheumatoid arthritis treated with corticosteroids. Clin Exp Rheumatol. May–Jun. 1995;13(3):293-7. [pmid: 7554554].
1477 Lems WF, Jahangier ZN, Raymakers JA, et al. Methods to score vertebral deformities in patients with rheumatoid arthritis. Br J Rheumatol. Feb. 1997;36(2):220-4. [pmid: 9133934].
1478 Leonardou A, Giali S, Daoussis D, et al. Moraxella catarrhalis-induced septic arthritis of a prosthetic knee joint in a patient with rheumatoid arthritis treated with anakinra: comment on the article by Schiff et al. Arthritis Rheum. Apr. 2005;52(4):1337. author reply 8. [pmid: 15818660].
1479 Lequerre T, Gauthier-Jauneau AC, Bansard C, et al. Gene profiling in white blood cells predicts infliximab responsiveness in rheumatoid arthritis. Arthritis Res Ther. 2006;8(4):R105. [pmid: 16817978].
1480 Lequerre T, Jouen F, Brazier M, et al. Autoantibodies, metalloproteinases and bone markers in rheumatoid arthritis patients are unable to predict their responses to infliximab. Rheumatology (Oxford). Mar. 2007;46(3):446-53. [pmid: 16899502].
1481 Lequerre T, Quartier P, Rosellini D, et al. Interleukin-1 receptor antagonist (anakinra) treatment in patients with systemic-onset juvenile idiopathic arthritis or adult onset Still disease: preliminary experience in France. Ann Rheum Dis. Mar. 2008;67(3):302-8. [pmid: 17947302].
1482 Lesnik A, Bolivar J, Morel J, et al. On the AJR viewbox. Pseudotumoral colonic tuberculosis complicating rheumatoid arthritis treated with a tumor necrosis factor antagonist. AJR Am J Roentgenol. Jun. 2006;186(6):1799-800. [pmid: 16714678].
1483 Levalampi T, Korpela M, Vuolteenaho K, et al. Infliximab treatment in patients with rheumatoid arthritis and spondyloarthropathies in clinical practice: adverse events and other reasons for discontinuation of treatment. Scand J Rheumatol. Jan–Feb. 2008;37(1):6-12. [pmid: 18189188].
1484 Levy Y, Uziel Y, Zandman GG, et al. Intravenous immunoglobulins in peripheral neuropathy associated with vasculitis. Ann Rheum Dis. Dec. 2003;62(12):1221-3. [pmid: 14644864].
1485 Lewiecki EM. Denosumab for joints and bones. Curr Rheumatol Rep. Jul. 2009;11(3):196-201. [pmid: 19604464].
1486 Li Gobbi F, Benucci M, Del Rosso A. Pneumonitis caused by Legionella pneumoniae in a patient with rheumatoid arthritis treated with anti-TNF-alpha therapy (infliximab). J Clin Rheumatol. Apr. 2005;11(2):119-20. [pmid: 16357717].
1487 Li JY, Lai PH, Lam HC, et al. Hypertrophic cranial pachymeningitis and lymphocytic hypophysitis in Sjogren’s syndrome. Neurology. Jan. 15. 1999;52(2):420-3. [pmid: 9932974].
1488 Li P, Blum MA, Von Feldt J, et al. Adherence, discontinuation, and switching of biologic therapies in medicaid enrollees with rheumatoid arthritis. Value Health. 2010;13(6):805-12. [pmid: 21054657].
1489 Li St, Kaur PP, Berney SN. Effects of methotrexate use in a patient with rheumatoid arthritis and multiple sclerosis. J Clin Rheumatol. Aug. 2008;14(4):241-2. [pmid: 18766127].
1490 Li T, Gignac M, Wells G, et al. Decreased external home help use with improved clinical status in rheumatoid arthritis: an exploratory analysis of the Abatacept in Inadequate responders to Methotrexate (AIM) trial. Clin Ther. 2008;30(4):734-48. [pmid: 18498922].
1491 Lian EC, Tzakis AG, Andrews D. Response of factor V inhibitor to rituximab in a patient who received liver transplantation for primary biliary cirrhosis. Am J Hematol. Dec. 2004;77(4):363-5. [pmid: 15551286].
1492 Liberopoulos EN, Drosos AA, Elisaf MS. Exacerbation of tuberculosis enteritis after treatment with infliximab. Am J Med. Nov. 2002;113(7):615. [pmid: 12459414].
1493 Lieberman-Maran L, Orzano IM, Passero MA, et al. Bronchiectasis in rheumatoid arthritis: report of four cases and a review of the literature--implications for management with biologic response modifiers. Semin Arthritis Rheum. Jun. 2006;35(6):379-87. [pmid: 16765715].
1494 Lin YT, Tsai MJ, Wang LH, et al. Efficacy and safety of methotrexate therapy for juvenile rheumatoid arthritis. J Formos Med Assoc. Aug. 2000;99(8):623-9. [pmid: 10969505].
1495 Linardaki G, Katsarou O, Ioannidou P, et al. Effective etanercept treatment for psoriatic arthritis complicating concomitant human immunodeficiency virus and hepatitis C virus infection. J Rheumatol. Jun. 2007;34(6):1353-5. [pmid: 17552060].
1496 Lindberg J, af Klint E, Catrina AI, et al. Effect of infliximab on mRNA expression profiles in synovial tissue of rheumatoid arthritis patients. Arthritis Res Ther. 2006;8(6):R179. [pmid: 17134501].
1497 Lindberg J, Wijbrandts CA, van Baarsen LG, et al. The gene expression profile in the synovium as a predictor of the clinical response to infliximab treatment in rheumatoid arthritis. PLoS One. 2010;5(6):e11310. [pmid: 20593016].
1498 Linde L, Hetland ML, Ostergaard M. Drug survival and reasons for discontinuation of intramuscular methotrexate: a study of 212 consecutive patients switching from oral methotrexate. Scand J Rheumatol. Mar–Apr. 2006;35(2):102-6. [pmid: 16641042].
1499 Lindgren P, Geborek P, Kobelt G. Modeling the cost-effectiveness of treatment of rheumatoid arthritis with rituximab using registry data from Southern Sweden. Int J Technol Assess Health Care. Apr. 2009;25(2):181-9. [pmid: 19331709].
1500 Lindsay K, Fraser AD, Layton A, et al. Liver fibrosis in patients with psoriasis and psoriatic arthritis on long-term, high cumulative dose methotrexate therapy. Rheumatology (Oxford). May. 2009;48(5):569-72. [pmid: 19273538].
1501 Ling S, Lewanczuk RZ, Russell AS, et al. Influence of controlled rheumatoid arthritis on the action and disposition of verapamil: focus on infliximab. J Clin Pharmacol. Mar. 2009;49(3):301-11. [pmid: 19168802].
1502 Lingg GM, Soltesz I, Kessler S, et al. Insufficiency and stress fractures of the long bones occurring in patients with rheumatoid arthritis and other inflammatory diseases, with a contribution on the possibilities of computed tomography. Eur J Radiol. Dec. 1997;26(1):54-63. [pmid: 9481588].
1503 Liote H, Liote F, Lenique F, et al. Adult-onset Still’s disease revealed by a pleuropericarditis. Eur Respir J. Oct. 1990;3(9):1064-6. [pmid: 2289554].
1504 Liou LB. Serum and in vitro production of IL-1 receptor antagonist correlate with C-reactive protein levels in newly diagnosed, untreated lupus patients. Clin Exp Rheumatol. Sep–Oct. 2001;19(5):515-23. [pmid: 11579710].
1505 Lipsky PE, van der Heijde DM, St Clair EW, et al. Infliximab and methotrexate in the treatment of rheumatoid arthritis. Anti-Tumor Necrosis Factor Trial in Rheumatoid Arthritis with Concomitant Therapy Study Group. N Engl J Med. Nov. 30. 2000;343(22):1594-602. [pmid: 11096166].
1506 Lisbona MP, Maymo J, Perich J, et al. Rapid reduction in tenosynovitis of the wrist and fingers evaluated by MRI in patients with rheumatoid arthritis after treatment with etanercept. Ann Rheum Dis. 2010;69(6):1117-22. [pmid: 20448287].
1507 Lisbona MP, Maymo J, Perich J, et al. Etanercept reduces synovitis as measured by magnetic resonance imaging in patients with active rheumatoid arthritis after only 6 weeks. J Rheumatol. 2008;35(3):394-7. [pmid: 18203329].
1508 Listing J, Brandt J, Rudwaleit M, et al. Impact of anti-tumour necrosis factor alpha treatment on admissions to hospital and days of sick leave in patients with ankylosing spondylitis. Ann Rheum Dis. Dec. 2004;63(12):1670-2. [pmid: 15547093].
1509 Listing J, Strangfeld A, Kary S, et al. Infections in patients with rheumatoid arthritis treated with biologic agents. Arthritis Rheum. Nov. 2005;52(11):3403-12. [pmid: 16255017].
1510 Listing J, Strangfeld A, Kekow J, et al. Does tumor necrosis factor alpha inhibition promote or prevent heart failure in patients with rheumatoid arthritis?. Arthritis Rheum. 2008;58(3):667-77. [pmid: 18311816].
1511 Liu FC, Chiang SY, Chang DM, et al. Purtscher’s-like retinopathy as an initial presentation of adult-onset Still’s disease: a case report and review of the literature. Clin Rheumatol. Jul. 2007;26(7):1204-6. [pmid: 16900301].
1512 Liu MF, Yang CY, Li JS, et al. Increased expression of down-regulatory CTLA-4 molecule on T lymphocytes from rheumatoid synovial compartment. Scand J Immunol. Jul. 1999;50(1):68-72. [pmid: 10404054].
1513 Li-Yu J, Clayburne GM, Sieck MS, et al. Calcium apatite crystals in synovial fluid rice bodies. Ann Rheum Dis. May. 2002;61(5):387-90. [pmid: 11959760].
1514 Ljung L, Olsson T, Engstrand S, et al. Interleukin-1 receptor antagonist is associated with both lipid metabolism and inflammation in rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2007;25(4):617-20. [pmid: 17888220].
1515 Lloyd ME, Davitt S, Hall JR. Bilateral tibia and fibula fractures in a patient with rheumatoid arthritis. Clin Rheumatol. 2001;20(4):270-2. [pmid: 11529635].
1516 Lodder MC, de Jong Z, Kostense PJ, et al. Bone mineral density in patients with rheumatoid arthritis: relation between disease severity and low bone mineral density. Ann Rheum Dis. Dec. 2004;63(12):1576-80. [pmid: 15547081].
1517 Lodder MC, Haugeberg G, Lems WF, et al. Radiographic damage associated with low bone mineral density and vertebral deformities in rheumatoid arthritis: the Oslo-Truro-Amsterdam (OSTRA) collaborative study. Arthritis Rheum. Apr. 15. 2003;49(2):209-15. [pmid: 12687512].
1518 Lonardo A, Neri P, Mascia MT, et al. Hereditary hemochromatosis masquerading as rheumatoid arthritis. Ann Ital Med Int. Jan–Mar. 2001;16(1):46-9. [pmid: 11688350].
1519 Long JA, Husted JA, Gladman DD, et al. The relationship between patient satisfaction with health and clinical measures of function and disease status in patients with psoriatic arthritis. J Rheumatol. Apr. 2000;27(4):958-66. [pmid: 10782823].
1520 Loos T, Dekeyzer L, Struyf S, et al. TLR ligands and cytokines induce CXCR3 ligands in endothelial cells: enhanced CXCL9 in autoimmune arthritis. Lab Invest. Sep. 2006;86(9):902-16. [pmid: 16847431].
1521 Lopes RV, Furtado RN, Parmigiani L, et al. Accuracy of intra-articular injections in peripheral joints performed blindly in patients with rheumatoid arthritis. Rheumatology (Oxford). Dec. 2008;47(12):1792-4. [pmid: 18820311].
1522 Lopez-Hoyos M, Rodrigo E, Fernandez-Fresnedo G, et al. Lack of effect of rapamycin in anti-CCP antibody production in a rheumatoid arthritis kidney allograft recipient. Clin Exp Rheumatol. Jul–Aug. 2005;23(4):529-31. [pmid: 16095125].
1523 Lorenzi AR, Morgan TA, Anderson A, et al. Thymic function in juvenile idiopathic arthritis. Ann Rheum Dis. Jun. 2009;68(6):983-90. [pmid: 18628282].
1524 Lories RJ, Derese I, Luyten FP, et al. Activation of nuclear factor kappa B and mitogen activated protein kinases in psoriatic arthritis before and after etanercept treatment. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):96-102. [pmid: 18328153].
1525 Louis M, Rauch J, Armstrong M, et al. Induction of autoantibodies during prolonged treatment with infliximab. J Rheumatol. Dec. 2003;30(12):2557-62. [pmid: 14719194].
1526 Louthrenoo W, Kongtawelert P, Sivasomboon C, et al. Correlation between serum hyaluronan and disease activity and severity in Thai patients with rheumatoid arthritis. J Med Assoc Thai. May. 2001;84(5):622-7. [pmid: 11560209].
1527 Louthrenoo W, Zager EL, Freundlich B, et al. Intravenous corticosteroid therapy of cervical cord compression in rheumatoid arthritis. Clin Exp Rheumatol. Mar–Apr. 1992;10(2):173-5. [pmid: 1505111].
1528 Lozeron P, Denier C, Lacroix C, et al. Long-term course of demyelinating neuropathies occurring during tumor necrosis factor-alpha-blocker therapy. Arch Neurol. Apr. 2009;66(4):490-7. [pmid: 19364934].
1529 Lu LJ, Bao CD, Dai M, et al. Multicenter, randomized, double-blind, controlled trial of treatment of active rheumatoid arthritis with T-614 compared with methotrexate. Arthritis Rheum. Jul. 15. 2009;61(7):979-87. [pmid: 19565542].
1530 Lubbe S, Tikly M, van der Merwe L, et al. Interleukin-1 receptor antagonist gene polymorphisms are associated with disease severity in Black South Africans with rheumatoid arthritis. Joint Bone Spine. Jul. 2008;75(4):422-5. [pmid: 18468936].
1531 Lubrano E, D’Angelo S, Parsons WJ, et al. Effects of a combination treatment of an intensive rehabilitation program and etanercept in patients with ankylosing spondylitis: a pilot study. J Rheumatol. Oct. 2006;33(10):2029-34. [pmid: 17014018].
1532 Luessenhop CP, Higgins LD, Brause BD, et al. Multiple prosthetic infections after total joint arthroplasty. Risk factor analysis. J Arthroplasty. Oct. 1996;11(7):862-8. [pmid: 8934329].
1533 Lun SW, Wong CK, Tam LS, et al. Decreased ex vivo production of TNF-alpha and IL-8 by peripheral blood cells of patients with rheumatoid arthritis after infliximab therapy. Int Immunopharmacol. Dec. 15. 2007;7(13):1668-77. [pmid: 17996676].
1534 Lurati A, Pontikaki I, Teruzzi B, et al. A comparison of response criteria to evaluate therapeutic response in patients with juvenile idiopathic arthritis treated with methotrexate and/or anti-tumor necrosis factor alpha agents. Arthritis Rheum. May. 2006;54(5):1602-7. [pmid: 16646003].
1535 Luukkainen R, Hakala M, Sajanti E, et al. Predictive value of synovial fluid analysis in estimating the efficacy of intra-articular corticosteroid injections in patients with rheumatoid arthritis. Ann Rheum Dis. Jul. 1992;51(7):874-6. [pmid: 1632661].
1536 Luzi G, Lagana B, Salemi S, et al. Are glucocorticoids a consistent risk factor for infections in rheumatoid arthritis patients under treatment with methotrexate and etanercept?. Clin Ter. Mar–Apr. 2009;160(2):121-3. [pmid: 19452100].
1537 Lyman J, Serebro L. Efalizumab-induced inflammatory polyarthritis: what are the implications?. South Med J. Apr. 2010;103(4):357-60. [pmid: 20224509].
1538 Lyngberg KK, Harreby M, Bentzen H, et al. Elderly rheumatoid arthritis patients on steroid treatment tolerate physical training without an increase in disease activity. Arch Phys Med Rehabil. Nov. 1994;75(11):1189-95. [pmid: 7979927].
1539 Lyons JS, Severns ML. Detection of early hydroxychloroquine retinal toxicity enhanced by ring ratio analysis of multifocal electroretinography. Am J Ophthalmol. May. 2007;143(5):801-9. [pmid: 17336914].
1540 Ma Y, Lin BR, Lin B, et al. Pharmacokinetics of CTLA4Ig fusion protein in healthy volunteers and patients with rheumatoid arthritis. Acta Pharmacol Sin. Mar. 2009;30(3):364-71. [pmid: 19262560].
1541 Machado P, Santos A, Pereira C, et al. Increased prevalence of allergic sensitisation in rheumatoid arthritis patients treated with anti-TNFalpha. Joint Bone Spine. 2009;76(5):508-13. [pmid: 19467899].
1542 Macias I, Garcia-Perez S, Ruiz-Tudela M, et al. Modification of pro- and antiinflammatory cytokines and vascular-related molecules by tumor necrosis factor-a blockade in patients with rheumatoid arthritis. J Rheumatol. Nov. 2005;32(11):2102-8. [pmid: 16265686].
1543 Mackie GC, Pohlen JM. Methotrexate-induced pulmonary non-Hodgkin lymphoma. Clin Nucl Med. May. 2006;31(5):272-4. [pmid: 16622335].
1544 MacLean CH, Mojica WA, Morton SC, et al. Effects of omega-3 fatty acids on lipids and glycemic control in type II diabetes and the metabolic syndrome and on inflammatory bowel disease, rheumatoid arthritis, renal disease, systemic lupus erythematosus, and osteoporosis. Evid Rep Technol Assess (Summ). Mar. 2004;(89):1-4. [pmid: 15133890].
1545 Maenpaa HM, Soini I, Lehto MU, et al. Insufficiency fractures in patients with chronic inflammatory joint diseases. Clin Exp Rheumatol. Jan–Feb. 2002;20(1):77-9. [pmid: 11894837].
1546 Magaro M, Tricerri A, Piane D, et al. Generalized osteoporosis in non-steroid treated rheumatoid arthritis. Rheumatol Int. 1991;11(2):73-6. [pmid: 1947672].
1547 Magliocco MA, Gottlieb AB. Etanercept therapy for patients with psoriatic arthritis and concurrent hepatitis C virus infection: report of 3 cases. J Am Acad Dermatol. Oct. 2004;51(4):580-4. [pmid: 15389194].
1548 Magnusson SE, Engstrom M, Jacob U, et al. High synovial expression of the inhibitory FcgammaRIIb in rheumatoid arthritis. Arthritis Res Ther. 2007;9(3):R51. [pmid: 17521421].
1549 Maillard H, Ornetti P, Grimault L, et al. Severe pyogenic infections in patients taking infliximab: a regional cohort study. Joint Bone Spine. Jul. 2005;72(4):330-4. [pmid: 16038846].
1550 Maimon N, Brunton J, Chan AK, et al. Fatal pulmonary Mycobacterium xenopi in a patient with rheumatoid arthritis receiving etanercept. Thorax. Aug. 2007;62(8):739-40. [pmid: 17687101].
1551 Maini R, St Clair EW, Breedveld F, et al. Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a randomised phase III trial. ATTRACT Study Group. Lancet. Dec. 4. 1999;354(9194):1932-9. [pmid: 10622295].
1552 Maini RN, Breedveld FC, Kalden JR, et al. Therapeutic efficacy of multiple intravenous infusions of anti-tumor necrosis factor alpha monoclonal antibody combined with low-dose weekly methotrexate in rheumatoid arthritis. Arthritis Rheum. Sep. 1998;41(9):1552-63. [pmid: 9751087].
1553 Maini RN, Breedveld FC, Kalden JR, et al. Sustained improvement over two years in physical function, structural damage, and signs and symptoms among patients with rheumatoid arthritis treated with infliximab and methotrexate. Arthritis Rheum. Apr. 2004;50(4):1051-65. [pmid: 15077287].
1554 Maini RN, Taylor PC, Szechinski J, et al. Double-blind randomized controlled clinical trial of the interleukin-6 receptor antagonist, tocilizumab, in European patients with rheumatoid arthritis who had an incomplete response to methotrexate. Arthritis Rheum. 2006;54(9):2817-29. [pmid: 16947782].
1555 Mainman H, McClaren E, Heycock C, et al. When should we use parenteral methotrexate?. Clin Rheumatol. Oct. 2010;29(10):1093-8. [pmid: 20544244].
1556 Maki-Petaja KM, Hall FC, Booth AD, et al. Rheumatoid arthritis is associated with increased aortic pulse-wave velocity, which is reduced by anti-tumor necrosis factor-alpha therapy. Circulation. Sep. 12. 2006;114(11):1185-92. [pmid: 16952987].
1557 Maksymowych WP. Ankylosing spondylitis. Not just another pain in the back. Can Fam Physician. Feb. 2004;50:257-62. [pmid: 15000337].
1558 Maksymowych WP, Blackburn WD Jr, Tami JA, et al. A randomized, placebo controlled trial of an antisense oligodeoxynucleotide to intercellular adhesion molecule-1 in the treatment of severe rheumatoid arthritis. J Rheumatol. Mar. 2002;29(3):447-53. [pmid: 11908555].
1559 Maksymowych WP, Inman RD, Salonen D, et al. Spondyloarthritis Research Consortium of Canada magnetic resonance imaging index for assessment of spinal inflammation in ankylosing spondylitis. Arthritis Rheum. Aug. 15. 2005;53(4):502-9. [pmid: 16082639].
1560 Maksymowych WP, Inman RD, Salonen D, et al. Spondyloarthritis research Consortium of Canada magnetic resonance imaging index for assessment of sacroiliac joint inflammation in ankylosing spondylitis. Arthritis Rheum. Oct. 15. 2005;53(5):703-9. [pmid: 16208659].
1561 Maksymowych WP, Jhangri GS, Lambert RG, et al. Infliximab in ankylosing spondylitis: a prospective observational inception cohort analysis of efficacy and safety. J Rheumatol. May. 2002;29(5):959-65. [pmid: 12022358].
1562 Maksymowych WP, Poole AR, Hiebert L, et al. Etanercept exerts beneficial effects on articular cartilage biomarkers of degradation and turnover in patients with ankylosing spondylitis. J Rheumatol. Oct. 2005;32(10):1911-7. [pmid: 16206346].
1563 Maksymowych WP, Reeve JP, Reveille JD, et al. High-throughput single-nucleotide polymorphism analysis of the IL1RN locus in patients with ankylosing spondylitis by matrix-assisted laser desorption ionization-time-of-flight mass spectrometry. Arthritis Rheum. Jul. 2003;48(7):2011-8. [pmid: 12847695].
1564 Malaviya AN, Kapoor S, Garg S, et al. A new strategy of drug treatment in NSAID-unresponsive ankylosing spondylitis: combination of pamidronate and methylprednisolone monthly intravenous infusions on the background of a combination of disease modifying drugs sulfasalazine and methotrexate. J Assoc Physicians India. Mar. 2007;55:193-7. [pmid: 17598330].
1565 Malesci D, Tirri R, Buono R, et al. Leflunomide in psoriatic arthritis: a retrospective study of discontinuation rate in daily clinical practice compared with methotrexate. Clin Exp Rheumatol. Nov–Dec. 2007;25(6):881-4. [pmid: 18173924].
1566 Malfait AM, Verbruggen G, Almqvist KF, et al. Coculture of human articular chondrocytes with peripheral blood mononuclear cells as a model to study cytokine-mediated interactions between inflammatory cells and target cells in the rheumatoid joint. In Vitro Cell Dev Biol Anim. Nov. 1994;30A(11):747-52. [pmid: 7881628].
1567 Malipeddi AS, Rajendran R, Kallarackal G. Disseminated tuberculosis after anti-TNFalpha treatment. Lancet. Jan. 13. 2007;369(9556):162. [pmid: 17223480].
1568 Malysheva OA, Wahle M, Wagner U, et al. Low-dose prednisolone in rheumatoid arthritis: adverse effects of various disease modifying antirheumatic drugs. J Rheumatol. 2008;35(6):979-85. [pmid: 18412314].
1569 Manadan AM, Block JA, Sequeira W. Mycobacteria tuberculosis peritonitis associated with etanercept therapy. Clin Exp Rheumatol. Jul–Aug. 2003;21(4):526. [pmid: 12942713].
1570 Mancarella L, Bobbio-Pallavicini F, Ceccarelli F, et al. Good clinical response, remission, and predictors of remission in rheumatoid arthritis patients treated with tumor necrosis factor-alpha blockers: the GISEA study. J Rheumatol. Aug. 2007;34(8):1670-3. [pmid: 17611987].
1571 Manda G, Neagu M, Constantin C, et al. Patterns of peripheral cellular immune disorders in severe rheumatoid arthritis. Roum Arch Microbiol Immunol. Jan–Dec. 1. 2005:64-4. 17. 26.
1572 Mang R, Stege H, Ruzicka T, et al. Response of severe psoriasis to infliximab. Dermatology. 2002;204(2):156-7. [pmid: 11937748].
1573 Mangat P, Whittle S, Cleland L, et al. Digital vasculitis: a late complication of anti-tumour necrosis factor alpha therapy. Clin Rheumatol. Dec. 2008;27(12):1593-5. [pmid: 18827960].
1574 Manger B, Rech J, Schett G. Use of methotrexate in adult-onset Still’s disease. Clin Exp Rheumatol. Sep–Oct. 2010;28(5 Suppl 61):S168-71. [pmid: 21044454].
1575 Marchesoni A, Arreghini M, Panni B, et al. Life-threatening reversible bone marrow toxicity in a rheumatoid arthritis patient switched from leflunomide to infliximab. Rheumatology (Oxford). Jan. 2003;42(1):193-4. [pmid: 12509641].
1576 Marchesoni A, Ceravolo GP, Battafarano N, et al. Cyclosporin A in the treatment of adult onset Still’s disease. J Rheumatol. Aug. 1997;24(8):1582-7. [pmid: 9263155].
1577 Marchesoni A, Puttini PS, Gorla R, et al. Cyclosporine in addition to infliximab and methotrexate in refractory rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2005;23(6):916-7. [pmid: 16396721].
1578 Marchesoni A, Zaccara E, Gorla R, et al. TNF-alpha antagonist survival rate in a cohort of rheumatoid arthritis patients observed under conditions of standard clinical practice. Ann N Y Acad Sci. 2009:1173837-46.
1579 Mariette X, Ravaud P, Steinfeld S, et al. Inefficacy of infliximab in primary Sjogren’s syndrome: results of the randomized, controlled Trial of Remicade in Primary Sjogren’s Syndrome (TRIPSS). Arthritis Rheum. Apr. 2004;50(4):1270-6. [pmid: 15077311].
1580 Maripuri S, Grande JP, Osborn TG, et al. Renal involvement in primary Sjogren’s syndrome: a clinicopathologic study. Clin J Am Soc Nephrol. Sep. 2009;4(9):1423-31. [pmid: 19679669].
1581 Markatseli TE, Kaltsonoudis ES, Voulgari PV, et al. Induction of psoriatic skin lesions in a patient with rheumatoid arthritis treated with rituximab. Clin Exp Rheumatol. Nov–Dec. 2009;27(6):996-8. [pmid: 20149320].
1582 Marotte H, Arnaud B, Diasparra J, et al. Association between the level of circulating bioactive tumor necrosis factor alpha and the tumor necrosis factor alpha gene polymorphism at -308 in patients with rheumatoid arthritis treated with a tumor necrosis factor alpha inhibitor. Arthritis Rheum. May. 2008;58(5):1258-63. [pmid: 18438841].
1583 Marotte H, Gineyts E, Miossec P, et al. Effects of infliximab therapy on biological markers of synovium activity and cartilage breakdown in patients with rheumatoid arthritis. Ann Rheum Dis. Jul. 2009;68(7):1197-200. [pmid: 18713784].
1584 Marotte H, Maslinski W, Miossec P. Circulating tumour necrosis factor-alpha bioactivity in rheumatoid arthritis patients treated with infliximab: link to clinical response. Arthritis Res Ther. 2005;7(1):R149-55. [pmid: 15642135].
1585 Marotte H, Pallot-Prades B, Grange L, et al. The shared epitope is a marker of severity associated with selection for, but not with response to, infliximab in a large rheumatoid arthritis population. Ann Rheum Dis. Mar. 2006;65(3):342-7. [pmid: 16096333].
1586 Marsh P, Pflugfelder SC. Topical nonpreserved methylprednisolone therapy for keratoconjunctivitis sicca in Sjogren syndrome. Ophthalmology. Apr. 1999;106(4):811-6. [pmid: 10201607].
1587 Marshall NJ, Wilson G, Lapworth K, et al. Patients’ perceptions of treatment with anti-TNF therapy for rheumatoid arthritis: a qualitative study. Rheumatology (Oxford). Aug. 2004;43(8):1034-8. [pmid: 15150436].
1588 Marti L, Golmia R, Golmia AP, et al. Alterations in cytokine profile and dendritic cells subsets in peripheral blood of rheumatoid arthritis patients before and after biologic therapy. Ann N Y Acad Sci. Sep. 2009;1173:334-42. [pmid: 19758170].
1589 Martin JA, Jarrett P. Rheumatoid papules treated with dapsone. Clin Exp Dermatol. Jul. 2004;29(4):387-9. [pmid: 15245537].
1590 Martin JC, Munro R, Campbell MK, et al. Effects of disease and corticosteroids on appendicular bone mass in postmenopausal women with rheumatoid arthritis: comparison with axial measurements. Br J Rheumatol. Jan. 1997;36(1):43-9. [pmid: 9117173].
1591 Martin JM, Ricart JM, Alcacer J, et al. Adalimumab-induced lupus erythematosus. Lupus. Jul. 2008;17(7):676-8. [pmid: 18625641].
1592 Martin K, Bentaberry F, Dumoulin C, et al. Peripheral neuropathy associated with leflunomide: is there a risk patient profile?. Pharmacoepidemiol Drug Saf. Jan. 2007;16(1):74-8. [pmid: 16845649].
1593 Martin Martin LS, Migliore A, Todino V, et al. Infliximab therapy in patients with secondary Sjogren’s syndrome: functional evaluation. Clin Exp Rheumatol. May–Jun. 2003;21(3):412. [pmid: 12846076].
1594 Martin N, Innes JA, Lambert CM, et al. Hypersensitivity pneumonitis associated with leflunomide therapy. J Rheumatol. Sep. 2007;34(9):1934-7. [pmid: 17611977].
1595 Martinez A, Salido M, Bonilla G, et al. Association of the major histocompatibility complex with response to infliximab therapy in rheumatoid arthritis patients. Arthritis Rheum. Apr. 2004;50(4):1077-82. [pmid: 15077289].
1596 Martinez Lopez JA, Loza E, Carmona L. Systematic review on the safety of methotrexate in rheumatoid arthritis regarding the reproductive system (fertility, pregnancy, and breastfeeding). Clin Exp Rheumatol. 2009;27(4):678-84. [pmid: 19772806].
1597 Maruani A, Wierzbicka E, Machet MC, et al. Reversal of multifocal cutaneous lymphoproliferative disease associated with Epstein-Barr virus after withdrawal of methotrexate therapy for rheumatoid arthritis. J Am Acad Dermatol. Nov. 2007;57(5 Suppl):S69-71. [pmid: 17938029].
1598 Marzo-Ortega H, McGonagle D, Jarrett S, et al. Infliximab in combination with methotrexate in active ankylosing spondylitis: a clinical and imaging study. Ann Rheum Dis. Nov. 2005;64(11):1568-75. [pmid: 15829577].
1599 Marzo-Ortega H, McGonagle D, O’Connor P, et al. Efficacy of etanercept in the treatment of the entheseal pathology in resistant spondylarthropathy: a clinical and magnetic resonance imaging study. Arthritis Rheum. Sep. 2001;44(9):2112-7. [pmid: 11592375].
1600 Marzo-Ortega H, McGonagle D, Rhodes LA, et al. Efficacy of infliximab on MRI-determined bone oedema in psoriatic arthritis. Ann Rheum Dis. Jun. 2007;66(6):778-81. [pmid: 17185324].
1601 Marzo-Ortega H, Misbah S, Emery P. Minocycline induced autoimmune disease in rheumatoid arthritis: a missed diagnosis?. J Rheumatol. Feb. 2001;28(2):377-8. [pmid: 11246682].
1602 Masera RG, Carignola R, Sartori ML, et al. Circadian abnormalities of natural killer cell activity in rheumatoid arthritis. Ann N Y Acad Sci. Jun. 22. 1999;876:88-90. [pmid: 10415597].
1603 Masi AT, Aldag JC, Chatterton RT, et al. Adrenal androgen and glucocorticoid dissociation in premenopausal rheumatoid arthritis: a significant correlate or precursor to onset?. Z Rheumatol. 2000;59(Suppl 2):II/54-61.
1604 Masi AT, Chatterton RT, Aldag JC, et al. Perspectives on the relationship of adrenal steroids to rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2002;966:1-12. [pmid: 12114253].
1605 Masiero S, Boniolo A, Wassermann L, et al. Effects of an educational-behavioral joint protection program on people with moderate to severe rheumatoid arthritis: a randomized controlled trial. Clin Rheumatol. Dec. 2007;26(12):2043-50. [pmid: 17404783].
1606 Massarotti EM. Medical aspects of rheumatoid arthritis. Diagnosis and treatment. Hand Clin. Aug. 1996;12(3):463-75. [pmid: 8842713].
1607 Mastroianni A, Minutilli E, Mussi A, et al. Cytokine profiles during infliximab monotherapy in psoriatic arthritis. Br J Dermatol. Sep. 2005;153(3):531-6. [pmid: 16120138].
1608 Masuda K, Mochida Y, Fujii J, et al. Primary cervical epidural malignant lymphoma with rheumatoid arthritis: a case report. Mod Rheumatol. 2007;17(3):239-42. [pmid: 17564781].
1609 Mateo L, Nolla JM, Bonnin MR, et al. Sex hormone status and bone mineral density in men with rheumatoid arthritis. J Rheumatol. Aug. 1995;22(8):1455-60. [pmid: 7473465].
1610 Mathias SD, Colwell HH, Miller DP, et al. Health-related quality of life and functional status of patients with rheumatoid arthritis randomly assigned to receive etanercept or placebo. Clin Ther. Jan. 2000;22(1):128-39. [pmid: 10688396].
1611 Mathieu S, Vellin JF, Poujol D, et al. Cat scratch disease during etanercept therapy. Joint Bone Spine. Mar. 2007;74(2):184-6. [pmid: 17337229].
1612 Matsuda M, Morita H, Ikeda S. Long-term follow-up of systemic reactive AA amyloidosis secondary to rheumatoid arthritis: successful treatment with intermediate-dose corticosteroid. Intern Med. May. 2002;41(5):403-7. [pmid: 12058893].
1613 Matsui T, Komiya A, Shimada K, et al. Neutrophil CD64 as a marker of infection in patients treated with tocilizumab. Mod Rheumatol. 2009;19(6):696-7. [pmid: 19728012].
1614 Matsui T, Kuga Y, Kaneko A, et al. Disease Activity Score 28 (DAS28) using C-reactive protein underestimates disease activity and overestimates EULAR response criteria compared with DAS28 using erythrocyte sedimentation rate in a large observational cohort of rheumatoid arthritis patients in Japan. Ann Rheum Dis. Sep. 2007;66(9):1221-6. [pmid: 17369281].
1615 Matsui T, Ohsumi K, Ozawa N, et al. CD64 on neutrophils is a sensitive and specific marker for detection of infection in patients with rheumatoid arthritis. J Rheumatol. Dec. 2006;33(12):2416-24. [pmid: 17080517].
1616 Matsumoto K, Hukuda S, Nishioka J, et al. Rupture of the Achilles tendon in rheumatoid arthritis with histologic evidence of enthesitis. A case report. Clin Orthop Relat Res. Jul. 1992;(280):235-40. [pmid: 1611751].
1617 Matsumoto T, Kaneko T, Seto M, et al. The membrane proteinase 3 expression on neutrophils was downregulated after treatment with infliximab in patients with rheumatoid arthritis. Clin Appl Thromb Hemost. Apr. 2008;14(2):186-92. [pmid: 18372277].
1618 Matsuo T, Koyama T, Morimoto N, et al. Retinal vasculitis as a complication of rheumatoid arthritis. Ophthalmologica. 1990;201(4):196-200. [pmid: 2077456].
1619 Matsushita I, Uzuki M, Matsuno H, et al. Rheumatoid nodulosis during methotrexate therapy in a patient with rheumatoid arthritis. Mod Rheumatol. 2006;16(6):401-3. [pmid: 17165004].
1620 Mattey DL, Brownfield A, Dawes PT. Relationship between pack-year history of smoking and response to tumor necrosis factor antagonists in patients with rheumatoid arthritis. J Rheumatol. 2009;36(6):1180-7. [pmid: 19447930].
1621 Matthews C, Fitzgerald O. Seropositive erosive rheumatoid arthritis (RA). Rheumatology (Oxford). Sep. 2006;45(9):1100. [pmid: 16943373].
1622 Maugars Y, Mathis C, Berthelot JM, et al. Assessment of the efficacy of sacroiliac corticosteroid injections in spondylarthropathies: a double-blind study. Br J Rheumatol. Aug. 1996;35(8):767-70. [pmid: 8761190].
1623 Mavragani CP, La DT, Stohl W, et al. Association of the response to tumor necrosis factor antagonists with plasma type I interferon activity and interferon-beta/alpha ratios in rheumatoid arthritis patients: a post hoc analysis of a predominantly Hispanic cohort. Arthritis Rheum. Feb. 2010;62(2):392-401. [pmid: 20112385].
1624 Mavropoulos JC, Cuchacovich M, Llanos C, et al. Anti-tumor necrosis factor-alpha therapy augments dipeptidyl peptidase IV activity and decreases autoantibodies to GRP78/BIP and phosphoglucose isomerase in patients with rheumatoid arthritis. J Rheumatol. Nov. 2005;32(11):2116-24. [pmid: 16265688].
1625 Maxwell JR, Potter C, Hyrich KL, et al. Association of the tumour necrosis factor-308 variant with differential response to anti-TNF agents in the treatment of rheumatoid arthritis. Hum Mol Genet. Nov. 15. 2008;17(22):3532-8. [pmid: 18713756].
1626 Mayer DF, Matteson EL. Testicular involvement in rheumatoid vasculitis. Clin Exp Rheumatol. 2004;22(6 Suppl 36):S62-4. [pmid: 15675137].
1627 Mayer Y, Balbir-Gurman A, Machtei EE. Anti-tumor necrosis factor-alpha therapy and periodontal parameters in patients with rheumatoid arthritis. J Periodontol. Sep. 2009;80(9):1414-20. [pmid: 19722791].
1628 Mazokopakis E, Katsogridakis K, Koutsopoulos A, et al. Fatal methotrexate-induced pneumonitis in a psoriatic patient. Mil Med. Apr. 2004;169(4):298-300. [pmid: 15132233].
1629 Mazzotta A, Esposito M, Costanzo A, et al. Efficacy and safety of etanercept in psoriasis after switching from other treatments: an observational study. Am J Clin Dermatol. 2009;10(5):319-24. [pmid: 19658444].
1630 Mazzotta A, Esposito M, Schipani C, et al. Long-term experience with etanercept in psoriatic arthritis patients: a 3-year observational study. J Dermatolog Treat. 2009;20(6):354-8. [pmid: 19954392].
1631 McCain ME, Quinet RJ, Davis WE. Etanercept and infliximab associated with cutaneous vasculitis. Rheumatology (Oxford). Jan. 2002;41(1):116-7. [pmid: 11792895].
1632 McCarthy CJ, Regan M, Coughlan RJ. Treatment of rheumatoid hand synovitis with a regional block technique. Ir J Med Sci. Apr. 1993;162(4):143-4. [pmid: 8514483].
1633 McCombe PA, Klestov AC, Tannenberg AE, et al. Sensorimotor peripheral neuropathy in rheumatoid arthritis. Clin Exp Neurol. 1991;28:146-53. [pmid: 1668274].
1634 McDonald JR, Zeringue AL, Caplan L, et al. Herpes zoster risk factors in a national cohort of veterans with rheumatoid arthritis. Clin Infect Dis. 2009;48(10):1364-71. [pmid: 19368499].
1635 McGarry F, Neilly J, Anderson N, et al. A polymorphism within the interleukin 1 receptor antagonist (IL-1Ra) gene is associated with ankylosing spondylitis. Rheumatology (Oxford). Dec. 2001;40(12):1359-64. [pmid: 11752505].
1636 McGonagle D, Tan AL, Madden J, et al. Rituximab use in everyday clinical practice as a first-line biologic therapy for the treatment of DMARD-resistant rheumatoid arthritis. Rheumatology (Oxford). Jun. 2008;47(6):865-7. [pmid: 18390581].
1637 McMinn JR Jr, Cohen S, Moore J, et al. Complete recovery from refractory immune thrombocytopenic purpura in three patients treated with etanercept. Am J Hematol. Jun. 2003;73(2):135-40. [pmid: 12749017].
1638 Mease PJ, Cohen S, Gaylis NB, et al. Efficacy and safety of retreatment in patients with rheumatoid arthritis with previous inadequate response to tumor necrosis factor inhibitors: results from the SUNRISE trial. J Rheumatol. 2010;37(5):917-27. [pmid: 20194448].
1639 Mease PJ, Gladman DD, Ritchlin CT, et al. Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. 2005;52(10):3279-89. [pmid: 16200601].
1640 Mease PJ, Goffe BS, Metz J, et al. Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet. Jul. 29. 2000;356(9227):385-90. [pmid: 10972371].
1641 Mease PJ, Kivitz AJ, Burch FX, et al. Continued inhibition of radiographic progression in patients with psoriatic arthritis following 2 years of treatment with etanercept. J Rheumatol. 2006;33(4):712-21. [pmid: 16463435].
1642 Mease PJ, Kivitz AJ, Burch FX, et al. Etanercept treatment of psoriatic arthritis: safety, efficacy, and effect on disease progression. Arthritis Rheum. 2004;50(7):2264-72. [pmid: 15248226].
1643 Mease PJ, Ory P, Sharp JT, et al. Adalimumab for long-term treatment of psoriatic arthritis: 2-year data from the Adalimumab Effectiveness in Psoriatic Arthritis Trial (ADEPT). Ann Rheum Dis. May. 2009;68(5):702-9. [pmid: 18684743].
1644 Mease PJ, Reich K. Alefacept with methotrexate for treatment of psoriatic arthritis: open-label extension of a randomized, double-blind, placebo-controlled study. J Am Acad Dermatol. Mar. 2009;60(3):402-11. [pmid: 19028407].
1645 Mease PJ, Revicki DA, Szechinski J, et al. Improved health-related quality of life for patients with active rheumatoid arthritis receiving rituximab: Results of the Dose-Ranging Assessment: International Clinical Evaluation of Rituximab in Rheumatoid Arthritis (DANCER) Trial. J Rheumatol. 2008;35(1):20-30. [pmid: 18050385].
1646 Mease PJ, Ritchlin CT, Martin RW, et al. Pneumococcal vaccine response in psoriatic arthritis patients during treatment with etanercept. J Rheumatol. Jul. 2004;31(7):1356-61. [pmid: 15229957].
1647 Mease PJ, Woolley JM, Singh A, et al. Patient-reported outcomes in a randomized trial of etanercept in psoriatic arthritis. J Rheumatol. 2010;37(6):1221-7. [pmid: 20395648].
1648 Mehta BM, Hashkes PJ, Avery R, et al. A 21-year-old man with Still’s disease with fever, rash, and pancytopenia. Arthritis Care Res (Hoboken). Apr. 2010;62(4):575-9. [pmid: 20391515].
1649 Meijer JM, Meiners PM, Vissink A, et al. Effectiveness of rituximab treatment in primary Sjogren’s syndrome: a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Apr. 2010;62(4):960-8. [pmid: 20131246].
1650 Meirer R, Muller-Gerbl M, Huemer GM, et al. Quantitative assessment of periarticular osteopenia in patients with early rheumatoid arthritis: a preliminary report. Scand J Rheumatol. 2004;33(5):307-11. [pmid: 15513678].
1651 Melikoglu MA, Melikoglu M, Gurbuz U, et al. Hydroxychloroquine-induced hyperpigmentation: a case report. J Clin Pharm Ther. Dec. 2008;33(6):699-701. [pmid: 19138249].
1652 Menard O, Petit N, Gillet P, et al. Association of histologically proven rheumatoid arthritis with pulmonary sarcoidosis. Eur Respir J. Mar. 1995;8(3):472-3. [pmid: 7789498].
1653 Menninger H, Herborn G, Sander O, et al. A 36 month comparative trial of methotrexate and gold sodium thiomalate in the treatment of early active and erosive rheumatoid arthritis. Br J Rheumatol. Oct. 1998;37(10):1060-8. [pmid: 9825744].
1654 Mertens M, Singh JA. Anakinra for rheumatoid arthritis. Cochrane Database Syst Rev. 2009;(1):CD005121. [pmid: 19160248].
1655 Mertz LE, Blair JE. Coccidioidomycosis in rheumatology patients: incidence and potential risk factors. Ann N Y Acad Sci. 2007:1111343-57.
1656 Messina OD, Barreira JC, Zanchetta JR, et al. Effect of low doses of deflazacort vs prednisone on bone mineral content in premenopausal rheumatoid arthritis. J Rheumatol. Oct. 1992;19(10):1520-6. [pmid: 1464862].
1657 Meusch U, Rossol M, Baerwald C, et al. Outside-to-inside signaling through transmembrane tumor necrosis factor reverses pathologic interleukin-1beta production and deficient apoptosis of rheumatoid arthritis monocytes. Arthritis Rheum. Sep. 2009;60(9):2612-21. [pmid: 19714631].
1658 Miceli-Richard C, Comets E, Verstuyft C, et al. A single tumour necrosis factor haplotype influences the response to adalimumab in rheumatoid arthritis. Ann Rheum Dis. Apr. 2008;67(4):478-84. [pmid: 17673491].
1659 Michaelsson G, Kajermo U, Michaelsson A, et al. Infliximab can precipitate as well as worsen palmoplantar pustulosis: possible linkage to the expression of tumour necrosis factor-alpha in the normal palmar eccrine sweat duct?. Br J Dermatol. Dec. 2005;153(6):1243-4. [pmid: 16307676].
1660 Michaud K, Wolfe F. The association of rheumatoid arthritis and its treatment with sinus disease. J Rheumatol. 2006;33(12):2412-5. [pmid: 17143978].
1661 Michel BA, Bloch DA, Fries JF. Predictors of fractures in early rheumatoid arthritis. J Rheumatol. Jun. 1991;18(6):804-8. [pmid: 1895260].
1662 Michel BA, Bloch DA, Wolfe F, et al. Fractures in rheumatoid arthritis: an evaluation of associated risk factors. J Rheumatol. Oct. 1993;20(10):1666-9. [pmid: 8295176].
1663 Michel M, Duvoux C, Hezode C, et al. Fulminant hepatitis after infliximab in a patient with hepatitis B virus treated for an adult onset still’s disease. J Rheumatol. Jul. 2003;30(7):1624-5. [pmid: 12858469].
1664 Michel M, Habibi A, Godeau B, et al. Characteristics and outcome of connective tissue diseases in patients with sickle-cell disease: report of 30 cases. Semin Arthritis Rheum. Dec. 2008;38(3):228-40. [pmid: 18177923].
1665 Mielants H, Goemaere S, De Vos M, et al. Intestinal mucosal permeability in inflammatory rheumatic diseases. I. Role of antiinflammatory drugs. J Rheumatol. Mar. 1991;18(3):389-93. [pmid: 1906938].
1666 Mielke F, Schweigert M. Safe adalimumab therapy for rheumatoid arthritis in a patient with pre-existing multiple myeloma. Nat Clin Pract Rheumatol. Apr. 2008;4(4):218-21. [pmid: 18301411].
1667 Migliore A, Bizzi E, Massafra U, et al. Can Cyclosporine-A associated to methotrexate maintain remission induced by anti-TNF agents in rheumatoid arthritis patients? (Cynar pilot study). Int J Immunopathol Pharmacol. Jul–Sep. 2010;23(3):783-90. [pmid: 20943048].
1668 Migliore A, Massafra U, Capuano A, et al. Combined use of teriparatide and TNFalpha blockade: safety. Aging Clin Exp Res. Jun. 2007;19(3 Suppl):18-20. [pmid: 18180602].
1669 Migliore A, Signore A, Capuano A, et al. Relevance of 99mTc-HYNIC-tir-octreotide scintigraphy in a patient affected by sarcoidosis with lung and joints involvement and secondary Sjogren’s syndrome treated with infliximab: case report. Eur Rev Med Pharmacol Sci. Mar–Apr. 2008;12(2):127-30. [pmid: 18575164].
1670 Mikashima Y, Kawamura K, Miyawaki M, et al. Neglected spontaneous rupture of the Achilles tendon in elderly patients with rheumatoid arthritis. J Clin Rheumatol. Aug. 2010;16(5):221-4. [pmid: 20661068].
1671 Mikhail M, Weinberg JM, Smith BL. Successful treatment with etanercept of von Zumbusch pustular psoriasis in a patient with human immunodeficiency virus. Arch Dermatol. Apr. 2008;144(4):453-6. [pmid: 18427038].
1672 Miller KL, Sawitzke AD, Doane J. Abatacept and serious respiratory infections in patients with previous lung disease. Clin Rheumatol. Dec. 2008;27(12):1569-71. [pmid: 18665325].
1673 Miller-Blair DJ, Robbins DL. Rheumatoid arthritis: new science, new treatment. Geriatrics. Jun. 1993;48(6):28-31. 5. 8. [pmid: 8388844].
1674 Mima T, Nishimoto N. Clinical value of blocking IL-6 receptor. Curr Opin Rheumatol. May. 2009;21(3):224-30. [pmid: 19365268].
1675 Min JK, Han NI, Kim JA, et al. A case of cholestatic autoimmune hepatitis and acute liver failure: an unusual hepatic manifestation of mixed connective tissue disease and Sjogren’s syndrome. J Korean Med Sci. Aug. 2001;16(4):512-5. [pmid: 11511800].
1676 Mirone L, Altomonte L, D’Agostino P, et al. A study of serum androgen and cortisol levels in female patients with rheumatoid arthritis. Correlation with disease activity. Clin Rheumatol. Jan. 1996;15(1):15-9. [pmid: 8929769].
1677 Misery L, Perrot JL, Gentil-Perret A, et al. Dermatological complications of etanercept therapy for rheumatoid arthritis. Br J Dermatol. Feb. 2002;146(2):334-5. [pmid: 11903255].
1678 Mishra KK, Pandey HP. A study on physiological changes in essential hypertension and rheumatoid arthritis with reference to the levels of cortisol, blood glucose, triglycerides and cholesterol. Indian J Physiol Pharmacol. Jan. 1995;39(1):68-70. [pmid: 7705874].
1679 Mishra KK, Pandey HP. A study on physiological changes in certain psychosomatic disorders with reference to cortisol, blood glucose and lipid profile. Indian J Physiol Pharmacol. Apr. 1996;40(2):151-4. [pmid: 9062810].
1680 Mitamura M, Tada Y, Koarada S, et al. Cyclosporin A treatment for Japanese patients with severe adult-onset Still’s disease. Mod Rheumatol. 2009;19(1):57-63. [pmid: 18839270].
1681 Mittendorf T, Dietz B, Sterz R, et al. Personal and economic burden of late-stage rheumatoid arthritis among patients treated with adalimumab: an evaluation from a patient’s perspective. Rheumatology (Oxford). Feb. 2008;47(2):188-93. [pmid: 18174232].
1682 Mittendorf T, Dietz B, Sterz R, et al. Improvement and longterm maintenance of quality of life during treatment with adalimumab in severe rheumatoid arthritis. J Rheumatol. Dec. 2007;34(12):2343-50. [pmid: 17918788].
1683 Miyagawa Y, Nagata N, Nakanishi Y, et al. A case of steroid-responsive organizing pneumonia in a patient with rheumatoid arthritis showing migratory infiltration and normal glucose levels in pleural effusions. Br J Rheumatol. Sep. 1993;32(9):829-31. [pmid: 8369898].
1684 Miyamoto S, Kageyama Y, Ozeki T, et al. Bone mineral density after total joint arthroplasty of lower extremities in rheumatoid arthritis patients. Arch Orthop Trauma Surg. 2001;121(3):127-30. [pmid: 11262775].
1685 Miyanishi K, Hara T, Hamada T, et al. Co-occurrence of subchondral insufficiency fracture of the femoral head and contralateral femoral neck fracture in a rheumatic patient receiving steroid treatment. Mod Rheumatol. 2008;18(6):619-22. [pmid: 18584289].
1686 Miyasaka N. Clinical investigation in highly disease-affected rheumatoid arthritis patients in Japan with adalimumab applying standard and general evaluation: the CHANGE study. Mod Rheumatol. 2008;18(3):252-62. [pmid: 18330677].
1687 Miyazaki T, Fujimaki K, Shirasugi Y, et al. Remission of lymphoma after withdrawal of methotrexate in rheumatoid arthritis: relationship with type of latent Epstein-Barr virus infection. Am J Hematol. Dec. 2007;82(12):1106-9. [pmid: 17654684].
1688 Moccia F, Mazzarello GP, Morra L. Effect of corticosteroid treatment on hemopoiesis in vivo and in vitro in a patient with Felty’s syndrome. Biomed Pharmacother. 1991;45(9):403-8. [pmid: 1786345].
1689 Mochizuki T, Momohara S, Ikari K, et al. Spontaneous multiple insufficiency fractures after pelvic abscess and sepsis in a rheumatoid arthritis patient treated with high-load corticosteroid therapy: a case report. Clin Rheumatol. Nov. 2007;26(11):1925-8. [pmid: 17235652].
1690 Mochizuki T, Momohara S, Ikari K, et al. The serum concentration of infliximab in cases of autologous blood donation for patients with rheumatoid arthritis. Mod Rheumatol. 2007;17(1):24-7. [pmid: 17278018].
1691 Mody GM, Meyers OL. Therapeutic requirements in rheumatoid arthritis. S Afr Med J. May. 19. 1990;77(10):497-9. [pmid: 2343346].
1692 Moen K, Kvalvik AG, Hellem S, et al. The long-term effect of anti TNF-alpha treatment on temporomandibular joints, oral mucosa, and salivary flow in patients with active rheumatoid arthritis: a pilot study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Oct. 2005;100(4):433-40. [pmid: 16182164].
1693 Mogosan C, Stoica V, Mihai C, et al. Rheumatoid arthritis: travelling biological era a Romanian X-ray population. J Med Life. Oct–Dec. 2009;2(4):414-25. [pmid: 20108756].
1694 Mohammad A, Kilcoyne A, Bond U, et al. Methotrexate information booklet study 2008. Clin Exp Rheumatol. Jul–Aug. 2009;27(4):649-50. [pmid: 19772799].
1695 Mohan AK, Cote TR, Block JA, et al. Tuberculosis following the use of etanercept, a tumor necrosis factor inhibitor. Clin Infect Dis. Aug. 1. 2004;39(3):295-9. [pmid: 15306993].
1696 Mohan N, Edwards ET, Cupps TR, et al. Demyelination occurring during anti-tumor necrosis factor alpha therapy for inflammatory arthritides. Arthritis Rheum. Dec. 2001;44(12):2862-9. [pmid: 11762947].
1697 Mohyuddin T, Elyan M, Kushner I. Pericarditis: a rare complication of methotrexate therapy. Clin Rheumatol. Dec. 2007;26(12):2157-8. [pmid: 17520171].
1698 Mok CC, Lau CS, Wong RW. Clinical characteristics, treatment, and outcome of adult onset Still’s disease in southern Chinese. J Rheumatol. Dec. 1998;25(12):2345-51. [pmid: 9858428].
1699 Mok MY, Lo Y, Leung PY, et al. Pregnancy outcome in patients with adult onset Still’s disease. J Rheumatol. Nov. 2004;31(11):2307-9. [pmid: 15517651].
1700 Mok MY, Wong SY, Chan TM, et al. Necrotizing fasciitis in rheumatic diseases. Lupus. 2006;15(6):380-3. [pmid: 16830885].
1701 Molenaar ET, Bultink IE, Dijkmans BA, et al. Development of fatal tuberculosis in a patient with rheumatoid arthritis after three years of treatment with infliximab: comment on the article by Wolfe et al. Arthritis Rheum. Apr. 2005;52(4):1334-6. [pmid: 15818690].
1702 Moller B, Kukoc-Zivojnov N, Koyama N, et al. Prednisolone induces interleukin-18 expression in mononuclear blood and myeloid progenitor cells. Inflamm Res. Sep. 2002;51(9):457-63. [pmid: 12365719].
1703 Molloy E, Ramakrishnan S, Murphy E, et al. Morbidity and mortality in rheumatoid patients during treatment with adalimumab and infliximab. Rheumatology (Oxford). Apr. 2004;43(4):522-3. [pmid: 15024136].
1704 Momeni M, Mehta AP, Katz JD. Anti-tumor necrosis factor therapy is tolerated in an individual with homozygous complement C2 deficiency. J Clin Rheumatol. Jun. 2005;11(3):180-2. [pmid: 16357744].
1705 Montagna GL, Malesci D, Buono R, et al. Asthenoazoospermia in patients receiving anti-tumour necrosis factor {alpha} agents. Ann Rheum Dis. Nov. 2005;64(11):1667. [pmid: 16227427].
1706 Montecucco C, Caporali R, Caprotti P, et al. Sex hormones and bone metabolism in postmenopausal rheumatoid arthritis treated with two different glucocorticoids. J Rheumatol. Dec. 1992;19(12):1895-900. [pmid: 1294736].
1707 Montero JA, Ruiz-Moreno JM, Rodriguez AE, et al. Endogenous endophthalmitis by Propionibacterium acnes associated with leflunomide and adalimumab therapy. Eur J Ophthalmol. Mar–Apr. 2006;16(2):343-5. [pmid: 16703558].
1708 Moore A, Phillips C, Hunsche E, et al. Economic evaluation of etoricoxib versus non-selective NSAIDs in the treatment of osteoarthritis and rheumatoid arthritis patients in the UK. Pharmacoeconomics. 2004;22(10):643-60. [pmid: 15244490].
1709 Moore J, Ma D, Will R, et al. A phase II study of Rituximab in rheumatoid arthritis patients with recurrent disease following haematopoietic stem cell transplantation. Bone Marrow Transplant. Aug. 2004;34(3):241-7. [pmid: 15235579].
1710 Mor A, Bingham C 3rd, Barisoni L, et al. Proliferative lupus nephritis and leukocytoclastic vasculitis during treatment with etanercept. J Rheumatol. Apr. 2005;32(4):740-3. [pmid: 15801034].
1711 Mor A, Bingham CO 3rd, Kishimoto M, et al. Methotrexate combined with isoniazid treatment for latent tuberculosis is well tolerated in patients with rheumatoid arthritis: experience from an urban arthritis clinic. Ann Rheum Dis. Apr. 2008;67(4):462-5. [pmid: 17711866].
1712 Morand EF, Jefferiss CM, Dixey J, et al. Impaired glucocorticoid induction of mononuclear leukocyte lipocortin-1 in rheumatoid arthritis. Arthritis Rheum. Feb. 1994;37(2):207-11. [pmid: 8129776].
1713 Moreland LW. Inhibitors of tumor necrosis factor: new treatment options for rheumatoid arthritis. Cleve Clin J Med. Jun. 1999;66(6):367-74. [pmid: 10375846].
1714 Moreland LW, Alten R, Van den Bosch F, et al. Costimulatory blockade in patients with rheumatoid arthritis: a pilot, dose-finding, double-blind, placebo-controlled clinical trial evaluating CTLA-4Ig and LEA29Y eighty-five days after the first infusion. Arthritis Rheum. Jun. 2002;46(6):1470-9. [pmid: 12115176].
1715 Moreland LW, Bucy RP, Weinblatt ME, et al. Immune function in patients with rheumatoid arthritis treated with etanercept. Clin Immunol. Apr. 2002;103(1):13-21. [pmid: 11987981].
1716 Moreland LW, Cohen SB, Baumgartner SW, et al. Long-term safety and efficacy of etanercept in patients with rheumatoid arthritis. J Rheumatol. Jun. 2001;28(6):1238-44. [pmid: 11409115].
1717 Moreland LW, Schiff MH, Baumgartner SW, et al. Etanercept therapy in rheumatoid arthritis. A randomized, controlled trial. Ann Intern Med. Mar. 16. 1999;130(6):478-86. [pmid: 10075615].
1718 Morelli S, Sgreccia A, Bernardo ML, et al. Primary aspergillosis of the larynx in a patient with Felty’s syndrome. Clin Exp Rheumatol. Jul–Aug. 2000;18(4):523-4. [pmid: 10949734].
1719 Mori K, Iijima M, Koike H, et al. The wide spectrum of clinical manifestations in Sjogren’s syndrome-associated neuropathy. Brain. Nov. 2005;128(Pt 11):2518-34. [pmid: 16049042].
1720 Mori S. A relationship between pharmacokinetics (PK) and the efficacy of infliximab for patients with rheumatoid arthritis: characterization of infliximab-resistant cases and PK-based modified therapy. Mod Rheumatol. 2007;17(2):83-91. [pmid: 17437161].
1721 Mori S, Cho I, Ichiyasu H, et al. Asymptomatic carriage of Pneumocystis jiroveci in elderly patients with rheumatoid arthritis in Japan: a possible association between colonization and development of Pneumocystis jiroveci pneumonia during low-dose MTX therapy. Mod Rheumatol. 2008;18(3):240-6. [pmid: 18306977].
1722 Mori S, Cho I, Sugimoto M. A followup study of asymptomatic carriers of Pneumocystis jiroveci during immunosuppressive therapy for rheumatoid arthritis. J Rheumatol. Aug. 2009;36(8):1600-5. [pmid: 19531759].
1723 Mori S, Ebihara K. A sudden onset of diabetic ketoacidosis and acute pancreatitis after introduction of mizoribine therapy in a patient with rheumatoid arthritis. Mod Rheumatol. 2008;18(6):634-8. [pmid: 18651203].
1724 Mori S, Imamura F, Kiyofuji C, et al. Pneumocystis jiroveci pneumonia in a patient with rheumatoid arthritis as a complication of treatment with infliximab, anti-tumor necrosis factor alpha neutralizing antibody. Mod Rheumatol. 2006;16(1):58-62. [pmid: 16622728].
1725 Mori S, Imamura F, Kiyofuji C, et al. Development of interstitial pneumonia in a rheumatoid arthritis patient treated with infliximab, an anti-tumor necrosis factor alpha-neutralizing antibody. Mod Rheumatol. 2006;16(4):251-5. [pmid: 16906378].
1726 Mori S, Koga Y, Imamura F, et al. Early rheumatoid arthritis in a patient with Sjogren’s syndrome and pulmonary nodular amyloidosis: clinical implication of early limited use of infliximab. Mod Rheumatol. 2007;17(6):500-6. [pmid: 18084704].
1727 Mori S, Tomita Y, Horikawa T, et al. Delayed spinal infection after laminectomy in a patient with rheumatoid arthritis interruptedly exposed to anti-tumor necrosis factor alpha agents. Clin Rheumatol. Jul. 2008;27(7):937-9. [pmid: 18330608].
1728 Morita Y, Fukazawa T, Hirashima M, et al. The effect of methotrexate (MTX) on expression of signalling lymphocytic activation molecule (SLAM) in patients with rheumatoid arthritis (RA) and its role in the regulation of cytokine production. Scand J Rheumatol. Jul–Aug. 2006;35(4):268-72. [pmid: 16882589].
1729 Morita Y, Sasae Y, Sakuta T, et al. Efficacy of low-dose tacrolimus added to methotrexate in patients with rheumatoid arthritis in Japan: a retrospective study. Mod Rheumatol. 2008;18(4):379-84. [pmid: 18463945].
1730 Morozzi G, Fabbroni M, Bellisai F, et al. Low serum level of COMP, a cartilage turnover marker, predicts rapid and high ACR70 response to adalimumab therapy in rheumatoid arthritis. Clin Rheumatol. Aug. 2007;26(8):1335-8. [pmid: 17285224].
1731 Morrison E, Crosbie D, Capell HA. Attitude of rheumatoid arthritis patients to treatment with oral corticosteroids. Rheumatology (Oxford). Oct. 2003;42(10):1247-50. [pmid: 12832705].
1732 Moszyk DJ, Sulit DJ. Rheumatoid arthritis in a military aviator. Aviat Space Environ Med. Jan. 2007;78(1):63-6. [pmid: 17225486].
1733 Motivala SJ, Khanna D, FitzGerald J, et al. Stress activation of cellular markers of inflammation in rheumatoid arthritis: protective effects of tumor necrosis factor alpha antagonists. Arthritis Rheum. Feb. 2008;58(2):376-83. [pmid: 18240230].
1734 Mourao AF, Rustin M, Isenberg D. Exacerbation of psoriatic skin lesions in patients with psoriatic arthritis receiving anti-tumour necrosis factor-alpha therapy: description of 3 cases and review of the literature. Clin Exp Rheumatol. May–Jun. 2010;28(3):408-10. [pmid: 20576227].
1735 Mrabet D, Meddeb N, Ajlani H, et al. Cerebral vasculitis in a patient with rheumatoid arthritis. Joint Bone Spine. Mar. 2007;74(2):201-4. [pmid: 17336121].
1736 Mufti AH, Toye BW, McKendry RR, et al. Mycobacterium abscessus infection after use of tumor necrosis factor alpha inhibitor therapy: case report and review of infectious complications associated with tumor necrosis factor alpha inhibitor use. Diagn Microbiol Infect Dis. Nov. 2005;53(3):233-8. [pmid: 16249064].
1737 Mugnier B, Balandraud N, Darque A, et al. Polymorphism at position -308 of the tumor necrosis factor alpha gene influences outcome of infliximab therapy in rheumatoid arthritis. Arthritis Rheum. Jul. 2003;48(7):1849-52. [pmid: 12847678].
1738 Mulherin D, Sheeran TP. Clinical image: hidden costs of anti-tumor necrosis factor alpha therapy. Arthritis Rheum. Mar. 2003;48(3):868. [pmid: 12632461].
1739 Mullan RH, Bresnihan B. Disease-modifying anti-rheumatic drug therapy and structural damage in early rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 2003;21(5 Suppl 31):S158-64. [pmid: 14969069].
1740 Muller K, Zak M, Nielsen S, et al. Interleukin-1 receptor antagonist in neonates, children and adults, and in patients with pauci- and polyarticular onset juvenile chronic arthritis. Clin Exp Rheumatol. Jul–Aug. 1997;15(4):439-44. [pmid: 9272308].
1741 Muntinghe FL, de Filippi JP, Breedveld RW, et al. A young woman with fever and a pericardial effusion. Neth J Med. Nov. 2002;60(10):414-5. [pmid: 12607594].
1742 Murata K, Yasuda T, Ito H, et al. Lack of increase in postoperative complications with low-dose methotrexate therapy in patients with rheumatoid arthritis undergoing elective orthopedic surgery. Mod Rheumatol. 2006;16(1):14-9. [pmid: 16622718].
1743 Murphy FT, Enzenauer RJ, Battafarano DF, et al. Etanercept-associated injection-site reactions. Arch Dermatol. Apr. 2000;136(4):556-7. [pmid: 10768663].
1744 Murphy NG. Current concepts in the management of rheumatoid arthritis. Del Med J. Apr. 1992;64(4):257-64. [pmid: 1352263].
1745 Murray RP, Bourne MH, Fitzgerald RH Jr. Metachronous infections in patients who have had more than one total joint arthroplasty. J Bone Joint Surg Am. Dec. 1991;73(10):1469-74. [pmid: 1748696].
1746 Musial J, Undas A, Celinska-Lowenhoff M. Polymyositis associated with infliximab treatment for rheumatoid arthritis. Rheumatology (Oxford). Dec. 2003;42(12):1566-8. [pmid: 14645861].
1747 Muto S, Asano Y, Okazaki H, et al. Renal potassium wasting in distal renal tubular acidosis: role of aldosterone. Intern Med. Aug. 1992;31(8):1047-51. [pmid: 1335804].
1748 Mutsukura K, Nakamura H, Iwanaga N, et al. Successful treatment of a patient with primary Sjogren’s syndrome complicated with pericarditis during pregnancy. Intern Med. 2007;46(14):1143-7. [pmid: 17634717].
1749 Muzaffer MA, Dayer JM, Feldman BM, et al. Differences in the profiles of circulating levels of soluble tumor necrosis factor receptors and interleukin 1 receptor antagonist reflect the heterogeneity of the subgroups of juvenile rheumatoid arthritis. J Rheumatol. May. 2002;29(5):1071-8. [pmid: 12022325].
1750 Myers WA, Najarian D, Gottlieb AB. New-onset, debilitating arthritis in psoriasis patients receiving efalizumab. J Dermatolog Treat. 2006;17(6):353-4. [pmid: 17853308].
1751 Mylona E, Golfinopoulou S, Samarkos M, et al. Acute hepatitis in adult Still’s disease during corticosteroid treatment successfully treated with anakinra. Clin Rheumatol. May. 2008;27(5):659-61. [pmid: 18095015].
1752 Mylona E, Vadala C, Papadakos V, et al. Cutaneous polyarteritis nodosa in adult onset Still’s disease. Eur J Dermatol. Nov–Dec. 2009;19(6):621-2. [pmid: 19592325].
1753 Nabae M, Inoue K, Ushiyama T, et al. Gene expressions of antiinflammatory mediators in THR retrieved interfacial membranes. Acta Orthop Scand. Apr. 1999;70(2):149-54. [pmid: 10366916].
1754 Nadarajah K, Pritchard C. Listeria monocytogenes septic arthritis in a patient treated with etanercept for rheumatoid arthritis. J Clin Rheumatol. Apr. 2005;11(2):120-2. [pmid: 16357718].
1755 Nadareishvili Z, Michaud K, Hallenbeck JM, et al. Cardiovascular, rheumatologic, and pharmacologic predictors of stroke in patients with rheumatoid arthritis: a nested, case-control study. Arthritis Rheum. 2008;59(8):1090-6. [pmid: 18668583].
1756 Nagasawa H, Kameda H, Sekiguchi N, et al. Normalisation of physical function by infliximab in patients with RA: factors associated with normal physical function. Clin Exp Rheumatol. May–Jun. 2010;28(3):365-72. [pmid: 20525444].
1757 Nagashima M, Matsuoka T, Saitoh K, et al. Treatment continuation rate in relation to efficacy and toxicity in long-term therapy with low-dose methotrexate, sulfasalazine, and bucillamine in 1,358 Japanese patients with rheumatoid arthritis. Clin Exp Rheumatol. 2006;24(3):260-7. [pmid: 16870092].
1758 Nair B, Raval G, Mehta P. TNF-alpha inhibitor etanercept and hematologic malignancies: report of a case and review of the literature. Am J Hematol. Nov. 2007;82(11):1022-4. [pmid: 17654504].
1759 Nakahara H, Mima T, Yoshio-Hoshino N, et al. A case report of a patient with refractory adult-onset Still’s disease who was successfully treated with tocilizumab over 6 years. Mod Rheumatol. 2009;19(1):69-72. [pmid: 18762861].
1760 Nakajima A, Inoue E, Tanaka E, et al. Mortality and cause of death in Japanese patients with rheumatoid arthritis based on a large observational cohort, IORRA. Scand J Rheumatol. 2010;39(5):360-7. [pmid: 20476859].
1761 Nakamura T, Higashi S, Tomoda K, et al. Efficacy of etanercept in patients with AA amyloidosis secondary to rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2007;25(4):518-22. [pmid: 17888205].
1762 Nakashima C, Tanioka M, Takahashi K, et al. Diffuse large B-cell lymphoma in a patient with rheumatoid arthritis treated with infliximab and methotrexate. Clin Exp Dermatol. Jul. 2008;33(4):437-9. [pmid: 18485021].
1763 Nakashima Y, Kondo M, Harada H, et al. Clinical evaluation of tocilizumab for patients with active rheumatoid arthritis refractory to anti-TNF biologics: tocilizumab in combination with methotrexate. Mod Rheumatol. Aug. 2010;20(4):343-52. [pmid: 20480201].
1764 Nakelchik M, Mangino JE. Reactivation of histoplasmosis after treatment with infliximab. Am J Med. Jan. 2002;112(1):78. [pmid: 11812415].
1765 Nakou M, Katsikas G, Sidiropoulos P, et al. Rituximab therapy reduces activated B cells in both the peripheral blood and bone marrow of patients with rheumatoid arthritis: depletion of memory B cells correlates with clinical response. Arthritis Res Ther. 2009;11(4):R131. [pmid: 19715572].
1766 Nampei A, Hashimoto J, Koyanagi J, et al. Characteristics of fracture and related factors in patients with rheumatoid arthritis. Mod Rheumatol. 2008;18(2):170-6. [pmid: 18297237].
1767 Nanke Y, Kotake S, Yonemoto K, et al. Cricoarytenoid arthritis with rheumatoid arthritis and systemic lupus erythematosus. J Rheumatol. Mar. 2001;28(3):624-6. [pmid: 11296970].
1768 Naranjo A, Sokka T, Descalzo MA, et al. Cardiovascular disease in patients with rheumatoid arthritis: results from the QUEST-RA study. Arthritis Res Ther. 2008;10(2):R30. [pmid: 18325087].
1769 Naredo E, Moller I, Cruz A, et al. Power Doppler ultrasonographic monitoring of response to anti-tumor necrosis factor therapy in patients with rheumatoid arthritis. Arthritis Rheum. Aug. 2008;58(8):2248-56. [pmid: 18668537].
1770 Narushima M, Suzuki H, Kasai T, et al. Pulmonary nocardiosis in a patient treated with corticosteroid therapy. Respirology. Mar. 2002;7(1):87-9. [pmid: 11915862].
1771 Narvaez J, Montala N, Busquets-Perez N, et al. Collagenous colitis and spondylarthropathy. Arthritis Rheum. Jun. 15. 2006;55(3):507-12. [pmid: 16739191].
1772 Nash P, Thaci D, Behrens F, et al. Leflunomide improves psoriasis in patients with psoriatic arthritis: an in-depth analysis of data from the TOPAS study. Dermatology. 2006;212(3):238-49. [pmid: 16549920].
1773 Nast A, Reytan N, Rosumeck S, et al. Low prescription rate for systemic treatments in the management of severe psoriasis vulgaris and psoriatic arthritis in dermatological practices in Berlin and Brandenburg, Germany: results from a patient registry. J Eur Acad Dermatol Venereol. Nov. 2008;22(11):1337-42. [pmid: 18624864].
1774 Natsuga K, Sawamura D, Homma E, et al. Amicrobial pustulosis associated with IgA nephropathy and Sjogren’s syndrome. J Am Acad Dermatol. Sep. 2007;57(3):523-6. [pmid: 17599665].
1775 Nawata M, Saito K, Nakayamada S, et al. Discontinuation of infliximab in rheumatoid arthritis patients in clinical remission. Mod Rheumatol. 2008;18(5):460-4. [pmid: 18535759].
1776 Ndongo S, Lekpa FK, Ka MM, et al. Presentation and severity of rheumatoid arthritis at diagnosis in Senegal. Rheumatology (Oxford). Sep. 2009;48(9):1111-3. [pmid: 19581382].
1777 Neeck G, Federlin K, Graef V, et al. Adrenal secretion of cortisol in patients with rheumatoid arthritis. J Rheumatol. Jan. 1990;17(1):24-9. [pmid: 2313668].
1778 Neeman N, Aronson MD, Schulze JE, et al. Improving pregnancy counseling for women with rheumatoid arthritis taking methotrexate. Am J Med. Nov. 2009;122(11):998-1000. [pmid: 19854323].
1779 Neff K, Stack J, Harney S, et al. The use of abatacept in debilitating cavitating lung disease associated with rheumatoid arthritis, bronchocentric granulomatosis and aspergillosis. Thorax. Jun. 2010;65(6):545-6. [pmid: 20522855].
1780 Neidel J, Schulze M, Lindschau J. Association between degree of bone-erosion and synovial fluid-levels of tumor necrosis factor alpha in the knee-joints of patients with rheumatoid arthritis. Inflamm Res. May. 1995;44(5):217-21. [pmid: 7655997].
1781 Nemoto Y, Taniguchi A, Kamioka M, et al. Epstein-Barr virus-infected subcutaneous panniculitis-like T-cell lymphoma associated with methotrexate treatment. Int J Hematol. Sep. 2010;92(2):364-8. [pmid: 20665252].
1782 Nerome Y, Imanaka H, Nonaka Y, et al. A case of planned pregnancy with an interruption in infliximab administration in a 27-year-old female patient with rheumatoid-factor-positive polyarthritis juvenile idiopathic arthritis which improved after restarting infliximab and methotrexate. Mod Rheumatol. 2008;18(2):189-92. [pmid: 18273538].
1783 Nesheiwat JP, Dillon K, McGlothan K, et al. An elderly man with rheumatoid arthritis and dyspnea. Chest. Apr. 2009;135(4):1090-3. [pmid: 19349405].
1784 Netea MG, Radstake T, Joosten LA, et al. Salmonella septicemia in rheumatoid arthritis patients receiving anti-tumor necrosis factor therapy: association with decreased interferon-gamma production and Toll-like receptor 4 expression. Arthritis Rheum. Jul. 2003;48(7):1853-7. [pmid: 12847679].
1785 Neustadt DH. Double blind evaluation of the long-term effects of etodolac versus ibuprofen in patients with rheumatoid arthritis. J Rheumatol Suppl. Feb. 1997;47:17-22. [pmid: 9035016].
1786 Newman DK, Isaacs JD, Watson PG, et al. Prevention of immune-mediated corneal graft destruction with the anti-lymphocyte monoclonal antibody, CAMPATH-1H. Eye. 1995;9(Pt 5):564-9. [pmid: 8543073].
1787 Newton SM, Mackie SL, Martineau AR, et al. Reduction of chemokine secretion in response to mycobacteria in infliximab-treated patients. Clin Vaccine Immunol. Mar. 2008;15(3):506-12. [pmid: 18160618].
1788 Ng CM, Bruno R, Combs D, et al. Population pharmacokinetics of rituximab (anti-CD20 monoclonal antibody) in rheumatoid arthritis patients during a phase II clinical trial. J Clin Pharmacol. Jul. 2005;45(7):792-801. [pmid: 15951469].
1789 Niemela RK, Hakala M. Primary Sjogren’s syndrome with severe central nervous system disease. Semin Arthritis Rheum. Aug. 1999;29(1):4-13. [pmid: 10468410].
1790 Niemela RK, Hakala M, Huikuri HV, et al. Comprehensive study of autonomic function in a population with primary Sjogren’s syndrome. No evidence of autonomic involvement. J Rheumatol. Jan. 2003;30(1):74-9. [pmid: 12508393].
1791 Niewold TB, Gibofsky A. Concomitant interferon-alpha therapy and tumor necrosis factor alpha inhibition for rheumatoid arthritis and hepatitis C. Arthritis Rheum. Jul. 2006;54(7):2335-7. [pmid: 16802375].
1792 Niitsu N, Okamoto M, Nakamine H, et al. Clinicopathologic correlations of diffuse large B-cell lymphoma in rheumatoid arthritis patients treated with methotrexate. Cancer Sci. May. 2010;101(5):1309-13. [pmid: 20210795].
1793 Nikas SN, Alamanos Y, Voulgari PV, et al. Infliximab treatment in ankylosing spondylitis: an observational study. Ann Rheum Dis. Jun. 2005;64(6):940-2. [pmid: 15564309].
1794 Nikas SN, Temekonidis TI, Zikou AK, et al. Treatment of resistant rheumatoid arthritis by intra-articular infliximab injections: a pilot study. Ann Rheum Dis. Jan. 2004;63(1):102-3. [pmid: 14672902].
1795 Nikas SN, Voulgari PV, Alamanos Y, et al. Efficacy and safety of switching from infliximab to adalimumab: a comparative controlled study. Ann Rheum Dis. Feb. 2006;65(2):257-60. [pmid: 15975964].
1796 Nikas SN, Voulgari PV, Takalou IP, et al. Healing of psoriatic skin lesions, and improvement of psoriatic arthritis resistant to immunosuppressive drugs, after infliximab treatment. Ann Rheum Dis. Nov. 2005;64(11):1665-7. [pmid: 16227426].
1797 Nishida K, Okada Y, Nawata M, et al. Induction of hyperadiponectinemia following long-term treatment of patients with rheumatoid arthritis with infliximab (IFX), an anti-TNF-alpha antibody. Endocr J. Mar. 2008;55(1):213-6. [pmid: 18270431].
1798 Nishie W, Sawamura D, Iitoyo M, et al. Intravascular histiocytosis associated with rheumatoid arthritis. Dermatology. 2008;217(2):144-5. [pmid: 18509245].
1799 Nishimoto N, Hashimoto J, Miyasaka N, et al. Study of active controlled monotherapy used for rheumatoid arthritis, an IL-6 inhibitor (SAMURAI): evidence of clinical and radiographic benefit from an x ray reader-blinded randomised controlled trial of tocilizumab. Ann Rheum Dis. 2007;66(9):1162-7. [pmid: 17485422].
1800 Nishimoto N, Miyasaka N, Yamamoto K, et al. Study of active controlled tocilizumab monotherapy for rheumatoid arthritis patients with an inadequate response to methotrexate (SATORI): significant reduction in disease activity and serum vascular endothelial growth factor by IL-6 receptor inhibition therapy. Mod Rheumatol. 2009;19(1):12-9. [pmid: 18979150].
1801 Nishimoto N, Terao K, Mima T, et al. Mechanisms and pathologic significances in increase in serum interleukin-6 (IL-6) and soluble IL-6 receptor after administration of an anti-IL-6 receptor antibody, tocilizumab, in patients with rheumatoid arthritis and Castleman disease. Blood. Nov. 15. 2008;112(10):3959-64. [pmid: 18784373].
1802 Nishimura H, Tachibana H, Makiura N, et al. Corticosteroid-responsive parkinsonism associated with primary Sjogren’s syndrome. Clin Neurol Neurosurg. Nov. 1994;96(4):327-31. [pmid: 7889697].
1803 Nissinen R, Leirisalo-Repo M, Peltomaa R, et al. Cytokine and chemokine receptor profile of peripheral blood mononuclear cells during treatment with infliximab in patients with active rheumatoid arthritis. Ann Rheum Dis. Jun. 2004;63(6):681-7. [pmid: 15140775].
1804 Niwa Y, Iio A, Niwa G, et al. Serum albumin metabolism in rheumatic diseases: relationship to corticosteroids and peptic ulcer. J Clin Lab Immunol. Jan. 1990;31(1):11-6. [pmid: 1966978].
1805 Nizam S, Johnstone A, Green M, et al. Necrotising scleritis and connective tissue disease--three cases and a review. Clin Rheumatol. Mar. 2009;28(3):339-41. [pmid: 19052835].
1806 Noguera-Pons R, Borras-Blasco J, Romero-Crespo I, et al. Optic neuritis with concurrent etanercept and isoniazid therapy. Ann Pharmacother. Dec. 2005;39(12):2131-5. [pmid: 16264061].
1807 Nonaka T, Nishisaka F, Fukuda K, et al. Relationship between bone mineral density and urine level of NTx in rheumatoid arthritis. J Bone Miner Metab. 2005;23(4):314-7. [pmid: 15981028].
1808 Novak S, Cikes N. Infliximab-induced lupus or rheumatoid arthritis (RA) overlapping with systemic lupus erythematosus (SLE) unmasked by infliximab. Clin Exp Rheumatol. Mar–Apr. 2004;22(2):268. [pmid: 15083903].
1809 Nozaki Y, Nagare Y, Hino S, et al. Therapeutic strategy and significance of serum rheumatoid factor in patients with rheumatoid arthritis during infliximab treatment. Nihon Rinsho Meneki Gakkai Kaishi. 2010;33(3):135-41. [pmid: 20601833].
1810 Nozaki Y, Nagare Y, Kinoshita K, et al. Successful treatment using tacrolimus plus corticosteroid in a patient with RA associated with MDS. Rheumatol Int. Mar. 2008;28(5):487-90. [pmid: 17764011].
1811 Nuijten MJ, Engelfriet P, Duijn K, et al. A cost-cost study comparing etanercept with infliximab in rheumatoid arthritis. Pharmacoeconomics. 2001;19(10):1051-64. [pmid: 11735673].
1812 Nuki G, Bresnihan B, Bear MB, et al. Long-term safety and maintenance of clinical improvement following treatment with anakinra (recombinant human interleukin-1 receptor antagonist) in patients with rheumatoid arthritis: extension phase of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Nov. 2002;46(11):2838-46. [pmid: 12428223].
1813 Nunez-Cornejo C, Borras-Blasco J, Gracia-Perez A, et al. Septic shock and community-acquired pneumonia associated with etanercept therapy. Int J Clin Pharmacol Ther. Apr. 2008;46(4):193-7. [pmid: 18397693].
1814 Nyhall-Wahlin BM, Petersson IF, Nilsson JA, et al. High disease activity disability burden and smoking predict severe extra-articular manifestations in early rheumatoid arthritis. Rheumatology (Oxford). Apr. 2009;48(4):416-20. [pmid: 19213849].
1815 Oberstein EM, Kromo O, Tozman EC. Type I reaction of Hansen’s disease with exposure to adalimumab: a case report. Arthritis Rheum. Jul. 15. 2008;59(7):1040-3. [pmid: 18576299].
1816 Ochi S, Harigai M, Mizoguchi F, et al. Leflunomide-related acute interstitial pneumonia in two patients with rheumatoid arthritis: autopsy findings with a mosaic pattern of acute and organizing diffuse alveolar damage. Mod Rheumatol. 2006;16(5):316-20. [pmid: 17039315].
1817 Ochi S, Taniguchi K, Nagashima M. Leflunomide-induced polymyositis in a patient with rheumatoid arthritis. Mod Rheumatol. 2009;19(4):443-6. [pmid: 19526307].
1818 Ochiai T, Washio H, Shiraiwa H, et al. Psoriatic onycho-pachydermo-periostitis successfully treated with low-dose methotrexate. Med Sci Monit. Apr. 2006;12(4):CS27-30. [pmid: 16572055].
1819 O’Connor PA, Eustace S, O’Byrne J. Spinal cord injury following osteoporotic vertebral fracture: case report. Spine. Sep. 15. 2002;27(18):E413-5. [pmid: 12634579].
1820 Oda S, Fujinaga H, Takahashi K. Infectious myositis involving the piriformis in a patient with rheumatoid arthritis. Mod Rheumatol. 2006;16(4):260-3. [pmid: 16906380].
1821 O’Dell J. Conventional DMARD options for patients with a suboptimal response to methotrexate. J Rheumatol Suppl. Jun. 2001;62:21-6. [pmid: 11409154].
1822 O’Dell JR, Petersen K, Leff R, et al. Etanercept in combination with sulfasalazine, hydroxychloroquine, or gold in the treatment of rheumatoid arthritis. J Rheumatol. Feb. 2006;33(2):213-8. [pmid: 16358366].
1823 Odessey E, Cohn A, Beaman K, et al. Invasive mucormycosis of the maxillary sinus: extensive destruction with an indolent presentation. Surg Infect (Larchmt). Feb. 2008;9(1):91-8. [pmid: 18363473].
1824 Oei HB, Hooker RS, Cipher DJ, et al. High rates of stopping or switching biological medications in veterans with rheumatoid arthritis. Clin Exp Rheumatol. 2009;27(6):926-34. [pmid: 20149307].
1825 Oelzner P, Schwabe A, Lehmann G, et al. Significance of risk factors for osteoporosis is dependent on gender and menopause in rheumatoid arthritis. Rheumatol Int. Sep. 2008;28(11):1143-50. [pmid: 18446340].
1826 Ogawa H, Itokazu M, Ito Y, et al. Quality of life evaluated by Short Form-8 in patients with rheumatoid arthritis who were receiving infusion of infliximab. Mod Rheumatol. 2009;19(1):27-32. [pmid: 18712459].
1827 Ogiwara Y, Mochizuki H, Morioka T, et al. A case with life-threatening interstitial pneumonia associated with bucillamine treatment. Mod Rheumatol. 2008;18(5):522-5. [pmid: 18504526].
1828 Oguz FM, Oguz A, Uzunlulu M. The effect of infliximab treatment on insulin resistance in patients with rheumatoid arthritis. Acta Clin Belg. Jul–Aug. 2007;62(4):218-22. [pmid: 17849692].
1829 Oh J, Arkfeld DG, Horwitz DA. Development of Crohn’s disease in a patient taking etanercept. J Rheumatol. Apr. 2005;32(4):752-3. [pmid: 15801037].
1830 Oh WM, Hwang IN, Son HH, et al. Rapid periapical bone destruction during endodontic treatment of a patient with rheumatoid arthritis. J Endod. Oct. 2008;34(10):1261-3. [pmid: 18793934].
1831 Ohshima S, Mima T, Sasai M, et al. Tumour necrosis factor alpha (TNF-alpha) interferes with Fas-mediated apoptotic cell death on rheumatoid arthritis (RA) synovial cells: a possible mechanism of rheumatoid synovial hyperplasia and a clinical benefit of anti-TNF-alpha therapy for RA. Cytokine. Mar. 2000;12(3):281-8. [pmid: 10704256].
1832 Ohsugi Y, Kishimoto T. The recombinant humanized anti-IL-6 receptor antibody tocilizumab, an innovative drug for the treatment of rheumatoid arthritis. Expert Opin Biol Ther. May. 2008;8(5):669-81. [pmid: 18407769].
1833 Oili KS, Niinisalo H, Korpilahde T, et al. Treatment of reactive arthritis with infliximab. Scand J Rheumatol. 2003;32(2):122-4. [pmid: 12737333].
1834 Okamoto H, Koizumi K, Kamitsuji S, et al. Beneficial action of statins in patients with rheumatoid arthritis in a large observational cohort. J Rheumatol. May. 2007;34(5):964-8. [pmid: 17444591].
1835 Okamoto O, Oishi M, Fujiwara S. Steroid-resistant adult-onset Still’s disease which showed a quick response to methotrexate. J Dermatol. Feb. 2008;35(2):106-10. [pmid: 18271807].
1836 Okuda Y, Takasugi K. Successful use of a humanized anti-interleukin-6 receptor antibody, tocilizumab, to treat amyloid A amyloidosis complicating juvenile idiopathic arthritis. Arthritis Rheum. Sep. 2006;54(9):2997-3000. [pmid: 16947531].
1837 Okuda Y, Takasugi K, Oyama T, et al. Intractable diarrhoea associated with secondary amyloidosis in rheumatoid arthritis. Ann Rheum Dis. Sep. 1997;56(9):535-41. [pmid: 9370878].
1838 Olewicz-Gawlik A, Korczowska-Lacka I, Lacki JK, et al. Fucosylation of serum alpha1-acid glycoprotein in rheumatoid arthritis patients treated with infliximab. Clin Rheumatol. Oct. 2007;26(10):1679-84. [pmid: 17310270].
1839 Olive A, del Blanco J, Pons M, et al. The clinical spectrum of remitting seronegative symmetrical synovitis with pitting edema. The Catalan Group for the Study of RS3PE. J Rheumatol. Feb. 1997;24(2):333-6. [pmid: 9034993].
1840 Oliveira B, Arkfeld DG, Weitz IC, et al. Successful rituximab therapy of acquired factor VIII inhibitor in a patient with rheumatoid arthritis. J Clin Rheumatol. Apr. 2007;13(2):89-91. [pmid: 17414538].
1841 Olivieri I, de Portu S, Salvarani C, et al. The psoriatic arthritis cost evaluation study: a cost-of-illness study on tumour necrosis factor inhibitors in psoriatic arthritis patients with inadequate response to conventional therapy. Rheumatology (Oxford). Nov. 2008;47(11):1664-70. [pmid: 18725374].
1842 Olivieri I, de Stefano G, Padula A, et al. Infliximab in a case of early adult-onset Still’s disease. Clin Rheumatol. Oct. 2003;22(4–5):369-70. [pmid: 14579170].
1843 Olivieri I, Palazzi C, Peruz G, et al. Management issues with elderly-onset rheumatoid arthritis: an update. Drugs Aging. 2005;22(10):809-22. [pmid: 16245956].
1844 Ollendorf DA, Massarotti E, Birbara C, et al. Frequency, predictors, and economic impact of upward dose adjustment of infliximab in managed care patients with rheumatoid arthritis. J Manag Care Pharm. Jun. 2005;11(5):383-93. [pmid: 15934797].
1845 Ollendorf DA, Peterson AN, Doyle J, et al. Impact of leflunomide versus biologic agents on the costs of care for rheumatoid arthritis in a managed care population. Am J Manag Care. May. 2002;8(7 Suppl):S203-13. [pmid: 12022236].
1846 Omdal R, Gunnarsson R. The effect of interleukin-1 blockade on fatigue in rheumatoid arthritis--a pilot study. Rheumatol Int. Aug. 2005;25(6):481-4. [pmid: 15071755].
1847 Ongaro A, De Mattei M, Pellati A, et al. Can tumor necrosis factor receptor II gene 676T>G polymorphism predict the response grading to anti-TNFalpha therapy in rheumatoid arthritis?. Rheumatol Int. Jul. 2008;28(9):901-8. [pmid: 18309487].
1848 Onuma S, Yamaji K, Kempe K, et al. Investigation of the clinical effect of large volume leukocytapheresis on methotrexate-resistant rheumatoid arthritis. Ther Apher Dial. Oct. 2006;10(5):404-11. [pmid: 17096694].
1849 Ooi KG, Wingate R, Adler PA. Necrotising anterior scleritis in a late-onset rheumatoid arthritis (LORA) patient. Ocul Immunol Inflamm. Jan–Feb. 2007;15(1):33-6. [pmid: 17365805].
1850 Oren S, Mandelboim M, Braun-Moscovici Y, et al. Vaccination against influenza in patients with rheumatoid arthritis: the effect of rituximab on the humoral response. Ann Rheum Dis. Jul. 2008;67(7):937-41. [pmid: 17981914].
1851 Ornetti P, Solau E, Gaudin P, et al. Increase in methotrexate dose in patients with rheumatoid arthritis who have an inadequate response to infliximab. Ann Rheum Dis. Sep. 2005;64(9):1379-80. [pmid: 16100349].
1852 Orstavik RE, Haugeberg G, Mowinckel P, et al. Vertebral deformities in rheumatoid arthritis: a comparison with population-based controls. Arch Intern Med. Feb. 23. 2004;164(4):420-5. [pmid: 14980993].
1853 Orstavik RE, Haugeberg G, Uhlig T, et al. Vertebral deformities in 229 female patients with rheumatoid arthritis: associations with clinical variables and bone mineral density. Arthritis Rheum. Jun. 15. 2003;49(3):355-60. [pmid: 12794791].
1854 Orstavik RE, Haugeberg G, Uhlig T, et al. Incidence of vertebral deformities in 255 female rheumatoid arthritis patients measured by morphometric X-ray absorptiometry. Osteoporos Int. Jan. 2005;16(1):35-42. [pmid: 15197538].
1855 Orstavik RE, Haugeberg G, Uhlig T, et al. Quantitative ultrasound and bone mineral density: discriminatory ability in patients with rheumatoid arthritis and controls with and without vertebral deformities. Ann Rheum Dis. Aug. 2004;63(8):945-51. [pmid: 15249321].
1856 Ortiz-Santamaria V, Valls-Roc M, Sanmarti M, et al. Anti-TNF treatment in secondary amyloidosis. Rheumatology (Oxford). Nov. 2003;42(11):1425-6. [pmid: 14578444].
1857 Osawa H, Yamabe H, Seino S, et al. A case of Sjogren’s syndrome associated with Sweet’s syndrome. Clin Rheumatol. Jan. 1997;16(1):101-5. [pmid: 9132312].
1858 Ostanek L, Pawlik A, Brzosko I, et al. The urinary excretion of pyridinoline and deoxypyridinoline during rheumatoid arthritis therapy with infliximab. Clin Rheumatol. Jun. 2004;23(3):214-7. [pmid: 15168147].
1859 Ostensen M, Eigenmann GO. Etanercept in breast milk. J Rheumatol. May. 2004;31(5):1017-8. [pmid: 15124283].
1860 Ostensen M, Forger F. Management of RA medications in pregnant patients. Nat Rev Rheumatol. Jul. 2009;5(7):382-90. [pmid: 19506586].
1861 Ostensen M, Raio L. A woman with rheumatoid arthritis whose condition did not improve during pregnancy. Nat Clin Pract Rheumatol. Dec. 2005;1(2):111-4. quiz 1 p following 4. [pmid: 16932640].
1862 Ostergaard M, Duer A, Nielsen H, et al. Magnetic resonance imaging for accelerated assessment of drug effect and prediction of subsequent radiographic progression in rheumatoid arthritis: a study of patients receiving combined anakinra and methotrexate treatment. Ann Rheum Dis. Oct. 2005;64(10):1503-6. [pmid: 15778238].
1863 Ostor AJ, Crisp AJ, Somerville MF, et al. Fatal exacerbation of rheumatoid arthritis associated fibrosing alveolitis in patients given infliximab. BMJ. Nov. 27. 2004;329(7477):1266. [pmid: 15564258].
1864 Ostrov BE. Beneficial effect of etanercept on rheumatoid lymphedema. Arthritis Rheum. Jan. 2001;44(1):240-1. [pmid: 11212167].
1865 Ostuni P, Botsios C, Punzi L, et al. Hepatitis B reactivation in a chronic hepatitis B surface antigen carrier with rheumatoid arthritis treated with infliximab and low dose methotrexate. Ann Rheum Dis. Jul. 2003;62(7):686-7. [pmid: 12810441].
1866 O’Sullivan MM, Amos N, Bedwell A, et al. Complement-mediated inhibition of immune precipitation in rheumatoid vasculitis. Rheumatol Int. 1990;10(4):159-63. [pmid: 2259841].
1867 Otabe S, Muto S, Asano Y, et al. Selective hypoaldosteronism in a patient with Sjogren’s syndrome: insensitivity to angiotensin II. Nephron. 1991;59(3):466-70. [pmid: 1758539].
1868 Otsuka T, Koyama T, Ohtani R, et al. Leflunomide-induced lung injury that developed after its withdrawal, coinciding with peripheral blood lymphocyte count decrease. Mod Rheumatol. 2008;18(1):96-9. [pmid: 18161003].
1869 Ott SJ, Baron A, Berghaus T, et al. Liver failure in adult Still’s disease during corticosteroid treatment. Eur J Gastroenterol Hepatol. Jan. 2003;15(1):87-90. [pmid: 12544700].
1870 Ouedraogo DD, Palazzo E, Nlome-Nze M, et al. Predominant cervical involvement in patients with psoriatic arthritis: report of two cases. Joint Bone Spine. Mar. 2007;74(2):175-8. [pmid: 16987680].
1871 Owino BO, Oyoo GO, Otieno CF. Socio-demographic and clinical aspects of rheumatoid arthritis. East Afr Med J. May. 2009;86(5):204-11. [pmid: 20084988].
1872 Ozaki D, Shirai Y, Nakayama Y, et al. A case report of insufficiency fracture of the Fossa acetabuli in a patient with rheumatoid arthritis. J Nippon Med Sch. Aug. 2000;67(4):267-70.
1873 Ozgocmen S, Godekmerdan A, Ozkurt-Zengin F. Acute-phase response, clinical measures and disease activity in ankylosing spondylitis. Joint Bone Spine. May. 2007;74(3):249-53. [pmid: 17387033].
1874 Ozgocmen S, Ozdemir H, Kiris A, et al. Clinical evaluation and power Doppler sonography in rheumatoid arthritis: evidence for ongoing synovial inflammation in clinical remission. South Med J. Mar. 2008;101(3):240-5. [pmid: 18364651].
1875 Pace J, Adami JZ, Mallia C, et al. Toxic epidermal necrolysis in a patient with psoriatic arthritis. Adv Exp Med Biol. 1999;455:557-60. [pmid: 10599399].
1876 Pachot A, Arnaud B, Marrote H, et al. Increased tumor necrosis factor-alpha mRNA expression in whole blood from patients with rheumatoid arthritis: reduction after infliximab treatment does not predict response. J Rheumatol. Nov. 2007;34(11):2158-61. [pmid: 17896807].
1877 Padyukov L, Lampa J, Heimburger M, et al. Genetic markers for the efficacy of tumour necrosis factor blocking therapy in rheumatoid arthritis. Ann Rheum Dis. Jun. 2003;62(6):526-9. [pmid: 12759288].
1878 Pagliano P, Attanasio V, Fusco U, et al. Does etanercept monotherapy enhance the risk of Listeria monocytogenes meningitis?. Ann Rheum Dis. Apr. 2004;63(4):462-3. [pmid: 15020347].
1879 Paira S, Caliani L, Luraquiz N. Distal extremity swelling with pitting oedema in rheumatoid arthritis. Clin Rheumatol. 2001;20(1):76-9. [pmid: 11254249].
1880 Palanichamy A, Roll P, Theiss R, et al. Modulation of molecular imprints in the antigen-experienced B cell repertoire by rituximab. Arthritis Rheum. Dec. 2008;58(12):3665-74. [pmid: 19035487].
1881 Palazzi C, D’Amico E, Pennese E, et al. Purpura and serum mixed cryoglobulinemia in psoriatic arthritis. Rheumatol Int. Dec. 2006;27(2):187-9. [pmid: 16900374].
1882 Palkonyai E, Kolarz G, Kopp M, et al. Depressive symptoms in early rheumatoid arthritis: a comparative longitudinal study. Clin Rheumatol. May. 2007;26(5):753-8. [pmid: 17332982].
1883 Pallinti V, Ganesan N, Anbazhagan M, et al. Serum biochemical markers in rheumatoid arthritis. Indian J Biochem Biophys. Aug. 2009;46(4):342-4. [pmid: 19788068].
1884 Pallotta P, Cianchini G, Ruffelli M, et al. Infliximab-induced lupus-like reaction in a patient with psoriatic arthritis. Rheumatology (Oxford). Jan. 2006;45(1):116-7. [pmid: 16319094].
1885 Palm S, Hinrichsen H, Barth J, et al. Modulation of lymphocyte subsets due to psychological stress in patients with rheumatoid arthritis. Eur J Clin Invest. Oct. 1992;22(Suppl 1):26-9. [pmid: 1459183].
1886 Pamuk ON, Harmandar F. A case of cervical spine meningioma following etanercept use in a patient with RA. Nat Rev Rheumatol. Aug. 2009;5(8):457-60. [pmid: 19648944].
1887 Pamuk ON, Harmandar F, Cakir N. The development of trigeminal neuralgia related to auricular chondritis in a patient with rheumatoid arthritis-relapsing polychondritis and its treatment with etanercept. Description of the first case. Clin Exp Rheumatol. Jan–Feb. 2009;27(1):128-9. [pmid: 19327242].
1888 Pan SM, Dehler S, Ciurea A, et al. Comparison of drug retention rates and causes of drug discontinuation between anti-tumor necrosis factor agents in rheumatoid arthritis. Arthritis Rheum. 2009;61(5):560-8. [pmid: 19405000].
1889 Panfilio CB, Hernandez-Cossio O, Hernandez-Fustes OJ. Orbital myositis and rheumatoid arthritis: case report. Arq Neuropsiquiatr. Mar. 2000;58(1):174-7. [pmid: 10770885].
1890 Panoulas VF, Douglas KM, Stavropoulos-Kalinoglou A, et al. Long-term exposure to medium-dose glucocorticoid therapy associates with hypertension in patients with rheumatoid arthritis. Rheumatology (Oxford). Jan. 2008;47(1):72-5. [pmid: 18077493].
1891 Panthakalam S, Bhatnagar D, Klimiuk P. The prevalence and management of hyperglycaemia in patients with rheumatoid arthritis on corticosteroid therapy. Scott Med J. Nov. 2004;49(4):139-41. [pmid: 15648707].
1892 Papadaki HA, Kritikos HD, Valatas V, et al. Anemia of chronic disease in rheumatoid arthritis is associated with increased apoptosis of bone marrow erythroid cells: improvement following anti-tumor necrosis factor-alpha antibody therapy. Blood. Jul. 15. 2002;100(2):474-82. [pmid: 12091338].
1893 Papadopoulos IA, Katsimbri P, Alamanos Y, et al. Early rheumatoid arthritis patients: relationship of age. Rheumatol Int. Mar. 2003;23(2):70-4. [pmid: 12634939].
1894 Papageorgiou SG, Kontaxis T, Bonakis A, et al. Orofacial dystonia related to Sjogren’s syndrome. Clin Rheumatol. Oct. 2007;26(10):1779-81. [pmid: 17225057].
1895 Papagoras CE, Argyropoulou MI, Voulgari PV, et al. A case of Brucella spondylitis in a patient with psoriatic arthritis receiving infliximab. Clin Exp Rheumatol. Jan–Feb. 2009;27(1):124-7. [pmid: 19327241].
1896 Papanikolaou IC, Sharma OP. A 47-year-old woman with rheumatoid arthritis and dyspnea on exertion. Chest. Dec. 2009;136(6):1694-7. [pmid: 19995773].
1897 Papoutsaki M, Chimenti MS, Costanzo A, et al. Adalimumab for severe psoriasis and psoriatic arthritis: an open-label study in 30 patients previously treated with other biologics. J Am Acad Dermatol. Aug. 2007;57(2):269-75. [pmid: 17574299].
1898 Parambil JG, Myers JL, Lindell RM, et al. Interstitial lung disease in primary Sjogren syndrome. Chest. Nov. 2006;130(5):1489-95. [pmid: 17099028].
1899 Parambil JG, Yi ES, Ryu JH. Obstructive bronchiolar disease identified by CT in the non-transplant population: analysis of 29 consecutive cases. Respirology. Apr. 2009;14(3):443-8. [pmid: 19210653].
1900 Park IN, Kim DS, Shim TS, et al. Acute exacerbation of interstitial pneumonia other than idiopathic pulmonary fibrosis. Chest. Jul. 2007;132(1):214-20. [pmid: 17400667].
1901 Park JH, Seo GY, Lee JS, et al. Positive conversion of tuberculin skin test and performance of interferon release assay to detect hidden tuberculosis infection during anti-tumor necrosis factor agent trial. J Rheumatol. Oct. 2009;36(10):2158-63. [pmid: 19723901].
1902 Park MC, Chung SJ, Park YB, et al. Relationship of serum TWEAK level to cytokine level, disease activity, and response to anti-TNF treatment in patients with rheumatoid arthritis. Scand J Rheumatol. May–Jun. 2008;37(3):173-8. [pmid: 18465450].
1903 Park SH, Kim CG, Kim JY, et al. Spontaneous regression of EBV-associated diffuse lymphoproliferative disease in a patient with rheumatoid arthritis after discontinuation of etanercept treatment. Rheumatol Int. Mar. 2008;28(5):475-7. [pmid: 17943259].
1904 Park YB, Ahn CW, Choi HK, et al. Atherosclerosis in rheumatoid arthritis: morphologic evidence obtained by carotid ultrasound. Arthritis Rheum. Jul. 2002;46(7):1714-9. [pmid: 12124853].
1905 Park YB, Choi HK, Kim MY, et al. Effects of antirheumatic therapy on serum lipid levels in patients with rheumatoid arthritis: a prospective study. Am J Med. Aug. 15. 2002;113(3):188-93. [pmid: 12208376].
1906 Park YB, Lee SK, Lee WK, et al. Lipid profiles in untreated patients with rheumatoid arthritis. J Rheumatol. Aug. 1999;26(8):1701-4. [pmid: 10451065].
1907 Parke FA, Reveille JD. Anti-tumor necrosis factor agents for rheumatoid arthritis in the setting of chronic hepatitis C infection. Arthritis Rheum. Oct. 15. 2004;51(5):800-4. [pmid: 15478165].
1908 Parker A, Izmailova ES, Narang J, et al. Peripheral blood expression of nuclear factor-kappab-regulated genes is associated with rheumatoid arthritis disease activity and responds differentially to anti-tumor necrosis factor-alpha versus methotrexate. J Rheumatol. Sep. 2007;34(9):1817-22. [pmid: 17696278].
1909 Parker SR, Solomon AR, Lane JE. A report of Epstein-Barr virus-positive primary cutaneous natural killer-/T-cell lymphoma. J Am Acad Dermatol. Jul. 2008;59(1):157-61. [pmid: 18468723].
1910 Paroli MP, Bruscolini A, De Carlo L, et al. Ring keratopathy in a patient with psoriatic arthritis and ulcerative rectocolitis. Ocul Immunol Inflamm. Jan–Feb. 2007;15(1):51-6. [pmid: 17365809].
1911 Parra Ruiz J, Ortego Centeno N, Raya Alvarez E. Development of tuberculosis in a patient treated with infliximab who had received prophylactic therapy with isoniazid. J Rheumatol. Jul. 2003;30(7):1657-8. [pmid: 12858475].
1912 Pasek M, Duk M, Podbielska M, et al. Galactosylation of IgG from rheumatoid arthritis (RA) patients--changes during therapy. Glycoconj J. Nov. 2006;23(7–8):463-71. [pmid: 17006638].
1913 Patel A, Kesler B, Wise RA. Persistent pneumomediastinum in interstitial fibrosis associated with rheumatoid arthritis: treatment with high-concentration oxygen. Chest. Jun. 2000;117(6):1809-13. [pmid: 10858424].
1914 Patel NK, Salathe C, Vu C, et al. Esophagitis dissecans: a rare cause of odynophagia. Endoscopy. Feb. 2007;39(Suppl 1):E127. [pmid: 17440858].
1915 Paulus HE, Di Primeo D, Sanda M, et al. Progression of radiographic joint erosion during low dose corticosteroid treatment of rheumatoid arthritis. J Rheumatol. Jul. 2000;27(7):1632-7. [pmid: 10914843].
1916 Paulus HE, Di Primeo D, Sharp JT, et al. Patient retention and hand-wrist radiograph progression of rheumatoid arthritis during a 3-year prospective study that prohibited disease modifying antirheumatic drugs. J Rheumatol. Mar. 2004;31(3):470-81. [pmid: 14994390].
1917 Pavelka K, Gatterova J, Tegzova D, et al. Radiographic progression of rheumatoid arthritis in patients from the Czech National Registry receiving infliximab treatment. Clin Exp Rheumatol. Jul–Aug. 2007;25(4):540-5. [pmid: 17888209].
1918 Pavletic SZ, Klassen LW, Pope R, et al. Treatment of relapse after autologous blood stem cell transplantation for severe rheumatoid arthritis. J Rheumatol Suppl. Oct. 2001;64:28-31. [pmid: 11642500].
1919 Pavlica L, Peric-Hajzler Z, Jovelic A, et al. Psoriatic arthritis: a retrospective study of 162 patients. Vojnosanit Pregl. Sep. 2005;62(9):613-20. [pmid: 16229202].
1920 Pawlik A, Herczynska M, Kurzawski M, et al. The effect of exon (19C>A) dihydroorotate dehydrogenase gene polymorphism on rheumatoid arthritis treatment with leflunomide. Pharmacogenomics. Feb. 2009;10(2):303-9. [pmid: 19207032].
1921 Pawlik A, Herczynska M, Kurzawski M, et al. IL-1beta, IL-6, and TNF gene polymorphisms do not affect the treatment outcome of rheumatoid arthritis patients with leflunomide. Pharmacol Rep. Mar–Apr. 2009;61(2):281-7. [pmid: 19443940].
1922 Pawlik A, Ostanek L, Brzosko I, et al. Therapy with infliximab decreases the CD4+CD28− T cell compartment in peripheral blood in patients with rheumatoid arthritis. Rheumatol Int. Nov. 2004;24(6):351-4. [pmid: 14504910].
1923 Peddle L, Butt C, Snelgrove T, et al. Interleukin (IL) 1alpha, IL1beta, IL receptor antagonist, and IL10 polymorphisms in psoriatic arthritis. Ann Rheum Dis. Jul. 2005;64(7):1093-4. [pmid: 15958769].
1924 Pelivani N, Hassan AS, Braathen LR, et al. Alopecia areata universalis elicited during treatment with adalimumab. Dermatology. 2008;216(4):320-3. [pmid: 18230980].
1925 Penn SK, Kao AH, Schott LL, et al. Hydroxychloroquine and glycemia in women with rheumatoid arthritis and systemic lupus erythematosus. J Rheumatol. Jun. 2010;37(6):1136-42. [pmid: 20436082].
1926 Perdriger A, Mariette X, Kuntz JL, et al. Safety of infliximab used in combination with leflunomide or azathioprine in daily clinical practice. J Rheumatol. May. 2006;33(5):865-9. [pmid: 16652418].
1927 Perera LC, Tymms KE, Wilson BJ, et al. Etanercept in severe active rheumatoid arthritis: first Australian experience. Intern Med J. Oct. 2006;36(10):625-31. [pmid: 16958637].
1928 Perez-De-Lis M, Akasbi M, Siso A, et al. Cardiovascular risk factors in primary Sjogren’s syndrome: a case-control study in 624 patients. Lupus. 2010;19(8):941-8. [pmid: 20581017].
1929 Perez-Ezquerra PR, de Barrio Fernandez M, de Castro Martinez FJ, et al. Delayed hypersensitivity to hydroxychloroquine manifested by two different types of cutaneous eruptions in the same patient. Allergol Immunopathol (Madr). Jul–Aug. 2006;34(4):174-5. [pmid: 16964632].
1930 Perez-Garcia C, Maymo J, Lisbona Perez MP, et al. Drug-induced systemic lupus erythematosus in ankylosing spondylitis associated with infliximab. Rheumatology (Oxford). Jan. 2006;45(1):114-6. [pmid: 16319096].
1931 Perez-Guijo VC, Cravo AR, Castro Mdel C, et al. Increased efficacy of infliximab associated with methotrexate in ankylosing spondylitis. Joint Bone Spine. May. 2007;74(3):254-8. [pmid: 17387031].
1932 Perhala RS, Wilke WS, Clough JD, et al. Local infectious complications following large joint replacement in rheumatoid arthritis patients treated with methotrexate versus those not treated with methotrexate. Arthritis Rheum. Feb. 1991;34(2):146-52. [pmid: 1994911].
1933 Peris P, Font J, Grau JM, et al. Calcitriol-mediated hypercalcaemia and increased interleukins in a patient with sarcoid myopathy. Clin Rheumatol. 1999;18(6):488-91. [pmid: 10638776].
1934 Perkins DJ, St Clair EW, Misukonis MA, et al. Reduction of NOS2 overexpression in rheumatoid arthritis patients treated with anti-tumor necrosis factor alpha monoclonal antibody (cA2). Arthritis Rheum. Dec. 1998;41(12):2205-10. [pmid: 9870877].
1935 Perlmutter A, Mittal A, Menter A. Tuberculosis and tumour necrosis factor-alpha inhibitor therapy: a report of three cases in patients with psoriasis. Comprehensive screening and therapeutic guidelines for clinicians. Br J Dermatol. Jan. 2009;160(1):8-15. [pmid: 19016693].
1936 Perotti LA, Peretti L, Lovino C, et al. Concentration of cortisol in the synovial fluid of patients with untreated rheumatoid arthritis. Relation to in vitro IL-8 production by synovial mononuclear cells. Ann N Y Acad Sci. Jun. 22. 1999;876:255-8. [pmid: 10415617].
1937 Perry MG, Kirwan JR, Jessop DS, et al. Overnight variations in cortisol, interleukin 6, tumour necrosis factor alpha and other cytokines in people with rheumatoid arthritis. Ann Rheum Dis. Jan. 2009;68(1):63-8. [pmid: 18375536].
1938 Pers JO, Saraux A, Pierre R, et al. Anti-TNF-alpha immunotherapy is associated with increased gingival inflammation without clinical attachment loss in subjects with rheumatoid arthritis. J Periodontol. Sep. 2008;79(9):1645-51. [pmid: 18771364].
1939 Peters MJ, Vis M, van Halm VP, et al. Changes in lipid profile during infliximab and corticosteroid treatment in rheumatoid arthritis. Ann Rheum Dis. Jul. 2007;66(7):958-61. [pmid: 17314120].
1940 Peterson JR, Hsu FC, Simkin PA, et al. Effect of tumour necrosis factor alpha antagonists on serum transaminases and viraemia in patients with rheumatoid arthritis and chronic hepatitis C infection. Ann Rheum Dis. Nov. 2003;62(11):1078-82. [pmid: 14583571].
1941 Peyrou J, Saxer-Sekulic N, Lerch R, et al. Fast progression of aortic stenosis in rheumatoid arthritis. Arch Cardiovasc Dis. Mar. 2009;102(3):251-2. [pmid: 19375680].
1942 Pfeil A, Lippold J, Eidner T, et al. Effects of leflunomide and methotrexate in rheumatoid arthritis detected by digital X-ray radiogrammetry and computer-aided joint space analysis. Rheumatol Int. Jan. 2009;29(3):287-95. [pmid: 18787830].
1943 Pflugfelder SC, Jones D, Ji Z, et al. Altered cytokine balance in the tear fluid and conjunctiva of patients with Sjogren’s syndrome keratoconjunctivitis sicca. Curr Eye Res. Sep. 1999;19(3):201-11. [pmid: 10487957].
1944 Pham TN, Rahman P, Richardson VJ. Divergent effects of infliximab and anakinra therapies on macrophage phenotype from patients with refractory rheumatoid arthritis. Int J Immunopathol Pharmacol. Apr–Jun. 2010;23(2):491-501. [pmid: 20646344].
1945 Phillips K, Aliprantis A, Coblyn J. Strategies for the prevention and treatment of osteoporosis in patients with rheumatoid arthritis. Drugs Aging. 2006;23(10):773-9. [pmid: 17067181].
1946 Phillips K, Weinblatt M. Granulomatous lung disease occurring during etanercept treatment. Arthritis Rheum. Aug. 15. 2005;53(4):618-20. [pmid: 16082636].
1947 Pickartz T, Pickartz H, Lochs H, et al. Overlap syndrome of autoimmune pancreatitis and cholangitis associated with secondary Sjogren’s syndrome. Eur J Gastroenterol Hepatol. Nov. 2004;16(12):1295-9. [pmid: 15618835].
1948 Pijpe J, Meijer JM, Bootsma H, et al. Clinical and histologic evidence of salivary gland restoration supports the efficacy of rituximab treatment in Sjogren’s syndrome. Arthritis Rheum. Nov. 2009;60(11):3251-6. [pmid: 19877054].
1949 Pijpe J, van Imhoff GW, Spijkervet FK, et al. Rituximab treatment in patients with primary Sjogren’s syndrome: an open-label phase II study. Arthritis Rheum. Sep. 2005;52(9):2740-50. [pmid: 16142737].
1950 Pijpe J, van Imhoff GW, Vissink A, et al. Changes in salivary gland immunohistology and function after rituximab monotherapy in a patient with Sjogren’s syndrome and associated MALT lymphoma. Ann Rheum Dis. Jun. 2005;64(6):958-60. [pmid: 15576414].
1951 Pileggi GS, de Souza CB, Ferriani VP. Safety and immunogenicity of varicella vaccine in patients with juvenile rheumatic diseases receiving methotrexate and corticosteroids. Arthritis Care Res (Hoboken). Jul. 2010;62(7):1034-9. [pmid: 20235203].
1952 Pillemer SR, Brennan MT, Sankar V, et al. Pilot clinical trial of dehydroepiandrosterone (DHEA) versus placebo for Sjogren’s syndrome. Arthritis Rheum. Aug. 15. 2004;51(4):601-4. [pmid: 15334433].
1953 Pincus T, Ferraccioli G, Sokka T, et al. Evidence from clinical trials and long-term observational studies that disease-modifying anti-rheumatic drugs slow radiographic progression in rheumatoid arthritis: updating a 1983 review. Rheumatology (Oxford). Dec. 2002;41(12):1346-56. [pmid: 12468813].
1954 Pincus T, Olsen NJ, Russell IJ, et al. Multicenter study of recombinant human erythropoietin in correction of anemia in rheumatoid arthritis. Am J Med. Aug. 1990;89(2):161-8. [pmid: 2200263].
1955 Pincus T, Swearingen CJ, Bergman M, et al. RAPID3 (Routine Assessment of Patient Index Data 3), a rheumatoid arthritis index without formal joint counts for routine care: proposed severity categories compared to disease activity score and clinical disease activity index categories. J Rheumatol. Nov. 2008;35(11):2136-47. [pmid: 18793006].
1956 Pisitkun P, Pattarowas C, Siriwongpairat P, et al. Reappraisal of cervical spine subluxation in Thai patients with rheumatoid arthritis. Clin Rheumatol. Feb. 2004;23(1):14-8. [pmid: 14749975].
1957 Pitsillides AA, Will RK, Bayliss MT, et al. Circulating and synovial fluid hyaluronan levels. Effects of intraarticular corticosteroid on the concentration and the rate of turnover. Arthritis Rheum. Jul. 1994;37(7):1030-8. [pmid: 8024612].
1958 Pittoni V, Bombardieri M, Spinelli FR, et al. Anti-tumour necrosis factor (TNF) alpha treatment of rheumatoid arthritis (infliximab) selectively down regulates the production of interleukin (IL) 18 but not of IL12 and IL13. Ann Rheum Dis. Aug. 2002;61(8):723-5. [pmid: 12117680].
1959 Pizzuti P, Liote F, Cerf-Payrastre I, et al. Hypersensitivity to glucocorticoids: does it exist?. Rev Rhum Engl Ed. Mar. 1996;63(3):223-6. [pmid: 8731243].
1960 Plant MJ, Borg AA, Dziedzic K, et al. Radiographic patterns and response to corticosteroid hip injection. Ann Rheum Dis. Aug. 1997;56(8):476-80. [pmid: 9306870].
1961 Podgorski MR, Goulding NJ, Hall ND, et al. Autoantibodies to lipocortin-1 are associated with impaired glucocorticoid responsiveness in rheumatoid arthritis. J Rheumatol. Nov. 1992;19(11):1668-71. [pmid: 1491384].
1962 Pollet SM, Vogt PJ, Leek JC. Serous peritonitis in adult Still’s syndrome. J Rheumatol. Jan. 1990;17(1):98-101. [pmid: 2313681].
1963 Polzer K, Baeten D, Soleiman A, et al. Tumour necrosis factor blockade increases lymphangiogenesis in murine and human arthritic joints. Ann Rheum Dis. Nov. 2008;67(11):1610-6. [pmid: 18174217].
1964 Pomerantz RG, Mody E, Husni ME, et al. Follow-up of psoriatic arthritis mutilans patients treated with anti-TNF-alpha therapy. J Drugs Dermatol. Apr. 2009;8(4):406-12. [pmid: 19363860].
1965 Pool AJ, Whipp BJ, Skasick AJ, et al. Serum cortisol reduction and abnormal prolactin and CD4+/CD8+ T-cell response as a result of controlled exercise in patients with rheumatoid arthritis and systemic lupus erythematosus despite unaltered muscle energetics. Rheumatology (Oxford). Jan. 2004;43(1):43-8. [pmid: 12867581].
1966 Poor G, Strand V. Efficacy and safety of leflunomide 10 mg versus 20 mg once daily in patients with active rheumatoid arthritis: multinational double-blind, randomized trial. Rheumatology (Oxford). Jun. 2004;43(6):744-9. [pmid: 15026583].
1967 Popa C, Leandro MJ, Cambridge G, et al. Repeated B lymphocyte depletion with rituximab in rheumatoid arthritis over 7 yrs. Rheumatology (Oxford). Apr. 2007;46(4):626-30. [pmid: 17189244].
1968 Popa C, Netea MG, de Graaf J, et al. Circulating leptin and adiponectin concentrations during tumor necrosis factor blockade in patients with active rheumatoid arthritis. J Rheumatol. Apr. 2009;36(4):724-30. [pmid: 19273452].
1969 Popa C, Netea MG, Radstake TR, et al. Markers of inflammation are negatively correlated with serum leptin in rheumatoid arthritis. Ann Rheum Dis. Aug. 2005;64(8):1195-8. [pmid: 15731289].
1970 Popa C, van den Hoogen FH, Radstake TR, et al. Modulation of lipoprotein plasma concentrations during long-term anti-TNF therapy in patients with active rheumatoid arthritis. Ann Rheum Dis. Nov. 2007;66(11):1503-7. [pmid: 17472994].
1971 Popa C, van Tits LJ, Barrera P, et al. Anti-inflammatory therapy with tumour necrosis factor alpha inhibitors improves high-density lipoprotein cholesterol antioxidative capacity in rheumatoid arthritis patients. Ann Rheum Dis. Jun. 2009;68(6):868-72. [pmid: 18635596].
1972 Pope RM, Kniker WT, Talal N, et al. Delayed type hypersensitivity in patients with rheumatoid arthritis. J Rheumatol. Jan. 1993;20(1):17-20. [pmid: 8441153].
1973 Porola P, Laine M, Virtanen I, et al. Androgens and integrins in salivary glands in Sjogren’s syndrome. J Rheumatol. Jun. 2010;37(6):1181-7. [pmid: 20436081].
1974 Porola P, Virkki L, Przybyla BD, et al. Androgen deficiency and defective intracrine processing of dehydroepiandrosterone in salivary glands in Sjogren’s syndrome. J Rheumatol. Nov. 2008;35(11):2229-35. [pmid: 18843777].
1975 Portales P, Fabre S, Vincent T, et al. Peripheral blood T4 cell surface CCR5 density as a marker of activity in rheumatoid arthritis treated with anti-CD20 monoclonal antibody. Immunology. Sep. 2009;128(1 Suppl):e738-45. [pmid: 19740335].
1976 Porterfield LM. Why has this patient developed sepsis?. Rn. Aug. 1999;62(8):89. [pmid: 10481735].
1977 Porterfield LM. Rheumatoid arthritis patient’s respiratory distress. Rn. Jan. 2009;72(1):21. [pmid: 19260415].
1978 Posten W, Swan J. Recurrence of alopecia areata in a patient receiving etanercept injections. Arch Dermatol. Jun. 2005;141(6):759-60. [pmid: 15967923].
1979 Potter C, Cordell HJ, Barton A, et al. Association between anti-tumour necrosis factor treatment response and genetic variants within the TLR and NF{kappa}B signalling pathways. Ann Rheum Dis. Jul. 2010;69(7):1315-20. [pmid: 20448286].
1980 Potter C, Hyrich KL, Tracey A, et al. Association of rheumatoid factor and anti-cyclic citrullinated peptide positivity, but not carriage of shared epitope or PTPN22 susceptibility variants, with anti-tumour necrosis factor response in rheumatoid arthritis. Ann Rheum Dis. 2009;68(1):69-74. [pmid: 18375541].
1981 Pou MA, Diaz-Torne C, Vidal S, et al. Development of autoimmune diseases after vaccination. J Clin Rheumatol. Aug. 2008;14(4):243-4. [pmid: 18766128].
1982 Price-Forbes AN, Callaghan R, Allen ME, et al. A regional audit of the use of COX-2 selective non-steroidal anti-inflammatory drugs (NSAIDs) in rheumatology clinics in the West Midlands, in relation to NICE guidelines. Rheumatology (Oxford). Jul. 2005;44(7):921-4. [pmid: 15827035].
1983 Priori R, Ceccarelli F, Barone F, et al. Clinical, biological and sonographic response to IL-1 blockade in adult-onset Still’s disease. Clin Exp Rheumatol. Sep–Oct. 2008;26(5):933-7. [pmid: 19032833].
1984 Probst C, Pongratz G, Capellino S, et al. Cryptococcosis mimicking cutaneous cellulitis in a patient suffering from rheumatoid arthritis: a case report. BMC Infect Dis. 2010;10:239. [pmid: 20699010].
1985 Probst LE, Holland EJ. Intraocular lens implantation in patients with juvenile rheumatoid arthritis. Am J Ophthalmol. Aug. 1996;122(2):161-70. [pmid: 8694084].
1986 Proudman SM, Keen HI, Stamp LK, et al. Response-driven combination therapy with conventional disease-modifying antirheumatic drugs can achieve high response rates in early rheumatoid arthritis with minimal glucocorticoid and nonsteroidal anti-inflammatory drug use. Semin Arthritis Rheum. Oct. 2007;37(2):99-111. [pmid: 17391739].
1987 Provenzano G, Termini A, Le Moli C, et al. Efficacy of infliximab in psoriatic arthritis resistant to treatment with disease modifying antirheumatic drugs: an open pilot study. Ann Rheum Dis. Jul. 2003;62(7):680-1. [pmid: 12810436].
1988 Puechal X, Miceli-Richard C, Mejjad O, et al. Anti-tumour necrosis factor treatment in patients with refractory systemic vasculitis associated with rheumatoid arthritis. Ann Rheum Dis. Jun. 2008;67(6):880-4. [pmid: 18037625].
1989 Pullerits R, Bokarewa M, Dahlberg L, et al. Synovial fluid expression of autoantibodies specific for RAGE relates to less erosive course of rheumatoid arthritis. Rheumatology (Oxford). Aug. 2007;46(8):1367-71. [pmid: 17569744].
1990 Pulsatelli L, Dolzani P, Silvestri T, et al. Synovial expression of vasoactive intestinal peptide in polymyalgia rheumatica. Clin Exp Rheumatol. Sep–Oct. 2006;24(5):562-6. [pmid: 17181926].
1991 Pun YL, Barraclough DR, Muirden KD. Leg ulcers in rheumatoid arthritis. Med J Aust. Nov. 19. 1990;153(10):585-7. [pmid: 2233432].
1992 Puri PK, Lountzis NI, Tyler W, et al. Hydroxychloroquine-induced hyperpigmentation: the staining pattern. J Cutan Pathol. Dec. 2008;35(12):1134-7. [pmid: 18727667].
1993 Pyrpasopoulou A, Douma S, Triantafyllou A, et al. Response to rituximab and timeframe to relapse in rheumatoid arthritis patients: association with B-cell markers. Mol Diagn Ther. Feb. 1. 2010;14(1):43-8. [pmid: 20121289].
1994 Quallich LG, Greenson J, Haftel HM, et al. Is it Crohn’s disease? A severe systemic granulomatous reaction to sulfasalazine in patient with rheumatoid arthritis. BMC Gastroenterol. 2001;1:8. [pmid: 11570976].
1995 Quartier P, Taupin P, Bourdeaut F, et al. Efficacy of etanercept for the treatment of juvenile idiopathic arthritis according to the onset type. Arthritis Rheum. Apr. 2003;48(4):1093-101. [pmid: 12687553].
1996 Quartuccio L, De Re V, Fabris M, et al. Atypical lymphoproliferation progressing into B-cell lymphoma in rheumatoid arthritis treated with different biological agents: clinical course and molecular characterization. Haematologica. May. 2006;91(5):691-4. [pmid: 16670074].
1997 Quartuccio L, Maset M, De Vita S. Efficacy of abatacept in a refractory case of adult-onset Still’s disease. Clin Exp Rheumatol. Mar–Apr. 2010;28(2):265-7. [pmid: 20483052].
1998 Queiro R, Torre JC, Belzunegui J, et al. Clinical features and predictive factors in psoriatic arthritis-related uveitis. Semin Arthritis Rheum. Feb. 2002;31(4):264-70. [pmid: 11836659].
1999 Quinn MA, Conaghan PG, O’Connor PJ, et al. Very early treatment with infliximab in addition to methotrexate in early, poor-prognosis rheumatoid arthritis reduces magnetic resonance imaging evidence of synovitis and damage, with sustained benefit after infliximab withdrawal: results from a twelve-month randomized, double-blind, placebo-controlled trial. Arthritis Rheum. Jan. 2005;52(1):27-35. [pmid: 15641102].
2000 Rachapalli S, O’Daunt S. Septic arthritis due to Listeria monocytogenes in a patient receiving etanercept. Arthritis Rheum. Mar. 2005;52(3):987. [pmid: 15751076].
2001 Racunica T, Cassidy D, Cicuttini F, et al. Trouble with tumor necrosis factor alpha inhibitors, not just tuberculosis. Arthritis Care Res (Hoboken). 2010;62(6):770-4. [pmid: 20535787].
2002 Radikova Z, Rovensky J, Vlcek M, et al. Adrenocortical response to low-dose ACTH test in female patients with rheumatoid arthritis. Ann N Y Acad Sci. Dec. 2008;1148:562-6. [pmid: 19120158].
2003 Radovits BJ, Kievit W, Laan RF. Tumour necrosis factor-alpha antagonists in the management of rheumatoid arthritis in the elderly: a review of their efficacy and safety. Drugs Aging. 2009;26(8):647-64. [pmid: 19685931].
2004 Radstake TR, Fransen J, Toonen EJ, et al. Macrophage migration inhibitory factor polymorphisms do not predict therapeutic response to glucocorticoids or to tumour necrosis factor alpha-neutralising treatments in rheumatoid arthritis. Ann Rheum Dis. Nov. 2007;66(11):1525-30. [pmid: 17456524].
2005 Raghavendra S, Nair MD, Chemmanam T, et al. Disseminated necrotizing leukoencephalopathy following low-dose oral methotrexate. Eur J Neurol. Mar. 2007;14(3):309-14. [pmid: 17355553].
2006 Rahman MU, Strusberg I, Geusens P, et al. Double-blinded infliximab dose escalation in patients with rheumatoid arthritis. Ann Rheum Dis. Sep. 2007;66(9):1233-8. [pmid: 17392352].
2007 Rahman N, Healy C, Flint SR, et al. Cautionary note: a possible association between oral squamous cell carcinoma and tumor necrosis factor antagonists; need for oral screening. J Clin Rheumatol. Jun. 2010;16(4):197-9. [pmid: 20511984].
2008 Rahmlow M, Shuster EA, Dominik J, et al. Leflunomide-associated progressive multifocal leukoencephalopathy. Arch Neurol. Nov. 2008;65(11):1538-9. [pmid: 19001176].
2009 Rajagopala S, Singh N, Gupta K, et al. Pulmonary amyloidosis in Sjogren’s syndrome: a case report and systematic review of the literature. Respirology. Jul. 2010;15(5):860-6. [pmid: 20546191].
2010 Rajakulendran S, Deighton C. Delayed multiple injection site reaction in a rheumatoid arthritis patient treated with etanercept. Rheumatology (Oxford). Dec. 2004;43(12):1588-9. [pmid: 15564639].
2011 Rajakulendran S, Deighton C. Adverse dermatological reactions in rheumatoid arthritis patients treated with etanercept, an anti-TNFalpha drug. Curr Drug Saf. Aug. 2006;1(3):259-64. [pmid: 18690936].
2012 Rajakulendran S, Gadsby K, Deighton C. Rheumatoid arthritis, alcohol, leflunomide and methotrexate. Can changes to the BSR guidelines for leflunomide and methotrexate on alcohol consumption be justified?. Musculoskeletal Care. Dec. 2008;6(4):233-45. [pmid: 18702106].
2013 Rajaraman RT, Kimura Y, Li S, et al. Retrospective case review of pediatric patients with uveitis treated with infliximab. Ophthalmology. Feb. 2006;113(2):308-14. [pmid: 16406545].
2014 Ramirez-Hernandez M, Marras C, Martinez-Escribano JA. Infliximab-induced vitiligo. Dermatology. 2005;210(1):79-80. [pmid: 15604556].
2015 Ramos-Casals M, Brito-Zeron P, Siso A, et al. High prevalence of serum metabolic alterations in primary Sjogren’s syndrome: influence on clinical and immunological expression. J Rheumatol. Apr. 2007;34(4):754-61. [pmid: 17309127].
2016 Ramos-Casals M, Garcia-Hernandez FJ, de Ramon E, et al. Off-label use of rituximab in 196 patients with severe, refractory systemic autoimmune diseases. Clin Exp Rheumatol. Jul–Aug. 2010;28(4):468-76. [pmid: 20525449].
2017 Ramos-Casals M, Lopez-Guillermo A, Brito-Zeron P, et al. Treatment of B-cell lymphoma with rituximab in two patients with Sjogren’s syndrome associated with hepatitis C virus infection. Lupus. 2004;13(12):969-71. [pmid: 15645755].
2018 Ranganathan P. Infliximab-induced scleredema in a patient with rheumatoid arthritis. J Clin Rheumatol. Dec. 2005;11(6):319-22. [pmid: 16371802].
2019 Rantalaiho V, Korpela M, Hannonen P, et al. The good initial response to therapy with a combination of traditional disease-modifying antirheumatic drugs is sustained over time: the eleven-year results of the Finnish rheumatoid arthritis combination therapy trial. Arthritis Rheum. May. 2009;60(5):1222-31. [pmid: 19404945].
2020 Raterman HG, Hoving JL, Nurmohamed MT, et al. Work ability: a new outcome measure in rheumatoid arthritis?. Scand J Rheumatol. Mar. 2010;39(2):127-31. [pmid: 20059369].
2021 Rau R, Sander O, van Riel P, et al. Intravenous human recombinant tumor necrosis factor receptor p55-Fc IgG1 fusion protein Ro 45–2081 (lenercept): a double blind, placebo controlled dose-finding study in rheumatoid arthritis. J Rheumatol. Apr. 2003;30(4):680-90. [pmid: 12672184].
2022 Rau R, Sander O, Wassenberg S. Erosion healing in rheumatoid arthritis after anakinra treatment. Ann Rheum Dis. Jul. 2003;62(7):671-3. [pmid: 12810433].
2023 Rau R, Simianer S, van Riel PL, et al. Rapid alleviation of signs and symptoms of rheumatoid arthritis with intravenous or subcutaneous administration of adalimumab in combination with methotrexate. Scand J Rheumatol. 2004;33(3):145-53. [pmid: 15228184].
2024 Ravindran J, Shenker N, Bhalla AK, et al. Case report: Response in proteinuria due to AA amyloidosis but not Felty’s syndrome in a patient with rheumatoid arthritis treated with TNF-alpha blockade. Rheumatology (Oxford). May. 2004;43(5):669-72. [pmid: 15103032].
2025 Raza N, Hameed A, Ali MK. Detection of subclinical joint involvement in psoriasis with bone scintigraphy and its response to oral methotrexate. Clin Exp Dermatol. Jan. 2008;33(1):70-3. [pmid: 18076689].
2026 Reddy AR, Backhouse OC. Does etanercept induce uveitis?. Br J Ophthalmol. Jul. 2003;87(7):925. [pmid: 12812909].
2027 Reed A, Haugen M, Pachman LM, et al. Abnormalities in serum osteocalcin values in children with chronic rheumatic diseases. J Pediatr. Apr. 1990;116(4):574-80. [pmid: 2319404].
2028 Regula CG, Hennessy J, Clarke LE, et al. Interstitial granulomatous drug reaction to anakinra. J Am Acad Dermatol. Aug. 2008;59(2 Suppl 1):S25-7. [pmid: 18625373].
2029 Rehnberg M, Amu S, Tarkowski A, et al. Short- and long-term effects of anti-CD20 treatment on B cell ontogeny in bone marrow of patients with rheumatoid arthritis. Arthritis Res Ther. 2009;11(4):R123. [pmid: 19686595].
2030 Rehnberg M, Brisslert M, Amu S, et al. Vaccination response to protein and carbohydrate antigens in patients with rheumatoid arthritis after rituximab treatment. Arthritis Res Ther. 2010;12(3):R111. [pmid: 20529331].
2031 Reitman CA, Lidsky MD, Heggeness MH. Neurologic and morphologic features of dural ectasia in ankylosing spondylitis and rheumatoid arthritis: a case report. Am J Orthop. Nov. 2006;35(11):530-1. [pmid: 17152976].
2032 Rejon E, Gimenez MD, Mayordomo L, et al. Therapeutic efficacy and safety of multiple intravenous infusions of infliximab in refractory ankylosing spondylitis patients with axial involvement. Scand J Rheumatol. 2004;33(5):323-6. [pmid: 15513681].
2033 Ren H, Wang WM, Chen XN, et al. Renal involvement and followup of 130 patients with primary Sjogren’s syndrome. J Rheumatol. Feb. 2008;35(2):278-84. [pmid: 18085734].
2034 Renato GM. B cell depletion in early rheumatoid arthritis: a new concept in therapeutics. Ann N Y Acad Sci. Sep. 2009;1173:729-35. [pmid: 19758222].
2035 Resmini E, Farkas C, Murillo B, et al. Body composition after endogenous (Cushing’s syndrome) and exogenous (rheumatoid arthritis) exposure to glucocorticoids. Horm Metab Res. Jul. 2010;42(8):613-8. [pmid: 20514604].
2036 Ribbens C, Andre B, Marcelis S, et al. Rheumatoid hand joint synovitis: gray-scale and power Doppler US quantifications following anti-tumor necrosis factor-alpha treatment: pilot study. Radiology. Nov. 2003;229(2):562-9. [pmid: 12970463].
2037 Ribbens C, Martin y Porras M, Franchimont N, et al. Increased matrix metalloproteinase-3 serum levels in rheumatic diseases: relationship with synovitis and steroid treatment. Ann Rheum Dis. Feb. 2002;61(2):161-6. [pmid: 11796404].
2038 Richards BL, Spies J, McGill N, et al. Effect of leflunomide on the peripheral nerves in rheumatoid arthritis. Intern Med J. Feb. 2007;37(2):101-7. [pmid: 17229252].
2039 Richette P, Dieude P, Damiano J, et al. Sensory neuropathy revealing necrotizing vasculitis during infliximab therapy for rheumatoid arthritis. J Rheumatol. Oct. 2004;31(10):2079-81. [pmid: 15468380].
2040 Richette P, Francois M, Vicaut E, et al. A high interleukin 1 receptor antagonist/IL-1beta ratio occurs naturally in knee osteoarthritis. J Rheumatol. Aug. 2008;35(8):1650-4. [pmid: 18597398].
2041 Richez C, Blanco P, Lagueny A, et al. Neuropathy resembling CIDP in patients receiving tumor necrosis factor-alpha blockers. Neurology. Apr. 26. 2005;64(8):1468-70. [pmid: 15851749].
2042 Richez C, Dumoulin C, Schaeverbeke T. Infliximab induced chilblain lupus in a patient with rheumatoid arthritis. J Rheumatol. Apr. 2005;32(4):760-1. [pmid: 15801042].
2043 Richter C, Wanke L, Steinmetz J, et al. Mononeuritis secondary to rheumatoid arthritis responds to etanercept. Rheumatology (Oxford). Dec. 2000;39(12):1436-7. [pmid: 11136899].
2044 Richter J, Benson V, Grobarova V, et al. CD161 receptor participates in both impairing NK cell cytotoxicity and the response to glycans and vimentin in patients with rheumatoid arthritis. Clin Immunol. Jul. 2010;136(1):139-47. [pmid: 20359956].
2045 Riepl B, Grassel S, Wiest R, et al. Tumor necrosis factor and norepinephrine lower the levels of human neutrophil peptides 1–3 secretion by mixed synovial tissue cultures in osteoarthritis and rheumatoid arthritis. Arthritis Res Ther. 2010;12(3):R110. [pmid: 20525314].
2046 Rihl M, Kruithof E, Barthel C, et al. Involvement of neurotrophins and their receptors in spondyloarthritis synovitis: relation to inflammation and response to treatment. Ann Rheum Dis. Nov. 2005;64(11):1542-9. [pmid: 15817657].
2047 Rihl M, Ulbricht K, Schmidt RE, et al. Treatment of sicca symptoms with hydroxychloroquine in patients with Sjogren’s syndrome. Rheumatology (Oxford). Jul. 2009;48(7):796-9. [pmid: 19433433].
2048 Riise T, Jacobsen BK, Gran JT. Changes in therapy of rheumatoid arthritis during the period 1979 to 1996. Scand J Rheumatol. 2001;30(4):199-202. [pmid: 11578013].
2049 Rijkeboer A, Voskuyl A, Van Agtmael M. Fatal Salmonella enteritidis septicaemia in a rheumatoid arthritis patient treated with a TNF-alpha antagonist. Scand J Infect Dis. 2007;39(1):80-3. [pmid: 17366020].
2050 Rimar D, Rozenbaum M, Slobodin G, et al. Etanercept related pseudo-empyema in rheumatoid arthritis. Clin Rheumatol. 2010;29(5):547-9. [pmid: 20127398].
2051 Rinaldi F, Provenzano G, Termini A, et al. Long term infliximab treatment for severe psoriatic arthritis: evidence of sustained clinical and radiographic response. Ann Rheum Dis. Sep. 2005;64(9):1375-6. [pmid: 16100346].
2052 Rindfleisch JA, Muller D. Diagnosis and management of rheumatoid arthritis. Am Fam Physician. Sep. 15. 2005;72(6):1037-47. [pmid: 16190501].
2053 Rivers JK, Podgorski MR, Goulding NJ, et al. The presence of autoantibody to recombinant lipocortin-I in patients with psoriasis and psoriatic arthritis. Br J Dermatol. Nov. 1990;123(5):569-72. [pmid: 2147389].
2054 Rizzo R, Rubini M, Govoni M, et al. HLA-G 14-bp polymorphism regulates the methotrexate response in rheumatoid arthritis. Pharmacogenet Genomics. Sep. 2006;16(9):615-23. [pmid: 16906016].
2055 Rodrigues K, Neves FS, Stoeterau KB, et al. Pulmonary amyloidosis in Sjogren’s syndrome: a rare diagnosis for nodular lung lesions. Int J Rheum Dis. Dec. 2009;12(4):358-60. [pmid: 20374376].
2056 Rodriguez-Escalera C, Belzunegui J, Lopez-Dominguez L, et al. Multifocal motor neuropathy with conduction block in a patient with rheumatoid arthritis on infliximab therapy. Rheumatology (Oxford). Jan. 2005;44(1):132-3. [pmid: 15611308].
2057 Rodriguez-Padilla JA, Hedges TR 3rd, Monson B, et al. High-speed ultra-high-resolution optical coherence tomography findings in hydroxychloroquine retinopathy. Arch Ophthalmol. Jun. 2007;125(6):775-80. [pmid: 17562988].
2058 Rokhsar C, Rabhan N, Cohen SR. Etanercept monotherapy for a patient with psoriasis, psoriatic arthritis, and concomitant hepatitis C infection. J Am Acad Dermatol. Feb. 2006;54(2):361-2. [pmid: 16443079].
2059 Roll P, Dorner T, Tony HP. Anti-CD20 therapy in patients with rheumatoid arthritis: predictors of response and B cell subset regeneration after repeated treatment. Arthritis Rheum. Jun. 2008;58(6):1566-75. [pmid: 18512772].
2060 Roll P, Palanichamy A, Kneitz C, et al. Regeneration of B cell subsets after transient B cell depletion using anti-CD20 antibodies in rheumatoid arthritis. Arthritis Rheum. Aug. 2006;54(8):2377-86. [pmid: 16869000].
2061 Rooryck C, Barnetche T, Richez C, et al. Influence of FCGR3A-V212F and TNFRSF1B-M196R genotypes in patients with rheumatoid arthritis treated with infliximab therapy. Clin Exp Rheumatol. Mar–Apr. 2008;26(2):340-2. [pmid: 18565259].
2062 Roos JC, Ostor AJ. Orbital cellulitis in a patient receiving infliximab for Ankylosing spondylitis. Am J Ophthalmol. Apr. 2006;141(4):767-9. [pmid: 16564827].
2063 Rosenvinge A, Krogh-Madsen R, Baslund B, et al. Insulin resistance in patients with rheumatoid arthritis: effect of anti-TNFalpha therapy. Scand J Rheumatol. Mar–Apr. 2007;36(2):91-6. [pmid: 17476613].
2064 Rosmarin D, Bush M, Scheinman PL. Patch testing a patient with allergic contact hand dermatitis who is taking infliximab. J Am Acad Dermatol. Jul. 2008;59(1):145-7. [pmid: 18468722].
2065 Roth EB, Stenberg P, Book C, et al. Antibodies against transglutaminases, peptidylarginine deiminase and citrulline in rheumatoid arthritis--new pathways to epitope spreading. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):12-8. [pmid: 16539813].
2066 Roth S. Effects of Prosorba column apheresis in patients with chronic refractory rheumatoid arthritis. J Rheumatol. Nov. 2004;31(11):2131-5. [pmid: 15517623].
2067 Roubenoff R, Roubenoff RA, Ward LM, et al. Catabolic effects of high-dose corticosteroids persist despite therapeutic benefit in rheumatoid arthritis. Am J Clin Nutr. Dec. 1990;52(6):1113-7. [pmid: 2239788].
2068 Roux CH, Brocq O, Albert CBV, et al. Cutaneous vasculitis and glomerulonephritis in a patient taking the anti-TNF alpha agent etanercept for rheumatoid arthritis. Joint Bone Spine. Sep. 2004;71(5):444-5. [pmid: 15474402].
2069 Roux N, Flipo RM, Cortet B, et al. Pneumocystis carinii pneumonia in rheumatoid arthritis patients treated with methotrexate. A report of two cases. Rev Rhum Engl Ed. Jun. 1996;63(6):453-6. [pmid: 8817757].
2070 Roux-Lombard P, Eberhardt K, Saxne T, et al. Cytokines, metalloproteinases, their inhibitors and cartilage oligomeric matrix protein: relationship to radiological progression and inflammation in early rheumatoid arthritis. A prospective 5-year study. Rheumatology (Oxford). May. 2001;40(5):544-51. [pmid: 11371663].
2071 Rovensky J, Bakosova J, Koska J, et al. Somatotropic, lactotropic and adrenocortical responses to insulin-induced hypoglycemia in patients with rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2002;966:263-70. [pmid: 12114282].
2072 Rovensky J, Bakosova J, Payer J, et al. Increased demand for steroid therapy in hyperprolactinemic patients with rheumatoid arthritis. Int J Tissue React. 2001;23(4):145-9. [pmid: 11771778].
2073 Rovensky J, Imrich R, Koska J, et al. Cortisol elimination from plasma in premenopausal women with rheumatoid arthritis. Ann Rheum Dis. Jul. 2003;62(7):674-6. [pmid: 12810434].
2074 Rovensky J, Radikova Z, Imrich R, et al. Gonadal and adrenal steroid hormones in plasma and synovial fluid of patients with rheumatoid arthritis. Endocr Regul. Dec. 2004;38(4):143-9. [pmid: 15841793].
2075 Rovensky J, Simorova E, Radikova Z, et al. Comparison of hormone transfer to pleural and synovial exudates. Endocr Regul. Jun. 2006;40(2):29-36. [pmid: 17100544].
2076 Rovere Querini P, Vecellio M, Sabbadini MG, et al. Miliary tuberculosis after biological therapy for rheumatoid arthritis. Rheumatology (Oxford). Feb. 2002;41(2):231. [pmid: 11886978].
2077 Roy A, Mould DR, Wang XF, et al. Modeling and simulation of abatacept exposure and interleukin-6 response in support of recommended doses for rheumatoid arthritis. J Clin Pharmacol. Nov. 2007;47(11):1408-20. [pmid: 17962428].
2078 Roy DB, Conte ET, Cohen DJ. The treatment of pyoderma gangrenosum using etanercept. J Am Acad Dermatol. Mar. 2006;54(3 Suppl 2):S128-34. [pmid: 16488326].
2079 Rozenbaum M, Boulman N, Slobodin G, et al. Polyarthritis flare complicating rheumatoid arthritis infliximab therapy: a paradoxic adverse reaction. J Clin Rheumatol. Dec. 2006;12(6):269-71. [pmid: 17149054].
2080 Rozenbaum M, Rosner I, Portnoy E. Remission of Behcet’s syndrome with TNFalpha blocking treatment. Ann Rheum Dis. Mar. 2002;61(3):283-4. [pmid: 11830448].
2081 Ruderman EM, Pope RM. The evolving clinical profile of abatacept (CTLA4-Ig): a novel co-stimulatory modulator for the treatment of rheumatoid arthritis. Arthritis Res Ther. 2005;7(Suppl 2):S21-5. [pmid: 15833145].
2082 Rudwaleit M, Baraliakos X, Listing J, et al. Magnetic resonance imaging of the spine and the sacroiliac joints in ankylosing spondylitis and undifferentiated spondyloarthritis during treatment with etanercept. Ann Rheum Dis. Sep. 2005;64(9):1305-10. [pmid: 15778243].
2083 Rudwaleit M, Listing J, Brandt J, et al. Prediction of a major clinical response (BASDAI 50) to tumour necrosis factor alpha blockers in ankylosing spondylitis. Ann Rheum Dis. Jun. 2004;63(6):665-70. [pmid: 15037444].
2084 Rudwaleit M, Van den Bosch F, Kron M, et al. Effectiveness and safety of adalimumab in patients with ankylosing spondylitis or psoriatic arthritis and history of anti-tumor necrosis factor therapy. Arthritis Res Ther. 2010;12(3):R117. [pmid: 20553600].
2085 Ruppert M, De Clerck L, van Offel J, et al. Intestinal necrosis in a patient with rheumatoid arthritis receiving anti-TNF treatment. Acta Chir Belg. Mar–Apr. 2006;106(2):225-7. [pmid: 16761484].
2086 Russell A, Haraoui B, Keystone E, et al. Current and emerging therapies for rheumatoid arthritis, with a focus on infliximab: clinical impact on joint damage and cost of care in canada. Clin Ther. Nov. 2001;23(11):1824-38. discussion 791. [pmid: 11768835].
2087 Russell E, Zeihen M, Wergin S, et al. Patients receiving etanercept may develop antibodies that interfere with monoclonal antibody laboratory assays. Arthritis Rheum. Apr. 2000;43(4):944. [pmid: 10765944].
2088 Ruyssen-Witrand A, Gossec L, Salliot C, et al. Complication rates of 127 surgical procedures performed in rheumatic patients receiving tumor necrosis factor alpha blockers. Clin Exp Rheumatol. May–Jun. 2007;25(3):430-6. [pmid: 17631740].
2089 Saad AA, Ashcroft DM, Watson KD, et al. Improvements in quality of life and functional status in patients with psoriatic arthritis receiving anti-tumor necrosis factor therapies. Arthritis Care Res (Hoboken). 2010;62(3):345-53. [pmid: 20391480].
2090 Saad AA, Symmons DP, Noyce PR, et al. Risks and benefits of tumor necrosis factor-alpha inhibitors in the management of psoriatic arthritis: systematic review and metaanalysis of randomized controlled trials. J Rheumatol. May. 2008;35(5):883-90. [pmid: 18381787].
2091 Saadeh C, Saadeh C. Asthma remission in a patient with rheumatoid arthritis while on antiangiogenesis therapy during a rheumatoid arthritis trial demonstrated by forced oscillation and spirometry. J Asthma. May. 2007;44(4):281-3. [pmid: 17530526].
2092 Saag KG, Koehnke R, Caldwell JR, et al. Low dose long-term corticosteroid therapy in rheumatoid arthritis: an analysis of serious adverse events. Am J Med. Feb. 1994;96(2):115-23. [pmid: 8109596].
2093 Saario R, Sonninen P, Mottonen T, et al. Bone mineral density of the lumbar spine in patients with advanced rheumatoid arthritis. Influence of functional capacity and corticosteroid use. Scand J Rheumatol. 1999;28(6):363-7. [pmid: 10665742].
2094 Saba NS, Kosseifi SG, Charaf EA, et al. Adalimumab-induced acute myelogenic leukemia. South Med J. Dec. 2008;101(12):1261-2. [pmid: 19005432].
2095 Saber TP, Ng CT, Renard G, et al. Remission in psoriatic arthritis: is it possible and how can it be predicted?. Arthritis Res Ther. 2010;12(3):R94. [pmid: 20482783].
2096 Saeki Y, Ohshima S, Ishida T, et al. Remission of the renal involvement in a patient with primary Sjogren’s syndrome (SS) after pulse high-dose corticosteroid infusion therapy. Clin Rheumatol. 2001;20(3):225-8. [pmid: 11434479].
2097 Saeki Y, Ohshima S, Mima T, et al. Suboptimal clinical response to anti-tumor necrosis factor alpha (TNFalpha) antibody therapy in a patient with severe rheumatoid arthritis and lymphadenopathy. Scand J Rheumatol. 1998;27(4):303-5. [pmid: 9751473].
2098 Sahin M, Keskin M, Tunc SE, et al. Kaposi’s sarcoma complicating rheumatoid arthritis treated with corticosteroid Kaposi’s sarcoma and rheumatoid arthritis. Saudi Med J. Jul. 2007;28(7):1133-4. [pmid: 17603728].
2099 Saiki O, Takao R, Naruse Y, et al. Infliximab but not methotrexate induces extra-high levels of VLDL-triglyceride in patients with rheumatoid arthritis. J Rheumatol. Oct. 2007;34(10):1997-2004. [pmid: 17787045].
2100 Saint Marcoux B, De Bandt M. Vasculitides induced by TNFalpha antagonists: a study in 39 patients in France. Joint Bone Spine. Dec. 2006;73(6):710-3. [pmid: 17127088].
2101 Saito S, Momohara S, Taniguchi A, et al. The intra-articular efficacy of hyaluronate injections in the treatment of rheumatoid arthritis. Mod Rheumatol. 2009;19(6):643-51. [pmid: 19649562].
2102 Sakai K, Hamaguchi T, Yamada M. Multiple cranial nerve enhancement on MRI in primary Sjogren’s syndrome. Intern Med. 2010;49(9):857-9. [pmid: 20453408].
2103 Sakai Y, Sakai S, Otsuka T, et al. Efficacy of high-throughput leukocytapheresis for rheumatoid arthritis with a reduced response to infliximab. Ther Apher Dial. Jun. 2009;13(3):179-85. [pmid: 19527463].
2104 Sakamoto O, Saita N, Ando M, et al. Two cases of Sjogren’s syndrome with multiple bullae. Intern Med. Feb. 2002;41(2):124-8. [pmid: 11868599].
2105 Sakaura H, Hosono N, Mukai Y, et al. Paraparesis due to exacerbation of preexisting spinal pseudoarthrosis following infliximab therapy for advanced ankylosing spondylitis. Spine J. May–Jun. 2006;6(3):325-9. [pmid: 16651229].
2106 Sakellariou GT, Vounotrypidis P, Berberidis C. Infliximab treatment in two patients with psoriatic arthritis and secondary IgA nephropathy. Clin Rheumatol. Jul. 2007;26(7):1132-3. [pmid: 16924391].
2107 Salamon L, Salamon T, Morovic-Vergles J. Thrombotic microangiopathy in adult-onset Still’s disease: case report and review of the literature. Wien Klin Wochenschr. 2009;121(17–18):583-8. [pmid: 19890748].
2108 Saleem B, Brown AK, Keen H, et al. Disease remission state in patients treated with the combination of tumor necrosis factor blockade and methotrexate or with disease-modifying antirheumatic drugs: A clinical and imaging comparative study. Arthritis Rheum. 2009;60(7):1915-22. [pmid: 19565512].
2109 Saleem B, Mackie S, Quinn M, et al. Does the use of tumour necrosis factor antagonist therapy in poor prognosis, undifferentiated arthritis prevent progression to rheumatoid arthritis?. Ann Rheum Dis. Aug. 2008;67(8):1178-80. [pmid: 18234715].
2110 Saleem G, Li SC, MacPherson BR, et al. Hepatitis with interface inflammation and IgG, IgM, and IgA anti-double-stranded DNA antibodies following infliximab therapy: comment on the article by Charles et al. Arthritis Rheum. Aug. 2001;44(8):1966-8. [pmid: 11508453].
2111 Salli A, Sahin N, Paksoy Y, et al. Treatment of periodontoid pannus with infliximab in a patient with rheumatoid arthritis. J Clin Rheumatol. Aug. 2009;15(5):250-1. [pmid: 19590438].
2112 Salliot C, Dougados M, Gossec L. Risk of serious infections during rituximab, abatacept and anakinra treatments for rheumatoid arthritis: meta-analyses of randomised placebo-controlled trials. Ann Rheum Dis. 2009;68(1):25-32. [pmid: 18203761].
2113 Salliot C, van der Heijde D. Long-term safety of methotrexate monotherapy in patients with rheumatoid arthritis: a systematic literature research. Ann Rheum Dis. Jul. 2009;68(7):1100-4. [pmid: 19060002].
2114 Salloum E, Cooper DL, Howe G, et al. Spontaneous regression of lymphoproliferative disorders in patients treated with methotrexate for rheumatoid arthritis and other rheumatic diseases. J Clin Oncol. Jun. 1996;14(6):1943-9. [pmid: 8656264].
2115 Salvarani C, Cantini F, Olivieri I, et al. Efficacy of infliximab in resistant psoriatic arthritis. Arthritis Rheum. Aug. 15. 2003;49(4):541-5. [pmid: 12910561].
2116 Salvarani C, Cantini F, Olivieri I, et al. Distal extremity swelling with pitting edema in psoriatic arthritis: evidence of 2 pathological mechanisms. J Rheumatol. Aug. 1999;26(8):1831-4. [pmid: 10451085].
2117 Samanta J, Kendall J, Samanta A. Polyarthralgia. BMJ. Apr. 19. 2003;326(7394):859. [pmid: 12702621].
2118 Sambrook P, Birmingham J, Champion D, et al. Postmenopausal bone loss in rheumatoid arthritis: effect of estrogens and androgens. J Rheumatol. Mar. 1992;19(3):357-61. [pmid: 1533677].
2119 Sanchez A, Maximiano C, Cantos B, et al. Neurological symptoms simulating cord compression in breast cancer patient. J Neurooncol. Apr. 2005;72(2):149-50. [pmid: 15925994].
2120 Sanchez G, Castro JS, Snih SA, et al. Durability of treatment with methotrexate in Venezuelan patients with rheumatoid arthritis. Rheumatol Int. Apr. 2007;27(6):531-6. [pmid: 17102944].
2121 Sandler C, Lindstedt KA, Joutsiniemi S, et al. Selective activation of mast cells in rheumatoid synovial tissue results in production of TNF-alpha, IL-1beta and IL-1Ra. Inflamm Res. Jun. 2007;56(6):230-9. [pmid: 17607547].
2122 Sankar V, Brennan MT, Kok MR, et al. Etanercept in Sjogren’s syndrome: a twelve-week randomized, double-blind, placebo-controlled pilot clinical trial. Arthritis Rheum. Jul. 2004;50(7):2240-5. [pmid: 15248223].
2123 Sanmarti R, Gomez-Centeno A, Ercilla G, et al. Prognostic factors of radiographic progression in early rheumatoid arthritis: a two year prospective study after a structured therapeutic strategy using DMARDs and very low doses of glucocorticoids. Clin Rheumatol. Jul. 2007;26(7):1111-8. [pmid: 17109060].
2124 Sano H, Arai K, Murai T, et al. Tight control is important in patients with rheumatoid arthritis treated with an anti-tumor necrosis factor biological agent: prospective study of 91 cases who used a biological agent for more than 1 year. Mod Rheumatol. 2009;19(4):390-4. [pmid: 19466615].
2125 Santiago-Casas Y, Gonzalez-Rivera TC, Castro-Santana LE, et al. Impact of age on clinical manifestations and outcome in Puerto Ricans with rheumatoid arthritis. Ethn Dis. Winter. 191. 2010;20(1 Suppl 1):S1-5. [pmid: 20521413].
2126 Santos-Ocampo AS, Santos-Ocampo RS. Non-contrast computed tomography-guided intra-articular corticosteroid injections of severe bilateral hip arthritis in a patient with ankylosing spondylitis. Clin Exp Rheumatol. Mar–Apr. 2003;21(2):239-40. [pmid: 12747284].
2127 Sany J, Bourgeois P, Saraux A, et al. Characteristics of patients with rheumatoid arthritis in France: a study of 1109 patients managed by hospital based rheumatologists. Ann Rheum Dis. Oct. 2004;63(10):1235-40. [pmid: 15361378].
2128 Sany J, Cohen JD, Combescure C, et al. Medico-economic evaluation of infliximab in rheumatoid arthritis--prospective French study of a cohort of 635 patients monitored for two years. Rheumatology (Oxford). Oct. 2009;48(10):1236-41. [pmid: 19620209].
2129 Sany J, Kaiser MJ, Jorgensen C, et al. Study of the tolerance of infliximab infusions with or without betamethasone premedication in patients with active rheumatoid arthritis. Ann Rheum Dis. Nov. 2005;64(11):1647-9. [pmid: 16227416].
2130 Sanz I, Anolik J. Reconstitution of the adult B cell repertoire after treatment with rituximab. Arthritis Res Ther. 2005;7(5):175-6. [pmid: 16207341].
2131 Saraux A, Devauchelle-Pensec V, Engerran L, et al. Most rheumatologists are conservative in active rheumatoid arthritis despite methotrexate therapy: results of the PRISME survey. J Rheumatol. Jul. 2006;33(7):1258-65. [pmid: 16783865].
2132 Sari I, Akar S, Birlik M, et al. Anti-tumor necrosis factor-alpha-induced psoriasis. J Rheumatol. Jul. 2006;33(7):1411-4. [pmid: 16821276].
2133 Saruhan-Direskeneli G, Inanc M, Fresko I, et al. The role of HLA-DRB1 shared epitope alleles in predicting short-term response to leflunomide in rheumatoid arthritis. Rheumatology (Oxford). Dec. 2007;46(12):1842-4. [pmid: 18032542].
2134 Sarzi-Puttini P, Antivalle M, Marchesoni A, et al. Efficacy and safety of anti-TNF agents in the Lombardy rheumatoid arthritis network (LORHEN). Reumatismo. Oct–Dec. 2008;60(4):290-5. [pmid: 19132154].
2135 Sarzi-Puttini P, Atzeni F, Scholmerich J, et al. Anti-TNF antibody treatment improves glucocorticoid induced insulin-like growth factor 1 (IGF1) resistance without influencing myoglobin and IGF1 binding proteins 1 and 3. Ann Rheum Dis. Mar. 2006;65(3):301-5. [pmid: 16079165].
2136 Sato H, Kazama JJ, Wada Y, et al. Decreased levels of circulating alpha2-Heremans-Schmid glycoprotein/Fetuin-A (AHSG) in patients with rheumatoid arthritis. Intern Med. 2007;46(20):1685-91. [pmid: 17938521].
2137 Sato H, Sakai T, Sugaya T, et al. Tocilizumab dramatically ameliorated life-threatening diarrhea due to secondary amyloidosis associated with rheumatoid arthritis. Clin Rheumatol. Sep. 2009;28(9):1113-6. [pmid: 19437089].
2138 Sato M, Takeda A, Honzu H, et al. Adult Still’s disease with Sjogren’s syndrome successfully treated with intravenous pulse methylprednisolone and oral cyclophosphamide. Intern Med. Sep. 1993;32(9):730-2. [pmid: 8142680].
2139 Sato T, Inokuma S, Sagawa A, et al. Factors associated with fatal outcome of leflunomide-induced lung injury in Japanese patients with rheumatoid arthritis. Rheumatology (Oxford). Oct. 2009;48(10):1265-8. [pmid: 19651883].
2140 Satoh K, Yoshida N, Imaizumi K, et al. Reversible methotrexate-associated lymphoproliferative disorder resembling advanced gastric cancer in a patient with rheumatoid arthritis. Am J Med Sci. Oct. 2009;338(4):334-5. [pmid: 19745701].
2141 Saunders SA, Capell HA, Stirling A, et al. Triple therapy in early active rheumatoid arthritis: a randomized, single-blind, controlled trial comparing step-up and parallel treatment strategies. Arthritis Rheum. 2008;58(5):1310-7. [pmid: 18438851].
2142 Saviola G, Abdi Ali L, Shams Eddin S, et al. Compared clinical efficacy and bone metabolic effects of low-dose deflazacort and methyl prednisolone in male inflammatory arthropathies: a 12-month open randomized pilot study. Rheumatology (Oxford). Jun. 2007;46(6):994-8. [pmid: 17384176].
2143 Saxne T, Larsson L, Geborek P. Results of anakinra treatment in rheumatoid arthritis patients previously treated with tumor necrosis factor alpha blockade: comment on the article by Buch et al. Arthritis Rheum. Sep. 2004;50(9):3049-50. author reply 50–1. [pmid: 15457477].
2144 Scali JJ, Visentini S, Salomon J, et al. Rapid and deep control of inflammation in rheumatoid arthritis with infliximab and its correlation with acute-phase reactants. Ann N Y Acad Sci. Sep. 2007;1110:389-401. [pmid: 17911454].
2145 Scarpa R, Peluso R, Atteno M, et al. The effectiveness of a traditional therapeutical approach in early psoriatic arthritis: results of a pilot randomised 6-month trial with methotrexate. Clin Rheumatol. Jul. 2008;27(7):823-6. [pmid: 18030515].
2146 Scarsi M, Ziglioli T, Airo P. Decreased circulating CD28-negative T cells in patients with rheumatoid arthritis treated with abatacept are correlated with clinical response. J Rheumatol. May. 2010;37(5):911-6. [pmid: 20231200].
2147 Schafer JA, Kjesbo NK, Gleason PP. Formulary review of 2 new biologic agents: tocilizumab for rheumatoid arthritis and ustekinumab for plaque psoriasis. J Manag Care Pharm. Jul–Aug. 2010;16(6):402-16. [pmid: 20635831].
2148 Schalk E, Krogel C, Scheinpflug K, et al. Lymphomatoid granulomatosis in a patient with rheumatoid arthritis receiving methotrexate: successful treatment with the anti-CD20 antibody mabthera. Onkologie. Jul. 2009;32(7):440-1. [pmid: 19556825].
2149 Schapira D, Militeanu D, Israel O, et al. Insufficiency fractures of the pubic ramus. Semin Arthritis Rheum. Jun. 1996;25(6):373-82. [pmid: 8792509].
2150 Scharf SL, Christophidis N. Second-line agents for rheumatoid arthritis. Med J Aust. Aug. 21. 1995;163(4):215-8. [pmid: 7651257].
2151 Schatteman L, Gyselbrecht L, De Clercq L, et al. Treatment of refractory inflammatory monoarthritis in ankylosing spondylitis by intraarticular injection of infliximab. J Rheumatol. Jan. 2006;33(1):82-5. [pmid: 16292792].
2152 Scheinberg M, Guedes-Barbosa LS, Mangueira C, et al. Yellow fever revaccination during infliximab therapy. Arthritis Care Res (Hoboken). 2010;62(6):896-8. [pmid: 20535801].
2153 Scheinberg M, Hamerschlak N, Kutner JM, et al. Rituximab in refractory autoimmune diseases: Brazilian experience with 29 patients 2002–2004. Clin Exp Rheumatol. Jan–Feb. 2006;24(1):65-9. [pmid: 16539821].
2154 Scheinfeld N. Menorrhagia and severe menstrual pain related to the use of adalimumab in a psoriatic. J Dermatolog Treat. 2008;19(3):188-9. [pmid: 18569277].
2155 Scherak O, Popp W, Kolarz G, et al. Bronchoalveolar lavage and lung biopsy in rheumatoid arthritis. In vivo effects of disease modifying antirheumatic drugs. J Rheumatol. Jun. 1993;20(6):944-9. [pmid: 8102405].
2156 Schett G, Herak P, Graninger W, et al. Listeria-associated arthritis in a patient undergoing etanercept therapy: case report and review of the literature. J Clin Microbiol. May. 2005;43(5):2537-41. [pmid: 15872306].
2157 Schiff M, Keiserman M, Codding C, et al. Efficacy and safety of abatacept or infliximab vs placebo in ATTEST: a phase III, multi-centre, randomised, double-blind, placebo-controlled study in patients with rheumatoid arthritis and an inadequate response to methotrexate. Ann Rheum Dis. 2008;67(8):1096-103. [pmid: 18055472].
2158 Schiff MH, DiVittorio G, Tesser J, et al. The safety of anakinra in high-risk patients with active rheumatoid arthritis: six-month observations of patients with comorbid conditions. Arthritis Rheum. Jun. 2004;50(6):1752-60. [pmid: 15188350].
2159 Schipper LG, Fransen J, Barrera P, et al. Methotrexate therapy in rheumatoid arthritis after failure to sulphasalazine: to switch or to add?. Rheumatology (Oxford). 2009;48(10):1247-53. [pmid: 19638454].
2160 Schipper LG, Fransen J, Barrera P, et al. Methotrexate in combination with sulfasalazine is more effective in rheumatoid arthritis patients who failed sulfasalazine than in patients naive to both drugs. Rheumatology (Oxford). 2009;48(7):828-33. [pmid: 19458163].
2161 Schirren CA, Zachoval R, Schirren CG, et al. A role for chronic hepatitis C virus infection in a patient with cutaneous vasculitis, cryoglobulinemia, and chronic liver disease. Effective therapy with interferon-alpha. Dig Dis Sci. Jun. 1995;40(6):1221-5. [pmid: 7781436].
2162 Schlaghecke R, Beuscher D, Kornely E, et al. Effects of glucocorticoids in rheumatoid arthritis. Diminished glucocorticoid receptors do not result in glucocorticoid resistance. Arthritis Rheum. Aug. 1994;37(8):1127-31. [pmid: 8053950].
2163 Schlaghecke R, Kornely E, Wollenhaupt J, et al. Glucocorticoid receptors in rheumatoid arthritis. Arthritis Rheum. Jul. 1992;35(7):740-4. [pmid: 1622411].
2164 Schmeling H, Horneff G. Infliximab in two patients with juvenile ankylosing spondylitis. Rheumatol Int. May. 2004;24(3):173-6. [pmid: 14648110].
2165 Schmeling H, Horneff G. Etanercept and uveitis in patients with juvenile idiopathic arthritis. Rheumatology (Oxford). Aug. 2005;44(8):1008-11. [pmid: 15855187].
2166 Schmid L, Muller M, Treumann T, et al. Induction of complete and sustained remission of rheumatoid pachymeningitis by rituximab. Arthritis Rheum. Jun. 2009;60(6):1632-4. [pmid: 19479865].
2167 Schmidt M, Hartung R, Capellino S, et al. Estrone/17beta-estradiol conversion to, and tumor necrosis factor inhibition by, estrogen metabolites in synovial cells of patients with rheumatoid arthritis and patients with osteoarthritis. Arthritis Rheum. Oct. 2009;60(10):2913-22. [pmid: 19790073].
2168 Schmidt M, Weidler C, Naumann H, et al. Reduced capacity for the reactivation of glucocorticoids in rheumatoid arthritis synovial cells: possible role of the sympathetic nervous system?. Arthritis Rheum. Jun. 2005;52(6):1711-20. [pmid: 15934114].
2169 Schneeweiss S, Setoguchi S, Weinblatt ME, et al. Anti-tumor necrosis factor alpha therapy and the risk of serious bacterial infections in elderly patients with rheumatoid arthritis. Arthritis Rheum. 2007;56(6):1754-64. [pmid: 17530704].
2170 Schneider SW, Staender S, Schluter B, et al. Infliximab-induced lupus erythematosus tumidus in a patient with rheumatoid arthritis. Arch Dermatol. Jan. 2006;142(1):115-6. [pmid: 16415403].
2171 Schoels M, Aletaha D, Funovits J, et al. Application of the DAREA/DAPSA score for assessment of disease activity in psoriatic arthritis. Ann Rheum Dis. Aug. 2010;69(8):1441-7. [pmid: 20525844].
2172 Schoels M, Kapral T, Stamm T, et al. Step-up combination versus switching of non-biological disease-modifying antirheumatic drugs in rheumatoid arthritis: results from a retrospective observational study. Ann Rheum Dis. 2007;66(8):1059-65. [pmid: 17307765].
2173 Schotte H, Schluter B, Drynda S, et al. Interleukin 10 promoter microsatellite polymorphisms are associated with response to long term treatment with etanercept in patients with rheumatoid arthritis. Ann Rheum Dis. Apr. 2005;64(4):575-81. [pmid: 15345504].
2174 Schotte H, Schluter B, Willeke P, et al. Long-term treatment with etanercept significantly reduces the number of proinflammatory cytokine-secreting peripheral blood mononuclear cells in patients with rheumatoid arthritis. Rheumatology (Oxford). Aug. 2004;43(8):960-4. [pmid: 15026584].
2175 Schramm C, Schneider A, Marx A, et al. Adalimumab could suppress the activity of non alcoholic steatohepatitis (NASH). Z Gastroenterol. Dec. 2008;46(12):1369-71. [pmid: 19053005].
2176 Schuh A, Zeiler G, Holzwarth U, et al. Malignant fibrous histiocytoma at the site of a total hip arthroplasty. Clin Orthop Relat Res. Aug. 2004;(425):218-22. [pmid: 15292811].
2177 Schumacher HR, Chen LX. Injectable corticosteroids in treatment of arthritis of the knee. Am J Med. Nov. 2005;118(11):1208-14. [pmid: 16271901].
2178 Schwartz JI, Agrawal NG, Wong PH, et al. Examination of the effect of increasing doses of etoricoxib on oral methotrexate pharmacokinetics in patients with rheumatoid arthritis. J Clin Pharmacol. Oct. 2009;49(10):1202-9. [pmid: 19783714].
2179 Schwetz BA. From the Food and Drug Administration. JAMA. Mar. 6. 2002;287(9):1103. [pmid: 11879090].
2180 Scott DL, Kingsley GH. Tumor necrosis factor inhibitors for rheumatoid arthritis. N Engl J Med. Aug. 17. 2006;355(7):704-12. [pmid: 16914706].
2181 Scrivo R, Conti F, Spinelli FR, et al. Switching between TNFalpha antagonists in rheumatoid arthritis: personal experience and review of the literature. Reumatismo. Apr–Jun. 2009;61(2):107-17. [pmid: 19633797].
2182 Scuderi F, Convertino R, Molino N, et al. Effect of pro-inflammatory/anti-inflammatory agents on cytokine secretion by peripheral blood mononuclear cells in rheumatoid arthritis and systemic lupus erythematosus. Autoimmunity. Mar. 2003;36(2):71-7. [pmid: 12820688].
2183 Seidl C, Donner H, Fischer B, et al. CTLA4 codon 17 dimorphism in patients with rheumatoid arthritis. Tissue Antigens. Jan. 1998;51(1):62-6. [pmid: 9459504].
2184 Seitz CS, Berens N, Brocker EB, et al. Leg ulceration in rheumatoid arthritis--an underreported multicausal complication with considerable morbidity: analysis of thirty-six patients and review of the literature. Dermatology. 2010;220(3):268-73. [pmid: 20332595].
2185 Seitz M, Loetscher P, Dewald B, et al. Production of interleukin-1 receptor antagonist, inflammatory chemotactic proteins, and prostaglandin E by rheumatoid and osteoarthritic synoviocytes--regulation by IFN-gamma and IL-4. J Immunol. Feb. 15. 1994;152(4):2060-5. [pmid: 8120407].
2186 Seitz M, Zwicker M, Villiger PM. Pretreatment cytokine profiles of peripheral blood mononuclear cells and serum from patients with rheumatoid arthritis in different american college of rheumatology response groups to methotrexate. J Rheumatol. Jan. 2003;30(1):28-35. [pmid: 12508386].
2187 Sekigawa I, Yanagida M, Iwabuchi K, et al. Protein biomarker analysis by mass spectrometry in patients with rheumatoid arthritis receiving anti-tumor necrosis factor-alpha antibody therapy. Clin Exp Rheumatol. Mar–Apr. 2008;26(2):261-7. [pmid: 18565247].
2188 Sekiguchi N, Kawauchi S, Furuya T, et al. Messenger ribonucleic acid expression profile in peripheral blood cells from RA patients following treatment with an anti-TNF-alpha monoclonal antibody, infliximab. Rheumatology (Oxford). Jun. 2008;47(6):780-8. [pmid: 18388148].
2189 Sekiya H, Horii T, Kariya Y, et al. Arthroscopic-assisted tibiotalocalcaneal arthrodesis using an intramedullary nail with fins: a case report. J Foot Ankle Surg. Jul–Aug. 2006;45(4):266-70. [pmid: 16818155].
2190 Sellam J, Bouvard B, Masson C, et al. Use of infliximab to treat psoriatic arthritis in HIV-positive patients. Joint Bone Spine. Mar. 2007;74(2):197-200. [pmid: 17321777].
2191 Semmler M, Seeck U, Neustadt B, et al. No effects of adalimumab therapy on the activation of NF-kappaB in lymphocytes from patients with severe rheumatoid arthritis. Clin Rheumatol. Sep. 2007;26(9):1499-504. [pmid: 17273811].
2192 Sennels H, Sorensen S, Ostergaard M, et al. Circulating levels of osteopontin, osteoprotegerin, total soluble receptor activator of nuclear factor-kappa B ligand, and high-sensitivity C-reactive protein in patients with active rheumatoid arthritis randomized to etanercept alone or in combination with methotrexate. Scand J Rheumatol. Jul–Aug. 2008;37(4):241-7. [pmid: 18612923].
2193 Seong SS, Choi CB, Woo JH, et al. Incidence of tuberculosis in Korean patients with rheumatoid arthritis (RA): effects of RA itself and of tumor necrosis factor blockers. J Rheumatol. Apr. 2007;34(4):706-11. [pmid: 17309133].
2194 Serelis J, Kontogianni MD, Katsiougiannis S, et al. Effect of anti-TNF treatment on body composition and serum adiponectin levels of women with rheumatoid arthritis. Clin Rheumatol. Jun. 2008;27(6):795-7. [pmid: 18305977].
2195 Seriolo B, Ferretti V, Sulli A, et al. Serum prolactin concentrations in male patients with rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2002;966:258-62. [pmid: 12114281].
2196 Seriolo B, Paolino S, Sulli A, et al. Effects of anti-TNF-alpha treatment on lipid profile in patients with active rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2006;1069:414-9. [pmid: 16855168].
2197 Seriolo B, Paolino S, Sulli A, et al. Bone metabolism changes during anti-TNF-alpha therapy in patients with active rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2006;1069:420-7. [pmid: 16855169].
2198 Seror P, Pluvinage P, d’Andre FL, et al. Frequency of sepsis after local corticosteroid injection (an inquiry on 1160000 injections in rheumatological private practice in France). Rheumatology (Oxford). Dec. 1999;38(12):1272-4. [pmid: 10587558].
2199 Seror R, Sordet C, Guillevin L, et al. Tolerance and efficacy of rituximab and changes in serum B cell biomarkers in patients with systemic complications of primary Sjogren’s syndrome. Ann Rheum Dis. Mar. 2007;66(3):351-7. [pmid: 16950808].
2200 Serratrice J, Granel B, Disdier P, et al. Resolution with etanercept of nephrotic syndrome due to renal AA amyloidosis in adult Still’s disease. Am J Med. Nov. 2003;115(7):589-90. [pmid: 14599647].
2201 Setoguchi S, Schneeweiss S, Avorn J, et al. Tumor necrosis factor-alpha antagonist use and heart failure in elderly patients with rheumatoid arthritis. Am Heart J. 2008;156(2):336-41. [pmid: 18657665].
2202 Seton M. Giant cell arteritis in a patient taking etanercept and methotrexate. J Rheumatol. Jul. 2004;31(7):1467. [pmid: 15229983].
2203 Settas LD, Tsimirikas G, Vosvotekas G, et al. Reactivation of pulmonary tuberculosis in a patient with rheumatoid arthritis during treatment with IL-1 receptor antagonists (anakinra). J Clin Rheumatol. Aug. 2007;13(4):219-20. [pmid: 17762459].
2204 Settergren M, Tornvall P. Does TNF-alpha blockade cause plaque rupture?. Atherosclerosis. Mar. 2004;173(1):149. [pmid: 15177137].
2205 Sfikakis PP. The first decade of biologic TNF antagonists in clinical practice: lessons learned, unresolved issues and future directions. Curr Dir Autoimmun. 2010;11:180-210. [pmid: 20173395].
2206 Sfikakis PP, Iliopoulos A, Elezoglou A, et al. Psoriasis induced by anti-tumor necrosis factor therapy: a paradoxical adverse reaction. Arthritis Rheum. Aug. 2005;52(8):2513-8. [pmid: 16052599].
2207 Shadick NA, Fanta CH, Weinblatt ME, et al. Bronchiectasis. A late feature of severe rheumatoid arthritis. Medicine (Baltimore). May. 1994;73(3):161-70. [pmid: 8190039].
2208 Shakiba K, Falcone T. Tumour necrosis factor-alpha blockers: potential limitations in the management of advanced endometriosis? A case report. Hum Reprod. Sep. 2006;21(9):2417-20. [pmid: 16785259].
2209 Shakoor N, Michalska M, Harris CA, et al. Drug-induced systemic lupus erythematosus associated with etanercept therapy. Lancet. Feb. 16. 2002;359(9306):579-80. [pmid: 11867114].
2210 Shan SJ, Wu EI, Akpek EK. Sterile corneal melt after descemet stripping endothelial keratoplasty in patients with previously undiagnosed Sjogren syndrome. Arch Ophthalmol. Feb. 2009;127(2):219-20. [pmid: 19204245].
2211 Sharma A, Baethge BA, Acebes JC, et al. Arthroscopic lavage treatment in rheumatoid arthritis of the knee. J Rheumatol. Nov. 1996;23(11):1872-4. [pmid: 8923370].
2212 Sharma S, Das M, Kumar A, et al. Interaction of genes from influx-metabolism-efflux pathway and their influence on methotrexate efficacy in rheumatoid arthritis patients among Indians. Pharmacogenet Genomics. Dec. 2008;18(12):1041-9. [pmid: 19093297].
2213 Sharma S, Das M, Kumar A, et al. Purine biosynthetic pathway genes and methotrexate response in rheumatoid arthritis patients among north Indians. Pharmacogenet Genomics. Oct. 2009;19(10):823-8. [pmid: 19902562].
2214 Shastri V, Betkerur J, Kushalappa PA, et al. Severe cutaneous adverse drug reaction to leflunomide: a report of five cases. Indian J Dermatol Venereol Leprol. Jul–Aug. 2006;72(4):286-9. [pmid: 16880575].
2215 Shawe D, Hesp R, Gumpel JM, et al. Physical activity as a determinant of bone conservation in the radial diaphysis in rheumatoid arthritis. Ann Rheum Dis. Aug. 1993;52(8):579-81. [pmid: 8215619].
2216 Shbeeb M, Uramoto KM, Gibson LE, et al. The epidemiology of psoriatic arthritis in Olmsted County, Minnesota, USA, 1982–1991. J Rheumatol. May. 2000;27(5):1247-50. [pmid: 10813295].
2217 Shedd AD, Reddy SG, Meffert JJ, et al. Acute onset of rash and oligoarthritis. J Fam Pract. Oct. 2007;56(10):811-4. [pmid: 17908511].
2218 Shehan JM, Sarma DP. Mycobacterium mucogenicum: report of a skin infection associated with etanercept. Dermatol Online J. 2008;14(1):5. [pmid: 18319022].
2219 Shergy WJ, Isern RA, Cooley DA, et al. Open label study to assess infliximab safety and timing of onset of clinical benefit among patients with rheumatoid arthritis. J Rheumatol. Apr. 2002;29(4):667-77. [pmid: 11950005].
2220 Sherrer Y. Abatacept in biologic-naive patients and TNF inadequate responders: clinical data in focus. Curr Med Res Opin. Aug. 2008;24(8):2283-94. [pmid: 18590608].
2221 Shibata S, Ubara Y, Sawa N, et al. Severe interstitial cystitis associated with Sjogren’s syndrome. Intern Med. Mar. 2004;43(3):248-52. [pmid: 15098610].
2222 Shih WJ, Ghesani N, Hongming Z, et al. F-18 FDG positron emission tomography demonstrates resolution of non-Hodgkin’s lymphoma of the parotid gland in a patient with Sjogren’s syndrome: before and after anti-CD20 antibody rituximab therapy. Clin Nucl Med. Feb. 2002;27(2):142-3. [pmid: 11786752].
2223 Shimada K, Matsui T, Kawakami M, et al. Methotrexate-related lymphomatoid granulomatosis: a case report of spontaneous regression of large tumours in multiple organs after cessation of methotrexate therapy in rheumatoid arthritis. Scand J Rheumatol. Jan–Feb. 2007;36(1):64-7. [pmid: 17454938].
2224 Shimizu H, Miyashita N, Obase Y, et al. An asymptomatic case of pulmonary cryptococcosis with endobronchial polypoid lesions and bilateral infiltrative shadow. J Infect Chemother. Aug. 2008;14(4):315-8. [pmid: 18709537].
2225 Shimojima Y, Ishii W, Matsuda M, et al. Cytomegalovirus-induced infectious mononucleosis-like syndrome in a rheumatoid arthritis patient treated with methotrexate and infliximab. Intern Med. 2010;49(10):937-40. [pmid: 20467180].
2226 Shimoyama M, Ohtahara A, Fukui H, et al. Acute secondary gastrointestinal amyloidosis in a patient with rheumatoid arthritis. Am J Med Sci. Sep. 2003;326(3):145-7. [pmid: 14501231].
2227 Shimura C, Satoh T, Takayama K, et al. Methotrexate-related lymphoproliferative disorder with extensive vascular involvement in a patient with rheumatoid arthritis. J Am Acad Dermatol. Jul. 2009;61(1):126-9. [pmid: 19539849].
2228 Shin IS, Baer AN, Kwon HJ, et al. Guillain-Barre and Miller Fisher syndromes occurring with tumor necrosis factor alpha antagonist therapy. Arthritis Rheum. May. 2006;54(5):1429-34. [pmid: 16645971].
2229 Shin K, Lee JC, Choi HJ, et al. Radiation synovectomy using 188Re-tin colloid improves knee synovitis as shown by MRI in refractory rheumatoid arthritis. Nucl Med Commun. Apr. 2007;28(4):239-44. [pmid: 17325584].
2230 Shin SJ, Na KS, Jung SS, et al. Acute acalculous cholecystitis associated with systemic lupus erythematosus with Sjogren’s syndrome. Korean J Intern Med. Mar. 2002;17(1):61-4. [pmid: 12014215].
2231 Shingu M, Fujikawa Y, Wada T, et al. Increased IL-1 receptor antagonist (IL-1ra) production and decreased IL-1 beta/IL-1ra ratio in mononuclear cells from rheumatoid arthritis patients. Br J Rheumatol. Jan. 1995;34(1):24-30. [pmid: 7881833].
2232 Shinoda K, Taki H, Hounoki H, et al. Severe autoimmune hemolytic anemia associated with IgM warm auto-antibodies in primary Sjogren’s syndrome. Int J Rheum Dis. Feb. 1. 2010;13(1):94-6. [pmid: 20374393].
2233 Shinozaki M, Inoue E, Nakajima A, et al. Elevation of serum matrix metalloproteinase-3 as a predictive marker for the long-term disability of rheumatoid arthritis patients in a prospective observational cohort IORRA. Mod Rheumatol. 2007;17(5):403-8. [pmid: 17929133].
2234 Shio K, Homma F, Kanno Y, et al. Doppler sonographic comparative study on usefulness of synovial vascularity between knee and metacarpophalangeal joints for evaluation of articular inflammation in patients with rheumatoid arthritis treated by infliximab. Mod Rheumatol. 2006;16(4):220-5. [pmid: 16906371].
2235 Shoda H, Inokuma S, Yajima N, et al. Higher maximal serum concentration of methotrexate predicts the incidence of adverse reactions in Japanese rheumatoid arthritis patients. Mod Rheumatol. 2007;17(4):311-6. [pmid: 17694265].
2236 Sholsberg J, Jackson R. Best evidence topic report. Intra-articular corticosteroid injections in acute rheumatoid monoarthritides. Emerg Med J. Mar. 2004;21(2):204. [pmid: 14988353].
2237 Shovman O, Anouk M, Vinnitsky N, et al. QuantiFERON-TB Gold in the identification of latent tuberculosis infection in rheumatoid arthritis: a pilot study. Int J Tuberc Lung Dis. Nov. 2009;13(11):1427-32. [pmid: 19861018].
2238 Shrestha RK, Stoller JK, Honari G, et al. Pneumonia due to Cryptococcus neoformans in a patient receiving infliximab: possible zoonotic transmission from a pet cockatiel. Respir Care. Jun. 2004;49(6):606-8. [pmid: 15165294].
2239 Shrim A, Koren G. Tumour necrosis factor alpha and use of infliximab. Safety during pregnancy. Can Fam Physician. May. 2005;51:667-8. [pmid: 15934268].
2240 Sibbitt WL Jr, Peisajovich A, Michael AA, et al. Does sonographic needle guidance affect the clinical outcome of intraarticular injections?. J Rheumatol. Sep. 2009;36(9):1892-902. [pmid: 19648304].
2241 Sibilia J, Javier RM, Albert A, et al. Pancytopenia secondary to hemophagocytic syndrome in rheumatoid arthritis treated with methotrexate and sulfasalazine. J Rheumatol. Jun. 1998;25(6):1218-20. [pmid: 9632090].
2242 Sichletidis L, Settas L, Spyratos D, et al. Tuberculosis in patients receiving anti-TNF agents despite chemoprophylaxis. Int J Tuberc Lung Dis. Oct. 2006;10(10):1127-32. [pmid: 17044206].
2243 Sicotte NL, Voskuhl RR. Onset of multiple sclerosis associated with anti-TNF therapy. Neurology. Nov. 27. 2001;57(10):1885-8. [pmid: 11723281].
2244 Sidiropoulos P, Bertsias G, Kritikos HD, et al. Infliximab treatment for rheumatoid arthritis, with dose titration based on the Disease Activity Score: dose adjustments are common but not always sufficient to assure sustained benefit. Ann Rheum Dis. Feb. 2004;63(2):144-8. [pmid: 14722202].
2245 Sidiropoulos P, Kritikos HD, Siakka P, et al. Low dose of infliximab is inadequate in most patients with spondylarthropathies. Clin Exp Rheumatol. Jul–Aug. 2005;23(4):513-6. [pmid: 16095121].
2246 Sidiropoulos PI, Siakka P, Pagonidis K, et al. Sustained improvement of vascular endothelial function during anti-TNFalpha treatment in rheumatoid arthritis patients. Scand J Rheumatol. Jan–Feb. 2009;38(1):6-10. [pmid: 18991190].
2247 Sidiropoulos PI, Siakka P, Raptopoulou A, et al. An open label, single dose study to evaluate the safety, efficacy, and effects on CD25 expression of ciclosporin in patients with active rheumatoid arthritis despite treatment with methotrexate and infliximab. Ann Rheum Dis. Apr. 2006;65(4):538-41. [pmid: 16126800].
2248 Sieper J, Baraliakos X, Listing J, et al. Persistent reduction of spinal inflammation as assessed by magnetic resonance imaging in patients with ankylosing spondylitis after 2 yrs of treatment with the anti-tumour necrosis factor agent infliximab. Rheumatology (Oxford). Dec. 2005;44(12):1525-30. [pmid: 16091396].
2249 Sills ES, Perloe M, Tucker MJ, et al. Successful ovulation induction, conception, and normal delivery after chronic therapy with etanercept: a recombinant fusion anti-cytokine treatment for rheumatoid arthritis. Am J Reprod Immunol. Nov. 2001;46(5):366-8. [pmid: 11712766].
2250 Simms R, Kipgen D, Dahill S, et al. ANCA-associated renal vasculitis following anti-tumor necrosis factor alpha therapy. Am J Kidney Dis. Mar. 2008;51(3):e11-4. [pmid: 18295046].
2251 Simsek I, Erdem H, Pay S, et al. Optic neuritis occurring with anti-tumour necrosis factor alpha therapy. Ann Rheum Dis. Sep. 2007;66(9):1255-8. [pmid: 17456525].
2252 Singh JA, Mahowald ML. Intra-articular botulinum toxin A as an adjunctive therapy for refractory joint pain in patients with rheumatoid arthritis receiving biologics: a report of two cases. Joint Bone Spine. Mar. 2009;76(2):190-4. [pmid: 18952480].
2253 Singh JA, Noorbaloochi S, Singh G. Golimumab for rheumatoid arthritis. Cochrane Database Syst Rev. 2010;(1):CD008341. [pmid: 20091667].
2254 Singh JA, Pando JA, Tomaszewski J, et al. Quantitative analysis of immunohistologic features of very early rheumatoid synovitis in disease modifying antirheumatic drug-and corticosteroid-naive patients. J Rheumatol. Jul. 2004;31(7):1281-5. [pmid: 15229944].
2255 Singh P, Taylor SF, Murali R, et al. Disseminated mucormycosis and orbital ischaemia in combination immunosuppression with a tumour necrosis factor alpha inhibitor. Clin Experiment Ophthalmol. Apr. 2007;35(3):275-80. [pmid: 17430516].
2256 Singh R, Cuchacovich R, Huang W, et al. Infliximab treatment in a patient with rheumatoid arthritis on hemodialysis. J Rheumatol. Mar. 2002;29(3):636-7. [pmid: 11908584].
2257 Singh S, Samant R, Joshi VR. Adult onset Still’s disease: a study of 14 cases. Clin Rheumatol. Jan. 2008;27(1):35-9. [pmid: 17701269].
2258 Sinha A, Patient C. Rheumatoid arthritis in pregnancy: successful outcome with anti-TNF agent (Etanercept). J Obstet Gynaecol. Oct. 2006;26(7):689-91. [pmid: 17071443].
2259 Sinigaglia L, Nervetti A, Mela Q, et al. A multicenter cross sectional study on bone mineral density in rheumatoid arthritis. Italian Study Group on Bone Mass in Rheumatoid Arthritis. J Rheumatol. Nov. 2000;27(11):2582-9. [pmid: 11093437].
2260 Sinsawaiwong S, Tiyapun N, Hirunpat C, et al. Simultaneous bilateral painful ophthalmoplegia and exudative retinal detachment in rheumatoid arthritis. J Med Assoc Thai. Nov. 1999;82(11):1170-3. [pmid: 10659556].
2261 Slifman NR, Gershon SK, Lee JH, et al. Listeria monocytogenes infection as a complication of treatment with tumor necrosis factor alpha-neutralizing agents. Arthritis Rheum. Feb. 2003;48(2):319-24. [pmid: 12571839].
2262 Sliwinska-Stanczyk P, Pazdur J, Ziolkowska M, et al. The effect of methylprednisolone on proliferation of PBMCs obtained from steroid-sensitive and steroid-resistant rheumatoid arthritis patients. Scand J Rheumatol. May–Jun. 2007;36(3):167-71. [pmid: 17657668].
2263 Slovis BS, Eyler AE. A 33-year-old man with pharyngitis, transient rash, and multiorgan system failure. Chest. Sep. 2007;132(3):1080-3. [pmid: 17873204].
2264 Smedby KE, Hjalgrim H, Askling J, et al. Autoimmune and chronic inflammatory disorders and risk of non-Hodgkin lymphoma by subtype. J Natl Cancer Inst. Jan. 4. 2006;98(1):51-60. [pmid: 16391371].
2265 Smeets TJ, Kraan MC, van Loon ME, et al. Tumor necrosis factor alpha blockade reduces the synovial cell infiltrate early after initiation of treatment, but apparently not by induction of apoptosis in synovial tissue. Arthritis Rheum. Aug. 2003;48(8):2155-62. [pmid: 12905468].
2266 Smith AP, Musacchio MJ, O’Toole JE. Spinal epidural abscess associated with infliximab treatment for psoriatic arthritis. Case report. J Neurosurg Spine. Sep. 2008;9(3):261-4. [pmid: 18928222].
2267 Smith D, Letendre S. Viral pneumonia as a serious complication of etanercept therapy. Ann Intern Med. Jan. 15. 2002;136(2):174. [pmid: 11790076].
2268 Smith GR, Tymms KE, Falk M. Etanercept treatment of renal amyloidosis complicating rheumatoid arthritis. Intern Med J. Sep–Oct. 2004;34(9–10):570-2. [pmid: 15482271].
2269 Smith KJ, Skelton HG. Rapid onset of cutaneous squamous cell carcinoma in patients with rheumatoid arthritis after starting tumor necrosis factor alpha receptor IgG1-Fc fusion complex therapy. J Am Acad Dermatol. Dec. 2001;45(6):953-6. [pmid: 11712048].
2270 Smith MD, Slavotinek J, Au V, et al. Successful treatment of rheumatoid arthritis is associated with a reduction in synovial membrane cytokines and cell adhesion molecule expression. Rheumatology (Oxford). Sep. 2001;40(9):965-77. [pmid: 11561106].
2271 Smith N, Ding T, Butt S, et al. The importance of the baseline Disease Activity Score 28 in determining responders and non-responders to anti-TNF in UK clinical practice. Rheumatology (Oxford). Sep. 2008;47(9):1389-91. [pmid: 18603597].
2272 Smitten AL, Choi HK, Hochberg MC, et al. The risk of herpes zoster in patients with rheumatoid arthritis in the United States and the United Kingdom. Arthritis Rheum. 2007;57(8):1431-8. [pmid: 18050184].
2273 Smitten AL, Choi HK, Hochberg MC, et al. The risk of hospitalized infection in patients with rheumatoid arthritis. J Rheumatol. 2008;35(3):387-93. [pmid: 18260176].
2274 Smolen J, Landewe RB, Mease P, et al. Efficacy and safety of certolizumab pegol plus methotrexate in active rheumatoid arthritis: the RAPID 2 study. A randomised controlled trial. Ann Rheum Dis. 2009;68(6):797-804. [pmid: 19015207].
2275 Smolen JS, Beaulieu A, Rubbert-Roth A, et al. Effect of interleukin-6 receptor inhibition with tocilizumab in patients with rheumatoid arthritis (OPTION study): a double-blind, placebo-controlled, randomised trial. Lancet. 2008;371(9617):987-97. [pmid: 18358926].
2276 Smolen JS, Han C, Bala M, et al. Evidence of radiographic benefit of treatment with infliximab plus methotrexate in rheumatoid arthritis patients who had no clinical improvement: a detailed subanalysis of data from the anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study. Arthritis Rheum. 2005;52(4):1020-30. [pmid: 15818697].
2277 Smolen JS, Han C, van der Heijde D, et al. Infliximab treatment maintains employability in patients with early rheumatoid arthritis. Arthritis Rheum. Mar. 2006;54(3):716-22. [pmid: 16508932].
2278 Smolen JS, Han C, van der Heijde DM, et al. Radiographic changes in rheumatoid arthritis patients attaining different disease activity states with methotrexate monotherapy and infliximab plus methotrexate: the impacts of remission and tumour necrosis factor blockade. Ann Rheum Dis. 2009;68(6):823-7. [pmid: 18593759].
2279 Smolen JS, Kay J, Doyle MK, et al. Golimumab in patients with active rheumatoid arthritis after treatment with tumour necrosis factor alpha inhibitors (GO-AFTER study): a multicentre, randomised, double-blind, placebo-controlled, phase III trial. Lancet. 2009;374(9685):210-21. [pmid: 19560810].
2280 Snowden JA, Biggs JC, Milliken ST, et al. A phase I/II dose escalation study of intensified cyclophosphamide and autologous blood stem cell rescue in severe, active rheumatoid arthritis. Arthritis Rheum. Nov. 1999;42(11):2286-92. [pmid: 10555022].
2281 Sobhani I, Brousse N, Vissuzaine C, et al. A diffuse T lymphocytic gastrointestinal mucosal infiltration associated with Sjogren’s syndrome resulting in a watery diarrhea syndrome and responsive to immunosuppressive therapy. Am J Gastroenterol. Dec. 1998;93(12):2584-6. [pmid: 9860433].
2282 Soderlin MK, Lindroth Y, Jacobsson LT. Trends in medication and health-related quality of life in a population-based rheumatoid arthritis register in Malmo, Sweden. Rheumatology (Oxford). 2007;46(8):1355-8. [pmid: 17567634].
2283 Soh MC, Hart HH, Corkill M. Pericardial effusions with tamponade and visceral constriction in patients with rheumatoid arthritis on tumour necrosis factor (TNF)-inhibitor therapy. Int J Rheum Dis. Apr. 2009;12(1):74-7. [pmid: 20374322].
2284 Sokka T, Kautiainen H, Toloza S, et al. QUEST-RA: quantitative clinical assessment of patients with rheumatoid arthritis seen in standard rheumatology care in 15 countries. Ann Rheum Dis. Nov. 2007;66(11):1491-6. [pmid: 17412740].
2285 Sokka T, Mottonen T, Hannonen P. Mortality in early “sawtooth” treated rheumatoid arthritis patients during the first 8–14 years. Scand J Rheumatol. 1999;28(5):282-7. [pmid: 10568424].
2286 Sokka T, Pincus T. Contemporary disease modifying antirheumatic drugs (DMARD) in patients with recent onset rheumatoid arthritis in a US private practice: methotrexate as the anchor drug in 90% and new DMARD in 30% of patients. J Rheumatol. Dec. 2002;29(12):2521-4. [pmid: 12465145].
2287 Sokka T, Pincus T. Eligibility of patients in routine care for major clinical trials of anti-tumor necrosis factor alpha agents in rheumatoid arthritis. Arthritis Rheum. Feb. 2003;48(2):313-8. [pmid: 12571838].
2288 Sokka T, Pincus T. Ascendancy of weekly low-dose methotrexate in usual care of rheumatoid arthritis from 1980 to 2004 at two sites in Finland and the United States. Rheumatology (Oxford). Oct. 2008;47(10):1543-7. [pmid: 18687711].
2289 Sokolove J, Strand V, Greenberg JD, et al. Risk of elevated liver enzymes associated with TNF inhibitor utilisation in patients with rheumatoid arthritis. Ann Rheum Dis. 2010;69(9):1612-7. [pmid: 20448284].
2290 Sokolovic S, Kasumagic S, Mackic-Durovic M, et al. The impact of Rituximab therapy on the chromosomes of patients with Rheumatoid arthritis. Bosn J Basic Med Sci. May. 2010;10(2):121-4. [pmid: 20507292].
2291 Solau-Gervais E, Legrand JL, Cortet B, et al. Magnetic resonance imaging of the hand for the diagnosis of rheumatoid arthritis in the absence of anti-cyclic citrullinated peptide antibodies: a prospective study. J Rheumatol. Sep. 2006;33(9):1760-5. [pmid: 16832852].
2292 Soliotis F, Glover M, Jawad AS. Severe skin reaction after leflunomide and etanercept in a patient with rheumatoid arthritis. Ann Rheum Dis. Sep. 2002;61(9):850-1. [pmid: 12176818].
2293 Solomon DH, Katz JN, Cabral D, et al. Osteoporosis management in patients with rheumatoid arthritis: Evidence for improvement. Arthritis Rheum. Dec. 15. 2006;55(6):873-7. [pmid: 17139663].
2294 Solomon DH, Kuntz KM. Should postmenopausal women with rheumatoid arthritis who are starting corticosteroid treatment be screened for osteoporosis? A cost-effectiveness analysis. Arthritis Rheum. Sep. 2000;43(9):1967-75. [pmid: 11014346].
2295 Solomon DH, Stedman M, Licari A, et al. Agreement between patient report and medical record review for medications used for rheumatoid arthritis: the accuracy of self-reported medication information in patient registries. Arthritis Rheum. Mar. 15. 2007;57(2):234-9. [pmid: 17330299].
2296 Somer BG, Tsai DE, Downs L, et al. Improvement in Sjogren’s syndrome following therapy with rituximab for marginal zone lymphoma. Arthritis Rheum. Jun. 15. 2003;49(3):394-8. [pmid: 12794796].
2297 Sommer WH, Ganiere V, Gachoud D, et al. Neurological and pulmonary adverse effects of subcutaneous methotrexate therapy. Scand J Rheumatol. Jul–Aug. 2008;37(4):306-9. [pmid: 18612932].
2298 Sorajja P, Poirier MK, Bundrick JB, et al. Autonomic failure and proximal skeletal myopathy in a patient with primary Sjogren syndrome. Mayo Clin Proc. Jul. 1999;74(7):695-7. [pmid: 10405700].
2299 Sordet C, Gottenberg JE, Hellmich B, et al. Lack of efficacy of rituximab in Felty’s syndrome. Ann Rheum Dis. Feb. 2005;64(2):332-3. [pmid: 15647445].
2300 Sorensen LK, Havemose-Poulsen A, Bendtzen K, et al. Aggressive periodontitis and chronic arthritis: blood mononuclear cell gene expression and plasma protein levels of cytokines and cytokine inhibitors. J Periodontol. Feb. 2009;80(2):282-9. [pmid: 19186969].
2301 Soubrier M, Haik S, Hauw JJ, et al. Creutzfeldt-Jakob disease in a patient treated by etanercept for rheumatoid arthritis (RA): just a coincidence?. Joint Bone Spine. Mar. 2010;77(2):174-5. [pmid: 20097590].
2302 Soubrier M, Jeannin G, Kemeny JL, et al. Organizing pneumonia after rituximab therapy: Two cases. Joint Bone Spine. May. 2008;75(3):362-5. [pmid: 18424211].
2303 Soubrier M, Jouanel P, Mathieu S, et al. Effects of anti-tumor necrosis factor therapy on lipid profile in patients with rheumatoid arthritis. Joint Bone Spine. Jan. 2008;75(1):22-4. [pmid: 17888710].
2304 Soubrier M, Mathieu S, Payet S, et al. Elderly-onset rheumatoid arthritis. Joint Bone Spine. Jul. 2010;77(4):290-6. [pmid: 20554241].
2305 Soubrier M, Puechal X, Sibilia J, et al. Evaluation of two strategies (initial methotrexate monotherapy vs its combination with adalimumab) in management of early active rheumatoid arthritis: data from the GUEPARD trial. Rheumatology (Oxford). Nov. 2009;48(11):1429-34. [pmid: 19741011].
2306 Sowter MC, Burgess NA, Woodsford PV, et al. Delayed presentation of an extradural abscess complicating thoracic extradural analgesia. Br J Anaesth. Jan. 1992;68(1):103-5. [pmid: 1739546].
2307 Spadaro A, Scrivo R, Riccieri V, et al. Effect of tumor necrosis factor alpha antagonists in a patient with rheumatoid arthritis and primary biliary cirrhosis. Joint Bone Spine. Jan. 2008;75(1):87-9. [pmid: 17890133].
2308 Spalding JR, Hay J. Cost effectiveness of tumour necrosis factor-alpha inhibitors as first-line agents in rheumatoid arthritis. Pharmacoeconomics. 2006;24(12):1221-32. [pmid: 17129076].
2309 Spanakis E, Sidiropoulos P, Papadakis J, et al. Modest but sustained increase of serum high density lipoprotein cholesterol levels in patients with inflammatory arthritides treated with infliximab. J Rheumatol. Dec. 2006;33(12):2440-6. [pmid: 17014005].
2310 Sperling RI, Coblyn JS, Larkin JK, et al. Inhibition of leukotriene B4 synthesis in neutrophils from patients with rheumatoid arthritis by a single oral dose of methotrexate. Arthritis Rheum. Aug. 1990;33(8):1149-55. [pmid: 2167685].
2311 Sprekeler R, Lemmel EM, Obert HJ. Correlation of clinical and serological findings in patients with rheumatoid arthritis treated for one year with interferon-gamma. Z Rheumatol. Jan–Feb. 1990;49(1):1-7. [pmid: 2109438].
2312 Squirrell DM, Winfield J, Amos RS. Peripheral ulcerative keratitis ‘corneal melt’ and rheumatoid arthritis: a case series. Rheumatology (Oxford). Dec. 1999;38(12):1245-8. [pmid: 10587553].
2313 Sri JC, Tsai CL, Deng A, et al. Osteomyelitis occurring during infliximab treatment of severe psoriasis. J Drugs Dermatol. Feb. 2007;6(2):207-10. [pmid: 17373180].
2314 Srivastava KC, Mustafa T. Ginger (Zingiber officinale) in rheumatism and musculoskeletal disorders. Med Hypotheses. Dec. 1992;39(4):342-8. [pmid: 1494322].
2315 St Clair EW, van der Heijde DM, Smolen JS, et al. Combination of infliximab and methotrexate therapy for early rheumatoid arthritis: a randomized, controlled trial. Arthritis Rheum. Nov. 2004;50(11):3432-43. [pmid: 15529377].
2316 Stafford L, Bleasel J, Giles A, et al. Androgen deficiency and bone mineral density in men with rheumatoid arthritis. J Rheumatol. Dec. 2000;27(12):2786-90. [pmid: 11128664].
2317 Stalenheim G, Gudbjornsson B. Anti-inflammatory drugs do not alleviate bronchial hyperreactivity in Sjogren’s syndrome. Allergy. Apr. 1997;52(4):423-7. [pmid: 9188924].
2318 Stamp LK, O’Donnell JL, Chapman PT, et al. Determinants of red blood cell methotrexate polyglutamate concentrations in rheumatoid arthritis patients receiving long-term methotrexate treatment. Arthritis Rheum. Aug. 2009;60(8):2248-56. [pmid: 19644853].
2319 Stamp LK, O’Donnell JL, Chapman PT, et al. Methotrexate polyglutamate concentrations are not associated with disease control in rheumatoid arthritis patients receiving long-term methotrexate therapy. Arthritis Rheum. Feb. 2010;62(2):359-68. [pmid: 20112376].
2320 Stanescu D, Bodaghi B, Huong du LT, et al. Pseudotumor cerebri associated with Sjogren’s syndrome. Graefes Arch Clin Exp Ophthalmol. Apr. 2003;241(4):339-42. [pmid: 12719998].
2321 Starmans-Kool MJ, Peeters HR, Houben HH. Pustular skin lesions in patients treated with infliximab: report of two cases. Rheumatol Int. Sep. 2005;25(7):550-2. [pmid: 15711788].
2322 Starosta MA, Brandwein SR. Clinical manifestations and treatment of rheumatoid pachymeningitis. Neurology. Mar. 27. 2007;68(13):1079-80. [pmid: 17389318].
2323 Steens SC, Steup-Beekman GM, Bosma GP, et al. The effect of corticosteroid medication on quantitative MR parameters of the brain. AJNR Am J Neuroradiol. Nov–Dec. 2005;26(10):2475-80. [pmid: 16286387].
2324 Steinfeld SD, Demols P, Salmon I, et al. Infliximab in patients with primary Sjogren’s syndrome: a pilot study. Arthritis Rheum. Oct. 2001;44(10):2371-5. [pmid: 11665979].
2325 Stepien KE, Han DP, Schell J, et al. Spectral-domain optical coherence tomography and adaptive optics may detect hydroxychloroquine retinal toxicity before symptomatic vision loss. Trans Am Ophthalmol Soc. Dec. 2009;107:28-33. [pmid: 20126479].
2326 Sterling LP. Rheumatoid arthritis: current concepts and management, Part 2. Am Pharm. Sep. 1990;NS30(9):49-54. [pmid: 1977296].
2327 Stern R, Wolfe F. Infliximab dose and clinical status: results of 2 studies in 1642 patients with rheumatoid arthritis. J Rheumatol. Aug. 2004;31(8):1538-45. [pmid: 15290732].
2328 Sterry W, Ortonne JP, Kirkham B, et al. Comparison of two etanercept regimens for treatment of psoriasis and psoriatic arthritis: PRESTA randomised double blind multicentre trial. Bmj. 2010;340:c147. [pmid: 20124563].
2329 Stewart M, Malkovska V, Krishnan J, et al. Lymphoma in a patient with rheumatoid arthritis receiving methotrexate treatment: successful treatment with rituximab. Ann Rheum Dis. Sep. 2001;60(9):892-3. [pmid: 11502618].
2330 Stewart MW, Palmer DG, Knight RG. A self-report articular index measure of arthritic activity: investigations of reliability, validity and sensitivity. J Rheumatol. Aug. 1990;17(8):1011-5. [pmid: 2213775].
2331 Stock CJ, Ogilvie EM, Samuel JM, et al. Comprehensive association study of genetic variants in the IL-1 gene family in systemic juvenile idiopathic arthritis. Genes Immun. Jun. 2008;9(4):349-57. [pmid: 18418395].
2332 Stokes MB, Foster K, Markowitz GS, et al. Development of glomerulonephritis during anti-TNF-alpha therapy for rheumatoid arthritis. Nephrol Dial Transplant. Jul. 2005;20(7):1400-6. [pmid: 15840673].
2333 Stoll ML, Solomon DH, Batra KL, et al. TNFalpha inhibitors may improve asthma symptoms: a case series of 12 patients with rheumatoid arthritis and asthma. J Clin Rheumatol. Jun. 2009;15(4):198-200. [pmid: 19455057].
2334 Stone M, Salonen D, Lax M, et al. Clinical and imaging correlates of response to treatment with infliximab in patients with ankylosing spondylitis. J Rheumatol. Jul. 2001;28(7):1605-14. [pmid: 11469469].
2335 Stone MA, Inman RD, Wright JG, et al. Validation exercise of the Ankylosing Spondylitis Assessment Study (ASAS) group response criteria in ankylosing spondylitis patients treated with biologics. Arthritis Rheum. Jun. 15. 2004;51(3):316-20. [pmid: 15188313].
2336 Stone MA, Payne U, Pacheco-Tena C, et al. Cytokine correlates of clinical response patterns to infliximab treatment of ankylosing spondylitis. Ann Rheum Dis. Jan. 2004;63(1):84-7. [pmid: 14672897].
2337 Strangfeld A, Hierse F, Rau R, et al. Risk of incident or recurrent malignancies among patients with rheumatoid arthritis exposed to biologic therapy in the German biologics register RABBIT. Arthritis Res Ther. 2010;12(1):R5. [pmid: 20064207].
2338 Strangfeld A, Listing J, Herzer P, et al. Risk of herpes zoster in patients with rheumatoid arthritis treated with anti-TNF-alpha agents. Jama. 2009;301(7):737-44. [pmid: 19224750].
2339 Stranzl T, Wolf J, Leeb BF, et al. Expression of folylpolyglutamyl synthetase predicts poor response to methotrexate therapy in patients with rheumatoid arthritis. Clin Exp Rheumatol. Jan–Feb. 2003;21(1):27-32. [pmid: 12673886].
2340 Stratigos AJ, Antoniou C, Stamathioudaki S, et al. Discoid lupus erythematosus-like eruption induced by infliximab. Clin Exp Dermatol. Mar. 2004;29(2):150-3. [pmid: 14987271].
2341 Straub RH, Gunzler C, Miller LE, et al. Anti-inflammatory cooperativity of corticosteroids and norepinephrine in rheumatoid arthritis synovial tissue in vivo and in vitro. Faseb J. Jul. 2002;16(9):993-1000. [pmid: 12087060].
2342 Straub RH, Harle P, Atzeni F, et al. Sex hormone concentrations in patients with rheumatoid arthritis are not normalized during 12 weeks of anti-tumor necrosis factor therapy. J Rheumatol. Jul. 2005;32(7):1253-8. [pmid: 15996060].
2343 Straub RH, Harle P, Yamana S, et al. Anti-interleukin-6 receptor antibody therapy favors adrenal androgen secretion in patients with rheumatoid arthritis: a randomized, double-blind, placebo-controlled study. Arthritis Rheum. Jun. 2006;54(6):1778-85. [pmid: 16729287].
2344 Straub RH, Kittner JM, Heijnen C, et al. Infusion of epinephrine decreases serum levels of cortisol and 17-hydroxyprogesterone in patients with rheumatoid arthritis. J Rheumatol. Aug. 2002;29(8):1659-64. [pmid: 12180725].
2345 Straub RH, Paimela L, Peltomaa R, et al. Inadequately low serum levels of steroid hormones in relation to interleukin-6 and tumor necrosis factor in untreated patients with early rheumatoid arthritis and reactive arthritis. Arthritis Rheum. Mar. 2002;46(3):654-62. [pmid: 11920401].
2346 Straub RH, Pongratz G, Cutolo M, et al. Increased cortisol relative to adrenocorticotropic hormone predicts improvement during anti-tumor necrosis factor therapy in rheumatoid arthritis. Arthritis Rheum. Apr. 2008;58(4):976-84. [pmid: 18383357].
2347 Straub RH, Pongratz G, Hirvonen H, et al. Acute cold stress in rheumatoid arthritis inadequately activates stress responses and induces an increase of interleukin 6. Ann Rheum Dis. Apr. 2009;68(4):572-8. [pmid: 18413439].
2348 Straub RH, Pongratz G, Scholmerich J, et al. Long-term anti-tumor necrosis factor antibody therapy in rheumatoid arthritis patients sensitizes the pituitary gland and favors adrenal androgen secretion. Arthritis Rheum. Jun. 2003;48(6):1504-12. [pmid: 12794817].
2349 Straub RH, Sarzi-Puttini P, Atzeni F, et al. Anti-tumour necrosis factor antibody treatment does not change serum levels of cortisol binding globulin in patients with rheumatoid arthritis but it increases androstenedione relative to cortisol. Ann Rheum Dis. Sep. 2005;64(9):1353-6. [pmid: 15708882].
2350 Straub RH, Weidler C, Demmel B, et al. Renal clearance and daily excretion of cortisol and adrenal androgens in patients with rheumatoid arthritis and systemic lupus erythematosus. Ann Rheum Dis. Aug. 2004;63(8):961-8. [pmid: 15249323].
2351 Strober B, Teller C, Yamauchi P, et al. Effects of etanercept on C-reactive protein levels in psoriasis and psoriatic arthritis. Br J Dermatol. Aug. 2008;159(2):322-30. [pmid: 18503600].
2352 Strober BE. Successful treatment of psoriasis and psoriatic arthritis with etanercept and methotrexate in a patient newly unresponsive to infliximab. Arch Dermatol. Mar. 2004;140(3):366. [pmid: 15023789].
2353 Strober BE, Clarke S. Etanercept for the treatment of psoriasis: combination therapy with other modalities. J Drugs Dermatol. May–Jun. 2004;3(3):270-2. [pmid: 15176161].
2354 Stucki G, Bruhlmann P, Stoll T, et al. Low serum creatine kinase activity is associated with muscle weakness in patients with rheumatoid arthritis. J Rheumatol. Apr. 1996;23(4):603-8. [pmid: 8730112].
2355 Studenski SA. Rheumatology, geriatrics, and a way forward. J Am Geriatr Soc. Oct. 2002;50(10):1737-8. [pmid: 12366631].
2356 Suarez-Almazor ME, Soskolne CL, Saunders LD, et al. Use of second line drugs for the treatment of rheumatoid arthritis in Edmonton, Alberta. Patterns of prescription and longterm effectiveness. J Rheumatol. May. 1995;22(5):836-43. [pmid: 8587069].
2357 Sugihara M, Tsutsumi A, Suzuki E, et al. Effects of infliximab therapy on gene expression levels of tumor necrosis factor alpha, tristetraprolin, T cell intracellular antigen 1, and Hu antigen R in patients with rheumatoid arthritis. Arthritis Rheum. Jul. 2007;56(7):2160-9. [pmid: 17599736].
2358 Sugimori S, Watanabe T, Tabuchi M, et al. Evaluation of small bowel injury in patients with rheumatoid arthritis by capsule endoscopy: effects of anti-rheumatoid arthritis drugs. Digestion. 2008;78(4):208-13. [pmid: 19142000].
2359 Sugimoto T, Yasuda M, Sakaguchi M, et al. Acute interstitial nephritis associated with etanercept. Rheumatol Int. Oct. 2008;28(12):1283-4. [pmid: 18493765].
2360 Sugioka Y, Inui K, Koike T. Use of etanercept in a patient with rheumatoid arthritis on hemodialysis. Mod Rheumatol. 2008;18(3):293-5. [pmid: 18299957].
2361 Suissa S, Bernatsky S, Hudson M. Antirheumatic drug use and the risk of acute myocardial infarction. Arthritis Rheum. 2006;55(4):531-6. [pmid: 16874796].
2362 Suissa S, Ernst P, Hudson M. TNF-alpha antagonists and the prevention of hospitalisation for chronic obstructive pulmonary disease. Pulm Pharmacol Ther. 2008;21(1):234-8. [pmid: 17517530].
2363 Suissa S, Hudson M, Ernst P. Leflunomide use and the risk of interstitial lung disease in rheumatoid arthritis. Arthritis Rheum. May. 2006;54(5):1435-9. [pmid: 16645972].
2364 Sulit DJ, Clarke JE. Psoriatic arthritis in a military aviator. Aviat Space Environ Med. Jul. 2005;76(7):684-8. [pmid: 16018354].
2365 Sulli A, Maestroni GJ, Villaggio B, et al. Melatonin serum levels in rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2002;966:276-83. [pmid: 12114284].
2366 Sulli A, Montecucco CM, Caporali R, et al. Glucocorticoid effects on adrenal steroids and cytokine responsiveness in polymyalgia rheumatica and elderly onset rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2006;1069:307-14. [pmid: 16855158].
2367 Sundberg E, Grundtman C, Af Klint E, et al. Systemic TNF blockade does not modulate synovial expression of the pro-inflammatory mediator HMGB1 in rheumatoid arthritis patients--a prospective clinical study. Arthritis Res Ther. 2008;10(2):R33. [pmid: 18346273].
2368 Suresh R, Gupta S, Sathananthan R. Sulphasalazine induced three-week syndrome. J Clin Rheumatol. Sep. 2009;15(6):311-2. [pmid: 19734741].
2369 Suwannalai P, Auethavekiat P, Udomsubpayakul U, et al. The infectious profiles of anti-tumor necrosis factor agents in a Thai population: a retrospective study a the university-based hospital. Int J Rheum Dis. 2009;12(2):118-24. [pmid: 20374328].
2370 Suzuki K, Kimura Y, Aoki M, et al. Persistent plaques and linear pigmentation in adult-onset Still’s disease. Dermatology. 2001;202(4):333-5. [pmid: 11455148].
2371 Suzuki K, Saito K, Tsujimura S, et al. Tacrolimus, a calcineurin inhibitor, overcomes treatment unresponsiveness mediated by P-glycoprotein on lymphocytes in refractory rheumatoid arthritis. J Rheumatol. Mar. 2010;37(3):512-20. [pmid: 20080907].
2372 Suzuki T, Tsutsumi A, Suzuki H, et al. Tristetraprolin (TTP) gene polymorphisms in patients with rheumatoid arthritis and healthy individuals. Mod Rheumatol. 2008;18(5):472-9. [pmid: 18536977].
2373 Suzuki Y, Inoue K, Chiba J, et al. Histological analysis of synovium by treatment of etanercept for rheumatoid arthritis. Int J Rheum Dis. Apr. 2009;12(1):7-13. [pmid: 20374310].
2374 Suzuki Y, Mizushima Y. Osteoporosis in rheumatoid arthritis. Osteoporos Int. 1997;7(Suppl 3):S217-22. [pmid: 9536336].
2375 Suzuki Y, Uehara R, Tajima C, et al. Elevation of serum hepatic aminotransferases during treatment of rheumatoid arthritis with low-dose methotrexate. Risk factors and response to folic acid. Scand J Rheumatol. 1999;28(5):273-81. [pmid: 10568423].
2376 Svenson M, Geborek P, Saxne T, et al. Monitoring patients treated with anti-TNF-alpha biopharmaceuticals: assessing serum infliximab and anti-infliximab antibodies. Rheumatology (Oxford). Dec. 2007;46(12):1828-34. [pmid: 18032541].
2377 Svensson B, Ahlmen M, Forslind K. Treatment of early RA in clinical practice: a comparative study of two different DMARD/corticosteroid options. Clin Exp Rheumatol. May–Jun. 2003;21(3):327-32. [pmid: 12846051].
2378 Svensson B, Hafstrom I, Forslind K, et al. Increased expression of proto-oncogene survivin predicts Joint destruction and persistent disease activity in early rheumatoid arthritis. Ann Med. 2010;42(1):45-54. [pmid: 20092399].
2379 Svensson B, Schaufelberger C, Teleman A, et al. Remission and response to early treatment of RA assessed by the Disease Activity Score. BARFOT study group. Better Anti-rheumatic Farmacotherapy. Rheumatology (Oxford). Sep. 2000;39(9):1031-6. [pmid: 10986311].
2380 Swale VJ, Perrett CM, Denton CP, et al. Etanercept-induced systemic lupus erythematosus. Clin Exp Dermatol. Nov. 2003;28(6):604-7. [pmid: 14616825].
2381 Swaneveld FH, van Vugt RM, de Boer JP, et al. A 57-year-old man who developed arthritis during R-CHOP chemotherapy for non-Hodgkin lymphoma. Clin Rheumatol. Feb. 2008;27(2):249-51. [pmid: 17660934].
2382 Swanson DL, Barnes SA, Mengden Koon SJ, et al. Caffeine consumption and methotrexate dosing requirement in psoriasis and psoriatic arthritis. Int J Dermatol. Feb. 2007;46(2):157-9. [pmid: 17269967].
2383 Sweet DD, Isac G, Morrison B, et al. Purulent pericarditis in a patient with rheumatoid arthritis treated with etanercept and methotrexate. Cjem. Jan. 2007;9(1):40-2. [pmid: 17391602].
2384 Szeto T, Peterson J, Silva F. A case of tuberculous peritonitis in the United States in a patient with rheumatoid arthritis treated with adalimumab. J Clin Rheumatol. Apr. 2010;16(3):135-7. [pmid: 20375825].
2385 Szturmowicz M, Wilinska E, Paczek A, et al. Primary Sjogren’s Syndrome with two extraglandular sites involvement - case report. Pneumonol Alergol Pol. 2010;78(6):445-50. [pmid: 21077037].
2386 Taban M, Dupps WJ, Mandell B, et al. Etanercept (enbrel)-associated inflammatory eye disease: case report and review of the literature. Ocul Immunol Inflamm. Jun. 2006;14(3):145-50. [pmid: 16766397].
2387 Tack CJ, Kleijwegt FS, Van Riel PL, et al. Development of type 1 diabetes in a patient treated with anti-TNF-alpha therapy for active rheumatoid arthritis. Diabetologia. Jul. 2009;52(7):1442-4. [pmid: 19440690].
2388 Tada Y, Fukuoka M, Mitamura M, et al. Nocardiosis in adult-onset Still’s disease and vasculitis syndrome. Am J Med Sci. Jul. 2008;336(1):77-80. [pmid: 18626243].
2389 Tai TL, O’Rourke KP, McWeeney M, et al. Pneumocystis carinii pneumonia following a second infusion of infliximab. Rheumatology (Oxford). Aug. 2002;41(8):951-2. [pmid: 12154220].
2390 Taira T, Matsuyama W, Mitsuyama H, et al. Increased serum high mobility group box-1 level in Churg-Strauss syndrome. Clin Exp Immunol. May. 2007;148(2):241-7. [pmid: 17437420].
2391 Taiwo B, Lee C, Venkat D, et al. Can tumor necrosis factor alpha blockade predispose to severe babesiosis?. Arthritis Rheum. Feb. 15. 2007;57(1):179-81. [pmid: 17266091].
2392 Takahashi A, Takeda I, Kanno T, et al. CD8-positive T cell-induced liver damage was found in a patient with polymyositis. Intern Med. 2006;45(18):1059-63. [pmid: 17043378].
2393 Takahashi H, Shigehara K, Yamamoto M, et al. Interferon gamma assay for detecting latent tuberculosis infection in rheumatoid arthritis patients during infliximab administration. Rheumatol Int. Oct. 2007;27(12):1143-8. [pmid: 17503048].
2394 Takahashi H, Tezuka F, Fujita S, et al. Vascular changes in major and lingual minor salivary glands in primary Sjogren’s syndrome. Anal Cell Pathol. Dec. 1995;9(4):243-56. [pmid: 8616101].
2395 Takahashi M, Mizutani H, Nakamura Y, et al. A case of multicentric reticulohistiocytosis, systemic sclerosis and Sjogren syndrome. J Dermatol. Aug. 1997;24(8):530-4. [pmid: 9301147].
2396 Takahashi T, Satoh M, Satoh H. Unilateral acute exacerbation of pulmonary fibrosis in association with Sjogren’s syndrome. Intern Med. Oct. 1996;35(10):811-4. [pmid: 8933193].
2397 Takami A, Nakao S, Miyamori H, et al. Adult-onset Still’s disease with submassive hepatic necrosis. Intern Med. Feb. 1995;34(2):89-91. [pmid: 7727885].
2398 Takasugi JE, Godwin JD. Lung abscess caused by Rhodococcus equi. J Thorac Imaging. Apr. 1991;6(2):72-4. [pmid: 1856905].
2399 Takatori R, Takahashi KA, Tokunaga D, et al. ABCB1 C3435T polymorphism influences methotrexate sensitivity in rheumatoid arthritis patients. Clin Exp Rheumatol. Sep–Oct. 2006;24(5):546-54. [pmid: 17181924].
2400 Takeuchi T, Miyasaka N, Inoue K, et al. Impact of trough serum level on radiographic and clinical response to infliximab plus methotrexate in patients with rheumatoid arthritis: results from the RISING study. Mod Rheumatol. 2009;19(5):478-87. [pmid: 19626391].
2401 Takeuchi T, Tatsuki Y, Nogami Y, et al. Postmarketing surveillance of the safety profile of infliximab in 5000 Japanese patients with rheumatoid arthritis. Ann Rheum Dis. Feb. 2008;67(2):189-94. [pmid: 17644554].
2402 Takeuchi T, Yamanaka H, Inoue E, et al. Retrospective clinical study on the notable efficacy and related factors of infliximab therapy in a rheumatoid arthritis management group in Japan: one-year outcome of joint destruction (RECONFIRM-2J). Mod Rheumatol. 2008;18(5):447-54. [pmid: 18493716].
2403 Talip F, Walker N, Khan W, et al. Treatment of Felty’s syndrome with leflunomide. J Rheumatol. Apr. 2001;28(4):868-70. [pmid: 11327265].
2404 Tam LS, Griffith JF, Yu AB, et al. Rapid improvement in rheumatoid arthritis patients on combination of methotrexate and infliximab: clinical and magnetic resonance imaging evaluation. Clin Rheumatol. Jun. 2007;26(6):941-6. [pmid: 16868816].
2405 Tam LS, Tomlinson B, Chu TT, et al. Impact of TNF inhibition on insulin resistance and lipids levels in patients with rheumatoid arthritis. Clin Rheumatol. Sep. 2007;26(9):1495-8. [pmid: 17237906].
2406 Tam MM, Meehan CJ. Subcutaneous granuloma annulare in a patient with rheumatoid arthritis and diabetes mellitus. Australas J Dermatol. Nov. 1996;37(4):199-201. [pmid: 8961588].
2407 Tambo Y, Fujimura M, Yasui M, et al. Eosinophilic pneumonia (EP) associated with rheumatoid arthritis in which drug-induced eosinophilic pneumonia could be ruled out. Intern Med. 2008;47(6):527-31. [pmid: 18344640].
2408 Tamura S, Koreeda T, Nakano T, et al. A case of rheumatoid arthritis which developed after recovery from adult respiratory distress syndrome. Jpn J Med. Nov–Dec. 1990;29(6):611-5. [pmid: 2101412].
2409 Tan AL, Marzo-Ortega H, O’Connor P, et al. Efficacy of anakinra in active ankylosing spondylitis: a clinical and magnetic resonance imaging study. Ann Rheum Dis. Sep. 2004;63(9):1041-5. [pmid: 15066864].
2410 Tan RJ, Gibbons LJ, Potter C, et al. Investigation of rheumatoid arthritis susceptibility genes identifies association of AFF3 and CD226 variants with response to anti-tumour necrosis factor treatment. Ann Rheum Dis. 2010;69(6):1029-35. [pmid: 20444755].
2411 Tanaka A, Shigematsu H, Kojima M, et al. Methotrexate-associated lymphoproliferative disorder arising in a patient with adult Still’s disease. J Oral Maxillofac Surg. Jul. 2008;66(7):1492-5. [pmid: 18571037].
2412 Tanaka E, Inoue E, Kawaguchi Y, et al. Acceptability and usefulness of mizoribine in the management of rheumatoid arthritis in methotrexate-refractory patients and elderly patients, based on analysis of data from a large-scale observational cohort study. Mod Rheumatol. 2006;16(4):214-9. [pmid: 16906370].
2413 Tanaka N, Sakahashi H, Hirose K, et al. Volume of a wash and the other conditions for maximum therapeutic effect of arthroscopic lavage in rheumatoid knees. Clin Rheumatol. Feb. 2006;25(1):65-9. [pmid: 16234990].
2414 Tanaka Y, Takeuchi T, Inoue E, et al. Retrospective clinical study on the notable efficacy and related factors of infliximab therapy in a rheumatoid arthritis management group in Japan: one-year clinical outcomes (RECONFIRM-2). Mod Rheumatol. 2008;18(2):146-52. [pmid: 18283523].
2415 Tanaka Y, Takeuchi T, Mimori T, et al. Discontinuation of infliximab after attaining low disease activity in patients with rheumatoid arthritis: RRR (remission induction by Remicade in RA) study. Ann Rheum Dis. Jul. 2010;69(7):1286-91. [pmid: 20360136].
2416 Tang B, Rahman M, Waters HC, et al. Treatment persistence with adalimumab, etanercept, or infliximab in combination with methotrexate and the effects on health care costs in patients with rheumatoid arthritis. Clin Ther. Jul. 2008;30(7):1375-84. [pmid: 18691998].
2417 Taniguchi A, Urano W, Tanaka E, et al. Validation of the associations between single nucleotide polymorphisms or haplotypes and responses to disease-modifying antirheumatic drugs in patients with rheumatoid arthritis: a proposal for prospective pharmacogenomic study in clinical practice. Pharmacogenet Genomics. Jun. 2007;17(6):383-90. [pmid: 17502830].
2418 Tanno M, Nakajima A, Ishiwata T, et al. Effect of general anesthesia on the abnormal immune response in patients with rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2004;22(6):727-32. [pmid: 15638047].
2419 Taraborelli M, Andreoli L, Archetti S, et al. Methylenetetrahydrofolate reductase polymorphisms and methotrexate: no association with response to therapy nor with drug-related adverse events in an Italian population of rheumatic patients. Clin Exp Rheumatol. 2009;27(3):499-502. [pmid: 19604445].
2420 Targonska-Stepniak B, Majdan M, Dryglewska M. Leptin serum levels in rheumatoid arthritis patients: relation to disease duration and activity. Rheumatol Int. Apr. 2008;28(6):585-91. [pmid: 17968549].
2421 Tascioglu F, Oner C, Armagan O. The effect of low-dose methotrexate on bone mineral density in patients with early rheumatoid arthritis. Rheumatol Int. Sep. 2003;23(5):231-5. [pmid: 14504915].
2422 Tassiopoulos S, Benopoulou O, Mytilineou E, et al. Late onset of long-lasting fever as a sole complication of treatment with anti-TNFalpha. Clin Exp Rheumatol. Jan–Feb. 2005;23(1):122-3. [pmid: 15789902].
2423 Tateiwa T, Shinmura K, Ko M, et al. Iliopectineal bursitis associated with rapid destruction of a rheumatoid hip joint. J Orthop Sci. Jul. 2009;14(4):455-8. [pmid: 19662482].
2424 Tauber T, Turetz J, Barash J, et al. Optic neuritis associated with etanercept therapy for juvenile arthritis. J Aapos. Feb. 2006;10(1):26-9. [pmid: 16527676].
2425 Taylor JC, Orkin R, Lanham J. Tuberculosis following therapy with infliximab may be refractory to antibiotic therapy. Rheumatology (Oxford). Jul. 2003;42(7):901-2. [pmid: 12826707].
2426 Taylor WJ, Rajapakse CN, Harris KA, et al. Inpatient treatment of rheumatoid arthritis with synacthen depot: a double blind placebo controlled trial with 6 month followup. J Rheumatol. Dec. 1999;26(12):2544-50. [pmid: 10606361].
2427 Tchetverikov I, Kraan MC, van El B, et al. Leflunomide and methotrexate reduce levels of activated matrix metalloproteinases in complexes with alpha2 macroglobulin in serum of rheumatoid arthritis patients. Ann Rheum Dis. Jan. 2008;67(1):128-30. [pmid: 17875551].
2428 Teh J, Stevens K, Williamson L, et al. Power Doppler ultrasound of rheumatoid synovitis: quantification of therapeutic response. Br J Radiol. Dec. 2003;76(912):875-9. [pmid: 14711774].
2429 Tektonidou MG, Skopouli FN. Visceral leishmaniasis in a patient with psoriatic arthritis treated with infliximab: reactivation of a latent infection?. Clin Rheumatol. Apr. 2008;27(4):541-2. [pmid: 17963018].
2430 Temekonidis TI, Alamanos Y, Nikas SN, et al. Infliximab therapy in patients with ankylosing spondylitis: an open label 12 month study. Ann Rheum Dis. Dec. 2003;62(12):1218-20. [pmid: 14644863].
2431 Temekonidis TI, Georgiadis AN, Alamanos Y, et al. Infliximab treatment in combination with cyclosporin A in patients with severe refractory rheumatoid arthritis. Ann Rheum Dis. Sep. 2002;61(9):822-5. [pmid: 12176808].
2432 ten Tusscher MP, Jacobs PJ, Busch MJ, et al. Bilateral anterior toxic optic neuropathy and the use of infliximab. BMJ. Mar. 15. 2003;326(7389):579. [pmid: 12637403].
2433 Teng YK, Levarht EW, Hashemi M, et al. Immunohistochemical analysis as a means to predict responsiveness to rituximab treatment. Arthritis Rheum. Dec. 2007;56(12):3909-18. [pmid: 18050222].
2434 Teng YK, Levarht EW, Toes RE, et al. Residual inflammation after rituximab treatment is associated with sustained synovial plasma cell infiltration and enhanced B cell repopulation. Ann Rheum Dis. Jun. 2009;68(6):1011-6. [pmid: 18647852].
2435 Tengstrand B, Carlstrom K, Fellander-Tsai L, et al. Abnormal levels of serum dehydroepiandrosterone, estrone, and estradiol in men with rheumatoid arthritis: high correlation between serum estradiol and current degree of inflammation. J Rheumatol. Nov. 2003;30(11):2338-43. [pmid: 14677174].
2436 Tengstrand B, Hafstrom I. Bone mineral density in men with rheumatoid arthritis is associated with erosive disease and sulfasalazine treatment but not with sex hormones. J Rheumatol. Nov. 2002;29(11):2299-305. [pmid: 12415584].
2437 Tengstrand B, Larsson E, Klareskog L, et al. Randomized withdrawal of long-term prednisolone treatment in rheumatoid arthritis: effects on inflammation and bone mineral density. Scand J Rheumatol. Sep–Oct. 2007;36(5):351-8. [pmid: 17963164].
2438 Terrier B, Lacroix C, Guillevin L, et al. Diagnostic and prognostic relevance of neuromuscular biopsy in primary Sjogren’s syndrome-related neuropathy. Arthritis Rheum. Dec. 15. 2007;57(8):1520-9. [pmid: 18050172].
2439 Terslev L, Torp-Pedersen S, Qvistgaard E, et al. Spectral Doppler and resistive index. A promising tool in ultrasonographic evaluation of inflammation in rheumatoid arthritis. Acta Radiol. Nov. 2003;44(6):645-52. [pmid: 14616209].
2440 Terslev L, Torp-Pedersen S, Qvistgaard E, et al. Effects of treatment with etanercept (Enbrel, TNRF:Fc) on rheumatoid arthritis evaluated by Doppler ultrasonography. Ann Rheum Dis. Feb. 2003;62(2):178-81. [pmid: 12525391].
2441 Theodoridou A, Kartsios C, Yiannaki E, et al. Reversible T-large granular lymphocyte expansion and neutropenia associated with adalimumab therapy. Rheumatol Int. Dec. 2006;27(2):201-2. [pmid: 16932958].
2442 Thomaidis T, Schorn C, Flaig W, et al. Immunoadsorption with tryptophan columns: a therapeutic option for the treatment of rheumatoid arthritis with septic complications. J Clin Apher. 2009;24(1):37-41. [pmid: 19156864].
2443 Thomas JE, Taoka CR, Gibbs BT, et al. Fatal pulmonary Mycobacterium abscessus infection in a patient using etanercept. Hawaii Med J. Jan. 2006;65(1):12-5. [pmid: 16602610].
2444 Thomas JW, Pflugfelder SC. Therapy of progressive rheumatoid arthritis-associated corneal ulceration with infliximab. Cornea. Aug. 2005;24(6):742-4. [pmid: 16015096].
2445 Thomason RW, Craig FE, Banks PM, et al. Epstein-Barr virus and lymphoproliferation in methotrexate-treated rheumatoid arthritis. Mod Pathol. Mar. 1996;9(3):261-6. [pmid: 8685225].
2446 Thompson AE, Bashook PG. Rheumatologists’ recommended patient information when prescribing methotrexate for rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2010;28(4):539-45. [pmid: 20663404].
2447 Thonhofer R, Gaugg M, Kriessmayr M, et al. Spontaneous remission of marginal zone B cell lymphoma in a patient with seropositive rheumatoid arthritis after discontinuation of infliximab-methotrexate treatment. Ann Rheum Dis. Jul. 2005;64(7):1098-9. [pmid: 15958773].
2448 Thonhofer R, Soleiman A, Kriessmayr M, et al. Decrease of proteinuria in a patient with adult-onset Still’s disease and glomerulonephritis after anti-TNFalpha therapy. Scand J Rheumatol. Nov–Dec. 2006;35(6):485-8. [pmid: 17343260].
2449 Thorne JE, Volpe NJ, Liu GT. Magnetic resonance imaging of acquired Brown syndrome in a patient with psoriasis. Am J Ophthalmol. Feb. 1999;127(2):233-5. [pmid: 10030581].
2450 Thorne JE, Woreta FA, Dunn JP, et al. Risk of cataract development among children with juvenile idiopathic arthritis-related uveitis treated with topical corticosteroids. Ophthalmology. Jul. 2010;117(7):1436-41. [pmid: 20363502].
2451 Thumboo J, Uramoto K, Shbeeb MI, et al. Risk factors for the development of psoriatic arthritis: a population based nested case control study. J Rheumatol. Apr. 2002;29(4):757-62. [pmid: 11950018].
2452 Thurlings RM, Vos K, Gerlag DM, et al. Disease activity-guided rituximab therapy in rheumatoid arthritis: the effects of re-treatment in initial nonresponders versus initial responders. Arthritis Rheum. Dec. 2008;58(12):3657-64. [pmid: 19035505].
2453 Thurlings RM, Vos K, Wijbrandts CA, et al. Synovial tissue response to rituximab: mechanism of action and identification of biomarkers of response. Ann Rheum Dis. Jul. 2008;67(7):917-25. [pmid: 17965121].
2454 Tiderius CJ, Sandin J, Svensson J, et al. Knee cartilage quality assessed with dGEMRIC in rheumatoid arthritis patients before and after treatment with a TNF inhibitor. Acta Radiol. Nov. 2010;51(9):1034-7. [pmid: 20942734].
2455 Tikiz H, Arslan O, Pirildar T, et al. The effect of anti-tumor necrosis factor (TNF)-alpha therapy with etanercept on endothelial functions in patients with rheumatoid arthritis. Anadolu Kardiyol Derg. Apr. 2010;10(2):98-103. [pmid: 20382605].
2456 Tikly M, Zannettou N, Hopley M. A longitudinal study of rheumatoid arthritis in South Africans. MedGenMed. Feb. 5. 2003;5(1):2. [pmid: 12827063].
2457 Tiliakos AN, Tiliakos NA. Ocular inflammatory disease in patients with RA taking etanercept: is discontinuation of etanercept necessary?. J Rheumatol. Dec. 2003;30(12):2727. [pmid: 14719226].
2458 Tilling L, Townsend S, David J. Methotrexate and hepatic toxicity in rheumatoid arthritis and psoriatic arthritis. Clin Drug Investig. 2006;26(2):55-62.
2459 Todoerti M, Scire CA, Boffini N, et al. Early disease control by low-dose prednisone comedication may affect the quality of remission in patients with early rheumatoid arthritis. Ann N Y Acad Sci. 2010;1193(1):139-45. [pmid: 20398020].
2460 Toh ML, Marotte H, Blond JL, et al. Overexpression of synoviolin in peripheral blood and synoviocytes from rheumatoid arthritis patients and continued elevation in nonresponders to infliximab treatment. Arthritis Rheum. Jul. 2006;54(7):2109-18. [pmid: 16802346].
2461 Tokayer A, Carsons SE, Chokshi B, et al. High levels of interleukin 13 in rheumatoid arthritis sera are modulated by tumor necrosis factor antagonist therapy: association with dendritic cell growth activity. J Rheumatol. Mar. 2002;29(3):454-61. [pmid: 11908556].
2462 Tokuda H, Sakai F, Yamada H, et al. Clinical and radiological features of Pneumocystis pneumonia in patients with rheumatoid arthritis, in comparison with methotrexate pneumonitis and Pneumocystis pneumonia in acquired immunodeficiency syndrome: a multicenter study. Intern Med. 2008;47(10):915-23. [pmid: 18480575].
2463 Tolusso B, Pietrapertosa D, Morelli A, et al. IL-1B and IL-1RN gene polymorphisms in rheumatoid arthritis: relationship with protein plasma levels and response to therapy. Pharmacogenomics. Jul. 2006;7(5):683-95. [pmid: 16886894].
2464 Toms TE, Panoulas VF, John H, et al. Methotrexate therapy associates with reduced prevalence of the metabolic syndrome in rheumatoid arthritis patients over the age of 60- more than just an anti-inflammatory effect? A cross sectional study. Arthritis Res Ther. 2009;11(4):R110. [pmid: 19607680].
2465 Tong D, Eather S, Manolios N. Psoriatic arthritis and chronic lymphoedema: treatment efficacy by adalimumab. Clin Rheumatol. Nov. 2009;28(11):1349-50. [pmid: 19693641].
2466 Toonen EJ, Coenen MJ, Kievit W, et al. The tumour necrosis factor receptor superfamily member 1b 676T>G polymorphism in relation to response to infliximab and adalimumab treatment and disease severity in rheumatoid arthritis. Ann Rheum Dis. Aug. 2008;67(8):1174-7. [pmid: 18385279].
2467 Torii H, Nakagawa H. Infliximab monotherapy in Japanese patients with moderate-to-severe plaque psoriasis and psoriatic arthritis. A randomized, double-blind, placebo-controlled multicenter trial. J Dermatol Sci. Jul. 2010;59(1):40-9. [pmid: 20547039].
2468 Torikai E, Kageyama Y, Suzuki M, et al. The effect of infliximab on chemokines in patients with rheumatoid arthritis. Clin Rheumatol. Jul. 2007;26(7):1088-93. [pmid: 17111092].
2469 Torikai E, Kageyama Y, Takahashi M, et al. The effect of methotrexate on bone metabolism markers in patients with rheumatoid arthritis. Mod Rheumatol. 2006;16(6):350-4. [pmid: 17164995].
2470 Toritsuka Y, Nakamura N, Lee SB, et al. Osteoclastogenesis in iliac bone marrow of patients with rheumatoid arthritis. J Rheumatol. Sep. 1997;24(9):1690-6. [pmid: 9292789].
2471 Torrance GW, Tugwell P, Amorosi S, et al. Improvement in health utility among patients with rheumatoid arthritis treated with adalimumab (a human anti-TNF monoclonal antibody) plus methotrexate. Rheumatology (Oxford). Jun. 2004;43(6):712-8. [pmid: 15039494].
2472 Torre-Cisneros J, Del Castillo M, Caston JJ, et al. Infliximab does not activate replication of lymphotropic herpesviruses in patients with refractory rheumatoid arthritis. Rheumatology (Oxford). Sep. 2005;44(9):1132-5. [pmid: 15927999].
2473 Torsteinsdottir I, Arvidson NG, Hallgren R, et al. Monocyte activation in rheumatoid arthritis (RA): increased integrin, Fc gamma and complement receptor expression and the effect of glucocorticoids. Clin Exp Immunol. Mar. 1999;115(3):554-60. [pmid: 10193433].
2474 Toubi E, Kessel A, Slobodin G, et al. Changes in macrophage function after rituximab treatment in patients with rheumatoid arthritis. Ann Rheum Dis. Jun. 2007;66(6):818-20. [pmid: 17148544].
2475 Tourinho TF, Capp E, Brenol JC, et al. Physical activity prevents bone loss in premenopausal women with rheumatoid arthritis: a cohort study. Rheumatol Int. Aug. 2008;28(10):1001-7. [pmid: 18317768].
2476 Tournadre A, Ledoux-Eberst J, Poujol D, et al. Exacerbation of interstitial lung disease during etanercept therapy: Two cases. Joint Bone Spine. Mar. 2008;75(2):215-8. [pmid: 17977770].
2477 Toussirot E, Berthelot JM, Pertuiset E, et al. Pulmonary nodulosis and aseptic granulomatous lung disease occurring in patients with rheumatoid arthritis receiving tumor necrosis factor-alpha-blocking agent: a case series. J Rheumatol. Nov. 2009;36(11):2421-7. [pmid: 19797509].
2478 Toussirot E, Nguyen NU, Dumoulin G, et al. Relationship between growth hormone-IGF-I-IGFBP-3 axis and serum leptin levels with bone mass and body composition in patients with rheumatoid arthritis. Rheumatology (Oxford). Jan. 2005;44(1):120-5. [pmid: 15466894].
2479 Toussirot E, Pertuiset E, Sordet C, et al. Safety of rituximab in rheumatoid arthritis patients with a history of severe or recurrent bacterial infection: observational study of 30 cases in everyday practice. Joint Bone Spine. Mar. 2010;77(2):142-5. [pmid: 20171921].
2480 Toussirot E, Wendling D. Bacillus calmette-guerin vaccination in a patient treated with infliximab. J Rheumatol. Dec. 2005;32(12):2500-1. [pmid: 16331800].
2481 Toy WC, Jasin HE. An unusual case of hypokalemic paralysis associated with primary Sjogren’s syndrome. J Ark Med Soc. Jun. 2008;104(12):286-7. [pmid: 18564466].
2482 Toyoda T, Inokuchi S, Saito S, et al. Bone loss of the radius in rheumatoid arthritis. Comparison between 34 patients and 40 controls. Acta Orthop Scand. Jun. 1996;67(3):269-73. [pmid: 8686466].
2483 Toyokawa Y, Kingetsu I, Yasuda C, et al. Pancytopenia, including macrocytic anemia, associated with leflunomide in a rheumatoid arthritis patient. Mod Rheumatol. 2007;17(5):436-40. [pmid: 17929140].
2484 Toyozawa S, Yamamoto Y, Nishide T, et al. Case report: a case of pyoderma gangrenosum with intractable leg ulcers treated by allogeneic cultured dermal substitutes. Dermatol Online J. 2008;14(11):17. [pmid: 19094855].
2485 Traer EA, Williams MR, Keenan JN. Erysipelothrix rhusiopathiae infection of a total knee arthroplasty an occupational hazard. J Arthroplasty. Jun. 2008;23(4):609-11. [pmid: 18514883].
2486 Tresch S, Trueb RM, Kamarachev J, et al. Disseminated herpes zoster mimicking rheumatoid vasculitis in a rheumatoid arthritis patient on etanercept. Dermatology. 2009;219(4):347-9. [pmid: 19648728].
2487 Trethewey P. The role of tumor necrosis factor inhibitors in patients with RA. Jaapa. Sep. 2002;15(9):23-4. 7. 30 passim. [pmid: 12395668].
2488 True DG, Penmetcha M, Peckham SJ. Disseminated cryptococcal infection in rheumatoid arthritis treated with methotrexate and infliximab. J Rheumatol. Jul. 2002;29(7):1561-3. [pmid: 12136922].
2489 Tsai TC, Chen CY, Lin WT, et al. Sjogren’s syndrome complicated with IgA nephropathy and leukocytoclastic vasculitis. Ren Fail. 2008;30(7):755-8. [pmid: 18704825].
2490 Tsakonas E, Fitzgerald AA, Fitzcharles MA, et al. Consequences of delayed therapy with second-line agents in rheumatoid arthritis: a 3 year followup on the hydroxychloroquine in early rheumatoid arthritis (HERA) study. J Rheumatol. Mar. 2000;27(3):623-9. [pmid: 10743799].
2491 Tsubota K, Fujita H, Tadano K, et al. Abnormal expression and function of Fas ligand of lacrimal glands and peripheral blood in Sjogren’s syndrome patients with enlarged exocrine glands. Clin Exp Immunol. Jul. 2002;129(1):177-82. [pmid: 12100038].
2492 Tsujimura S, Saito K, Nawata M, et al. Overcoming drug resistance induced by P-glycoprotein on lymphocytes in patients with refractory rheumatoid arthritis. Ann Rheum Dis. Mar. 2008;67(3):380-8. [pmid: 17660216].
2493 Tsukahara S, Momohara S, Ikari K, et al. Disturbances of the symphysis pubis in rheumatoid arthritis: report of two cases. Mod Rheumatol. 2007;17(4):344-7. [pmid: 17694273].
2494 Tsuzaka K, Itami Y, Takeuchi T, et al. ADAMTS5 is a biomarker for prediction of response to infliximab in patients with rheumatoid arthritis. J Rheumatol. Jul. 2010;37(7):1454-60. [pmid: 20516019].
2495 Tubach F, Salmon D, Ravaud P, et al. Risk of tuberculosis is higher with anti-tumor necrosis factor monoclonal antibody therapy than with soluble tumor necrosis factor receptor therapy: The three-year prospective French Research Axed on Tolerance of Biotherapies registry. Arthritis Rheum. Jul. 2009;60(7):1884-94. [pmid: 19565495].
2496 Tudhope SJ, von Delwig A, Falconer J, et al. Profound invariant natural killer T-cell deficiency in inflammatory arthritis. Ann Rheum Dis. Oct. 2010;69(10):1873-9. [pmid: 20444757].
2497 Turesson C, Riesbeck K. Septicemia with Staphylococcus aureus, beta-hemolytic streptococci group B and G, and Escherichia coli in a patient with rheumatoid arthritis treated with a recombinant human interleukin 1 receptor antagonist (Anakinra). J Rheumatol. Sep. 2004;31(9):1876. [pmid: 15338480].
2498 Ueki Y, Sagawa A, Tanimura K, et al. A multicenter study of leukocytapheresis in rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2007;25(6):810-6. [pmid: 18173913].
2499 Umeda N, Ito S, Hayashi T, et al. A patient with rheumatoid arthritis who had a normal delivery under etanercept treatment. Intern Med. 2010;49(2):187-9. [pmid: 20075588].
2500 Uneda S, Sonoki T, Nakamura Y, et al. Rapid vanishing of tumors by withdrawal of methotrexate in Epstein-Barr virus-related B cell lymphoproliferative disorder. Intern Med. 2008;47(15):1445-6. [pmid: 18670155].
2501 Unger L, Kayser M, Nusslein HG. Successful treatment of severe rheumatoid vasculitis by infliximab. Ann Rheum Dis. Jun. 2003;62(6):587-8. [pmid: 12759302].
2502 Unlu E, Pamuk ON, Cakir N. Color and duplex Doppler sonography to detect sacroiliitis and spinal inflammation in ankylosing spondylitis. Can this method reveal response to anti-tumor necrosis factor therapy?. J Rheumatol. Jan. 2007;34(1):110-6. [pmid: 17216679].
2503 Usui Y, Kimula Y, Miura H, et al. A case of bronchiolitis obliterans organizing pneumonia associated with primary Sjogren’s syndrome who died of superimposed diffuse alveolar damage. Respiration. 1992;59(2):122-4. [pmid: 1620982].
2504 Uthman I, Bizri AR, Hajj Ali R, et al. Miliary tuberculosis presenting as tenosynovitis in a case of rheumatoid arthritis. J Infect. Sep. 1998;37(2):196-8. [pmid: 9821101].
2505 Uthman I, Husari A, Touma Z, et al. Fatal streptococcal toxic shock syndrome in a patient with rheumatoid arthritis treated with etanercept. Rheumatology (Oxford). Sep. 2005;44(9):1200-1. [pmid: 15870144].
2506 Uthman I, Vazquez-Abad D, Senecal JL. Distinctive features of idiopathic inflammatory myopathies in French Canadians. Semin Arthritis Rheum. Aug. 1996;26(1):447-58. [pmid: 8870112].
2507 Vaglio A, Palmisano A, Ferretti S, et al. Peripheral inflammatory arthritis in patients with chronic periaortitis: report of five cases and review of the literature. Rheumatology (Oxford). Mar. 2008;47(3):315-8. [pmid: 18218649].
2508 Vaidya B, Pearce SH, Charlton S, et al. An association between the CTLA4 exon 1 polymorphism and early rheumatoid arthritis with autoimmune endocrinopathies. Rheumatology (Oxford). Feb. 2002;41(2):180-3. [pmid: 11886967].
2509 Valentino R, Savastano S, Tommaselli AP, et al. Hormonal pattern in women affected by rheumatoid arthritis. J Endocrinol Invest. Sep. 1993;16(8):619-24. [pmid: 8258650].
2510 Valenzuela-Castano A, Garcia-Lopez A, Perez-Vilches D, et al. The predictive value of the HLA shared epitope for severity of radiological joint damage in patients with rheumatoid arthritis. A 10 year observational prospective study. J Rheumatol. Mar. 2000;27(3):571-4. [pmid: 10743791].
2511 Valleala H, Mandelin J, Laasonen L, et al. Effect of cyclical intermittent etidronate therapy on circulating osteoprotegerin levels in patients with rheumatoid arthritis. Eur J Endocrinol. May. 2003;148(5):527-30. [pmid: 12720535].
2512 Vallerskog T, Heimburger M, Gunnarsson I, et al. Differential effects on BAFF and APRIL levels in rituximab-treated patients with systemic lupus erythematosus and rheumatoid arthritis. Arthritis Res Ther. 2006;8(6):R167. [pmid: 17092341].
2513 Valtysdottir ST, Wide L, Hallgren R. Low serum dehydroepiandrosterone sulfate in women with primary Sjogren’s syndrome as an isolated sign of impaired HPA axis function. J Rheumatol. Jun. 2001;28(6):1259-65. [pmid: 11409117].
2514 Valtysdottir ST, Wide L, Hallgren R. Mental wellbeing and quality of sexual life in women with primary Sjogren’s syndrome are related to circulating dehydroepiandrosterone sulphate. Ann Rheum Dis. Sep. 2003;62(9):875-9. [pmid: 12922962].
2515 van Baarsen LG, Wijbrandts CA, Rustenburg F, et al. Regulation of IFN response gene activity during infliximab treatment in rheumatoid arthritis is associated with clinical response to treatment. Arthritis Res Ther. 2010;12(1):R11. [pmid: 20096109].
2516 van de Putte LB, Atkins C, Malaise M, et al. Efficacy and safety of adalimumab as monotherapy in patients with rheumatoid arthritis for whom previous disease modifying antirheumatic drug treatment has failed. Ann Rheum Dis. May. 2004;63(5):508-16. [pmid: 15082480].
2517 van de Putte LB, Rau R, Breedveld FC, et al. Efficacy and safety of the fully human anti-tumour necrosis factor alpha monoclonal antibody adalimumab (D2E7) in DMARD refractory patients with rheumatoid arthritis: a 12 week, phase II study. Ann Rheum Dis. Dec. 2003;62(12):1168-77. [pmid: 14644854].
2518 van den Bemt BJ, den Broeder AA, Snijders GF, et al. Sustained effect after lowering high-dose infliximab in patients with rheumatoid arthritis: a prospective dose titration study. Ann Rheum Dis. Dec. 2008;67(12):1697-701. [pmid: 18245109].
2519 Van den Bosch F, Kruithof E, Baeten D, et al. Effects of a loading dose regimen of three infusions of chimeric monoclonal antibody to tumour necrosis factor alpha (infliximab) in spondyloarthropathy: an open pilot study. Ann Rheum Dis. Jun. 2000;59(6):428-33. [pmid: 10834859].
2520 Van den Bosch F, Kruithof E, De Vos M, et al. Crohn’s disease associated with spondyloarthropathy: effect of TNF-alpha blockade with infliximab on articular symptoms. Lancet. Nov. 25. 2000;356(9244):1821-2. [pmid: 11117919].
2521 Van den Bosch F, Manger B, Goupille P, et al. Effectiveness of adalimumab in treating patients with active psoriatic arthritis and predictors of good clinical responses for arthritis, skin and nail lesions. Ann Rheum Dis. Feb. 2010;69(2):394-9. [pmid: 19815494].
2522 van den Brink HR, van Wijk MJ, Bijlsma JW. Influence of steroid hormones on proliferation of peripheral blood mononuclear cells in patients with rheumatoid arthritis. Br J Rheumatol. Oct. 1992;31(10):663-7. [pmid: 1393371].
2523 van den Brink HR, van Wijk MJ, Geertzen RG, et al. Influence of corticosteroid pulse therapy on the serum levels of soluble interleukin 2 receptor, interleukin 6 and interleukin 8 in patients with rheumatoid arthritis. J Rheumatol. Mar. 1994;21(3):430-4. [pmid: 7911833].
2524 van den Hout WB, Goekoop-Ruiterman YP, Allaart CF, et al. Cost-utility analysis of treatment strategies in patients with recent-onset rheumatoid arthritis. Arthritis Rheum. Mar. 15. 2009;61(3):291-9. [pmid: 19248130].
2525 van der Bijl AE, Breedveld FC, Antoni CE, et al. An open-label pilot study of the effectiveness of adalimumab in patients with rheumatoid arthritis and previous infliximab treatment: relationship to reasons for failure and anti-infliximab antibody status. Clin Rheumatol. Aug. 2008;27(8):1021-8. [pmid: 18350329].
2526 van der Bijl AE, Emmer BJ, Breedveld FC, et al. Advanced magnetic resonance imaging of the brain in patients treated with TNF-alpha blocking agents. Clin Exp Rheumatol. Mar–Apr. 2007;25(2):301-4. [pmid: 17543158].
2527 van der Bijl AE, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. Infliximab and methotrexate as induction therapy in patients with early rheumatoid arthritis. Arthritis Rheum. Jul. 2007;56(7):2129-34. [pmid: 17599726].
2528 van der Heide A, Jacobs JW, Bijlsma JW, et al. The effectiveness of early treatment with “second-line” antirheumatic drugs. A randomized, controlled trial. Ann Intern Med. Apr. 15. 1996;124(8):699-707. [pmid: 8633829].
2529 van der Heijde D, Burmester G, Melo-Gomes J, et al. The safety and efficacy of adding etanercept to methotrexate or methotrexate to etanercept in moderately active rheumatoid arthritis patients previously treated with monotherapy. Ann Rheum Dis. Feb. 2008;67(2):182-8. [pmid: 17728331].
2530 van der Heijde D, Dijkmans B, Geusens P, et al. Efficacy and safety of infliximab in patients with ankylosing spondylitis: results of a randomized, placebo-controlled trial (ASSERT). Arthritis Rheum. Feb. 2005;52(2):582-91. [pmid: 15692973].
2531 van der Heijde D, Klareskog L, Boers M, et al. Comparison of different definitions to classify remission and sustained remission: 1 year TEMPO results. Ann Rheum Dis. Nov. 2005;64(11):1582-7. [pmid: 15860509].
2532 van der Heijde D, Klareskog L, Rodriguez-Valverde V, et al. Comparison of etanercept and methotrexate, alone and combined, in the treatment of rheumatoid arthritis: two-year clinical and radiographic results from the TEMPO study, a double-blind, randomized trial. Arthritis Rheum. Apr. 2006;54(4):1063-74. [pmid: 16572441].
2533 van der Heijde D, Klareskog L, Singh A, et al. Patient reported outcomes in a trial of combination therapy with etanercept and methotrexate for rheumatoid arthritis: the TEMPO trial. Ann Rheum Dis. Mar. 2006;65(3):328-34. [pmid: 16079172].
2534 van der Heijde D, Landewe R, Klareskog L, et al. Presentation and analysis of data on radiographic outcome in clinical trials: experience from the TEMPO study. Arthritis Rheum. Jan. 2005;52(1):49-60. [pmid: 15641062].
2535 van der Helm-van Mil AH, le Cessie S, van Dongen H, et al. A prediction rule for disease outcome in patients with recent-onset undifferentiated arthritis: how to guide individual treatment decisions. Arthritis Rheum. Feb. 2007;56(2):433-40. [pmid: 17265478].
2536 van der Klooster JM, Bosman RJ, Oudemans-van Straaten HM, et al. Disseminated tuberculosis, pulmonary aspergillosis and cutaneous herpes simplex infection in a patient with infliximab and methotrexate. Intensive Care Med. Dec. 2003;29(12):2327-9. [pmid: 14600805].
2537 van der Kooij SM, de Vries-Bouwstra JK, Goekoop-Ruiterman YP, et al. Patient-reported outcomes in a randomized trial comparing four different treatment strategies in recent-onset rheumatoid arthritis. Arthritis Rheum. Jan. 15. 2009;61(1):4-12. [pmid: 19116965].
2538 van der Kooij SM, de Vries-Bouwstra JK, Goekoop-Ruiterman YP, et al. Limited efficacy of conventional DMARDs after initial methotrexate failure in patients with recent onset rheumatoid arthritis treated according to the disease activity score. Ann Rheum Dis. Oct. 2007;66(10):1356-62. [pmid: 17293364].
2539 van der Kooij SM, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. Drug-free remission, functioning and radiographic damage after 4 years of response-driven treatment in patients with recent-onset rheumatoid arthritis. Ann Rheum Dis. 2009;68(6):914-21. [pmid: 18662933].
2540 van der Kooij SM, le Cessie S, Goekoop-Ruiterman YP, et al. Clinical and radiological efficacy of initial vs delayed treatment with infliximab plus methotrexate in patients with early rheumatoid arthritis. Ann Rheum Dis. Jul. 2009;68(7):1153-8. [pmid: 18930988].
2541 van der Laken CJ, Lems WF, van Soesbergen RM, et al. Paraplegia in a patient receiving anti-tumor necrosis factor therapy for rheumatoid arthritis: comment on the article by Mohan et al. Arthritis Rheum. Jan. 2003;48(1):269-70. [pmid: 12528130].
2542 van der Laken CJ, Voskuyl AE, Roos JC, et al. Imaging and serum analysis of immune complex formation of radiolabelled infliximab and anti-infliximab in responders and non-responders to therapy for rheumatoid arthritis. Ann Rheum Dis. Feb. 2007;66(2):253-6. [pmid: 16793840].
2543 van der Pouw Kraan TC, Wijbrandts CA, van Baarsen LG, et al. Responsiveness to anti-tumour necrosis factor alpha therapy is related to pre-treatment tissue inflammation levels in rheumatoid arthritis patients. Ann Rheum Dis. Apr. 2008;67(4):563-6. [pmid: 18042642].
2544 van der Veen MJ, Bijlsma JW. Effects of different regimes of corticosteroid treatment on calcium and bone metabolism in rheumatoid arthritis. Clin Rheumatol. Sep. 1992;11(3):388-92. [pmid: 1458788].
2545 van der Veen MJ, Bijlsma JW. The effect of methylprednisolone pulse therapy on methotrexate treatment of rheumatoid arthritis. Clin Rheumatol. Dec. 1993;12(4):500-5. [pmid: 8124913].
2546 van der Veen MJ, Dekker JJ, Dinant HJ, et al. Fatal pulmonary fibrosis complicating low dose methotrexate therapy for rheumatoid arthritis. J Rheumatol. Sep. 1995;22(9):1766-8. [pmid: 8523359].
2547 Van Doornum S, McColl G, Wicks IP. Tumour necrosis factor antagonists improve disease activity but not arterial stiffness in rheumatoid arthritis. Rheumatology (Oxford). Nov. 2005;44(11):1428-32. [pmid: 16076882].
2548 van Ede A, den Broeder A, Wagenaar M, et al. Etanercept-related extensive pulmonary nodulosis in a patient with rheumatoid arthritis. J Rheumatol. Jul. 2007;34(7):1590-2. [pmid: 17610313].
2549 van Eijk IC, Peters MJ, Nurmohamed MT, et al. Decrease of fructosamine levels during treatment with adalimumab in patients with both diabetes and rheumatoid arthritis. Eur J Endocrinol. Mar. 2007;156(3):291-3. [pmid: 17322487].
2550 van Everdingen AA, Huisman AM, Wenting MJ, et al. Down regulation of glucocorticoid receptors in early-diagnosed rheumatoid arthritis. Clin Exp Rheumatol. Jul–Aug. 2002;20(4):463-8. [pmid: 12175100].
2551 van Halm VP, Nurmohamed MT, Twisk JW, et al. Disease-modifying antirheumatic drugs are associated with a reduced risk for cardiovascular disease in patients with rheumatoid arthritis: a case control study. Arthritis Res Ther. 2006;8(5):R151. [pmid: 16984661].
2552 van Ingen J, Boeree M, Janssen M, et al. Pulmonary Mycobacterium szulgai infection and treatment in a patient receiving anti-tumor necrosis factor therapy. Nat Clin Pract Rheumatol. Jul. 2007;3(7):414-9. [pmid: 17599076].
2553 van Leeuwen MA, van der Heijde DM, van Rijswijk MH, et al. Interrelationship of outcome measures and process variables in early rheumatoid arthritis. A comparison of radiologic damage, physical disability, joint counts, and acute phase reactants. J Rheumatol. Mar. 1994;21(3):425-9. [pmid: 7516430].
2554 van Leeuwen MA, van Rijswijk MH, van der Heijde DM, et al. The acute-phase response in relation to radiographic progression in early rheumatoid arthritis: a prospective study during the first three years of the disease. Br J Rheumatol. Jun. 1993;32(Suppl 3):9-13. [pmid: 8508266].
2555 van Lieshout AW, Fransen J, Flendrie M, et al. Circulating levels of the chemokine CCL18 but not CXCL16 are elevated and correlate with disease activity in rheumatoid arthritis. Ann Rheum Dis. Oct. 2007;66(10):1334-8. [pmid: 17350968].
2556 van Middendorp H, Geenen R, Sorbi MJ, et al. Neuroendocrine-immune relationships between emotion regulation and health in patients with rheumatoid arthritis. Rheumatology (Oxford). Jul. 2005;44(7):907-11. [pmid: 15814576].
2557 van Oosterhout M, Levarht EW, Sont JK, et al. Clinical efficacy of infliximab plus methotrexate in DMARD naive and DMARD refractory rheumatoid arthritis is associated with decreased synovial expression of TNF alpha and IL18 but not CXCL12. Ann Rheum Dis. Apr. 2005;64(4):537-43. [pmid: 15769913].
2558 van Roon EN, Hoekstra M, Tobi H, et al. Leflunomide in the treatment of rheumatoid arthritis. An analysis of predictors for treatment continuation. Br J Clin Pharmacol. Sep. 2005;60(3):319-25. [pmid: 16120072].
2559 van Roon EN, van den Bemt PM, Jansen TL, et al. An evidence-based assessment of the clinical significance of drug-drug interactions between disease-modifying antirheumatic drugs and non-antirheumatic drugs according to rheumatologists and pharmacists. Clin Ther. Aug. 2009;31(8):1737-46. [pmid: 19808132].
2560 van Roon JA, Hartgring SA, Wenting-van Wijk M, et al. Persistence of interleukin 7 activity and levels on tumour necrosis factor alpha blockade in patients with rheumatoid arthritis. Ann Rheum Dis. May. 2007;66(5):664-9. [pmid: 17185327].
2561 van Staa TP, Geusens P, Bijlsma JW, et al. Clinical assessment of the long-term risk of fracture in patients with rheumatoid arthritis. Arthritis Rheum. Oct. 2006;54(10):3104-12. [pmid: 17009229].
2562 van Thiel RJ, van der Burg S, Groote AD, et al. Bronchiolitis obliterans organizing pneumonia and rheumatoid arthritis. Eur Respir J. Jul. 1991;4(7):905-11. [pmid: 1955014].
2563 Van Tilt I, Lories RJ, Westhovens R, et al. Unusual cervical spine involvement in psoriatic arthritis: a case series. Clin Rheumatol. Nov. 2009;28(11):1343-6. [pmid: 19669083].
2564 van Tuyl LH, Lems WF, Voskuyl AE, et al. Tight control and intensified COBRA combination treatment in early rheumatoid arthritis: 90% remission in a pilot trial. Ann Rheum Dis. Nov. 2008;67(11):1574-7. [pmid: 18625629].
2565 van Tuyl LH, Plass AM, Lems WF, et al. Facilitating the use of COBRA combination therapy in early rheumatoid arthritis: a pilot implementation study. J Rheumatol. Jul. 2009;36(7):1380-6. [pmid: 19487259].
2566 van Vollenhoven R, Harju A, Brannemark S, et al. Treatment with infliximab (Remicade) when etanercept (Enbrel) has failed or vice versa: data from the STURE registry showing that switching tumour necrosis factor alpha blockers can make sense. Ann Rheum Dis. Dec. 2003;62(12):1195-8. [pmid: 14644858].
2567 van Vollenhoven RF, Cifaldi MA, Ray S, et al. Improvement in work place and household productivity for patients with early rheumatoid arthritis treated with adalimumab plus methotrexate: work outcomes and their correlations with clinical and radiographic measures from a randomized controlled trial companion study. Arthritis Care Res (Hoboken). 2010;62(2):226-34. [pmid: 20191522].
2568 van Vollenhoven RF, Emery P, Bingham CO 3rd, et al. Longterm safety of patients receiving rituximab in rheumatoid arthritis clinical trials. J Rheumatol. 2010;37(3):558-67. [pmid: 20110520].
2569 van Vollenhoven RF, Ernestam S, Geborek P, et al. Addition of infliximab compared with addition of sulfasalazine and hydroxychloroquine to methotrexate in patients with early rheumatoid arthritis (Swefot trial): 1-year results of a randomised trial. Lancet. 2009;374(9688):459-66. [pmid: 19665644].
2570 van Vollenhoven RF, Ernestam S, Harju A, et al. Etanercept versus etanercept plus methotrexate: a registry-based study suggesting that the combination is clinically more efficacious. Arthritis Res Ther. 2003;5(6):R347-51. [pmid: 14680509].
2571 van Vollenhoven RF, Houbiers JG, Buttgereit F, et al. The selective estrogen receptor alpha agonist Org 37663 induces estrogenic effects but lacks antirheumatic activity: a phase IIa trial investigating efficacy and safety of Org 37663 in postmenopausal female rheumatoid arthritis patients receiving stable background methotrexate or sulfasalazine. Arthritis Rheum. Feb. 2010;62(2):351-8. [pmid: 20112368].
2572 van Vollenhoven RF, Klareskog L. Infliximab dosage and infusion frequency in clinical practice: experiences in the Stockholm biologics registry STURE. Scand J Rheumatol. Nov–Dec. 2007;36(6):418-23. [pmid: 18092261].
2573 van Woerkom JM, Kruize AA, Geenen R, et al. Safety and efficacy of leflunomide in primary Sjogren’s syndrome: a phase II pilot study. Ann Rheum Dis. Aug. 2007;66(8):1026-32. [pmid: 17223657].
2574 Vander Cruyssen B, Durez P, Westhovens R, et al. Seven-year follow-up of infliximab therapy in rheumatoid arthritis patients with severe long-standing refractory disease: attrition rate and evolution of disease activity. Arthritis Res Ther. 2010;12(3):R77. [pmid: 20459619].
2575 Vandergheynst F, Gosset J, van de Borne P, et al. Myopericarditis revealing adult-onset Still’s disease. Acta Clin Belg. Sep–Oct. 2005;60(4):205-8. [pmid: 16279403].
2576 Vandooren B, Kruithof E, Yu DT, et al. Involvement of matrix metalloproteinases and their inhibitors in peripheral synovitis and down-regulation by tumor necrosis factor alpha blockade in spondylarthropathy. Arthritis Rheum. Sep. 2004;50(9):2942-53. [pmid: 15457463].
2577 Varani K, Massara A, Vincenzi F, et al. Normalization of A2A and A3 adenosine receptor up-regulation in rheumatoid arthritis patients by treatment with anti-tumor necrosis factor alpha but not methotrexate. Arthritis Rheum. Oct. 2009;60(10):2880-91. [pmid: 19790066].
2578 Varatharajan N, Lim IG, Anandacoomarasamy A, et al. Methotrexate: long-term safety and efficacy in an Australian consultant rheumatology practice. Intern Med J. Apr. 2009;39(4):228-36. [pmid: 19402861].
2579 Vasques Godinho FM, Parreira Santos MJ, Canas da Silva J. Refractory adult onset Still’s disease successfully treated with anakinra. Ann Rheum Dis. Apr. 2005;64(4):647-8. [pmid: 15374853].
2580 Vassallo R, Matteson E, Thomas CF Jr. Clinical response of rheumatoid arthritis-associated pulmonary fibrosis to tumor necrosis factor-alpha inhibition. Chest. Sep. 2002;122(3):1093-6. [pmid: 12226061].
2581 Vassilopoulos D, Apostolopoulou A, Hadziyannis E, et al. Long-term safety of anti-TNF treatment in patients with rheumatic diseases and chronic or resolved hepatitis B virus infection. Ann Rheum Dis. Jul. 2010;69(7):1352-5. [pmid: 20472596].
2582 Vassilopoulos D, Sialevris K, Malahtari S, et al. Subacute thyroiditis presenting as fever of unknown origin in a patient with rheumatoid arthritis under etanercept treatment. J Clin Rheumatol. Mar. 2010;16(2):88-9. [pmid: 20216130].
2583 Vastesaeger N, Xu S, Aletaha D, et al. A pilot risk model for the prediction of rapid radiographic progression in rheumatoid arthritis. Rheumatology (Oxford). Sep. 2009;48(9):1114-21. [pmid: 19589891].
2584 Vavricka SR, Wettstein T, Speich R, et al. Pulmonary granulomas after tumour necrosis factor alpha antagonist therapy. Thorax. Mar. 2003;58(3):278-9. [pmid: 12612312].
2585 Vazquez I, Graell E, Gratacos J, et al. Prognostic markers of clinical remission in early rheumatoid arthritis after two years of DMARDs in a clinical setting. Clin Exp Rheumatol. Mar–Apr. 2007;25(2):231-8. [pmid: 17543147].
2586 Vazquez-Del Mercado M, Delgado-Rizo V, Munoz-Valle JF, et al. Expression of interleukin-1 beta, tumor necrosis factor alpha, interleukins-6, -10 and -4, and metalloproteases by freshly isolated mononuclear cells from early never-treated and non-acute treated rheumatoid arthritis patients. Clin Exp Rheumatol. Sep–Oct. 1999;17(5):575-83. [pmid: 10544841].
2587 Vena GA, Altomare G, Ayala F, et al. Incidence of psoriasis and association with comorbidities in Italy: a 5-year observational study from a national primary care database. Eur J Dermatol. Sep–Oct. 2010;20(5):593-8. [pmid: 20605768].
2588 Venarucci D, Catalini P, Scendoni P, et al. Evaluation of certain immunity parameters in rheumatoid arthritis, treated with cortisone. Panminerva Med. Dec. 1994;36(4):188-91. [pmid: 7603736].
2589 Vera-Llonch M, Massarotti E, Wolfe F, et al. Cost-effectiveness of abatacept in patients with moderately to severely active rheumatoid arthritis and inadequate response to tumor necrosis factor-alpha antagonists. J Rheumatol. Sep. 2008;35(9):1745-53. [pmid: 18634164].
2590 Vera-Llonch M, Massarotti E, Wolfe F, et al. Cost-effectiveness of abatacept in patients with moderately to severely active rheumatoid arthritis and inadequate response to methotrexate. Rheumatology (Oxford). Apr. 2008;47(4):535-41. [pmid: 18356179].
2591 Verbruggen LA, Versaen H, Rebmann V, et al. Soluble HLA-DR levels in serum are associated with therapy and genetic factors in rheumatoid arthritis. Hum Immunol. Sep. 2002;63(9):758-64. [pmid: 12175730].
2592 Vergara G, Silvestre JF, Betlloch I, et al. Cutaneous drug eruption to infliximab: report of 4 cases with an interface dermatitis pattern. Arch Dermatol. Sep. 2002;138(9):1258-9. [pmid: 12225003].
2593 Vergunst CE, Gerlag DM, von Moltke L, et al. MLN3897 plus methotrexate in patients with rheumatoid arthritis: safety, efficacy, pharmacokinetics, and pharmacodynamics of an oral CCR1 antagonist in a phase IIa, double-blind, placebo-controlled, randomized, proof-of-concept study. Arthritis Rheum. Dec. 2009;60(12):3572-81. [pmid: 19950299].
2594 Verhave JC, van Altena R, Wijnands MJ, et al. Tuberculous peritonitis during infliximab therapy. Neth J Med. Feb. 2008;66(2):77-80. [pmid: 18292611].
2595 Verhelst X, Orlent H, Colle I, et al. Subfulminant hepatitis B during treatment with adalimumab in a patient with rheumatoid arthritis and chronic hepatitis B. Eur J Gastroenterol Hepatol. Apr. 2010;22(4):494-9. [pmid: 20306568].
2596 Verhoef CM, van Roon JA, Vianen ME, et al. The immune suppressive effect of dexamethasone in rheumatoid arthritis is accompanied by upregulation of interleukin 10 and by differential changes in interferon gamma and interleukin 4 production. Ann Rheum Dis. Jan. 1999;58(1):49-54. [pmid: 10343540].
2597 Verhoeven AC, Boers M, te Koppele JM, et al. Bone turnover, joint damage and bone mineral density in early rheumatoid arthritis treated with combination therapy including high-dose prednisolone. Rheumatology (Oxford). Nov. 2001;40(11):1231-7. [pmid: 11709606].
2598 Verschueren K, Van Essche E, Verschueren P, et al. Development of sarcoidosis in etanercept-treated rheumatoid arthritis patients. Clin Rheumatol. Nov. 2007;26(11):1969-71. [pmid: 17340045].
2599 Verschueren P, Esselens G, Westhovens R. Daily practice effectiveness of a step-down treatment in comparison with a tight step-up for early rheumatoid arthritis. Rheumatology (Oxford). Jan. 2008;47(1):59-64. [pmid: 18039681].
2600 Verstappen SM, Jacobs JW, van der Veen MJ, et al. Intensive treatment with methotrexate in early rheumatoid arthritis: aiming for remission. Computer Assisted Management in Early Rheumatoid Arthritis (CAMERA, an open-label strategy trial). Ann Rheum Dis. Nov. 2007;66(11):1443-9. [pmid: 17519278].
2601 Verwilghen J, Lovis R, De Boer M, et al. Expression of functional B7 and CTLA4 on rheumatoid synovial T cells. J Immunol. Aug. 1. 1994;153(3):1378-85. [pmid: 7517975].
2602 Vidal F, Fontova R, Richart C. Severe neutropenia and thrombocytopenia associated with infliximab. Ann Intern Med. Aug. 5. 2003;139(3):W-W63.
2603 Vieira Serrao V, Martins A, Lopes MJ. Infliximab in recalcitrant generalized pustular arthropatic psoriasis. Eur J Dermatol. Jan–Feb. 2008;18(1):71-3. [pmid: 18086593].
2604 Vigna-Perez M, Abud-Mendoza C, Portillo-Salazar H, et al. Immune effects of therapy with Adalimumab in patients with rheumatoid arthritis. Clin Exp Immunol. Aug. 2005;141(2):372-80. [pmid: 15996202].
2605 Vignes S, Le Moing V, Meekel P, et al. Acquired hemophilia: a rare complication of Sjogren’s syndrome. Clin Exp Rheumatol. Sep–Oct. 1996;14(5):559-60. [pmid: 8913660].
2606 Viguier M, Richette P, Aubin F, et al. Onset of psoriatic arthritis in patients treated with efalizumab for moderate to severe psoriasis. Arthritis Rheum. Jun. 2008;58(6):1796-802. [pmid: 18512820].
2607 Vila AT, Puig L, Fernandez-Figueras MT, et al. Adverse cutaneous reactions to anakinra in patients with rheumatoid arthritis: clinicopathological study of five patients. Br J Dermatol. Aug. 2005;153(2):417-23. [pmid: 16086759].
2608 Vila LM, Molina MJ. Chronic anemia and thrombocytosis as the initial presentation of Still’s disease in an elderly patient. Gerontology. 2007;53(5):289-92. [pmid: 17510560].
2609 Vine JE, Hymes SR, Warner NB, et al. Pustular psoriasis induced by hydroxychloroquine: a case report and review of the literature. J Dermatol. May. 1996;23(5):357-61. [pmid: 8675829].
2610 Vintimilla M, Joseph A, Ranganathan P. Acquired factor VIII inhibitor in Sjogren’s syndrome. Arthritis Care Res (Hoboken). Jul. 2010;62(7):1047-50. [pmid: 20589701].
2611 Virkki LM, Konttinen YT, Peltomaa R, et al. Cost-effectiveness of infliximab in the treatment of rheumatoid arthritis in clinical practice. Clin Exp Rheumatol. Nov–Dec. 2008;26(6):1059-66. [pmid: 19210870].
2612 Virkki LM, Porola P, Forsblad-d’Elia H, et al. Dehydroepiandrosterone (DHEA) substitution treatment for severe fatigue in DHEA-deficient patients with primary Sjogren’s syndrome. Arthritis Care Res (Hoboken). Jan. 15. 2010;62(1):118-24. [pmid: 20191499].
2613 Vis M, Bos WH, Wolbink G, et al. IgM-rheumatoid factor, anti-cyclic citrullinated peptide, and anti-citrullinated human fibrinogen antibodies decrease during treatment with the tumor necrosis factor blocker infliximab in patients with rheumatoid arthritis. J Rheumatol. Mar. 2008;35(3):425-8. [pmid: 18322974].
2614 Vis M, Nurmohamed MT, Wolbink G, et al. Short term effects of infliximab on the lipid profile in patients with rheumatoid arthritis. J Rheumatol. Feb. 2005;32(2):252-5. [pmid: 15693084].
2615 Vis M, Voskuyl AE, Wolbink GJ, et al. Bone mineral density in patients with rheumatoid arthritis treated with infliximab. Ann Rheum Dis. Feb. 2005;64(2):336-7. [pmid: 15647447].
2616 Vis M, Wolbink GJ, Lodder MC, et al. Early changes in bone metabolism in rheumatoid arthritis patients treated with infliximab. Arthritis Rheum. Oct. 2003;48(10):2996-7. [pmid: 14558111].
2617 Visser K, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. A matrix risk model for the prediction of rapid radiographic progression in patients with rheumatoid arthritis receiving different dynamic treatment strategies: post hoc analyses from the BeSt study. Ann Rheum Dis. Jul. 2010;69(7):1333-7. [pmid: 20498212].
2618 Visvanathan S, Wagner C, Rojas J, et al. E-selectin, interleukin 18, serum amyloid a, and matrix metalloproteinase 9 are associated with clinical response to golimumab plus methotrexate in patients with active rheumatoid arthritis despite methotrexate therapy. J Rheumatol. Jul. 2009;36(7):1371-9. [pmid: 19487269].
2619 Visvanathan S, Wagner C, Smolen J, et al. IgG and IgM anticardiolipin antibodies following treatment with infliximab plus methotrexate in patients with early rheumatoid arthritis. Arthritis Rheum. Sep. 2006;54(9):2840-4. [pmid: 16948115].
2620 Vital EM, Dass S, Rawstron AC, et al. Management of nonresponse to rituximab in rheumatoid arthritis: predictors and outcome of re-treatment. Arthritis Rheum. May. 2010;62(5):1273-9. [pmid: 20131284].
2621 Vivarelli M, D’Urbano LE, Insalaco A, et al. Macrophage migration inhibitory factor (MIF) and oligoarticular juvenile idiopathic arthritis (o-JIA): association of MIF promoter polymorphisms with response to intra-articular glucocorticoids. Clin Exp Rheumatol. Sep–Oct. 2007;25(5):775-81. [pmid: 18078632].
2622 Vlachaki E, Psathakis K, Tsintiris K, et al. Delayed response to anti-tuberculosis treatment in a patient on infliximab. Respir Med. May. 2005;99(5):648-52. [pmid: 15823465].
2623 Vlachoyiannopoulos PG, Kanellopoulos PG, Ioannidis JP, et al. Atherosclerosis in premenopausal women with antiphospholipid syndrome and systemic lupus erythematosus: a controlled study. Rheumatology (Oxford). May. 2003;42(5):645-51. [pmid: 12709540].
2624 Vogl D, Falk W, Dorner M, et al. Serum levels of pregnenolone and 17-hydroxypregnenolone in patients with rheumatoid arthritis and systemic lupus erythematosus: relation to other adrenal hormones. J Rheumatol. Feb. 2003;30(2):269-75. [pmid: 12563679].
2625 Volpe A, Caramaschi P, Carletto A, et al. Psoriasis onset during infliximab treatment: description of two cases. Rheumatol Int. Oct. 2006;26(12):1158-60. [pmid: 16738903].
2626 Vonkeman H, ten Napel C, Rasker H, et al. Disseminated primary varicella infection during infliximab treatment. J Rheumatol. Dec. 2004;31(12):2517-8. [pmid: 15570661].
2627 Voog U, Alstergren P, Eliasson S, et al. Progression of radiographic changes in the temporomandibular joints of patients with rheumatoid arthritis in relation to inflammatory markers and mediators in the blood. Acta Odontol Scand. Feb. 2004;62(1):7-13. [pmid: 15124777].
2628 Vordenbaumen S, Neuen-Jacob E, Richter J, et al. Inclusion body myositis in a patient with long standing rheumatoid arthritis treated with anti-TNFalpha and rituximab. Clin Rheumatol. May. 2010;29(5):555-8. [pmid: 20108015].
2629 Vos K, Thurlings RM, Wijbrandts CA, et al. Early effects of rituximab on the synovial cell infiltrate in patients with rheumatoid arthritis. Arthritis Rheum. Mar. 2007;56(3):772-8. [pmid: 17328049].
2630 Voskuyl AE, Van de Laar MA, Moens HJ, et al. Extra-articular manifestations of rheumatoid arthritis: risk factors for serious gastrointestinal events. Ann Rheum Dis. Nov. 1993;52(11):771-5. [pmid: 8250607].
2631 Voskuyl AE, Zwinderman AH, Westedt ML, et al. Factors associated with the development of vasculitis in rheumatoid arthritis: results of a case-control study. Ann Rheum Dis. Mar. 1996;55(3):190-2. [pmid: 8712883].
2632 Voulgarelis M, Giannouli S, Anagnostou D, et al. Combined therapy with rituximab plus cyclophosphamide/doxorubicin/vincristine/prednisone (CHOP) for Sjogren’s syndrome-associated B-cell aggressive non-Hodgkin’s lymphomas. Rheumatology (Oxford). Aug. 2004;43(8):1050-3. [pmid: 15187246].
2633 Voulgari PV, Alamanos Y, Nikas SN, et al. Infliximab therapy in established rheumatoid arthritis: an observational study. Am J Med. May. 2005;118(5):515-20. [pmid: 15866254].
2634 Voulgari PV, Markatseli TE, Exarchou SA, et al. Granuloma annulare induced by anti-tumour necrosis factor therapy. Ann Rheum Dis. Apr. 2008;67(4):567-70. [pmid: 17728330].
2635 Voulgari PV, Venetsanopoulou AI, Exarchou SA, et al. Sustained clinical response and high infliximab survival in psoriatic arthritis patients: a 3-year long-term study. Semin Arthritis Rheum. Apr. 2008;37(5):293-8. [pmid: 17888499].
2636 Voutilainen M, Sokka T, Juhola M, et al. Nonsteroidal anti-inflammatory drug-associated upper gastrointestinal lesions in rheumatoid arthritis patients. Relationships to gastric histology, Helicobacter pylori infection, and other risk factors for peptic ulcer. Scand J Gastroenterol. Aug. 1998;33(8):811-6. [pmid: 9754727].
2637 Vrzogic P, Pasic A, Podobnik-Takac T. Psoriasis vulgaris and arthritis psoriatica gravis mutilans. Acta Dermatovenerol Croat. 2003;11(1):22-8. [pmid: 12718792].
2638 Vytasek R, Sedova L, Vilim V. Increased concentration of two different advanced glycation end-products detected by enzyme immunoassays with new monoclonal antibodies in sera of patients with rheumatoid arthritis. BMC Musculoskelet Disord. 2010;11:83. [pmid: 20433772].
2639 Wachi K, Prasertsuntarasai T, Kishimoto M, et al. T-cell lymphopenia associated with infliximab and cyclophosphamide. Am J Med Sci. Jul. 2005;330(1):48-51. [pmid: 16020999].
2640 Wagner U, Pierer M, Wahle M, et al. Ex vivo homeostatic proliferation of CD4+ T cells in rheumatoid arthritis is dysregulated and driven by membrane-anchored TNFalpha. J Immunol. Aug. 15. 2004;173(4):2825-33. [pmid: 15295001].
2641 Waguri-Nagaya Y, Kobayashi M, Goto H, et al. Septic arthritis of the right ankle caused by Staphylococcus aureus infection in a rheumatoid arthritis patient treated with etanercept. Mod Rheumatol. 2007;17(4):338-40. [pmid: 17694271].
2642 Wakabayashi H, Sudo A, Hasegawa M, et al. Retrospective clinical study of the efficacy of lower-dose methotrexate and infliximab therapy in patients with rheumatoid arthritis. Clin Rheumatol. 2010;29(6):671-5. [pmid: 20204668].
2643 Wakefield RJ, Freeston JE, Hensor EM, et al. Delay in imaging versus clinical response: a rationale for prolonged treatment with anti-tumor necrosis factor medication in early rheumatoid arthritis. Arthritis Rheum. Dec. 15. 2007;57(8):1564-7. [pmid: 18050231].
2644 Wall E, Walker-Bone K. Use of bisphosphonates and dual-energy X-ray absorptiometry scans in the prevention and treatment of glucocorticoid-induced osteoporosis in rheumatology. Qjm. Apr. 2008;101(4):317-23. [pmid: 18270228].
2645 Wallace DJ, Metzger AL, Stecher VJ, et al. Cholesterol-lowering effect of hydroxychloroquine in patients with rheumatic disease: reversal of deleterious effects of steroids on lipids. Am J Med. Sep. 1990;89(3):322-6. [pmid: 2393036].
2646 Wallberg-Jonsson S, Johansson H, Ohman ML, et al. Extent of inflammation predicts cardiovascular disease and overall mortality in seropositive rheumatoid arthritis. A retrospective cohort study from disease onset. J Rheumatol. Dec. 1999;26(12):2562-71. [pmid: 10606363].
2647 Wallberg-Jonsson S, Ohman M, Rantapaa-Dahlqvist S. Which factors are related to the presence of atherosclerosis in rheumatoid arthritis?. Scand J Rheumatol. 2004;33(6):373-9. [pmid: 15794194].
2648 Wallberg-Jonsson S, Ohman ML, Dahlqvist SR. Cardiovascular morbidity and mortality in patients with seropositive rheumatoid arthritis in Northern Sweden. J Rheumatol. Mar. 1997;24(3):445-51. [pmid: 9058647].
2649 Walsh CA, Fearon U, FitzGerald O, et al. Decreased CD20 expression in rheumatoid arthritis synovium following 8 weeks of rituximab therapy. Clin Exp Rheumatol. Jul–Aug. 2008;26(4):656-8. [pmid: 18799100].
2650 Walsh CA, Minnock P, Slattery C, et al. Quality of life and economic impact of switching from established infliximab therapy to adalimumab in patients with rheumatoid arthritis. Rheumatology (Oxford). Jul. 2007;46(7):1148-52. [pmid: 17478471].
2651 Walsh LJ, Wong CA, Pringle M, et al. Use of oral corticosteroids in the community and the prevention of secondary osteoporosis: a cross sectional study. BMJ. Aug. 10. 1996;313(7053):344-6. [pmid: 8760745].
2652 Wang M, Tsai RT, Ou WC, et al. Treatment with cytotoxic immunosuppression agents increases urinary excretion of JCV in patients with autoimmune disease. J Med Virol. Dec. 2000;62(4):505-10. [pmid: 11074480].
2653 Wang SJ, Yang YH, Lin YT, et al. Attained adult height in juvenile rheumatoid arthritis with or without corticosteroid treatment. Clin Rheumatol. Sep. 2002;21(5):363-8. [pmid: 12223982].
2654 Ward MM, Fries JF. Trends in antirheumatic medication use among patients with rheumatoid arthritis, 1981–1996. J Rheumatol. Mar. 1998;25(3):408-16. [pmid: 9517756].
2655 Wardwell NR Jr, Miller R, Ware LB. Pulmonary alveolar proteinosis associated with a disease-modifying antirheumatoid arthritis drug. Respirology. Sep. 2006;11(5):663-5. [pmid: 16916345].
2656 Wasko MC, Hubert HB, Lingala VB, et al. Hydroxychloroquine and risk of diabetes in patients with rheumatoid arthritis. Jama. Jul. 11. 2007;298(2):187-93. [pmid: 17622600].
2657 Wasserman MJ, Weber DA, Guthrie JA, et al. Infusion-related reactions to infliximab in patients with rheumatoid arthritis in a clinical practice setting: relationship to dose, antihistamine pretreatment, and infusion number. J Rheumatol. Oct. 2004;31(10):1912-7. [pmid: 15468353].
2658 Wasserteil V, Bruce S, Sessoms SL, et al. Pyoderma gangrenosum treated with hyperbaric oxygen therapy. Int J Dermatol. Aug. 1992;31(8):594-6. [pmid: 1428456].
2659 Watanabe H, Suzuki R, Asano T, et al. A case of emphysematous pyelonephritis in a patient with rheumatoid arthritis taking corticosteroid and low-dose methotrexate. Int J Rheum Dis. May. 2010;13(2):180-3. [pmid: 20536605].
2660 Watanabe T, Tsuchida T, Furue M, et al. Annular erythema, dermatomyositis, and Sjogren’s syndrome. Int J Dermatol. Apr. 1996;35(4):285-7. [pmid: 8786189].
2661 Watson DJ, Rhodes T, Cai B, et al. Lower risk of thromboembolic cardiovascular events with naproxen among patients with rheumatoid arthritis. Arch Intern Med. May. 27. 2002;162(10):1105-10. [pmid: 12020179].
2662 Weaver AL, Lautzenheiser RL, Schiff MH, et al. Real-world effectiveness of select biologic and DMARD monotherapy and combination therapy in the treatment of rheumatoid arthritis: results from the RADIUS observational registry. Curr Med Res Opin. Jan. 2006;22(1):185-98. [pmid: 16393444].
2663 Weidler C, Struharova S, Schmidt M, et al. Tumor necrosis factor inhibits conversion of dehydroepiandrosterone sulfate (DHEAS) to DHEA in rheumatoid arthritis synovial cells: a prerequisite for local androgen deficiency. Arthritis Rheum. Jun. 2005;52(6):1721-9. [pmid: 15934093].
2664 Weinblatt ME, Abbott GF, Koreishi AF. Case records of the Massachusetts General Hospital. Case 13–2009. A 54-year-old woman with respiratory failure and a cavitary lesion in the lung. N Engl J Med. Apr. 23. 2009;360(17):1770-9. [pmid: 19387019].
2665 Weinblatt ME, Kavanaugh A, Burgos-Vargas R, et al. Treatment of rheumatoid arthritis with a Syk kinase inhibitor: a twelve-week, randomized, placebo-controlled trial. Arthritis Rheum. Nov. 2008;58(11):3309-18. [pmid: 18975322].
2666 Weinblatt ME, Kavanaugh A, Genovese MC, et al. An oral spleen tyrosine kinase (Syk) inhibitor for rheumatoid arthritis. N Engl J Med. Sep. 30. 2010;363(14):1303-12. [pmid: 20879879].
2667 Weinblatt ME, Keystone EC, Furst DE, et al. Adalimumab, a fully human anti-tumor necrosis factor alpha monoclonal antibody, for the treatment of rheumatoid arthritis in patients taking concomitant methotrexate: the ARMADA trial. Arthritis Rheum. Jan. 2003;48(1):35-45. [pmid: 12528101].
2668 Weinblatt ME, Kremer JM, Bankhurst AD, et al. A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. N Engl J Med. Jan. 28. 1999;340(4):253-9. [pmid: 9920948].
2669 Weinblatt ME, Schiff MH, Ruderman EM, et al. Efficacy and safety of etanercept 50 mg twice a week in patients with rheumatoid arthritis who had a suboptimal response to etanercept 50 mg once a week: results of a multicenter, randomized, double-blind, active drug-controlled study. Arthritis Rheum. Jul. 2008;58(7):1921-30. [pmid: 18576334].
2670 Weisman MH, Moreland LW, Furst DE, et al. Efficacy, pharmacokinetic, and safety assessment of adalimumab, a fully human anti-tumor necrosis factor-alpha monoclonal antibody, in adults with rheumatoid arthritis receiving concomitant methotrexate: a pilot study. Clin Ther. Jun. 2003;25(6):1700-21. [pmid: 12860493].
2671 Weisman MH, Paulus HE, Burch FX, et al. A placebo-controlled, randomized, double-blinded study evaluating the safety of etanercept in patients with rheumatoid arthritis and concomitant comorbid diseases. Rheumatology (Oxford). 2007;46(7):1122-5. [pmid: 17470434].
2672 Weiss AH, Wallace CA, Sherry DD. Methotrexate for resistant chronic uveitis in children with juvenile rheumatoid arthritis. J Pediatr. Aug. 1998;133(2):266-8. [pmid: 9709718].
2673 Weitoft T, Forsberg C. Importance of immobilization after intraarticular glucocorticoid treatment for elbow synovitis: a randomized controlled study. Arthritis Care Res (Hoboken). May. 2010;62(5):735-7. [pmid: 20461791].
2674 Weitoft T, Larsson A, Ronnblom L. Serum levels of sex steroid hormones and matrix metalloproteinases after intra-articular glucocorticoid treatment in female patients with rheumatoid arthritis. Ann Rheum Dis. Mar. 2008;67(3):422-4. [pmid: 17878211].
2675 Weitoft T, Ronnblom L. Glucocorticoid resorption and influence on the hypothalamic-pituitary-adrenal axis after intra-articular treatment of the knee in resting and mobile patients. Ann Rheum Dis. Jul. 2006;65(7):955-7. [pmid: 16769782].
2676 Weitoft T, Uddenfeldt P. Importance of synovial fluid aspiration when injecting intra-articular corticosteroids. Ann Rheum Dis. Mar. 2000;59(3):233-5. [pmid: 10700435].
2677 Wells G, Becker JC, Teng J, et al. Validation of the 28-joint Disease Activity Score (DAS28) and European League Against Rheumatism response criteria based on C-reactive protein against disease progression in patients with rheumatoid arthritis, and comparison with the DAS28 based on erythrocyte sedimentation rate. Ann Rheum Dis. Jun. 2009;68(6):954-60. [pmid: 18490431].
2678 Wells G, Li T, Maxwell L, et al. Responsiveness of patient reported outcomes including fatigue, sleep quality, activity limitation, and quality of life following treatment with abatacept for rheumatoid arthritis. Ann Rheum Dis. 2008;67(2):260-5. [pmid: 17846044].
2679 Wells G, Li T, Tugwell P. Investigation into the impact of abatacept on sleep quality in patients with rheumatoid arthritis, and the validity of the MOS-Sleep questionnaire Sleep Disturbance Scale. Ann Rheum Dis. Oct. 2010;69(10):1768-73. [pmid: 20610444].
2680 Wells GA, Boers M, Li T, et al. Investigating the validity of the minimal disease activity state for patients with rheumatoid arthritis treated with abatacept. J Rheumatol. Feb. 2009;36(2):260-5. [pmid: 19208559].
2681 Wendling D, Materne GE, Michel F, et al. Infliximab continuation rates in patients with rheumatoid arthritis in everyday practice. Joint Bone Spine. Jul. 2005;72(4):309-12. [pmid: 16038842].
2682 Wendling D, Streit G, Toussirot E, et al. Herpes zoster in patients taking TNFalpha antagonists for chronic inflammatory joint disease. Joint Bone Spine. Oct. 2008;75(5):540-3. [pmid: 18674945].
2683 Wessels JA, de Vries-Bouwstra JK, Heijmans BT, et al. Efficacy and toxicity of methotrexate in early rheumatoid arthritis are associated with single-nucleotide polymorphisms in genes coding for folate pathway enzymes. Arthritis Rheum. Apr. 2006;54(4):1087-95. [pmid: 16572443].
2684 Wessels JA, Kooloos WM, De Jonge R, et al. Relationship between genetic variants in the adenosine pathway and outcome of methotrexate treatment in patients with recent-onset rheumatoid arthritis. Arthritis Rheum. Sep. 2006;54(9):2830-9. [pmid: 16947783].
2685 Wessels JA, van der Kooij SM, le Cessie S, et al. A clinical pharmacogenetic model to predict the efficacy of methotrexate monotherapy in recent-onset rheumatoid arthritis. Arthritis Rheum. Jun. 2007;56(6):1765-75. [pmid: 17530705].
2686 West SG, Troutner JL, Baker MR, et al. Sacral insufficiency fractures in rheumatoid arthritis. Spine. Sep. 15. 1994;19(18):2117-21. [pmid: 7825055].
2687 Westhovens R, Houssiau F, Joly J, et al. A phase I study assessing the safety, clinical response, and pharmacokinetics of an experimental infliximab formulation for subcutaneous or intramuscular administration in patients with rheumatoid arthritis. J Rheumatol. May. 2006;33(5):847-53. [pmid: 16583466].
2688 Westhovens R, Nijs J, Taelman V, et al. Body composition in rheumatoid arthritis. Br J Rheumatol. Apr. 1997;36(4):444-8. [pmid: 9159537].
2689 Weusten BL, Jacobs JW, Bijlsma JW. Corticosteroid pulse therapy in active rheumatoid arthritis. Semin Arthritis Rheum. Dec. 1993;23(3):183-92. [pmid: 8122121].
2690 Weycker D, Yu EB, Woolley JM, et al. Retrospective study of the costs of care during the first year of therapy with etanercept or infliximab among patients aged > or =65 years with rheumatoid arthritis. Clin Ther. May. 2005;27(5):646-56. [pmid: 15978314].
2691 White D, Fayez S, Doube A. Atherogenic lipid profiles in rheumatoid arthritis. N Z Med J. 2006;119(1240):U2125. [pmid: 16924276].
2692 White KL. Psoriasis and psoriatic arthritis, axial type. Dermatol Online J. Dec. 2001;7(2):12. [pmid: 12165228].
2693 Wiatrowski M, Furfaro N. Patient profiles in psoriatic disease: a case-based approach. Dermatol Nurs. Oct. 2007;(Suppl):5-19. quiz 20–1. [pmid: 18341241].
2694 Wick MC, Ernestam S, Lindblad S, et al. Adalimumab (Humira) restores clinical response in patients with secondary loss of efficacy from infliximab (Remicade) or etanercept (Enbrel): results from the STURE registry at Karolinska University Hospital. Scand J Rheumatol. Sep–Oct. 2005;34(5):353-8. [pmid: 16234182].
2695 Wiens A, Correr CJ, Pontarolo R, et al. A systematic review and meta-analysis of the efficacy and safety of etanercept for treating rheumatoid arthritis. Scand J Immunol. 2009;70(4):337-44. [pmid: 19751268].
2696 Wiens A, Venson R, Correr CJ, et al. Meta-analysis of the efficacy and safety of adalimumab, etanercept, and infliximab for the treatment of rheumatoid arthritis. Pharmacotherapy. 2010;30(4):339-53. [pmid: 20334454].
2697 Wijbrandts CA, Dijkgraaf MG, Kraan MC, et al. The clinical response to infliximab in rheumatoid arthritis is in part dependent on pretreatment tumour necrosis factor alpha expression in the synovium. Ann Rheum Dis. Aug. 2008;67(8):1139-44. [pmid: 18055470].
2698 Wijbrandts CA, Klaasen R, Dijkgraaf MG, et al. Bone mineral density in rheumatoid arthritis patients 1 year after adalimumab therapy: arrest of bone loss. Ann Rheum Dis. Mar. 2009;68(3):373-6. [pmid: 18408246].
2699 Wijbrandts CA, Remans PH, Klarenbeek PL, et al. Analysis of apoptosis in peripheral blood and synovial tissue very early after initiation of infliximab treatment in rheumatoid arthritis patients. Arthritis Rheum. Nov. 2008;58(11):3330-9. [pmid: 18975323].
2700 Wijngaarden S, van de Winkel JG, Bijlsma JW, et al. Treatment of rheumatoid arthritis patients with anti-TNF-alpha monoclonal antibody is accompanied by down-regulation of the activating Fcgamma receptor I on monocytes. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):89-95. [pmid: 18328152].
2701 Wikaningrum R, Highton J, Parker A, et al. Pathogenic mechanisms in the rheumatoid nodule: comparison of proinflammatory cytokine production and cell adhesion molecule expression in rheumatoid nodules and synovial membranes from the same patient. Arthritis Rheum. Oct. 1998;41(10):1783-97. [pmid: 9778219].
2702 Wiland P, Wiela-Hojenska A, Glowska A, et al. Renal function in rheumatoid arthritis patients treated with methotrexate and infliximab. Clin Exp Rheumatol. Jul–Aug. 2004;22(4):469-72. [pmid: 15301246].
2703 Wilder RL. Adrenal and gonadal steroid hormone deficiency in the pathogenesis of rheumatoid arthritis. J Rheumatol Suppl. Mar. 1996;44:10-2. [pmid: 8833045].
2704 Williams CS, Butler E, Roman GC. Treatment of myelopathy in Sjogren syndrome with a combination of prednisone and cyclophosphamide. Arch Neurol. May. 2001;58(5):815-9. [pmid: 11346378].
2705 Wilson ML, Sewell LD, Mowad CM. Primary cutaneous Cryptococcosis during therapy with methotrexate and adalimumab. J Drugs Dermatol. Jan. 2008;7(1):53-4. [pmid: 18246698].
2706 Winfield H, Lain E, Horn T, et al. Eosinophilic cellulitislike reaction to subcutaneous etanercept injection. Arch Dermatol. Feb. 2006;142(2):218-20. [pmid: 16490850].
2707 Wirnsberger RM, de Vries J, Wouters EF, et al. Clinical presentation of sarcoidosis in The Netherlands an epidemiological study. Neth J Med. Aug. 1998;53(2):53-60. [pmid: 9766153].
2708 Wislowska M, Jakubicz D. Preliminary evaluation in rheumatoid arthritis activity in patients treated with TNF-alpha blocker plus methotrexate versus methotrexate or leflunomide alone. Rheumatol Int. May. 2007;27(7):641-7. [pmid: 17235556].
2709 Wittkowski H, Foell D, af Klint E, et al. Effects of intra-articular corticosteroids and anti-TNF therapy on neutrophil activation in rheumatoid arthritis. Ann Rheum Dis. Aug. 2007;66(8):1020-5. [pmid: 17223658].
2710 Wolbink GJ, Voskuyl AE, Lems WF, et al. Relationship between serum trough infliximab levels, pretreatment C reactive protein levels, and clinical response to infliximab treatment in patients with rheumatoid arthritis. Ann Rheum Dis. May. 2005;64(5):704-7. [pmid: 15485995].
2711 Wolf J, Kapral T, Grisar J, et al. Glucocorticoid treatment in rheumatoid arthritis: low-dose therapy does not reduce responsiveness to higher doses. Clin Exp Rheumatol. Jan–Feb. 2008;26(1):113-6. [pmid: 18328156].
2712 Wolfe F, Caplan L, Michaud K. Treatment for rheumatoid arthritis and the risk of hospitalization for pneumonia: associations with prednisone, disease-modifying antirheumatic drugs, and anti-tumor necrosis factor therapy. Arthritis Rheum. Feb. 2006;54(2):628-34. [pmid: 16447241].
2713 Wolfe F, Caplan L, Michaud K. Rheumatoid arthritis treatment and the risk of severe interstitial lung disease. Scand J Rheumatol. 2007;36(3):172-8. [pmid: 17657669].
2714 Wolfe F, Hawley DJ. The comparative risk and predictors of adverse gastrointestinal events in rheumatoid arthritis and osteoarthritis: a prospective 13 year study of 2131 patients. J Rheumatol. Jul. 2000;27(7):1668-73. [pmid: 10914849].
2715 Wolfe F, Marmor MF. Rates and predictors of hydroxychloroquine retinal toxicity in patients with rheumatoid arthritis and systemic lupus erythematosus. Arthritis Care Res (Hoboken). Jun. 2010;62(6):775-84. [pmid: 20535788].
2716 Wolfe F, Michaud K. Lymphoma in rheumatoid arthritis: the effect of methotrexate and anti-tumor necrosis factor therapy in 18,572 patients. Arthritis Rheum. Jun. 2004;50(6):1740-51. [pmid: 15188349].
2717 Wolfe F, Michaud K. Heart failure in rheumatoid arthritis: rates, predictors, and the effect of anti-tumor necrosis factor therapy. Am J Med. Mar. 1. 2004;116(5):305-11. [pmid: 14984815].
2718 Wolfe F, Michaud K. Assessment of pain in rheumatoid arthritis: minimal clinically significant difference, predictors, and the effect of anti-tumor necrosis factor therapy. J Rheumatol. Aug. 2007;34(8):1674-83. [pmid: 17611989].
2719 Wolfe F, Michaud K. The effect of methotrexate and anti-tumor necrosis factor therapy on the risk of lymphoma in rheumatoid arthritis in 19,562 patients during 89,710 person-years of observation. Arthritis Rheum. 2007;56(5):1433-9. [pmid: 17469100].
2720 Wolfe F, Michaud K, Anderson J, et al. Tuberculosis infection in patients with rheumatoid arthritis and the effect of infliximab therapy. Arthritis Rheum. Feb. 2004;50(2):372-9. [pmid: 14872478].
2721 Wolfe F, Michaud K, Li T. Sleep disturbance in patients with rheumatoid arthritis: evaluation by medical outcomes study and visual analog sleep scales. J Rheumatol. Oct. 2006;33(10):1942-51. [pmid: 16960928].
2722 Wollina U, Hansel G, Koch A, et al. Tumor necrosis factor-alpha inhibitor-induced psoriasis or psoriasiform exanthemata: first 120 cases from the literature including a series of six new patients. Am J Clin Dermatol. 2008;9(1):1-14. [pmid: 18092839].
2723 Wollina U, Konrad H. Treatment of recalcitrant psoriatic arthritis with anti-tumor necrosis factor-alpha antibody. J Eur Acad Dermatol Venereol. Mar. 2002;16(2):127-9. [pmid: 12046813].
2724 Wondergem MJ, Voskuyl AE, van Agtmael MA. A case of legionellosis during treatment with a TNFalpha antagonist. Scand J Infect Dis. 2004;36(4):310-1. [pmid: 15198192].
2725 Wong JB, Singh G, Kavanaugh A. Estimating the cost-effectiveness of 54 weeks of infliximab for rheumatoid arthritis. Am J Med. Oct. 1. 2002;113(5):400-8. [pmid: 12401535].
2726 Wong T, Majchrzak B, Bogoch E, et al. Therapeutic implications for interferon-alpha in arthritis: a pilot study. J Rheumatol. May. 2003;30(5):934-40. [pmid: 12734885].
2727 Wood KL, Hage CA, Knox KS, et al. Histoplasmosis after treatment with anti-tumor necrosis factor-alpha therapy. Am J Respir Crit Care Med. May. 1. 2003;167(9):1279-82. [pmid: 12615627].
2728 Wooten MD, Reddy GV, Johnson RD. Atrial fibrillation occurring in a patient taking etanercept plus methotrexate for rheumatoid arthritis. Del Med J. Dec. 2000;72(12):517-9. [pmid: 11200291].
2729 Wright T, Cron RQ. Pediatric rheumatology for the adult rheumatologist II: uveitis in juvenile idiopathic arthritis. J Clin Rheumatol. Aug. 2007;13(4):205-10. [pmid: 17762455].
2730 Wu E, Chen L, Birnbaum H, et al. Cost of care for patients with rheumatoid arthritis receiving TNF-antagonist therapy using claims data. Curr Med Res Opin. Aug. 2007;23(8):1749-59. [pmid: 17588306].
2731 Wulffraat NM, Sanders LA, Kuis W. Autologous hemopoietic stem-cell transplantation for children with refractory autoimmune disease. Curr Rheumatol Rep. Aug. 2000;2(4):316-23. [pmid: 11123077].
2732 Wung PK, Pipeling MR, Wigley FM. “Still” ill?. Am J Med”. Jun. 2008;121(6):491-3. [pmid: 18501228].
2733 Xiao H, Xu J, Zhou X, et al. Associations between the genetic polymorphisms of MTHFR and outcomes of methotrexate treatment in rheumatoid arthritis. Clin Exp Rheumatol. Sep–Oct. 2010;28(5):728-33. [pmid: 20863444].
2734 Xu JX, Hoshida Y, Hongyo T, et al. Analysis of p53 and Bak gene mutations in lymphoproliferative disorders developing in rheumatoid arthritis. J Cancer Res Clin Oncol. Feb. 2007;133(2):125-33. [pmid: 16988840].
2735 Xu Z, Vu T, Lee H, et al. Population pharmacokinetics of golimumab, an anti-tumor necrosis factor-alpha human monoclonal antibody, in patients with psoriatic arthritis. J Clin Pharmacol. Sep. 2009;49(9):1056-70. [pmid: 19617465].
2736 Yakushiji F, Kita M, Hiroi N, et al. Exacerbation of rheumatoid arthritis after removal of adrenal adenoma in Cushing’s syndrome. Endocr J. Apr. 1995;42(2):219-23. [pmid: 7627266].
2737 Yam LY, Wong R. Bronchiolitis obliterans and rheumatoid arthritis. Report of a case in a Chinese patient on d-penicillamine and review of the literature. Ann Acad Med Singapore. May. 1993;22(3):365-8. [pmid: 8373121].
2738 Yamada H, Kato EH, Ebina Y, et al. Fetal treatment of congenital heart block ascribed to anti-SSA antibody: case reports with observation of cardiohemodynamics and review of the literature. Am J Reprod Immunol. Oct. 1999;42(4):226-32. [pmid: 10580604].
2739 Yamada S, Takagi H, Tsuchiya H, et al. Comparative studies on effect of risedronate and alfacalcidol against glucocorticoid-induced osteoporosis in rheumatoid arthritic patients. Yakugaku Zasshi. Sep. 2007;127(9):1491-6. [pmid: 17827929].
2740 Yamada T, Okuda Y, Takasugi K, et al. Relative serum amyloid A (SAA) values: the influence of SAA1 genotypes and corticosteroid treatment in Japanese patients with rheumatoid arthritis. Ann Rheum Dis. Feb. 2001;60(2):124-7. [pmid: 11156544].
2741 Yamamoto M, Takahashi H, Wakasugi H, et al. Leukoencephalopathy during administration of etanercept for refractory rheumatoid arthritis. Mod Rheumatol. 2007;17(1):72-4. [pmid: 17278027].
2742 Yamanaka H, Inoue E, Singh G, et al. Improvement of disease activity of rheumatoid arthritis patients from 2000 to 2006 in a large observational cohort study IORRA in Japan. Mod Rheumatol. 2007;17(4):283-9. [pmid: 17694260].
2743 Yamanaka H, Tanaka Y, Sekiguchi N, et al. Retrospective clinical study on the notable efficacy and related factors of infliximab therapy in a rheumatoid arthritis management group in Japan (RECONFIRM). Mod Rheumatol. 2007;17(1):28-32. [pmid: 17278019].
2744 Yamauchi PS, Gindi V, Lowe NJ. The treatment of psoriasis and psoriatic arthritis with etanercept: practical considerations on monotherapy, combination therapy, and safety. Dermatol Clin. Oct. 2004;22(4):449-59. ix. [pmid: 15450340].
2745 Yamauchi PS, Turner L, Lowe NJ, et al. Treatment of recurrent Sweet’s syndrome with coexisting rheumatoid arthritis with the tumor necrosis factor antagonist etanercept. J Am Acad Dermatol. Mar. 2006;54(3 Suppl 2):S122-6. [pmid: 16488324].
2746 Yamazawa K, Matsui H, Sekiya S. Gastric perforation induced by combination chemotherapy in a patient with long-term use of corticosteroids. Int J Gynaecol Obstet. Aug. 2002;78(2):165-6. [pmid: 12175721].
2747 Yamout B, El-Hajj T, Barada W, et al. Successful treatment of refractory neuroSjogren with Rituximab. Lupus. 2007;16(7):521-3. [pmid: 17670852].
2748 Yang C, Gu J, Rihl M, et al. Serum levels of matrix metalloproteinase 3 and macrophage colony-stimulating factor 1 correlate with disease activity in ankylosing spondylitis. Arthritis Rheum. Oct. 15. 2004;51(5):691-9. [pmid: 15478146].
2749 Yang DH, Chang DM, Lai JH, et al. Etanercept as a rescue agent in patient with adult onset Still’s disease complicated with congestive heart failure. Rheumatol Int. Nov. 2008;29(1):95-8. [pmid: 18500457].
2750 Yasuda M, Yasuda D, Tomooka K, et al. Plasma concentration of human atrial natriuretic hormone in patients with connective tissue diseases. Clin Rheumatol. Jun. 1993;12(2):231-5. [pmid: 8358985].
2751 Yasunori K, Masaaki T, Tetsuyuki N, et al. Reduction of urinary levels of pyridinoline and deoxypyridinoline and serum levels of soluble receptor activator of NF-kappaB ligand by etanercept in patients with rheumatoid arthritis. Clin Rheumatol. Sep. 2008;27(9):1093-101. [pmid: 18338203].
2752 Yazdani C, McLaughlin T, Cummins G, et al. Comparison of rheumatoid arthritis care costs in patients starting therapy with leflunomide versus etanercept. Am J Manag Care. Sep. 2001;7(13 Suppl):S419-26. [pmid: 11594238].
2753 Yazdani-Biuki B, Stadlmaier E, Mulabecirovic A, et al. Blockade of tumour necrosis factor {alpha} significantly alters the serum level of IgG- and IgA-rheumatoid factor in patients with rheumatoid arthritis. Ann Rheum Dis. Aug. 2005;64(8):1224-6. [pmid: 16014683].
2754 Yazdani-Biuki B, Wohlfahrt K, Mulabecirovic A, et al. Long term treatment of psoriatic arthritis with infliximab. Ann Rheum Dis. Nov. 2004;63(11):1531-2. author reply 2. [pmid: 15479917].
2755 Yazici S, Yazici M, Erer B, et al. The platelet indices in patients with rheumatoid arthritis: mean platelet volume reflects disease activity. Platelets. 2010;21(2):122-5. [pmid: 20050760].
2756 Yazici Y, Erkan D. Do etanercept-naive patients with rheumatoid arthritis respond better to infliximab than patients for whom etanercept has failed?. Ann Rheum Dis. May. 2004;63(5):607-8. author reply 8. [pmid: 15082503].
2757 Yazici Y, Erkan D, Kulman I, et al. Decreased flares of rheumatoid arthritis during the first year of etanercept treatment: further evidence of clinical effectiveness in the “real world”. Ann Rheum Dis. Jul. 2002;61(7):638-40. [pmid: 12079908].
2758 Yazici Y, Erkan D, Lockshin MD. A preliminary study of etanercept in the treatment of severe, resistant psoriatic arthritis. Clin Exp Rheumatol. Nov–Dec. 2000;18(6):732-4. [pmid: 11138337].
2759 Yazici Y, Erkan D, Lockshin MD. Etanercept in the treatment of severe, resistant psoriatic arthritis: continued efficacy and changing patterns of use after two years. Clin Exp Rheumatol. Jan–Feb. 2002;20(1):115. [pmid: 11892697].
2760 Yazici Y, Krasnokutsky S, Barnes JP, et al. Changing patterns of tumor necrosis factor inhibitor use in 9074 patients with rheumatoid arthritis. J Rheumatol. May. 2009;36(5):907-13. [pmid: 19332636].
2761 Yazici Y, McMorris BJ, Darkow T, et al. Patient and physician perception of the infusion process of the biologic agents abatacept, infliximab, and rituximab for the treatment of rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2009;27(6):907-13. [pmid: 20149304].
2762 Yee CS, Filer A, Pace A, et al. The prevalence of patients with rheumatoid arthritis in the West Midlands fulfilling the BSR criteria for anti-tumour necrosis factor therapy: an out-patient study. Rheumatology (Oxford). Jul. 2003;42(7):856-9. [pmid: 12730544].
2763 Yeh HM, Liu MF, Chang KK, et al. Adult-onset Still’s disease complicated with hemophagocytic syndrome. J Formos Med Assoc. Jan. 2010;109(1):85-8. [pmid: 20123591].
2764 Yelin E, Trupin L, Katz P, et al. Association between etanercept use and employment outcomes among patients with rheumatoid arthritis. Arthritis Rheum. Nov. 2003;48(11):3046-54. [pmid: 14613265].
2765 Yelin EH, Trupin LS, Katz PP. Impact of managed care on the use of biologic agents for rheumatoid arthritis. Arthritis Rheum. Jun. 15. 2005;53(3):423-30. [pmid: 15934109].
2766 Yeo SW, Park SN. Immune-mediated sensorineural hearing loss in a patient with ankylosing spondylitis: a case report. Otolaryngol Head Neck Surg. Jul. 2001;125(1):113-4. [pmid: 11458230].
2767 Yigla M, Simsolo C, Goralnik L, et al. The problem of empyematous pleural effusion in rheumatoid arthritis: report of two cases and review of the literature. Clin Rheumatol. May. 2002;21(2):180-3. [pmid: 12086173].
2768 Yilmaz L, Ozoran K, Gunduz OH, et al. Alendronate in rheumatoid arthritis patients treated with methotrexate and glucocorticoids. Rheumatol Int. Feb. 2001;20(2):65-9. [pmid: 11269535].
2769 Yim K, Nazeer SH, Kiska D, et al. Recurrent Mycobacterium xenopi infection in a patient with rheumatoid arthritis receiving etanercept. Scand J Infect Dis. 2004;36(2):150-4. [pmid: 15061673].
2770 Yocum DE, Furst DE, Bensen WG, et al. Safety of tacrolimus in patients with rheumatoid arthritis: long-term experience. Rheumatology (Oxford). Aug. 2004;43(8):992-9. [pmid: 15014199].
2771 Yokoo H, Nakazato Y, Harigaya Y, et al. Massive myelinolytic leukoencephalopathy in a patient medicated with low-dose oral methotrexate for rheumatoid arthritis: an autopsy report. Acta Neuropathol. Oct. 2007;114(4):425-30. [pmid: 17357801].
2772 Yokota S, Imagawa T, Mori M, et al. Efficacy and safety of tocilizumab in patients with systemic-onset juvenile idiopathic arthritis: a randomised, double-blind, placebo-controlled, withdrawal phase III trial. Lancet. Mar. 22. 2008;371(9617):998-1006. [pmid: 18358927].
2773 Yokoyama E, Muto M. Adult variant of self-healing papular mucinosis in a patient with rheumatoid arthritis: predominant proliferation of dermal dendritic cells expressing CD34 or factor XIIIa in association with dermal deposition of mucin. J Dermatol. Jan. 2006;33(1):30-5. [pmid: 16469081].
2774 Yonezawa T, Tsuji H, Matsui H, et al. Subaxial lesions in rheumatoid arthritis. Radiographic factors suggestive of lower cervical myelopathy. Spine. Jan. 15. 1995;20(2):208-15. [pmid: 7716627].
2775 Yoshida A, Morozumi K, Suganuma T, et al. Clinicopathological findings of bucillamine-induced nephrotic syndrome in patients with rheumatoid arthritis. Am J Nephrol. 1991;11(4):284-8. [pmid: 1799186].
2776 Yoshida K, Bandoh S, Fujita J, et al. Pyothorax caused by Nocardia otitidiscaviarum in a patient with rheumatoid vasculitis. Intern Med. Jul. 2004;43(7):615-9. [pmid: 15335193].
2777 Yoshida K, Yokoyama T, Toyokawa Y, et al. Cryofibrinogenemia associated with Sjogren’s syndrome: a case of successful treatment with high-dose corticosteroid. Intern Med. 2007;46(13):1039-42. [pmid: 17603248].
2778 Yoshioka T, Tachihara A, Koyama T, et al. Rapid destruction of the hip joint associated with enlarged iliopsoas bursa in a patient with refractory rheumatoid arthritis. J Nippon Med Sch. Aug. 2008;75(4):233-8.
2779 Yosipovitch G, Tang MB. Practical management of psoriasis in the elderly: epidemiology, clinical aspects, quality of life, patient education and treatment options. Drugs Aging. 2002;19(11):847-63. [pmid: 12428994].
2780 You CG, Yin YS, Xie XD, et al. Sex influences on the penetrance of IL-1beta and IL-1RN genotypes for rheumatoid arthritis in the Chinese population. J Int Med Res. May–Jun. 2007;35(3):323-8. [pmid: 17593860].
2781 You CR, Kim HR, Yoon CH, et al. Macrophage activation syndrome in juvenile rheumatoid arthritis successfully treated with cyclosporine A: a case report. J Korean Med Sci. Dec. 2006;21(6):1124-7. [pmid: 17179701].
2782 Youm JY, Woo JH, Kim TH, et al. Interleukin-1beta and interleukin-1 receptor antagonist gene polymorphisms in Korean patients with adult-onset Still’s disease. Scand J Rheumatol. Sep–Oct. 2007;36(5):390-3. [pmid: 17963170].
2783 Young MG, Rijhsinghani S. Leflunomide and acute hypocalcemia. Endocr Pract. Nov–Dec. 2007;13(7):805-7. [pmid: 18194940].
2784 Young PJ, Weeden S, Kirwan JR. The analysis of a bivariate multi-state Markov transition model for rheumatoid arthritis with an incomplete disease history. Stat Med. Jul. 15. 1999;18(13):1677-90. [pmid: 10407237].
2785 Yount S, Sorensen MV, Cella D, et al. Adalimumab plus methotrexate or standard therapy is more effective than methotrexate or standard therapies alone in the treatment of fatigue in patients with active, inadequately treated rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2007;25(6):838-46. [pmid: 18173917].
2786 Yousem SA, Dacic S. Pulmonary lymphohistiocytic reactions temporally related to etanercept therapy. Mod Pathol. May. 2005;18(5):651-5. [pmid: 15529178].
2787 Yu EN, Meniconi ME, Tufail F, et al. Outcomes of treatment with immunomodulatory therapy in patients with corticosteroid-resistant juvenile idiopathic arthritis-associated chronic iridocyclitis. Ocul Immunol Inflamm. Sep–Oct. 2005;13(5):353-60. [pmid: 16419420].
2788 Yu EN, Paredes I, Foster CS. Surgery for hypotony in patients with juvenile idiopathic arthritis-associated uveitis. Ocul Immunol Inflamm. Jan–Feb. 2007;15(1):11-7. [pmid: 17365801].
2789 Yu X, Ma J, Tian J, et al. A controlled study of double filtration plasmapheresis in the treatment of active rheumatoid arthritis. J Clin Rheumatol. Aug. 2007;13(4):193-8. [pmid: 17762452].
2790 Yukawa E, Mori S, Ueda K, et al. Population pharmacokinetic investigation of low-dose methotrexate in rheumatoid arthritics Japanese patients. J Clin Pharm Ther. Dec. 2007;32(6):573-8. [pmid: 18021334].
2791 Yukawa S, Yamaoka K, Sawamukai N, et al. Involvement of mast cells in systemic sclerosis. Nihon Rinsho Meneki Gakkai Kaishi. 2010;33(2):81-6. [pmid: 20453443].
2792 Yukioka M, Komatsubara Y, Yukioka K, et al. Adrenocorticotropic hormone and dehydroepiandrosterone sulfate levels of rheumatoid arthritis patients treated with glucocorticoids. Mod Rheumatol. 2006;16(1):30-5. [pmid: 16622721].
2793 Yum HK, Kim ES, Ok KS, et al. Lymphocytic interstitial pneumonitis associated with Epstein-Barr virus in Systemic Lupus Erythematosus and Sjogren’s Syndrome. Complete remission with corticosteriod and cyclophosphamide. Korean J Intern Med. Sep. 2002;17(3):198-203. [pmid: 12298431].
2794 Yun JE, Lee SW, Kim TH, et al. The incidence and clinical characteristics of Mycobacterium tuberculosis infection among systemic lupus erythematosus and rheumatoid arthritis patients in Korea. Clin Exp Rheumatol. Mar–Apr. 2002;20(2):127-32. [pmid: 12051389].
2795 Zabinski SJ, Sculco TP, Dicarlo EF, et al. Osteonecrosis in the rheumatoid femoral head. J Rheumatol. Sep. 1998;25(9):1674-80. [pmid: 9733445].
2796 Zamarron C, Maceiras F, Gonzalez J, et al. Worsening of obstructive sleep apnoeas in a patient with rheumatoid arthritis treated with anti-tumor necrosis factor. Respir Med. Feb. 2004;98(2):123-5. [pmid: 14971874].
2797 Zamarron C, Maceiras F, Mera A, et al. Effect of the first infliximab infusion on sleep and alertness in patients with active rheumatoid arthritis. Ann Rheum Dis. Jan. 2004;63(1):88-90. [pmid: 14672898].
2798 Zandbelt MM, de Wilde P, van Damme P, et al. Etanercept in the treatment of patients with primary Sjogren’s syndrome: a pilot study. J Rheumatol. Jan. 2004;31(1):96-101. [pmid: 14705226].
2799 Zandbelt MM, van den Hoogen FH, de Wilde PC, et al. Reversibility of histological and immunohistological abnormalities in sublabial salivary gland biopsy specimens following treatment with corticosteroids in Sjogren’s syndrome. Ann Rheum Dis. May. 2001;60(5):511-3. [pmid: 11302875].
2800 Zangrilli A, Papoutsaki M, Talamonti M, et al. Long-term efficacy of adalimumab in generalized pustular psoriasis. J Dermatolog Treat. 2008;19(3):185-7. [pmid: 18569276].
2801 Zautra AJ, Burleson MH, Matt KS, et al. Interpersonal stress, depression, and disease activity in rheumatoid arthritis and osteoarthritis patients. Health Psychol. Mar. 1994;13(2):139-48. [pmid: 8020457].
2802 Zeidler HK, Kvien TK, Hannonen P, et al. Progression of joint damage in early active severe rheumatoid arthritis during 18 months of treatment: comparison of low-dose cyclosporin and parenteral gold. Br J Rheumatol. Aug. 1998;37(8):874-82. [pmid: 9734679].
2803 Zhang LL, Wei W, Xiao F, et al. A randomized, double-blind, multicenter, controlled clinical trial of chicken type II collagen in patients with rheumatoid arthritis. Arthritis Rheum. Jul. 15. 2008;59(7):905-10. [pmid: 18576295].
2804 Zhang W, Bansback N, Guh D, et al. Short-term influence of adalimumab on work productivity outcomes in patients with rheumatoid arthritis. J Rheumatol. Sep. 2008;35(9):1729-36. [pmid: 18688916].
2805 Zhao B, Takami M, Miyamoto Y, et al. Characterization of synovial cell clones isolated from rheumatoid arthritis patients: possible involvement of TNF-alpha in reduction of osteoprotegerin in synovium. Cytokine. Jan. 2008;41(1):61-70. [pmid: 18083042].
2806 Zhou H. Clinical pharmacokinetics of etanercept: a fully humanized soluble recombinant tumor necrosis factor receptor fusion protein. J Clin Pharmacol. May. 2005;45(5):490-7. [pmid: 15831771].
2807 Zhou H, Buckwalter M, Boni J, et al. Population-based pharmacokinetics of the soluble TNFr etanercept: a clinical study in 43 patients with ankylosing spondylitis compared with post hoc data from patients with rheumatoid arthritis. Int J Clin Pharmacol Ther. May. 2004;42(5):267-76. [pmid: 15176649].
2808 Zhou H, Mayer PR, Wajdula J, et al. Unaltered etanercept pharmacokinetics with concurrent methotrexate in patients with rheumatoid arthritis. J Clin Pharmacol. Nov. 2004;44(11):1235-43. [pmid: 15496641].
2809 Zhu G, Liu G, Liu Y, et al. Liver abnormalities in adult onset Still's disease: a retrospective study of 77 Chinese patients. J Clin Rheumatol. Sep. 2009;15(6):284-8. [pmid: 19734733].
2810 Ziakas PD, Giannouli S, Tzioufas AG, et al. Lymphoma development in a patient receiving anti-TNF therapy. Haematologica. Jul. 2003;88(7):ECR25. [pmid: 12857572].
2811 Zikou AK, Argyropoulou MI, Voulgari PV, et al. Magnetic resonance imaging quantification of hand synovitis in patients with rheumatoid arthritis treated with adalimumab. J Rheumatol. Feb. 2006;33(2):219-23. [pmid: 16465650].
2812 Zink A, Listing J, Kary S, et al. Treatment continuation in patients receiving biological agents or conventional DMARD therapy. Ann Rheum Dis. Sep. 2005;64(9):1274-9. [pmid: 15708884].
2813 Zink A, Listing J, Ziemer S, et al. Practice variation in the treatment of rheumatoid arthritis among German rheumatologists. J Rheumatol. Oct. 2001;28(10):2201-8. [pmid: 11669156].
2814 Zintzaras E, Dahabreh IJ, Giannouli S, et al. Infliximab and methotrexate in the treatment of rheumatoid arthritis: a systematic review and meta-analysis of dosage regimens. Clin Ther. Nov. 2008;30(11):1939-55. [pmid: 19108784].
2815 Ziolkowska M, Kurowska M, Radzikowska A, et al. High levels of osteoprotegerin and soluble receptor activator of nuclear factor kappa B ligand in serum of rheumatoid arthritis patients and their normalization after anti-tumor necrosis factor alpha treatment. Arthritis Rheum. Jul. 2002;46(7):1744-53. [pmid: 12124857].
2816 Ziswiler HR, Aeberli D, Villiger PM, et al. High-resolution ultrasound confirms reduced synovial hyperplasia following rituximab treatment in rheumatoid arthritis. Rheumatology (Oxford). Aug. 2009;48(8):939-43. [pmid: 19491302].
2817 Zoli A, Ferlisi EM, Lizzio M, et al. Prolactin/cortisol ratio in rheumatoid arthritis. Ann N Y Acad Sci. Jun. 2002;966:508-12. [pmid: 12114312].
2818 Zoli A, Lizzio MM, Ferlisi EM, et al. ACTH, cortisol and prolactin in active rheumatoid arthritis. Clin Rheumatol. Aug. 2002;21(4):289-93. [pmid: 12189455].
2819 Zoukos Y, Leonard JP, Thomaides T, et al. beta-Adrenergic receptor density and function of peripheral blood mononuclear cells are increased in multiple sclerosis: a regulatory role for cortisol and interleukin-1. Ann Neurol. Jun. 1992;31(6):657-62. [pmid: 1325138].

## Reference Source: International Pharmaceutical Abstracts

1 First Latin American position paper on the pharmacological treatment of rheumatoid arthritis. Rheumatology. 01. 01. 2006;45(JUN):7-2.
2 Aggarwal R, Manadan AM, Poliyedath A, et al. Safety of Etanercept in Patients at High Risk for Mycobacterial Tuberculosis Infections. Journal of Rheumatology. 2009;36:914. [pmid: 19332623].
3 Alcorn N, Saunders S, Madhok R, et al. Benefit-Risk Assessment of Leflunomide An Appraisal of Leflunomide in Rheumatoid Arthritis 10 Years After Licensing. Drug Safety (New Zealand). 2009;32:1123.
4 Aletaha D, Funovits J, Breedveld FC, et al. Rheumatoid Arthritis Joint Progression in Sustained Remission Is Determined by Disease Activity Levels Preceding the Period of Radiographic Assessment. Arthritis and Rheumatism (USA). 2009:601242.
5 Atlizumab - Anti-IL-6 receptor antibody - Chugai, anti-interleukin-6 receptor antibody - Chugai, MRA - Chugai. BioDrugs. 2003;17:369-72. [pmid: 14498766].
6 Tocilizumab for rheumatoid arthritis. Drug and Therapeutics Bulletin (England). 2010;48:9.
7 Antoniu SA. Apr. Cytokine Antagonists for the Treatment of Asthma Progress to Date. BioDrugs (New Zealand). 2009:23241.
8 Asahina A, Ohshima N, Nakayama H, et al. Henoch-Schonlein purpura in a patient with rheumatoid arthritis receiving etanercept. European Journal of Dermatology (France). 2010;20:521-2.
9 Baggott JE, Morgan SL. Aug. Methotrexate Catabolism to 7-Hydroxymethotrexate in Rheumatoid Arthritis Alters Drug Efficacy and Retention and Is Reduced by Folic Acid Supplementation. Arthritis and Rheumatism (USA). 2009:602257.
10 Bansard C, Lequerre T, Daveau M, et al. Can rheumatoid arthritis responsiveness to methotrexate and biologics be predicted?. Rheumatology. 2009;481021.
11 Bansback NJ, Ara R, Barkham N, et al. Estimating the cost and health status consequences of treatment with TNF antagonists in patients with psoriatic arthritis. Rheumatology. 08. 01. 2006;45(Aug):1029-38. [pmid: 16782734].
12 Bathon JM, Fleischmann RM, van der Heijde DM, et al. Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. Journal of Rheumatology. 02. 01. 2006;33(Feb):234-43. [pmid: 16465653].
13 Bell S. Payers have biologic alternative for patients with moderate to severe rheumatoid arthritis who do not respond to other DMARD therapies. Biotechnology Healthcare. 06. 01. 2006;3(Jun):24-8.
14 Benhamou M, Rincheval N, Roy C, et al. The Gap Between Practice and Guidelines in the Choice of First-line Disease Modifying Antirheumatic Drug in Early Rheumatoid Arthritis: Results from the ESPOIR Cohort. Journal of Rheumatology. 2009;36934.
15 Bernatsky S, Habel Y, Rahme E. Observational Studies of Infections in Rheumatoid Arthritis: A Metaanalysis of Tumor Necrosis Factor Antagonists. Journal of Rheumatology. 2010:37928-31.
16 Bingham CO, Ince A, Haraoui B, et al. Effectiveness and safety of etanercept in subjects with RA who have failed infliximab therapy: 16-week, open-label, observational study. Current Medical Research and Opinion (England). 2009:251131.
17 Borah BJ, Huang XY, Zarotsky V, et al. Trends in RA patients' adherence to subcutaneous anti-TNF therapies and costs. Current Medical Research and Opinion (England). 2009:251365.
18 Bours MJ, Peeters RH, Landewe RB, et al. Adenosine 5′-triphosphate infusions reduced disease activity and inflammation in a patient with active rheumatoid arthritis. Rheumatology (Oxford). 2010;49:2223-5. [pmid: 20547656].
19 Boyce EG, Halilovic J, Stan-Ugbene O. Golimumab: Review of the Efficacy and Tolerability of a Recently Approved Tumor Necrosis Factor-alpha Inhibitor. Clinical Therapeutics (USA). 2010;32:1681-703.
20 Bruce SP. Recent Developments in the Treatment of Rheumatoid Arthritis. Journal of Pharmacy Practice. 2009;22:65-74.
21 Bullano MF, McNeeley BJ, Yu YF, et al. Comparison of costs associated with the use of etanercept, infliximab, and adamlimumab for the treatment of rheumatoid arthritis. Managed Care Interface (USA). 09. 01. 2006;19(Sep):47-53.
22 Butterly SJ, Pillans P, Horn B, et al. Off-label use of rituximab in a tertiary Queensland hospital. Internal Medicine Journal. 2010;40:443-52. [pmid: 19460062].
23 Cambridge G, Stohl W, Leandro MJ, et al. Circulating levels of B lymphocyte stimulator in patients with rheumatoid arthritis following rituximab treatment - Relationships with B cell depletion, circulating antibodies, and clinical relapse. Arthritis and Rheumatism (USA). 03. 01. 2006;54(Mar):723-32.
24 Campas-Moya C. Golimumab: A novel anti-INF-alpha human monoclonal antibody for rheumatoid arthritis, psoriatic arthritis and ankylosing spondylitis. Drugs of Today (Spain). 2010;46:13-22.
25 Cannon CP, Curtis SP, Bolognese JA, et al. Clinical trial design and patient demographics of the multinational etoricoxib and diclofenac arthritis long-term (MEDAL) study program: Cardiovascular outcomes with etoricoxib versus diclofenac in patients with osteoarthritis and rheumatoid arthritis. American Heart Journal. 02. 01. 2006;152(Feb):237-45. [pmid: 16875903].
26 Cannon CP, Curtis SP, FitzGerald GA, et al. Cardiovascular outcomes with etoricoxib and diclofenac in patients with osteoarthritis and rheumatoid arthritis in the Multinational Etoricoxib and Diclofenac Arthritis Long-term (MEDAL) programme: a randomised comparison. Lancet, The (USA). 01. 01. 2006;368(Jan):1771-81.
27 Cantaert T, van Baarsen LG, Wijbrandts CA, et al. Type I interferons have no major influence on humoral autoimmunity in rheumatoid arthritis. Rheumatology (Oxford). 2010;49:156. [pmid: 19933783].
28 Carazo JL, Santos LM, Martinez VO. Safety of etanercept in psoriasis - A critical review. Drug Safety (New Zealand). 08. 01. 2006;29(Aug):675-85.
29 Cavill I, Auerbach M, Bailie GR, et al. Iron and the anaemia of chronic disease: a review and strategic recommendations. Current Medical Research and Opinion (England). 04. 01. 2006;22(Apr):731-7.
30 Chung SJ, Kim JK, Park MC, et al. Reactivation of Hepatitis B Viral Infection in Inactive HBsAg Carriers Following Anti-Tumor Necrosis Factor-alpha Therapy. Journal of Rheumatology. 2009;362416.
31 Coates LC, Helliwell PS. Validation of Minimal Disease Activity Criteria for Psoriatic Arthritis Using Interventional Trial Data. Arthritis Care and Research. 2010;62:965. [pmid: 20589696].
32 Cohen PR. May. Neutrophilic Dermatoses. A Review of Current Treatment Options. American Journal of Clinical Dermatology (New Zealand). 2009:10301.
33 Cohen SB. Updates from B cell trials: Efficacy. Journal of Rheumatology. 01. 01. 2006;33(MAY):12-7. [pmid: 16652440].
34 Cui J, Saevarsdottir S, Thomson B, et al. Rheumatoid Arthritis Risk Allele PTPRC Is Also Associated With Response to Anti-Tumor Necrosis Factor alpha Therapy. Arthritis and Rheumatism (USA). 2010;62:1849.
35 Curtis JR, Chen L, Harrold LR, et al. Physician Preference Motivates the Use of Anti-Tumor Necrosis Factor Therapy Independent of Clinical Disease Activity. Arthritis Care and Research. 2010;62:101-7. [pmid: 20191497].
36 Curtis SP, Ko AT, Bolognese JA, et al. Pooled analysis of thrombotic cardiovascular events in clinical trials of the COX-2 selective inhibitor etoricoxib. Current Medical Research and Opinion (England). 12. 01. 2006;22(Dec):2365-74.
37 DaSilva V, Roux CH, Bernard E, et al. Neuromeningeal Tuberculosis in a Patient with Rheumatoid Arthritis Previously Exposed to Ineffective Etanercept Therapy and Revealed by Infliximab. Journal of Rheumatology. 2010;37:471-2. [pmid: 20147485].
38 De Rycke L, Baeten D, Kruithof E, et al. Infliximab, but not etanercept, induces IgM anti-double-stranded DNA autoantibodies as main antinuclear reactivity - Biologic and clinical implications in autoimmune arthritis. Arthritis and Rheumatism (USA). 07. 01. 2005;52(Jul):2192-201.
39 de Vlam K, Lories RJ. Efficacy, effectiveness and safety of etanercept in monotherapy for refractory psoriatic arthritis: a 26-week observational study. Rheumatology. 03. 01. 2006;45(Mar):321-4. [pmid: 16234275].
40 de Vries-Bouwstra J, Le Cessie S, Allaart C, et al. Using predicted disease outcome to provide differentiated treatment of early rheumatoid arthritis. Journal of Rheumatology. 09. 01. 2006;33(Sep):1747-53. [pmid: 16845710].
41 Deighton C, Hyrich K, Ding T, et al. BSR and BHPR rheumatoid arthritis guidelines on eligibility criteria for the first biological therapy. Rheumatology (Oxford). 2010;49:1197-9. [pmid: 20308121].
42 Dewan P, Jawad A, Goldsmith P, et al. Melanoma in patients with rheumatoid arthritis treated with antitumour necrosis factor: cause or coincidence? Report of two cases. British Journal of Dermatology (England). 2009:1611412.
43 Doan QV, Chiou CF, Dubois RW. Review of eight pharmacoeconomic studies of the value of biologic DMARDs (adalimumab, etanercept, and infliximab) in the management of rheumatoid arthritis. Journal of Managed Care Pharmacy (USA). 07. 01. 2006;12(Jul):555-69.
44 Driessen RJ, de Jong EM, Salemink GW, et al. Analysis of 4-year Dutch reimbursement application data of biological therapies for psoriatic arthritis. Rheumatology (Oxford). 2010;49:588-91. [pmid: 20040525].
45 Duggan ST, Keam SJ. Jun. Certolizumab Pegol In Rheumatoid Arthritis. BioDrugs (New Zealand). 2009;23:407.
46 Eder L, Chandran V, Ueng J, et al. Predictors of response to intra-articular steroid injection in psoriatic arthritis. Rheumatology (Oxford). 2010;49:1367-73. [pmid: 20388640].
47 El Miedany Y, Youssef SS, El Gaafary M. Short-term outcome after anti-tumor necrosis factor-alpha therapy in rheumatoid arthritis: Do we need to revise our assessment criteria?. Journal of Rheumatology. 2006;33(3):490-6. [pmid: 16511918].
48 Emery P, Fleischmann R, Filipowicz-Sosnowska A, et al. The efficacy and safety of rituximab in patients with active rheumatoid arthritis despite methotrexate treatment - Results of a phase IIb randomized, double-blind, placebo-controlled, dose-ranging trial. Arthritis and Rheumatism (USA). 2006;54(May):1390-400.
49 Emery P, Genovese MC, van Vollenhoven R, et al. Less Radiographic Progression with Adalimumab Plus Methotrexate Versus Methotrexate Monotherapy Across the Spectrum of Clinical Response in Early Rheumatoid Arthritis. Journal of Rheumatology. 2009;361429.
50 Emery P, Kosinski M, Li T, et al. Treatment of rheumatoid arthritis patients with abatacept and methotrexate significantly improved health-related quality of life. Journal of Rheumatology. 2006;33(Apr):681-9. [pmid: 16568505].
51 Esposito M, Mazzotta A, de Felice C, et al. Treatment of erythrodermic psoriasis with etanercept. British Journal of Dermatology (England). 01. 01. 2006;155(Jan):156-9.
52 Finckh A, Bansback N, Marra CA, et al. Treatment of Very Early Rheumatoid Arthritis With Symptomatic Therapy, Disease-Modifying Antirheumatic Drugs, or Biologic Agents A Cost-Effectiveness Analysis. Annals of Internal Medicine (USA). 2009;151:612.
53 Fleurence R, Spackman E. Cost-effectiveness of biologic agents for treatment of autoimmune disorders: Structured review of the literature. Journal of Rheumatology. 11. 01. 2006;33(Nov):2124-31. [pmid: 17086602].
54 Fouache D, Goeb V, Massy-Guillemant N, et al. Paradoxical adverse events of anti-tumour necrosis factor therapy for spondyloarthropathies: a retrospective study. Rheumatology. 2009;48761.
55 Frey N, Grange S, Woodworth T. Population Pharmacokinetic Analysis of Tocilizumab in Patients With Rheumatoid Arthritis. Journal of Clinical Pharmacology (USA). 2010;50:754-66.
56 Furlan AD, Sandoval JA, Mailis-Gagnon A, et al. Opioids for chronic noncancer pain: a meta-analysis of effectiveness and side effects. Canadian Medical Association Journal (Canada). 11. 01. 2006;174(Nov):1589-94.
57 Gaffo A, Saag KG, Curtis JR. Treatment of rheumatoid arthritis. American Journal of Health-System Pharmacy (USA). 01. 01. 2006;63(Jan):2451-65.
58 Garcia JJ, Lobato JP, Garrido SL, et al. Biological therapies in rheumatoid arthritis. Atencion Farmaceutica: European Journal of Clinical Pharmacy. 2008;10(98):100-11.
59 Garnero P, Thompson E, Woodworth T, et al. Rapid and Sustained Improvement in Bone and Cartilage Turnover Markers With the Anti-Interleukin-6 Receptor Inhibitor Tocilizumab Plus Methotrexate in Rheumatoid Arthritis Patients With an Inadequate Response to Methotrexate Results From a Substudy of the Multicenter Double-Blind, Placebo-Controlled Trial of Tocilizumab in Inadequate Responders to Methotrexate Alone. Arthritis and Rheumatism (USA). 2010;62:33.
60 Gladman DD, Sampalis JS, Illouz O, et al. Responses to Adalimumab in Patients with Active Psoriatic Arthritis Who Have Not Adequately Responded to Prior Therapy: Effectiveness and Safety Results From an Open-label Study. Journal of Rheumatology. 2010;37:1898. [pmid: 20595284].
61 Gladman DD, Tom BD, Mease PJ, et al. Informing Response Criteria for Psoriatic Arthritis. I: Discrimination Models Based on Data from 3 Anti-Tumor Necrosis Factor Randomized Studies. Journal of Rheumatology. 2010;37:1892-7. [pmid: 20595285].
62 Gompels LL, Smith A, Charles PJ, et al. Single-blind randomized trial of combination antibiotic therapy in rheumatoid arthritis. Journal of Rheumatology. 02. 01. 2006;33(Feb):224-7. [pmid: 16465651].
63 Gonzalez-Juanatey C, Llorca J, Garcia-Porrua C, et al. Effect of anti-tumor necrosis factor alpha therapy on the progression of subclinical atherosclerosis in severe rheumatoid arthritis. Arthritis and Rheumatism-Arthritis Care and Research. 01. 01. 2006;55(Jan):150-3. [pmid: 16463428].
64 Graudal N, Juergens G. Similar Effects of Disease-Modifying Antirheumatic Drugs, Glucocorticoids, and Biologic Agents on Radiographic Progression in Rheumatoid Arthritis Meta-Analysis of 70 Randomized Placebo-Controlled or Drug-Controlled Studies, Including 112 Comparisons. Arthritis and Rheumatism (USA). 2010;62:2852.
65 Grijalva CG, Kaltenbach L, Arbogast PG, et al. Initiation of rheumatoid arthritis treatments and the risk of serious infections. Rheumatology (Oxford). 2010:4982-90.
66 Hallinen TA, Soini EJ, Eklund K, et al. Cost-utility of different treatment strategies after the failure of tumour necrosis factor inhibitor in rheumatoid arthritis in the Finnish setting. Rheumatology (Oxford). 2010;49:767-77. [pmid: 20100793].
67 Haringman JJ, Gerlag DM, Smeets TJ, et al. A randomized controlled trial with an anti-CCL2 (anti-monocyte chemotactic protein 1) monoclonal antibody in patients with rheumatoid arthritis. Arthritis and Rheumatism (USA). 08. 01. 2006;54(Aug):2387-92.
68 Harris CL, Raisch DW, Abhyankar U, et al. GI risk factors and use of GI protective agents among patients receiving nonsteroidal antiinflammatory drugs. Annals of Pharmacotherapy (USA). 11. 01. 2006;40(Nov):1924-31.
69 Hassan B, Maxwell JR, Hyrich KL, et al. Genotype at the sIL-6R A358C polymorphism does not influence response to anti-TNF therapy in patients with rheumatoid arthritis. Rheumatology (Oxford). 2010;49:43-7. [pmid: 19926672].
70 Hetland ML, Christensen IJ, Tarp U, et al. Direct Comparison of Treatment Responses, Remission Rates, and Drug Adherence in Patients With Rheumatoid Arthritis Treated With Adalimumab, Etanercept, or Infliximab Results From Eight Years of Surveillance of Clinical Practice in the Nationwide Danish DANBIO Registry. Arthritis and Rheumatism (USA). 2010:6222-32.
71 Hetland ML, Stengaard-Pedersen K, Junker P, et al. Combination treatment with methotrexate, cyclosporine, and intraarticular betamethasone compared with methotrexate and intraarticular betamethasone in early active rheumatoid arthritis - An investigator-initiated, multicenter, randomized, double-blind, parallel-group, placebo-controlled study. Arthritis and Rheumatism (USA). 05. 01. 2006;54(May):1401-9.
72 Hu CP, Xu ZH, Rahman MU, et al. A latent variable approach for modeling categorical endpoints among patients with rheumatoid arthritis treated with golimumab plus methotrexate. Journal of Pharmacokinetics and Pharmacodynamics (USA). 2010;37:309-21.
73 Hudson M, Suissa S. Avoiding Common Pitfalls in the Analysis of Observational Studies of New Treatments for Rheumatoid Arthritis. Arthritis Care and Research. 2010;62:805-10. [pmid: 20535791].
74 Hyrich KL, Watson KD, Silman AJ, et al. Predictors of response to anti-TNF-alpha therapy among patients with rheumatoid arthritis: results from the British Society for Rheumatology Biologics Register. Rheumatology. 2006;45(Dec):1558-65. [pmid: 16705046].
75 Isenberg DA. B cell targeted therapies in autoimmune diseases. Journal of Rheumatology. 01. 01. 2006;33(MAY):24-8. [pmid: 16395746].
76 Jacobs JW, van Everdingen AA, Verstappen SM, et al. Followup radiographic data on patients with rheumatoid arthritis who participated in a two-year trial of prednisone therapy or placebo. Arthritis and Rheumatism (USA). 05. 01. 2006;54(May):1422-8.
77 Jarand J, Zochodne DW, Martin LO, et al. Neurological complications of infliximab. Journal of Rheumatology. 05. 01. 2006;33(May):1018-20. [pmid: 16511935].
78 Jazayeri JA, Carroll GJ, Vernallis AB. Interleukin-6 subfamily cytokines and rheumatoid arthritis: Role of antagonists. International Immunopharmacology (USA). 2010;10:1-8.
79 Kavanaugh A. Anakinra (interleukin-1 receptor antagonist) has positive effects on function and quality of life in patients with rheumatoid arthritis. Advances in Therapy (USA). 02. 01. 2006;23(Feb):208-17.
80 Kavanaugh AF. B cell targeted therapies: Safety considerations. Journal of Rheumatology. 01. 01. 2006;33(MAY):18-23. [pmid: 16652441].
81 Kawai S, Hashimoto H, Kondo H, et al. Comparison of tacrolimus and mizoribine in a randomized, double-blind controlled study in patients with rheumatoid arthritis. Journal of Rheumatology. 11. 01. 2006;33(Nov):2153-61. [pmid: 16960930].
82 Kawai S, Yamamoto K. Safety of tacrolimus, an immunosuppressive agent, in the treatment of rheumatoid arthritis in elderly patients. Rheumatology. 04. 01. 2006;45(Apr):441-4. [pmid: 16263777].
83 Kawakami K, Ikari K, Kawamura K, et al. Complications and features after joint surgery in rheumatoid arthritis patients treated with tumour necrosis factor-alpha blockers: perioperative interruption of tumour necrosis factor-alpha blockers decreases complications?. Rheumatology (Oxford). 2010:49341-7.
84 Kawashiri SY, Kawakami A, Iwamoto N, et al. Proinflammatory Cytokines Synergistically Enhance the Production of Chemokine Ligand 20 (CCL20) from Rheumatoid Fibroblast-like Synovial Cells in vitro and Serum CCL20 Is Reduced in vivo by Biologic Disease-modifying Antirheumatic Drugs. Journal of Rheumatology. 2009;362397.
85 Kay LJ, Griffiths ID. Management BSRBR. UK consultant rheumatologists' access to biological agents and views on the BSR Biologics Register. Rheumatology. 11. 01. 2006;45(Nov):1376-9. [pmid: 17040892].
86 Kivitz A, Cohen S, Dowd JE, et al. Clinical assessment of pain, tolerability, and preference of an autoinjection pen versus a prefilled syringe for patient self-administration of the fully human, monoclonal antibody adalimumab: The TOUCH trial. Clinical Therapeutics (USA). 10. 01. 2006;28(Oct):1619-29.
87 Kling MC, Larian AA, Scordi-Bello I, et al. Fatal Influenza A(H1N1) Respiratory Tract Infection in a Patient Having Psoriasis Treated With Infliximab. Archives of Dermatology (USA). 2010;146:651-4.
88 Koeller MD, Aletaha D, Funovits J, et al. Response of elderly patients with rheumatoid arthritis to methotrexate or TNF inhibitors compared with younger patients. Rheumatology. 2009;481575.
89 Korkina L, Trakhtman P, De Luca C, et al. EFFICACY AND SAFETY OF BIOLOGICALS AGAINST IMMUNE-MEDIATED DISEASES: DO BENEFITS OUTWEIGH RISKS?. Drugs of Today (Spain). 2010;46:119-36.
90 Krathen MS, Gottlieb AB, Mease PJ. Pharmacologic Immunomodulation and Cutaneous Malignancy in Rheumatoid Arthritis, Psoriasis, and Psoriatic Arthritis. Journal of Rheumatology. 2010;37:2205-15. [pmid: 20810498].
91 Kremer JM, Genant HK, Moreland LW, et al. Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis - A randomized trial. Annals of Internal Medicine (USA). 2006;144(Dec):865-76.
92 Kuan WP, Tam LS, Wong CK, et al. CXCL 9 and CXCL 10 as Sensitive Markers of Disease Activity in Patients with Rheumatoid Arthritis. Journal of Rheumatology. 2010;37:257-64. [pmid: 20032101].
93 Landewe R, van der Heijde D, Klareskog L, et al. Disconnect between inflammation and joint destruction after treatment with etanercept plus methotrexate - Results from the trial of etanercept and methotrexate with radiographic and patient outcomes. Arthritis and Rheumatism (USA). 10. 01. 2006;54(Oct):3119-25.
94 Lee YH, Ji JD, Bae SC, et al. Associations Between Tumor Necrosis Factor-alpha (TNF-alpha) -308 and -238 G/A Polymorphisms and Shared Epitope Status and Responsiveness to TNF-alpha Blockers in Rheumatoid Arthritis: A Metaanalysis Update. Journal of Rheumatology. 2010;37:740-6. [pmid: 20194454].
95 Lee YH, Song GG. Associations between the C677T and A1298C Polymorphisms of MTHFR and the Efficacy and Toxicity of Methotrexate in Rheumatoid Arthritis A Meta-Analysis. Clinical Drug Investigation (New Zealand). 2010;30:101-8.
96 Lester SE, Proudman SM, Lee AT, et al. Treatment-induced stable, moderate reduction in blood cell counts correlate to disease control in early rheumatoid arthritis. Internal Medicine Journal. 2009;39:296. [pmid: 19371393].
97 Looney RJ. B cell-targeted therapy for rheumatoid arthritis - An update on the evidence. Drugs (New Zealand). 05. 01. 2006;66(May):625-39.
98 Luman KL, Amireh H, Gonzalez ER. A medication utilization evaluation of abatacept: a retrospective study. ASHP Midyear Clinical Meeting. 2010;2009:119.
99 Luman KL, Amireh H, Gonzalez ER. A medication utilization evaluation of infliximab: a retrospective study. ASHP Midyear Clinical Meeting. 2010;2009:120.
100 Luqmani R, Hennell S, Estrach C, et al. British society for rheumatology and british health professionals in rheumatology guideline for the management of rheumatoid arthritis (the first two years). Rheumatology. 09. 01. 2006;45(Sep):1167-9. [pmid: 16844700].
101 Ma MH, Kingsley GH, Scott DL. A systematic comparison of combination DMARD therapy and tumour necrosis inhibitor therapy with methotrexate in patients with early rheumatoid arthritis. Rheumatology (Oxford). 2010;49:91-8. [pmid: 19917618].
102 Madland TM, Bjoerkkjaer T, Brunborg LA, et al. Subjective improvement in patients with psoriatic arthritis after short-term oral treatment with seal oil. A pilot study with double blind comparison to soy oil. Journal of Rheumatology. 02. 01. 2006;33(Feb):307-10. [pmid: 16465662].
103 Magnusson M, Brisslert M, Zendjanchi K, et al. Epstein-Barr virus in bone marrow of rheumatoid arthritis patients predicts response to rituximab treatment. Rheumatology (Oxford). 2010;49:1911-9. [pmid: 20547657].
104 Maignen F, Hauben M, Tsintis P. Modelling the Time to Onset of Adverse Reactions with Parametric Survival Distributions A Potential Approach to Signal Detection and Evaluation. Drug Safety (New Zealand). 2010;33:417-34.
105 Marra C. Rheumatoid arthritis: A primer for pharmacists. American Journal of Health-System Pharmacy (USA). 01. 01. 2006;63(Feb):S4-10.
106 McCluggage LK, Scholtz JM. Golimumab: A Tumor Necrosis Factor Alpha Inhibitor for the Treatment of Rheumatoid Arthritis. Annals of Pharmacotherapy (USA). 2010;44:135-44.
107 McDermott MF. Jun. RILONACEPT IN THE TREATMENT OF CHRONIC INFLAMMATORY DISORDERS. Drugs of Today (Spain). 2009:45423.
108 McLean-Tooke A, Aldridge C, Waugh S, et al. Methotrexate, rheumatoid arthritis and infection riskwhat is the evidence. Rheumatology. 2009;48:867. [pmid: 19447771].
109 Mease PJ, Gladman DD, Keystone EC, et al. Alefacept in combination with methotrexate for the treatment of psoriatic arthritis - Results of a randomized, double-blind, placebo-controlled study. Arthritis and Rheumatism (USA). 05. 01. 2006;54(May):1638-45.
110 Michot C, Costes V, Gerard-Dran D, et al. Subcutaneous panniculitis-like T-cell lymphoma in a patient receiving etanercept for rheumatoid arthritis. British Journal of Dermatology (England). 2009:160889.
111 Montecucco C. Remission, a therapeutic goal in inflammatory arthropathies? Clinical data from adalimumab studies. Drugs (New Zealand). 01. 01. 2006;66(Mar):1783-95.
112 Muhammad K, Roll P, Einsele H, et al. Delayed Acquisition of Somatic Hypermutations in Repopulated IgD+CD27+ Memory B Cell Receptors After Rituximab Treatment. Arthritis and Rheumatism (USA). 2009:602284.
113 Mulleman D, Lin DC, Ducourau E, et al. Trough Infliximab Concentrations Predict Efficacy and Sustained Control of Disease Activity in Rheumatoid Arthritis. Therapeutic Drug Monitoring (USA). 2010;32:232.
114 Nagashima T, Minota S. Subcutaneous calcification following injection of triamcinolone hexacetonide for plantar fasciitis. Rheumatology, Dec. 2008;47:1838-40.
115 Nakamura T, Higashi S, Tomoda K, et al. Significance of SAA1.3 allele genotype in Japanese patients with amyloidosis secondary to rheumatoid arthritis. Rheumatology. 01. 01. 2006;45(Jan):43-9. [pmid: 16219644].
116 Nannini C, Cantini F, Niccoli L, et al. Single-Center Series and Systematic Review of Randomized Controlled Trials of Malignancies in Patients With Rheumatoid Arthritis, Psoriatic Arthritis, and Ankylosing Spondylitis Receiving Anti-Tumor Necrosis Factor alpha Therapy: Is There a Need for More Comprehensive Screening Procedures? Arthritis and Rheumatism-. Arthritis Care and Research. 2009:61801.
117 Navarro-Sarabia F, Ariza-Ariza R, Hernandez-Cruz B, et al. Adalimumab for treating rheumatoid arthritis. Journal of Rheumatology. 2006;33(Jun):1075-81. [pmid: 16652437].
118 Odai T, Matsunawa M, Takahashi R, et al. Correlation of CX3CL1 and CX3CR1 Levels with Response to Infliximab Therapy in Patients with Rheumatoid Arthritis. Journal of Rheumatology. 2009;361158.
119 Oldfield V, Dhillon S, Plosker GL. Tocilizumab A Review of its Use in the Management of Rheumatoid Arthritis. Drugs. 2009;69:609-32. [pmid: 19368420].
120 Paul-Pletzer K. Tocilizumab: Blockade of interleukin-6 signaling pathway as a therapeutic strategy for inflammatory disorders. Drugs of Today (Spain). 09. 01. 2006;42(Sep):559-76.
121 Phung OJ, Coleman CI. Sep. Golimumab: A human anti-TNF-alpha monoclonal antibody for the treatment of autoimmune joint diseases. Formulary (USA). 2009:44264.
122 Pincus T, Chung C, Segurado OG, et al. An index of patient reported outcomes (PRO-Index) discriminates effectively between active and control treatment in 4 clinical trials of adalimumab in rheumatoid arthritis. Journal of Rheumatology. 11. 01. 2006;33(Nov):2146-52. [pmid: 17080518].
123 Plushner SL. Tocilizumab: An Interleukin-6 Receptor Inhibitor for the Treatment of Rheumatoid Arthritis. Annals of Pharmacotherapy. 2008;42:1660-8. [pmid: 18957621].
124 Polinski JM, Mohr PE, Johnson L, et al. Impact of Medicare Part D on Access to and Cost Sharing for Specialty Biologic Medications for Beneficiaries With Rheumatoid Arthritis. Arthritis and Rheumatism-Arthritis Care and Research. 2009;61:745. [pmid: 19479704].
125 Prodanovich S, Ricotti C, Glick BP, et al. Etanercept: An Evolving Role in Psoriasis and Psoriatic Arthritis. American Journal of Clinical Dermatology (New Zealand). 2010;11:3-9.
126 Pucino F, Harbus PT, Goldbach-Mansky R. Use of biologics in rheumatoid arthritis: Where are we going?. American Journal of Health-System Pharmacy (USA). 01. 01. 2006;63(Feb):S19-41.
127 Quartuccio L, Fabris M, Salvin S, et al. Rheumatoid factor positivity rather than anti-CCP positivity, a lower disability and a lower number of anti-TNF agents failed are associated with response to rituximab in rheumatoid arthritis. Rheumatology. 2009;481557.
128 Rachapalli SM, Williams R, Walsh DA, et al. First-line DMARD choice in early rheumatoid arthritis-do prognostic factors play a role?. Rheumatology (Oxford). 2010;49:1267-71. [pmid: 20008093].
129 Raghavendran RR, Peart F, Grindulis KA. Long-term tocilizumab therapy in a patient with rheumatoid arthritis and chronic hepatitis B. Rheumatology. Dec. 2008:47.
130 Ranganathan P, McLeod HL. Methotrexate pharmacogenetics - The first step toward individualized therapy in rheumatoid arthritis. Arthritis and Rheumatism (USA). 05. 01. 2006;54(May):1366-77.
131 Raterman HG, Simsek S, Lems WF, et al. Rituximab and Thyroid Function. Archives of Internal Medicine (USA). 2009:1691073.
132 Reiff A, Lovell DJ, van Adelsberg J, et al. Evaluation of the comparative efficacy and tolerability of rofecoxib and naproxen in children and adolescents with juvenile rheumatoid arthritis: A 12-week randomized controlled clinical trial with a 52-week open-label extension. Journal of Rheumatology. 05. 01. 2006;33(May):985-95. [pmid: 16583464].
133 Resman-Targoff BH. Medical therapy: Where are we now?. American Journal of Health-System Pharmacy (USA). 01. 01. 2006;63(Feb):S11-8.
134 Ristic GG, Lepic T, Gilsic B, et al. Rheumatoid arthritis is an independent risk factor for increased carotid intima-media thickness: impact of anti-inflammatory treatment. Rheumatology (Oxford). 2010;49:1076. [pmid: 20208070].
135 Ritchlin CT. Therapies for psoriatic enthesopathy. A systematic review. Journal of Rheumatology. 07. 01. 2006;33(Jul):1435-8. [pmid: 16724370].
136 Robinson V, Boers M, Brooks P, et al. Patient-reported pain is central to OMERACT rheumatology core measurement sets. Drug Information Journal (USA). 01. 01. 2006;40(Jan):111-6.
137 Roman-Blas JA, Castaneda S, Cutolo M, et al. Efficacy and Safety of a Selective Estrogen Receptor beta Agonist, ERB-041, in Patients With Rheumatoid Arthritis: A 12-Week, Randomized, Placebo-Controlled, Phase II Study. Arthritis Care and Research. 2010;62:1588-93. [pmid: 20556817].
138 Rongioletti F, Burlando M, Parodi A. Adverse Effects of Biological Agents in the Treatment of Psoriasis. American Journal of Clinical Dermatology (New Zealand). 2010;11:35-7.
139 Rottem M, Mader R. Successful Use of Etanercept in Acquired Angioedema in a Patient with Psoriatic Arthritis. Journal of Rheumatology. 2010;37:209. [pmid: 20040647].
140 Roux CH, Brocq O, Breuil V, et al. Safety of anti-TNF-alpha therapy in rheumatoid arthritis and spondylarthropathies with concurrent B or C chronic hepatitis. Rheumatology. 10. 01. 2006;45(Oct):1294-7. [pmid: 16603583].
141 Saad AA, Ashcroft DM, Watson KD, et al. Efficacy and safety of anti-TNF therapies in psoriatic arthritis: an observational study from the British Society for Rheumatology Biologics Register. Rheumatology (Oxford). 2010:49697-705.
142 Saraux A, Gossec L, Goupille P, et al. Cost-effectiveness modelling of biological treatment sequences in moderate to severe rheumatoid arthritis in France. Rheumatology (Oxford). 2010;49:733-40. [pmid: 20081224].
143 Schiff MH, Yu EB, Weinblatt ME, et al. Long-term experience with etanercept in the treatment of rheumatoid arthritis in elderly and younger patients - Patient-reported outcomes from multiple controlled and open-label extension studies. Drugs and Aging (New Zealand). 02. 01. 2006;23(Feb):167-78.
144 Schlesselman LS, Hussey AP. Tocilizumab - A humanized anti-IL-6 receptor monoclonal antibody for the treatment of rheumatoid arthritis. Formulary. 2008;43:272-9.
145 Scott DL. Pursuit of optimal outcomes in rheumatoid arthritis. PharmacoEconomics (New Zealand). 02. 01. 2004;22(Feb):13-26.
146 Sebba A. Tocilizumab: The first interleukin-6-receptor inhibitor. American Journal of Health System Pharmacy. 2008;65:1413-8. [pmid: 18653811].
147 Shadick NA, Cook NR, Karlson EW, et al. C-reactive protein in the prediction of rheumatoid arthritis in women. Archives of Internal Medicine (USA). 01. 01. 2006;166(Jan):2490-4.
148 Sheth NU, Hilas O, Charneski L. Abatacept: A novel agent for rheumatoid arthritis. Journal of Pharmacy Technology (USA). 06. 01. 2006;22(Jun):336-41.
149 Siddigui MA, Scott LJ. Spotlight on infliximab in Crohn disease and rheumatoid arthritis. BioDrugs (New Zealand). 01. 01. 2006;20(Jan):67-70.
150 Siegel JN, Zhen BG. Use of the American College of Rheumatology N (ACR-N) Index of improvement in rheumatoid arthritis - Argument in favor. Arthritis and Rheumatism (USA). 06. 01. 2005;52(Jun):1637-41.
151 Signorovitch JE, Wu EQ, Yu AP, et al. Comparative Effectiveness Without Head-to-Head Trials A Method for Matching-Adjusted Indirect Comparisons Applied to Psoriasis Treatment with Adalimumab or Etanercept. PharmacoEconomics (New Zealand). 2010;28:935-45.
152 Sihvonen S, Korpela M, Mustonen J, et al. Mortality in patients with rheumatoid arthritis treated with low-dose oral glucocorticoids. A population-based cohort study. Journal of Rheumatology. 09. 01. 2006;33(Sep):1740-6. [pmid: 16881099].
153 Silverman GJ. Therapeutic B cell depletion and regeneration in rheumatoid arthritis - Emerging patterns and paradigms. Arthritis and Rheumatism (USA). 08. 01. 2006;54(Aug):2356-67.
154 Singh JA, Christensen R, Wells GA, et al. A network meta-analysis of randomized controlled trials of biologics for rheumatoid arthritis: a Cochrane overview. Canadian Medical Association Journal (Canada). 2009:181787.
155 Smolen JS, Han C, Bala M, et al. Evidence of radiographic benefit of treatment with infliximab plus methotrexate in rheumatoid arthritis patients who had no clinical improvement - A detailed subanalysis of data from the anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study. Arthritis and Rheumatism (USA). 04. 01. 2005;52(Apr):1020-30.
156 Smolen JS, van der Heijde DM, St Clair EW, et al. Predictors of joint damage in patients with early rheumatoid arthritis treated with high-dose methotrexate with or without concomitant infliximab - Results from the ASPIRE trial. Arthritis and Rheumatism (USA). 03. 01. 2006;54(Mar):702-10.
157 Snyder RA. Psoriatic Arthritis: A Dermatologist's Perspective. American Journal of Clinical Dermatology (New Zealand). 2010;11:19-22.
158 Sobanko JF, Freeman AF, Palmore TN, et al. A Sri Lankan woman with rheumatoid arthritis and anesthetic plaques. Journal of the American Academy of Dermatology (USA). 2009:601018.
159 Solomon DH, Avorn J, Katz JN, et al. Immunosuppressive medications and hospitalization for cardiovascular events in patients with rheumatoid arthritis. Arthritis and Rheumatism (USA). 2006;54(Dec):3790-8.
160 Soubrier M, Puechal X, Sibilia J, et al. Evaluation of two strategies (initial methotrexate monotherapy vs its combination with adalimumab) in management of early active rheumatoid arthritis: data from the GUEPARD trial. Rheumatology. 2009;48:1429. [pmid: 19741011].
161 Stockl KM, Shin JS, Lew HC, et al. Outcomes of a Rheumatoid Arthritis Disease Therapy Management Program Focusing on Medication Adherence. Journal of Managed Care Pharmacy (USA). 2010;16:593-604.
162 Strand V, Cohen S, Crawford B, et al. Patient-reported outcomes better discriminate active treatment from placebo in randomized controlled trials in rheumatoid arthritis. Rheumatology. 05. 01. 2004;43(May):640-7. [pmid: 15039493].
163 Strand V, Singh JA. Newer Biological Agents in Rheumatoid Arthritis Impact on Health-Related Quality of Life and Productivity. Drugs (New Zealand). 2010;70:121-45.
164 Straub RH, Haerle P, Yamana S, et al. Anti-interleukin-6 receptor antibody therapy favors adrenal androgen secretion in patients with rheumatoid arthritis - A randomized, double-blind, placebo-controlled study. Arthritis and Rheumatism (USA). 06. 01. 2006;54(Jun):1778-85.
165 Stuhlmueller B, Haeupl T, Hernandez MM, et al. CD11c as a Transcriptional Biomarker to Predict Response to Anti-TNF Monotherapy With Adalimumab in Patients With Rheumatoid Arthritis. Clinical Pharmacology and Therapeutics (USA). 2010;87:311-21.
166 Sweet BV. Abatacept. American Journal of Health-System Pharmacy (USA). 01. 01. 2006;63(Jan):2065-77.
167 Takatori S, Kamata Y, Murosaki T, et al. Abrupt Development of Sarcoidosis with a Prodromal Increase in Plasma Osteopontin in a Patient with Rheumatoid Arthritis During Treatment with Etanercept. Journal of Rheumatology. 2010;37:210-2. [pmid: 20040649].
168 Taylor PC, Steuer A, Gruber J, et al. Ultrasonographic and radiographic results from a two-year controlled trial of immediate or one-year-delayed addition of infliximab to ongoing methotrexate therapy in patients with erosive early rheumatoid arthritis. Arthritis and Rheumatism (USA). 01. 01. 2006;54(Jan):47-53.
169 Thayer S, Watson C, Song R, et al. Etanercept treatment patterns in managed-care patients with psoriasis or psoriatic arthritis. Journal of Medical Economics (England). 2010;13:228-35.
170 Tielemans MM, Eikendal T, Jansen JB, et al. Identification of NSAID Users at Risk for Gastrointestinal Complications A Systematic Review of Current Guidelines and Consensus Agreements. Drug Safety (New Zealand). 2010;33:443-53.
171 Torikai E, Kageyama Y, Takahashi M, et al. The effect of infliximab on bone metabolism markers in patients with rheumatoid arthritis. Rheumatology. 06. 01. 2006;45(Jun):761-4. [pmid: 16436492].
172 Tran S, Hooker RS, Cipher DJ, et al. Patterns of Biologic Agent Use in Older Males with Inflammatory Diseases An Institution-Focused, Observational Post-Marketing Study. Drugs and Aging (New Zealand). 2009;26:607.
173 Tubach F, Ravaud P, Salmon-Ceron D, et al. Emergence of Legionella pneumophila pneumonia in patients receiving tumor necrosis factor-alpha antagonist. Clinical Infectious Diseases. 10. 01. 2006;43(Oct):E95-100. [pmid: 17051484].
174 van Assen S, Holvast A, Benne CA, et al. Humoral Responses After Influenza Vaccination Are Severely Reduced in Patients With Rheumatoid Arthritis Treated With Rituximab. Arthritis and Rheumatism (USA). 2010;62:75-81.
175 van der Linden MP, van der Woude D, Ioan-Facsinay A, et al. Value of Anti-Modified Citrullinated Vimentin and Third-Generation Anti-Cyclic Citrullinated Peptide Compared With Second-Generation Anti-Cyclic Citrullinated Peptide and Rheumatoid Factor in Predicting Disease Outcome in Undifferentiated Arthritis and Rheumatoid Arthritis. Arthritis and Rheumatism (USA). 2009:602232.
176 Van Rijthoven AW, Bijlsma JW, Canninga-Van Dijk M, et al. Onset of systemic lupus erythematosus after conversion of infliximab to adalimumab treatment in rheumatoid arthritis with a pre-existing anti-dsDNA antibody level. Rheumatology. 10. 01. 2006;45(Oct):1317-9. [pmid: 16844698].
177 Vanags D, Williams B, Johnson B, et al. Therapeutic efficacy and safety of chaperonin 10 in patients with rheumatoid arthritis: a double-blind randomised trial. Lancet, The (USA). 01. 01. 2006;368(Apr):855-63.
178 Varani K, Massara A, Vincenzi F, et al. Normalization of A_2A_ and A_3_ Adenosine Receptor Up-Regulation in Rheumatoid Arthritis Patients by Treatment With Anti-Tumor Necrosis Factor alpha but Not Methotrexate. Arthritis and Rheumatism (USA). 2009:602880.
179 Vergles JM, Radic M, Kovacic J, et al. Successful Use of Adalimumab for Treating Rheumatoid Arthritis with Autoimmune Sensorineural Hearing Loss: Two Birds with One Stone. Journal of Rheumatology. 2010;37:1080. [pmid: 20439536].
180 Villa-Blanco JI, Calvo-Alen J. Sep. Elderly Onset Rheumatoid Arthritis Differential Diagnosis and Choice of First-Line and Subsequent Therapy. Drugs and Aging (New Zealand). 2009:26739.
181 Virkki LM, Sumathikutty BC, Aarnio M, et al. Biological Therapy for Psoriatic Arthritis in Clinical Practice: Outcomes Up to 2 Years. Journal of Rheumatology. 2010:372362-8.
182 Watson DJ, Bolognese JA, Yu C, et al. Use of gastroprotective agents and discontinuations due to dyspepsia with the selective cyclooxygenase-2 inhibitor etoricoxib compared with non-selective NSAIDs. Current Medical Research and Opinion (England). 12. 01. 2004;20(Dec):1899-908.
183 Weisman MH, Durez P, Hallegua D, et al. Reduction of inflammatory biomarker response by abatacept in treatment of rheumatoid arthritis. Journal of Rheumatology. 11. 01. 2006;33(Nov):2162-6. [pmid: 17014006].
184 Welsing PM, Severens JL, Hartman M, et al. The initial validation of a Markov model for the economic evaluation of (New) treatments for rheumatoid arthritis. PharmacoEconomics (New Zealand). 10. 01. 2006;24(Oct):1011-20.
185 Weng HH, Ranganath VK, Khanna D, et al. Equivalent Responses to Disease-modifying Antirheumatic Drugs Initiated at Any Time During the First 15 Months After Symptom Onset in Patients with Seropositive Rheumatoid Arthritis. Journal of Rheumatology. 2010;37:550-7. [pmid: 20110517].
186 Westhovens R, Cole JC, Li T, et al. Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology. 2006;45(Oct):1238-46. [pmid: 16567357].
187 Westlake SL, Colebatch AN, Baird J, et al. The effect of methotrexate on cardiovascular disease in patients with rheumatoid arthritis: a systematic literature review. Rheumatology (Oxford). 2010;49:295. [pmid: 19946022].
188 White DH, Chapman PT, O'Donnell JL, et al. Lack of association between elevated mean red cell volume and haematological toxicity in patients receiving long-term methotrexate for rheumatoid arthritis. Internal Medicine Journal. 2010;40:561-5. [pmid: 19811562].
189 Williams GW, Kivitz AJ, Brown MT, et al. A comparison of valdecoxib and naproxen in the treatment of rheumatoid arthritis symptoms. Clinical Therapeutics (USA). 02. 01. 2006;28(Feb):204-21.
190 Wolbink GJ, Vis M, Lems W, et al. Development of antiinfliximab antibodies and relationship to clinical response in patients with rheumatoid arthritis. Arthritis and Rheumatism (USA). 03. 01. 2006;54(Mar):711-5.
191 Yuan Y, Trivedi D, Maclean R, et al. Indirect cost-effectiveness analyses of abatacept and rituximab in patients with moderate-to-severe rheumatoid arthritis in the United States. Journal of Medical Economics (England). 2010;13(1):33-41.
192 Zaiac M. The Role of Biological Agents in the Treatment of Nail Psoriasis. American Journal of Clinical Dermatology (New Zealand). 2010;11:27.
193 Zandbelt MM, Houbiers JG, van den Hoogen FH, et al. Intranasal administration of recombinant human cartilage glycoprotein-39. A phase I escalating cohort study in patients with rheumatoid arthritis. Journal of Rheumatology. 09. 01. 2006;33(Sep):1726-33. [pmid: 16960935].
194 Zhang XP, Huang Y, Navarro MT, et al. A Proof-of-Concept and Drug-Drug Interaction Study of Pamapimod, a Novel p38 MAP Kinase Inhibitor, With Methotrexate in Patients With Rheumatoid Arthritis. Journal of Clinical Pharmacology (USA). 2010;50:1031-8.
195 Zink A, Strangfeld A, Schneider M, et al. Effectiveness of tumor necrosis factor inhibitors in rheumatoid arthritis in an observational cohort study - Comparison of patients according to their eligibility for major randomized clinical trials. Arthritis and Rheumatism (USA). 11. 01. 2006;54(Nov):3399-407.

## Reference Source: Handsearches (e.g., Scopus)

1 Cochrane Collaboration guidelines.
2 The BUGS Project. Stevens A. Hosted by the MRC Biostatistics Unit, Cambridge, UK. Accessed on May 2, 2011. www.mrc-bsu.cam.ac.uk/bugs/welcome.shtml.
3 Sulfasalazine in early rheumatoid arthritis. The Australian Multicentre Clinical Trial Group. J Rheumatol. Nov. 1992;19(11):1672-7. [pmid: 1362778].
4 Screening for hydroxychloroquine retinopathy. 2006.
5 National and state medical expenditures and lost earnings attributable to arthritis and other rheumatic conditions--United States, 2003. MMWR Morb Mortal Wkly Rep. 2007;56(1):4-7. [pmid: 17218935].
6 Chapter 9: Analysing data and undertaking meta-analyses. Cochrane Handbook of Systematic Reviews of Intervention Version 500 (Updated February 2008). 2008.
7 Rituxan (Rituximab) [Package Insert]. 2008.
8 Ostensen M, Motta M. Therapy Insight: The use of antirheumatic drugs during nursing. Nature Clinical Practice Rheumatology. 2007;3(7):400-6.
9 Ostensen M, Khamashta M, Lockshin M, et al. Anti-inflammatory and immunosuppressive drugs and reproduction. Arthritis Research and Therapy. 2006;8(3).
10 Abeles AM, Pillinger MH. The role of the synovial fibroblast in rheumatoid arthritis: Cartilage destruction and the regulation of matrix metalloproteinases. Bulletin of the NYU Hospital for Joint Diseases. 2006;64(1–2):20-4. [pmid: 17121485].
11 Ackermann C, Kavanaugh A. Economic burden of psoriatic arthritis. PharmacoEconomics. 2008;26(2):121-9. [pmid: 18198932].
12 ACR. Guidelines for the management of rheumatoid arthritis: 2002 Update. Arthritis Rheum. Feb. 2002;46(2):328-46. [pmid: 11840435].
13 ACR. ACR Hotline: Update on safety issues concerning TNF inhibitors. available at http://www.rheumatology.org/publications/hotline/0506JAMATNF.asp. 2006.
14 Agency for Healthcare Research and Quality. Methods reference guide for effectiveness and comparative effectiveness reviews, version 1.0. [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. 2007.
15 Agrawal S, Misra R, Aggarwal A. Autoantibodies in rheumatoid arthritis: Association with severity of disease in established RA. Clinical rheumatology. 2007;26(2):201-4. [pmid: 16572283].
16 Alamanos Y, Voulgari PV, Drosos AA. Incidence and prevalence of psoriatic arthritis: A systematic review. Journal of Rheumatology. 2008;35(7):1354-8. [pmid: 18464305].
17 Aletaha D, Machold KP, Nell VPK, et al. The perception of rheumatoid arthritis core set measures by rheumatologists. Results of a survey. Rheumatology. 2006;45(9):1133-9. [pmid: 16522674].
18 Aletaha D, Nell VP, Stamm T, et al. Acute phase reactants add little to composite disease activity indices for rheumatoid arthritis: validation of a clinical activity score. Arthritis Res Ther. 2005;7(4):R796-806. [pmid: 15987481].
19 Aletaha D, Neogi T, Silman AJ, et al. 2010 Rheumatoid arthritis classification criteria: an American College of Rheumatology/European League Against Rheumatism collaborative initiative. Ann Rheum Dis. 2010;69(9):1580-8. [pmid: 20699241].
20 Aletaha D, Smolen JS. The definition and measurement of disease modification in inflammatory rheumatic diseases. Rheumatic Disease Clinics of North America. 2006;32(1):9-44. [pmid: 16504819].
21 Allaart CF, Goekoop-Ruiterman YP, de Vries-Bouwstra JK, et al. Aiming at low disease activity in rheumatoid arthritis with initial combination therapy or initial monotherapy strategies: the BeSt study. Clin Exp Rheumatol. Nov–Dec. 2006;24(6 Suppl 43):S-77-82.
22 Alonso-Ruiz A, Pijoan JI, Ansuategui E, et al. Tumor necrosis factor alpha drugs in rheumatoid arthritis: Systematic review and metaanalysis of efficacy and safety. BMC Musculoskeletal Disorders. 2008;9.
23 American College of Rheumatology Ad Hoc Committee on Clinical Guidelines. Guidelines for monitoring drug therapy in rheumatoid arthritis. Arthritis Rheum. May. 1996;39(5):723-31. [pmid: 8639168].
24 Anandarajah AP, Ritchlin CT. Pathogenesis of psoriatic arthritis. Curr Opin Rheumatol. Jul. 2004;16(4):338-43. [pmid: 15201594].
25 Ang DC, Paulus HE, Louie JS. Patient's ethnicity does not influence utilization of effective therapies in rheumatoid arthritis. J Rheumatol. May. 2006;33(5):870-8. [pmid: 16652419].
26 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the lower extremities. Arthritis Rheum. 2001;45(4):384-91. [pmid: 11501727].
27 Undertaking systematic reviews of research on effectiveness: CRD's guidance for those carrying out or commissioning reviews, CRD Report Number 4. 2nd edition. 2001. 2001.
28 Cortisone Acetate package insert. Pharmacia & Upjohn Co. Kalamazoo, MI. 2002.
29 Cortef (hydrocortisone) package insert. Pharmacia & Upjohn Co. Kalamazoo, MI. 2002.
30 Dexamethasone package insert. Roxane Laboratories, Inc. Columbus, OH. 2003.
31 PredniSONE package insert. Roxane Laboratories, Inc. Columbus, OH. 2003.
32 Kineret (anakinra) package insert. Amgen, Inc. Thousand Oaks, CA. 2004.
33 Hydroxychloroquine package insert. Sandoz, Inc. Broomfield, CO. 2004.
34 Orencia (abatacept) package insert. Bristol-Myers Squibb. Princeton, NJ. 2005.
35 Methotrexate package insert. Mayne Pharma (USA) Inc. Paramus, NJ. 2005.
36 Arava (leflunomide) package insert. Aventis Pharmaceuticals Inc. Kansas City, MO. 2005.
37 Remicade (infliximab) package insert. Centocor, Inc. Malvern, PA. 2006.
38 Humira (adalimumab) package insert. Abbott Labs. North Chicago, IL. 2006.
39 Enbrel (etanercept) package insert. Immunex Corporation. Thousand Oaks, CA. 2006.
40 MethylPREDNIsolone package insert. Sandoz, Inc. Princeton NJ. 2006.
41 Azulfidine (sulfasalazine) package insert. Pharmacia & Upjohn Co. NY, NY. 2006.
42 Rituxan (rituximab) package insert. Genetech, Inc. South San Francisco, CA. 2007.
43 Arkfeld DG. The potential utility of B cell-directed biologic therapy in autoimmune diseases. Rheumatology international. 2008;28(3):205-15. [pmid: 17957371].
44 Arnett FC, Edworthy SM, Bloch DA, et al. The American Rheumatism Association 1987 revised criteria for the classification of rheumatoid arthritis. Arthritis Rheum. Mar. 1988;31(3):315-24. [pmid: 3358796].
45 Askling J, Fored CM, Brandt L, et al. Risks of solid cancers in patients with rheumatoid arthritis and after treatment with tumour necrosis factor antagonists. Ann Rheum Dis. Oct. 2005;64(10):1421-6. [pmid: 15829572].
46 AteÅŸ A, Kinikli G, Turgay M, et al. Effects of rheumatoid factor isotypes on disease activity and severity in patients with rheumatoid arthritis: A comparative study. Clinical rheumatology. 2007;26(4):538-45. [pmid: 16804738].
47 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. [pmid: 15615589].
48 Baecklund E, Ekbom A, Sparen P, et al. Disease activity and risk of lymphoma in patients with rheumatoid arthritis: nested case-control study. Bmj. Jul. 18. 1998;317(7152):180-1. [pmid: 9665898].
49 Balk EM, Lau J, Bonis PA. Reading and critically appraising systematic reviews and meta-analyses: a short primer with a focus on hepatology. J Hepatol. 2005;43(4):729-36. [pmid: 16120472].
50 Bansback NJ, Ara R, Barkham N, et al. Estimating the cost and health status consequences of treatment with TNF antagonists in patients with psoriatic arthritis. Rheumatology (Oxford). Aug. 2006;45(8):1029-38. [pmid: 16782734].
51 Bendtzen K, Geborek P, Svenson M, et al. Individualized monitoring of drug bioavailability and immunogenicity in rheumatoid arthritis patients treated with the tumor necrosis factor alpha inhibitor infliximab. Arthritis Rheum. Dec. 2006;54(12):3782-9. [pmid: 17133559].
52 Berends MAM, Snoek J, De Jong EMGJ, et al. Liver injury in long-term methotrexate treatment in psoriasis is relatively infrequent. Alimentary Pharmacology and Therapeutics. 2006;24(5):805-11. [pmid: 16918884].
53 Berglin E, Johansson T, Sundin U, et al. Radiological outcome in rheumatoid arthritis is predicted by presence of antibodies against cyclic citrullinated peptide before and at disease onset, and by IgA-RF at disease onset. Annals of the rheumatic diseases. 2006;65(4):453-8. [pmid: 16176994].
54 Bergman GJ, Hochberg MC, Boers M, et al. Indirect comparison of tocilizumab and other biologic agents in patients with rheumatoid arthritis and inadequate response to disease-modifying antirheumatic drugs. Semin Arthritis Rheum. 2010;39(6):425-41. [pmid: 20223500].
55 Berliner AR, Haas M, Choi MJ. Sarcoidosis: the nephrologist's perspective. Am J Kidney Dis. Nov. 2006;48(5):856-70. [pmid: 17060009].
56 Bermas BL. Use of immunosuppressive drugs in pregnancy and lactation. 2007.
57 Bliddal H, Terslev L, Qvistgaard E, et al. A randomized, controlled study of a single intra-articular injection of etanercept or glucocorticosteroids in patients with rheumatoid arthritis. Scand J Rheumatol. Sep–Oct. 2006;35(5):341-5. [pmid: 17062431].
58 BlueCross BlueShield Technology Evaluation Center (TEC). Special report: evidence on sequencing of conventional and biological disease-modifying anti-rheumatic drugs. 2003. 2003;18(11).
59 Boers M. Add-on or step-up trials for new drug development in rheumatoid arthritis: a new standard?. Arthritis Rheum. Jun. 2003;48(6):1481-3. [pmid: 12794813].
60 Boers M. Abatacept in rheumatoid arthritis: a new branch on the "biologics" tree. Ann Intern Med. Jun. 20. 2006;144(12):933-5. [pmid: 16785481].
61 Boetticher NC, Peine CJ, Kwo P, et al. A randomized, double-blinded, placebo-controlled multicenter trial of etanercept in the treatment of alcoholic hepatitis. Gastroenterology. Dec. 2008;135(6):1953-60. [pmid: 18848937].
62 Boini S, Fuillemin F. Review. Radiographic scoring methods as outcome measures in rheumatoid arthritis: properties and advantages. Ann Rheum Dis. 2001;60:817-27. [pmid: 11502606].
63 Boini S, Guillemin F. Radiographic scoring methods as outcome measures in rheumatoid arthritis: properties and advantages. Ann Rheum Dis. Sep. 2001;60(9):817-27. [pmid: 11502606].
64 Bolen J, Helmick CG, Sacks JJ, et al. Prevalence of self-reported arthritis or chronic joint symptoms among adults--United States, 2001. MMWR Morb Mortal Wkly Rep. Oct. 25. 2002;51(42):948-50. [pmid: 12437034].
65 Bologna C, Viu P, Picot MC, et al. Long-term follow-up of 453 rheumatoid arthritis patients treated with methotrexate: an open, retrospective, observational study. Br J Rheumatol. May. 1997;36(5):535-40. [pmid: 9189054].
66 Bond SJ, Farewell VT, Schentag CT, et al. Predictors for radiological damage in psoriatic arthritis: Results from a single centre. Ann Rheum Dis. 2006. Aug. 17.
67 Bongartz T, Sutton AJ, Sweeting MJ, et al. Anti-TNF antibody therapy in rheumatoid arthritis and the risk of serious infections and malignancies: systematic review and meta-analysis of rare harmful effects in randomized controlled trials. JAMA. May. 17. 2006;295(19):2275-85. [pmid: 16705109].
68 Bongartz T, Warren FC, Mines D, et al. Etanercept therapy in rheumatoid arthritis and the risk of malignancies: a systematic review and individual patient data meta-analysis of randomised controlled trials. Ann Rheum Dis. 2009;68(7):1177-83. [pmid: 19019889].
69 Borman P, Toy GG, Babaoglu S, et al. A comparative evaluation of quality of life and life satisfaction in patients with psoriatic and rheumatoid arthritis. Clin Rheumatol. 2006. Apr. 19.
70 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: A comparison of the performance of meta-analytical methods with rare events. Statistics in Medicine. 2007;26(1):53-77. [pmid: 16596572].
71 Braun J, McHugh N, Singh A, et al. Improvement in patient-reported outcomes for patients with ankylosing spondylitis treated with etanercept 50 mg once-weekly and 25 mg twice-weekly. Rheumatology (Oxford). Jun. 2007;46(6):999-1004. [pmid: 17389658].
72 Braun J, Sieper J. Biological therapies in the spondyloarthritides--the current state. Rheumatology (Oxford). Sep. 2004;43(9):1072-84. [pmid: 15187239].
73 Bren L. The importance of patient-reported outcomes... it's all about the patients. FDA Consumer. 2006;40(6).
74 Brennan FM, McInnes IB. Evidence that cytokines play a role in rheumatoid arthritis. Journal of Clinical Investigation. 2008;118(11):3537-45. [pmid: 18982160].
75 Bruce SP, Boyce EG. Update on abatacept: A selective costimulation modulator for rheumatoid arthritis. Annals of Pharmacotherapy. 2007;41(7–8):1153-62. [pmid: 17609234].
76 Bruce TO. Comorbid depression in rheumatoid arthritis: pathophysiology and clinical implications. Curr Psychiatry Rep. 2008;10(3):258-64. [pmid: 18652795].
77 Bruynesteyn K, van der Heijde D, Boers M, et al. Determination of the minimal clinically important difference in rheumatoid arthritis joint damage of the Sharp/van der Heijde and Larsen/Scott scoring methods by clinical experts and comparison with the smallest detectable difference. Arthritis Rheum. Apr. 2002;46(4):913-20. [pmid: 11953967].
78 Buch MH, Bingham SJ, Bejarano V, et al. Therapy of patients with rheumatoid arthritis: outcome of infliximab failures switched to etanercept. Arthritis Rheum. Apr. 15. 2007;57(3):448-53. [pmid: 17394231].
79 Bucher HC, Guyatt GH, Griffith LE, et al. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. Jun. 1997;50(6):683-91. [pmid: 9250266].
80 Bucher HC, Guyatt GH, Griffith LE, et al. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. Jun. 1997;50(6):683-91. [pmid: 9250266].
81 Bukhari MA, Wiles NJ, Lunt M, et al. Influence of disease-modifying therapy on radiographic outcome in inflammatory polyarthritis at five years: results from a large observational inception study. Arthritis Rheum. Jan. 2003;48(1):46-53. [pmid: 12528102].
82 Burmester GR, Mease P, Dijkmans BA, et al. Adalimumab safety and mortality rates from global clinical trials of six immune-mediated inflammatory diseases. Ann Rheum Dis. Dec. 2009;68(12):1863-9. [pmid: 19147611].
83 Canadian Agency for Drugs and Technologies in Health. CADTH Therapeutic Review: Clinical and Economic Overview: Biological Response Modifier Agents for Adults with Rheumatoid Arthritis. 2010.
84 Cannella AC, O'Dell JR. Early rheumatoid arthritis: pitfalls in diagnosis and review of recent clinical trials. Drugs. 2006;66(10):1319-37. [pmid: 16903767].
85 Capell H, Madhok R, Porter D, et al. Combination therapy with sulphasalazine and methotrexate is more effective than either drug alone in rheumatoid arthritis (ra) patients with a suboptimal response to sulphasalazine: Results from the double blind placebo controlled mascot study. Ann Rheum Dis. 2006. August. 22. [doi: 10.1136/ard.2006.057133].
86 Carlin CS, Feldman SR, Krueger JG, et al. A 50% reduction in the Psoriasis Area and Severity Index (PASI 50) is a clinically significant endpoint in the assessment of psoriasis. J Am Acad Dermatol. Jun. 2004;50(6):859-66. [pmid: 15153885].
87 Carmona L, Descalzo MÃ, Perez-Pampin E, et al. All-cause and cause-specific mortality in rheumatoid arthritis are not greater than expected when treated with tumour necrosis factor antagonists. Annals of the rheumatic diseases. 2007;66(7):880-5. [pmid: 17324968].
88 Carmona L, Hernandez-Garcia C, Vadillo C, et al. Increased risk of tuberculosis in patients with rheumatoid arthritis. J Rheumatol. Jul. 2003;30(7):1436-9. [pmid: 12858438].
89 Cassell S, Kavanaugh AF. Therapies for psoriatic nail disease. A systematic review. J Rheumatol. Jul. 2006;33(7):1452-6. [pmid: 16724366].
90 Cassell S, Tutuncu Z, Kremer J, et al. Psoriatic arthritis patients have different rates of adverse events than rheumatoid arthritis patients when treated with TNF inhihitors: analysis from CORRONA Database [Abstract 491]. Arthritis Rheum. 2005;52(Suppl 9):S211-S2.
91 Chakravarty EF, Michaud K, Wolfe F. Skin cancer, rheumatoid arthritis, and tumor necrosis factor inhibitors. J Rheumatol. Nov. 2005;32(11):2130-5. [pmid: 16265690].
92 Cheifetz A, Smedley M, Martin S, et al. The incidence and management of infusion reactions to infliximab: a large center experience. Am J Gastroenterol. Jun. 2003;98(6):1315-24. [pmid: 12818276].
93 Chen Y, Jobanputra P, Barton P, et al. A systematic review of the effectiveness of adalimumab, etanercept and infliximab for the treatment of rheumatoid arthritis in adults and an economic evaluation of their cost-effectiveness. Heath Technology Assessment. 2006;10(42).
94 Chernoff MC, Wang M, Anderson JJ, et al. Problems and suggested solutions in creating an archive of clinical trials data to permit later meta-analysis: an example of methotrexate trials in rheumatoid arthritis. Control Clin Trials. Oct. 1995;16(5):342-55. [pmid: 8582152].
95 Choy EH, Panayi GS. Cytokine pathways and joint inflammation in rheumatoid arthritis. N Engl J Med. Mar. 22. 2001;344(12):907-16. [pmid: 11259725].
96 Chung CP, Thompson JL, Koch GG, et al. Are American College of Rheumatology 50% response criteria superior to 20% criteria in distinguishing active aggressive treatment in rheumatoid arthritis clinical trials reported since 1997? A meta-analysis of discriminant capacities. Annals of the rheumatic diseases. 2006;65(12):1602-7. [pmid: 16504992].
97 Chung ES, Packer M, Lo KH, et al. Randomized, double-blind, placebo-controlled, pilot trial of infliximab, a chimeric monoclonal antibody to tumor necrosis factor-alpha, in patients with moderate-to-severe heart failure: results of the anti-TNF Therapy Against Congestive Heart Failure (ATTACH) trial. Circulation. Jul. 1. 2003;107(25):3133-40. [pmid: 12796126].
98 Coburn LA, Wise PE, Schwartz DA. The successful use of adalimumab to treat active Crohn's disease of an ileoanal pouch during pregnancy. Digestive Diseases and Sciences. 2006;51(11):2045-7. [pmid: 17009112].
99 Cohen JD, Dougados M, Goupille P, et al. Health assessment questionnaire score is the best predictor of 5-year quality of life in early rheumatoid arthritis. Journal of Rheumatology. 2006;33(10):1936-41. [pmid: 16924692].
100 Coletta AP, Clark AL, Banarjee P, et al. Clinical trials update: RENEWAL (RENAISSANCE and RECOVER) and ATTACH. Eur J Heart Fail. Aug. 2002;4(4):559-61. [pmid: 12167397].
101 Combe B, Codreanu C, Fiocco U, et al. Etanercept and sulfasalazine, alone and combined, in patients with active rheumatoid arthritis despite receiving sulfasalazine: A double-blind comparison. Annals of the rheumatic diseases. 2006;65(10):1357-62. [pmid: 16606651].
102 Combe B, Landewe R, Lukas C, et al. EULAR recommendations for the management of early arthritis: Report of a task force of the European Standing Committee for International Clinical Studies Including Therapeutics (ESCISIT). Annals of the rheumatic diseases. 2007;66(1):34-45. [pmid: 16396980].
103 Connell L, McInnes IB. New cytokine targets in inflammatory rheumatic diseases. Best Practice and Research: Clinical Rheumatology. 2006;20(5):865-78. [pmid: 16980211].
104 Cope AP. T cells in rheumatoid arthritis. Arthritis Research and Therapy. 2008;10(SUPPL 1).
105 Corbo M, Tay LK, Leon F, et al. A single dose of abatacept does not prevent the development of a positive immune response to tetanus and pneumococcal vacciness. Ann Rheum Dis. 2006;65(SUPPL II):184. [pmid: 15975972].
106 Cvetkovic RS, Scott LJ. Adalimumab: a review of its use in adult patients with rheumatoid arthritis. BioDrugs. 2006;20(5):293-311. [pmid: 17025376].
107 Davis MJ, Dawes PT, Fowler PD, et al. Should disease-modifying agents be used in mild rheumatoid arthritis?. Br J Rheumatol. Dec. 1991;30(6):451-4. [pmid: 1747702].
108 De Filippis L, Caliri A, Anghelone S, et al. Improving outcomes in tumour necrosis factor a treatment: comparison of the efficacy of the tumour necrosis factor a blocking agents etanercept and infliximab in patients with active rheumatoid arthritis. Panminerva Med. 2006;48(2):129-35. [pmid: 16953150].
109 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173.
110 Devine EB, Alfonso-Cristancho R, Sullivan SD. Effectiveness of biologic therapies for rheumatoid arthritis: an indirect comparisons approach. Pharmacotherapy. 2011;31(1):39-51. [pmid: 21182357].
111 Dixon WG, Hyrich KL, Watson KD, et al. Drug-specific risk of tuberculosis in patients with rheumatoid arthritis treated with anti-TNF therapy: results from the British Society for Rheumatology Biologics Register (BSRBR). Ann Rheum Dis. 2010;69(3):522-8. [pmid: 19854715].
112 Dixon WG, Symmons DP, Lunt M, et al. Serious infection following anti-tumor necrosis factor alpha therapy in patients with rheumatoid arthritis: lessons from interpreting data from observational studies. Arthritis Rheum. 2007;56(9):2896-904. [pmid: 17763441].
113 Dixon WG, Watson K, Lunt M, et al. Rates of serious infection, including site-specific and bacterial intracellular infection, in rheumatoid arthritis patients receiving anti-tumor necrosis factor therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum. Jul. 25. 2006;54(8):2368-76. [pmid: 16868999].
114 Donahue KE, Gartlehner G, Jonas DE, et al. Comparative effectiveness of drug therapy for rheumatoid arthritis and psoriatic arthritis in adults, Comparative Effectiveness Review No 11. (Prepared by RTI-University of North Carolina Evidence-based Practice Center under Contract No 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. 2007.
115 Edmonds J, Saudan A, Lassere M, et al. Introduction to reading radiographs by the Scott modification of the Larsen method. J Rheumatol. 1999;26:740-2. [pmid: 10090193].
116 Efthimiou P, Kontzias A, Ward CM, et al. Adult-onset Still's disease: can recent advances in our understanding of its pathogenesis lead to targeted therapy?. Nat Clin Pract Rheumatol. Jun. 2007;3(6):328-35. [pmid: 17538564].
117 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. 2nd edition. 2001. 2001.
118 Emery P, Breedveld FC, Jubb RW, et al. Efficacy and safety of leflunomide vs. methotrexate in rheumatoid arthritis (RA): results of a double-blind, randomized, 2-year trial. Arthritis and Rheumatism. 1999;42(9 (Suppl)):S271.
119 Emery P, Fleischmann R, Filipowicz-Sosnowska A, et al. The efficacy and safety of rituximab in patients with active rheumatoid arthritis despite methotrexate treatment: results of a phase IIB randomized, double-blind, placebo-controlled, dose-ranging trial. Arthritis Rheum. 2006;54(5):1390-400. [pmid: 16649186].
120 Feagan BG, Yan S, Bala M, et al. The effects of infliximab maintenance therapy on health-related quality of life. Am J Gastroenterol. Oct. 2003;98(10):2232-8. [pmid: 14572573].
121 Felson DT, Anderson JJ, Boers M, et al. The American College of Rheumatology preliminary core set of disease activity measures for rheumatoid arthritis clinical trials. The Committee on Outcome Measures in Rheumatoid Arthritis Clinical Trials. Arthritis Rheum. Jun. 1993;36(6):729-40. [pmid: 8507213].
122 Felson DT, Anderson JJ, Boers M, et al. ACR preliminary definition of improvement in rheumatoid arthritis. Arthritis Rheum. 1995;38(6):727-35. [pmid: 7779114].
123 Felson DT, Anderson JJ, Boers M, et al. American College of Rheumatology. Preliminary definition of improvement in rheumatoid arthritis. Arthritis Rheum. 1995;38(6):727-35. [pmid: 7779114].
124 Felson DT, Anderson JJ, Meenan RF. The comparative efficacy and toxicity of second-line drugs in rheumatoid arthritis. Results of two metaanalyses. Arthritis Rheum. Oct. 1990;33(10):1449-61. [pmid: 1977391].
125 Felson DT, Anderson JJ, Meenan RF. The efficacy and toxicity of combination therapy in rheumatoid arthritis. A meta-analysis. Arthritis Rheum. Oct. 1994;37(10):1487-91. [pmid: 7945474].
126 Fernandez-Espartero MC, Perez-Zafrilla B, Naranjo A, et al. Demyelinating Disease in Patients Treated with TNF Antagonists in Rheumatology: Data from BIOBADASER, a Pharmacovigilance Database, and a Systematic Review. Semin Arthritis Rheum. 2010;40(4):330-7. [pmid: 20864146].
127 Finckh A, Liang MH, Van Herckenrode CM, et al. Long-term impact of early treatment on radiographic progression in rheumatoid arthritis: Ameta-analysis. Arthritis and rheumatism. 2006;55(6):86-172. [pmid: 16463418].
128 Finckh A, Simard JF, Gabay C, et al. Evidence for differential acquired drug resistance to anti-tumour necrosis factor agents in rheumatoid arthritis. Ann Rheum Dis. Jun. 2006;65(6):746-52. [pmid: 16339288].
129 Firestein GS. Etiology and pathogenesis of rheumatoid arthritis. Kelley's Testbook of Rheumatology. 2005;7.
130 Fleischmann R, Iqbal I. Risk: benefit profile of etanercept in elderly patients with rheumatoid arthritis, ankylosing spondylitis or psoriatic arthritis. Drugs Aging. 2007;24(3):239-54. [pmid: 17362051].
131 Fleischmann R, Iqbal I, Nandeshwar P, et al. Safety and efficacy of disease-modifying anti-rheumatic agents: focus on the benefits and risks of etanercept. Drug Saf. 2002;25(3):173-97. [pmid: 11945114].
132 Fleischmann RM, Baumgartner SW, Tindall EA, et al. Response to etanercept (Enbrel) in elderly patients with rheumatoid arthritis: a retrospective analysis of clinical trial results. J Rheumatol. Apr. 2003;30(4):691-6. [pmid: 12672185].
133 Flendrie M, Vissers WH, Creemers MC, et al. Dermatological conditions during TNF-alpha-blocking therapy in patients with rheumatoid arthritis: a prospective study. Arthritis Res Ther. 2005;7(3):R666-76. [pmid: 15899052].
134 Food and Drug Administration. FDA alert on rituximab. available at: http://www.fda.gov/cder/drug/infopage/rituximab/default.htm. 2006.
135 Frankel EH, Strober BE, Crowley JJ, et al. Etanercept improves psoriatic arthritis patient-reported outcomes: results from EDUCATE. Cutis. Apr. 2007;79(4):322-6. [pmid: 17500381].
136 Fransen J, van Riel PL. The Disease Activity Score and the EULAR response criteria. Rheum Dis Clin North Am. 2009;35(4):745-57. vii. viii. [pmid: 19962619].
137 Fredriksson T, Pettersson U. Severe psoriasis--oral therapy with a new retinoid. Dermatologica. 1978;157(4):238-44. [pmid: 357213].
138 Friedrich-Rust M, Ong M, Martens S, et al. Performance of Transient Elastography for the Staging of Liver Fibrosis: A Meta-Analysis. Gastroenterology. 2008;134(4).
139 Fries JF, Spitz P, Kraines RG, et al. Measurement of patient outcome in arthritis. Arthritis Rheum. Feb. 1980;23(2):137-45. [pmid: 7362664].
140 Fries JF, Williams CA, Morfeld D, et al. Reduction in long-term disability in patients with rheumatoid arthritis by disease-modifying antirheumatic drug-based treatment strategies. Arthritis Rheum. Apr. 1996;39(4):616-22. [pmid: 8630111].
141 Furst D, Luggen M, Thompson A, et al. Adding leflunomide to patients with active rheumatoid arthritis patients while receiving methotrexate improves physical function and health related quality of life. Arthritis and Rheumatism. 2000;43(Suppl):S344.
142 Furst DE, Breedveld FC, Kalden JR, et al. Updated consensus statement on biological agents for the treatment of rheumatic diseases, 2007. Annals of the rheumatic diseases. 2007;66(SUPPL 3).
143 Furst DE, Keystone EC, Kirkham B, et al. Updated consensus statement on biological agents for the treatment of rheumatic diseases, 2008. Annals of the rheumatic diseases. 2008;67(SUPPL 3).
144 Galloway JB, Hyrich KL, Mercer LK, et al. Anti-TNF therapy is associated with an increased risk of serious infections in patients with rheumatoid arthritis especially in the first 6 months of treatment: updated results from the British Society for Rheumatology Biologics Register with special emphasis on risks in the elderly. Rheumatology (Oxford, England). 2011;50(1):124-31.
145 GalvaÃ± VG, Oltra MR, Rueda D, et al. Severe acute hepatitis related to hydroxychloroquine in a woman with mixed connective tissue disease. Clinical rheumatology. 2007;26(6):971-2. [pmid: 16575495].
146 Gartlehner G, Hansen R, Thieda P, et al. Drug Class Review on Targeted Immune Modulators, Final AHRQ-approved report December 2006. available at http://www.ohsu.edu/drugeffectiveness/reports/draft.cfm. 2006.
147 Gartlehner G, Hansen RA, Jonas BL, et al. The comparative efficacy and safety of biologics for the treatment of rheumatoid arthritis: a systematic review and metaanalysis. J Rheumatol. 2006.
148 Gelfand JM, Gladman DD, Mease PJ, et al. Epidemiology of psoriatic arthritis in the population of the United States. J Am Acad Dermatol. 2005;53(4):573. [pmid: 16198775].
149 Genant HK, Peterfy C, Westhovens R. Abatacept sustains inhibition of radiographic progression over 2 years in rheumatoid arthritis patients with an inadequate response to methotrexate: Results from the long-term extension of the AIM trial. Ann Rheum Dis. 2006;65:57-8. [pmid: 15919679].
150 Genovese M, Kaine J, Lowenstein M. Ocrelizumab, a novel humanized anti-CD20 antibody: Week 72 results from a phase I/II clinical trial in patients with rheumatoid arthritis [abstract]. American College of Rheumatology Annual Meeting. 2007.
151 Genovese MC, Mease PJ, Thomson GT, et al. Safety and efficacy of adalimumab in treatment of patients with psoriatic arthritis who had failed disease modifying antirheumatic drug therapy. J Rheumatol. 2007;34(5):1040-50. [pmid: 17444593].
152 Gilaberte Y, Coscojuela C, Vazquez C, et al. Perforating folliculitis associated with tumour necrosis factor-alpha inhibitors administered for rheumatoid arthritis. Br J Dermatol. Feb. 2007;156(2):368-71. [pmid: 17223880].
153 Gladman DD. Effectiveness of psoriatic arthritis therapies. Semin Arthritis Rheum. Aug. 2003;33(1):29-37. [pmid: 12920694].
154 Gladman DD, Antoni C, Mease P, et al. Psoriatic arthritis: epidemiology, clinical features, course, and outcome. Ann Rheum Dis. 2005;64(Suppl 2ii):14-7.
155 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
156 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
157 Golding A, Haque UJ, Giles JT. Rheumatoid arthritis and reproduction. Rheum Dis Clin North Am. May. 2007;33(2):319-43. vi. vii. [pmid: 17499710].
158 Goldman JA, Xia HA, White B, et al. Evaluation of a modified ACR20 scoring system in patients with rheumatoid arthritis receiving treatment with etanercept. Ann Rheum Dis. Dec. 2006;65(12):1649-52. [pmid: 17105853].
159 Gonzalez-Lopez MA, Blanco R, Gonzalez-Vela MC, et al. Development of sarcoidosis during etanercept therapy. Arthritis Rheum. Oct. 15. 2006;55(5):817-20. [pmid: 17013853].
160 Goodman SN. Toward evidence-based medical statistics. 2: The Bayes factor. Ann Intern Med. Jun. 15. 1999;130(12):1005-13. [pmid: 10383350].
161 Gottlieb AB, Boehncke WH, Darif M. Safety and efficacy of alefacept in elderly patients and other special populations. J Drugs Dermatol. Nov–Dec. 2005;4(6):718-24. [pmid: 16302557].
162 Greenberg JD, Reed G, Kremer JM, et al. Association of methotrexate and tumour necrosis factor antagonists with risk of infectious outcomes including opportunistic infections in the CORRONA registry. Ann Rheum Dis. 2010;69(2):380-6. [pmid: 19359261].
163 Greiner A, Plischke H, Kellner H, et al. Association of Anti-Cyclic Citrullinated Peptide Antibodies, Anti-Citrullin Antibodies, and IgM and IgA Rheumatoid Factors with Serological Parameters of Disease Activity in Rheumatoid Arthritis. Ann N Y Acad Sci. Jun. 2005;1050:295-303. [pmid: 16014545].
164 Grismer LE, Gill SA, Harris MD. Liver biopsy in psoriatic arthritis to detect methotrexate hepatotoxicity. J Clin Rheumatol. Aug. 2001;7(4):224-7. [pmid: 17039139].
165 Guyatt G, Gutterman D, Baumann MH, et al. Grading strength of recommendations and quality of evidence in clinical guidelines: report from an american college of chest physicians task force. Chest. Jan. 2006;129(1):174-81. [pmid: 16424429].
166 HÃ¤kkinen A, Kautiainen H, Hannonen P, et al. Muscle strength, pain, and disease activity explain individual subdimensions of the Health Assessment Questionnaire disability index, especially in women with rheumatoid arthritis. Annals of the rheumatic diseases. 2006;65(1):30-4. [pmid: 15901635].
167 Hallert E, Husberg M, Skogh T. Costs and course of disease and function in early rheumatoid arthritis: a 3-year follow-up (the Swedish TIRA project). Rheumatology (Oxford). Mar. 2006;45(3):325-31. [pmid: 16287927].
168 Han C, Robinson DW Jr, Hackett MV, et al. Cardiovascular disease and risk factors in patients with rheumatoid arthritis, psoriatic arthritis, and ankylosing spondylitis. J Rheumatol. Nov. 2006;33(11):2167-72. [pmid: 16981296].
169 Hara M, Abe T, Sugawara S, et al. Efficacy and safety of iguratimod compared with placebo and salazosulfapyridine in active rheumatoid arthritis: a controlled, multicenter, double-blind, parallel-group study. Mod Rheumatol. 2007;17(1):1-9. [pmid: 17278015].
170 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
171 Hasan U. Tumour necrosis factor inhibitors--what we need to know. N Z Med J. 2006;119(1246):U2336. [pmid: 17151710].
172 Hays RD, Morales LS. The RAND-36 measure of health-related quality of life. Ann Med. 2001;33(5):350-7. [pmid: 11491194].
173 Heiberg MS, Kaufmann C, Rodevand E, et al. The comparative effectiveness of anti-TNF therapy and methotrexate in patients with psoriatic arthritis: 6 month results from a longitudinal, observational, multicentre study. Ann Rheum Dis. Aug. 2007;66(8):1038-42. [pmid: 17213251].
174 Heiberg MS, RÃ¸devand E, Mikkelsen K, et al. Adalimumab and methotrexate is more effective than adalimumab alone in patients with established rheumatoid arthritis: Results from a 6-month longitudinal, observational, multicentre study. Annals of the rheumatic diseases. 2006;65(10):1379-83. [pmid: 16679432].
175 Helliwell PS. Therapies for dactylitis in psoriatic arthritis. A systematic review. J Rheumatol. Jul. 2006;33(7):1439-41. [pmid: 16724369].
176 Helliwell PS, Ibrahim G. Ethnic differences in responses to disease modifying drugs. Rheumatology (Oxford). Oct. 2003;42(10):1197-201. [pmid: 12810940].
177 Helliwell PS, Taylor WJ. Classification and diagnostic criteria for psoriatic arthritis. Ann Rheum Dis. Mar. 2005;64(Suppl 2):ii3-8. [pmid: 15708931].
178 Helmick CG, Felson DT, Lawrence RC, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part I. Arthritis Rheum. 2008;58(1):15-25. [pmid: 18163481].
179 Hewlett S, Hehir M, Kirwan JR. Measuring fatigue in rheumatoid arthritis: A systematic review of scales in use. Arthritis Care and Research. 2007;57(3):429-39. [pmid: 17394228].
180 Higgins JP, Whitehead A. Borrowing strength from external trials in a meta-analysis. Stat Med. 1996;15(24):2733-49. [pmid: 8981683].
181 Hochberg MC, Tracy JK, Flores RH. "Stepping-up" from methotrexate: a systematic review of randomised placebo controlled trials in patients with rheumatoid arthritis with an incomplete response to methotrexate. Ann Rheum Dis. Nov. 2001;60(Suppl 3):iii51-4. [pmid: 11890654].
182 Hochberg MC, Tracy JK, Hawkins-Holt M, et al. Comparison of the efficacy of the tumour necrosis factor alpha blocking agents adalimumab, etanercept, and infliximab when added to methotrexate in patients with active rheumatoid arthritis. Ann Rheum Dis. 2003;62(Suppl 2):ii13-6. [pmid: 14532140].
183 Huedo-Medina TB, SÃ¡nchez-Meca J, MarÃ‐n-MartÃ‐nez F, et al. Assessing heterogeneity in meta-analysis: Q statistic or I^2^ Index?. Psychological Methods. 2006;11(2):193-206. [pmid: 16784338].
184 Hurst NP, Kind P, Ruta D, et al. Measuring health-related quality of life in rheumatoid arthritis: validity, responsiveness and reliability of EuroQol (EQ-5D). Br J Rheumatol. May. 1997;36(5):551-9. [pmid: 9189057].
185 Huscher D, Merkesdal S, Thiele K, et al. Cost of illness in rheumatoid arthritis, ankylosing spondylitis, psoriatic arthritis and systemic lupus erythematosus in Germany. Ann Rheum Dis. Sep. 2006;65(9):1175-83. [pmid: 16540552].
186 Husted JA, Gladman DD, Farewell VT, et al. Health-related quality of life of patients with psoriatic arthritis: a comparison with patients with rheumatoid arthritis. Arthritis Rheum. Apr. 2001;45(2):151-8. [pmid: 11324779].
187 Hyrich KL, Symmons DP, Watson KD, et al. Comparison of the response to infliximab or etanercept monotherapy with the response to cotherapy with methotrexate or another disease-modifying antirheumatic drug in patients with rheumatoid arthritis: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum. May. 30. 2006;54(6):1786-94. [pmid: 16736520].
188 ICH. International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use ICH Harmonised Tripartite Guideline Clinical Safety Data Management. Definitions and Standards for Expedited Reporting E2A. available at http://www.ich.org/LOB/media/MEDIA436.pdf. 1994.
189 Jansen JP, Crawford B, Bergman G, et al. Bayesian meta-analysis of multiple treatment comparisons: an introduction to mixed treatment comparisons. Value Health. Sep–Oct. 2008;11(5):956-64. [pmid: 18489499].
190 Javitz HS, Ward MM, Farber E, et al. The direct cost of care for psoriasis and psoriatic arthritis in the United States. J Am Acad Dermatol. Jun. 2002;46(6):850-60. [pmid: 12063481].
191 Jobanputra P, Barton P, Bryan S, et al. The effectiveness of infliximab and etanercept for the treatment of rheumatoid arthritis: a systematic review and economic evaluation. Health Technol Assess. 2002;6(21):1-110. [pmid: 12387732].
192 Kaine J, Kivitz A, Birbara C, et al. Effect of adalimumab (HumiraÂ®) on response to pneumococcal and influenza virus vaccines in patients with rheumatoid arthritis (RA). Ann Rheum Dis. 2006;65(SUPPL II):304.
193 Kaine JL, Kivitz AJ, Birbara C, et al. Immune responses following administration of influenza and pneumococcal vaccines to patients with rheumatoid arthritis receiving adalimumab. J Rheumatol. Feb. 2007;34(2):272-9. [pmid: 17304653].
194 Kapetanovic M, Saxne T, Nilsson J. Influenza vaccination as model for testing immune modulation of anti-TNF and methotrexate therapy in rheumatoid arthritis patients. Ann Rheum Dis. 2006;65(SUPPL II):184. [pmid: 15975972].
195 Katchamart W, Ortiz Z, Shea B, et al. Folic acid and folinic acid for reducing side effects in patients receiving methotrexate for rheumatoid arthritis (an update systematic review and metaanalysis). Arthritis Rheum. 2008;58.
196 Kavanaugh A, Antoni C, Mease P, et al. Effect of infliximab therapy on employment, time lost from work, and productivity in patients with psoriatic arthritis. J Rheumatol. 2006;33(11):2254-9. [pmid: 16960923].
197 Kavanaugh A, Krueger GG, Beutler A, et al. Infliximab maintains a high degree of clinical response in patients with active psoriatic arthritis through 1 year of treatment: results from the IMPACT 2 trial. Ann Rheum Dis. Apr. 2007;66(4):498-505. [pmid: 17114188].
198 Kavanaugh AF, Ritchlin CT. Systematic review of treatments for psoriatic arthritis: an evidence based approach and basis for treatment guidelines. J Rheumatol. Jul. 2006;33(7):1417-21. [pmid: 16724373].
199 Kievit W, Fransen J, Kupper HH, et al. The drug survival of adalimumab compared to etanercept and infliximab in the treatment of patients with rheumatoid arthritis in daily clinical practice. Ann Rheum Dis. June. 1. 2006. 2006;65(Suppl 2):325.
200 Kim HY, Lee SK, Song YW, et al. A randomized, double-blind, placebo-controlled, phase III study of the human anti-tumor necrosis factor antibody adalimumab administered as subcutaneous injections in Korean rheumatoid arthritis patients treated with methotrexate. APLAR Journal of Rheumatology. 2007;10(1):9-16.
201 Kind P. The EuroQol instrument: An index of health-related quality of life, Quality of life and PharmacoEconomics in Clinical Trials. 2nd ed. Philadelphia. Lippincott-Raven Publishers. 1996.
202 Kirwan JR, Bijlsma JW, Boers M, et al. Effects of glucocorticoids on radiological progression in rheumatoid arthritis. Cochrane Database Syst Rev. 2007;(1):CD006356. [pmid: 17253590].
203 Kosinski M, Zhao SZ, Dedhiya S, et al. Determining minimally important changes in generic and disease-specific health-related quality of life questionnaires in clinical trials of rheumatoid arthritis. Arthritis Rheum. 2000;43(7):1478-87. [pmid: 10902749].
204 Kremer J, Westhovens R, Luggen M. Long-term efficacy and safety of abatacept through 3 years of treatment in rheumatoid arthritis patients in the AIM and ATTAIN trials [abstract]. American College of Rheumatology Meeting.
205 Kremer JL, Blanco R, Brzosko M, et al. Tocilizumab inhibits structural joint damage in rheumatoid arthritis patients with inadequate responses to methotrexate at 1 year: The LITHE study. Arthritis Rheum. 2010.
206 Kremer JM. Safety, efficacy, and mortality in a long-term cohort of patients with rheumatoid arthritis taking methotrexate: followup after a mean of 13.3 years. Arthritis Rheum. May. 1997;40(5):984-5. [pmid: 9153566].
207 Kremer JM, Caldwell JR, Cannon GW, et al. The combination of leflunomide and methotrexate in patients with active rheumatoid arthritis who are failing on methotrexate treatment alone: a double-blind placebo-controlled study. Arthritis Rheum. 2000;43(Suppl 9):S224.
208 Kremer JM, Dougados M, Emery P, et al. Treatment of rheumatoid arthritis with the selective costimulation modulator abatacept: twelve-month results of a phase iib, double-blind, randomized, placebo-controlled trial. Arthritis Rheum. Aug. 2005;52(8):2263-71. [pmid: 16052582].
209 Kristensen LE, Christensen R, Bliddal H, et al. The number needed to treat for adalimumab, etanercept, and infliximab based on ACR50 response in three randomized controlled trials on established rheumatoid arthritis: A systematic literature review. Scandinavian Journal of Rheumatology. 2007;36(6):411-7. [pmid: 18092260].
210 Laivoranta-Nyman S, Mottonen T, Hannonen P, et al. Association of tumour necrosis factor a, b and c microsatellite polymorphisms with clinical disease activity and induction of remission in early rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 2006;24(6):636-42. [pmid: 17207378].
211 Landewe R, van der Heijde D, van der Linden S, et al. Twenty-eight-joint counts invalidate the DAS28 remission definition owing to the omission of the lower extremity joints: a comparison with the original DAS remission. Ann Rheum Dis. May. 2006;65(5):637-41. [pmid: 16219709].
212 Lard LR, Visser H, Speyer I, et al. Early versus delayed treatment in patients with recent-onset rheumatoid arthritis: comparison of two cohorts who received different treatment strategies. Am J Med. Oct. 15. 2001;111(6):446-51. [pmid: 11690569].
213 Larsen A. Radiological grading of rheumatoid arthritis. An interobserver study. Scand J Rheumatol. 1973;2(3):136-8. [pmid: 4769066].
214 Larsen A. How to apply Larsen score in evaluating radiographs of rheumatoid arthritis in long-term studies. J Rheumatol. 1995;22:1974-5. [pmid: 8992003].
215 Larsen A, Dale K, Eek M. Radiographic evaluation of rheumatoid arthritis and related conditions by standard reference films. Acta Radiol Diagn (Stockh). Jul. 1977;18(4):481-91. [pmid: 920239].
216 Lau J, Ioannidis JPA, Terrin N, et al. The case of the misleading funnel plot. British Medical Journal. 2006;333(7568):597-600. [pmid: 16974018].
217 Lawrence RC, Felson DT, Helmick CG, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part II. Arthritis Rheum. 2008;58(1):26-35. [pmid: 18163497].
218 Lee YH, Woo JH, Rho YH, et al. Meta-analysis of the combination of TNF inhibitors plus MTX compared to MTX monotherapy, and the adjusted indirect comparison of TNF inhibitors in patients suffering from active rheumatoid arthritis. Rheumatology international. 2008;28(6):553-9. [pmid: 17943257].
219 Leombruno JP, Einarson TR, Keystone EC. The safety of anti-tumour necrosis factor treatments in rheumatoid arthritis: meta and exposure-adjusted pooled analyses of serious adverse events. Ann Rheum Dis. 2009;68(7):1136-45. [pmid: 18753157].
220 Lequerre T, Vittecoq O, Klemmer N, et al. Management of infusion reactions to infliximab in patients with rheumatoid arthritis or spondyloarthritis: experience from an immunotherapy unit of rheumatology. J Rheumatol. Jul. 2006;33(7):1307-14. [pmid: 16758513].
221 Li X, Gignac MA, Anis AH. The indirect costs of arthritis resulting from unemployment, reduced performance, and occupational changes while at work. Med Care. 2006;44(4):304-10. [pmid: 16565630].
222 Liao KP, Batra KL, Chibnik L, et al. Anti-cyclic citrullinated peptide revised criteria for the classification of rheumatoid arthritis. Ann Rheum Dis. 2008;67(11):1557-61. [pmid: 18234714].
223 Lim LL, Fraunfelder FW, Rosenbaum JT. Do tumor necrosis factor inhibitors cause uveitis? A registry-based study. Arthritis Rheum. Oct. 2007;56(10):3248-52. [pmid: 17907169].
224 Lindqvist E, Saxne T, Geborek P, et al. Ten year outcome in a cohort of patients with early rheumatoid arthritis: health status, disease process, and damage. Ann Rheum Dis. Dec. 2002;61(12):1055-9. [pmid: 12429534].
225 Lindsay K, Gough A. Psoriatic arthritis, methotrexate and the liver - Are rheumatologists putting their patients at risk?. Rheumatology. 2008;47(7):939-41. [pmid: 18474510].
226 Listing J, Strangfeld A, Rau R, et al. Clinical and functional remission: even though biologics are superior to conventional DMARDs overall success rates remain low--results from RABBIT, the German biologics register. Arthritis Res Ther. 2006;8(3):R66. [pmid: 16600016].
227 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
228 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
229 MÃ¤ki-PetÃ¤jÃ¤ KM, Booth AD, Hall FC, et al. Ezetimibe and Simvastatin Reduce Inflammation, Disease Activity, and Aortic Stiffness and Improve Endothelial Function in Rheumatoid Arthritis. Journal of the American College of Cardiology. 2007;50(9):852-8. [pmid: 17719471].
230 Mader R, Keystone E. Optimizing treatment with biologics. Journal of Rheumatology. 2007;34(SUPPL 80):16-24. [pmid: 17216674].
231 Maetzel A, Wong A, Strand V, et al. Meta-analysis of treatment termination rates among rheumatoid arthritis patients receiving disease-modifying anti-rheumatic drugs. Rheumatology (Oxford). Sep. 2000;39(9):975-81. [pmid: 10986302].
232 Manadan AM, Mohan AK. Tuberculosis and etanercept treatment. Arthritis Rheum. 2002;46:S166.
233 Marcora SM, Chester KR, Mittal G, et al. Randomized phase 2 trial of anti-tumor necrosis factor therapy for cachexia in patients with early rheumatoid arthritis. Am J Clin Nutr. Dec. 2006;84(6):1463-72. [pmid: 17158431].
234 Markham T, Mathews C, Rogers S, et al. Downregulation of the inhibitor of apoptosis protein survivin in keratinocytes and endothelial cells in psoriasis skin following infliximab therapy. British Journal of Dermatology. 2006;155(6):1191-6. [pmid: 17107388].
235 Martin M, Kosinski M, Bjorner JB, et al. Item response theory methods can improve the measurement of physical function by combining the modified health assessment questionnaire and the SF-36 physical function scale. Qual Life Res. May. 2007;16(4):647-60. [pmid: 17334829].
236 Mau W, Listing J, Huscher D, et al. Employment across chronic inflammatory rheumatic diseases and comparison with the general population. J Rheumatol. Apr. 2005;32(4):721-8. [pmid: 15801031].
237 McHorney CA, Ware JE Jr, Lu JF, et al. The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care. Jan. 1994;32(1):40-66. [pmid: 8277801].
238 McHorney CA, Ware JE Jr, Raczek AE. The MOS 36-Item Short-Form Health Survey (SF-36): II. Psychometric and clinical tests of validity in measuring physical and mental health constructs. Med Care. Mar. 1993;31(3):247-63. [pmid: 8450681].
239 McHorney CA, Ware JE Jr, Rogers W, et al. The validity and relative precision of MOS short- and long-form health status scales and Dartmouth COOP charts. Results from the Medical Outcomes Study. Med Care. May. 1992;30(5 Suppl):MS253-65. [pmid: 1583937].
240 McInnes IB, Schett G. Cytokines in the pathogenesis of rheumatoid arthritis. Nature Reviews Immunology. 2007;7(6):429-42.
241 Mease P. Psoriatic arthritis update. Bulletin of the NYU Hospital for Joint Diseases. 2006;64(1–2):25-31. [pmid: 17121486].
242 Mease PJ, Antoni CE, Gladman DD, et al. Psoriatic arthritis assessment tools in clinical trials. Ann Rheum Dis. Mar. 2005;64(Suppl 2):ii49-54. [pmid: 15708937].
243 Mease PJ, Gladman DD, Keystone EC. Alefacept in combination with methotrexate for the treatment of psoriatic arthritis: results of a randomized, double-blind, placebo-controlled study. Arthritis Rheum. May. 2006;54(5):1638-45. [pmid: 16646026].
244 Michaud K, Messer J, Choi HK, et al. Direct medical costs and their predictors in patients with rheumatoid arthritis: a three-year study of 7,527 patients. Arthritis Rheum. Oct. 2003;48(10):2750-62. [pmid: 14558079].
245 Miller LG, Hays RD. Adherence to combination antiretroviral therapy: synthesis of the literature and clinical implications. AIDS Read. Mar. 2000;10(3):177-85. [pmid: 10758022].
246 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov. 27. 1999;354(9193):1896-900. [pmid: 10584742].
247 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Int J Surg. 2010;8(5):336-41. [pmid: 20171303].
248 Moreland LW, Baumgartner SW, Schiff MH, et al. Treatment of rheumatoid arthritis with a recombinant human tumor necrosis factor receptor (p75)-Fc fusion protein. N Engl J Med. Jul. 17. 1997;337(3):141-7. [pmid: 9219699].
249 Moreland LW, Cohen SB, Baumgartner S, et al. Long-term use of etanercept in patients with DMARD-refractory arthritis. Arthritis Rheum. 1992;42(Suppl 9):S401.
250 Moreland LW, Genovese MC, Sato R, et al. Effect of etanercept on fatigue in patients with recent or established rheumatoid arthritis. Arthritis Rheum. Apr. 15. 2006;55(2):287-93. [pmid: 16583424].
251 Moreland LW, Weinblatt ME, Keystone EC, et al. Etanercept treatment in adults with established rheumatoid arthritis: 7 years of clinical experience. J Rheumatol. May. 2006;33(5):854-61. [pmid: 16541481].
252 Moss ML, Sklair-Tavron L, Nudelman R. Drug Insight: Tumor necrosis factor-converting enzyme as a pharmaceutical target for rheumatoid arthritis. Nature Clinical Practice Rheumatology. 2008;4(6):300-9.
253 Mroczkowski PJ, Weinblatt ME, Kremer JM. Methotrexate and leflunomide combination therapy for patients with active rheumatoid arthritis. Clin Exp Rheumatol. Nov–Dec. 1999;17(6 Suppl 18):S66-8. [pmid: 10589360].
254 Muller-Ladner U, Pap T, Gay RE, et al. Mechanisms of disease: the molecular and cellular basis of joint destruction in rheumatoid arthritis. Nat Clin Pract Rheumatol. Dec. 2005;1(2):102-10. [pmid: 16932639].
255 Multi-Parameter Evidence Synthesis (MPES) Research Group. Available at: https://www.bris.ac.uk/cobm/research/mpes/mtc.html.
256 Munafo A, Priestley A, Nestorov I, et al. Safety, pharmacokinetics and pharmacodynamics of atacicept in healthy volunteers. European Journal of Clinical Pharmacology. 2007;63(7):647-56. [pmid: 17473917].
257 Munoz P, Giannella M, Valerio M, et al. Cryptococcal meningitis in a patient treated with infliximab. Diagn Microbiol Infect Dis. Apr. 2007;57(4):443-6. [pmid: 17240111].
258 Nam JL, Winthrop KL, van Vollenhoven RF, et al. Current evidence for the management of rheumatoid arthritis with biological disease-modifying antirheumatic drugs: a systematic literature review informing the EULAR recommendations for the management of RA. Ann Rheum Dis. 2010;69(6):976-86. [pmid: 20447957].
259 Nash P. Therapies for axial disease in psoriatic arthritis. A systematic review. J Rheumatol. Jul. 2006;33(7):1431-4. [pmid: 16724371].
260 Nathan DM, Angus PW, Gibson PR. Hepatitis B and C virus infections and anti-tumor necrosis factor-Î± therapy: Guidelines for clinical approach. Journal of Gastroenterology and Hepatology. 2006;21(9):1366-71. [pmid: 16911678].
261 Nishimoto N, Kishimoto T. Humanized antihuman IL-6 receptor antibody, tocilizumab. Handbook of experimental pharmacology. 2008;(181):151-60. [pmid: 18071945].
262 Nixon RM, Bansback N, Brennan A. Using mixed treatment comparisons and meta-regression to perform indirect comparisons to estimate the efficacy of biologic treatments in rheumatoid arthritis. Statistics in Medicine. 2007;26(6):1237-54. [pmid: 16900557].
263 Norris SL, Atkins D. Challenges in using nonrandomized studies in systematic reviews of treatment interventions. Ann Intern Med. Jun. 21. 2005;142(12 Pt 2):1112-9. [pmid: 15968036].
264 O'Dell J, Leff R, Paulsen G, et al. Methotrexate (M)-Hydroxychloroquine (H)-Sulfasalazine (S) versus M-H or M-S for rheumatoid arthritis (RA): results of a double-blind study. Arthritis Rheum. 1999;42(Suppl 9):S117.
265 O'Dell JR, Haire CE, Erikson N, et al. Treatment of rheumatoid arthritis with methotrexate alone, sulfasalazine and hydroxychloroquine, or a combination of all three medications. N Engl J Med. May. 16. 1996;334(20):1287-91. [pmid: 8609945].
266 Ogrendik M. Levofloxacin treatment in patients with rheumatoid arthritis receiving methotrexate. South Med J. Feb. 2007;100(2):135-9. [pmid: 17330681].
267 Ohsugi Y. Recent advances in immunopathophysiology of interleukin-6: An innovative therapeutic drug, tocilizumab (recombinant humanized anti-human interleukin-6 receptor antibody), unveils the mysterious etiology of immune-mediated inflammatory diseases. Biological and Pharmaceutical Bulletin. 2007;30(11):2001-6. [pmid: 17978466].
268 Ojeda-Uribe M, Gilliot C, Jung G, et al. Administration of rituximab during the first trimester of pregnancy without consequences for the newborn. Journal of Perinatology. 2006;26(4):252-5. [pmid: 16570081].
269 Okada SK, Siegel JN. Risk of serious infections and malignancies with anti-TNF antibody therapy in rheumatoid arthritis. Jama. Nov. 8. 2006;296(18):2201-2. author reply 3–4. [pmid: 17090760].
270 Olivieri I, Mantovani LG, D'Angelo S, et al. Psoriatic arthritis: pharmacoeconomic considerations. Curr Rheumatol Rep. 2009;11(4):263-9. [pmid: 19691929].
271 Oren C, Mendelbaum M, Paran D. Vaccination against influenza in rheumatoid arthritis patients: The effect of rituximab on the humoral response. Arthritis Rheum. 2006;54(SUPPL 9).
272 Ornetti P, Chevillotte H, Zerrak A, et al. Anti-tumour necrosis factor-alpha therapy for rheumatoid and other inflammatory arthropathies: update on safety in older patients. Drugs Aging. 2006;23(11):855-60. [pmid: 17109564].
273 Orozco G, Rueda B, Martin J. Genetic basis of rheumatoid arthritis. Biomed Pharmacother. Dec. 2006;60(10):656-62. [pmid: 17055211].
274 Ory PA. Interpreting radiographic data in rheumatoid arthritis. Ann Rheum Dis. Jul. 2003;62(7):597-604. [pmid: 12810418].
275 Ostergaard M, Baslund B, Rigby W. Ofatumumab, a human CD20 monoclonal antibody, in the treatment of rheumatoid arthritis: Early results from an ongoing, double-blind, randomized, placebo-controlled clinical trial [abstract]. American College of Rheumatology Annual Meeting. 2007.
276 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
277 Ozminkowski RJ, Burton WN, Goetzel RZ, et al. The impact of rheumatoid arthritis on medical expenditures, absenteeism, and short-term disability benefits. J Occup Environ Med. Feb. 2006;48(2):135-48. [pmid: 16474262].
278 Pallavicini FB, Caporali R, Sarzi-Puttini P, et al. Tumour necrosis factor antagonist therapy and cancer development: analysis of the LORHEN registry. Autoimmun Rev. 2010;9(3):175-80. [pmid: 19647103].
279 Papp KA, Caro I, Leung HM, et al. Efalizumab for the treatment of psoriatic arthritis. J Cutan Med Surg. Mar–Apr. 2007;11(2):57-66. [pmid: 17374316].
280 Pieringer H, Stuby U, Biesenbach G. Patients with Rheumatoid Arthritis Undergoing Surgery: How Should We Deal with Antirheumatic Treatment?. Seminars in Arthritis and Rheumatism. 2007;36(5):278-86. [pmid: 17204310].
281 Pincus T, Marcum SB, Callahan LF. Longterm drug therapy for rheumatoid arthritis in seven rheumatology private practices: II. Second line drugs and prednisone. J Rheumatol. Dec. 1992;19(12):1885-94. [pmid: 1294735].
282 Pincus T, O'Dell JR, Kremer JM. Combination therapy with multiple disease-modifying antirheumatic drugs in rheumatoid arthritis: a preventive strategy. Ann Intern Med. Nov. 16. 1999;131(10):768-74. [pmid: 10577301].
283 Pincus T, Yazici Y, Bergman M. A practical guide to scoring a Multi-Dimensional Health Assessment Questionnaire (MDHAQ) and Routine Assessment of Patient Index Data (RAPID) scores in 10–20 seconds for use in standard clinical care, without rulers, calculators, websites or computers. Best Practice and Research: Clinical Rheumatology. 2007;21(4):755-87. [pmid: 17678834].
284 Pinzani M, Vizzutti F, Arena U, et al. Technology Insight: Noninvasive assessment of liver fibrosis by biochemical scores and elastography. Nature Clinical Practice Gastroenterology and Hepatology. 2008;5(2):95-106.
285 Popovic M, Stefanovic D, Pejnovic N, et al. Comparative study of the clinical efficacy of four DMARDs (leflunomide, methotrexate, cyclosporine, and levamisole) in patients with rheumatoid arthritis. Transplant Proc. Dec. 1998;30(8):4135-6. [pmid: 9865325].
286 Pouchot J. How can we improve the management of adult-onset Still's disease?. Joint Bone Spine. Mar. 2007;74(2):117-9. [pmid: 17321778].
287 Prevoo ML, van Gestel AM, van THMA, et al. Remission in a prospective study of patients with rheumatoid arthritis. American Rheumatism Association preliminary remission criteria in relation to the disease activity score. Br J Rheumatol. Nov. 1996;35(11):1101-5. [pmid: 8948296].
288 Pugner KM, Scott DI, Holmes JW, et al. The costs of rheumatoid arthritis: an international long-term view. Semin Arthritis Rheum. Apr. 2000;29(5):305-20. [pmid: 10805355].
289 Quinn MA, Conaghan PG, O'Connor PJ. Very early treatment with infliximab in addition to methotrexate in early, poor-prognosis rheumatoid arthritis reduces magnetic resonance imaging evidence of synovitis and damage, with sustained benefit after infliximab withdrawal: Results from a twelve-month ran-liver disease?. Hepatology. 2006;43:352-61. [pmid: 16440362].
290 Ramey DR, Fries JF, Singh G. The Health Assessment Questionnaire 1995 -- Status and Review. Spilker B, editor. Quality of Life and Pharmacoleconomics in Clinical Trials. 2nd ed. Philadelphia. Lippincott-Raven Publischers. 1996:227-37.
291 Ranganath VK, Furst DE. Disease-modifying antirheumatic drug use in the elderly rheumatoid arthritis patient. Rheum Dis Clin North Am. Feb. 2007;33(1):197-217. [pmid: 17367700].
292 Ravindran V, Scott DL, Choy EH. A systematic review and meta-analysis of efficacy and toxicity of disease modifying anti-rheumatic drugs and biological agents for psoriatic arthritis. Annals of the rheumatic diseases. 2008;67(6):855-9. [pmid: 17827183].
293 Reddy SM, Bingham Iii CO. Outcome measures in psoriatic arthritis clinical trials. Curr Rheumatol Rep. 2005;7(4):299-305. [pmid: 16045833].
294 Reich K, Nestle FO, Papp K, et al. Improvement in quality of life with infliximab induction and maintenance therapy in patients with moderate-to-severe psoriasis: a randomized controlled trial. Br J Dermatol. Jun. 2006;154(6):1161-8. [pmid: 16704649].
295 Rioda WT, Adorni G. Infliximab treatment in psoriatic arthritis: our experience. Acta Biomed. Aug. 2006;77(2):95-102. [pmid: 17172189].
296 Ritchie DA, Boyle JA, McInnes JM, et al. Evaluation of a simple articular index for joint tenderness in rheumatoid arthritis. Ann Rheum Dis. Mar. 1969;28(2):196. [pmid: 4887770].
297 Ritchie DM, Boyle JA, McInnes JM, et al. Clinical studies with an articular index for the assessment of joint tenderness in patients with rheumatoid arthritis. Q J Med. Jul. 1968;37(147):393-406. [pmid: 4877784].
298 Ritchlin CT, Kavanaugh A, Gladman DD, et al. Treatment recommendations for psoriatic arthritis. Ann Rheum Dis. Sep. 2009;68(9):1387-94. [pmid: 18952643].
299 Roux CH, Brocq O, Breuil V, et al. Pregnancy in rheumatology patients exposed to anti-tumour necrosis factor (TNF)-Î± therapy. Rheumatology. 2007;46(4):695-8. [pmid: 17158212].
300 Ruderman EM, Markenson J. Granulomatous infections and tumor necrosis factor antagonists therapy: update through June 2002. Arthritis Rheum. 2003;48(9):S241.
301 Saad AA, Ashcroft DM, Watson KD, et al. Persistence with anti-tumour necrosis factor therapies in patients with psoriatic arthritis: observational study from the British Society of Rheumatology Biologics Register. Arthritis Res Ther. 2009;11(2):R52. [pmid: 19356232].
302 Saag KG, Gim GT, Patkar NM, et al. American College of Rheumatology 2008 recommendations for the use of nonbiologic and biologic disease-modifying antirheumatic drugs in rheumatoid arthritis. Arthritis Care and Research. 2008;59(6):762-84. [pmid: 18512708].
303 Salliot C, Gossec L, Ruyssen-Witrand A, et al. Infections during tumour necrosis factor-{alpha} blocker therapy for rheumatic diseases in daily practice: a systematic retrospective study of 709 patients. Rheumatology. 2006. July. 31. 2006:kel236.
304 Salliot C, Gossec L, Ruyssen-Witrand A, et al. Infections during tumour necrosis factor-Î± blocker therapy for rheumatic diseases in daily practice: A systematic retrospective study of 709 patients. Rheumatology. 2007;46(2):327-34. [pmid: 16880188].
305 Samsa G, Edelman D, Rothman ML, et al. Determining clinically important differences in health status measures: a general approach with illustration to the Health Utilities Index Mark II. Pharmacoeconomics. 1999;15(2):141-55. [pmid: 10351188].
306 Sauriol L, Laporta M, Edwardes MD, et al. Meta-analysis comparing newer antipsychotic drugs for the treatment of schizophrenia: evaluating the indirect approach. Clin Ther. Jun. 2001;23(6):942-56. [pmid: 11440294].
307 Sbeity ZH, Baydoun L, Schmidt S, et al. Visual field changes in methotrexate therapy. Case report and review of the literature. J Med Liban. Jul–Sep. 2006;54(3):164-7. [pmid: 17190135].
308 Schaible TF. Long term safety of infliximab. Can J Gastroenterol. Sep. 2000;14(Suppl C):29C-32C.
309 Schardt C, Adams MB, Owens T, et al. Utilization of the PICO framework to improve searching PubMed for clinical questions. BMC Medical Informatics and Decision Making. 2007;7.
310 Schiff MH, Burmester GR, Kent JD, et al. Safety analyses of adalimumab (HUMIRA) in global clinical trials and US postmarketing surveillance of patients with rheumatoid arthritis. Ann Rheum Dis. Jul. 2006;65(7):889-94. [pmid: 16439435].
311 Schuna AA. Rituximab for the treatment of rheumatoid arthritis. Pharmacotherapy. 2007;27(12 I):1702-10. [pmid: 18041890].
312 Scott DL, Coulton BL, Bacon PA, et al. Methods of X-ray assessment in rheumatoid arthritis: a re-evaluation. Br J Rheumatol. Feb. 1985;24(1):31-9. [pmid: 3978364].
313 Scott DL, Houssien DA, Laasonen L. Proposed modification to Larsen's scoring methods for hand and wrist radiographs. Br J Rheum. 1995;34:56.
314 Setoguchi S, Solomon DH, Weinblatt ME, et al. Tumor necrosis factor alpha antagonist use and cancer in patients with rheumatoid arthritis. Arthritis Rheum. Sep. 2006;54(9):2757-64. [pmid: 16947774].
315 Sharp JT, Young DY, Bluhm GB, et al. How many joints in the hands and wrists should be included in a score of radiologic abnormalities used to assess rheumatoid arthritis?. Arthritis Rheum. Dec. 1985;28(12):1326-35. [pmid: 4084327].
316 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: A measurement tool to assess the methodological quality of systematic reviews. BMC Medical Research Methodology. 2007;7.
317 Smolen JS, Aletaha D, Keystone E. Superior efficacy of combination therapy for rheumatoid arthritis: fact or fiction?. Arthritis Rheum. Oct. 2005;52(10):2975-83. [pmid: 16200577].
318 Smolen JS, Keystone EC, Emery P, et al. Consensus statement on the use of rituximab in patients with rheumatoid arthritis. Annals of the rheumatic diseases. 2007;66(2):143-50. [pmid: 17068064].
319 Smolen JS, Landewe R, Breedveld FC, et al. EULAR recommendations for the management of rheumatoid arthritis with synthetic and biological disease-modifying antirheumatic drugs. Ann Rheum Dis. 2010;69(6):964-75. [pmid: 20444750].
320 Sokka T, Pincus T. Most patients receiving routine care for rheumatoid arthritis in 2001 did not meet inclusion criteria for most recent clinical trials or american college of rheumatology criteria for remission. J Rheumatol. Jun. 2003;30(6):1138-46. [pmid: 12784382].
321 Sokoll KB, Helliwell PS. Comparison of disability and quality of life in rheumatoid and psoriatic arthritis. J Rheumatol. Aug. 2001;28(8):1842-6. [pmid: 11508587].
322 Solomon DH. The comparative safety and effectiveness of TNF-alpha antagonists [corrected]. J Manag Care Pharm. Jan. 2007;13(1 Suppl):S7-18. [pmid: 17378700].
323 Song F, Altman DG, Glenny AM, et al. Validity of indirect comparison for estimating efficacy of competing interventions: empirical evidence from published meta-analyses. Bmj. Mar. 1. 2003;326(7387):472. [pmid: 12609941].
324 Soriano ER, McHugh NJ. Therapies for peripheral joint disease in psoriatic arthritis. A systematic review. J Rheumatol. Jul. 2006;33(7):1422-30. [pmid: 16724372].
325 Stewart AL, Hays RD, Ware JE Jr. The MOS short-form general health survey. Reliability and validity in a patient population. Med Care. Jul. 1988;26(7):724-35. [pmid: 3393032].
326 Stewart AL, Ware JE. Measuring Functioning and Well-Being: The Medical Outcomes Study Approach. Durham, NC. Duke University Press. 1992.
327 Strand. Improved health-related quality of life with effective disease-modifying antirheumatic drugs: Evidence from randomized controlled trials (American Journal of Managed Care). American Journal of Managed Care. 2008;14(4):234.
328 Strand V, Balbir-Gurman A, Pavelka K, et al. Sustained benefit in rheumatoid arthritis following one course of rituximab: improvements in physical function over 2 years. Rheumatology (Oxford). 2006;45(12):1505-13. [pmid: 17062648].
329 Strand V, Tugwell P, Bombardier C, et al. Function and health-related quality of life: results from a randomized controlled trial of leflunomide versus methotrexate or placebo in patients with active rheumatoid arthritis. Leflunomide Rheumatoid Arthritis Investigators Group. Arthritis Rheum. Sep. 1999;42(9):1870-8. [pmid: 10513801].
330 Szekanecz Z, Koch AE. Macrophages and their products in rheumatoid arthritis. Current Opinion in Rheumatology. 2007;19(3):289-95. [pmid: 17414958].
331 Tak PP, Thurlings RM, Rossier C, et al. Atacicept in patients with rheumatoid arthritis: Results of a multicenter, phase Ib, double-blind, placebo-controlled, dose-escalating, single- and repeated-dose study. Arthritis and rheumatism. 2008;58(1):61-72. [pmid: 18163485].
332 Tanaka Y. Biologics: current therapeutic strategies for rheumatoid arthritis. Nippon rinsho Japanese journal of clinical medicine. 2007;65(7):1179-84.
333 Taylor W, Gladman D, Helliwell P, et al. Classification criteria for psoriatic arthritis: development of new criteria from a large international study. Arthritis Rheum. Aug. 2006;54(8):2665-73. [pmid: 16871531].
334 Tilg H, Kaser A, Moschen AR. How to modulate inflammatory cytokines in liver diseases. Liver International. 2006;26(9):1029-39. [pmid: 17032402].
335 Todd DJ, Costenbader KH, Weinblatt ME. Abatacept in the treatment of rheumatoid arthritis. International Journal of Clinical Practice. 2007;61(3):494-500. [pmid: 17313619].
336 Tracey D, Klareskog L, Sasso EH, et al. Tumor necrosis factor antagonist mechanisms of action: A comprehensive review. Pharmacology and Therapeutics. 2008;117(2):244-79. [pmid: 18155297].
337 Tugwell P, Wells G, Strand V, et al. Clinical improvement as reflected in measures of function and health-related quality of life following treatment with leflunomide compared with methotrexate in patients with rheumatoid arthritis: sensitivity and relative efficiency to detect a treatment effect in a twelve-month, placebo-controlled trial. Leflunomide Rheumatoid Arthritis Investigators Group. Arthritis Rheum. Mar. 2000;43(3):506-14. [pmid: 10728742].
338 Turesson C, Schaid DJ, Weyand CM, et al. The impact of HLA-DRB1 genes on extra-articular disease manifestations in rheumatoid arthritis. Arthritis Res Ther. 2005;7(6):R1386-93. [pmid: 16277691].
339 van der Heijde D. How to read radiographs according to the Sharp/van der Heijde method. J Rheumatol. Mar. 1999;26(3):743-5. [pmid: 10090194].
340 van der Heijde D. How to read radiographs according to the Sharp/van der Heijde method. J Rheumatol. Jan. 2000;27(1):261-3. [pmid: 10648051].
341 van der Heijde D, Da Silva JC, Dougados M, et al. Etanercept 50 mg once weekly is as effective as 25 mg twice weekly in patients with ankylosing spondylitis. Ann Rheum Dis. Dec. 2006;65(12):1572-7. [pmid: 16968715].
342 van der Heijde D, Dankert T, Nieman F, et al. Reliability and sensitivity to change of a simplification of the Sharp/van der Heijde radiological assessment in rheumatoid arthritis. Rheumatology (Oxford). Oct. 1999;38(10):941-7. [pmid: 10534543].
343 van der Heijde D, Kavanaugh A, Gladman DD, et al. Infliximab inhibits progression of radiographic damage in patients with active psoriatic arthritis through one year of treatment: Results from the induction and maintenance psoriatic arthritis clinical trial 2. Arthritis Rheum. 2007;56(8):2698-707. [pmid: 17665424].
344 van der Heijde D, Klareskog L, Landewe R, et al. Disease remission and sustained halting of radiographic progression with combination etanercept and methotrexate in patients with rheumatoid arthritis. Arthritis Rheum. 2007;56(12):3928-39. [pmid: 18050208].
345 van der Heijde DM. Overview of radiologic efficacy of new treatments. Rheum Dis Clin North Am. May. 2004;30(2):285-93. vi. [pmid: 15172041].
346 van der Heijde DM, van Leeuwen MA, van Riel PL, et al. Biannual radiographic assessments of hands and feet in a three-year prospective followup of patients with early rheumatoid arthritis. Arthritis Rheum. Jan. 1992;35(1):26-34. [pmid: 1731813].
347 van Dongen H, van Aken J, Lard LR, et al. Efficacy of methotrexate treatment in patients with probable rheumatoid arthritis: a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. May. 2007;56(5):1424-32. [pmid: 17469099].
348 van Gestel AM, Anderson JJ, van Riel PL, et al. ACR and EULAR improvement criteria have comparable validity in rheumatoid arthritis trials. American College of Rheumatology European League of Associations for Rheumatology. J Rheumatol. 1999;26(3):705-11. [pmid: 10090187].
349 van Gestel AM, Prevoo ML, van 't Hof MA, et al. Development and validation of the European League Against Rheumatism response criteria for rheumatoid arthritis. Comparison with the preliminary American College of Rheumatology and the World Health Organization/International League Against Rheumatism Criteria. Arthritis Rheum. 1996;39(1):34-40. [pmid: 8546736].
350 van Riel PL, Taggart AJ, Sany J, et al. Efficacy and safety of combination etanercept and methotrexate versus etanercept alone in patients with rheumatoid arthritis with an inadequate response to methotrexate: The ADORE study. Ann Rheum Dis. 2006. Feb. 7.
351 van Tuyl LH, Vlad SC, Felson DT, et al. Defining remission in rheumatoid arthritis: results of an initial American College of Rheumatology/European League Against Rheumatism consensus conference. Arthritis Rheum. 2009;61(5):704-10. [pmid: 19405006].
352 Verhoeven AC, Boers M, Tugwell P. Combination therapy in rheumatoid arthritis: updated systematic review. Br J Rheumatol. Jun. 1998;37(6):612-9. [pmid: 9667614].
353 Visser K, Katchamart W, Loza E, et al. Multinational evidence-based recommendations for the use of methotrexate in rheumatic disorders with a focus on rheumatoid arthritis: Integrating systematic literature research and expert opinion of a broad international panel of rheumatologists in the 3E Initiative. Annals of the rheumatic diseases. 2009;68(7):1086-93. [pmid: 19033291].
354 Visvanathan S, Keenan GF, Baker DG, et al. Response to pneumococcal vaccine in patients with early rheumatoid arthritis receiving infliximab plus methotrexate or methotrexate alone. J Rheumatol. May. 2007;34(5):952-7. [pmid: 17444589].
355 Visvanathan S, Marini JC, Smolen JS, et al. Changes in biomarkers of inflammation and bone turnover and associations with clinical efficacy following infliximab plus methotrexate therapy in patients with early rheumatoid arthritis. J Rheumatol. Jul. 2007;34(7):1465-74. [pmid: 17552048].
356 Wailoo A, Brennan A, Bansback N, et al. Modeling the cost effectiveness of etanercept, adalimumab and anakinra compared to infliximab in the treatment of patients with rheumatoid arthritis in the Medicare program. AHRQ Technology Assessment Program. 2006.
357 Wallis RS, Broder MS, Wong JY, et al. Granulomatous infectious diseases associated with tumor necrosis factor antagonists. Clin Infect Dis. May. 1. 2004;38(9):1261-5. [pmid: 15127338].
358 Walters SJ, Brazier JE. What is the relationship between the minimally important difference and health state utility values? The case of the SF-6D. Health Qual Life Outcomes. 2003;14.
359 Ware JE Jr, Kosinski M, Bayliss MS, et al. Comparison of methods for the scoring and statistical analysis of SF-36 health profile and summary measures: summary of results from the Medical Outcomes Study. Med Care. Apr. 1995;33(4 Suppl):AS264-79. [pmid: 7723455].
360 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
361 Ware JE, Snow KK, Kosinski M, et al. SF-36® Health Survey Manual and Interpretation Guide. 1993.
362 Weinblatt ME, Bathon JM, Kremer JM, et al. Safety and efficacy of etanercept beyond 10 years of therapy in North American patients with early and long-standing rheumatoid arthritis. Arthritis Care Res (Hoboken). 2010.
363 Weinblatt ME, Keystone EC, Furst DE, et al. Long term efficacy and safety of adalimumab plus methotrexate in patients with rheumatoid arthritis: ARMADA 4 year extended study. Ann Rheum Dis. Jun. 2006;65(6):753-9. [pmid: 16308341].
364 Weinblatt ME, Kremer JM, Coblyn JS, et al. Pharmacokinetics, safety, and efficacy of combination treatment with methotrexate and leflunomide in patients with active rheumatoid arthritis. Arthritis Rheum. Jul. 1999;42(7):1322-8. [pmid: 10403258].
365 Wells GA, Sultan SA, Chen L. Indirect evidence: Indirect treatment comparisons in meta-analysis. Ottawa (ON). Canadian Agency for Drugs and Technologies in Health. 2009.
366 Wells GA, Tugwell P, Kraag GR, et al. Minimum important difference between patients with rheumatoid arthritis: the patient's perspective. J Rheumatol. 1993;20(3):557-60. [pmid: 8478873].
367 Welton NJ, Caldwell DM, Adamopoulos E, et al. Mixed treatment comparison meta-analysis of complex interventions: psychological interventions in coronary heart disease. Am J Epidemiol. 2009;169(9):1158-65. [pmid: 19258485].
368 Westhovens R, Cole JC, Li T, et al. Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology (Oxford). Oct. 2006;45(10):1238-46. [pmid: 16567357].
369 Whitehead A. Meta-analysis of controlled clinical trials. Chichester, UK. John Wiley & Sons, Ltd. 2002.
370 Willkens RF, Williams HJ, Ward JR, et al. Randomized, double-blind, placebo controlled trial of low-dose pulse methotrexate in psoriatic arthritis. Arthritis Rheum. 1984;27(4):376-81. [pmid: 6712754].
371 Wood AJ. Thrombotic thrombocytopenic purpura and clopidogrel--a need for new approaches to drug safety. N Engl J Med. Jun. 15. 2000;342(24):1824-6. [pmid: 10853007].
372 Woolacott N, Bravo Vergel Y, Hawkins N, et al. Etanercept and infliximab for the treatment of psoriatic arthritis: a systematic review and economic evaluation. Health Technol Assess. Sep. 2006;10(31):1-258. [pmid: 17083854].
373 Yamamoto M, Takahashi H, Ohara M, et al. A new conceptualization for Mikulicz's disease as an IgG4-related plasmacytic disease. Mod Rheumatol. 2006;16(6):335-40. [pmid: 17164992].
374 Yamanaka H, Inoue E, Tanaka E, et al. Influence of methotrexate dose on its efficacy and safety in rheumatoid arthritis patients: Evidence based on the variety of prescribing approaches among practicing Japanese rheumatologists in a single institute-based large observational cohort (IORRA). Modern Rheumatology. 2007;17(2):98-105. [pmid: 17437163].
375 Yelin E. Work disability in rheumatic diseases. Current Opinion in Rheumatology. 2007;19(2):91-6. [pmid: 17278920].
376 Young MS, Furfaro N. The rheumatology/dermatology collaboration. Dermatol Nurs. Oct. 2006;(Suppl):10-22. [pmid: 17444251].
377 Zachariae H, Zachariae R, Blomqvist K, et al. Quality of life and prevalence of arthritis reported by 5,795 members of the Nordic Psoriasis Associations. Data from the Nordic Quality of Life Study. Acta Derm Venereol. 2002;82(2):108-13. [pmid: 12125937].
378 Zhao LK, Liao ZT, Li CH, et al. Evaluation of quality of life using ASQoL questionnaire in patients with ankylosing spondylitis in a Chinese population. Rheumatol Int. May. 2007;27(7):605-11. [pmid: 17103172].
379 Zink A, Strangfeld A, Schneider M, et al. Effectiveness of tumor necrosis factor inhibitors in rheumatoid arthritis in an observational cohort study: comparison of patients according to their eligibility for major randomized clinical trials. Arthritis Rheum. Nov. 2006;54(11):3399-407. [pmid: 17075823].

## Reference Source: Embase

1 Abrahamian H, Endler G, Exner M, et al. Association of low-grade inflammation with nephropathy in type 2 diabetic patients: role of elevated CRP-levels and 2 different gene-polymorphisms of proinflammatory cytokines. Experimental and clinical endocrinology & diabetes : official journal, German Society of Endocrinology [and] German Diabetes Association. 2007;(1):38-41.
2 Abrahamyan L, Beyene J, Feng J, et al. Response times follow lognormal or gamma distribution in arthritis patients. Journal of Clinical Epidemiology. 2010;63(12):1363-9. [pmid: 20430577].
3 Accardo S, Seriolo B, Samanta E, et al. Controlled-Release Naproxen in Rheumatoid Arthritis. CURR THER RES CLIN EXP. 1991;49I(6):936-42.
4 Adams J, Burridge J, Mullee M, et al. The clinical effectiveness of static resting splints in early rheumatoid arthritis: A randomized controlled trial. Rheumatology. 2008;47(10):1548-53. [pmid: 18701540].
5 Agnew-Blais JC, Coblyn JS, Katz JN, et al. Measuring quality of care for rheumatic diseases using an electronic medical record. Annals of the Rheumatic Diseases. 2009;68(5):680-4. [pmid: 18511547].
6 Aguilar-Chavez EA, Gamez-Nava JI, Lopez-Olivo MA, et al. Circulating leptin and bone mineral density in rheumatoid arthritis. Journal of Rheumatology. 2009;36(3):512-6. [pmid: 19208597].
7 Ahern MJ, Wetherall M, Leslie A, et al. A Comparison of Ketoprofen Sr and Sulindac in the Elderly With Rheumatoid Arthritis. Br J Clin Pract. 1992;46(4):229-33. [pmid: 1290729].
8 Alarcon G, Castaneda O, Nair M, et al. Controlled Trial of Methotrexate Versus 10-Deazaaminopterin in the Treatment of Rheumatoid Arthritis. Ann Rheum Dis. 1992;51(5):600-3. [pmid: 1616322].
9 Alarcon GS, Castaneda O, Ferrandiz M, et al. Efficacy and Safety of 10-Deazaaminopterin in the Treatment of Rheumatoid Arthritis. A One-Year Continuation, Double-Blind Study. Arthritis Rheum. 1992;35(11):1318-21. [pmid: 1445448].
10 Alarcon I, Moreland G, Jaffe L, et al. The Use of Methotrexate Perioperatively in Patients With Rheumatoid Arthritis Undergoing Major Joint Replacement Surgery: Will We Ever Have Consensus About Its Use?. J Clin Rheumatol. 1996;2(1):6-8. [pmid: 19078020].
11 Albert DA, Huang G, Dubrow G, et al. Criteria for Improvement in Rheumatoid Arthritis: Alternatives to the American College of Rheumatology 20. J Rheumatol. 2004;31(5):856-66. [pmid: 15124243].
12 Aletaha D, Smolen J, Ward MM. Measuring function in rheumatoid arthritis: Identifying reversible and irreversible components. Arthritis and Rheumatism. 2006;54(9):2784-92. [pmid: 16947781].
13 Ali ML, Alam MN, Haq SA, et al. Efficacy of Methotrexate in Rheumatoid Arthritis. Bangladesh Medical Research Council bulletin. 1997;23(3):72-6. [pmid: 9621475].
14 Allen ZA, Shanahan EM, Crotty M. Does suprascapular nerve block reduce shoulder pain following stroke: A double-blind randomised controlled trial with masked outcome assessment. BMC Neurology. 2010;10.
15 Almarzouqi M, Scarsbrook D, Klinkhoff A. Gold therapy in women planning pregnancy: Outcomes in one center. Journal of Rheumatology. 2007;34(9):1827-31. [pmid: 17696276].
16 Alten R, Doring G, Cutolo M, et al. Hypothalamus-pituitary-adrenal axis function in patients with rheumatoid arthritis treated with nighttime-release prednisone. Journal of Rheumatology. 2010;37(10):2025-31. [pmid: 20682671].
17 Alten R, Gromnica-Ihle E, Pohl C, et al. Inhibition of Leukotriene B4-Induced Cd11b/Cd18 (Mac-1) Expression by Biil 284, a New Long Acting Ltb4 Receptor Antagonist, in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2004;63(2):170-6. [pmid: 14722206].
18 Alten RE, Zerbini C, Jeka S, et al. Efficacy and safety of pamapimod in patients with active rheumatoid arthritis receiving stable methotrexate therapy. 2010.
19 Anaya JM, Fabre D, Bressolle F, et al. Effect of Etodolac on Methotrexate Pharmacokinetics in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1994;21(2):293-8. [pmid: 8182639].
20 Anders HJ, Rihl M, Loch O, et al. Prediction of Creatinine Clearance From Serum Creatinine in Patients With Rheumatoid Arthritis: Comparison of Six Formulae and One Nomogram. Clinical rheumatology. 2000;19(1):26-9. [pmid: 10752495].
21 Andersen LS, Hansen EL, Knudsen JB, et al. Prospectively Measured Red Cell Folate Levels in Methotrexate Treated Patients With Rheumatoid Arthritis: Relation to Withdrawal and Side Effects. The Journal of rheumatology. 1997;24(5):830-7. [pmid: 9150068].
22 Anderson JJ, O'Neill A, Woodworth T, et al. Health Status Response of Rheumatoid Arthritis to Treatment With Dab486il-2. Arthritis care and research : the official journal of the Arthritis Health Professions Association. 1996;9(2):112-9. [pmid: 8970269].
23 Anderson KO, Bradley LA, Turner RA, et al. Pain Behavior of Rheumatoid Arthritis Patients Enrolled in Experimental Drug Trials. Arthritis care and research : the official journal of the Arthritis Health Professions Association. 1994;7(2):64-8. [pmid: 7857995].
24 Andrianakos A, Trontzas P, Christoyannis F, et al. Prevalence and management of rheumatoid arthritis in the general population of Greece - The ESORDIG study. Rheumatology. 2006;45(12):1549-54. [pmid: 16690763].
25 Antoni C, Kalden J. Combination Therapy of the Chimeric Monoclonal Anti-Tumor Necrosis Factor Alpha Antibody (Infliximab) With Methotrexate in Patients With Rheumatoid Arthritis. Clinical and experimental rheumatology. 1999;17(6 Suppl 18):S73-7. [pmid: 10589362].
26 Appel H, Mertz A, Distler A, et al. The 19 Kda Protein of Yersinia Enterocolitica O:3 Is Recognized on the Cellular and Humoral Level by Patients With Yersinia Induced Reactive Arthritis. J Rheumatol. 1999;26(9):1964-71. [pmid: 10493678].
27 April P, Abeles M, Baraf H, et al. Does the Acetyl Group of Aspirin Contribute to the Antiinflammatory Efficacy of Salicylic Acid in the Treatment of Rheumatoid Arthritis?. Seminars in arthritis and rheumatism. 1990;19(4 Suppl 2):20-8. [pmid: 2181674].
28 Arborelius MJ, Konttinen YT, Nordstrom DC, et al. Gly-X-Y Repeat Sequences in the Treatment of Active Rheumatoid Arthritis. Rheumatology international. 1999;18(4):129-35. [pmid: 10220832].
29 Arendt-Nielsen L, Drewes AM, Svendsen L, et al. Quantitative Assessment of Joint Pain Following Treatment of Rheumatoid Arthritis With Ibuprofen Cream. Scandinavian journal of rheumatology. 1994;23(6):334-7. [pmid: 7801058].
30 Arnold MH, O'Callaghan J, McCredie M, et al. Comparative Controlled Trial of Low-Dose Weekly Methotrexate Versus Azathioprine in Rheumatoid Arthritis: 3-Year Prospective Study. British journal of rheumatology. 1990;29(2):120-5. [pmid: 2182169].
31 Arvidson NG, Gudbjornsson B, Larsson A, et al. The Timing of Glucocorticoid Administration in Rheumatoid Arthritis. Annals of the rheumatic diseases. 1997;56(1):27-31. [pmid: 9059137].
32 Aryaeian N, Shahram F, Djalali M, et al. Effect of conjugated linoleic acids, vitamin E and their combination on the clinical outcome of Iranian adults with active rheumatoid arthritis. International Journal of Rheumatic Diseases. 2009;12(1):20-8. [pmid: 20374312].
33 Asahina A, Nakagawa H, Etoh T, et al. Adalimumab in Japanese patients with moderate to severe chronic plaque psoriasis: Efficacy and safety results from a Phase II/III randomized controlled study. Journal of Dermatology. 2010;37(4):299-310. [pmid: 20507398].
34 Assous N, Gossec L, Dougados M, et al. Efficacy of rituximab in patients with rheumatoid arthritis refractory or with contra-indication to anti-tumor necrosis factor-alpha drugs in daily practice: An open label observational study [3]. Clinical and Experimental Rheumatology. 2007;25(3).
35 Astrauskiene D. Efficacy of Empirically Prescribed Amoxicillin and Amoxicillin + Clavulanic Acid in Children's Reactive Arthritis: a Randomised Trial. Clinical and experimental rheumatology. 2003;21(4):515-21. [pmid: 12942708].
36 Atkinson M, Khanna V, Menard H, et al. A Comparison of Tenoxicam and Piroxicam in the Treatment of Rheumatoid Arthritis. The Journal of rheumatology. 1992;19(4):538-42. [pmid: 1593574].
37 Atkinson MH, Buchanan WW, Fitzgerald AA, et al. A Comparison of Flurbiprofen and Naproxen in the Treatment of Rheumatoid Arthritis: a Canadian Multi-Centre Study. Current medical research and opinion. 1990;12(2):76-85. [pmid: 2202552].
38 Azuma T, Oishi M, Takei M, et al. Tacrolimus-related nocturnal myoclonus of the lower limbs in elderly patients with rheumatoid arthritis. Modern Rheumatology. 2007;17(3):247-50. [pmid: 17564783].
39 Bacon P, Luqmani RA, Bossingham DH, et al. A Comparison of Two Formulations of Indomethacin ('flexin Continus' Tablets and 'indocid' Capsules) in the Treatment of Rheumatoid Arthritis. Current medical research and opinion. 1990;12(2):128-34. [pmid: 2202550].
40 Baerwald C, Goebel KM, Krause A, et al. A randomized controlled trial of ciamexon versus placebo in the immunomodulatory treatment of rheumatoid arthritis. Arthritis Rheum. May. 1990;33(5):733-8. [pmid: 2189417].
41 Bagge E, Geijer M, Tarkowski A. Intra-Articular Administration of Polyclonal Immunoglobulin G in Rheumatoid Arthritis. A Double-Blind, Placebo-Controlled Pilot Study. Scandinavian journal of rheumatology. 1996;25(3):174-6. [pmid: 8668962].
42 Bahadori B, Uitz E, Thonhofer R, et al. (omega)-3 fatty acids infusions as adjuvant therapy in rheumatoid arthritis. Journal of Parenteral and Enteral Nutrition. 2010;34(2):151-5. [pmid: 20375422].
43 Bakker MF, Jacobs JWG, Welsing PMJ, et al. Are switches from oral to subcutaneous methotrexate or addition of ciclosporin to methotrexate useful steps in a tight control treatment strategy for rheumatoid arthritis? A post hoc analysis of the CAMERA study. Annals of the rheumatic diseases. 2010;69(10):1849-52. [pmid: 20511610].
44 Barnett ML, Kremer JM, St Clair EW, et al. Treatment of Rheumatoid Arthritis With Oral Type Ii Collagen. Results of a Multicenter, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 1998;41(2):290-7. [pmid: 9485087].
45 Barrera P, Boerbooms AM, Demacker PN, et al. Circulating Soluble Tumor Necrosis Factor Receptors, Interleukin-2 Receptors, Tumor Necrosis Factor Alpha, and Interleukin-6 Levels in Rheumatoid Arthritis. Longitudinal Evaluation During Methotrexate and Azathioprine Therapy. Arthritis and rheumatism. 1994;33(11):1017-24.
46 Barrera P, Haagsma C, Boerbooms A, et al. Effect of Methotrexate Alone or in Combination With Sulphasalazine on the Production and Circulating Concentrations of Cytokines and Their Antagonists. Longitudinal Evaluation in Patients With Rheumatoid Arthritis. British journal of rheumatology. 1995;34(8):747-55. [pmid: 7551660].
47 Barrera P, Joosten LA, den Broeder AA, et al. Effects of Treatment With a Fully Human Anti-Tumour Necrosis Factor Alpha Monoclonal Antibody on the Local and Systemic Homeostasis of Interleukin 1 and Tnfalpha in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2001;60(7):660-9. [pmid: 11406520].
48 Barrera P, van der Maas A, van Ede AE, et al. Drug Survival, Efficacy and Toxicity of Monotherapy With a Fully Human Anti-Tumour Necrosis Factor-a Antibody Compared With Methotrexate in Long-Standing Rheumatoid Arthritis. Rheumatology. 2002;41(4):430-9. [pmid: 11961174].
49 Baslund B, Tvede N, Danneskiold-Samsoe B, et al. Targeting Interleukin-15 in Patients With Rheumatoid Arthritis: a Proof-of-Concept Study. Arthritis and rheumatism. 2005;52(9):2686-92. [pmid: 16142748].
50 Bateman J, Penfold R, Rigby SP. Comment on: Kidney disease in RA patients: Prevalence and implication on RA-related drugs management: The MATRIX study. Rheumatology. 2008;47(8).
51 Battistone MJ, Manaster BJ, Reda DJ, et al. The Prevalence of Sacroilitis in Psoriatic Arthritis: New Perspectives From a Large, Multicenter Cohort. A Department of Veterans Affairs Cooperative Study. Skeletal radiology. 1999;28(4):196-201. [pmid: 10384989].
52 Bazzani C, Filippini M, Caporali R, et al. Anti-TNFalpha therapy in a cohort of rheumatoid arthritis patients: Clinical outcomes. Autoimmunity Reviews. 2009;8(3):260-5. [pmid: 19027090].
53 Beard AJ, Sleath B, Blalock SJ, et al. Predictors of rheumatoid arthritis patient-physician communication about medication costs during visits to rheumatologists. Arthritis Care and Research. 2010;62(5):632-9. [pmid: 20191466].
54 Bejarano V, Conaghan PG, Proudman SM, et al. Long-term efficacy and toxicity of ciclosporin A in combination with methotrexate in poor prognosis rheumatoid arthritis. Annals of the Rheumatic Diseases. 2009;68(5):761-3. [pmid: 19366897].
55 Bejarano V, Conaghan PG, Quinn MA, et al. Benefits 8 years after a remission induction regime with an infliximab and methotrexate combination in early rheumatoid arthritis. Rheumatology. 2010;49(10):1971-4. [pmid: 20595536].
56 Benenson E, Timina O. Prospidine Versus Methotrexate Pulse in Highly Active Rheumatoid Arthritis: a Controlled 6-Month Clinical Trial. Clinical rheumatology. 1994;13(1):54-9. [pmid: 8187445].
57 Bengtsson A, Bengtsson M, Nilsson I, et al. Effects of Intravenous Regional Administration of Methylprednisolone Plus Mepivacaine in Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1998;27(4):277-80. [pmid: 9751468].
58 Benitha R, Tikly M. Functional disability and health-related quality of life in South Africans with rheumatoid arthritis and systemic lupus erythematosus. Clinical Rheumatology. 2007;26(1):24-9. [pmid: 16538390].
59 Bensen W, Weaver A, Espinoza L, et al. Efficacy and Safety of Valdecoxib in Treating the Signs and Symptoms of Rheumatoid Arthritis: a Randomized, Controlled Comparison With Placebo and Naproxen. Rheumatology (Oxford). 2002;41(9):1008-16. [pmid: 12209034].
60 Berliner MN, Giesecke T, Bornhovd KD. Impact of transdermal fentanyl on quality of life in rheumatoid arthritis. Clinical Journal of Pain. 2007;23(6):530-4. [pmid: 17575494].
61 Bianchi L, Giunta A, Papoutsaki M, et al. Efficacy and safety of long-term infliximab therapy in moderate to severe psoriasis and psoriatic arthritis. Giornale Italiano di Dermatologia e Venereologia. 2006;141(1):73-8.
62 Bianchi Porro G, Montrone F, Lazzaroni M, et al. Clinical and Gastroscopic Evaluation of Amtolmetin Guacyl Versus Diclofenac in Patients With Rheumatoid Arthritis. Ital J Gastroenterol Hepatol. 1999;31(5):378-85. [pmid: 10470596].
63 Bingham ICO, Looney RJ, Deodhar A, et al. Immunization responses in rheumatoid arthritis patients treated with rituximab: Results from a controlled clinical trial. 2010.
64 Bird H, Broggini M. Paroxetine Versus Amitriptyline for Treatment of Depression Associated With Rheumatoid Arthritis: a Randomized, Double Blind, Parallel Group Study. The Journal of rheumatology. 2000;27(12):2791-7. [pmid: 11128665].
65 Blackburn WDJ, Prupas HM, Silverfield JC, et al. Tenidap in Rheumatoid Arthritis. A 24-Week Double-Blind Comparison With Hydroxychloroquine-Plus-Piroxicam, and Piroxicam Alone. Arthritis and rheumatism. 1995;38(10):1447-56. [pmid: 7575694].
66 Bluhm GB, Sharp JT, Tilley BC, et al. Radiographic Results From the Minocycline in Rheumatoid Arthritis (Mira) Trial. The Journal of rheumatology. 1997;24(7):1295-302. [pmid: 9228128].
67 Bombardier C, Laine L, Reicin A, et al. Comparison of upper gastrointestinal toxicity of rofecoxib and naproxen in patients with rheumatoid arthritis. VIGOR Study Group. N Engl J Med. 2000;343(21):1520-8. [pmid: 11087881].
68 Bombardier C, Peloso P, Goldsmith C. Salsalate, a Nonacetylated Salicylate, Is as Efficacious as Diclofenac in Patients With Rheumatoid Arthritis. Salsalate-Diclofenac Study Group. The Journal of rheumatology. 1995;22(4):617-24. [pmid: 7791151].
69 Bonilla E, Lee YY, Phillips PE, et al. Hypoglycaemia after initiation of treatment with etanercept in a patient with type 2 diabetes mellitus [5]. Annals of the Rheumatic Diseases. 2007;66(12).
70 Borg AA, Davis MJ, Fowler PD, et al. Rifampicin in Early Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1993;22(2):39-42. [pmid: 8434246].
71 Borg G, Allander E, Berg E, et al. Auranofin Treatment in Early Rheumatoid Arthritis May Postpone Early Retirement. Results From a 2-Year Double Blind Trial. The Journal of rheumatology. 1991;18(7):1015-20. [pmid: 1920306].
72 Borrs-Blasco J, Gracia-Prez A, Rosique-Robles JD, et al. Acceptability of switching adalimumab from a prefilled syringe to an autoinjection pen. Expert Opinion on Biological Therapy. 2010;10(3):301-7. [pmid: 20059372].
73 Bos WH, Dijkmans BAC, Boers M, et al. Effect of dexamethasone on autoantibody levels and arthritis development in patients with arthralgia: A randomised trial. Annals of the rheumatic diseases. 2010;69(3):571-4. [pmid: 19363022].
74 Bourikas LA, Sidiropoulos PI, Goulielmos GN, et al. Concomitant onset of Graves disease and rheumatoid arthritis after a serious life event [5]. Journal of Clinical Rheumatology. 2006;12(6):326-7. [pmid: 17149073].
75 Bradley JD, Dmitrienko AA, Kivitz AJ, et al. A Randomized, Double-Blinded, Placebo-Controlled Clinical Trial of Ly333013, a Selective Inhibitor of Group Ii Secretory Phospholipase A2, in the Treatment of Rheumatoid Arthritis. The Journal of rheumatology. 2005;32(3):417-23. [pmid: 15742431].
76 Breedveld FC, Han C, Bala M, et al. Association Between Baseline Radiographic Damage and Improvement in Physical Function After Treatment of Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2005;64(1):52-5. [pmid: 15286005].
77 Bressolle F, Kinowski J, Morel J, et al. Folic Acid Alters Methotrexate Availability in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 2000;27(9):2110-4. [pmid: 10990220].
78 Bridges SL Jr, Causey ZL, Burgos PI, et al. Radiographic severity of rheumatoid arthritis in African Americans: Results from a multicenter observational study. Arthritis Care and Research. 2010;62(5):624-31. [pmid: 20461784].
79 Brooks PJ, Spruill WJ, Parish RC, et al. Pharmacokinetics of Methotrexate Administered by Intramuscular and Subcutaneous Injections in Patients With Rheumatoid Arthritis. Arthritis & Rheumatism. 1990;33(1):91-4. [pmid: 2302272].
80 Buchanan WW, Kean WF, St-Jean J, et al. Clinical Evaluation of a Sustained Release Compared to a Standard Formulation of Tiaprofenic Acid (Surgam (R)) in Rheumatoid Arthritis: a Canadian Multicenter Study. J RHEUMATOL. 1991;18(7):1046-54. [pmid: 1717688].
81 Buckley L, Vacek P, Cooper S. Administration of Folinic Acid After Low Dose Methotrexate in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1990;17(9):1158-61. [pmid: 2132565].
82 Cacace E, Anedda C, Ruggiero V, et al. Etanercept in rheumatoid arthritis: Long term anti-inflammatory efficacy in clinical practice. European Journal of Inflammation. 2006;4(3):171-6.
83 Caldwell J. Comparison of the Efficacy, Safety, and Pharmacokinetic Profiles of Extended-Release Ketoprofen and Piroxicam in Patients With Rheumatoid Arthritis. Clinical therapeutics. 1994;16(2):222-35. [pmid: 8062318].
84 Calguneri M, Pay S, Caliskaner Z, et al. Combination Therapy Versus Monotherapy for the Treatment of Patients With Rheumatoid Arthritis. Clinical and experimental rheumatology. 1999;17(6):699-704. [pmid: 10609068].
85 Camp NJ, Cox A, di Giovine FS, et al. Evidence of a Pharmacogenomic Response to Interleukin-L Receptor Antagonist in Rheumatoid Arthritis. Genes Immun. 2005;6(6):467-71. [pmid: 15931231].
86 Cannon GW, Reading JC, Ward JR, et al. Clinical and Laboratory Outcomes During the Treatment of Rheumatoid Arthritis With Methotrexate. Scandinavian journal of rheumatology. 1990;19(4):285-94. [pmid: 2205907].
87 Cantatore F, Acquista C, Pipitone V. Evaluation of Bone Turnover and Osteoclastic Cytokines in Early Rheumatoid Arthritis Treated With Alendronate. The Journal of rheumatology. 1999;41(3):247-51.
88 Capell H, Maiden N, Madhok R, et al. Intention-to-Treat Analysis of 200 Patients With Rheumatoid Arthritis 12 Years After Random Allocation to Either Sulfasalazine or Penicillamine. The Journal of rheumatology. 1998;25(10):1880-6. [pmid: 9779839].
89 Capell H, Marabani M, Madhok R, et al. Degree and Extent of Response to Sulphasalazine or Penicillamine Therapy for Rheumatoid Arthritis: Results From a Routine Clinical Environment Over a Two-Year Period. The Quarterly journal of medicine. 1990;75(276):335-44. [pmid: 1974723].
90 Caperton E, Heim Duthoy K, Matzke G, et al. Ceftriaxone Therapy of Chronic Inflammatory Arthritis. A Double-Blind Placebo Controlled Trial. Archives of internal medicine. 1990;150(8):1677-82. [pmid: 2383162].
91 Carmichael S, Beal J, Day R, et al. Combination Therapy With Methotrexate and Hydroxychloroquine for Rheumatoid Arthritis Increases Exposure to Methotrexate. The Journal of rheumatology. 2002;29(10):2077-83. [pmid: 12375315].
92 Carpenter M, West S, Vogelgesang S, et al. Postoperative joint infections in rheumatoid arthritis patients on methotrexate therapy. Orthopedics. 1996;19(3):207-10. [pmid: 8867548].
93 Carpentier N, Bertin P, Marquet P, et al. Is There an Optimal Time to Administer Methotrexate in the Treatment of Rheumatoid Arthritis?. The Journal of rheumatology. 1998;25(7):1270-5. [pmid: 9676755].
94 Cavazzana I, Franceschini F, Quinzanini M, et al. Anti-Ro/SSA antibodies in rheumatoid arthritis: Clinical and immunologic associations. Clinical and Experimental Rheumatology. 2006;24(1):59-64. [pmid: 16539820].
95 Cazzola M, Antivalle M, Sarzi Puttini P, et al. Oral Type Ii Collagen in the Treatment of Rheumatoid Arthritis. A Six-Month Double Blind Placebo-Controlled Study. Clinical and experimental rheumatology. 2000;18(5):571-7. [pmid: 11072596].
96 Chan FKL, Hung LCT, Suen BY, et al. Celecoxib versus diclofenac plus omeprazole in high-risk arthritis patients: results of a randomized double-blind trial. Gastroenterology. 2004;127(4):1038-43. [pmid: 15480981].
97 Chan G, Goh F, Hodgson T, et al. Outpatient follow-up for patients with rheumatoid arthritis in relation to New Zealand Rheumatology Association guidelines at Dunedin Hospital. New Zealand Medical Journal. 2008;121(1274):34-41. [pmid: 18535644].
98 Chandrashekara S, Syed M, Swapna R. Is three selected parameters adequate to monitor rheumatoid arthritis?. Clinical Rheumatology. 2007;26(6):911-4. [pmid: 17028793].
99 Chard M, Crisp A. Astemizole, an H1 Antagonist, Has No Additional Therapeutic Effect in Rheumatoid Arthritis. The Journal of rheumatology. 1991;18(2):203-4. [pmid: 1673723].
100 Charles P, Elliott MJ, Davis D, et al. Regulation of Cytokines, Cytokine Inhibitors, and Acute-Phase Proteins Following Anti-Tnf-Alpha Therapy in Rheumatoid Arthritis. Journal of immunology (Baltimore, Md : 1950). 1999;163(3):1521-8.
101 Chen DY, Chou SJ, Hsieh TY, et al. Randomized, double-blind, placebo-controlled, comparative study of human anti-TNF antibody adalimumab in combination with methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis. 2009.
102 Chiang E, Selhub J, Bagley P, et al. Pyridoxine Supplementation Corrects Vitamin B6 Deficiency but Does Not Improve Inflammation in Patients With Rheumatoid Arthritis. Arthritis Res Ther. 2005;7(6):R1404-11. [pmid: 16277693].
103 Chijiwa T, Nishiya K, Hashimoto K. Serum Transferrin Receptor Levels in Patients With Rheumatoid Arthritis Are Correlated With Indicators for Anaemia. Clinical rheumatology. 2001;20(5):307-13. [pmid: 11642510].
104 Chong BF, Wong HK. Treatment of psoriasis with etanercept in a patient with a history of primary B-cell lymphoma. Clinical and Experimental Dermatology. 2009;34(5):e11-e3. [pmid: 19040508].
105 Choy EH, Kingsley GH, Khoshaba B, et al. A Two Year Randomised Controlled Trial of Intramuscular Depot Steroids in Patients With Established Rheumatoid Arthritis Who Have Shown an Incomplete Response to Disease Modifying Antirheumatic Drugs. Ann Rheum Dis. 2005;64(9):1288-93. [pmid: 15760929].
106 Choy EHS, Scott DL, Kingsley GH, et al. Treating Rheumatoid Arthritis Early With Disease Modifying Drugs Reduces Joint Damage: a Randomised Double Blind Trial of Sulphasalazine Vs Diclofenac Sodium. Clinical and experimental rheumatology. 2002;20(3):351-8. [pmid: 12102471].
107 Christensen AF, Lottenburger T, Lindegaard H, et al. Differential association of the N-propeptide of collagen IIA (PIIANP) and collagen II C-telopeptide (CTX-II) with synovitis and erosions in early and longstanding rheumatoid arthritis. Clinical and Experimental Rheumatology. 2009;27(2):307-14. [pmid: 19473573].
108 Ciconelli R, Ferraz M, Visioni R, et al. A Randomized Double-Blind Controlled Trial of Sulphasalazine Combined With Pulses of Methylprednisolone or Placebo in the Treatment of Rheumatoid Arthritis. British journal of rheumatology. 1996;35(2):150-4. [pmid: 8612028].
109 Claessen SJJ, Hazes JMW, Huisman MAM, et al. Use of risk stratification to target therapies in patients with recent onset arthritis; Design of a prospective randomized multicenter controlled trial. 2009.
110 Clark P, Casas E, Tugwell P, et al. Hydroxychloroquine Compared With Placebo in Rheumatoid Arthritis. A Randomized Controlled Trial. Annals of internal medicine. 1993;119(11):1067-71. [pmid: 8239224].
111 Clegg DO, Reda DJ, Weisman MH, et al. Comparison of Sulfasalazine and Placebo in the Treatment of Psoriatic Arthritis. A Department of Veterans Affairs Cooperative Study. Arthritis and rheumatism. 1996;39(12):2021-7. [pmid: 8961907].
112 Cohen G, Gossec L, Dougados M, et al. Radiological damage in patients with rheumatoid arthritis on sustained remission. Annals of the Rheumatic Diseases. 2007;66(3):358-63. [pmid: 16935911].
113 Cohen S, Cannon G, Schiff M, et al. Two-Year, Blinded, Randomized, Controlled Trial of Treatment of Active Rheumatoid Arthritis With Leflunomide Compared With Methotrexate. Utilization of Leflunomide in the Treatment of Rheumatoid Arthritis Trial Investigator Group. Arthritis and rheumatism. 2001;44(9):1984-92. [pmid: 11592358].
114 Cohen S, Zwillich SH, Chow V, et al. Co-administration of the JAK inhibitor CP-690,550 and methotrexate is well tolerated in patients with rheumatoid arthritis without need for dose adjustment. British Journal of Clinical Pharmacology. 2010;69(2):143-51. [pmid: 20233177].
115 Cohen SB, Emery P, Greenwald MW, et al. Rituximab for rheumatoid arthritis refractory to anti-tumor necrosis factor therapy: Results of a multicenter, randomized, double-blind, placebo-controlled, phase III trial evaluating primary efficacy and safety at twenty-four weeks. Arthritis and Rheumatism. 2006;54(9):2793-806. [pmid: 16947627].
116 Cojocaru L, Rusali A, Craiu E, et al. The efficacy and safety of simvastatin in patients with rheumatoid arthritis. Archives of the Balkan Medical Union. 2010;45(1):49-53.
117 Colombel JF, Sandborn WJ, Rutgeerts P, et al. Adalimumab for maintenance of clinical response and remission in patients with Crohn's disease: the CHARM trial. Gastroenterology. 2007;(1):52-65. [pmid: 17241859].
118 Combe B, Goupille P, Kuntz J, et al. Sulphasalazine in Psoriatic Arthritis: a Randomized, Multicentre, Placebo-Controlled Study. British journal of rheumatology. 1996;35(7):664-8. [pmid: 8670601].
119 Combe B, Velicitat P, Garzon N, et al. Comparison of Intramuscular and Oral Meloxicam in Rheumatoid Arthritis Patients. Inflammation research : official journal of the European Histamine Research Society [et al]. 2001;50(Suppl 1):S10-6.
120 Cordero OJ, Salgado FJ, Mera-Varela A, et al. Serum Interleukin-12, Interleukin-15, Soluble Cd26, and Adenosine Deaminase in Patients With Rheumatoid Arthritis. Rheumatology international. 2001;21(2):69-74. [pmid: 11732862].
121 Corkill MM, Kirkham BW, Chikanza IC, et al. Intramuscular Depot Methylprednisolone Induction of Chrysotherapy in Rheumatoid Arthritis: a 24-Week Randomized Controlled Trial. British journal of rheumatology. 1990;29(4):274-9. [pmid: 2198977].
122 Corvetta A, Della B, Luchetti M, et al. Tenoxicam and Ketoprofen Level Monitoring With High Performance Liquid Chromatography in Patients Affected by Rheumatoid Arthritis. CLIN EXP RHEUMATOL. 1991;9(2):143-8. [pmid: 2060161].
123 Courvoisier N, Dougados M, Cantagrel A, et al. Prognostic factors of 10-year radiographic outcome in early rheumatoid arthritis: A prospective study. Arthritis Research and Therapy. 2008;10(5).
124 Crowley B, Hamill J, Lyndon S, et al. Controlled-Release Indomethacin and Sustained-Release Diclofenac Sodium in the Treatment of Rheumatoid Arthritis: a Comparative Controlled Clinical Trial. Current medical research and opinion. 1990;12(3):143-50. [pmid: 2272188].
125 Cush J, Jasin H, Johnson R, et al. Relationship Between Clinical Efficacy and Laboratory Correlates of Inflammatory and Immunologic Activity in Rheumatoid Arthritis Patients Treated With Nonsteroidal Antiinflammatory Drugs. Arthritis and rheumatism. 1990;33(5):623-33. [pmid: 2346518].
126 Cush J, Lipsky P, Postlethwaite A, et al. Correlation of Serologic Indicators of Inflammation With Effectiveness of Nonsteroidal Antiinflammatory Drug Therapy in Rheumatoid Arthritis. Arthritis & Rheumatism. 1990;33(1):19-28. [pmid: 2302265].
127 Dalbeth N, Yeoman S, Dockerty JL, et al. A Randomised Placebo Controlled Trial of Delipidated, Deglycolipidated Mycobacterium Vaccae as Immunotherapy for Psoriatic Arthritis. Annals of the rheumatic diseases. 2004;63(6):790-4.
128 Danis V, Franic G, Rathjen D, et al. Circulating Cytokine Levels in Patients With Rheumatoid Arthritis: Results of a Double Blind Trial With Sulphasalazine. Annals of the rheumatic diseases. 1992;51(8):946-50. [pmid: 1358037].
129 Dawczynski C, Schubert R, Hein G, et al. Long-term moderate intervention with n-3 long-chain PUFA-supplemented dairy products: Effects on pathophysiological biomarkers in patients with rheumatoid arthritis. British Journal of Nutrition. 2009;101(10):1517-26. [pmid: 19245735].
130 de Boer IG, Peeters A, Ronday HK, et al. The usage of functional wrist orthoses in patients with rheumatoid arthritis. Disability and Rehabilitation. 2008;30(4):286-95. [pmid: 17852215].
131 De Graaf T, Van Ommen E, Van der Stelt M, et al. Effects of Low Dose Methotrexate Therapy on the Concentration and the Glycosylation of Alpha 1-Acid Glycoprotein in the Serum of Patients With Rheumatoid Arthritis: a Longitudinal Study. The Journal of rheumatology. 1994;21(12):2209-16. [pmid: 7699621].
132 Deighton CM, George E, Kiely PDW, et al. Updating the British Society for Rheumatology guidelines for anti-tumour necrosis factor therapy in adult rheumatoid arthritis (again). Rheumatology. 2006;45(6):649-52. [pmid: 16527881].
133 Dennison W, Loeser R, Turner R, et al. A Double Blind Placebo Controlled Trial of Low Dose Clotrimazole in Rheumatoid Arthritis. The Journal of rheumatology. 1990;17(8):1003-7. [pmid: 2213773].
134 DeWitt EM, Glick HA, Albert DA, et al. Medicare coverage of tumor necrosis factor alpha inhibitors as an influence on physicians' prescribing behavior. Archives of Internal Medicine. 2006;166(1):57-63. [pmid: 16401811].
135 Di Munno O, Mazzantini M, Milani S, et al. Clinical Equivalence Between Deflazacort Oral Drops and Tablets in Active Rheumatoid Arthritis. Clinical rheumatology. 1999;18(2):140-4. [pmid: 10357120].
136 Dick W, Franchimont P, Veys E. Double-Blind Comparison of Etodolac and Piroxicam in the Treatment of Rheumatoid Arthritis. Clinical therapeutics. 1993;15(1):148-59. [pmid: 8458044].
137 Dimitrijevic M, Bartlett R. Leflunomide, a Novel Immunomodulating Drug, Inhibits Homotypic Adhesion of Peripheral Blood and Synovial Fluid Mononuclear Cells in Rheumatoid Arthritis. Inflammation research : official journal of the European Histamine Research Society [et al]. 1996;30(8):4132-3.
138 Dixon WG, Watson KD, Lunt M, et al. Reduction in the incidence of myocardial infarction in patients with rheumatoid arthritis who respond to anti-tumor necrosis factor alpha therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis and Rheumatism. 2007;56(9):2905-12. [pmid: 17763428].
139 Dooley MA, Cush JJ, Lipsky PE, et al. The Effects of Nonsteroidal Antiinflammatory Drug Therapy in Early Rheumatoid Arthritis on Serum Levels of Soluble Interleukin 2 Receptor, Cd4, and Cd8. The Journal of rheumatology. 1993;20(11):1857-62. [pmid: 8308770].
140 Dore RK, Cohen SB, Lane NE, et al. Effects of denosumab on bone mineral density and bone turnover in patients with rheumatoid arthritis receiving concurrent glucocorticoids or bisphosphonates. Annals of the rheumatic diseases. 2010;69(5):872-5. [pmid: 19734132].
141 Dougados M, Combe B, Cantagrel A, et al. Combination Therapy in Early Rheumatoid Arthritis: a Randomised, Controlled, Double Blind 52 Week Clinical Trial of Sulphasalazine and Methotrexate Compared With the Single Components. Annals of the rheumatic diseases. 1999;58(4):220-5. [pmid: 10364900].
142 Drevlow BE, Lovis R, Haag MA, et al. Recombinant Human Interleukin-1 Receptor Type I in the Treatment of Patients With Active Rheumatoid Arthritis. Arthritis and rheumatism. 1996;39(2):257-65. [pmid: 8849376].
143 Drewes AM, Andreasen A, Jennum P, et al. Zopiclone as Night Medication in Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1998;27(3):180-7. [pmid: 9645412].
144 Drosos AA, Tsifetaki N, Tsiakou EK, et al. Influence of Methotrexate on Radiographic Progression in Rheumatoid Arthritis: a Sixty-Month Prospective Study. Clinical and experimental rheumatology. 1997;15(3):263-7. [pmid: 9177920].
145 Duffy T, Belton O, Bresnihan B, et al. Inhibition of PGE2 Production by Nimesulide Compared With Diclofenac in the Acutely Inflamed Joint of Patients With Arthritis. Drugs. 2003;63(Suppl 1):31-6. [pmid: 14506909].
146 Dugina JL, Petrov VI, Babayeva AR, et al. A Randomized, Open-Label, Comparative, 6-Month Trial of Oral Ultra-Low Doses of Antibodies to Tumor Necrosis Factor-Alpha and Diclofenac in Rheumatoid Arthritis. Int J Tissue React. 2005;27(1):15-21. [pmid: 15847101].
147 Dupuis LL, Koren G, Shore A, et al. Methotrexate-Nonsteroidal Antiinflammatory Drug Interaction in Children With Arthritis. Journal of Rheumatology. 1990;17(11):1469-73. [pmid: 2273487].
148 Eastell R, Devogelaer JP, Peel NF, et al. Prevention of Bone Loss With Risedronate in Glucocorticoid-Treated Rheumatoid Arthritis Patients. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA. 2000;11(4):331-7. [pmid: 10928223].
149 Eder L, Chandran V, Schentag CT, et al. Time and predictors of response to tumour necrosis factor-(alpha) blockers in psoriatic arthritis: An analysis of a longitudinal observational cohort. Rheumatology. 2010;49(7):1361-6. [pmid: 20385615].
150 Edwards JCW, Leandro MJ, Cambridge G. B Lymphocyte Depletion in Rheumatoid Arthritis: Targeting of Cd20. Curr Dir Autoimmun. 2005;1422(8):175-92. [pmid: 15564721].
151 Eggelmeijer F, Papapoulos S, van Paassen H, et al. Clinical and Biochemical Response to Single Infusion of Pamidronate in Patients With Active Rheumatoid Arthritis: a Double Blind Placebo Controlled Study. The Journal of rheumatology. 1994;21(11):2016-20. [pmid: 7869303].
152 Eggelmeijer F, Papapoulos SE, van Paassen HC, et al. Increased Bone Mass With Pamidronate Treatment in Rheumatoid Arthritis. Results of a Three-Year Randomized, Double-Blind Trial. Arthritis and rheumatism. 1996;39(3):396-402. [pmid: 8607888].
153 Egsmose C, Lund B, Borg G, et al. Patients With Rheumatoid Arthritis Benefit From Early 2nd Line Therapy: 5 Year Followup of a Prospective Double Blind Placebo Controlled Study. The Journal of rheumatology. 1995;22(12):2208-13. [pmid: 8835550].
154 Egsmose C, TMH, Andersen LS, et al. Limited Effect of Sulphasalazine Treatment in Reactive Arthritis. A Randomised Double Blind Placebo Controlled Trial. Annals of the rheumatic diseases. 1997;56(1):32-6. [pmid: 9059138].
155 Eichler HG, Mavros P, Geling O, et al. Association Between Health-Related Quality of Life and Clinical Efficacy Endpoints in Rheumatoid Arthritis Patients After Four Weeks Treatment With Anti-Inflammatory Agents. International journal of clinical pharmacology and therapeutics. 2005;43(5):209-16. [pmid: 15906586].
156 Elewski B, Leonardi C, Gottlieb AB, et al. Comparison of clinical and pharmacokinetic profiles of etanercept 25 mg twice weekly and 50 mg once weekly in patients with psoriasis. The British journal of dermatology. 2007;(1):138-42. [pmid: 17199580].
157 Emery P. Disease Modification in Rheumatoid Arthritis With Leflunomide. Scandinavian journal of rheumatology Supplement. 1999;112(9):9-14. [pmid: 10668522].
158 Emery P, Breedveld FC, Lemmel EM, et al. A Comparison of the Efficacy and Safety of Leflunomide and Methotrexate for the Treatment of Rheumatoid Arthritis. Rheumatology (Oxford). 2000;39(6):655-65. [pmid: 10888712].
159 Emery P, Clarke A, Williams P, et al. Nabumetone Compared With Naproxen in the Treatment of Rheumatoid Arthritis: a Multicenter, Double Blind, Randomized, Parallel Group Trial in Hospital Outpatients. The Journal of rheumatology Supplement. 1992;36:41-7. [pmid: 1474534].
160 Emery P, Durez P, Dougados M, et al. Impact of T-cell costimulation modulation in patients with undifferentiated inflammatory arthritis or very early rheumatoid arthritis: A clinical and imaging study of abatacept (the ADJUST trial). Annals of the rheumatic diseases. 2010;69(3):510-6. [pmid: 19933744].
161 Emery P, Genovese MC, Fleischmann RM, et al. Efficacy of Golimumab, a human anti-TNF(alpha) antibody, by baseline CRP level in patients with rheumatoid arthritis: Results from three phase 3, randomized, double-blind, placebo-controlled studies. Rheumatology. 2010:49i101.
162 Emery P, Zeidler H, Kvien TK, et al. Celecoxib Versus Diclofenac in Long-Term Management of Rheumatoid Arthritis: Randomised Double-Blind Comparison. Lancet. 2000;354(9196):2106-11. [pmid: 10609815].
163 Ergun T, Inanc N, Tuney D, et al. Skin manifestations of rheumatoid arthritis: A study of 215 Turkish patients. International Journal of Dermatology. 2008;47(9):894-902. [pmid: 18937651].
164 Eriksson LO, Sturfelt G, Thysell H, et al. Effects of Sulindac and Naproxen on Prostaglandin Excretion in Patients With Impaired Renal Function and Rheumatoid Arthritis. The American journal of medicine. 1990;89(3):313-21. [pmid: 2203262].
165 Faarvang K, Egsmose C, Kryger P, et al. Hydroxychloroquine and Sulphasalazine Alone and in Combination in Rheumatoid Arthritis: a Randomised Double Blind Trial. Annals of the rheumatic diseases. 1993;52(10):711-5. [pmid: 7903034].
166 Fallatah HI, Akbar HO, Qari YA. Autoimmune hepatitis: Single-center experience of clinical presentation, response to treatment and prognosis in Saudi Arabia. Saudi Journal of Gastroenterology. 2010;16(2):95-9. [pmid: 20339178].
167 Farr M, Kitas G, Waterhouse L, et al. Sulphasalazine in Psoriatic Arthritis: a Double-Blind Placebo-Controlled Study. British journal of rheumatology. 1990;29(1):46-0. [pmid: 1968355].
168 Fernandez A, Quintana G, Rondon F, et al. Lupus arthropathy: A case series of patients with rhupus. Clinical Rheumatology. 2006;25(2):164-7. [pmid: 15980935].
169 Ferraz MB, Pinheiro GR, Helfenstein M, et al. Combination Therapy With Methotrexate and Chloroquine in Rheumatoid Arthritis. A Multicenter Randomized Placebo-Controlled Trial. Scandinavian journal of rheumatology. 1994;23(5):231-6. [pmid: 7973475].
170 Fleischmann R. Safety and efficacy of etanercept in the elderly. Aging Health. 2006;2(2):189-97.
171 Flicinski J, Brzosko M, Olewniczak S. Multiple haemangiomas in a psoriatic arthritis patient treated with cyclosporine [13]. Acta Dermato Venereologica. 2006;86(3):271-2. [pmid: 16710599].
172 Foell D, Kane D, Bresnihan B, et al. Expression of the Pro-Inflammatory Protein S100a12 (En-Rage) in Rheumatoid and Psoriatic Arthritis. Rheumatology (Oxford). 2003;42(11):1383-9. [pmid: 12832707].
173 Foell D, Wulffraat N, Wedderburn LR, et al. Methotrexate withdrawal at 6 vs 12 months in juvenile idiopathic arthritis in remission a randomized clinical trial. JAMA - Journal of the American Medical Association. 2010;303(13):1266-73.
174 Franck H, Ittel T, Tasch O, et al. Osteocalcin in Patients With Rheumatoid Arthritis. A One-Year Followup Study. The Journal of rheumatology. 1994;21(7):1256-9. [pmid: 7966066].
175 Fransen J, Visser K, Van Dongen H, et al. Validity of the disease activity score in undifferentiated arthritis. Arthritis Care and Research. 2010;62(10):1392-8. [pmid: 20506371].
176 Fraser AD, van Kuijk AWR, Westhovens R, et al. A Randomised, Double Blind, Placebo Controlled, Multicentre Trial of Combination Therapy With Methotrexate Plus Ciclosporin in Patients With Active Psoriatic Arthritis. Ann Rheum Dis. 2005;64(6):859-64. [pmid: 15528283].
177 Fraser S, Hopkins R, Hunter J, et al. Sulphasalazine in the Management of Psoriatic Arthritis. British journal of rheumatology. 1993;32(10):923-5. [pmid: 8104656].
178 Friedman DM, Llanos C, Izmirly PM, et al. Evaluation of fetuses in a study of intravenous immunoglobulin as preventive therapy for congenital heart block: Results of a multicenter, prospective, open-label clinical trial. Arthritis and rheumatism. 2010;62(4):1138-46. [pmid: 20391423].
179 Furst D, Erikson N, Clute L, et al. Adverse Experience With Methotrexate During 176 Weeks of a Longterm Prospective Trial in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1990;12:1628-35. [pmid: 2084236].
180 Furst D, Felson D, Thoren G, et al. Immunoadsorption for the Treatment of Rheumatoid Arthritis: Final Results of a Randomized Trial. Prosorba Trial Investigators. Ther Apher. 2002;6(1):99.
181 Furst DE, Kolba KS, Fleischmann R, et al. Dose Response and Safety Study of Meloxicam up to 22.5 Mg Daily in Rheumatoid Arthritis: a 12 Week Multicenter, Double Blind, Dose Response Study Versus Placebo and Diclofenac. The Journal of rheumatology. 2002;29(3):436-46. [pmid: 11908554].
182 Furuya T, Kotake S, Inoue E, et al. Risk factors associated with incident fractures in Japanese men with rheumatoid arthritis: A prospective observational cohort study. Journal of Bone and Mineral Metabolism. 2008;26(5):499-505. [pmid: 18758909].
183 Furuya T, Kotake S, Inoue E, et al. Risk factors associated with incident clinical vertebral and nonvertebral fractures in Japanese women with rheumatoid arthritis: A prospective 54-month observational study. Journal of Rheumatology. 2007;34(2):303-10. [pmid: 17143973].
184 Furuya Y, Ozeki T, Takayanagi R, et al. Theory based analysis of anti-inflammatory effect of infliximab on Crohn's disease. Drug metabolism and pharmacokinetics. 2007;(1):20-5. [pmid: 17329907].
185 Furuzawa-Carballeda J, Fenutria-Ausmequet R, Gil-Espinosa V, et al. Polymerized-type I collagen for the treatment of patients with rheumatoid arthritis. Effect of intramuscular administration in a double blind placebo-controlled clinical trial. Clinical and Experimental Rheumatology. 2006;24(5):514-20. [pmid: 17181919].
186 Garnero P, Thompson E, Woodworth T, et al. Rapid and sustained improvement in bone and cartilage turnover markers with the anti-interleukin-6 receptor inhibitor tocilizumab plus methotrexate in rheumatoid arthritis patients with an inadequate response to methotrexate: Results from a substudy of the multicenter double-blind, placebo-controlled trial of tocilizumab in inadequate responders to methotrexate alone. 2010.
187 Gasparyan AY, Stavropoulos-Kalinoglou A, Toms TE, et al. Association of mean platelet volume with hypertension in rheumatoid arthritis. Inflammation and Allergy - Drug Targets. 2010;9(1):45-50. [pmid: 19906007].
188 Genant HK. Interleukin-1 Receptor Antagonist Treatment of Rheumatoid Arthritis Patients: Radiologic Progression and Correlation of Genant/Sharp and Larsen Scoring Methods. Seminars in arthritis and rheumatism. 2001;30(5 Suppl 2):26-32. [pmid: 11357169].
189 Genant HK, Peterfy CG, Westhovens R, et al. Abatacept inhibits progression of structural damage in rheumatoid arthritis: Results from the long-term extension of the AIM trial. Annals of the Rheumatic Diseases. 2007;67(8):1084-9. [pmid: 18086727].
190 Genovese MC, McKay JD, Nasonov EL, et al. Interleukin-6 receptor inhibition with tocilizumab reduces disease activity in rheumatoid arthritis with inadequate response to disease-modifying antirheumatic drugs: The tocilizumab in combination with traditional disease-modifying antirheumatic drug therapy study. Arthritis and Rheumatism. 2008;58(10):2968-80. [pmid: 18821691].
191 Genta MS, Kardes H, Gabay C. Clinical evaluation of a cohort of patients with rheumatoid arthritis treated with anti-TNF-alpha in the community. Joint Bone Spine. 2006;73(1):51-6. [pmid: 16386446].
192 Gerlag DM, Haringman JJ, Smeets TJM, et al. Effects of Oral Prednisolone on Biomarkers in Synovial Tissue and Clinical Improvement in Rheumatoid Arthritis. Arthritis and rheumatism. 2004;50(12):3783-91. [pmid: 15593225].
193 Gerlag DM, Hollis S, Layton M, et al. Preclinical and clinical investigation of a CCR5 antagonist, AZD5672, in patients with rheumatoid arthritis receiving methotrexate. Arthritis and rheumatism. 2010;62(11):3154-60. [pmid: 20662070].
194 Geusens P, Alten R, Rovensky J, et al. Efficacy, Safety and Tolerability of Lumiracoxib in Patients With Rheumatoid Arthritis. Int J Clin Pract. 2004;58(11):1033-41. [pmid: 15605667].
195 Geusens P, Truitt K, Sfikakis P, et al. A Placebo and Active Comparator-Controlled Trial of Rofecoxib for the Treatment of Rheumatoid Arthritis. Scandinavian journal of rheumatology. 2002;31(4):230-8. [pmid: 12369656].
196 Ghosh B, Halder S, Ghosh A, et al. Early rheumatoid arthritis: Clinical and therapeutic evaluation in a tertiary care centre in India. Indian Journal of Rheumatology. 2008;3(2):48-51.
197 Giannini EH, Ilowite NT, Lovell DJ, et al. Long-term safety and effectiveness of etanercept in children with selected categories of juvenile idiopathic arthritis. 2009.
198 Gladman D, Blake R, Brubacher B, et al. Chloroquine Therapy in Psoriatic Arthritis. The Journal of rheumatology. 1992;19(11):1724-6. [pmid: 1491390].
199 Gladman DD, Mease PJ, Cifaldi MA, et al. Adalimumab improves joint-related and skin-related functional impairment in patients with psoriatic arthritis: patient-reported outcomes of the Adalimumab Effectiveness in Psoriatic Arthritis Trial. Ann Rheum Dis. 2007;66(2):163-8. [pmid: 17046964].
200 Gladman DD, Mease PJ, Ritchlin CT, et al. Adalimumab for long-term treatment of psoriatic arthritis: forty-eight week data from the adalimumab effectiveness in psoriatic arthritis trial. Arthritis Rheum. Feb. 2007;56(2):476-88. [pmid: 17265483].
201 Godfrey C, Sweeney K, Miller K, et al. The Population Pharmacokinetics of Long-Term Methotrexate in Rheumatoid Arthritis. British journal of clinical pharmacology. 1998;46(4):369-76. [pmid: 9803986].
202 Goekoop-Ruiterman YPM, De Vries-Bouwstra JK, Allaart CF, et al. Comparison of treatment strategies in early rheumatoid arthritis: A randomized trial. Annals of Internal Medicine. 2007;146(6):406-15. [pmid: 17371885].
203 Goekoop-Ruiterman YPM, De Vries-Bouwstra JK, Kerstens PJSM, et al. DAS-driven therapy versus routine care in patients with recent-onset active rheumatoid arthritis. 2010.
204 Gonzalez-Alvaro I, Descalzo MA, Carmona L. Trends towards an improved disease state in rheumatoid arthritis over time: Influence of new therapies and changes in management approach: Analysis of the EMECAR cohort. Arthritis Research and Therapy. 2008;10(6).
205 Goodnough L, Marcus R. The Erythropoietic Response to Erythropoietin in Patients With Rheumatoid Arthritis. The Journal of laboratory and clinical medicine. 1997;130(4):381-6. [pmid: 9358076].
206 Gossec L, van der Heijde D, Melian A, et al. Efficacy of Cyclo-Oxygenase-2 Inhibition by Etoricoxib and Naproxen on the Axial Manifestations of Ankylosing Spondylitis in the Presence of Peripheral Arthritis. Annals of the rheumatic diseases. 2005;64(1):1563-7. [pmid: 15731291].
207 Gøtzsche P, Johansen H. Meta-Analysis of Short-Term Low Dose Prednisolone Versus Placebo and Non-Steroidal Anti-Inflammatory Drugs in Rheumatoid Arthritis. British medical journal. 1998;316(7144):1606-7.
208 Gotzsche PC, Hansen M, Stoltenberg M, et al. Randomized, Placebo Controlled Tial of Withdrawal of Slow-Acting Antirheumatic Drugs and of Observer Bias in Rheumatoid Arthritis. Scandinavian Journal of Rheumatology. 1996;25(4):194-0. [pmid: 8792795].
209 Graell E, Vazquez I, Larrosa M, et al. Disability measured by the modified health assessment questionnaire in early rheumatoid arthritis: Prognostic factors after two years of follow-up. Clinical and Experimental Rheumatology. 2009;27(2):284-91. [pmid: 19473570].
210 Graham DY, White RH, Moreland LW, et al. Duodenal and Gastric Ulcer Prevention With Misoprostol in Arthritis Patients Taking Nsaids. Misoprostol Study Group. Annals of internal medicine. 1993;119(4):257-62. [pmid: 8328732].
211 Greenberg JD, Bingham ICO, Abramson SB, et al. Assessment of coxib utilization by rheumatologists for nonsteroidal antiinflammatory drug gastroprotection prior to the coxib market withdrawals. Arthritis Care and Research. 2006;55(4):543-50. [pmid: 16874798].
212 Greenwood MC, Rathi J, Hakim AJ, et al. Regression to the mean using the disease activity score in eligibility and response criteria for prescribing TNF-alpha inhibitors in adults with rheumatoid arthritis. Rheumatology. 2007;46(7):1165-7. [pmid: 17488751].
213 Griffith SM, Fisher J, Clarke S, et al. Do Patients With Rheumatoid Arthritis Established on Methotrexate and Folic Acid 5 Mg Daily Need to Continue Folic Acid Supplements Long Term?. Rheumatology (Oxford). 2000;39(10):1102-9. [pmid: 11035130].
214 Grigor C, Capell H, Stirling A, et al. Effect of a Treatment Strategy of Tight Control for Rheumatoid Arthritis (the Ticora Study): a Single-Blind Randomised Controlled Trial. Lancet. 2004;364(9430):263-9. [pmid: 15262104].
215 Gulec G, Yenilmez C, Ayranci U. Sulfasalazine plus chloroquine-induced mood disorder in a patient with rheumatoid arthritis. Iranian Journal of Medical Sciences. 2009;34(1):72-5.
216 Guler-Yuksel M, Allaart CF, Watt I, et al. Treatment with TNF-(alpha) inhibitor infliximab might reduce hand osteoarthritis in patients with rheumatoid arthritis. Osteoarthritis and Cartilage. 2010;18(10):1256-62. [pmid: 20691795].
217 Gupta AK, Grober JS, Hamilton TA, et al. Sulfasalazine Therapy for Psoriatic Arthritis: a Double Blind, Placebo Controlled Trial. The Journal of rheumatology. 1996;22(5):894-8. [pmid: 8587078].
218 Haagsma C, Russel F, Vree T, et al. Combination of Methotrexate and Sulphasalazine in Patients With Rheumatoid Arthritis: Pharmacokinetic Analysis and Relationship to Clinical Response. British journal of clinical pharmacology. 1997;36(10):1082-8.
219 Haagsma C, van Riel P, de Jong A, et al. Combination of Sulphasalazine and Methotrexate Versus the Single Components in Early Rheumatoid Arthritis: a Randomized, Controlled, Double-Blind, 52 Week Clinical Trial. British journal of rheumatology. 1997;36(10):1082-8. [pmid: 9374925].
220 Haagsma C, van Riel P, van de Putte L. Combining Sulphasalazine and Methotrexate in Rheumatoid Arthritis: Early Clinical Impressions. British journal of rheumatology. 1995;34(Suppl 2):104-8. [pmid: 8535640].
221 Haagsma CJ, Blom HJ, van Riel PL, et al. Influence of Sulphasalazine, Methotrexate, and the Combination of Both on Plasma Homocysteine Concentrations in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 1999;58(2):79-84. [pmid: 10343521].
222 Haagsma CJ, van Riel PL, de Rooij DJ, et al. Combination of Methotrexate and Sulphasalazine Vs Methotrexate Alone: a Randomized Open Clinical Trial in Rheumatoid Arthritis Patients Resistant to Sulphasalazine Therapy. British journal of rheumatology. 1994;33(11):1049-55. [pmid: 7981992].
223 Haar D, Solvkjaer M, Unger B, et al. A Double-Blind Comparative Study of Hydroxychloroquine and Dapsone, Alone and in Combination, in Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1993;22(3):113-8. [pmid: 8316771].
224 Hafstrem I, Albertsson K, Boonen A, et al. Remission achieved after 2 years treatment with low-dose prednisolone in addition to diseasemodifying anti-rheumatic drugs in early rheumatoid arthritis is associated with reduced joint destruction still present after 4 years: An open 2-year continuation study. 2009.
225 Hakala M, Risteli J, Aman S, et al. Combination drug strategy in recent-onset rheumatoid arthritis suppresses collagen I degradation and is associated with retardation of radiological progression. Scandinavian Journal of Rheumatology. 2008;37(2):90-3. [pmid: 18415764].
226 Hamalainen H, Kaarela K, Kroger H, et al. Changes in bone mineral density in premenopausal women with rheumatoid arthritis during a two-year follow-up. Joint Bone Spine. 2007;74(5):482-7. [pmid: 17905634].
227 Hamilton J, McInnes I, Thomson E, et al. Comparative Study of Intramuscular Gold and Methotrexate in a Rheumatoid Arthritis Population From a Socially Deprived Area. Annals of the rheumatic diseases. 2001;60(6):566-72. [pmid: 11350844].
228 Hamilton R, Kremer J. Why Intramuscular Methotrexate May Be More Efficacious Than Oral Dosing in Patients With Rheumatoid Arthritis. British journal of rheumatology. 1997;36(1):86-90. [pmid: 9117183].
229 Hamilton S, Campbell N, Kara M, et al. The Effect of Ingestion of Ferrous Sulfate on the Absorption of Oral Methotrexate in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 2003;30(9):1948-50. [pmid: 12966595].
230 Hannequin JR. Efficacy of Arthrotec in the Treatment of Rheumatoid Arthritis. Scandinavian journal of rheumatology Supplement. 1992;96:7-14. [pmid: 1439627].
231 Hannonen P, Mottonen T, Hakola M, et al. Sulfasalazine in Early Rheumatoid Arthritis. A 48-Week Double-Blind, Prospective, Placebo-Controlled Study. Arthritis and rheumatism. 1993;36(11):1501-9. [pmid: 7902092].
232 Hansen M, Podenphant J, Florescu A, et al. A Randomised Trial of Differentiated Prednisolone Treatment in Active Rheumatoid Arthritis. Clinical Benefits and Skeletal Side Effects. Annals of the rheumatic diseases. 1999;58(11):713-8. [pmid: 10531077].
233 Hansen TM, Kryger P, Elling H, et al. Double Blind Placebo Controlled Trial of Pulse Treatment With Methylprednisolone Combined With Disease Modifying Drugs in Rheumatoid Arthritis. British medical journal. 1990;301(6749):268-70. [pmid: 2202458].
234 Hanyuda M, Kasama T, Isozaki T, et al. Activated Leucocytes Express and Secrete Macrophage Inflammatory Protein-1alpha Upon Interaction With Synovial Fibroblasts of Rheumatoid Arthritis Via a Beta2-Integrin/Icam-1 Mechanism. Rheumatology (Oxford). 2003;42(11):1390-7. [pmid: 12832710].
235 Haringman J, Kraan M, Smeets TJ, et al. Chemokine Blockade and Chronic Inflammatory Disease: Proof of Concept in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2003;62(8):715-21. [pmid: 12860725].
236 Hartmann SN, Rordorf CM, Milosavljev S, et al. Lumiracoxib Does Not Affect Methotrexate Pharmacokinetics in Rheumatoid Arthritis Patients. The Annals of pharmacotherapy. 2004;38(10):1582-7. [pmid: 15340127].
237 Hasegawa J, Nagashima M, Yamamoto M, et al. Bone Resorption and Inflammatory Inhibition Efficacy of Intermittent Cyclical Etidronate Therapy in Rheumatoid Arthritis. The Journal of rheumatology. 2004;38(10):1582-7.
238 Hatakka K, Martio J, Korpela M, et al. Effects of Probiotic Therapy on the Activity and Activation of Mild Rheumatoid Arthritis--a Pilot Study. Scandinavian journal of rheumatology. 2003;32(4):211-5. [pmid: 14626627].
239 Haugeberg G, Green MJ, Quinn MA, et al. Hand bone loss in early undifferentiated arthritis: Evaluating bone mineral density loss before the development of rheumatoid arthritis. Annals of the Rheumatic Diseases. 2006;65(6):736-40. [pmid: 16284095].
240 Haugeberg G, Strand A, Kvien T, et al. Reduced Loss of Hand Bone Density With Prednisolone in Early Rheumatoid Arthritis: Results From a Randomized Placebo-Controlled Trial. Archives of internal medicine. 2005;165(11):1293-7. [pmid: 15956010].
241 Hazes JM, Taylor P, Strand V, et al. Physical function improvements and relief from fatigue and pain are associated with increased productivity at work and at home in rheumatoid arthritis patients treated with certolizumab pegol. Rheumatology. 2010;49(10):1900-10. [pmid: 20547658].
242 Hemmings F, Farhan M, Rowland J, et al. Tolerability and Pharmacokinetics of the Collagenase-Selective Inhibitor Trocade in Patients With Rheumatoid Arthritis. Rheumatology (Oxford). 2001;40(5):537-43. [pmid: 11371662].
243 Henriksson K, Uribe A, Sandstedt B, et al. Helicobacter Pylori Infection, Abo Blood Group, and Effect of Misoprostol on Gastroduodenal Mucosa in Nsaid-Treated Patients With Rheumatoid Arthritis. Digestive diseases and sciences. 1993;38(9):1688-96. [pmid: 8359082].
244 Hepburn T, Totoritis M, Davis C. Antibody-Mediated Stripping of Cd4 From Lymphocyte Cell Surface in Patients With Rheumatoid Arthritis. Rheumatology (Oxford). 2003;42(1):54-61. [pmid: 12509613].
245 Hernandez-Cruz B, Ariza-Ariza R, Cardiel-Rios MH. Cost of the standard rheumatology care in active rheumatoid arthritis patients seen in a tertiary care center in Mexico City. Reumatologia Clinica. 2006;2(3):124-30. [pmid: 21794315].
246 Herrick A, Grennan D, Griffen K, et al. Lack of Interaction Between Flucloxacillin and Methotrexate in Patients With Rheumatoid Arthritis. British journal of clinical pharmacology. 1996;41(3):223-7. [pmid: 8866922].
247 Hetland ML, Ejbjerg B, Horslev-Petersen K, et al. MRI bone oedema is the strongest predictor of subsequent radiographic progression in early rheumatoid arthritis. Results from a 2-year randomised controlled trial (CIMESTRA). 2009.
248 Hetland ML, Lindegaard HM, Hansen A, et al. Do changes in prescription practice in patients with rheumatoid arthritis treated with biological agents affect treatment response and adherence to therapy? Results from the nationwide Danish DANBIO Registry. Annals of the Rheumatic Diseases. 2008;67(7):1023-6. [pmid: 18272669].
249 Heurkens A, Westedt M, Breedveld F. Prednisone Plus Azathioprine Treatment in Patients With Rheumatoid Arthritis Complicated by Vasculitis. Archives of internal medicine. 1991;151(11):2249-54. [pmid: 1953230].
250 Hewlett S, Mitchell K, Haynes J, et al. Patient-Initiated Hospital Follow-up for Rheumatoid Arthritis. Rheumatology (Oxford). 2000;39(9):990-7. [pmid: 10986304].
251 Hickling P, Jacoby R, Kirwan J. Joint Destruction After Glucocorticoids Are Withdrawn in Early Rheumatoid Arthritis. Arthritis and Rheumatism Council Low Dose Glucocorticoid Study Group. British journal of rheumatology. 1994;21(3):435-41.
252 Hidaka T, Suzuki K, Kawakami M, et al. Dynamic Changes in Cytokine Levels in Serum and Synovial Fluid Following Filtration Leukocytapheresis Therapy in Patients With Rheumatoid Arthritis. J Clin Apher. 2001;16(2):74-81. [pmid: 11746532].
253 Hidaka T, Suzuki K, Matsuki Y, et al. Changes in Cd4+ T Lymphocyte Subsets in Circulating Blood and Synovial Fluid Following Filtration Leukocytapheresis Therapy in Patients With Rheumatoid Arthritis. Ther Apher. 1999;3(2):178-85. [pmid: 10341394].
254 Hilliquin P, Chermat Izard V, Menkes CJ. A Double Blind, Placebo Controlled Study of a Platelet Activating Factor Antagonist in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1998;25(8):1502-7. [pmid: 9712091].
255 Hoekstra M, Haagsma C, Neef C, et al. Bioavailability of Higher Dose Methotrexate Comparing Oral and Subcutaneous Administration in Patients With Rheumatoid Arthritis. Journal of Rheumatology. 2004;31(4):645-8. [pmid: 15088287].
256 Hoekstra M, van Ede A, Haagsma C, et al. Factors associated with toxicity, final dose, and efficacy of methotrexate in patients with rheumatoid arthritis. Annals of the rheumatic diseases. 2003;62(5):423-6. [pmid: 12695153].
257 Hoffman GS, Cid MC, Rendt-Zagar KE, et al. Infliximab for maintenance of glucocorticosteroid-induced remission of giant cell arteritis: a randomized trial. Annals of internal medicine. 2007;(9):621-30. [pmid: 17470830].
258 Holm B, Jacobsen S, Skjodt H, et al. Keitel functional test for patients with rheumatoid arthritis: Translation, reliability, validity, and responsiveness. Physical Therapy. 2008;88(5):664-78. [pmid: 18276936].
259 Hor BTY, Vasoo S, Koh ET. The use of anti-tumour necrosis factor-alpha therapies for rheumatoid arthritis in Singapore. APLAR Journal of Rheumatology. 2006;9(2):157-60.
260 Horng MS. Early rheumatoid arthritis: Is there a best treatment?. Journal of Clinical Outcomes Management. 2007;14(5):233-4.
261 Huang F, Wang L, Zhang J, et al. Risk of tuberculosis in a Chinese registry of rheumatoid arthritis and ankylosing spondylitis for tumour necrosis factor-alpha antagonists. APLAR Journal of Rheumatology. 2006;9(2):170-4.
262 Huang SC, Wei JCC, Wu DJ, et al. Vitamin B6 supplementation improves pro-inflammatory responses in patients with rheumatoid arthritis. European Journal of Clinical Nutrition. 2010;64(9):1007-13. [pmid: 20571496].
263 Huffstutter J, Craig WD, Schimizzi G, et al. A multicenter, randomized, open study to evaluate the impact of an electronic data capture system on the care of patients with rheumatoid arthritis. Current Medical Research and Opinion. 2007;23(8):1967-79. [pmid: 17626700].
264 Hughes RA, Carr AJ, Carr M, et al. Improving patient safety: Reducing medication errors through use of acceptable, accessible medicines packaging. Pharmaceutical Journal. 2008;280(7484):22-5.
265 Huisman AM, Siewertsz van Everdingen AA, Wenting MJG, et al. Glucocorticoid Receptor up-Regulation in Early Rheumatoid Arthritis Treated With Low Dose Prednisone or Placebo. Clinical and experimental rheumatology. 2003;21(2):217-20. [pmid: 12747278].
266 Hunter J, Parnham M, Balaguer X. Aceclofenac in Rheumatoid Arthritis: a Useful and Novel Anti-Inflammatory. Clinical rheumatology. 1996;15(4):329-34. [pmid: 8853164].
267 Hurowitz EJ, Gould JS, Fleisig GS, et al. Outcome analysis of agility total ankle replacement with prior adjunctive procedures: Two to six year followup. Foot and Ankle International. 2007;28(3):308-12. [pmid: 17371654].
268 Huskisson EC. Four Commonly Prescribed Non-Steroidal Anti-Inflammatory Drugs for Rheumatoid Arthritis. European journal of rheumatology and inflammation. 1991;11(2):8-12. [pmid: 1365474].
269 Hyams J, Crandall W, Kugathasan S, et al. Induction and maintenance infliximab therapy for the treatment of moderate-to-severe Crohn's disease in children. Gastroenterology. 2007;(3):863-73. quiz 1165–6. [pmid: 17324398].
270 Iagnocco A, Cerioni A, Coari G, et al. Intra-articular methotrexate in the treatment of rheumatoid arthritis and psoriatic arthritis: A clinical and sonographic study. Clinical Rheumatology. 2006;25(2):159-63. [pmid: 15948014].
271 Ichikawa Y, Saito T, Yamanaka H, et al. Clinical activity after 12 weeks of treatment with nonbiologics in early rheumatoid arthritis may predict articular destruction 2 years later. Journal of Rheumatology. 2010;37(4):723-9. [pmid: 20194455].
272 Iglehart IWr,, Sutton JD, Bender JC, et al. Intravenous Pulsed Steroids in Rheumatoid Arthritis: a Comparative Dose Study. The Journal of rheumatology. 1990;17(2):159-62. [pmid: 2319516].
273 Ince A, Yazici Y, Hamuryudan V, et al. The Frequency and Clinical Characteristics of Methotrexate (Mtx) Oral Toxicity in Rheumatoid Arthritis (Ra): a Masked and Controlled Study. Clinical rheumatology. 1996;15(5):491-4. [pmid: 8894364].
274 Iqbal M, Baig J, Ali A, et al. The Effects of Non-Steroidal Anti-Inflammatory Drugs on the Disposition of Methotrexate in Patients With Rheumatoid Arthritis. Biopharmaceutics & drug disposition. 1998;19(3):163-7.
275 Ishikawa H, Murasawa A, Nakazono K, et al. The patient-based outcome of upper-extremity surgeries using the DASH questionnaire and the effect of disease activity of the patients with rheumatoid arthritis. Clinical Rheumatology. 2008;27(8):967-73. [pmid: 18214571].
276 Islam M, Alam M, Haq S, et al. Efficacy of Sulphasalazine Plus Methotrexate in Rheumatoid Arthritis. Bangladesh Medical Research Council bulletin. 2000;26(1):1-7. [pmid: 11192489].
277 Isozaki T, Sato M, Takahashi R, et al. Effects of low-dose tacrolimus therapy in combination with methotrexate in patients with methotrexate-refractory rheumatoid arthritis. 2010:229-34.
278 Izumi Y, Tominaga M, Iwanaga N, et al. Twenty-four-week follow-up examination of a leukocytapheresis therapy in rheumatoid arthritis. Modern Rheumatology. 2006;16(1):20-3. [pmid: 16622719].
279 Jacobs J, Rasker J, van Riel P, et al. Rheumajecta and Vasolastine in the Treatment of Rheumatoid Arthritis--the Results of a Placebo-Controlled, Double-Blind Trial of a Complementary Treatment. Scandinavian journal of rheumatology. 1991;20(6):434-40. [pmid: 1771401].
280 Jahangier ZN, Jacobs JWG, Lafeber FPJG, et al. Is Radiation Synovectomy for Arthritis of the Knee More Effective Than Intraarticular Treatment With Glucocorticoids? Results of an Eighteen-Month, Randomized, Double-Blind, Placebo-Controlled, Crossover Trial. Arthritis and rheumatism. 2005;52(11):3391-402. [pmid: 16255016].
281 Jakez Ocampo J, Richaud Patin Y, Simon J, et al. Weekly Dose of Leflunomide for the Treatment of Refractory Rheumatoid Arthritis: an Open Pilot Comparative Study. Joint, bone, spine : revue du rhumatisme. 2004;51(1):147-8.
282 Jakob A, Porstmann R, Rompel R. Skin ulceration after leflunomide treatment in two patients with rheumatoid arthritis. [German, English]. JDDG Journal of the German Society of Dermatology. 2006;4(4):324-7.
283 Jamal S, Patra K, Keystone EC. Adalimumab response in patients with early versus established rheumatoid arthritis: DE019 randomized controlled trial subanalysis. 2009.
284 Jaswal S, Mehta H, Sood A, et al. Antioxidant Status in Rheumatoid Arthritis and Role of Antioxidant Therapy. 2003;338:1-2. international journal of clinical chemistry.
285 Jelinek G, Will R, Dusci L, et al. Intravenous Regional Administration of Methylprednisolone in Rheumatoid Arthritis. Rheumatology international. 1991;11(4–5):147-50. [pmid: 1784882].
286 Jenks K, Stebbings S, Burton J, et al. Probiotic therapy for the treatment of spondyloarthritis: A randomized controlled trial. Journal of Rheumatology. 2010;37(10):2118-25. [pmid: 20716665].
287 Jessop JD, O'Sullivan MM, Lewis PA, et al. A Long-Term Five-Year Randomized Controlled Trial of Hydroxychloroquine, Sodium Aurothiomalate, Auranofin and Penicillamine in the Treatment of Patients With Rheumatoid Arthritis. British journal of rheumatology. 1998;37(9):992-1002. [pmid: 9783766].
288 Jeurissen ME, Boerbooms AM, van de Putte LB, et al. Influence of Methotrexate and Azathioprine on Radiologic Progression in Rheumatoid Arthritis. A Randomized, Double-Blind Study. Annals of internal medicine. 1991;114(12):999-1004. [pmid: 2029111].
289 Jones G, Sebba A, Gu J, et al. Comparison of tocilizumab monotherapy versus methotrexate monotherapy in patients with moderate to severe rheumatoid arthritis: The AMBITION study. 2010.
290 Joyce D, Will R, Hoffman D, et al. Exacerbation of Rheumatoid Arthritis in Patients Treated With Methotrexate After Administration of Folinic Acid. Annals of the rheumatic diseases. 1991;50(12):913-4. [pmid: 1768158].
291 Kafediska I, Spasovski D, Gruev T, et al. Association between Sharp's radiographic index and acute phase reactants in rheumatoid arthritis. Journal of Medical Biochemistry. 2008;27(4):447-53.
292 Kageyama Y, Sano M, Ishihara C, et al. Flexor tendon ruptures in both small fingers of a patient with rheumatoid arthritis [2]. Journal of Clinical Rheumatology. 2006;12(2):103-4. [pmid: 16601550].
293 Kahn KL, MacLean CH, Wong AL, et al. Assessment of American College of Rheumatology quality criteria for rheumatoid arthritis in a pre-quality criteria patient cohort. Arthritis Care and Research. 2007;57(5):707-15. [pmid: 17530663].
294 Kalden JR, Schattenkirchner M, Sorensen H, et al. The Efficacy and Safety of Leflunomide in Patients With Active Rheumatoid Arthritis: a Five-Year Followup Study. Arthritis and rheumatism. 2003;48(6):1513-20. [pmid: 12794818].
295 Kalden JR, Scott DL, Smolen JS, et al. Improved Functional Ability in Patients With Rheumatoid Arthritis - Longterm Treatment With Leflunomide Versus Sulfasalazine. Journal of Rheumatology. 2001;28(9):1983-91. [pmid: 11550964].
296 Kalden Nemeth D, Grebmeier J, Antoni C, et al. Nmr Monitoring of Rheumatoid Arthritis Patients Receiving Anti-Tnf-Alpha Monoclonal Antibody Therapy. Rheumatology international. 1997;16(6):249-55. [pmid: 9106936].
297 Kaltwasser J, Nash P, Gladman D, et al. Efficacy and Safety of Leflunomide in the Treatment of Psoriatic Arthritis and Psoriasis: a Multinational, Double-Blind, Randomized, Placebo-Controlled Clinical Trial. Arthritis and rheumatism. 2004;50(6):1393-50.
298 Kamel M, Serafi T. Fucose Concentrations in Sera From Patients With Rheumatoid Arthritis. Clinical and experimental rheumatology. 1995;13(2):243-6. [pmid: 7656471].
299 Kanbe K, Inoue K. Efficacy of arthroscopic synovectomy for the effect attenuation cases of infliximab in rheumatoid arthritis. Clinical Rheumatology. 2006;25(6):877-81. [pmid: 16374576].
300 Kanik K, Yarboro C, Naparstek Y, et al. Failure of Low-Dose Intravenous Immunoglobulin Therapy to Suppress Disease Activity in Patients With Treatment-Refractory Rheumatoid Arthritis. Arthritis and rheumatism. 1997;82(4):1279-83.
301 Karim A, Tolbert D, Hunt T, et al. Celecoxib, a Specific Cox-2 Inhibitor, Has No Significant Effect on Methotrexate Pharmacokinetics in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1999;26(12):2539-43. [pmid: 10606360].
302 Kavanaugh A, Genovese M, Baughman J, et al. Allele and Antigen-Specific Treatment of Rheumatoid Arthritis: a Double Blind, Placebo Controlled Phase 1 Trial. The Journal of rheumatology. 2003;30(3):449-54. [pmid: 12610799].
303 Kavanaugh A, Menter A, Mendelsohn A, et al. Effect of ustekinumab on physical function and health-related quality of life in patients with psoriatic arthritis: A randomized, placebo-controlled, phase II trial. Current Medical Research and Opinion. 2010;26(10):2385-92. [pmid: 20831455].
304 Kawai S, Uchida E, Kondo M, et al. Efficacy and safety of ketoprofen patch in patients with rheumatoid arthritis: A randomized, double-blind, placebo-controlled study. Journal of Clinical Pharmacology. 2010;50(10):1171-9. [pmid: 20133510].
305 Kekow J, Moots RJ, Emery P, et al. Patient-reported outcomes improve with etanercept plus methotrexate in active early rheumatoid arthritis and the improvement is strongly associated with remission: The COMET trial. 2010.
306 Kerstens P, Boerbooms A, Jeurissen M, et al. Radiological and Clinical Results of Longterm Treatment of Rheumatoid Arthritis With Methotrexate and Azathioprine. The Journal of rheumatology. 2000;27(5):1148-55. [pmid: 10813280].
307 Kerstens P, Boerbooms A, Jeurissen M, et al. Accelerated Nodulosis During Low Dose Methotrexate Therapy for Rheumatoid Arthritis. An Analysis of Ten Cases. The Journal of rheumatology. 1992;19(6):867-71. [pmid: 1404122].
308 Kerstens P, Boerbooms A, Jeurissen M, et al. Antiperinuclear Factor and Disease Activity in Rheumatoid Arthritis. Longitudinal Evaluation During Methotrexate and Azathioprine Therapy. The Journal of rheumatology. 1994;21(12):2190-4. [pmid: 7699617].
309 Keystone E, Haraoui B, Bykerk V. Role of Adalimumab in the Treatment of Early Rheumatoid Arthritis. Clinical and experimental rheumatology. 2003;21(5 Suppl 31):S198-9. [pmid: 14969077].
310 Khan S, Otter S, Springett K. The effects of reflexology on foot pain and quality of life in a patient with rheumatoid arthritis: A case report. Foot. 2006;16(2):112-6.
311 Kiely P, Williams R, Walsh D, et al. Contemporary patterns of care and disease activity outcome in early rheumatoid arthritis: The ERAN cohort. Rheumatology. 2009;48(1):57-60. [pmid: 18984608].
312 Kim H, Song Y. A Comparison Between Bucillamine and D-Penicillamine in the Treatment of Rheumatoid Arthritis. Rheumatology international. 1997;17(1):5-9. [pmid: 9194208].
313 Kimball AB, Bensimon AG, Guerin A, et al. Efficacy and safety of adalimumab among patients with moderate to severe psoriasis with co-morbidities: Subanalysis of results from a randomized, double-blind, placebo-controlled, phase III trial. American Journal of Clinical Dermatology. 2011;12(1):51-62. [pmid: 21110526].
314 Kirkham B, Corkill M, Davison S, et al. Response to Glucocorticoid Treatment in Rheumatoid Arthritis: in Vitro Cell Mediated Immune Assay Predicts in Vivo Responses. The Journal of rheumatology. 1991;18(6):821-5. [pmid: 1895263].
315 Kirkham B, Davison S, Corkill M, et al. Serial Soluble Interleukin 2 Receptor Levels in Rheumatoid Arthritis: Differences in Response to Glucocorticoid Treatment and Chrysotherapy. The Journal of rheumatology. 1993;20(6):935-9. [pmid: 8350327].
316 Kirkham B, Navarro F, Corkill M, et al. In Vivo Analysis of Disease Modifying Drug Therapy Activity in Rheumatoid Arthritis by Sequential Immunohistological Analysis of Synovial Membrane Interleukin 1 Beta. The Journal of rheumatology. 1994;21(9):1615-9. [pmid: 7799337].
317 Kirwan J, Byron M, Watt I. The Relationship Between Soft Tissue Swelling, Joint Space Narrowing and Erosive Damage in Hand X-Rays of Patients With Rheumatoid Arthritis. Rheumatology (Oxford). 2001;40(3):688-95.
318 Kirwan JR, Hallgren R, Mielants H, et al. A Randomised Placebo Controlled 12 Week Trial of Budesonide and Prednisolone in Rheumatoid Arthritis. Annals of the rheumatic diseases. 2004:63-6. 688. 95.
319 Kloppenburg M, Breedveld F, Terwiel J, et al. Minocycline in Active Rheumatoid Arthritis. A Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 1994;37(5):629-36. [pmid: 8185689].
320 Kloppenburg M, Dijkmans B, Verweij C, et al. Inflammatory and Immunological Parameters of Disease Activity in Rheumatoid Arthritis Patients Treated With Minocycline. Immunopharmacology. 1996;31(2–3):163-9. [pmid: 8861742].
321 Knijff Dutmer E, Kalsbeek Batenburg E, Koerts J, et al. Platelet Function Is Inhibited by Non-Selective Non-Steroidal Anti-Inflammatory Drugs but Not by Cyclo-Oxygenase-2-Selective Inhibitors in Patients With Rheumatoid Arthritis. Rheumatology (Oxford). 2002;41(4):458-61. [pmid: 11961179].
322 Knijff Dutmer E, Martens A, vd Laar M. Effects of Nabumetone Compared With Naproxen on Platelet Aggregation in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 1999;58(4):257-9. [pmid: 10364907].
323 Knijff-Dutmer E, Drossaers-Bakker W, Verhoeven A, et al. Rheumatoid Factor Measured by Fluoroimmunoassay: a Responsive Measure of Rheumatoid Arthritis Disease Activity That Is Associated With Joint Damage. Annals of the rheumatic diseases. 2002;61(7):603-7. [pmid: 12079900].
324 Knudsen LS, Klarlund M, Skjodt H, et al. Biomarkers of inflammation in patients with unclassified polyarthritis and early rheumatoid arthritis. Relationship to disease activity and radiographic outcome. Journal of Rheumatology. 2008;35(7):1277-87. [pmid: 18597410].
325 Kollerup G, Hansen M, Horslev Petersen K. Urinary Hydroxypyridinium Cross-Links of Collagen in Rheumatoid Arthritis. Relation to Disease Activity and Effects of Methylprednisolone. British journal of rheumatology. 1994;33(9):816-20. [pmid: 8081665].
326 Kondo H, Abe T, Hashimoto H, et al. Efficacy and Safety of Tacrolimus (Fk506) in Treatment of Rheumatoid Arthritis: a Randomized, Double Blind, Placebo Controlled Dose-Finding Study. The Journal of rheumatology. 2004;31(2):243-51. [pmid: 14760792].
327 Kopp S, Akerman S, Nilner M. Short-Term Effects of Intra-Articular Sodium Hyaluronate, Glucocorticoid, and Saline Injections on Rheumatoid Arthritis of the Temporomandibular Joint. Journal of craniomandibular disorders : facial & oral pain. 1991;5(4):231-8.
328 Kornasoff D, Maisenbacher J, Bowdler J, et al. The Efficacy and Tolerability of Aceclofenac Compared to Indomethacin in Patients With Rheumatoid Arthritis. Rheumatology international. 1996;15(6):225-30. [pmid: 8778950].
329 Korpela M, Laasonen L, Hannonen P, et al. Retardation of Joint Damage in Patients With Early Rheumatoid Arthritis by Initial Aggressive Treatment With Disease-Modifying Antirheumatic Drugs: Five-Year Experience From the Fin-Raco Study. Arthritis and rheumatism. 2004;50(7):2072-81. [pmid: 15248204].
330 Korthals-de Bos I, Van Tulder M, Boers M, et al. Indirect and Total Costs of Early Rheumatoid Arthritis: a Randomized Comparison of Combined Step-Down Prednisolone, Methotrexate, and Sulfasalazine With Sulfasalazine Alone. The Journal of rheumatology. 2004;31(9):1709-16. [pmid: 15338488].
331 Kraan MC, de Koster BM, Elferink JG, et al. Inhibition of Neutrophil Migration Soon After Initiation of Treatment With Leflunomide or Methotrexate in Patients With Rheumatoid Arthritis: Findings in a Prospective, Randomized, Double-Blind Clinical Trial in Fifteen Patients. Arthritis and rheumatism. 2000;43(7):1488-95. [pmid: 10902750].
332 Kraan MC, Reece RJ, Barg EC, et al. Modulation of Inflammation and Metalloproteinase Expression in Synovial Tissue by Leflunomide and Methotrexate in Patients With Active Rheumatoid Arthritis. Findings in a Prospective, Randomized, Double-Blind, Parallel-Design Clinical Trial in Thirty-Nine Patients at Two Centers. Arthritis and rheumatism. 2000;43(8):1820-30. [pmid: 10943872].
333 Kraan MC, Smeets TJM, van Loon MJ, et al. Differential Effects of Leflunomide and Methotrexate on Cytokine Production in Rheumatoid Arthritis. Annals of the rheumatic diseases. 2004;63(9):1056-61. [pmid: 15115713].
334 Kremer J, Genovese M, Cannon GW, et al. Combination Leflunomide and Methotrexate (Mtx) Therapy for Patients With Active Rheumatoid Arthritis Failing Mtx Monotherapy: Open-Label Extension of a Randomized, Double-Blind, Placebo Controlled Trial. The Journal of rheumatology. 2004;31(8):1521-31. [pmid: 15290730].
335 Kremer JM, Davies JM, Rynes RI, et al. Every-Other-Week Methotrexate in Patients With Rheumatoid Arthritis. A Double-Blind, Placebo-Controlled Prospective Study. Arthritis and rheumatism. 1995;38(5):601-7. [pmid: 7748214].
336 Kremer JM, Genovese MC, Cannon GW, et al. Concomitant Leflunomide Therapy in Patients With Active Rheumatoid Arthritis Despite Stable Doses of Methotrexate. A Randomized, Double-Blind, Placebo-Controlled Trial. Annals of internal medicine. 2002;137(9):726-33. [pmid: 12416946].
337 Kristensen LE, Geborek P, Saxne T. Dose escalation of infliximab therapy in arthritis patients is related to diagnosis and concomitant methotrexate treatment: Observational results from the South Swedish Arthritis Treatment Group register. Rheumatology. 2009;48(3):243-5. [pmid: 19106164].
338 Krug H, Broadwell L, Berry M, et al. Tolerability and Efficacy of Nabumetone and Naproxen in the Treatment of Rheumatoid Arthritis. Clinical therapeutics. 2000;22(1):40-52. [pmid: 10688389].
339 Kumar K, Gordon C, Toescu V, et al. Beliefs about medicines in patients with rheumatoid arthritis and systemic lupus erythematosus: A comparison between patients of South Asian and White British origin. Rheumatology. 2008;47(5):690-7. [pmid: 18375972].
340 Kurowski M, Menninger H, Pauli E. The Efficacy and Relative Bioavailability of Diclofenac Resinate in Rheumatoid Arthritis Patients. International journal of clinical pharmacology and therapeutics. 1994;32(8):433-40. [pmid: 7981929].
341 Kuuliala A, Leirisalo-Repo M, Mottonen T, et al. Serum Soluble Interleukin-2 Receptor Predicts Early Remission in Patients With Recent-Onset Rheumatoid Arthritis Treated With a Single Disease-Modifying Antirheumatic Drug. Clinical and experimental rheumatology. 2005;23(2):243-6. [pmid: 15895898].
342 Kvien TK, Gaston JSH, Bardin T, et al. Three Month Treatment of Reactive Arthritis With Azithromycin: a EULAR Double Blind, Placebo Controlled Study. Annals of the rheumatic diseases. 2004;63(9):1113-9. [pmid: 15308521].
343 Laan RF, van Riel PL, van de Putte LB, et al. Low-Dose Prednisone Induces Rapid Reversible Axial Bone Loss in Patients With Rheumatoid Arthritis. A Randomized, Controlled Study. Annals of internal medicine. 1993;119(10):963-8. [pmid: 8105737].
344 Laas K, Peltomaa R, Puolakka K, et al. Early improvement of health-related quality of life during treatment with etanercept and adalimumab in patients with rheumatoid arthritis in routine practice. Clinical and Experimental Rheumatology. 2009;27(2):315-20. [pmid: 19473574].
345 Laasila K, Laasonen L, Leirisalo RM. Antibiotic Treatment and Long Term Prognosis of Reactive Arthritis. Annals of the rheumatic diseases. 2003;62(7):655-8. [pmid: 12810429].
346 Lacki J, Leszczynski P, Mackiewicz S. Intravenous Cyclophosphamide Combined With Methylprednisolone in the Treatment of Severe Refractory Rheumatoid Arthritis: the Effect on Lymphocytes. Journal of investigational allergology & clinical immunology : official organ of the International Association of Asthmology (INTERASMA) and Sociedad Latinoamericana de Alergia e Inmunología. 1996;6(4):232-6.
347 Lacki J, Mackiewicz S, Wiktorowicz K. Lymphocyte Phenotype Studies of Rheumatoid Arthritis Patients Treated With Methotrexate. Archivum immunologiae et therapiae experimentalis. 1994;42(4):287-90. [pmid: 7487368].
348 Lacki J, Samborski W, Mackiewicz S. Interleukin-10 and Interleukin-6 in Lupus Erythematosus and Rheumatoid Arthritis, Correlations With Acute Phase Proteins. Clinical rheumatology. 1997;16(3):275-8. [pmid: 9184265].
349 Lacki JK, Schochat T, Sobieska M, et al. Immunological Studies in Patients With Rheumatoid Arthritis Treated With Methotrexate or Cyclophosphamide. Zeitschrift für Rheumatologie. 1994;53(2):76-82.
350 Laharie D, Seneschal J, Schaeverbeke T, et al. Assessment of liver fibrosis with transient elastography and FibroTest in patients treated with methotrexate for chronic inflammatory diseases: A case-control study. Journal of Hepatology. 2010;53(6):1035-40. [pmid: 20801541].
351 Laine L, Connors L, Griffin MR, et al. Prescription rates of protective co-therapy for NSAID users at high GI risk and results of attempts to improve adherence to guidelines. 2009.
352 Laine L, Curtis SP, Cryer B, et al. Assessment of upper gastrointestinal safety of etoricoxib and diclofenac in patients with osteoarthritis and rheumatoid arthritis in the Multinational Etoricoxib and Diclofenac Arthritis Long-term (MEDAL) programme: a randomised comparison. Lancet. 2007;369(9560):465-73. [pmid: 17292766].
353 Laine L, Curtis SP, Cryer B, et al. Risk factors for NSAID-associated upper GI clinical events in a long-term prospective study of 34 701 arthritis patients. Alimentary Pharmacology and Therapeutics. 2010;32(10):1240-8. [pmid: 20955443].
354 Laine L, Goldkind L, Curtis SP, et al. How common is diclofenac-associated liver injury? Analysis of 17,289 arthritis patients in a long-term prospective clinical trial. American Journal of Gastroenterology. 2009;104(2):356-62. [pmid: 19174782].
355 Lambert CM, Sandhu S, Lochhead A, et al. Dose Escalation of Parenteral Methotrexate in Active Rheumatoid Arthritis That Has Been Unresponsive to Conventional Doses of Methotrexate: a Randomized, Controlled Trial. Arthritis and rheumatism. 2004;50(2):364-71. [pmid: 14872477].
356 Landewe R, Geusens P, van der Heijde D, et al. Arthritis Instantaneously Causes Collagen Type I and Type Ii Degradation in Patients With Early Rheumatoid Arthritis: a Longitudinal Analysis. Ann Rheum Dis. 2006;65(1):40-4. [pmid: 16126801].
357 Lard LR, Boers M, Verhoeven A, et al. Early and Aggressive Treatment of Rheumatoid Arthritis Patients Affects the Association of Hla Class Ii Antigens With Progression of Joint Damage. Arthritis and rheumatism. 2002;46(4):899-905. [pmid: 11953965].
358 Larsen A, Kvien TK, Schattenkirchner M, et al. Slowing of Disease Progression in Rheumatoid Arthritis Patients During Long-Term Treatment With Leflunomide or Sulfasalazine. Scandinavian journal of rheumatology. 2001;30(3):135-42. [pmid: 11469522].
359 Larsen CM, Faulenbach M, Vaag A, et al. Interleukin-1-receptor antagonist in type 2 diabetes mellitus. The New England journal of medicine. 2007;(15):1517-26. [pmid: 17429083].
360 Lauhio A, Leirisalo Repo M, Lahdevirta J, et al. Double-Blind, Placebo-Controlled Study of Three-Month Treatment With Lymecycline in Reactive Arthritis, With Special Reference to Chlamydia Arthritis. Arthritis and rheumatism. 1991;34(1):6-14. [pmid: 1670621].
361 Le Gallez P, Bird H, Wright V. A Comparison of Choline Magnesium Trisalicylate and Acetylsalicylic Acid in Patients With Rheumatoid Arthritis. Current medical research and opinion. 1990;12(2):71-5. [pmid: 2202551].
362 Lee EY, Lee EB, Park BJ, et al. Tramadol 37.5-mg/acetaminophen 325-mg combination tablets added to regular therapy for rheumatoid arthritis pain: A 1-Week, randomized, double-blind, placebo-controlled trial. Clinical Therapeutics. 2006;28(12):2052-60. [pmid: 17296461].
363 Lee KKC, You JHS, Ho JTS, et al. Economic Analysis of Celecoxib Versus Diclofenac Plus Omeprazole for the Treatment of Arthritis in Patients at Risk of Ulcer Disease. Alimentary pharmacology & therapeutics. 2003;18(2):217-22. [pmid: 12869082].
364 Lee VWY, Chan CW, Chan LH, et al. The direct medical cost of rheumatoid arthritis in Hong Kong. Journal of Medical Economics. 2007;10(4):443-53.
365 Lehman A, Esdaile J, Klinkhoff A, et al. A 48-Week, Randomized, Double-Blind, Double-Observer, Placebo-Controlled Multicenter Trial of Combination Methotrexate and Intramuscular Gold Therapy in Rheumatoid Arthritis: Results of the Metgo Study. Arthritis Rheum. 2005;52(5):1360-70. [pmid: 15880810].
366 Lemmel EM. Comparison of Pyritinol and Auranofin in the Treatment of Rheumatoid Arthritis. British Journal of Rheumatology. 1993;32(5):375-82. [pmid: 8495257].
367 Lemmel EM, Bolten W, Burgos-Vargas R, et al. Efficacy and Safety of Meloxicam in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1997;24(2):282-90. [pmid: 9034984].
368 Lerndal T, Svensson B. A Clinical Study of Cph 82 Vs Methotrexate in Early Rheumatoid Arthritis. Rheumatology (Oxford). 2000;39(3):316-20. [pmid: 10788542].
369 Levalampi T, Korpela M, Vuolteenaho K, et al. Etanercept and adalimumab treatment in patients with rheumatoid arthritis and spondyloarthropathies in clinical practice: Adverse events and other reasons leading to discontinuation of the treatment. Rheumatology International. 2008;28(3):261-9. [pmid: 17846778].
370 Leventhal L, Boyce E, Zurier R. Treatment of Rheumatoid Arthritis With Gammalinolenic Acid. Annals of internal medicine. 1993;119(9):867-73. [pmid: 8214997].
371 Levi S, Goodlad RA, Lee CY, et al. Effects of Nonsteroidal Anti-Inflammatory Drugs and Misoprostol on Gastroduodenal Epithelial Proliferation in Arthritis. Gastroenterology. 1992;102(5):1609-11.
372 Lewandowski B, Bernacka K, Kucharewicz B, et al. Assessment of Beta-2-Microglobulin Concentration in Serum and Urine in Rheumatoid Arthritis. Roczniki Akademii Medycznej w Bia&#322;ymstoku (1995). 1996;41(2):482-91.
373 Li LC, Maetzel A, Davis AM, et al. Primary therapist model for patients referred for rheumatoid arthritis rehabilitation: A cost-effectiveness analysis. Arthritis Care and Research. 2006;55(3):402-10. [pmid: 16739183].
374 Li T, Wells G, Westhovens R, et al. Validation of a simple activity participation measure for rheumatoid arthritis clinical trials. Rheumatology. 2009;48(2):170-5. [pmid: 19141573].
375 Lightfoot R. Comparison of the Efficacy and Safety of Etodolac and Piroxicam in Patients With Rheumatoid Arthritis. Etodolac Study 326 Rheumatoid Arthritis Investigators Group. The Journal of rheumatology Supplement. 1997;47:10-6. [pmid: 9035015].
376 Lin Q, Gu JR, Li TW, et al. Value of the peripheral blood B-cells subsets in patients with ankylosing spondylitis. 2009.
377 Lin Q, Lin Z, Gu J, et al. Abnormal high-expression of CD154 on T lymphocytes of ankylosing spondylitis patients is down-regulated by etanercept treatment. 2010.
378 Lipsky P, Isakson P. Outcome of Specific Cox-2 Inhibition in Rheumatoid Arthritis. The Journal of rheumatology Supplement. 1997;49:9-14. [pmid: 9249645].
379 Lisse JR. Clinical Efficacy and Safety of Naprelan Versus Naprosyn in the Treatment of Rheumatoid Arthritis. The American journal of orthopedics. 1996;25(9 Suppl):21-9. [pmid: 8886214].
380 Litinsky I, Paran D, Levartovsky D, et al. The effects of leflunomide on clinical parameters and serum levels of IL-6, IL-10, MMP-1 and MMP-3 in patients with resistant rheumatoid arthritis. Cytokine. 2006;33(2):106-10. [pmid: 16487722].
381 Littman B, Drury C, Zimmerer R, et al. Rheumatoid Arthritis Treated With Tenidap and Piroxicam. Clinical Associations With Cytokine Modulation by Tenidap. Arthritis and rheumatism. 1995;38(1):29-37. [pmid: 7818568].
382 Liu C, Batliwalla F, Li W, et al. Genome-wide association scan identifies candidate polymorphisms associated with differential response to anti-TNF treatment in rheumatoid arthritis. Molecular Medicine. 2008;14(9–10):575-81. [pmid: 18615156].
383 Lonauer G, Tisscher J, Lim H, et al. Double-Blind Comparison of Etodolac and Diclofenac in Patients With Rheumatoid Arthritis. Current medical research and opinion. 1993;13(2):70-7. [pmid: 8325044].
384 Lopez-Gonzalez R, Hernandez-Garcia C, Abasolo L, et al. Differences between rheumatology attending physicians and training residents in the management of rheumatoid arthritis in Spain. Scandinavian Journal of Rheumatology. 2008;37(6):419-26. [pmid: 18609260].
385 Lopez-Mendez A, Daniel WW, Reading JC, et al. Radiographic Assessment of Disease Progression in Rheumatoid Arthritis Patients Enrolled in the Cooperative Systematic Studies of the Rheumatic Diseases Program Randomized Clinical Trial of Methotrexate, Auranofin, or a Combination of the Two. Arthritis and rheumatism. 1993;36(10):1364-9. [pmid: 8216395].
386 Louly PG, Medeiros-Souza P, Santos-Neto L. N-of-1 double-blind, randomized controlled trial of tramadol to treat chronic cough. 2009.
387 Lu C, Zha Q, Chang A, et al. Pattern differentiation in traditional chinese medicine can help define specific indications for biomedical therapy in the treatment of rheumatoid arthritis. 2009.
388 Luis M, Pacheco-Tena C, Cazarin-Barrientos J, et al. Comparison of Two Schedules for Administering Oral Low-Dose Methotrexate (Weekly Versus Every-Other-Week) in Patients With Rheumatoid Arthritis in Remission: a Twenty-Four Week, Single Blind, Randomized Study. Arthritis and rheumatism. 1999;42(10):2160-5. [pmid: 10524688].
389 Maccagno A, Di Giorgio E, Roldan E, et al. Double Blind Radiological Assessment of Continuous Oral Pamidronic Acid in Patients With Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1994;23(4):211-4. [pmid: 8091148].
390 Machold K, Neumann K, Smolen J. Recombinant Human Interferon Gamma in the Treatment of Rheumatoid Arthritis: Double Blind Placebo Controlled Study. Annals of the rheumatic diseases. 1992;51(9):1039-43. [pmid: 1417133].
391 Machold KP, Landewe R, Smolen JS, et al. The Stop Arthritis Very Early (SAVE) trial, an international multicentre, randomised, double-blind, placebo-controlled trial on glucocorticoids in very early arthritis. Annals of the rheumatic diseases. 2010;69(3):495-502. [pmid: 20223838].
392 Maetzel A, Strand V, Tugwell P, et al. Economic Comparison of Leflunomide and Methotrexate in Patients With Rheumatoid Arthritis: an Evaluation Based on a 1-Year Randomised Controlled Trial. PharmacoEconomics. 2002;20(1):61-70. [pmid: 11817993].
393 Maillefert JF, Combe B, Goupille P, et al. Long Term Structural Effects of Combination Therapy in Patients With Early Rheumatoid Arthritis: Five Year Follow up of a Prospective Double Blind Controlled Study. Annals of the rheumatic diseases. 2003;62(8):764-6. [pmid: 12860733].
394 Maksymowych WP, Salonen D, Inman RD, et al. Low-dose infliximab (3 mg/kg) significantly reduces spinal inflammation on magnetic resonance imaging in patients with ankylosing spondylitis: A randomized placebo-controlled study. Journal of Rheumatology. 2010;37(8):1728-34. [pmid: 20436073].
395 Manorot M, Rojanasathien N, Louthrenoo W, et al. Comparative Studies of Quality and Bioavailability of Methotrexate in Thai Patients With Rheumatoid Arthritis. Journal of the Medical Association of Thailand = Chotmaihet thangphaet. 1998;81(12):978-85. [pmid: 9916387].
396 Mariette X, Tubach F, Bagheri H, et al. Lymphoma in patients treated with anti-TNF: Results of the 3-year prospective French RATIO registry. Annals of the rheumatic diseases. 2010;69(2):400-8. [pmid: 19828563].
397 Marshall D, Hunter J, Capell H. Double Blind, Placebo Controlled Study of Metronidazole as a Disease Modifying Agent in the Treatment of Rheumatoid Arthritis. Annals of the rheumatic diseases. 1992;51(6):758-60. [pmid: 1616359].
398 Martens H, Sheets P, Tenover J, et al. Decreased Testosterone Levels in Men With Rheumatoid Arthritis: Effect of Low Dose Prednisone Therapy. The Journal of rheumatology. 1994;21(8):1427-31. [pmid: 7983641].
399 Martin Mola E, Gijon Banos J, Ansoleaga J. Aceclofenac in Comparison to Ketoprofen in the Treatment of Rheumatoid Arthritis. Rheumatology international. 1995;15(3):111-6. [pmid: 8588120].
400 Matsumoto AK, Melian A, Mandel DR, et al. A Randomized, Controlled, Clinical Trial of Etoricoxib in the Treatment of Rheumatoid Arthritis. The Journal of rheumatology. 2002;29(8):1623-30. [pmid: 12180720].
401 Matsuno H, Yudoh K, Kondo M, et al. Biochemical Effect of Intra-Articular Injections of High Molecular Weight Hyaluronate in Rheumatoid Arthritis Patients. Inflammation research : official journal of the European Histamine Research Society [et al]. 1999;48(3):154-9.
402 Matteson EL, Yocum DE, St Clair EW, et al. Treatment of Active Refractory Rheumatoid Arthritis With Humanized Monoclonal Antibody Campath-1h Administered by Daily Subcutaneous Injection. Arthritis and rheumatism. 1995;38(9):1187-93. [pmid: 7575711].
403 Mayo P, Skeith K, Russell A, et al. Decreased Dromotropic Response to Verapamil Despite Pronounced Increased Drug Concentration in Rheumatoid Arthritis. British journal of clinical pharmacology. 2000;50(6):605-13. [pmid: 11136300].
404 Mazzantini M, Di Munno O, Metelli M, et al. Single Infusion of Neridronate (6-Amino-1-Hydroxyhexylidene-1,1-Bisphosphonate) in Patients With Active Rheumatoid Arthritis: Effects on Disease Activity and Bone Resorption Markers. Aging Clin Exp Res. 2002;14(3):197-201. [pmid: 12387527].
405 McCarey DW, McInnes IB, Madhok R, et al. Trial of Atorvastatin in Rheumatoid Arthritis (Tara): Double-Blind, Randomised Placebo-Controlled Trial. Lancet. 2004;262(9426):2015-21. [pmid: 15207950].
406 Mcgee B, Small RE, Singh R, et al. B Lymphocytic Clonal Expansion in Rheumatoid Arthritis. The Journal of rheumatology. 1996;23(1):36-43. [pmid: 8838506].
407 McInnes I, Porter D, Murphy E, et al. Low Dose Desensitisation Does Not Reduce the Toxicity of Sulphasalazine in Rheumatoid Arthritis. Annals of the rheumatic diseases. 1996;55(5):328-30. [pmid: 8660109].
408 McKendry R, Kraag G, Seigel S, et al. Therapeutic Value of Colchicine in the Treatment of Patients With Psoriatic Arthritis. Annals of the rheumatic diseases. 1993;52(11):826-8. [pmid: 8250615].
409 McKendry RJ. Azathioprine and Methotrexate as Combination Chemotherapy in Rheumatoid Arthritis. The Journal of rheumatology Supplement. 1990;25:28-33. [pmid: 2273519].
410 McLachlan A, Tett S, Cutler D, et al. Disposition of the Enantiomers of Hydroxychloroquine in Patients With Rheumatoid Arthritis Following Multiple Doses of the Racemate. British journal of clinical pharmacology. 1993;36(1):78-81. [pmid: 8373715].
411 McLachlan A, Tett S, Cutler D, et al. Bioavailability of Hydroxychloroquine Tablets in Patients With Rheumatoid Arthritis. British journal of rheumatology. 1994;33(3):235-9. [pmid: 8156285].
412 Mease PJ. Cytokine Blockers in Psoriatic Arthritis. Annals of the rheumatic diseases. 2001;60(Suppl 3):iii37-40. [pmid: 11890650].
413 Mease PJ, Hobbs K, Chalmers A, et al. Local delivery of a recombinant adenoassociated vector containing a tumour necrosis factor alpha antagonist gene in inflammatory arthritis: A phase 1 dose-escalation safety and tolerability study. 2009.
414 Mease PJ, Signorovitch J, Yu AP, et al. Impact of adalimumab on symptoms of psoriatic arthritis in patients with moderate to severe psoriasis: A pooled analysis of randomized clinical trials. Dermatology. 2010;220(1):1-7. [pmid: 19940437].
415 Mease PJ, Wei N, Fudman EJ, et al. Safety, tolerability, and clinical outcomes after intraarticular injection of a recombinant adeno-associated vector containing a tumor necrosis factor antagonist gene: Results of a phase 1/2 study. Journal of Rheumatology. 2010;37(4):692-703. [pmid: 20032102].
416 Mehta S, Dasarathy S, Tandon R, et al. A Prospective Randomized Study of the Injurious Effects of Aspirin and Naproxen on the Gastroduodenal Mucosa in Patients With Rheumatoid Arthritis. The American journal of gastroenterology. 1992;87(8):996-1000. [pmid: 1642224].
417 Meineke I, Turck D. Population Pharmacokinetic Analysis of Meloxicam in Rheumatoid Arthritis Patients. British journal of clinical pharmacology. 2003;55(1):32-8. [pmid: 12534638].
418 Melikterminas E, Ranganath V, Furst DE. Treatment of the elderly rheumatoid arthritis patient. Future Rheumatology. 2008;3(3):235-8.
419 Menter A, Feldman SR, Weinstein GD, et al. A randomized comparison of continuous vs. intermittent infliximab maintenance regimens over 1 year in the treatment of moderate-to-severe plaque psoriasis. J Am Acad Dermatol. Jan. 2007;56(1):31 e1-15. [pmid: 17097378].
420 Merkel PA, Dooley MA, Dawson DV, et al. Interleukin-2 Receptor Levels in Sera of Patients With Rheumatoid Arthritis Treated With Sulfasalazine, Parenteral Gold, or Placebo. The Journal of rheumatology. 1996;23(11):1856-61. [pmid: 8923356].
421 Michaels R, Reading J, Beezhold D, et al. Serum Phospholipase A2 Activity in Patients With Rheumatoid Arthritis Before and After Treatment With Methotrexate, Auranofin, or Combination of the Two. Journal of Rheumatology. 1996;23(2):226-9. [pmid: 8882023].
422 Mierau M, Schoels M, Gonda G, et al. Assessing remission in clinical practice. Rheumatology. 2007;46(6):975-9. [pmid: 17341506].
423 Miese FR, Ostendorf B, Wittsack HJ, et al. Metacarpophalangeal joints in rheumatoid arthritis: Delayed gadolinium-enhanced MR imaging of cartilage - A feasibility study. Radiology. 2010;257(2):441-7. [pmid: 20807848].
424 Miyake K, Kusunoki M, Shinji Y, et al. Bisphosphonate increases risk of gastroduodenal ulcer in rheumatoid arthritis patients on long-term nonsteroidal antiinflammatory drug therapy. Journal of Gastroenterology. 2009;44(2):113-20. [pmid: 19214672].
425 Miyake K, Ueki N, Suzuki K, et al. Preventive Therapy for Non-Steroidal Anti-Inflammatory Drug-Induced Ulcers in Japanese Patients With Rheumatoid Arthritis: the Current Situation and a Prospective Controlled-Study of the Preventive Effects of Lansoprazole or Famotidine. Alimentary pharmacology & therapeutics. 2005;21(Suppl 2):67-72. [pmid: 15943850].
426 Miyamoto S, Kageyama Y, Ozeki T, et al. Effects of Glucocorticoids on Bone Mineral Density in Rheumatoid Arthritis Patients. A Longitudinal Study. Archives of orthopaedic and trauma surgery. 1999;199(1–2):18-21. [pmid: 10076939].
427 Mladenovic V, Domljan Z, Rozman B, et al. Safety and Effectiveness of Leflunomide in the Treatment of Patients With Active Rheumatoid Arthritis. Results of a Randomized, Placebo-Controlled, Phase Ii Study. Arthritis and rheumatism. 1995;38(11):1595-603. [pmid: 7488280].
428 Montrone F, Petrillo M, Caruso I, et al. A Comparison of Severe Gastric Damage as a Result of Pirprofen and Naproxen Treatment in Rheumatoid Arthritis: a Controlled Endoscopic Study. Journal of internal medicine. 1994;236(2):153-9. [pmid: 8046314].
429 Moore A, Gordon KB, Kang S, et al. A randomized, open-label trial of continuous versus interrupted etanercept therapy in the treatment of psoriasis. Journal of the American Academy of Dermatology. 2007;(4):598-603. [pmid: 17113190].
430 Moreland L, RG, King K, et al. Results of a Phase-I/II Randomized, Masked, Placebo-Controlled Trial of Recombinant Human Interleukin-11 (Rhil-11) in the Treatment of Subjects With Active Rheumatoid Arthritis. Arthritis Res. 2001;3(4):247-52. [pmid: 11438043].
431 Moreland LW. Disease modifiers: Making the right therapeutic choices for our patients. Journal of Rheumatology. 2007;34(SUPPL 79):21-6. [pmid: 17611975].
432 Moreland LW, Pratt PW, Mayes MD, et al. Double-Blind, Placebo-Controlled Multicenter Trial Using Chimeric Monoclonal Anti-Cd4 Antibody, Cm-T412, in Rheumatoid Arthritis Patients Receiving Concomitant Methotrexate. Arthritis and rheumatism. 1995;38(11):1581-8. [pmid: 7488278].
433 Morgan AW, Hale G, Rebello PRUB, et al. A pilot study of combination anti-cytokine and anti-lymphocyte biological therapy in rheumatoid arthritis. Qjm. 2008;101(4):299-306. [pmid: 18287112].
434 Morris V, Cruwys S, Kidd B. Characterisation of Capsaicin-Induced Mechanical Hyperalgesia as a Marker for Altered Nociceptive Processing in Patients With Rheumatoid Arthritis. Pain. 1997;71(2):179-86. [pmid: 9211479].
435 Mottonen T, Hannonen P, Korpela M, et al. Delay to Institution of Therapy and Induction of Remission Using Single-Drug or Combination-Disease-Modifying Antirheumatic Drug Therapy in Early Rheumatoid Arthritis. Arthritis Rheum. 2002;46(4):894-8. [pmid: 11953964].
436 Mottonen T, Hannonen P, Leirisalo-Repo M, et al. Comparison of Combination Therapy With Single-Drug Therapy in Early Rheumatoid Arthritis: a Randomised Trial. Lancet. 1999;353(9164):1568-73. [pmid: 10334255].
437 Mould DR, Davis CB, Minthorn EA, et al. A Population Pharmacokinetic-Pharmacodynamic Analysis of Single Doses of Clenoliximab in Patients With Rheumatoid Arthritis. Clinical pharmacology and therapeutics. 1999;66(3):246-57. [pmid: 10511060].
438 Muller Fassbender HR. A 6-Month Randomized Dose Range Study of Om-8980 in Rheumatoid Arthritis. Br J Rheumatol. 1993;32(8):746-50. [pmid: 8348280].
439 Muller-Ladner U, Rockwitz K, Brandt-Jurgens J, et al. Tolerability and patient/physician satisfaction with subcutaneously administered methotrexate provided in two formulations of different drug concentrations in patients with rheumatoid arthritis. Open Rheumatology Journal. 2010;4:15-22. [pmid: 20461222].
440 Mur E, Hartig F, Eibl G, et al. Randomized Double Blind Trial of an Extract From the Pentacyclic Alkaloid-Chemotype of Uncaria Tomentosa for the Treatment of Rheumatoid Arthritis. The Journal of rheumatology. 2002;29(4):678-81. [pmid: 11950006].
441 Nagafuchi H, Suzuki N, Kaneko A, et al. Prolactin Locally Produced by Synovium Infiltrating T Lymphocytes Induces Excessive Synovial Cell Functions in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1999;26(9):1890-900. [pmid: 10493666].
442 Nair R, Saag KG. The use of low-dose glucocorticoids for the treatment of early rheumatoid arthritis: What can we learn about bone effects of glucocorticoids from randomized controlled trials?. Current Rheumatology Reports. 2006;8(1):47-8.
443 Nakamura H, Ueki Y, Sakito S, et al. Clinical Effects of Actarit in Rheumatoid Arthritis: Improvement of Early Disease Activity Mediated by Reduction of Serum Concentrations of Nitric Oxide. Clinical and experimental rheumatology. 2000;18(4):455-50.
444 Naredo E, Collado P, Cruz A, et al. Longitudinal power Doppler ultrasonographic assessment of joint inflammatory activity in early rheumatoid arthritis: Predictive value in disease activity and radiologic progression. Arthritis Care and Research. 2007;57(1):116-24. [pmid: 17266071].
445 Nehring AK, Dua U, Mollee P, et al. Epstein-Barr virus T-cell immunity despite rituximab. British journal of haematology. 2007;(4):628-32. [pmid: 17223914].
446 Nieto-Colonia AM, Santos WS, Keusseyan SP, et al. Antibodies to citrullinated peptides are not associated with the rate of joint destruction in patients with a well-established diagnosis of rheumatoid arthritis. Brazilian Journal of Medical and Biological Research. 2008;41(3):188-92. [pmid: 18235966].
447 Nikolaisen C, Figenschau Y, Nossent JC. Anemia in early rheumatoid arthritis is associated with interleukin 6-mediated bone marrow suppression, but has no effect on disease course or mortality. Journal of Rheumatology. 2008;35(3):380-6. [pmid: 18260177].
448 Nisar M, Carlisle L, Amos R. Methotrexate and Sulphasalazine as Combination Therapy in Rheumatoid Arthritis. British journal of rheumatology. 1994;33(7):651-4. [pmid: 7912633].
449 Nishimoto N, Miyasaka N, Yamamoto K, et al. Long-term safety and efficacy of tocilizumab, an anti-IL-6 receptor monoclonal antibody, in monotherapy, in patients with rheumatoid arthritis (the STREAM study): Evidence of safety and efficacy in a 5-year extension study. 2009.
450 Nishimoto N, Yoshizaki K, Miyasaka N, et al. Treatment of Rheumatoid Arthritis With Humanized Anti-Interleukin-6 Receptor Antibody: a Multicenter, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 2004;50(6):1761-9. [pmid: 15188351].
451 Nived O, Sturfelt G, Eckernas S, et al. A Comparison of 6 Months’ Compliance of Patients With Rheumatoid Arthritis Treated With Tenoxicam and Naproxen. Use of Patient Computer Data to Assess Response to Treatment. The Journal of rheumatology. 1994;21(8):1537-41. [pmid: 7983661].
452 Nobunaga M, Yasuda M. Comparison of Clinical Effects of Bucillamine Between Additive Combination and Single Administration Study in Rheumatoid Arthritis. Agents and actions Supplements. 1993;44:105-9. [pmid: 8372720].
453 Nomura T, Kodama K, Nishimura M, et al. Animation as a useful tool for assessing functional status in psoriatic arthritis. Journal of Dermatological Science. 2006;44(3):172-4. [pmid: 17049209].
454 Nourmohammadi I, Athari-Nikazm S, Vafa MR, et al. Effects of antioxidant supplementations on oxidative stress in rheumatoid arthritis patients. Journal of Biological Sciences. 2010;10(1):63-6.
455 Numo R. Multicentre Double-Blind Study of the Efficacy, Safety and Tolerance of Pirazolac Compared With Sulindac in Patients With Rheumatoid Arthritis. Drugs under experimental and clinical research. 1990;16(1):17-27. [pmid: 2198156].
456 Nunez M, Nunez E, Yoldi C, et al. Health-related quality of life in rheumatoid arthritis: Therapeutic education plus pharmacological treatment versus pharmacological treatment only. Rheumatology International. 2006;26(8):752-7. [pmid: 16247548].
457 Ochi T, Hakomori S, Fujimoto M, et al. Therapeutic Effect of Intradermal Injections With Difucosyl Lactosamine (Dimeric Lex) on Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1993;20(12):2038-45. [pmid: 7912285].
458 O’Connor K, Burke R, Riminton S. Hospital supply of off-label immunomodulatory drugs. 2009.
459 O’Dell JR, Blakely KW, Mallek JA, et al. Treatment of Early Seropositive Rheumatoid Arthritis: a Two-Year, Double-Blind Comparison of Minocycline and Hydroxychloroquine. Arthritis and rheumatism. 2001;44(10):2235-41. [pmid: 11665963].
460 O’Dell JR, Leff R, Paulsen G, et al. Treatment of Rheumatoid Arthritis With Methotrexate and Hydroxychloroquine, Methotrexate and Sulfasalazine, or a Combination of the Three Medications: Results of a Two-Year, Randomized, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 2002;46(5):1164-70. [pmid: 12115219].
461 O’Dell JR, Paulsen G, Haire CE, et al. Treatment of Early Seropositive Rheumatoid Arthritis With Minocycline: Four-Year Followup of a Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 1999;42(8):1691-5. [pmid: 10446869].
462 Odio C, Ramirez T, Arias G, et al. Double Blind, Randomized, Placebo-Controlled Study of Dexamethasone Therapy for Hematogenous Septic Arthritis in Children. The Pediatric infectious disease journal. 2003;22(10):883-8. [pmid: 14551489].
463 Ogrendik M. Treatment of rheumatoid arthritis with ornidazole: A randomized, double-blind, placebo-controlled study. Rheumatology International. 2006;26(12):1132-7. [pmid: 16770616].
464 Ollendorf DA, Klingman D, Hazard E, et al. Differences in annual medication costs and rates of dosage increase between tumor necrosis factor-antagonist therapies for rheumatoid arthritis in a managed care population. Clinical Therapeutics. 2009;31(4):825-35. [pmid: 19446156].
465 Olsen N, Teal G, Brooks R. Igm-Rheumatoid Factor and Responses to Second-Line Drugs in Rheumatoid Arthritis. Agents and actions. 1991;34(1–2):124-9.
466 Olsen NJ, Brooks RH, Cush JJ, et al. A Double-Blind, Placebo-Controlled Study of Anti-Cd5 Immunoconjugate in Patients With Rheumatoid Arthritis. Arthritis and rheumatism. 1996;39(7):1102-8. [pmid: 8670317].
467 Osiri M, Deesomchok U, Tugwell P. Disease activity and functional changes of RA patients receiving different DMARDs in clinical practice. Clinical Rheumatology. 2006;25(5):721-7. [pmid: 16365685].
468 Osterhaus JT, Purcaru O, Richard L. Discriminant validity, responsiveness and reliability of the rheumatoid arthritis-specific Work Productivity Survey (WPS-RA). 2009.
469 Paleolog E, Young S, Stark A, et al. Modulation of Angiogenic Vascular Endothelial Growth Factor by Tumor Necrosis Factor Alpha and Interleukin-1 in Rheumatoid Arthritis. Arthritis and rheumatism. 1998;41(7):1258-65. [pmid: 9663484].
470 Paleolog EM, Hunt M, Elliott MJ, et al. Deactivation of Vascular Endothelium by Monoclonal Anti-Tumor Necrosis Factor Alpha Antibody in Rheumatoid Arthritis. Arthritis and rheumatism. 1996;39(7):1082-91. [pmid: 8670315].
471 Palosaari K, Vuotila J, Takalo R, et al. Bone oedema predicts erosive progression on wrist MRI in early RA - A 2-yr observational MRI and NC scintigraphy study. Rheumatology. 2006;45(12):1542-8. [pmid: 16670155].
472 Pandya S, Aggarwal A, Misra R. Methotrexate Twice Weekly Vs Once Weekly in Rheumatoid Arthritis: a Pilot Double-Blind, Controlled Study. Rheumatology international. 2002;22(1):1-4. [pmid: 12120905].
473 Panicheeva S, Ngsriwongse S, Mokkhavesa C, et al. Original Versus Generic Piroxicams, Their Cost-Effective Evaluation in Rheumatoid Arthritis (Ra) Patients. Journal of the Medical Association of Thailand = Chotmaihet thangphaet. 1992;75(2):104-9. [pmid: 1645047].
474 Park JY, Kim KA, Lee YH, et al. Pharmacokinetic comparison and bioequivalence of two leflunomide formulations in humans: A single dose, randomized, open-label, two-way crossover study. International Journal of Clinical Pharmacology and Therapeutics. 2010;48(4):291-5. [pmid: 20353751].
475 Pascual-Ramos V, Contreras-Yanez I, Villa AR, et al. Medication persistence over 2 years of follow-up in a cohort of early rheumatoid arthritis patients: Associated factors and relationship with disease activity and with disability. Arthritis Research and Therapy. 2009;11(1).
476 Pasero G, Marcolongo R, Serni U, et al. A Multi-Centre, Double-Blind Comparative Study of the Efficacy and Safety of Aceclofenac and Diclofenac in the Treatment of Rheumatoid Arthritis. Current medical research and opinion. 1995;13(6):305-15. [pmid: 8829889].
477 Paul BJ, Thachil EJ, Jayachandran NV, et al. Clinical efficacy and adverse effects of weekly single dose leflunomide in refractory rheumatoid arthritis. Indian Journal of Rheumatology. 2007;2(1):3-7.
478 Paulus H, Egger M, Ward J, et al. Analysis of Improvement in Individual Rheumatoid Arthritis Patients Treated With Disease-Modifying Antirheumatic Drugs, Based on the Findings in Patients Treated With Placebo. The Cooperative Systematic Studies of Rheumatic Diseases Group. Arthritis and rheumatism. 1990;33(4):477-84. [pmid: 2109613].
479 Pavelka K, Jarosova K, Suchy D, et al. Increasing the infliximab dose in rheumatoid arthritis patients: A randomised, double blind study failed to confirm its efficacy. 2009.
480 Pavelka K, Recker D, Verburg K. Valdecoxib Is as Effective as Diclofenac in the Management of Rheumatoid Arthritis With a Lower Incidence of Gastroduodenal Ulcers: Results of a 26-Week Trial. Rheumatology (Oxford). 2003;42(10):1207-15. [pmid: 12810937].
481 Pease C, Pope JE, Thorne C, et al. Canadian variation by province in rheumatoid arthritis initiating anti-tumor necrosis factor therapy: Results from the optimization of adalimumab trial. Journal of Rheumatology. 2010;37(12):2469-74. [pmid: 20843910].
482 Peeters HR, Jongen-Lavrencic M, Bakker CH, et al. Recombinant Human Erythropoietin Improves Health-Related Quality of Life in Patients With Rheumatoid Arthritis and Anaemia of Chronic Disease; Utility Measures Correlate Strongly With Disease Activity Measures. Rheumatology international. 1999;18(5–6):201-6. [pmid: 10399796].
483 Peeters HR, Jongen-Lavrencic M, Vreugdenhil G, et al. Effect of Recombinant Human Erythropoietin on Anaemia and Disease Activity in Patients With Rheumatoid Arthritis and Anaemia of Chronic Disease: a Randomised Placebo Controlled Double Blind 52 Weeks Clinical Trial. Annals of the rheumatic diseases. 1996;55(10):739-44. [pmid: 8984939].
484 Peltomaa R, Paimela L, Helve T, et al. Comparison of Intramuscular Gold and Sulphasalazine in the Treatment of Early Rheumatoid Arthritis. A One Year Prospective Study. Scandinavian journal of rheumatology. 1995;24(6):330-5. [pmid: 8610215].
485 Pentek M, Kobelt G, Czirjak L, et al. Costs of rheumatoid arthritis in Hungary. Journal of Rheumatology. 2007;34(6):1437-9. [pmid: 17552071].
486 Peretz A, Siderova V, Neve J. Selenium Supplementation in Rheumatoid Arthritis Investigated in a Double Blind, Placebo-Controlled Trial. Scandinavian journal of rheumatology. 2001;30(4):208-12. [pmid: 11578015].
487 Perez Ruiz F, Alonso Ruiz A, Ansoleaga J. Comparative Study of the Efficacy and Safety of Aceclofenac and Tenoxicam in Rheumatoid Arthritis. Clinical rheumatology. 1996;15(5):473-7. [pmid: 8894360].
488 Pettersson T, Soderblom T, Nyberg P, et al. Pleural Fluid Soluble Interleukin 2 Receptor in Rheumatoid Arthritis and Systemic Lupus Erythematosus. The Journal of rheumatology. 1994;21(10):1820-4. [pmid: 7837144].
489 Pincus T, Swearingen CJ, Luta G, et al. Efficacy of prednisone 1–4 mg/day in patients with rheumatoid arthritis: A randomised, double-blind, placebo controlled withdrawal clinical trial. 2009.
490 Pisoni L, Murgo A, Paresce E, et al. Effectiveness and safety of leflunomide in the clinical practice. A different experience [1]. Clinical and Experimental Rheumatology. 2007;25(1).
491 Plant M, O’Sullivan MM, Lewis P, et al. What Factors Influence Functional Ability in Patients With Rheumatoid Arthritis. Do They Alter Over Time? Rheumatology (Oxford). 2005;44(9):1181-5.
492 Plant MJ, Williams AL, O’Sullivan MM, et al. Relationship Between Time-Integrated C-Reactive Protein Levels and Radiologic Progression in Patients With Rheumatoid Arthritis. Arthritis and rheumatism. 2000;43(7):1473-7. [pmid: 10902748].
493 Podas T, Nightingale JMD, Oldham R, et al. Is rheumatoid arthritis a disease that starts in the intestine? A pilot study comparing an elemental diet with oral prednisolone. Postgraduate Medical Journal. 2007;83(976):128-31. [pmid: 17308218].
494 Polisson RP, Dooley MA, Dawson DV, et al. Interleukin-2 Receptor Levels in the Sera of Rheumatoid Arthritis Patients Treated With Methotrexate. Arthritis and rheumatism. 1994;37(1):50-6. [pmid: 8129764].
495 Popp W, Rauscher H, Ritschka L, et al. Prediction of Interstitial Lung Involvement in Rheumatoid Arthritis; the Value of Clinical Data, Chest Roentgenogram, Lung Function, and Serologic Parameters. CHEST. 1992;102(2):391-4. [pmid: 1643920].
496 Porter D, Capell H. The ‘natural’ History of Active Rheumatoid Arthritis Over 3–6 Months--an Analysis of Patients Enrolled Into Trials of Potential Disease-Modifying Anti-Rheumatic Drugs, and Treated With Placebo. British journal of rheumatology. 1993;32(6):423-8.
497 Porter D, Madhok R, Hunter J, et al. Prospective Trial Comparing the Use of Sulphasalazine and Auranofin as Second Line Drugs in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 1992;52(6):416-4.
498 Porter D, McInnes I, Hunter J, et al. Outcome of second line therapy in rheumatoid arthritis. Annals of the rheumatic diseases. 1994;53(12):812-5. [pmid: 7864689].
499 Prins AMA, Vos K, Franssen EJF. Instability of topical ciclosporin emulsion for nail psoriasis [4]. Dermatology. 2007;215(4):362-3. [pmid: 17911999].
500 Prochorec-Sobieszek M, Chelstowska M, Rymkiewicz G, et al. Biclonal T-cell receptor gammadelta+ large granular lymphocyte leukemia associated with rheumatoid arthritis. Leukemia and Lymphoma. 2008;49(4):828-31. [pmid: 18398755].
501 Pullerits R, D’Elia HF, Tarkowski A, et al. The decrease of soluble RAGE levels in rheumatoid arthritis patients following hormone replacement therapy is associated with increased bone mineral density and diminished bone/cartilage turnover: A randomized controlled trial. 2009.
502 Puolakka K, Kautiainen H, Mottonen T, et al. Early Suppression of Disease Activity Is Essential for Maintenance of Work Capacity in Patients With Recent-Onset Rheumatoid Arthritis: Five-Year Experience From the Fin-Raco Trial. Arthritis and rheumatism. 2005;52(1):36-41. [pmid: 15641055].
503 Puolakka K, Kautiainen H, Mottonen T, et al. Use of the Stanford Health Assessment Questionnaire in estimation of long-term productivity costs in patients with recent-onset rheumatoid arthritis. Scandinavian Journal of Rheumatology. 2009;38(2):96-103. [pmid: 19274516].
504 Puolakka K, Kautiainen H, Mottonen T, et al. Impact of Initial Aggressive Drug Treatment With a Combination of Disease-Modifying Antirheumatic Drugs on the Development of Work Disability in Early Rheumatoid Arthritis: a Five-Year Randomized Followup Trial. Arthritis and rheumatism. 2004;50(1):55-62. [pmid: 14730599].
505 Puri S, Bery A, Sekhon JS, et al. Prescription practices of general physicians in the treatment of rheumatoid arthritis. Indian Journal of Rheumatology. 2008;3(2):86-7.
506 Rao U, Naidu M, Kumar T, et al. Comparison of Phenytoin With Auranofin and Chloroquine in Rheumatoid Arthritis--a Double Blind Study. The Journal of rheumatology. 1995;22(7):1235-40. [pmid: 7562751].
507 Raspe H, Deck R, Mattussek S. The Outcome of Traditional or Comprehensive Outpatient Care for Rheumatoid Arthritis (Ra). Results of an Open, Non-Randomized, 2-Year Prospective Study. Zeitschrift für Rheumatologie. 1992;51(Suppl 1):61-6.
508 Rau R, Herborn G, Karger T, et al. A Double-Blind Comparison of Parenteral Methotrexate and Parenteral Gold in the Treatment of Early Erosive Rheumatoid Arthritis: an Interim Report on 102 Patients After 12 Months. Seminars in arthritis and rheumatism. 1991;21(2 Suppl 1):13-30. [pmid: 1749945].
509 Rau R, Herborn G, Menninger H, et al. Comparison of Intramuscular Methotrexate and Gold Sodium Thiomalate in the Treatment of Early Erosive Rheumatoid Arthritis: 12 Month Data of a Double-Blind Parallel Study of 174 Patients. British journal of rheumatology. 2997;36(3):345-52. [pmid: 9133967].
510 Rau R, Herborn G, Menninger H, et al. Progression in Early Erosive Rheumatoid Arthritis: 12 Month Results From a Randomized Controlled Trial Comparing Methotrexate and Gold Sodium Thiomalate. British journal of rheumatology. 1998;37(11):1220-6. [pmid: 9851273].
511 Rau R, Wassenberg S, Zeidler H. Low Dose Prednisolone Therapy (LDPT) Retards Radiographically Detectable Destruction in Early Rheumatoid Arthritis--Preliminary Results of a Multicenter, Randomized, Parallel, Double Blind Study. Zeitschrift für Rheumatologie. 2000;59(Supple 2):II/90-6.
512 Reece RJ, Kraan MC, Radjenovic A, et al. Comparative Assessment of Leflunomide and Methotrexate for the Treatment of Rheumatoid Arthritis, by Dynamic Enhanced Magnetic Resonance Imaging. Arthritis and rheumatism. 2002;46(2):366-72. [pmid: 11840438].
513 Reginster J, Distel M, Bluhmki E. A Double-Blind, Three-Week Study to Compare the Efficacy and Safety of Meloxicam 7.5 Mg and Meloxicam 15 Mg in Patients With Rheumatoid Arthritis. British journal of rheumatology. 1996;35(Suppl 1):17-21. [pmid: 8630631].
514 Rell Bakalarska M, Filipowicz Sosnowska A, Garwolinska H, et al. Assessment of the Results of Combined Treatment With Cyclophosphamide and Prednisone or Methotrexate and Prednisone in Patients With Rheumatoid Arthritis With Concomitant Vasculitis. Reumatologia. 1998;36(1):15-22.
515 Rheumatoid Arthritis Clinical Trial Archive Group. The Effect of Age and Renal Function on the Efficacy and Toxicity of Methotrexate in Rheumatoid Arthritis. J Rheumatol. 1995;22(2):218-23. [pmid: 7738941].
516 Rigopoulos D, Gregoriou S, Lazaridou E, et al. Treatment of nail psoriasis with adalimumab: An open label unblinded study: ORIGINAL ARTICLE. Journal of the European Academy of Dermatology and Venereology. 2010;24(5):530-4. [pmid: 19807825].
517 Robak T, Gladalska A, Stepien H. The Tumour Necrosis Factor Family of Receptors/Ligands in the Serum of Patients With Rheumatoid Arthritis. European cytokine network. 1998;9(2):145-54. [pmid: 9681390].
518 Robinson AJ, Taylor DH, Wright GD. Infliximab therapy reduces periodontoid rheumatoid pannus formation [5]. Rheumatology. 2008;47(2):225-6. [pmid: 18056149].
519 Rodriguez de la Serna A, Geli Ferrer C, Diaz Lopez C, et al. Comparative Double-Blind Study of Droxicam (New Nsaid) Versus Indomethacin in Rheumatoid Arthritis. European journal of rheumatology and inflammation. 1991;11(4):35-44. [pmid: 1365489].
520 Rozman B. Clinical Experience With Leflunomide in Rheumatoid Arthritis. The Journal of rheumatology. 1998;52(Suppl):27-32. [pmid: 9666415].
521 Rubbert-Roth A, Tak PP, Zerbini C, et al. Efficacy and safety of various repeat treatment dosing regimens of rituximab in patients with active rheumatoid arthritis: Results of a Phase III randomized study (MIRROR). Rheumatology. 2010;49(9):1683-93. [pmid: 20463186].
522 Russell AS, Wallenstein GV, Li T, et al. Abatacept improves both the physical and mental health of patients with rheumatoid arthritis who have inadequate response to methotrexate treatment. Ann Rheum Dis. Feb. 2007;66(2):189-94. [pmid: 16984942].
523 Sacerdote P, Carrabba M, Galante A, et al. Plasma and Synovial Fluid Interleukin-1, Interleukin-6 and Substance P Concentrations in Rheumatoid Arthritis Patients: Effect of the Nonsteroidal Anti Inflammatory Drugs Indomethacin, Diclofenac and Naproxen. Inflammation research : official journal of the European Histamine Research Society [et al]. 1995;44(11):486-90.
524 Salaffi F, Filippucci E, Carotti M, et al. Inter-observer agreement of standard joint counts in early rheumatoid arthritis: A comparison with grey scale ultrasonography - A preliminary study. Rheumatology. 2008;47(1):54-8. [pmid: 18037688].
525 Salemi S, Picchianti-Diamanti A, Germano V, et al. Influenza vaccine administration in rheumatoid arthritis patients under treatment with TNF(alpha) blockers: Safety and immunogenicity. Clinical Immunology. 2010;134(2):113-20. [pmid: 19846344].
526 Salvarani C, Macchioni P, Manzini C, et al. Infliximab plus prednisone or placebo plus prednisone for the initial treatment of polymyalgia rheumatica: a randomized trial. Annals of internal medicine. 2007;(9):631-9. [pmid: 17470831].
527 Sanchez Andrada S, Rodriguez Valverde V. A Double-Blind Randomised Controlled Trial of Droxicam Versus Indomethacin in Rheumatoid Arthritis. European journal of rheumatology and inflammation. 1991;11(4):35-44. [pmid: 1365489].
528 Sander O, Rau R. Treatment of Refractory Rheumatoid Arthritis With a Tumor Necrosis Factor Alpha Receptor Fusion Protein (Tnfr 55-Igg1) - a Monocentric Observation in 80 Patients. Zeitschrift fur Rheumatologie. 1998;57(5):307-11. [pmid: 9864836].
529 Sands BE, Kozarek R, Spainhour J, et al. Safety and tolerability of concurrent natalizumab treatment for patients with Crohn’s disease not in remission while receiving infliximab. Inflammatory bowel diseases. 2007;(1):2-11. [pmid: 17206633].
530 Sany J, Anaya JM, Canovas F, et al. Influence of Methotrexate on the Frequency of Postoperative Infectious Complications in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1993;20(7):1129-32. [pmid: 8371204].
531 Sarzi Puttini P, Santandrea S, Boccassini L, et al. The Role of Nsaids in Psoriatic Arthritis: Evidence From a Controlled Study With Nimesulide. Clinical and experimental rheumatology. 2001;19(1 Suppl 22):S17-20. [pmid: 11296544].
532 Sasso E, Merrill C, Furst T. Immunoglobulin Binding Properties of the Prosorba Immunadsorption Column in Treatment of Rheumatoid Arthritis. Ther Apher. 2001;5(2):84-91. [pmid: 11354304].
533 Saul P, Korlipara K. Acemetacin and Indomethacin in the Treatment of Rheumatoid Arthritis: a Double-Blind Comparative Study in General Practice. Current medical research and opinion. 1991;12(5):332-41. [pmid: 2004546].
534 Savolainen E, Kautiainen H, Koivula MK, et al. Change of diagnoses and outcome of patients with early inflammatory joint diseases during a mean 13-month follow-up. Scandinavian Journal of Rheumatology. 2007;36(3):194-7. [pmid: 17657673].
535 Schattenkirchner M. Double-Blind Comparison of Etodolac and Piroxicam in Patients With Rheumatoid Arthritis. Curr Med Res Opin. 1991;12(8):497-506. [pmid: 1837260].
536 Scheel AK, Hermann KGA, Ohrndorf S, et al. Prospective 7 year follow up imaging study comparing radiography, ultrasonography, and magnetic resonance imaging in rheumatoid arthritis finger joints. Annals of the Rheumatic Diseases. 2006;65(5):595-600. [pmid: 16192290].
537 Schiff MH. Role of Interleukin 1 and Interleukin 1 Receptor Antagonist in the Mediation of Rheumatoid Arthritis. Ann Rheum Dis. 2000;59(Suppl 1):i103-8. [pmid: 11053099].
538 Schirmer M, Mur E, Pfeiffer K, et al. The Safety Profile of Low-Dose Cladribine in Refractory Rheumatoid Arthritis. A Pilot Trial. Scandinavian journal of rheumatology. 1997;26(5):376-9. [pmid: 9385350].
539 Schlumpf U, Hofmann P. Comparison of Medium- and High-Dose Methylprednisolone Pulse Therapy in Rheumatoid Arthritis. Zeitschrift fur Rheumatologie. 1990;49(3):160-4. [pmid: 2378175].
540 Schmajuk G, Schneeweiss S, Katz JN, et al. Treatment of older adult patients diagnosed with rheumatoid arthritis: Improved but not optimal. Arthritis Care and Research. 2007;57(6):928-34. [pmid: 17665462].
541 Schnabel A, Herlyn K, Burchardi C, et al. Long-Term Tolerability of Methotrexate at Doses Exceeding 15 Mg Per Week in Rheumatoid Arthritis. Rheumatology international. 1996;15(5):195-200. [pmid: 8717103].
542 Schnabel A, Reinhold K, Willmann V, et al. Side Effects and Efficacy of 15 Mg and 25 Mg Methotrexate Per Week in Rheumatoid Arthritis. Z RHEUMATOL. 1994;53(3):142-9. [pmid: 8091868].
543 Schnabel A, Reinhold Keller E, Willmann V, et al. Tolerability of Methotrexate Starting With 15 or 25 Mg/Week for Rheumatoid Arthritis. Rheumatology international. 1994;14(1):33-8. [pmid: 7939138].
544 Schnitzer TJ, Truitt K, Fleischmann R, et al. The Safety Profile, Tolerability, and Effective Dose Range of Rofecoxib in the Treatment of Rheumatoid Arthritis. Clinical Therapeutics. 1999;21(10):1688-702. [pmid: 10566565].
545 Schrohenloher R, Koopman W, Woodworth T, et al. Suppression of in Vitro IgM Rheumatoid Factor Production by Diphtheria Toxin Interleukin 2 Recombinant Fusion Protein (Dab 486il-2) in Patients With Refractory Rheumatoid Arthritis. The Journal of rheumatology. 1996;23(11):1845-8. [pmid: 8923354].
546 Schuerwegh AJ, van Offel JF, Bridts CH, et al. Influence of Longterm Therapy With Methotrexate and Low Dose Corticosteroids on Type 1 and Type 2 Cytokine Production in Cd4+ and Cd8+ T Lymphocytes of Patients With Rheumatoid Arthritis. The Journal of rheumatology. 2001;28(8):1793-9. [pmid: 11508581].
547 Schuerwegh AJ, Van Offel JF, Stevens WJ, et al. Influence of Therapy With Chimeric Monoclonal Tumour Necrosis Factor-Alpha Antibodies on Intracellular Cytokine Profiles of T Lymphocytes and Monocytes in Rheumatoid Arthritis Patients. Rheumatology (Oxford). 2003;42(4):541-8. [pmid: 12649401].
548 Schwartz JI, Agrawal NG, Wong PH, et al. Lack of Pharmacokinetic Interaction Between Rofecoxib and Methotrexate in Rheumatoid Arthritis Patients. Journal of clinical pharmacology. 2001;41(10):1120-30. [pmid: 11583481].
549 Scott BL, Ramakrishnan A, Fosdal M, et al. Anti-thymocyte globulin plus etanercept as therapy for myelodysplastic syndromes (MDS): A phase II study. British Journal of Haematology. 2010;149(5):706-10. [pmid: 20331464].
550 Scott DL. Leflunomide Improves Quality of Life in Rheumatoid Arthritis. Scandinavian journal of rheumatology Supplement. 1999;112:23-9. [pmid: 10668524].
551 Scott DL, Smolen JS, Kalden JR, et al. Treatment of Active Rheumatoid Arthritis With Leflunomide: Two Year Follow up of a Double Blind, Placebo Controlled Trial Versus Sulfasalazine. Annals of the rheumatic diseases. 2001;60(10):913-23. [pmid: 11557646].
552 Seideman P. Additive Effect of Combined Naproxen and Paracetamol in Rheumatoid Arthritis. British journal of rheumatology. 1993;32(12):1077-82. [pmid: 8252318].
553 Seideman P. Better Effect of Methotrexate on C-Reactive Protein During Daily Compared to Weekly Treatment in Rheumatoid Arthritis. Clinical rheumatology. 1993;12(2):347-9.
554 Seideman P, Beck O, Eksborg S, et al. The Pharmacokinetics of Methotrexate and Its 7-Hydroxy Metabolite in Patients With Rheumatoid Arthritis. British journal of clinical pharmacology. 1993;35(4):409-12. [pmid: 8485020].
555 Seppala E, Nissila M, Isomaki H, et al. Effects of Non-Steroidal Anti-Inflammatory Drugs and Prednisolone on Synovial Fluid White Cells, Prostaglandin E2, Leukotriene B4 and Cyclic Amp in Patients With Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1990;19(1):71-5. [pmid: 2155476].
556 Sharif M, Salisbury C, Taylor D, et al. Changes in Biochemical Markers of Joint Tissue Metabolism in a Randomized Controlled Trial of Glucocorticoid in Early Rheumatoid Arthritis. Arthritis and rheumatism. 1998;41(7):1203-9. [pmid: 9663476].
557 Sharp JT, Strand V, Leung H, et al. Treatment With Leflunomide Slows Radiographic Progression of Rheumatoid Arthritis: Results From Three Randomized Controlled Trials of Leflunomide in Patients With Active Rheumatoid Arthritis. Arthritis and rheumatism. 2000;43(3):495-505. [pmid: 10728741].
558 Shashikumar NS, Shivamurthy MC, Chandrashekara S. Evaluation of efficacy of combination of methotrexate and hydroxychloroquine with leflunomide in active rheumatoid arthritis. Indian Journal of Pharmacology. 2010;42(6):358-61. [pmid: 21189905].
559 Sheeran T, Roobottom C, Wanklyn P, et al. The Effect of Bed Rest and Intra-Articular Steroids on the Acute Phase Response in Rheumatoid Arthritis. Clinical and experimental rheumatology. 1993;11(1):49-52. [pmid: 8453797].
560 Sheldon P. Ileum-Targeted Steroid Therapy in Rheumatoid Arthritis: Double-Blind, Placebo-Controlled Trial of Controlled-Release Budesonide. Rheumatology international. 2003;23(4):154-8. [pmid: 12856138].
561 Shi W, Wang Y, Li L, et al. Safety and Efficacy of Oral Nonsteroidal Anti-Inflammatory Drugs in Patients With Rheumatoid Arthritis: a Six-Month Randomised Study. Clinical Drug Investigation. 2004;24(2):89-101. [pmid: 17516695].
562 Shikiar R, Heffernan M, Langley RG, et al. Adalimumab treatment is associated with improvement in health-related quality of life in psoriasis: patient-reported outcomes from a phase II randomized controlled trial. The Journal of dermatological treatment. 2007;(1):25-31. [pmid: 17365264].
563 Shiokawa Y, Shichikawa K, Nobunaga M, et al. Clinical Study of a New Anti-Rheumatic Drug, Ms-932 on Rheumatoid Arthritis: Double-Blind Comparative Study With Placebo. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1991;7(Suppl 2):113-47.
564 Shiozawa S, Shiozawa K, Kita M, et al. A Preliminary Study on the Effect of Alpha-Interferon Treatment on the Joint Inflammation and Serum Calcium in Rheumatoid Arthritis. British journal of rheumatology. 1992;31(6):405-8. [pmid: 1596703].
565 Shiroky J, Neville C, Skelton J. High Dose Intravenous Methotrexate for Refractory Rheumatoid Arthritis. The Journal of rheumatology. 1992;19(2):247-51. [pmid: 1629823].
566 Shiroky JB, Neville C, Esdaile JM, et al. Low-Dose Methotrexate With Leucovorin (Folinic Acid) in the Management of Rheumatoid Arthritis. Results of a Multicenter Randomized, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 1993;36(6):795-803. [pmid: 8507221].
567 Siddiqui AK, Huberfeld SI, Weidenheim KM, et al. Hydroxychloroquine-induced toxic myopathy causing respiratory failure. Chest. 2007;131(2):588-90. [pmid: 17296665].
568 Sieper J, Fendler C, Laitko S, et al. No Benefit of Long-Term Ciprofloxacin Treatment in Patients With Reactive Arthritis and Undifferentiated Oligoarthritis: a Three-Month, Multicenter, Double-Blind, Randomized, Placebo-Controlled Study. Arthritis and rheumatism. 1999;42(7):1386-96. [pmid: 10403266].
569 Sigidin Y, Loukina G, Skurkovich B, et al. Randomized, Double-Blind Trial of Anti-Interferon-Gamma Antibodies in Rheumatoid Arthritis. Scandinavian journal of rheumatology. 2001;30(4):203-7. [pmid: 11578014].
570 Silverstein FE, Graham DY, Senior JR, et al. Misoprostol Reduces Serious Gastrointestinal Complications in Patients With Rheumatoid Arthritis Receiving Nonsteroidal Anti-Inflammatory Drugs. A Randomized, Double-Blind, Placebo-Controlled Trial. Annals of internal medicine. 1995;123(4):241-9. [pmid: 7611589].
571 Simon F, Parola P, Grandadam M, et al. Chikungunya infection: An emerging rheumatism among travelers returned from Indian Ocean islands. Report of 47 cases. Medicine. 2007;86(3):123-37. [pmid: 17505252].
572 Simon L, Robinson D, Basch C. Naproxen Levels in Plasma and Synovial Fluid of Patients With Rheumatoid Arthritis. CLIN THER. 1991;13(Suppl A):35-43.
573 Simon LS, Weaver AL, Graham DY, et al. Anti-Inflammatory and Upper Gastrointestinal Effects of Celecoxib in Rheumatoid Arthritis: a Randomized Controlled Trial. JAMA. 1999;282(20):1921-8. [pmid: 10580457].
574 Slaughter JR, Parker JC, Martens MP, et al. Clinical Outcomes Following a Trial of Sertraline in Rheumatoid Arthritis. Psychosomatics. 2002;43(1):36-41. [pmid: 11927756].
575 Smieja M, MacPherson DW, Kean W, et al. Randomised, Blinded, Placebo Controlled Trial of Doxycycline for Chronic Seronegative Arthritis. Annals of the rheumatic diseases. 2001;60(12):1088-94. [pmid: 11709448].
576 Smith AM, Sperling JW, O’Driscoll SW, et al. Arthroscopic shoulder synovectomy in patients with rheumatoid arthritis. Arthroscopy Journal of Arthroscopic and Related Surgery. 2006;22(1):50-6.
577 Smith DM, Johnson JA, Loeser R, et al. Evaluation of Tenidap (Cp-66,248) on Human Neutrophil Arachidonic Acid Metabolism, Chemotactic Potential and Clinical Efficacy in the Treatment of Rheumatoid Arthritis. Agents and actions. 1990;31(1–2):102-9. [pmid: 2126672].
578 Smolen J, Emery P. Efficacy and Safety of Leflunomide in Active Rheumatoid Arthritis. Rheumatology. 2000;39(Suppl 1):48-56. [pmid: 11001380].
579 Smolen JS. Efficacy and Safety of the New Dmard Leflunomide: Comparison to Placebo and Sulfasalazine in Active Rheumatoid Arthritis. Scandinavian journal of rheumatology Supplement. 1999;112:15-21. [pmid: 10668523].
580 Smolen JS, Kalden JR, Scott DL, et al. Efficacy and Safety of Leflunomide Compared With Placebo and Sulphasalazine in Active Rheumatoid Arthritis: a Double-Blind, Randomised, Multicentre Trial. Lancet. 1999;353(9149):259-66. [pmid: 9929017].
581 Snowden JA, Biggs JC, Milliken ST, et al. A Randomised, Blinded, Placebo-Controlled, Dose Escalation Study of the Tolerability and Efficacy of Filgrastim for Haemopoietic Stem Cell Mobilisation in Patients With Severe Active Rheumatoid Arthritis. Bone marrow transplantation. 1998;22(11):1035-41. [pmid: 9877264].
582 Soderlin MK, Geborek P. Changing pattern in the prescription of biological treatment in rheumatoid arthritis. A 7-year follow-up of 1839 patients in southern Sweden. Annals of the Rheumatic Diseases. 2008;67(1):37-42. [pmid: 19623680].
583 Song YW, Lee EY, Koh EM, et al. Assessment of comparative pain relief and tolerability of SKI306X compared with celecoxib in patients with rheumatoid arthritis: A 6-week, multicenter, randomized, double-blind, double-dummy, phase III, noninferiority clinical trial. Clinical Therapeutics. 2007;29(5):862-73. [pmid: 17697905].
584 Spalding SJ, Kent CK, Boudreau R, et al. Three-dimensional and thermal surface imaging produces reliable measures of joint shape and temperature: A potential tool for quantifying arthritis. Arthritis Research and Therapy. 2008;10(1).
585 Sreekanth V, Handa R, Wali J, et al. Doxycycline in the Treatment of Rheumatoid Arthritis--a Pilot Study. The Journal of the Association of Physicians of India. 2000;48(8):804-7. [pmid: 11273473].
586 St Clair EW, Cohen SB, Lee ML, et al. Treatment of Rheumatoid Arthritis With a Dr4/1 Peptide. The Journal of rheumatology. 2000;27(8):1855-63. [pmid: 10955324].
587 St Clair EW, Wagner CL, Fasanmade AA, et al. The Relationship of Serum Infliximab Concentrations to Clinical Improvement in Rheumatoid Arthritis: Results From Attract, a Multicenter, Randomized, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 2002;46(6):1451-9. [pmid: 12115174].
588 Steen KSS, Nurmohamed MT, Visman I, et al. Decreasing incidence of symptomatic gastrointestinal ulcers and ulcer complications in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 2008;67(2):256-9. [pmid: 17604285].
589 Stenberg VI, Fiechtner JJ, Rice JR, et al. Endocrine Control of Inflammation: Rheumatoid Arthritis Double-Blind, Crossover Clinical Trial. International journal of clinical pharmacology research. 1992;12(1):11-8. [pmid: 1526694].
590 Stewart C, Fleming R, Arkin C, et al. Coadministration of Naproxen and Low-Dose Methotrexate in Patients With Rheumatoid Arthritis. Clinical Pharmacology & Therapeutics. 1990;47(4):540-6. [pmid: 2328562].
591 Stichenwirth M, Riedl E, Pehamberger H, et al. Pyoderma Gangrenosum in a patient with seronegative rheumatoid arthritis during therapy with adalimumab: Toxic effects of adalimumab or failure of adalimumab to prevent the onset of this phenomenon?. Archives of Dermatology. 2008;144(6):817-8. [pmid: 18559788].
592 Stoch SA, Saag KG, Greenwald M, et al. Once-weekly oral alendronate 70 mg in patients with glucocorticoid-induced bone loss: A 12-month randomized, placebo-controlled clinical trial. 2009.
593 Strand V, Cohen S, Schiff M, et al. Treatment of Active Rheumatoid Arthritis With Leflunomide Compared With Placebo and Methotrexate. Archives of Internal Medicine. 1999;159(21):2542-50. [pmid: 10573044].
594 Stubenrauch K, Wessels U, Birnboeck H, et al. Subset analysis of patients experiencing clinical events of a potentially immunogenic nature in the pivotal clinical trials of tocilizumab for rheumatoid arthritis: Evaluation of an antidrug antibody ELISA using clinical adverse event-driven immunogenicity testing. Clinical Therapeutics. 2010;32(9):1597-609. [pmid: 20974317].
595 Suarez Almazor M, Russell A. Parenteral Methotrexate or Gold for Rheumatoid Arthritis: a Follow up. Clinical & Experimental Rheumatology. 1990;8(2):163-6. [pmid: 2110877].
596 Subbanna PKT, Chandy SJ, Danda D, et al. Correlation between serum methotrexate concentrations and disease remission status in rheumatoid arthritis patients on triple disease-modifying antirheumatic drug therapy [1]. Indian Journal of Pharmacology. 2007;39(2):117-8.
597 Sugiura F, Kojima T, Oguchi T, et al. A case of peripheral neuropathy and skin ulcer in a patient with rheumatoid arthritis after a single infusion of tocilizumab. Modern Rheumatology. 2009;19(2):199-203. [pmid: 18987779].
598 Sundal E, Bertelletti D. Thymopentin Treatment of Rheumatoid Arthritis. Progress in drug research Fortschritte der Arzneimittelforschung Progrès des recherches pharmaceutiques. 1994;44(10):1145-9.
599 Suzuki A, Yamada R, Ohtake-Yamanaka M, et al. Anti-Citrullinated Collagen Type I Antibody Is a Target of Autoimmunity in Rheumatoid Arthritis. Biochemical and biophysical research communications. 2005;333(2):418-26. [pmid: 15950180].
600 Svensson B, Boonen A, Albertsson K, et al. Low-Dose Prednisolone in Addition to the Initial Disease-Modifying Antirheumatic Drug in Patients With Early Active Rheumatoid Arthritis Reduces Joint Destruction and Increases the Remission Rate: a Two-Year Randomized Trial. Arthritis and rheumatism. 2005;52(11):3360-70. [pmid: 16255010].
601 Symmons D, Tricker K, Harrison M, et al. Patients with stable long-standing rheumatoid arthritis continue to deteriorate despite intensified treatment with traditional disease modifying anti-rheumatic drugs - Results of the British Rheumatoid Outcome Study Group randomized controlled clinical trial. Rheumatology. 2006;45(5):558-65. [pmid: 16263778].
602 Symmons D, Tricker K, Roberts C, et al. The British Rheumatoid Outcome Study Group (Brosg). Randomised Controlled Trial to Compare the Effectiveness and Cost-Effectiveness of Aggressive Versus Symptomatic Therapy in Established Rheumatoid Arthritis. Health Technol Assess. 2005;9(34):iii-iv. ix. x. 1. 78.
603 Szmyrka-Kaczmarek M, Nowak B, Swierkot J, et al. Antinuclear antibodies and anti-cyclic citrullinated peptide antibodies in patients treated with adalimumab. Central European Journal of Immunology. 2008;33(3):120-6.
604 Taha AS, McLaughlin S, Holland PJ, et al. Effect on Gastric and Duodenal Mucosal Prostaglandins of Repeated Intake of Therapeutic Doses of Naproxen and Etodolac in Rheumatoid Arthritis. Annals of the rheumatic diseases. 1990;49(6):354-8. [pmid: 2143369].
605 Tak PP, Taylor PC, Breedveld FC, et al. Decrease in cellularity and expression of adhesion molecules by anti-tumor necrosis factor alpha monoclonal antibody treatment in patients with rheumatoid arthritis. Arthritis and rheumatism. 1996;39(7):1077-81. [pmid: 8670314].
606 Tak PP, van der Lubbe PA, Cauli A, et al. Reduction of Synovial Inflammation After Anti-Cd4 Monoclonal Antibody Treatment in Early Rheumatoid Arthritis. Arthritis and rheumatism. 1995;38(10):1457-65. [pmid: 7575695].
607 Takada K, Danning C, Kuroiwa T, et al. Lymphocyte Depletion With Fludarabine in Patients With Psoriatic Arthritis: Clinical and Immunological Effects. Annals of the rheumatic diseases. 2003;62(11):1112-5. [pmid: 14583577].
608 Takahashi M, Suzuki M, Kushida K, et al. Relationship Between Pentosidine Levels in Serum and Urine and Activity in Rheumatoid Arthritis. British journal of rheumatology. 1997;36(6):637-42. [pmid: 9236672].
609 Tanno M, Nakamura I, Kobayashi S, et al. New-onset demyelination induced by infliximab therapy in two rheumatoid arthritis patients. Clinical Rheumatology. 2006;25(6):929-33. [pmid: 16328088].
610 Taukumova L, Mouravjoy Y, Gribakin S. Mucocutaneous Side Effects and Continuation of Aurotherapy in Patients With Rheumatoid Arthritis. Advances in experimental medicine and biology. 1999;455:367-73. [pmid: 10599371].
611 Taylor P, Steuer A, Gruber J, et al. Ultrasonographic and radiographic results from a two-year controlled trial of immediate or one-year-delayed addition of infliximab to ongoing methotrexate therapy in patients with erosive early rheumatoid arthritis. Arthritis and rheumatism. 2006;54(1):47-53. [pmid: 16385521].
612 Taylor PC, Steuer A, Gruber J, et al. Comparison of Ultrasonographic Assessment of Synovitis and Joint Vascularity With Radiographic Evaluation in a Randomized, Placebo-Controlled Study of Infliximab Therapy in Early Rheumatoid Arthritis. Arthritis and rheumatism. 2004;50(4):1107-16. [pmid: 15077292].
613 Tebib J, Mariette X, Bourgeois P, et al. Masitinib in the treatment of active rheumatoid arthritis: Results of a multicentre, open-label, dose-ranging, phase 2a study. 2009.
614 Tebib JG, Manil LM, Modder G, et al. Better Results With Rhenium-186 Radiosynoviorthesis Than With Cortivazol in Rheumatoid Arthritis (Ra): a Two-Year Follow-up Randomized Controlled Multicentre Study. Clinical and experimental rheumatology. 2004;22(5):609-16. [pmid: 15485015].
615 Tegelberg A, Kopp S. A 3-Year Follow-up of Temporomandibular Disorders in Rheumatoid Arthritis and Ankylosing Spondylitis. Acta odontologica Scandinavica. 1996;54(1):14-8. [pmid: 8669235].
616 Teir J, Koduri G, Meadows A, et al. An audit of recording cardiovascular risk factors in patients with rheumatoid arthritis and systemic lupus erythematosus in centres in East Anglia and the South East. Rheumatology. 2008;47(8):1252-4. [pmid: 18573801].
617 ten Klooster PM, Drossaers-Bakker KW, Taal E, et al. Can we assess baseline pain and global health retrospectively?. Clinical and Experimental Rheumatology. 2007;25(2):176-81. [pmid: 17543139].
618 Ten Klooster PM, Veehof MM, Taal E, et al. Changes in priorities for improvement in patients with rheumatoid arthritis during 1 year of anti-tumour necrosis factor treatment. Annals of the Rheumatic Diseases. 2007;66(11):1485-90. [pmid: 17472993].
619 ten Wolde S, Breedveld FC, Hermans J, et al. Randomised Placebo-Controlled Study of Stopping Second-Line Drugs in Rheumatoid Arthritis. Lancet. 1996;347(8998):347-52. [pmid: 8598699].
620 Tenembaum SN. Therapy of multiple sclerosis in children and adolescents. Clinical Neurology and Neurosurgery. 2010;112(7):633-40. [pmid: 20471159].
621 Tesser J, Fleischmann R, Dore R, et al. Concomitant Medication Use in a Large, International, Multicenter, Placebo Controlled Trial of Anakinra, a Recombinant Interleukin 1 Receptor Antagonist, in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 2004;31(4):649-54. [pmid: 15088288].
622 Tett S, Cutler D, Beck C, et al. Concentration-Effect Relationship of Hydroxychloroquine in Patients With Rheumatoid Arthritis--a Prospective, Dose Ranging Study. The Journal of rheumatology. 2000;27(7):1656-60. [pmid: 10914847].
623 The Australian Multicentre Clinical Trial Group. Sulfasalazine in Early Rheumatoid Arthritis. J Rheumatol. 1992;7;19(11):1672.
624 Thurlings RM, Boumans M, Tekstra J, et al. Relationship between the type I interferon signature and the response to rituximab in rheumatoid arthritis patients. Arthritis Care and Research. 2010;62(12):3607-14. [pmid: 20722020].
625 Tikiz C, Utuk O, Pirildar T, et al. Effects of Angiotensin-Converting Enzyme Inhibition and Statin Treatment on Inflammatory Markers and Endothelial Functions in Patients With Longterm Rheumatoid Arthritis. The Journal of rheumatology. 2005;32(11):2095-101. [pmid: 16265685].
626 Tilley BC, Alarcon GS, Heyse SP, et al. Minocycline in Rheumatoid Arthritis. A 48-Week, Double-Blind, Placebo-Controlled Trial. Mira Trial Group. Annals of internal medicine. 1995;122(2):81-9. [pmid: 7993000].
627 Torsteinsdottir I, Groth T, UL. Production and Elimination of Hyaluronan in Rheumatoid Arthritis Patients: Estimation With a Loading Test. Seminars in arthritis and rheumatism. 1999;28(4):268-79. [pmid: 10073501].
628 Toussirot E, Pertuiset E, Kantelip B, et al. Sarcoidosis occuring during anti-TNF-alpha treatment for inflammatory rheumatic diseases: Report of two cases. Clinical and Experimental Rheumatology. 2008;26(3):471-5. [pmid: 18578973].
629 Tracy T, Worster T, Bradley J, et al. Methotrexate Disposition Following Concomitant Administration of Ketoprofen, Piroxicam and Flurbiprofen in Patients With Rheumatoid Arthritis. British journal of clinical pharmacology. 1994;37(5):453-6. [pmid: 8054251].
630 Tugwell P, Bombardier C, Buchanan WW, et al. Methotrexate in Rheumatoid Arthritis. Impact on Quality of Life Assessed by Traditional Standard-Item and Individualized Patient Preference Health Status Questionnaires. Archives of internal medicine. 1990;150(1):59-62. [pmid: 2404483].
631 Turiel M, Tomasoni L, Sitia S, et al. Effects of long-term disease-modifying antirheumatic drugs on endothelial function in patients with early rheumatoid arthritis. Cardiovascular Therapeutics. 2010;28(5):e53-e64. [pmid: 20337633].
632 Tutuncu Z, Kavanaugh A. Treatment of elderly rheumatoid arthritis. Future Rheumatology. 2007;2(3):313-9.
633 Uddenfeldt P, Leden I, Rubin B. A Double-Blind Comparison of Oral Ketoprofen ‘controlled Release’ and Indomethacin Suppository in the Treatment of Rheumatoid Arthritis With Special Regard to Morning Stiffness and Pain on Awakening. Current medical research and opinion. 1993;13(3):127-32. [pmid: 8222739].
634 Uutela T, Hannonen P, Kautianen H, et al. Positive treatment response improves the health-ralated quality of life of patients with early rheumatiod arthritis. Clinical and Experimental Rheumatology. 2009;27(1):108-11. [pmid: 19327237].
635 Valleala H, Laasonen L, Koivula M-K, et al. Two Year Randomized Controlled Trial of Etidronate in Rheumatoid Arthritis: Changes in Serum Aminoterminal Telopeptides Correlate With Radiographic Progression of Disease. The Journal of rheumatology. 2003;30(3):468-73. [pmid: 12610803].
636 Valleala H, Laitinen K, Pylkkanen L, et al. Clinical and Biochemical Response to Single Infusion of Clodronate in Active Rheumatoid Arthritis - Double Blind Placebo Controlled Study. Inflammation Research. 2001;50(12):598-601. [pmid: 11822785].
637 Van Aken J, Van Dongen H, Le Cessie S, et al. Comparison of long term outcome of patients with rheumatoid arthritis presenting with undifferentiated arthritis or with rheumatoid arthritis: An observational cohort study. Annals of the Rheumatic Diseases. 2006;65(1):20-5. [pmid: 15901632].
638 van Berlo WTM, van de Wiel HBM, Taal E, et al. Sexual functioning of people with rheumatoid arthritis: A multicenter study. Clinical Rheumatology. 2007;26(1):30-8. [pmid: 16508697].
639 Van Den Bemt BJF, Van Den Hoogen FHJ, Benraad B, et al. Adherence rates and associations with nonadherence in patients with rheumatoid arthritis using disease modifying antirheumatic drugs. 2009.
640 Van Der Bijl AE, Teng YKO, Van Oosterhout M, et al. Efficacy of intraarticular infliximab in patients with chronic or recurrent gonarthritis: A clinical randomized trial. 2009.
641 Van Der Heijde D, Breedveld FC, Kavanaugh A, et al. Disease activity, physical function, and radiographic progression after longterm therapy with adalimumab plus methotrexate: 5-Year results of PREMIER. Journal of Rheumatology. 2010;37(11):2237-46. [pmid: 20889601].
642 Van Der Kooij SM, Goekoop-Ruiterman YPM, De Vries-Bouwstra JK, et al. Probability of continued low disease activity in patients with recent onset rheumatoid arthritis treated according to the disease activity score. Annals of the Rheumatic Diseases. 2008;67(2):266-9. [pmid: 17947301].
643 van der Lubbe PA, Dijkmans BA, Markusse HM, et al. A Randomized, Double-Blind, Placebo-Controlled Study of Cd4 Monoclonal Antibody Therapy in Early Rheumatoid Arthritis. Arthritis and rheumatism. 1995;38(8):1097-106. [pmid: 7639806].
644 van der Lubbe PA, Reiter C, Breedveld FC, et al. Chimeric Cd4 Monoclonal Antibody Cm-T412 as a Therapeutic Approach to Rheumatoid Arthritis. Arthritis and rheumatism. 1993;36(10):1375-9. [pmid: 8216397].
645 van der Lubbe PA, Reiter C, Miltenburg AM, et al. Treatment of Rheumatoid Arthritis With a Chimeric Cd4 Monoclonal Antibody (Cm-T412): Immunopharmacological Aspects and Mechanisms of Action. Scandinavian journal of immunology. 1994;39(3):286-94. [pmid: 8128188].
646 van der Veen M, Bijlsma J. The Effect of Methylprednisolone Pulse Therapy on Methotrexate Treatment of Rheumatoid Arthritis. Clinical rheumatology. 1993;12(4):74-6.
647 van Ede AE, Laan RFJM, Blom HJ, et al. Homocysteine and Folate Status in Methotrexate-Treated Patients With Rheumatoid Arthritis. Rheumatology (Oxford). 2002;41(6):658-65. [pmid: 12048292].
648 Van Eijk Y, Boonen A, Schulpen G, et al. Safety and patient satisfaction of infliximab administration in an extramural setting supervised by a rheumatology specialist nurse. Annals of the Rheumatic Diseases. 2006;65(2).
649 van Everdingen AA, Jacobs JWG, Siewertsz Van Reesema DR, et al. Low-Dose Prednisone Therapy for Patients With Early Active Rheumatoid Arthritis: Clinical Efficacy, Disease-Modifying Properties, and Side Effects: a Randomized, Double-Blind, Placebo-Controlled Clinical Trial. Annals of internal medicine. 2002;136(1):1-12. [pmid: 11777359].
650 van Everdingen AA, Siewertsz van Reesema DR, Jacobs JWG, et al. Low-Dose Glucocorticoids in Early Rheumatoid Arthritis: Discordant Effects on Bone Mineral Density and Fractures?. Clinical and experimental rheumatology. 2003;21(2):155-60. [pmid: 12747268].
651 van Everdingen AA, Siewertsz van Reesema DR, Jacobs JWG, et al. The Clinical Effect of Glucocorticoids in Patients With Rheumatoid Arthritis May Be Masked by Decreased Use of Additional Therapies. Arthritis and rheumatism. 2004;51(2):217-20.
652 van Holten J, Pavelka K, Vencovsky J, et al. A Multicentre, Randomised, Double Blind, Placebo Controlled Phase Ii Study of Subcutaneous Interferon Beta-1a in the Treatment of Patients With Active Rheumatoid Arthritis. Ann Rheum Dis. 2005;64(1):64-9. [pmid: 15242865].
653 van Jaarsveld CH, Jacobs JW, van der Veen MJ, et al. Aggressive Treatment in Early Rheumatoid Arthritis: a Randomised Controlled Trial. Annals of the Rheumatic Diseases. 2000;59(6):468-77. [pmid: 10834865].
654 van Jaarsveld CH, Jahangier ZN, Jacobs JW, et al. Toxicity of Anti-Rheumatic Drugs in a Randomized Clinical Trial of Early Rheumatoid Arthritis. Rheumatology (Oxford). 2000;39(12):1374-82. [pmid: 11136881].
655 Van Kuijk AWR, Gerlag DM, Vos K, et al. A prospective, randomised, placebo-controlled study to identify biomarkers associated with active treatment in psoriatic arthritis: Effects of adalimumab treatment on synovial tissue. 2009.
656 Van Offel JF, Schuerwegh AJ, Bridts CH, et al. Influence of Cyclic Intravenous Pamidronate on Proinflammatory Monocytic Cytokine Profiles and Bone Density in Rheumatoid Arthritis Treated With Low Dose Prednisolone and Methotrexate. Clinical and experimental rheumatology. 2001;19(1):13-20. [pmid: 11247319].
657 Van Riel PLCM, Freundlich B, MacPeek D, et al. Patient-reported health outcomes in a trial of etanercept monotherapy versus combination therapy with etanercept and methotrexate for rheumatoid arthritis: The ADORE trial. Annals of the Rheumatic Diseases. 2008;67(8):1104-10. [pmid: 17666447].
658 van Roon J, Wijngaarden S, Lafeber FPJG, et al. Interleukin 10 Treatment of Patients With Rheumatoid Arthritis Enhances Fc Gamma Receptor Expression on Monocytes and Responsiveness to Immune Complex Stimulation. The Journal of rheumatology. 2003;30(4):648-51. [pmid: 12672180].
659 van Roon JA, van Roy JL, Gmelig-Meyling FH, et al. Prevention and Reversal of Cartilage Degradation in Rheumatoid Arthritis by Interleukin-10 and Interleukin-4. Arthritis and rheumatism. 1996;39(5):829-35. [pmid: 8639180].
660 van Schaardenburg D, Valkema R, Dijkmans BA, et al. Prednisone Treatment of Elderly-Onset Rheumatoid Arthritis. Disease Activity and Bone Mass in Comparison With Chloroquine Treatment. Arthritis and rheumatism. 1995;38(3):334-42. [pmid: 7880187].
661 Verdickt W, Moran C, Hantzschel H, et al. A Double-Blind Comparison of the Gastroduodenal Safety and Efficacy of Diclofenac and a Fixed Dose Combination of Diclofenac and Misoprostol in the Treatment of Rheumatoid Arthritis. Scandinavian journal of rheumatology. 1992;21(2):85-91. [pmid: 1570496].
662 Verhoef J, Toussaint PJ, Zwetsloot-Schonk JHM, et al. Effectiveness of the introduction of an international classification of functioning, disability and health-based rehabilitation tool in multidisciplinary team care in patients with rheumatoid arthritis. Arthritis Care and Research. 2007;57(2):240-8. [pmid: 17330301].
663 Verhoeven AC, Bibo JC, Boers M, et al. Cost-Effectiveness and Cost-Utility of Combination Therapy in Early Rheumatoid Arthritis: Randomized Comparison of Combined Step-Down Prednisolone, Methotrexate and Sulphasalazine With Sulphasalazine Alone. British journal of rheumatology. 1998;37(10):1102-9. [pmid: 9825750].
664 Verstappen S, Jacobs J, Bijlsma JW. The Utrecht Experience With Different Treatment Strategies in Early Rheumatoid Arthritis. Clinical and experimental rheumatology. 2003;21(5 Suppl 31):S165-8. [pmid: 14969070].
665 Verstappen S, van Albada Kuipers G, Bijlsma J, et al. A Good Response to Early Dmard Treatment of Patients With Rheumatoid Arthritis in the First Year Predicts Remission During Follow up. Ann Rheum Dis. 2005;64(1):38-43. [pmid: 15130899].
666 Verstappen SMM, Jacobs JWG, Bijlsma JWJ, et al. Five-Year Followup of Rheumatoid Arthritis Patients After Early Treatment With Disease-Modifying Antirheumatic Drugs Versus Treatment According to the Pyramid Approach in the First Year. Arthritis and rheumatism. 2003;48(7):1797-807. [pmid: 12847672].
667 Verstappen SMM, McCoy MJ, Roberts C, et al. Beneficial effects of a 3-week course of intramuscular glucocorticoid injections in patients with very early inflammatory polyarthritis: Results of the STIVEA trial. Annals of the rheumatic diseases. 2010;69(3):503-9. [pmid: 19825849].
668 Veys E, Menkes C, Emery P. A Randomized, Double-Blind Study Comparing Twenty-Four-Week Treatment With Recombinant Interferon-Gamma Versus Placebo in the Treatment of Rheumatoid Arthritis. Arthritis and rheumatism. 1997;40(1):62-8. [pmid: 9008601].
669 Vis M, Havaardsholm EA, Haugeberg G, et al. Evaluation of bone mineral density, bone metabolism, osteoprotegerin and receptor activator of the NFkappaB ligand serum levels during treatment with infliximab in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 2006;65(11):1495-9. [pmid: 16606653].
670 Vischer TL. Follow-up With Om-8980 After a Double-Blind Study of Om-8980 and Auranofin in Rheumatoid Arthritis. Clinical rheumatology. 1990;9(3):356-61. [pmid: 2261735].
671 Vlak T, Eldar R. Disability in Rheumatoid Arthritis After Monotherapy With Dmards. International Journal Rehabilitation Research. 2003;26(3):207-12.
672 von Scheele B, Pena B, Wong J, et al. Economic Evaluation of Oral Valdecoxib Versus Diclofenac in the Treatment of Patients With Rheumatoid Arthritis in a Randomized Clinical Trial. Rheumatology (Oxford). 2003;42(Suppl 3):iii53-9. [pmid: 14585918].
673 Wailoo AJ, Bansback N, Brennan A, et al. Biologie drugs for rheumatoid arthritis in the medicare program: A cost-effectiveness analysis. Arthritis and Rheumatism. 2008;58(4):939-46. [pmid: 18383356].
674 Wakefield D, McCluskey P, Verma M, et al. Ciprofloxacin Treatment Does Not Influence Course or Relapse Rate of Reactive Arthritis and Anterior Uveitis. Arthritis and rheumatism. 1999;42(9):1894-7. [pmid: 10513804].
675 Walitt B, Pettinger M, Weinstein A, et al. Effects of postmenopausal hormone therapy on rheumatoid arthritis: The women’s health initiative randomized controlled trials. Arthritis Care and Research. 2008;59(3):302-10. [pmid: 18311749].
676 Walsh JK, Muehlbach MJ, Lauter SA, et al. Effects of Triazolam on Sleep, Daytime Sleepiness, and Morning Stiffness in Patients With Rheumatoid Arthritis. The Journal of rheumatology. 1996;23(2):245-52. [pmid: 8882027].
677 Wassenberg S, Rau R, Steinfeld P, et al. Very Low-Dose Prednisolone in Early Rheumatoid Arthritis Retards Radiographic Progression Over Two Years: a Multicenter, Double-Blind, Placebo-Controlled Trial. Arthritis and rheumatism. 2005;52(11):3371-80. [pmid: 16255011].
678 Weinblatt M, Maier A, Coblyn J. Low Dose Leucovorin Does Not Interfere With the Efficacy of Methotrexate in Rheumatoid Arthritis: an 8 Week Randomized Placebo Controlled Trial. The Journal of rheumatology. 1993;20(6):950-2. [pmid: 8350329].
679 Weinblatt M, Maier A, Fraser P, et al. Longterm Prospective Study of Methotrexate in Rheumatoid Arthritis: Conclusion After 132 Months of Therapy. The Journal of rheumatology. 1988;25(2):238-42. [pmid: 9489813].
680 Weinblatt M, Polisson R, Blotner SD, et al. The Effects of Drug Therapy on Radiographic Progression of Rheumatoid Arthritis. Results of a 36-Week Randomized Trial Comparing Methotrexate and Auranofin. Arthritis and rheumatism. 1993;36(5):613-9. [pmid: 8489539].
681 Weinblatt M, Schiff M, Goldman A, et al. Selective costimulation modulation using abatacept in patients with active rheumatoid arthritis while receiving etanercept: a randomised clinical trial. Annals of the rheumatic diseases. 2007;(2):228-34. [pmid: 16935912].
682 Weinblatt ME, Kaplan H, Germain BF, et al. Methotrexate in Rheumatoid Arthritis. A Five-Year Prospective Multicenter Study. Arthritis and rheumatism. 1994;37(10):1492-8. [pmid: 7945475].
683 Weinblatt ME, Kaplan H, Germain BF, et al. Low-Dose Methotrexate Compared With Auranofin in Adult Rheumatoid Arthritis. A Thirty-Six-Week, Double-Blind Trial. Arthritis and rheumatism. 1990;33(3):330-8. [pmid: 2180405].
684 Weinblatt ME, Kaplan H, Germain BF, et al. Methotrexate in Rheumatoid Arthritis: Effects on Disease Activity in a Multicenter Prospective Study. The Journal of rheumatology. 1991;18(3):334-8. [pmid: 1856803].
685 Weinblatt ME, Kremer JM, Coblyn JS, et al. Zileuton, a 5-Lipoxygenase Inhibitor in Rheumatoid Arthritis. The Journal of rheumatology. 1992;19(10):1537-41. [pmid: 1334515].
686 Weinblatt ME, Maddison PJ, Bulpitt KJ, et al. Campath-1h, a Humanized Monoclonal Antibody, in Refractory Rheumatoid Arthritis. An Intravenous Dose-Escalation Study. Arthritis and rheumatism. 1995;38(11):1589-94. [pmid: 7488279].
687 Weinblatt ME, Weissman BN, Holdsworth DE, et al. Long-Term Prospective Study of Methotrexate in the Treatment of Rheumatoid Arthritis. 84-Month Update. Arthritis and rheumatism. 1992;35(2):129-37. [pmid: 1734901].
688 Weitoft T, Larsson A, Saxne T, et al. Changes of Cartilage and Bone Markers After Intra-Articular Glucocorticoid Treatment With and Without Postinjection Rest in Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2005;64(12):1750-3. [pmid: 15843449].
689 Wendling D, Racadot E, Wijdenes J, et al. A Randomized, Double Blind, Placebo Controlled Multicenter Trial of Murine Anti-Cd4 Monoclonal Antibody Therapy in Rheumatoid Arthritis. The Journal of rheumatology. 1998;25(8):1457-61. [pmid: 9712083].
690 Wendling D, Wijdenes J, Racadot E, et al. Therapeutic use of monoclonal anti-CD4 antibody in rheumatoid arthritis. J Rheumatol. Mar. 1991;18(3):325-7. [pmid: 1713269].
691 Westhovens R, Robles M, Ximenes AC, et al. Clinical efficacy and safety of abatacept in methotrexate-naive patients with early rheumatoid arthritis and poor prognostic factors. 2009.
692 Westhovens R, Verwilghen J, Dequeker J. Total Lymphoid Irradiation in Rheumatoid Arthritis. A Ten-Year Followup. Arthritis and rheumatism. 1997;40(3):426-9. [pmid: 9082928].
693 Whitehead J, Thomas P. A Sequential Trial of Pain Killers in Arthritis: Issues of Multiple Comparisons With Control and of Interval-Censored Survival Data. Journal of Biopharmaceutical Statistics. 1997;7(3):333-53. [pmid: 9252829].
694 Wijnands M, van Riel P, van ‘t Hof M, et al. Longterm Treatment With Nonsteroidal Antiinflammatory Drugs in Rheumatoid Arthritis: a Prospective Drug Survival Study. The Journal of rheumatology. 1991;18(2):184-7. [pmid: 2023212].
695 Williams HJ, Ward JR, Reading JC, et al. Comparison of Auranofin, Methotrexate, and the Combination of Both in the Treatment of Rheumatoid Arthritis. A Controlled Clinical Trial. Arthritis and rheumatism. 1992;35(3):259-69. [pmid: 1536666].
696 Willich SN, Rossnagel K, Roll S, et al. Rose hip herbal remedy in patients with rheumatoid arthritis - a randomised controlled trial. 2010.
697 Willkens R, Sharp J, Stablein D, et al. Comparison of Azathioprine, Methotrexate, and the Combination of the Two in the Treatment of Rheumatoid Arthritis. A Forty-Eight-Week Controlled Clinical Trial With Radiologic Outcome Assessment. Arthritis and rheumatism. 1995;38(12):1799-806. [pmid: 8849352].
698 Willkens R, Stablein D. Combination Treatment of Rheumatoid Arthritis Using Azathioprine and Methotrexate: a 48 Week Controlled Clinical Trial. The Journal of rheumatology Supplement. 1996;44:64-8. [pmid: 8833056].
699 Willkens RF, Urowitz MB, Stablein DM, et al. Comparison of Azathioprine, Methotrexate, and the Combination of Both in the Treatment of Rheumatoid Arthritis. A Controlled Clinical Trial. Arthritis and rheumatism. 1992;35(8):849-56. [pmid: 1642652].
700 Wojtulewski JA, Schattenkirchner M, Barcelo P, et al. A Six-Month Double-Blind Trial to Compare the Efficacy and Safety of Meloxicam 7.5 Mg Daily and Naproxen 750 Mg Daily in Patients With Rheumatoid Arthritis. British journal of rheumatology. 1996;35(Suppl 1):22-8. [pmid: 8630632].
701 Wolfe F, Michaud K. Biologic treatment of rheumatoid arthritis and the risk of malignancy: Analyses from a large US observational study. Arthritis and Rheumatism. 2007;56(9):2886-95. [pmid: 17729297].
702 Wong M, Oakley SP, Young L, et al. Infliximab improves vascular stiffness in patients with rheumatoid arthritis. 2009.
703 Wood ND, Aitken M, Durston S, Harris S, McClelland GR, Sharp S. Cartilage Protective Agent (Cpa) Ro 32–3555, a New Matrix Metalloproteinase Inhibitor for the Treatment of Rheumatoid Arthritis. Agents and Actions Supplements. 1998;36(8):1087-8.
704 Woodworth TG. Early Clinical Studies of Il-2 Fusion Toxin in Patients With Severe Rheumatoid Arthritis and Recent Onset Insulin-Dependent Diabetes Mellitus. Clinical and experimental rheumatology. 1993;11(Suppl 8):S177-80. [pmid: 8324945].
705 Wu E, Chen L, Birnbaum H, et al. Retrospective claims data analysis of dosage adjustment patterns of TNF antagonists among patients with rheumatoid arthritis. Current Medical Research and Opinion. 2008;24(8):2229-40. [pmid: 18577308].
706 Wylie G, Appelboom T, Bolten W, et al. A Comparative Study of Tenidap, a Cytokine-Modulating Anti-Rheumatic Drug, and Diclofenac in Rheumatoid Arthritis: a 24-Week Analysis of a 1-Year Clinical Trial. British journal of rheumatology. 1995;34(6):554-63. [pmid: 7543348].
707 Yang ZX, Li ZB, Sun ZC, et al. Correlations between serum macrophage migration inhibitory factor and active rheumatoid arthritis. Journal of Clinical Rehabilitative Tissue Engineering Research. 2008;12(37):7390-3.
708 Yasuda M, Sakai K, Oribe M, et al. Efficacy of Additive Dmard Therapy in Patients With Rheumatoid Arthritis. Double Blind Controlled Trial Using Bucillamine and Placebo With Maintenance Doses of Gold Sodium Thiomalate. J Rheumatol. 1994;21(1):33-50. [pmid: 8151583].
709 Yocum D, Furst D, Kaine JL, et al. Efficacy and Safety of Tacrolimus in Patients With Rheumatoid Arthritis: a Double-Blind Trial. Arthritis Rheum. 2003;48(12):3328-37. [pmid: 14673984].
710 Yxfeldt A, Wallberg-Jonsson S, Hultdin J, et al. Homocysteine in Patients With Rheumatoid Arthritis in Relation to Inflammation and B-Vitamin Treatment. Scand J Rheumatol. 2003;32(4):205-10. [pmid: 14626626].
711 Zanette SdA, Born IG, Brenol JCT, et al. A pilot study of acupuncture as adjunctive treatment of rheumatoid arthritis. Clinical Rheumatology. 2008;27(5):627-35. [pmid: 17989918].
712 Zhang FC, Hou Y, Huang F, et al. Infliximab versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: A preliminary study from China. APLAR Journal of Rheumatology. 2006;9(2):127-30.
713 Zhao S, Fiechtner JI, Tindall E, et al. Evaluation of Health-Related Quality of Life of Rheumatoid Arthritis Patients Treated With Celecoxib. Arthritis care and research : the official journal of the Arthritis Health Professions Association. 2000;13(2):112-21. [pmid: 14635284].
714 Zhou X, Zhou Z, Jin M, et al. Clinical Study of Qingluo Tongbi Granules in Treating 63 Patients With Rheumatoid Arthritis of the Type of Yin-Deficiency and Heat in Collaterals. J Tradit Chin Med. 2004;24(2):83-7. [pmid: 15270253].
715 Ziebland S, Fitzpatrick R, Jenkinson C, et al. Comparison of Two Approaches to Measuring Change in Health Status in Rheumatoid Arthritis: the Health Assessment Questionnaire (Haq) and Modified Haq. Annals of the rheumatic diseases. 1992;51(11):1202-5. [pmid: 1466596].
716 Zoppi M, Peretti G, Boccard E. Placebo-Controlled Study of the Analgesic Efficacy of an Effervescent Formulation of 500 Mg Paracetamol in Arthritis of the Knee or the Hip. European Journal of Pain. 1995;16(1–2):42-8.
717 Zuo X, Duan L, Cao Z, et al. A Clinical Study on Rheumatoid Arthritis Treated by Cu.zn-Sod. Bulletin of Hunan Medical University. 1995;20(3):275-7.

## Reference Source: Dossiers

1 Askling J, Fored CM, Baecklund E, et al. Haematopoietic malignancies in rheumatoid arthritis: lymphoma risk and characteristics after exposure to tumour necrosis factor antagonists. Ann Rheum Dis. Oct. 2005;64(10):1414-20. [pmid: 15843454].
2 Baecklund E, Iliadou A, Askling J, et al. Association of chronic inflammation, not its treatment, with increased lymphoma risk in rheumatoid arthritis. Arthritis Rheum. Mar. 2006;54(3):692-701. [pmid: 16508929].
3 Bernstein LE, Berry J, Kim S, et al. Effects of etanercept in patients with the metabolic syndrome. Arch Intern Med. Apr. 24. 2006;166(8):902-8. [pmid: 16636217].
4 Breedveld FC, Kalden JR. Appropriate and effective management of rheumatoid arthritis. Ann Rheum Dis. Jun. 2004;63(6):627-33. [pmid: 15140767].
5 Brodszky V, Pentek M, Gulacsi L. Efficacy of adalimumab, etanercept, and infliximab in psoriatic arthritis based on ACR50 response after 24 weeks of treatment. Scand J Rheumatol. Sep–Oct. 2008;37(5):399-400. [pmid: 18821278].
6 Cardiel MH. First Latin American position paper on the pharmacological treatment of rheumatoid arthritis. Rheumatology (Oxford). Jun. 2006;45(Suppl 2):ii7-ii22. [pmid: 16709584].
7 Cella D, Yount S, Sorensen M, et al. Validation of the Functional Assessment of Chronic Illness Therapy Fatigue Scale relative to other instrumentation in patients with rheumatoid arthritis. J Rheumatol. May. 2005;32(5):811-9. [pmid: 15868614].
8 Combe BG, Codreanu C, Fiocco U, et al. Double-blind comparison of Etanercept and Sulphasalazine, alone and combined, in patients with active rheumatoid arthritis despite receiving Sulphasalazine. Ann Rheum Dis. 2006. Apr. 10.
9 Emery P. Role of adalimumab, a novel TNF antagonist in advancing rheumatoid arthritis control. Drugs Today (Barc). 2003;39(Suppl B):17-23. [pmid: 14668929].
10 Fleischmann RM, Tesser J, Schiff MH, et al. Safety of extended treatment with anakinra in patients with rheumatoid arthritis. Ann Rheum Dis. Aug. 2006;65(8):1006-12. [pmid: 16396977].
11 Hashimoto J, Garnero P, van der Heijde D, et al. Humanized anti-interleukin-6-receptor antibody (tocilizumab) monotherapy is more effective in slowing radiographic progression in patients with rheumatoid arthritis at high baseline risk for structural damage evaluated with levels of biomarkers, radiography, and BMI: data from the SAMURAI study. Mod Rheumatol. 2010. Jun. 24.
12 Haugeberg G, Conaghan PG, Quinn M, et al. Bone loss in patients with active early rheumatoid arthritis: infliximab and methotrexate compared with methotrexate treatment alone. Explorative analysis from a 12-month randomised, double-blind, placebo-controlled study. Ann Rheum Dis. Dec. 2009;68(12):1898-901. [pmid: 19386610].
13 Jones G, Crotty M, Brooks P. Psoriatic arthritis: a quantitative overview of therapeutic options. The Psoriatic Arthritis Meta-Analysis Study Group. Br J Rheumatol. Jan. 1997;36(1):95-9. [pmid: 9117186].
14 Kavanaugh A, Antoni CE, Gladman D, et al. The Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT): results of radiographic analyses after 1 year. Ann Rheum Dis. Aug. 2006;65(8):1038-43. [pmid: 16439444].
15 Kempeni J. Preliminary results of early clinical trials with the fully human anti-TNFalpha monoclonal antibody D2E7. Ann Rheum Dis. November. 1. 1999;58(90001):70i-2.
16 Kempeni J. Update on D2E7: a fully human anti-tumour necrosis factor alpha monoclonal antibody. Ann Rheum Dis. November. 1. 2000;59(90001):44i-5. [pmid: 10627426].
17 Keystone EC. Appropriate and effective rheumatoid arthritis control: role of TNF antagonists. Drugs Today (Barc). 2003;39(Suppl B):9-15. [pmid: 14668928].
18 Klareskog L, Gaubitz M, Rodriguez-Valverde V, et al. A Long-Term, Open-Label Trial of the Safety and Efficacy of Etanercept (ENBREL(R)) In Patients With Rheumatoid Arthritis Not Treated With Other DMARDs (3-year Interim Report). Ann Rheum Dis. 2006. Mar. 15.
19 Machold KP, Smolen JS. Adalimumab - a new TNF-alpha antibody for treatment of inflammatory joint disease. Expert Opin Biol Ther. Apr. 2003;3(2):351-60. [pmid: 12662147].
20 Mease PJ. Adalimumab: an anti-TNF agent for the treatment of psoriatic arthritis. Expert Opin Biol Ther. 2005;5(11):1491-504. [pmid: 16255652].
21 Migliore A, Bizzi E, Lagana B, et al. The safety of anti-TNF agents in the elderly. Int J Immunopathol Pharmacol. 2009;22(2):415-26. [pmid: 19505394].
22 Parekh K, Ching D, Rahman MU, et al. Onset of Wegener’s granulomatosis during therapy with golimumab for rheumatoid arthritis: a rare adverse event?. Rheumatology (Oxford). Sep. 2010;49(9):1785-7. [pmid: 20403913].
23 Pavelka K. Adalimumab in the treatment of rheumatoid arthritis. Aging Health. 2006;2(4):533-45.
24 Rau R. Adalimumab (a fully human anti-tumour necrosis factor {alpha} monoclonal antibody) in the treatment of active rheumatoid arthritis: the initial results of five trials. Ann Rheum Dis. November. 1. 2002. 2002;61(90002):70ii-3. [pmid: 11779764].
25 Rigopoulos D, Gregoriou S, Stratigos A, et al. Evaluation of the efficacy and safety of infliximab on psoriatic nails: an unblinded, nonrandomized, open-label study. Br J Dermatol. Aug. 2008;159(2):453-6. [pmid: 18565184].
26 Salfeld JG. Use of new biotechnology to design rational drugs against newly defined targets. Best Pract Res Clin Rheumatol. Feb. 2004;18(1):81-95. [pmid: 15123039].
27 Saliu OY, Sofer C, Stein DS, et al. Tumor-necrosis-factor blockers: differential effects on mycobacterial immunity. J Infect Dis. Aug. 15. 2006;194(4):486-92. [pmid: 16845632].
28 Santora LC, Kaymakcalan Z, Sakorafas P, et al. Characterization of noncovalent complexes of recombinant human monoclonal antibody and antigen using cation exchange, size exclusion chromatography, and BIAcore. Anal Biochem. Dec. 15. 2001;299(2):119-29. [pmid: 11730333].
29 Simpson D, Scott LJ. Adalimumab : in psoriatic arthritis. Drugs. 2006;66(11):1487-96. [pmid: 16906782].
30 Smolen JS. Objectives and strategies for rheumatoid arthritis therapy: yesterday vs. today. Drugs Today (Barc). 2003;39(Suppl B):3-8. [pmid: 14668927].
31 Suissa S, Ernst P, Hudson M, et al. Newer disease-modifying antirheumatic drugs and the risk of serious hepatic adverse events in patients with rheumatoid arthritis. Am J Med. Jul. 15. 2004;117(2):87-92. [pmid: 15234643].
32 van de Putte L, Nichol MB. Adalimumab for Rheumatoid Arthritis: Considerations for Reimbursement by Third-Party Payors Disease. Management & Health Outcomes. 2004;12(1):1-8.
33 Voulgari PV, Venetsanopoulou AI, Epagelis EK, et al. Infliximab in refractory psoriatic arthritis with severe psoriasis: a 2-year experience. Ann Rheum Dis. Feb. 2007;66(2):270-1. [pmid: 17068063].
34 Weinblatt M, Combe B, Covucci A, et al. Safety of the selective costimulation modulator abatacept in rheumatoid arthritis patients receiving background biologic and nonbiologic disease-modifying antirheumatic drugs: A one-year randomized, placebo-controlled study. Arthritis Rheum. Aug. 31. 2006;54(9):2807-16. [pmid: 16947384].
35 Westhovens R, Yocum D, Han J, et al. The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum. Apr. 2006;54(4):1075-86. [pmid: 16572442].
36 Yazici Y, Adler NM, Yazici H. Most tumour necrosis factor inhibitor trials in rheumatology are undeservedly called ‘efficacy and safety’ trials: a survey of power considerations. Rheumatology (Oxford). Jul. 2008;47(7):1054-7. [pmid: 18495823].

## Reference Source: The Cochrane Library

1 Aerts NE, Ebo DG, Bridts CH, et al. T cell signal transducer and activator of transcription (STAT) 4 and 6 are affected by adalimumab therapy in rheumatoid arthritis. Clinical and experimental rheumatology. 2010;(2):208-14. [pmid: 20483042].
2 Akobeng AK, Thomas AG. Enteral nutrition for maintenance of remission in Crohn’s disease. Cochrane Database of Systematic Reviews. 2007;(3).
3 Alfadhli A, McDonald J, Feagan B. Methotrexate for Induction of Remission in Refractory Crohn’s Disease. The Cochrane Database of Systematic Reviews. 2004;2004(4).
4 Blumenauer B, Judd M, Cranney A, et al. Etanercept for the Treatment of Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2003;2003(3).
5 Blumenauer B, Judd M, Wells G, et al. Infliximab for the Treatment of Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2002;2002(3).
6 Bongartz T. Tocilizumab for rheumatoid and juvenile idiopathic arthritis. Lancet. 2008;(9617):961-3. [pmid: 18358909].
7 Bravo Vergel Y, Palmer S, Erhorn S, et al. Adalimumab for the treatment of moderate to severe psoriatic arthritis. Health Technology Assessment. 2010.
8 Burls A, Clark WK, Jobanputra P. Anakinra for Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2005;2005(1).
9 Chen J, Liu C. Methotrexate for Ankylosing Spondylitis The Cochrane Database of Systematic Reviews. 2003;2003(3).
10 Chen J, Liu C. Sulfasalazine for Ankylosing Spondylitis The Cochrane Database of Systematic Reviews. 2005;2005(2).
11 Chen J, Liu C, Lin J. Methotrexate for ankylosing spondylitis. Cochrane Database of Systematic Reviews. 2006;(4).
12 Christensen AF, Hørslev-Petersen K, Christgau S, et al. Uncoupling of collagen II metabolism in newly diagnosed, untreated rheumatoid arthritis is linked to inflammation and antibodies against cyclic citrullinated peptides. The Journal of rheumatology. 2010;(6):1113-20. [pmid: 20436079].
13 Clark W, Jobanputra P, Barton P, et al. The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis (Brief record). Health Technology Assessment. 2004;(18):1-118.
14 Clarke R, Derry S, Moore RA, et al. Single dose oral etoricoxib for acute postoperative pain in adults. Cochrane Database of Systematic Reviews. 2009;(2).
15 Coombs JH, Bloom BJ, Breedveld FC, et al. Improved pain, physical functioning and health status in patients with rheumatoid arthritis treated with CP-690,550, an orally active Janus kinase (JAK) inhibitor: results from a randomised, double-blind, placebo-controlled trial. Annals of the rheumatic diseases. 2010;(2):413-6. [pmid: 19587388].
16 Criswell L, Saag K, Sems KM, et al. Moderate-term, low-dose corticosteroids for rheumatoid arthritis. 1998.
17 Criswell L, Saag KG, Sems KM, et al. Moderate-Term, Low-Dose Corticosteroids for Rheumatoid Arthritis. The Cochrane Database of Systematic Reviews. 1998;1998(3).
18 de Courten B, Barber Melissa N, Johnston Renea V, et al. Hypolipidemic and antihypertensive drugs for prevention of cardiovascular complications in patients with rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2008;(3).
19 Deodhar A, Dore RK, Mandel D, et al. Denosumab-mediated increase in hand bone mineral density associated with decreased progression of bone erosion in rheumatoid arthritis patients. Arthritis care & research. 2010;(4):569-74. [pmid: 20391513].
20 Derry S, Barden J, McQuay Henry J, et al. Single dose oral celecoxib for acute postoperative pain in adults. Cochrane Database of Systematic Reviews. 2008;(4).
21 Egan M, Brosseau L, Farmer M, et al. Splints and Orthosis for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2001;2001(4).
22 Englbrecht M, Wang Y, Ronneberger M, et al. Measuring joint involvement in polyarticular psoriatic arthritis: an introduction of alternatives. Arthritis care & research. 2010;(7):977-83. [pmid: 20191568].
23 Flint Wagner HG, Lisse J, Lohman TG, et al. Assessment of a sixteen-week training program on strength, pain, and function in rheumatoid arthritis patients. Journal of clinical rheumatology : practical reports on rheumatic & musculoskeletal diseases. 2009;15(4):165-71.
24 Garner S, Fidan D, Frankish R, et al. Celecoxib for Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2002;2002(4).
25 Garner S, Fidan DD, Frankish RR, et al. Rofecoxib for Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2005;2005(1).
26 Garner Sarah E, Fidan D, Frankish Ruth R, et al. Rofecoxib for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2005;(1).
27 Gøtzsche P, Johansen H. Short-Term Low-Dose Corticosteroids Vs Placebo and Nonsteroidal Antiinflammatory Drugs in Rheumatoid Arthritis. The Cochrane Database of Systematic Reviews. 2005;2005(1).
28 Hashimoto J, Garnero P, van der Heijde D, et al. A combination of biochemical markers of cartilage and bone turnover, radiographic damage and body mass index to predict the progression of joint destruction in patients with rheumatoid arthritis treated with disease-modifying anti-rheumatic drugs. Modern rheumatology/the Japan Rheumatism Association. 2009;19(3):273-82. [pmid: 19452245].
29 Health Technology A. Adalimumab, etanercept, infliximab, rituximab and abatacept for the treatment of rheumatoid arthritis after the failure of a TNF inhibitor: a systematic review and economic evaluation (Project record). Health Technology Assessment. 2010.
30 Health Technology A. The clinical and cost effectiveness of etanercept, infliximab and adalimumab - psoriatic arthritis (guidance review 104 and 125) (Project record). Health Technology Assessment. 2010.
31 Homer D, Nightingale P, Jobanputra P. Providing patients with information about disease-modifying anti-rheumatic drugs: Individually or in groups? A pilot randomized controlled trial comparing adherence and satisfaction. Musculoskeletal care. 2009;7(2):78-92. [pmid: 18792423].
32 Jones G, Crotty M, Brooks P. Interventions for Treating Psoriatic Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(3).
33 Keystone E, Genovese MC, Klareskog L, et al. Golimumab in patients with active rheumatoid arthritis despite methotrexate therapy: 52-week results of the GO-FORWARD study. Annals of the rheumatic diseases. 2010;(6):1129-35. [pmid: 20444749].
34 Kirwan J, Shea B, Boers M. Glucocorticoids for Slowing Radiological Progression in Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2005;2005(1).
35 Klarenbeek NB, van der Kooij SM, Huizinga TJ, et al. Blood pressure changes in patients with recent-onset rheumatoid arthritis treated with four different treatment strategies: a post hoc analysis from the BeSt trial. Annals of the rheumatic diseases. 2010;(7):1342-5. [pmid: 20472597].
36 Lawson MM, Thomas AG, Akobeng AK. Tumour necrosis factor alpha blocking agents for induction of remission in ulcerative colitis. Cochrane Database of Systematic Reviews. 2006;(3).
37 Lekander I, Borgstrom F, Svarvar P, et al. Cost-effectiveness of real-world infliximab use in patients with rheumatoid arthritis in Sweden. International Journal of Technology Assessment in Health Care. 2010;26(1):54-61. [pmid: 20059781].
38 Li L, Judd M, Pencharz JN, Li L, Judd M, Pencharz JN. Comprehensive physiotherapy for rheumatoid arthritis. The Cochrane Database of Systematic Reviews: Protocols. 2004;(2). John Wiley & Sons, Ltd. Chichester, UK. [doi: 10.1002/14651858.CD004802]. John Wiley & Sons, Ltd. 2004. 2004(2).
39 Lin JF, Chen JM, Liu C. A systematic review of methotrexate for ankylosing spondylitis (Brief record). Chinese Journal of Evidence-Based Medicine. 2007;(4):260-6.
40 Little C, Parsons T. Herbal Therapy for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(4).
41 Little Christine V, Parsons T, Logan S. Herbal therapy for treating osteoarthritis. 2000. Available at: http://www.mrw.interscience.wiley.com/cochrane/clsysrev/articles/CD002947/frame.html.
42 Lopez-Olivo Maria A, Amezaga M, McGahan L, et al. Rituximab for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2008;(4).
43 Lu D, Song H, Shi G. Anti-TNF-&#945; treatment for pelvic pain associated with endometriosis. Cochrane Database of Systematic Reviews. 2010(3).
44 Lukas C, van der Heijde D, Fatenajad S, et al. Repair of erosions occurs almost exclusively in damaged joints without swelling. Annals of the rheumatic diseases. 2010;(5):851-5. [pmid: 19846407].
45 Lv D, Song H, Shi G. Anti-TNF-&#945; treatment for pelvic pain associated with endometriosis. 2009. Available at: http://www.mrw.interscience.wiley.com/cochrane/clsysrev/articles/CD008088/frame.html.
46 Lv D, Song H, Shi G. Anti-TNF-&#945; treatment for pelvic pain associated with endometriosis. Cochrane Database of Systematic Reviews. 2010;(3).
47 Maxwell L, Singh Jasvinder A. Abatacept for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2008;(3).
48 Maxwell L, Singh Jasvinder A. Abatacept for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2009;(4).
49 Navarro Sarabia F, Ariza Ariza R, Hernandez Cruz B, et al. Adalimumab for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2005;2005(3).
50 Osiri M, Shea B, Robinson V, et al. Leflunomide for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2002;2002(3).
51 Osiri M, Shea B, Welch V, et al. Leflunomide for the treatment of rheumatoid arthritis. 2002.
52 Ramiro S, Radner H, van der Heijde D, et al. Combination therapy for pain management in inflammatory arthritis. Cochrane Database of Systematic Reviews. 2010;(12).
53 Rooney T, Roux-Lombard P, Veale DJ, et al. Synovial tissue and serum biomarkers of disease activity, therapeutic response and radiographic progression: analysis of a proof-of-concept randomised clinical trial of cytokine blockade. Annals of the rheumatic diseases. 2010;(4):706-14. [pmid: 19460761].
54 Ruiz Garcia V, Burls A, Cabello López Juan CL, et al. Certolizumab pegol (CDP870) for rheumatoid arthritis in adults. Cochrane Database of Systematic Reviews. 2009;(1).
55 Schiff M, Pritchard C, Huffstutter JE, et al. The 6-month safety and efficacy of abatacept in patients with rheumatoid arthritis who underwent a washout after anti-tumour necrosis factor therapy or were directly switched to abatacept: the ARRIVE trial. Annals of the rheumatic diseases. 2009;68(11):1708-14. [pmid: 19074911].
56 Sharp JT, Tsuji W, Ory P, et al. Denosumab prevents metacarpal shaft cortical bone loss in patients with erosive rheumatoid arthritis. Arthritis care & research. 2010;(4):537-44. [pmid: 20391509].
57 Singh Jasvinder A, Beg S, Lopez Olivo, Maria A. Tocilizumab for rheumatoid arthritis. 2010.
58 Singh Jasvinder A, Beg S, Lopez-Olivo Maria A. Tocilizumab for rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2010;(7).
59 Singh Jasvinder A, Christensen R, Wells George A, et al. Biologics for rheumatoid arthritis: an overview of Cochrane reviews. Cochrane Database of Systematic Reviews. 2009;(2).
60 Singh Jasvinder A, Christensen R, Wells George A, et al. Biologics for rheumatoid arthritis: an overview of Cochrane reviews. Cochrane Database of Systematic Reviews. 2009;(4).
61 Smolen JS, Aletaha D, Grisar JC, et al. Estimation of a numerical value for joint damage-related physical disability in rheumatoid arthritis clinical trials. Annals of the rheumatic diseases. 2010;(6):1058-64. [pmid: 19717399].
62 Smolen JS, van der Heijde DM, Aletaha D, et al. Progression of radiographic joint damage in rheumatoid arthritis: independence of erosions and joint space narrowing. Annals of the rheumatic diseases. 2009;68(10):1535-40. [pmid: 18957487].
63 Suarez Almazor M, Belseck E, Shea BJ, et al. Antimalarials for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(4).
64 Suarez Almazor M, Belseck E, Shea BJ, et al. Methotrexate for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 1998;1998(2).
65 Suarez Almazor M, Belseck E, Shea BJ, et al. Sulfasalazine for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 1998;1998(2).
66 Suarez Almazor M, Belseck E, Spooner C. Penicillamine for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(4).
67 Suarez Almazor M, Spooner C, Belseck E. Azathioprine for Treating Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(4).
68 Suarez Almazor M, Spooner CH, Belseck E, et al. Auranofin Versus Placebo in Rheumatoid Arthritis The Cochrane Database of Systematic Reviews. 2000;2000(2).
69 Suarez-Almazor Maria E, Belseck E, Shea B, et al. Sulfasalazine for treating rheumatoid arthritis. Cochrane Database of Systematic Reviews. 1998;(2).
70 Suarez-Almazor Maria E, Belseck E, Shea B, et al. Cyclophosphamide for treating rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2000;(4).
71 Tirunagari Shravan K, Derry S, Moore RA, et al. Single dose oral etodolac for acute postoperative pain in adults. Cochrane Database of Systematic Reviews. 2009;(3).
72 Towheed T, Hochberg Marc C, Shea B, et al. Analgesia and non-aspirin, non-steroidal anti-inflammatory drugs for osteoarthritis of the hip. Cochrane Database of Systematic Reviews. 2006;(1).
73 van der Heijde D, Burmester G, Melo Gomes J, et al. Inhibition of radiographic progression with combination etanercept and methotrexate in patients with moderately active rheumatoid arthritis previously treated with monotherapy. Annals of the rheumatic diseases. 2009;68(7):1113-8. [pmid: 18718986].
74 van Tuyl LH, Boers M, Lems WF, et al. Survival, comorbidities and joint damage 11 years after the COBRA combination therapy trial in early rheumatoid arthritis. Annals of the rheumatic diseases. 2010;(5):807-12. [pmid: 19451137].
75 Verstappen SM, Bakker MF, Heurkens AH, et al. Adverse events and factors associated with toxicity in patients with early rheumatoid arthritis treated with methotrexate tight control therapy: the CAMERA study. Annals of the rheumatic diseases. 2010;(6):1044-8. [pmid: 19581281].
76 Vidal L, Gafter-Gvili A, Leibovici L, et al. Rituximab as maintenance therapy for patients with follicular lymphoma. Cochrane Database of Systematic Reviews. 2007;(2).
77 Wallen Margaret M, Gillies D. Intra-articular steroids and splints/rest for children with juvenile idiopathic arthritis and adults with rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2006;(1).
78 Westhovens R, Kremer JM, Moreland LW, et al. Safety and efficacy of the selective costimulation modulator abatacept in patients with rheumatoid arthritis receiving background methotrexate: a 5-year extended phase IIB study. The Journal of rheumatology. 2009;36(4):736-42. [pmid: 19273451].
79 Wienecke T, Gøtzsche P. Paracetamol Versus Nonsteroidal Anti-Inflammatory Drugs for Rheumatoid Arthritis. The Cochrane Database of Systematic Reviews. 2004;2004(1).