# Search Strings

## 2007 Search

Search | Most Recent Queries | Result
#2 | Search (“Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH]) | 82356
#3 | Search (“Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH]) Limits: All Adult: 19+ years, English, Publication Date from 1990, Humans | 16462
#5 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 190820
#6 | Search #3 AND #5 | 686
#7 | Search #3 AND #5 Limits: Editorial, Letter, Practice Guideline | 18
#8 | Search #6 NOT #7 | 668
#18 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 28712
#28 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin”[Substance Name] OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 8701
#29 | Search #3 AND #18 | 1365
#30 | Search #3 AND #28 | 777
#31 | Search #3 AND #18 Limits: Editorial, Letter, Practice Guideline | 237
#32 | Search #29 NOT #31 | 1128
#33 | Search #3 AND #28 Limits: Editorial, Letter, Practice Guideline | 178
#34 | Search #30 NOT #33 | 599
#35 | Search #8 OR #30 OR #34 | 1405

## July 2009 Search

Search | Most Recent Queries | Result
#1 | Search “Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH] | 85528
#2 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 239378
#3 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 31900
#4 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin”[Substance Name] OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 15567
#5 | Search (((“CDP870 “[Substance Name] OR certolizumab OR cimzia) OR “efalizumab “[Substance Name] OR raptiva) OR “alefacept “[Substance Name] OR amevive) OR “natalizumab “[Substance Name] OR tysabri | 1127
#6 | Search “golimumab “[Substance Name] | 12
#7 | Search #2 OR #3 OR #4 OR #5 OR #6 | 283303
#8 | Search #7 AND #1 | 11283
#9 | Search #7 AND #1 Limits: Editorial, Letter, Practice Guideline | 1368
#10 | Search #8 NOT #9 | 9915
#11 | Search #8 NOT #9 Limits: Humans, English, All Adult: 19+ years | 4079
#12 | Search Limits: Entrez Date from 2006/06/01, Humans, English, All Adult: 19+ years | 498212
#13 | Search #11 AND #12 | 1027

## August 2009 Search (for Tocilizumab)

Search | Most Recent Queries | Result
#1 | Search “Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH] | 85692
#2 | Search actemra | 4
#4 | Search “tocilizumab “[Substance Name] | 103
#5 | Search #2 OR #4 | 104
#6 | Search #5 AND #1 | 75
#7 | Search #5 AND #1 Limits: Editorial, Letter, Practice Guideline | 8
#8 | Search #6 NOT #7 | 67
#9 | Search #6 NOT #7 Limits: Humans, English, All Adult: 19+ years | 14
#10 | Search #9 Limits: Entrez Date from 2006/06/01 | 14

## March 2010 Search

Search | Most Recent Queries | Result
#1 | Search “Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH] | 87507
#2 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 244454
#3 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 32512
#12 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin” OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 16979
#13 | Search (((“CDP870 “[Substance Name] OR certolizumab OR cimzia) OR “efalizumab “[Substance Name] OR raptiva) OR “alefacept “[Substance Name] OR amevive) OR “natalizumab “[Substance Name] OR tysabri | 1309
#14 | Search actemra OR “tocilizumab”[Substance Name] | 134
#15 | Search “golimumab “[Substance Name] | 32
#16 | Search #2 OR #3 OR #12 OR #13 OR #14 OR #15 | 290354
#17 | Search #16 AND #1 | 11855
#18 | Search #17 Limits: Editorial, Letter, Practice Guideline | 1450
#19 | Search #17 NOT #18 | 10405
#20 | Search #19 Limits: Humans, English, All Adult: 19+ years | 4358
#21 | Search “2009/05/01”[Entrez Date] : “3000”[Entrez Date] Limits: Humans, English, All Adult: 19+ years | 89610
#22 | Search #20 AND #21 Limits: Humans, English, All Adult: 19+ years Sort by: PublicationDate | 176

## August 2010 Search

Search | Most Recent Queries | Result
#1 | Search “Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH] | 89162
#2 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 248455
#3 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 33034
#4 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin” OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 18212
#5 | Search (((“CDP870 “[Substance Name] OR certolizumab OR cimzia) OR “efalizumab “[Substance Name] OR raptiva) OR “alefacept “[Substance Name] OR amevive) OR “natalizumab “[Substance Name] OR tysabri | 1468
#6 | Search actemra OR “tocilizumab”[Substance Name] | 250
#7 | Search “golimumab “[Substance Name] | 47
#8 | Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 296041
#9 | Search #1 AND #8 | 12290
#10 | Search #9 Limits: Editorial, Letter, Practice Guideline | 1498
#11 | Search #9 NOT #10 | 10792
#12 | Search #11 Limits: Humans, English, All Adult: 19+ years | 4578
#13 | Search ((#12) AND “2010/01/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] Sort by: Author | 125

## January 2011 Search

Search | Most Recent Queries | Result
#1 | Search “Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH] | 90392
#2 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 251312
#3 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 33430
#4 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin” OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 19150
#5 | Search (((“CDP870 “[Substance Name] OR certolizumab OR cimzia) OR “efalizumab “[Substance Name] OR raptiva) OR “alefacept “[Substance Name] OR amevive) OR “natalizumab “[Substance Name] OR tysabri | 1583
#6 | Search actemra OR “tocilizumab”[Substance Name] | 305
#7 | Search “golimumab “[Substance Name] | 56
#8 | Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 300191
#9 | Search #1 AND #8 | 12597
#10 | Search #9 Limits: Editorial, Letter, Practice Guideline | 1540
#11 | Search #9 NOT #10 | 11057
#12 | Search #11 Limits: Humans, English, All Adult: 19+ years | 4714
#13 | Search ((#12) AND “2010/05/01”[Entrez Date] : “3000”[Entrez Date]) AND “0”[Entrez Date] : “3000”[Entrez Date] Sort by: Author | 116