# Appendixes

Appendix A Search Strings

Appendix B Review and Abstraction Forms

Appendix C Articles by Database Searched

Appendix D Excluded Studies

Appendix E Evidence Tables

Appendix F Criteria for Assessing the Quality of Individual Studies

Appendix G Clinical and Self-Reported Scales and Instruments Commonly Used in Studies of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis

Appendix H Characteristics of Studies with Poor Internal Validity

Appendix I Strength of Evidence Tables