# Acknowledgments

We acknowledge Stephanie Chang, M.D., M.P.H. Director of the AHRQ Evidence-based Practice Center (EPC) Program and Carmen Kelly, Pharm.D., the AHRQ Task Order Officer for this project.

We extend our appreciation to our Technical Expert Panel: Teresa J. Brady, Ph.D., our Patient Representative; Dr. Jeffrey Curtis, M.D., M.P.H., Assistant Professor, Clinical Immunology and Rheumatology, University of Alabama at Birmingham; Marion McDonagh, Pharm.D., Assistant Professor, Informatics and Clinical Epidemiology and Project Director for DERP reports, Oregon Health & Science University; and Christopher T. Ritchlin, M.D., M.P.H., Rheumatologist, University of Rochester, our psoriatic arthritis clinical expert. All provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to research analysts: Tammeka Swinson Evans, B.A., Stacey Lloyd, M.P.H., and Loraine Monroe, our EPC publications specialist.