# Results

## Literature Search

The initial searches done in September 2009 covering the period from January 2005-December 2009 found a total of 18,667 titles. A further search was done on PubMed alerts which produced 178 total citations. Reference mining contributed an additional 217 citations. In October and November 2010 an update search was done and then a final update search was done in March 2011 which produced a total of 7,304 hits. All 26,366 citations were imported into EndNote and screened. In total, reviewers selected 2,440 relevant titles for abstract review out of 26,366 titles identified in the searches (see Figure 2). Abstract review resulted in rejection of 1,644 articles. Reasons for abstract exclusion included the following: articles were not on osteoporosis (535), design (772), fracture not reported (only in effectiveness analyses) (262), population (75). Eight articles were not found, and 127 were already in the original report. Thus, 661 full-text articles were available for the next stage of screening (short form).

Screening of retrieved articles resulted in further exclusion of 384. Reasons for exclusion included the following: design not relevant for analyses (213 articles), outcomes not relevant to project (80 articles), no enrollment criteria (six articles), population not relevant to project (40 articles), interventions not relevant to project (45 articles). Twenty-two background articles were not included in any of the analyses but are narratively described in the report. Appendix D lists all citations that were excluded, by reason.

Among the 255 articles accepted based on short form review, 84 articles reported on adherence, of which 7 were subsequently rejected for not answering a key question and one was rejected for duplicate data. Of 53 trials with fracture outcomes, all were accepted for inclusion in the efficacy analysis. Of 134 articles that reported adverse events, 89 were trials and 45 were observational (large cohort) studies. Of the 89 trials, 10 were subsequently rejected for either design (crossover), reporting no actual adverse event data, or not reporting relevant outcomes. Of the remaining 79 trials, 66 were included in meta-analyses conducted for this report, and 13 were described narratively. Among the 45 large observational studies, 12 were subsequently rejected for either design (crossover), not actually reporting adverse event data, or not reporting relevant outcomes. Of the remaining 35 observational studies, 23 were included in meta-analyses conducted for this report, and 10 were described narratively.

The analysis of studies on efficacy and effectiveness included 5 articles from the original report (referred to as LBD1 in Figure 2), and the adverse events analysis included 307 articles from the original report.14

Figure 2 displays the flow as described above.

Figure 2 Literature flow

LBD = Low Bone Density

Figure 2 is a flow chart that summarizes the study retrieval and selection process for articles on the comparative effectiveness and safety of osteoporosis therapies. The figure displays the same information described in the first paragraph of Chapter 3. The figure shows the following numbers of studies that were reviewed for each Key Question: Key Question 1 and 2 (efficacy by therapy type and efficacy by subgroup): 53Trials with fracture outcomes; Key Question 3 (adherence to and persistence with treatment), 76 studies; Key Question 4 (adverse events), 79 trials and 33 observational studies; Key Question 5: not specified (included in trials for Key Questions 1 and 2). In addition, 38 systematic reviews were included.

## Key Question 1 What Are the Comparative Benefits in Fracture Risk Reduction Among the Following Therapeutic Modalities for low Bone Density: Bisphosphonates, Denosumab, Menopausal Hormone Therapy, Selective Estrogen Receptor Modulators (Raloxifene), Parathyroid Hormone, Calcium, Vitamin D, and Physical Activity?

For this question, we identified 55 RCTs and 10 observational studies in addition to 58 systematic reviews (from both the original and current report) that assessed the effects of interventions compared to placebo: nine systematic reviews and 10 RCTs for alendronate, 10 systematic reviews and 13 RCTs for risedronate, three systematic reviews and three RCTs for ibandronate, four RCTs for zoledronic acid, one systematic review and two RCTs for denosumab, three systematic review and three RCTs for raloxifene, two systematic reviews and three RCTs for teriparatide, six RCTs for menopausal estrogen therapy, four systematic reviews and six RCTs for calcium alone, 15 systematic reviews and seven RCTs for vitamin D alone, four RCTs for vitamin D plus calcium, and one systematic review and one RCT for physical activity.

### Key Findings for Key Question 1

- There is a high level of evidence from RCTs that alendronate, risedronate, ibandronate, zoledronic acid, denosumab, teriparatide, and raloxifene reduce the risk of vertebral fractures in postmenopausal women with osteoporosis.
- There is a high level of evidence from RCTs that alendronate, risedronate, zoledronic acid and denosumab reduce the risk of nonvertebral fractures in postmenopausal women with osteoporosis and moderate evidence that teriparatide reduces the risk of nonvertebral fractures.
- There is a high level of evidence from RCTs that alendronate, risedronate, zoledronic acid, and denosumab reduce the risk of hip fractures in postmenopausal women with osteoporosis.
- The original report found a high level of evidence that estrogen is associated with a reduced incidence of vertebral, nonvertebral, and hip fractures; however studies identified for this report, which tended to focus on postmenopausal women with established osteoporosis (rather than on postmenopausal women with low bone density only or postmenopausal women in general) did not show significant reductions in fracture risk.
- The evidence is moderate, based on a published systematic review and several RCTs, that there is no difference between calcium alone and placebo in reducing the risk for vertebral and nonvertebral fractures; however, calcium significantly reduced hip fracture risk in one pooled analysis, and overall fracture risk in another pooled analysis.
- A large body of literature showed mixed results for an effect of vitamin D in lowering the risk for fracture, varying with dose, fracture site, analogs, and population. Evidence is moderate that Vitamin D, 700 to 800 I.U. daily, particularly when given with calcium, reduces the risk of hip and nonvertebral fractures among institutionalized populations (one systematic review) and the overall risk of fractures (a second systematic review).
- There is a high level of evidence, based on six previously published systematic reviews, that there is no difference in vertebral, nonvertebral, or hip fracture risk with administration of vitamin D alone compared to administration of calcium alone.
- The evidence is insufficient to low regarding the effect of physical activity on fracture risk compared to placebo: One study showed a small effect on fracture prevention. No studies compared the effect of physical activity to that of other interventions.
- The evidence is insufficient from head-to-head trials of bisphosphonates to prove or disprove superiority for the prevention of fractures for any agent.
- The evidence is insufficient from head-to-head trials of bisphosphonates compared to calcium, teriparatide, or raloxifene to prove or disprove superiority for the prevention of fractures. (three trials)
- Evidence is moderate, based on six head-to-head RCTs, that there is no difference in fracture incidence between bisphosphonates and menopausal hormone therapy.
- The evidence is low, based on one head-to-head trial, that the combination of alendronate and calcium significantly decreased the risk for any type of clinical fracture compared with alendronate alone.
- The evidence is low, based on limited head-to-head trial data (two trials), for a difference in fracture incidence between menopausal hormone therapy and raloxifene or vitamin D.
- The evidence is insufficient regarding the use of combinations of osteoporosis therapies or sequential use of osteoporosis therapies in relation to fracture outcomes.

### Overview of Results for Key Question 1

The results presented here are an update of the findings of the original 2007 report. For each osteoporosis medication (Table 1), we first describe previously published systematic reviews presented in the original report as well as systematic reviews published subsequent to the original report consistent with the incorporation of prior systematic reviews into new complex systematic reviews as articulated by Whitlock and colleagues.28 Subsequently, for each medication, we present results of original studies published subsequent to the systematic reviews. This information will be presented in the following sequence: effectiveness of individual agents compared with placebo (bisphosphonates, biologics, selective estrogen receptor modulators (SERMs), peptide hormones, menopausal hormone therapy, dietary supplements, and lifestyle interventions), head-to-head comparisons of medications, and sequential or combination use of medications.

#### Agents Compared With Placebo

In this section, we present the findings of systematic reviews and original studies not included in a prior systematic review that compared the effects of an active intervention with those of a placebo.

For each drug/placebo combination, we first show the matrix of all the prior systematic reviews and the original studies they included; then we show the actual findings of meta-analyses; then we describe the results of any original studies not included in prior meta-analyses.

##### Bisphosphonates

This section presents the results of prior systematic reviews and original studies not included in a prior systematic review on the bisphosphonates alendronate, risedronate, ibandronate, and zoledronic acid. Although the original report also included etidronate and pamidronate, these agents have been excluded from the current report as they are not indicated for the prevention/treatment of primary osteoporosis in the US.

###### Alendronate

###### Prior Systematic Reviews

We identified nine systematic reviews evaluating the antifracture efficacy of alendronate compared to placebo or no treatment29-37 (Table 3). In aggregate, the systematic reviews included data from 17 RCTs, the characteristics of which are summarized in Table 3. Of the nine, five assessed vertebral fracture risk, six assessed non-vertebral fracture risk, six assessed hip fracture risk, and four assessed wrist fracture risk.

Table 3 Randomized controlled trials included in systematic reviews of effect of alendronate on fracture relative to placebo or no treatment, by fracture type

| Systematic Review (Author, Year)
| Cra, 2002^29^ | | | | Kar, 1997^30^ | | | Pap, 2004^31^ | Ste, 2005^32^ | | | | Boo, 2005^34^ | Ngu, 2006^33^ | Saw, 2005^35^ | | Jan, 2009^36^ | Wel, 2008^37^
| Fracture Type
RCTs (Author, Year) | V | NV | H | W | NV | H | W | H | V | NV | H | W | NV | H | V | NV | V | V | NV | H | W
Adami,1995^38^ | X | X | | | X | X | X
Ascott Evans, 2003^39^ | | | | | | | | | | | | | | | | | | X | X | X
Black, 1996^40^ | X | X | X | X | | | | X | X | X | X | X | X | X | | | X | X | X | X | X
Bone, 1997^41^ | X | X | | | | | | | | | | | | | | | | X | X
Bonnick, 1998^42^ | | X | | | | | | X | | | | | | X
Chesnut, 1995^43^ | X | X | | | X | X | X | | | | | | | | | | | X | X
Cummings, 1998^44^ | X | X | | | | | | X | X | | X | X | X | X | | | X | X | X | X | X
Dursun, 2001^45^ | | | | | | | | | X | | | | | | | | | X
Greenspan, 1998^46^ | | | | | | | | X | | | | | | | | | | | X | X | X
Greenspan, 2002^47^ | | | | | | | | | | | | | | X | | | | | | X
Hosking, 1998^48^ | X | X | | | | | | | | | | | | | | | | X | X
Liberman, 1995^49^ | X | X | | | X | X | X | X | X | X | X | X | X | X | | | X | | X | X | X
McClung, 1998^50^ | X | X
Orwoll, 2000^51^ | | | | | | | | | | | | | | | | | | | | X | X
Pols, 1999^52^ | | X | | | | | | | | X | | | | X | | | | X | X | X | X
Ringe, 2004^53^ | | | | | | | | | | | | | | | X | X
Weinstein, 1994^54^ | | | | | X | X | X

V=vertebral, NV=non-vertebral, H=hip, W=wrist/forearm; X= included in pooled analysis

References for systematic reviews: Cranney, Endocr Rev, 2002^29^; Karpf, JAMA, 1997^30^; Papapoulous, Osteoporos Int, 2004^31^; Stevenson, Health Technol Assess, 2005^32^; Boonen, Osteoporos Int, 2005^34^; Nguyen, J Bone Miner Res, 2006^33^; Sawka, BMC Musculoskelet Disord, 2005^35^; Jansen, Curr Med Res Opin, 2009^36^; Wells, Cochrane Database Syst Rev, 2008^37^

Table 4 lists the systematic reviews that reported pooled risk estimates for fracture risk associated with alendronate relative to placebo or no treatment. For vertebral fractures, we found two new pooled estimates in addition to the three pooled estimates included in the original 2007 report. For non-vertebral fractures, we found one new pooled estimate in addition to the five pooled estimates included in the original 2007 report. For hip fractures, we found one new pooled estimate in addition to the five estimates included in the original 2007 report. For wrist fractures, we found one new estimate in addition to the three estimates included in the original 2007 report.

Table 4 Pooled risk estimates of fracture risk associated with alendronate, relative to placebo or no treatment, among postmenopausal women^*^

Author, Year | # Trials | Sample Size | RR | (95% CI)
Vertebral Fractures
Original 2007 Report
Cranney, 2002^29^
Prevention trials, dose > 5 mg/d | 2 | 1,355 | 0.45 | (0.06, 3.15)
Treatment trials, dose > 5 mg/d | 7 | 8,005 | 0.53 | (0.43, 0.65)
Sawka, 2005^35^ | 2 | 375 | 0.36 | (0.17, 0.77)
Stevenson, 2005^32^
Subjects with osteoporosis or osteopenia | 3 | 5,093 | 0.60 | (0.46, 0.80)
Subjects with osteoporosis or severe osteoporosis | 2 | 2,827 | 0.53 | (0.42, 0.67)
Update Report
Jansen, 2009^36^ 5–20mg/d | 3 | 7,453 | 0.47 | (0.35, 0.57)
Wells, 2008^37^
All trials 5 mg | 3 | 1,314/1,493 | 0.40 | (0.29, 0.55)
10 mg | 4 | 3,486/3,670 | 0.55 | (0.45, 0. 67)
Primary Prevention 5 mg | 0 | n/a | n/a | n/a
10 mg | 1 | 2,214/2,218 | 0.55 | (0.38, 0.80)
Secondary Prevention 5 mg | 3 | 1,314/1,493 | 0.40 | (0.29, 0.55)
10 mg | 3 | 1,272/1,452 | 0.55 | (0.43, 0.69)
Nonvertebral Fractures
Original 2007 Report
Boonen, 2005^34^ | 3 | 7,453 | 0.86 | (0.76, 0.97)
Cranney, 2002^29^
All trials, 5 mg/d | 8 | 8,603 | 0.87 | (0.73, 1.02)
All trials, 10–40 mg/d | 6 | 3,723 | 0.51 | (0.38, 0.69)
Treatment trials, 10–40 mg/d | | | 0.51 | (0.38, 0.69)
Karpf, 1997^30^ | 5 | 1,602 | 0.71 | (0.50, 1.00)
Sawka, 2005^35^ | 2 | 375 | 0.73 | (0.32, 1.67)
Stevenson, 2005^32^
Subjects with osteoporosis or osteopenia | 3 | 6,626 | 0.74 | (0.52, 1.06)
Subjects with osteoporosis or severe osteoporosis | 2 | 3,021 | 0.81 | (0.66, 0.98)
Update Report
Wells, 2008^37^
All trials 5 mg | 2 | 591/592 | 0.95 | (0.34, 2.67)
10 mg | 5 | 4,843/4,638 | 0.84 | (0.74, 0.94)
Primary Prevention 5 mg | 1 | 498/501 | 1.50 | (0.82, 3.05)
10 mg | 1 | 2,214/2,218 | 0.89 | (0.76, 1.04)
Secondary Prevention 5 mg | 1 | 93/91 | 0.55 | (0.26, 1.18)
10 mg | 4 | 2,629/2,420 | 0.77 | (0.64, 0.92)
Hip Fractures
Original 2007 Report
Cranney, 2002^29^
All trials, 5 mg/d | 8 | 8,603 | 0.70 | (0.46, 1.05)
All trials, 10-40 mg/d | 6 | 3,723 | 0.45 | (0.18, 1.13)
All trials, 5-40 mg/d | 11 | 11,808 | 0.63 | (0.43, 0.92)
Karpf, 1997^30^ | 5 | 1,602 | 0.46 | (0.15, 1.36)
Nguyen, 2006^33^ | 6 | 10,389 | 0.55 | (0.27, 1.12)
Papapoulos, 2005^31^
Subjects with T score < 2.0 or with vertebral fracture | 6 | 9,023 | 0.55 | (0.36, 0.84)
Subjects with T score < 2.5 or with vertebral fracture | 6 | 6,804 | 0.45 | (0.28, 0.71)
Stevenson, 2005^32^
Subjects with osteoporosis or osteopenia | 2 | 5,426 | 0.68 | (0.30, 1.54)
Subjects with osteoporosis or severe osteoporosis | 2 | 3,021 | 0.46 | (0.23, 0.91)
Update Report
Wells, 2008^37^
All trials 5 mg | 0 | n/a | n/a | n/a
10 mg | 6 | 5,005/4,802 | 0.61 | (0.40, 0.92)
Primary Prevention 5 mg | 0 | n/a | n/a | n/a
10mg | 1 | 2,214/2,218 | 0.79 | (0.44, 1.44)
Secondary Prevention 5 mg | 0 | n/a | n/a | n/a
10 mg | 5 | 2,792/2,584 | 0.47 | (0.26, 0.85)
Forearm/Wrist Fractures
Original 2007 Report
Cranney, 2002^29^
All trials, 5 mg/d | 8 | 8,603 | 0.84 | (0.51, 1.40)
All trials, 10-40 mg/d | 6 | 3,723 | 0.48 | (0.29, 0.78)
Karpf, 1997^30^ | 5 | 1,602 | 0.39 | (0.19, 0.78)
Stevenson, 2005^32^
Subjects with osteoporosis or Osteopenia | 2 | 5,426 | 0.67 | (0.19, 2.32)
Subjects with osteoporosis or established osteoporosis | 2 | 3,071 | 0.48 | (0.31, 0.75)
Update Report
Wells, 2008^37^
All trials 5 mg | 0 | n/a | n/a | n/a
10 mg | 5 | 4,843/4,638 | 0.68 | (0.34, 1.37)
Primary Prevention 5 mg | 0 | n/a | n/a | n/a
10 mg | 1 | 2,214/2,218 | 1.19 | (0.87, 1.62)
Secondary Prevention 5 mg | 0 | n/a | n/a | n/a
10 mg | 4 | 2,629/2,420 | 0.50 | (0.34, 0.73)

* Cranney: ‘treatment trial’ population has T-score < -2 SD and/or baseline prevalence of fracture is >20% and/or average age is >62; ‘prevention trial’ population has T-score ≥ -2 SD and/or baseline prevalence of fracture is ≤20% and/or average age is ≤62. Stevenson: severe osteoporosis defined as T-score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T-score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

Vertebral fracture risk reduction associated with alendronate relative to placebo ranged from 40 percent to 64 percent; with one exception (a study testing a lower preventive 5 mg alendronate dose that found no significant increase or decrease in fracture risk with alendronate versus placebo), all studies showed a statistically significantly lower relative risk of vertebral fracture associated with alendronate compared to placebo or no treatment (Table 4).

The reduction in nonvertebral fracture risk with 10 mg or more alendronate vs. placebo ranged from 11 percent to 49 percent, and all but one study showed statistically significant reduction in nonvertebral fracture risk with a dose of 10 mg or more of alendronate versus placebo or no treatment. In contrast, nonvertebral fracture risk was not statistically significantly reduced with 5 mg doses of alendronate relative to placebo or no treatment.

The reduction in hip fracture risk associated with alendronate vs. placebo or no treatment ranged from 21 percent to 55 percent, and was statistically significant in 6 of the 12 pooled estimates. There was a suggestion that the effect was not statistically significant in the primary prevention setting (osteopenia as opposed to osteoporosis), and with doses lower than 10 mg daily. Thus, differences in baseline disease severity and alendronate doses across trials may explain heterogeneity in magnitudes and statistical significance of estimates of hip fracture reduction associated with alendronate use.

Alendronate in doses of 10 mg or more daily versus placebo or no treatment was associated with a statistically significant reduction in risk of wrist fracture, but reduction in risk of wrist fractures was not statistically significant with alendronate dosing of 5 mg daily, or with less severe pre-existing disease (primary prevention, osteopenia).

###### New Original Placebo-Controlled Studies

Characteristics of RCTs that examined fracture risk with alendronate (and were not included in a prior systematic review) vs. placebo are displayed in Table 5. Seven studies were included in the original report and three studies were newly identified for this report.55-57 The quality of the newly identified studies, assessed according to the method of Jadad, scores of the new studies were 5, 0, and 5. In addition to possible differences in effect by dose and baseline disease severity (primary vs. secondary prevention, osteopenia vs. osteoporosis) noted in the pooled estimates (above), other study characteristics may explain differences in estimates of fracture risk reduction across alendronate studies (Table 5). Although longer alendronate treatment was not associated with a statistically significant decrease in overall fracture risk, only the study with a longer alendronate treatment duration (54 months) was associated with a statistically significant (57 percent) reduction in vertebral fracture risk (Table 5). Small absolute numbers of fracture events and small numbers of participants in several of the studies (ranging from 1 to 9 fracture events in all but one study) may contribute to the lack of statistical significance of the reduction in vertebral fracture risk associated with alendronate vs. placebo. Similarly, the estimates of reductions in nonvertebral fracture risk with alendronate vs. placebo were not statistically significant, but total numbers of fractures in the three studies were low, ranging from 1 event to 10 events. Compared to placebo, alendronate was associated with a 70 percent statistically significant reduction in hip fracture risk. Because no wrist or humerus fractures occurred in studies of alendronate vs. placebo, we do not display estimates of reduction in risk of wrist or humerus fracture associated with alendronate.

Table 5 Randomized controlled trials assessing risk of fracture for alendronate, any dose, relative to placebo, by anatomical site of fracture group (not included in prior meta-analyses)

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Alendronate | Number of Fractures, Placebo | Odds Ratio (95% CI)
Total Fractures
Original 2007 Report
Bone, 2000^58^ | 24 months | Any clinical fracture | 5/92 | 4/50 | 0.65 (0.16, 2.66)
Greenspan, 2003^59^ | 36 months | Clinical fracture | 7/93 | 9/93 | 0.76 (0.27, 2.12)
Hosking, 2003^60^ | 12 months | Clinically diagnosed vertebral or nonvertebral | 6/172 | 2/89 | 1.52 (0.34, 6.67)
Update report: No new studies
Vertebral Fractures
Original 2007 Report
McClung, 2006^61^ | 12 months | Clinical vertebral fracture | 1/46 | 1/46 | 1.00 (0.06, 16.23)
Quandt, 2005^62^ | 54 months | Clinical vertebral fracture | 12/1,878 | 29/1,859 | 0.43 (0.23, 0.79)
Zein, 2005^63^ | 12 months | New compression/vertebral fracture | 1/14 | 0/13 | 6.88 (0.14, 347.7)
Update Report
Papaioannou,2008^55^ | 12 months | Vertebral | 0/23 | 2/24 | 0.14 (0.01, 2.23)
Ringe, 2007^56,a^ | 24 months | Vertebral | 4/30 | 5/30 | 0.77 (0.19, 3.15)
Nonvertebral Fractures
Original 2007 Report
Zein, 2005^63^ | 12 months | Peripheral fracture | 0/14 | 1/13 | 0.13 (0.00, 6.33)
Update Report
de Nijs, 2006^57^ | 18 months | Nonvertebral | 2/99 | 3/101 | 0.68 (0.12,3.99)
Ringe, 2007^56,*^ | 24 months | Nonvertebral | 6/30 | 4/30 | 1.6 (0.42,6.16)
Hip Fractures
Original 2007 Report
Sato, 2006^64^ | 48 months | Hip fracture | 4/131 | 14/129 | 0.30 (0.12, 0.78)
Update Report: No new studies
Wrist Fractures
Original 2007 Report
McClung, 2006^61^ | 12 months | Radius, ulna, or both | 0/46 | 0/46 | NC
Update Report: No new studies
Humerus Fractures (Original 2007 report, no new studies for current report)
McClung, 2006^61^ | 12 months | Humerus | 0/46 | 0/46 | NC
Update Report: No new studies

NC = not calculable

* Numbers of fractures are presented for the group assigned to receive alendronate + calcium + vitamin D in comparison to the group assigned to receive alfacalcidol + calcium.

Using the criteria of Gartlehner and colleagues25 to assess the applicability of the three new studies, we determined that they were moderately applicable: In particular, two studies were small, and one enrolled only individuals using glucocorticoids to control autoimmune diseases.

In summary, pooled analyses and RCTs provide a high level of evidence that treatment of osteoporosis with alendronate 10 mg daily compared to placebo significantly reduces the risk of vertebral fracture, nonvertebral fracture, and hip fracture in patients with osteoporosis. Data are less compelling about nonvertebral and hip fractures in patients without osteoporosis.

###### Risedronate

###### Prior Systematic Reviews

We found 10 systematic reviews that reported the relative risk of fracture with risedronate vs. placebo or no treatment32-34,65-71 (Table 6). Together, these systematic reviews encompassed 14 RCTs. Of the 10 systematic reviews, eight addressed vertebral fracture risk, five addressed non-vertebral fracture risk, three addressed hip fracture risk, and two addressed wrist fracture risk.

Table 6 Randomized controlled trials included in systematic reviews of effect of risedronate on fracture relative to placebo or no treatment

| Systematic Review (Author, Year)
| Cra, 2002^65^ | | Ste, 2005^32^ | | | | Boo, 2005^34^ | Mil, 2005^66^ | Ngu, 2006^33^ | Wat, 2003^87^ | Wal, 2000^68^ | Bia, 2008^69^ | Wel, 2008^70^ | | | | Zho, 2009^71^
| Fracture Type
RCTs (Author, Year) | V | NV | V | NV | H | W | NV | V | H | V | V | V | V | NV | H | W | V | NV
Clemmensen, 1997^88^ | X | X | | | | | | | | | | | X | X
Cohen, 1999^89^ | | | | | | | | | | | X
Fogelman, 2000^90^ | X | X | | | | | | X | | | | | X | X
Harris, 1999^91^ | X | X | X | X | X | X | X | X | X | X | | X | X | X | X | X
Hooper, 2005^92^ | | | | | | | | X
McClung, 1998^93,*^ | | X | | | | | | X | | | | | X | X
McClung, 2001^94,*^ | | X | | | X | | X | X | X | | | | | X | X
Mortensen, 1998^95^ | X | X
Reginster, 2000^96^ | X | X | X | X | X | X | X | X | X | X | | X | X | X | X | X
Reid, 2000^97^ | | | | | | | | | | | X | X | X | X | X
Reid, 2001^98^ | | | | | | | | | | | | | | | | | X
Ringe, 2006^81^ | | | | | | | | | | | | | | | | | X | X
Sato, 2005^78^ | | | | | | | | | | | | | | | | | | X
Sato, 2007^72^ | | | | | | | | | | | | | | | | | | X

V=vertebral, NV=nonvertebral, H=hip, W=wrist/forearm; X= Included in pooled analysis

* Same study reported in two different abstracts.

References for systematic reviews: Cranney, Endocr Rev, 2002^29^; Stevenson, Health Technol Assess, 2005^32^; Boonen, Osteoporos Int, 2005^34^; Miller, J Bone Miner Res, 2005^66^; Nguyen, J Bone Miner Res, 2006^33^; Watts, J Clin Endocrinol Metab, 2003^87^; Wallach, Calcif Tissue Int, 2000^68^; Bianchi, Curr Med Res Opin, 2008^69^; Wells, Cochrane Database Syst Rev, 2008^70^; Zhong, Clin Drug Investig, 2009^71^

Compared to the original 2007 report, we found additional pooled estimates of the relative risk of fracture with risedronate vs. placebo or no treatment: two new estimates for vertebral fractures, two for nonvertebral fractures, one for hip fractures, and one for wrist fractures (Table 7).

Table 7 Pooled risk estimates of fracture for risedronate, relative to placebo or no treatment^*^

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Original 2007 Report
Cranney, 2002^65^ | 5 | 2,604 | 0.64 | (0.54, 0.77)
Miller, 2005^66^
Subjects with severe renal impairment | 9 | 232 | 0.56 | (0.11, 0.78)
Subjects with moderate renal impairment | 9 | 2,426 | 0.45 | (0.31, 0.57)
Subjects with mild renal impairment | 9 | 3,088 | 0.32 | (0.14, 0.46)
Stevenson, 2005^32^ | 2 | 2,064 | 0.62 | (0.50, 0.77)
Update Report
Zhong, 2009^71,†^ | 4 | 1,022 | 0.31 | (0.16, 0.60)
Wells, 2008^70^
Overall 2.5mg^‡^ | 4 | 1,460/1,532 | 0.62 | (0.46, 0.83)
5 mg | 4 | 1,534/1,532 | 0.63 | (0.51, 0.77)
Primary 2.5 mg^‡^ | 1 | 127/135 | 1.08 | (0.48, 2.46)
5 mg | 2 | 166/161 | 0.97 | (0.42, 2.25)
Secondary 2.5 mg^‡^ | 3 | 1,333/1,407 | 0.57 | (0.42, 0.78)
5 mg | 3 | 1,405/1,407 | 0.61 | (0.50, 0.76)
Nonvertebral Fractures
Original 2007 Report
Boonen, 2005^34^ | 3 | 11,770 | 0.81 | (0.71, 0.92)
Cranney, 2002^65^ | 7 | 12,958 | 0.73 | (0.61, 0.87)
Stevenson, 2005^32^ | 2 | 2,439 | 0.67 | (0.50, 0.90)
Update Report
Zhong, 2009^71,†^ | 4 | 1,022 | 0.40 | (0.23, 0.70)
Wells, 2008^70^
Overall 2.5mg^‡^ | 2 | 235/305 | 0.50 | (0.21, 1.19)
5 mg | 5 | 7,731/4,666 | 0.80 | (0.72, 0.90)
Primary 2.5 mg^‡^ | 1 | 127/125 | 0.49 | (0.1, 1.92)
5 mg | 1 | 129/125 | 0.81 | (0.25, 2.58)
Secondary 2.5 mg^‡^ | 1 | 108/180 | 0.51 | (0.17, 1.53)
5 mg | 4 | 7,602/4,541 | 0.80 | (0.72, 0.90)
Hip Fractures
Original 2007 Report
Nguyen, 2006^33^ | 3 | 7,196 | 0.66 | (0.11, 3.68)
Stevenson, 2005^32^
Subjects with osteoporosis or osteopenia | 3 | 4,142 | 0.60 | (0.42, 0.88)
Subjects with osteoporosis or severe osteoporosis | 3 | 7,884 | 0.66 | (0.48, 0.89)
Update Report
Wells, 2008^70^
Overall 5 mg | 3 | 7,425/4,361 | 0.74 | (0.59,0.94)
Primary 5 mg | 1 | 37/36 | NE^b^
Secondary 5 mg | 3 | 7,425/4,361 | 0.74 | (0.59,0.94)
Wrist Fractures
Original 2007 Report
Stevenson, 2005^32^
Subjects with severe osteoporosis | 2 | 2,439 | 0.68 | (0.43, 1.08)
Update Report
Wells, 2008^70^
Overall 5mg | 2 | 1,265/1,263 | 0.67 | (0.42, 1.07)
Primary 5 mg | 1 | 37/36 | NE
Secondary 5 mg | 2 | 1,228/1,227 | 0.67 | (0.42, 1.07)

NE = not estimable

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

† Men.

‡ The 2.5mg dose is no longer available.

The two meta-analyses of primary prevention studies revealed no statistically significant reductions in vertebral fracture associated with risedronate vs. placebo or no treatment, but the remainder of the pooled estimates suggested reductions of 46 percent to 69 percent in risk of vertebral fractures with risedronate relative to placebo or no treatment. Among subgroups with mild, moderate, and severe renal impairment, risedronate was associated with statistically significant (44 percent to 68 percent) reduction in vertebral fracture risk, but overlapping confidence internals do not allow assessment of whether effects vary by degree of renal impairment.

Except in the primary prevention setting, compared to placebo or no treatment, risedronate was associated with a statistically significant 19 percent to 60 percent reduction in nonvertebral fracture risk. In the primary prevention setting, and with dosing of 2.5 mg daily, risedronate was not associated with reduction in nonvertebral fractures.

Four of the five available pooled estimates reported statistically significant reductions (ranging from 36-40 percent) in hip fracture risk with risedronate therapy vs. placebo or no treatment. The association of risedronate with reduced hip fracture risk was not estimable separately in the primary prevention setting.

Pooled estimates show no statistically significant reduction in risk of wrist fractures with risedronate relative to placebo or no treatment.

###### New Original Placebo Controlled Studies

The original report included nine RCTs not included in a prior systematic review that compared the effects of risedronate on fracture risk with that of placebo. Four additional studies were identified for the current report, with Jadad scores ranging from 1 to 5.^72-75^ Characteristics of RCTs that analyzed the relative reductions in fracture risk with risedronate vs. placebo are displayed in Table 8 according to anatomical site of fracture. Risedronate (all doses in aggregate) was not associated with reduction in fractures in aggregate. Here we describe the results by dose compared with placebo.

Table 8 Risk of fracture for risedronate, relative to placebo, by dose and fracture group

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Risedronate | Number of Fractures, Placebo | Odds Ratio (95% CI)
Any Dose, All Fractures
Original 2007 Report
Greenspan, 2006^83^ | 12 months | Fracture | 2/43 | 0/44 | 7.75 (0.48, 125.9)
Hosking, 2003^60^ | 12 months | Clinically diagnosed vertebral or nonvertebral | 6/178 | 2/89 | 1.47 (0.33, 6.52)
Milgrom, 2004^82^ | 14 weeks | All stress fracture | 24/165 | 21/159 | 1.12 (0.60, 2.10)
Update Report: No new studies
2.5 mg Daily, Vertebral
Original 2007 Report
Kanaji, 2006^76^ | 12 months | Vertebral | 0/12 | 0/11 | NC
Update Report: No new studies
2.5 mg Daily, Nonvertebral
Original 2007 Report
Sato, 2005^77^ | 18 months | Nonvertebral | 8/231 | 29/230 | 0.29 (0.15, 0.57)
Update Report: No new studies
2.5 mg^*^ Daily, Hip
Original 2007 Report
Sato, 2005^77^ | 18 months | Hip | 5/231 | 19/230 | 0.29 (0.13, 0.66)
Sato, 2005^78^ | 18 months | Hip | 2/134 | 10/133 | 0.25 (0.08, 0.78)
Sato, 2005^79^ | 12 months | Hip | 1/172 | 7/173 | 0.22 (0.05, 0.88)
Update Report
Sato, 2007^72^ | 24 months | Hip | 3/121 | 9/121 | 0.35 (0.11, 1.12)
5.0 mg Daily, Vertebral
Original 2007 Report
Sorensen, 2003^80^ | 24 months | Vertebral | 15/109 | 29/103 | 0.42 (0.22, 0.81)
Update Report: No new studies
5.0 mg Daily, Nonvertebral
Original 2007 Report
Sorensen, 2003^80^ | 24 months | Nonvertebral | 7/135 | 11/129 | 0.59 (0.23, 1.54)
Update Report
Ringe, 2009^73^ | 24 months | Nonvertebral | 18/152 | 33/148 | 0.48 (0.26, 0.87)
Ringe, 2006^81^ | 12 months | Nonvertebral | 10/158 | 17/158 | 0.57 (0.26, 1.25)
5.0 mg Daily, Humerus
Original 2007 Report
Sorensen, 2003^80^ | 24 months | Humerus | 3/136 | 6/130 | 0.48 (0.13, 1.81)
Update Report: No new studies
30-35 mg Weekly, All Fractures
Greenspan, 2006^83^ | 12 months | Fracture | 2/43 | 0/44 | 7.75 (0.48, 125.9)
Milgrom, 2004^82^ | 14 weeks | All stress fractures | 24/165 | 21/159 | 1.12 (0.60, 2.10)
Update report: no new studies
35 mg Weekly, Vertebral
Original 2007 report
Palomba, 2005^84^ | 12 months | Vertebral | 5/40 | 14/41 | 0.30 (0.11, 0.84)
Update Report
Boonen, 2009^74^ | 2 years | Vertebral | 2/191 | 0/93 | 4.45 (0.23, 85.68)
Palomba, 2008^75^ | 2 years | Vertebral | 4/40 | 7/41 | 0.55 (0.16, 1.95)
Palomba, 2008^75^ | 3 years | Vertebral | 3/40 | 9/41 | 0.32 (0.1, 1.09)
35 mg Weekly, Nonvertebral
Original 2007 Report
Palomba, 2005^84^ | 12 months | Nonvertebral | 0/40 | 4/41 | 0.13 (0.02, 0.95)
Update Report
Palomba, 2008^75^ | 2 years | Nonvertebral | 1/40 | 7/41 | 0.2 (0.05, 0.85)
Palomba, 2008^75^ | 3 years | Nonvertebral | 1/40 | 4/41 | 0.29 (0.05, 1.75)

NC = not calculable

* The 2.5mg dose is no longer available.

Risedronate 2.5 mg Daily Dose. Vertebral fracture risk reduction associated with the 2.5 mg dose of risedronate was not evaluable due to inadequate numbers of events in the one available RCT.76 Compared to placebo, risedronate 2.5 mg daily was associated with 71 percent reduced risk of nonvertebral fracture.77 Three of four RCTs reported statistically significantly decreased risk of hip fracture with risedronate 2.5 mg daily vs. placebo, ranging from 71 percent to 78 percent.72,77-79

Risedronate 5.0 mg Daily Dose. In one RCT, compared to placebo, risedronate 5 mg daily was associated with a statistically significant 58 percent reduction in vertebral fracture risk, but no statistically significant reduction in humerus fracture risk.80 The reduction of nonvertebral fracture risk associated with risedronate 5 mg daily vs. placebo was not statistically significant in two comparisons,80,81 including one 12-month study of men with primary or secondary osteoporosis,81 but was significant in the same study at 24-months.73

Risedronate 30-35 mg Weekly Dose. Overall fracture risk was not statistically different with risedronate 30-35 mg weekly compared to placebo.82,83 In three of four comparisons, risedronate 35 mg weekly vs. placebo was not associated with a statistically significant reduction in risk of vertebral fractures.74,75,84 In two of three comparisons involving the same population of postmenopausal women at 12, 24, and 36 months, the relative risk of nonvertebral fracture with risedronate 35 mg weekly vs. placebo was significantly decreased (0.13-0.20).75,84

Using the criteria of Gartlehner et al.25, to assess the applicability of the four new studies, we determined that they were moderately to highly applicable. However, two of the studies enrolled only men, a third enrolled only patients with inflammatory bowel disease, and the largest excluded many comorbid disorders.

###### New Original Head-to-Head Dosing Comparisons

Five studies compared dosing regimens head to head: three from the original report and two identified for this report.85 86 The Jadad scores for these two studies were 1 and 2. Table 9 shows the head-to-head comparisons of various doses of risedronate, including 2.5 mg daily, 5 mg daily, 17.5 mg weekly, 35 mg weekly, 50 mg weekly, and 150 mg monthly on two consecutive days per month. The combination of the studies from the original report and the newly identified studies provide 12 comparisons among different doses of risedronate in relation to vertebral and nonvertebral fracture risk. In general, all of the direct comparisons among various doses of risedronate showed no statistically significant differences in the relative risk of vertebral or nonvertebral fracture among the different doses although the 95% confidence intervals for some estimates are quite wide, meaning that clinically important differences could not be excluded. Using the criteria of Gartlehner et al.,25 to assess the applicability of the two new studies identified for this report, we determined that their applicability was moderately high.

Table 9 Randomized controlled trials assessing risk of fracture for risedronate, relative to different doses of risedronate, by fracture group (not included in prior systematic reviews)

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Risedronate, Weekly^*^ | Number of Fractures, Risedronate, Daily | Odds Ratio (95% CI)^†^
Risedronate 2.5 Mg/D vs. Risedronate 17.5 mg/Week
Vertebral
Original 2007 report
Kishimoto, 2006^99^ | 48 weeks | Vertebral | 6/222 | 5/227 | 1.23 (0.37, 4.00)
Update report: No new studies
Risedronate 5 Mg/D vs. Risedronate 35 mg/Week
Vertebral
Original 2007 report
Brown, 2002^100^ | 24 months | New morphometric vertebral | 6/480 | 5/485 | 1.21 (0.37, 3.98)
Harris, 2004^101^ | 24 months | Morphometric vertebral | 12/415 | 7/422 | 1.92 (0.75, 4.88)
Update report: No new studies
Nonvertebral
Original 2007 report
Brown, 2002^100^ | 24 months | Any non-vertebral | 24/480 | 28/485 | 0.86 (0.49, 1.50)
Update report: No new studies
Risedronate 5 Mg/D vs. Risedronate 50 mg/Week
Vertebral
Original 2007 report
Brown, 2002^100^ | 24 months | New morphometric vertebral | 6/480 | 2/491 | 2.8 (0.7, 11.26)
Harris, 2004^101^ | 24 months | Morphometric vertebral | 12/415 | 7/422 | 1.74 (0.70, 4.32)
Update report: No new studies
Nonvertebral
Original 2007 report
Brown, 2002^100^ | 24 months | Any non-vertebral | 24/480 | 24/491 | 1.02 (0.57, 1.83)
Update report: No new studies
Risedronate 35 Mg/Week vs. Risedronate 50 mg/Week
Vertebral
Original 2007 report
Brown, 2002^100^ | 24 months | New morphometric vertebral | 5/485 | 2/491 | 1.19 (0.68, 2.08)
Harris, 2004^101^ | 24 months | Morphometric vertebral | 12/415 | 7/422 | 0.9 (0.30, 2.68)
Update report: No new studies
Non-Vertebral
Original 2007 report
Brown, 2002^100^ | 24 months | Any nonvertebral | 28/485 | 24/491 | 1.19 (0.68, 2.08)
Update report: No new studies
Risedronate 150 mg Daily for 2 Consecutive Days per Month vs. Risedronate 5 mg/D
Vertebral
Original 2007 report: No comparable studies from the original report
Update report
Delmas, 2008^85^ | 12 months | Vertebral | 6/616 | 7/613 | 0.85 (0.29, 2.54)
Delmas, 2008^86^ | 12 months | Vertebral | 8/650 | 8/642 | 0.99 (0.37, 2.65)

NC=not calculable

* Number of fractures/number of participants included in treatment arm.

† An odds ratio greater than 1 indicates higher risk of fracture in the group receiving active treatment.

In summary, for treatment of osteoporosis, compared to placebo, risedronate in any currently FDA-approved dosing regimen decreases the risk of vertebral, nonvertebral, and hip fractures.

###### Ibandronate

###### Prior Systematic Reviews

The antifracture effects of ibandronate vs. placebo or no treatment was examined in three meta-analyses (two specific to ibandronate102,103 and the third covering multiple bisphosphonates)36 (Table 10).

Table 10 Randomized controlled trials included in systematic review of effect of ibandronate on fracture relative to placebo or no treatment by fracture type

| Systematic Review (Author, Year)
| Cranney, 2009^102,*^ | Harris, 2008^103^ | | Jansen, 2009^36^
| Fracture Type
RCTs (Author, Year) | NV | A | NV | V
Chestnut, 2004 107 | X | X | X | X
Recker, 2004^108^ | X | X | X
Miller, 2005^109^ | X
Delmas, 2006^110^ | X

V = vertebral; A = all; NV = nonvertebral; X = included in pooled analysis

* Studies within drug comparison.

Pooled estimates of the effects of ibandronate among postmenopausal women from the three meta-analyses are summarized in Table 11, including separate pooled estimates by tertile of annual cumulative exposure for one of the meta-analyses.103 We include RCT evidence for the effect of ibandronate vs. placebo in reducing vertebral fracture risk (51 percent statistically significant). In postmenopausal women, the RR of nonvertebral fracture was not significantly different with ibandronate less than 7.2 mg daily (lower annual cumulative exposure, which includes the 2.5 mg daily oral dose) vs. placebo. A statistically significant reduction in RR of nonvertebral fracture and of clinical fracture, of approximately 30 percent, was apparent only with higher annual cumulative exposure, i.e. 10.8 mg or more, a dosing regimen that includes 150 mg monthly oral dose and the 3 mg quarterly IV dose.

Table 11 Pooled risk estimates of fracture for ibandronate, relative to lower dose, placebo, or no treatment, among postmenopausal women

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Original Report: No comparable studies from the original report
Update Report:
Jansen, 2009^36^
2.5 mg/d or 20 mg every other day | 1 | 2.946 | 0.49 | (0.26, 0.66)
Nonvertebral Fractures
Original Report: No comparable studies from the original report
Update Report
Cranney, 2009 102
Lower ACE (5.5 mg) vs. placebo^*^ | 3 | 3,212 | 1.073^†^ | (0.79, 1.46)
Harris, 2008 103
Key Nonvertebral Site Fractures
Higher ACE (≥10.8 mg) all-years^‡^ | 4 | 8,710 | 0.66^§,**^ | (0.45. 0.96)
Higher ACE (≥10.8 mg) two-years | 4 | 8,710 | 0.72 | (0.48, 1.08)
Mid ACE (5.5-7.2 mg) all-years | 4 | 8,710 | 1.15 | (0.90, 1.46)
Mid ACE (5.5-7.2 mg) two-years | 4 | 8,710 | 1.23 | (0.93, 1.64)
Low ACE (≤4.0 mg) all years | 4 | 8,710 | 0.87 | (0.66, 1.15)
Low ACE (≤4.0 mg) two-years | 4 | 8,710 | 0.93 | (0.66, 1.31)
All Nonvertebral Fractures
Higher ACE (≥10.8 mg) all-years | 4 | 8,710 | 0.70^**^ | (0.50, 0.99)
Higher ACE (≥10.8 mg) two-years | 4 | 8,710 | 0.73 | (0.51, 1.04)
Mid ACE (5.5-7.2 mg) all-years | 4 | 8,710 | 1.04 | (0.83, 1.20)
Mid ACE (5.5-7.2 mg) two-years | 4 | 8,710 | 1.06 | (0.82, 1.38)
Low ACE (≤4.0 mg) all-years | 4 | 8,710 | 0.89 | (0.69, 1.15)
Low ACE (≤4.0 mg) two-years | 4 | 8,710 | 0.87 | (0.64, 1.18)
Clinical Vertebral and Nonvertebral Fractures ††
Original Report: No comparable studies from the original report
Update Report
Harris, 2008^103^
Higher ACE (≥10.8 mg) all-years | 4 | 8,710 | 0.73^**^ | (0.56, 0.95)
Higher ACE (≥10.8 mg) two-years | 4 | 8,710 | 0.71^**^ | (0.54, 0.93)
Mid ACE (5.5-7.2 mg) all-years | 4 | 8,710 | 0.92 | (0.77, 1.09)
Mid ACE (5.5-7.2 mg) two-years | 4 | 8,710 | 0.88 | (0.72, 1.08)
Low ACE (≤4.0 mg) all years | 4 | 8,710 | 0.82 | (0.67, 1.00)
Low ACE (≤4.0 mg) two years | 4 | 8,710 | 0.76^**^ | (0.60, 0.97)

* ACE: annual cumulative exposure (annual dose [mg] × bioavailability [0.6% for oral; 100% for IV]), Higher ACE (>10.8mg) vs. lower ACE (<7.2mg) described in head-to-head comparisons; 150 mg oral once- monthly and 3 mg IV quarterly are both approved, marketed dosages and fall within the high-dose group. The 2.5 mg daily approved dose fell within the low-ACE group.

† Unadjusted hazard ratio.

‡ 4 trials were pooled: two 2-year trials and two 3-year trials; the all-years comparisons included data from all available study years (both 2-year and 3-year). Also, oral and IV routes of administration were pooled.

§ Adjusted hazard ratio.

** Significantly different.

†† Clinical trials include nonvertebral and symptomatic vertebral, all ascertained by x-ray.

###### Original Placebo-Controlled Studies

We classified fracture risk associated with ibandronate vs. placebo according to anatomical fracture site from the three original studies (Table 12) not included in existing systematic reviews (two included in the first report 104,105 and one identified for this report106). The latter study had a Jadad score of 5. After 12 months, ibandronate was associated with a statistically significantly reduction in relative risk of overall fractures compared to placebo (OR 0.002, 95% CI: 0.00, 0.48).104 However, results were conflicting regarding the relative risk of vertebral fracture associated with ibandronate vs. placebo after 12 months, with one trial showing no reduction in risk, and the other showing a statistically significant 85 percent reduction (RR 0.15, 95% CI 0.04, 0. 60). The confidence intervals of these two studies overlap and their numbers of fracture events were small, so that their apparently discrepant conclusions may be due to random variation.

Table 12 Randomized controlled trials assessing risk of fracture for ibandronate, any dose, relative to placebo, by anatomical fracture site (not included in prior systematic reviews)

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Ibandronate^*^ | Number of Fractures, Placebo^*^ | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Ravn, 1996^104^ | 12 months | Fracture | 0/150^†^ | 1/30 | 0.002 (0.00, 0.477)
Update report: No new studies
Vertebral Fractures
Original 2007 Report
Grotz, 2001^105^ | 12 months | Vertebral | 1/40 | 1/40 | 1.00 (0.006, 16.27)
Update Report
Fahrleitner-Pammer, 2009^106^ | 12 months | Morphometric vertebral | 2/17 | 10/18 | 0.15 (.04,.60)

* Number of fractures/number of participants included in treatment arm.

† .0.25mg , 0.50mg, 1.0mg, 2.5mg and 5.0 mg dose groups combined.

The pooled analyses encompassed thousands of participants, whereas the RCTs not included in original meta-analyses had 35-180 participants and few fracture events (ranging from only 1 to 12 fractures). Using the criteria of Gartlehner et al.25 to assess the applicability of the one study newly identified for this report, we determined that its applicability to the general population was moderately low. The population comprised a small group of men who were heart transplant recipients and the analysis was not intention-to-treat.106

If the results of the pooled analysis are classified in terms of the currently available FDA-approved doses of ibandronate, statistically significant reductions in fracture risk are associated with ibandronate doses of 150 mg monthly orally or 3 mg IV quarterly for 3 years (nonvertebral and overall clinical fracture), and for 2.5 mg orally daily for 2 years (overall clinical fractures).

In summary, compared to placebo, ibandronate in currently FDA-approved doses reduces the risk of vertebral, nonvertebral fractures, and overall clinical fractures, in individuals with osteoporosis.

###### Zoledronic Acid

###### Prior Systematic Reviews

We identified no prior systematic reviews of studies assessing the effects of zoledronic acid.

###### Original Placebo-Controlled Studies

Table 13 shows the results of RCTs of intravenous zoledronic acid vs. placebo in postmenopausal women. Two studies were identified from the original report.111,112 Since that report, two additional publications were identified for inclusion in this update (Jadad scores of 5 and 2).113,114 Included RCTs were 12, 24, or 36 months in duration. Doses and dosing intervals tested were 4 mg (single dose), 5 mg (single dose), 2 mg twice yearly, 0.25 mg quarterly, 0.5 mg quarterly, and 1 mg quarterly

Table 13 Randomized controlled trials assessing risk of intravenous zoledronic acid relative to placebo, by dose and frequency among postmenopausal women

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Zoledronic Acid | Number of Fractures, Placebo | Odds Ratio (95% CI)
5 Milligrams Once
Original 2007 report
Black, 2007^111^ | 36 months | Any clinical | 308/3,667 | 456/3,563 | 0.63 (0.54, 0.72)
Black, 2007^111^ | 36 months | Nonvertebral | 292/3,650 | 388/3,626 | 0.73 (0.62, 0.85)
Black, 2007^111^ | 36 months | Morphometric vertebral | 92/2,788 | 310/2,844 | 0.32 (0.26, 0.39)
Black, 2007^111^ | 36 months | Clinical vertebral | 19/3,800 | 84/3,231 | 0.23 (0.16, 0.34)
Black, 2007^111^ | 36 months | Hip | 52/3,714 | 88/3,520 | 0.56 (0.40, 0.78)
Update report
Lyles, 2007^113^ | 24 months | Hip fracture | 23/1,065 | 33/1,062 | 0.69 (0.41, 1.17)
Lyles, 2007^113^ | 24 months | Any fracture | 92/1,065 | 139/1,062 | 0.63 (0.48, 0.83)
Lyles, 2007^113^ | 24 months | Nonvertebral | 79/1,065 | 107/1062 | 0.72 (0.53, 0 .93)
Lyles, 2007^113^ | 24 months | Vertebral | 21/1,065 | 39/1,062 | 0.54 (0.32, 0.90)
4 Milligrams Once
Original 2007 report
Reid, 2002^112^ | 12 months | Nonvertebral | 1/60 | 1/59 | 0.98 (0.06, 15.91)
Reid, 2002^112^ | 12 months | Vertebral | 0/60 | 0/59 | NC
Update report: No new studies
2 Milligrams, Every 6 Months
Original 2007 report
Reid, 2002^112^ | 12 months | Nonvertebral | 1/61 | 1/59 | 0.97 (0.06, 15.65)
Reid, 2002^112^ | 12 months | Vertebral | 0/61 | 0/59 | NC
Update report
Chapman, 2009^114^ | 24 months | Nonvertebral | 0/10 | 0/12 | NC
Chapman, 2009^114^ | 24 months | Vertebral | 0/10 | 0/12 | NC
0.25 Milligrams, Every 3 Months
Original 2007 report
Reid, 2002^112^ | 12 months | Nonvertebral | 0/60 | 1/59 | 0.13 (0.00, 6.71)
Reid, 2002^112^ | 12 months | Vertebral | 0/60 | 0/59 | NC
Update report: No new studies
0.5 Milligrams, Every 3 Months
Original 2007 report
Reid, 2002^112^ | 12 months | Nonvertebral | 1/58 | 1/59 | 1.02 (0.06, 16.46)
Reid, 2002^112^ | 12 months | Vertebral | 0/58 | 0/59 | NC
Update report: No new studies
1 Milligram, Every 3 Months
Reid, 2002^112^ | 12 months | Nonvertebral | 2/53 | 1/59 | 2.2 (0.22, 21.7)
Reid, 2002^112^ | 12 months | Vertebral | 0/53 | 0/59 | NC
Update report: No new studies

NC = not calculable

5 mg Single Dose. RCTs showed statistically significant reduction in any clinical fracture among postmenopausal women (RR 0.63, one RCT),111 nonvertebral fracture among postmenopausal women and men and women post-hip fracture (RR 0.72-0.73, two RCTs),111,113 morphometric vertebral fracture (RR 0.32, one RCT), clinical vertebral fracture (0.23, one RCT),111, and vertebral fracture among men and women post-hip fracture (RR 0.54, one RCT)113 with zoledronic acid vs. placebo. A 36-month RCT reported statistically significant reductions in hip fracture with zoledronic acid vs. placebo among postmenopausal women (RR 0.56, 95% CI: 0.40, 0.78),111 but the shorter trial of 24-month duration in the post-hip fracture population found that hip fracture risk was not statistically significantly decreased with zoledronic acid vs. placebo (RR 0.69, 95% CI: 0.41, 1.17).113

4 mg Single Dose. Among postmenopausal women, only one RCT testing the 4 mg single dose was available; this study was included in the original report.112 The trial recorded 2 fracture events, and had small numbers of participants. Risk of nonvertebral fracture was not statistically significantly different with zoledronic acid vs. placebo. Fractures of other types did not occur in the RCT of this dose of zoledronic acid, prohibiting estimates of the effect of this dose in relation to other types of fracture.

2 mg Every 6 Months. Among postmenopausal women, only two RCTs that tested a 2 mg dose every 6 months were identified, one in the original report112 and one for the current report;114 only the older study reported any fractures. The trial recorded two fracture events, and had small numbers of participants. Risk of nonvertebral fracture was not statistically significantly different with zoledronic acid vs. placebo. Fractures of other types did not occur in RCTs of this dose of zoledronic acid, prohibiting estimates of the effect of this dose in relation to other types of fracture.

0.25 mg Every 3 Months. Among postmenopausal women, only one RCT testing a 0.25 mg dose every 3 months was available.112 The trial recorded one fracture event and had small numbers of participants. Risk of nonvertebral fracture was not statistically significantly different with zoledronic acid vs. placebo. Fractures of other types did not occur in the RCT of this dose of zoledronic acid, prohibiting estimates of the effect of this dose in relation to other types of fracture.

0.5 mg Every 3 Months. Among postmenopausal women, only one RCT testing a 0.5 mg dose every three months was available.112 The trial recorded two fracture events, and had small numbers of participants. Risk of nonvertebral fracture was not statistically significantly different with zoledronic acid vs. placebo. Fractures of other types did not occur in the RCT of this dose of zoledronic acid, prohibiting estimates of effectiveness of this dose in relation to other types of fracture.

1 mg Every 3 Months. Among postmenopausal women, only one RCT testing a 1 mg dose every 3 months was available.112 The trial recorded three fracture events and had small numbers of participants. Risk of nonvertebral fracture was not statistically significantly different with zoledronic acid vs. placebo. Fractures of other types did not occur in the RCT of this dose of zoledronic acid, prohibiting estimates of the effect of this dose in relation to other types of fracture.

Using the criteria of Gartlehner et al.25, to assess the applicability of the two studies newly identified for this report, we determined that their applicability was moderate to high.

In summary, in comparison with placebo, zoledronic acid reduces the risk of clinical fractures, nonvertebral fractures, vertebral fractures, and hip fractures.

##### Biologics

Since the completion of the original report, a new class of agents has been approved for the treatment of osteoporosis in postmenopausal women. The one agent currently constituting this class is the human monoclonal antibody denosumab.

###### Denosumab

###### Prior Systematic Reviews

We found one systematic review of fracture risk associated with denosumab relative to placebo or no treatment.115 (Tables 14 and 15) The systematic review included data from 3 RCTs encompassing 919 participants and assessed risk of clinical fractures, although participants in one of the studies comprised only cancer patients.116 The risk of clinical fracture was reduced, but not statistically significantly so, with denosumab versus placebo (RR 0.74, 95% CI: 0.33, 1.64) (Table 15); however including only 3 trials, the meta-analysis may have been underpowered to detect a change in fracture risk.

Table 14 Randomized controlled trials included in meta-analysis of effect of Denosumab on fracture relative to placebo or no treatment by fracture type

| Meta-analysis (Author, Year)
| Anastasilakis, 2009^115^
| Fracture Type
RCTs (Author, Year) | A
Bone, 2008 117 | X
Ellis, 2008 116 | X
Lewiecki, 2007^119^ | X

A = all; X = included in pooled analysis

Table 15 Pooled risk estimates of fracture for denosumab relative to placebo or no treatment

Author, Year | # Studies | Sample Size | RR | (95% CI)
Clinical Fractures
Original 2007 report: No comparable studies from the original report
Update report
Anastasilakis, 2009^115^ | 3 | 919 | 0.74 | (0.33, 1.64)

###### Original Placebo-Controlled Studies

Two placebo-controlled trials of denosumab were identified for the current report, two years and 36 months in duration (Jadad scores of 2 and 1), respectively (Table 16).117,118 The smaller RCT of shorter duration (two years)117 and with fewer fracture events (nine nonvertebral and one vertebral) found no statistically significant difference in risk of vertebral or nonvertebral fracture with denosumab vs. placebo. The much larger RCT (more than 3,600 participants) reported a statistically significantly lower risk of fracture with denosumab vs. placebo.118 In this study, denosumab was associated with a 41 percent lower risk of hip fracture (OR 0.59, 0.36, 0.94), a 20 percent lower risk of nonvertebral fracture (OR 0.8, 0.67, 0.95), a 60 percent lower risk of multiple new vertebral fracture (OR 0.4, 0.26, 0.61), a 66 percent lower risk of new clinical vertebral fracture (OR 0.34, 0.24, 0.48), and a 66 percent lower risk of vertebral fracture (OR 0.34 0.27, 0.42). Given the larger numbers of participants (several times as many patients as all prior RCTs put together) and longer trial duration, this latter study provides a better estimate of fracture risk reduction associated with denosumab. Using the criteria of Gartlehner et al., to assess the applicability of the two studies newly identified for this report, we determined that the applicability of the smaller study was moderate117 and the applicability of the larger study was high.118

Table 16 Denosumab versus placebo

Author, Year | Study Duration | Fracture Type | Number of Fractures, Denosumab | Number of Fractures, Placebo | Odds Ratio (95% CI)
Original report: No comparable studies from the original report
Update report
Cummings, 2009^118^ | 36 months | Hip fracture | 26/3,714 | 43/3,583 | 0.59 (0.36, 0.94)
Cummings, 2009^118^ | 36 months | Nonvertebral | 238/3,662 | 293/3,663 | 0.8 (0.67, 0.95)
Cummings, 2009^118^ | 36 months | Multiple new vertebral | 23/3,833 | 59/3,688 | 0.4 (0.26, 0.61)
Cummings, 2009^118^ | 36 months | New clinical vertebral | 29/3,625 | 92/3,538 | 0.34 (0.24, 0.48)
Bone, 2008^117^ | 2 years | Nonvertebral | 2/166 | 7/166 | 0.32 (0.09, 1.2)
Cummings, 2009^118^ | 36 months | Vertebral | 86/3,739 | 264/3,667 | 0.34 (0.27, 0.42)
Bone, 2008^117^ | 2 years | Vertebral | 0/166 | 1/166 | 0.14 (0, 6.82)

In summary, compared to placebo, denosumab reduces the risk of vertebral, nonvertebral, and hip fractures in postmenopausal women with osteoporosis.

##### Selective Estrogen Receptor Modulators (SERMs)

In this section, we present results regarding the effects of the SERM raloxifene on fracture prevention. Although the original report included tamoxifen, it was excluded from this report, as it is not primarily used for osteoporosis prevention or treatment. A newer agent, lasofoxifene, has been tested for its efficacy in preventing fracture but is excluded in this report, as it has not been approved for use in the U.S.

###### Raloxifene

###### Prior Systematic Reviews

No new meta-analyses regarding antifracture effects of raloxifene were identified since the last report. The prior report found consistent evidence for a statistically significant reduction in vertebral fractures, ranging from 19-41 percent, with raloxifene vs. placebo (Table 17). In contrast, studies found that, compared to placebo, raloxifene does not decrease the risk of nonvertebral, hip, or wrist fractures.

Table 17 Risk estimates of fracture for raloxifene relative to placebo or no treatment among postmenopausal women as reported in prior meta-analyses^*^

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Schachter, 2005^123^
Ettinger study at four years | 1 | 7,705 | 0.60 | (0.52, 0.69)
Ettinger and Lufkin studies at four years | 2 | 7,848 | 0.81 | (0.43, 1.51)
Stevenson, 2005^32^
Women with severe osteoporosis | 1 | NR | 0.69 | (0.56, 0.86)
Women with severe osteoporosis or osteoporosis | 1 | 4,551 | 0.65 | (0.53, 0.79)
Women with osteoporosis | 1 | NR | 0.53 | (0.35, 0.79)
Women with osteopenia | 1 | NR | 0.53 | (0.32, 0.88)
Seeman, 2006^124^
60 mg | 5 | 5,600 | 0.60 | (0.49, 0.74)
120/150 mg | 4 | 5,403 | 0.51 | (0.41, 0.64)
Non-vertebral Fractures
Stevenson, 2005^32^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 0.92 | (0.79, 1.07)
Hip Fractures
Stevenson, 2005^32^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 1.12 | (0.65, 1.95)
Wrist Fractures
Stevenson, 2005^32^
Women with severe osteoporosis or osteoporosis | 1 | 6,828 | 0.89 | (0.68, 1.15)

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

###### Original Placebo-Controlled Studies

Since the original 2007 report, we have added eight new estimates of fracture risk with raloxifene relative to placebo from two studies (Jadad scores of 4 and 3) (Table 18). 120,121 All but one RCT was consistent with a statistically significant reduction in vertebral fracture risk, ranging from 34 percent -to 44 percent, with raloxifene vs. placebo. The exception was the original RCT with five fracture events (RR 1.72, 0.26, 11.05).122 However, raloxifene was not associated with a statistically significantly decrease in the risk of nonvertebral (two RCTs), hip (one RCT), or wrist (one RCT) fractures.120,121 We conclude that, compared to placebo, raloxifene decreases the risk of vertebral fractures, but not nonvertebral, hip, or wrist fractures.

Table 18 Risk of vertebral fracture for raloxifene, relative to placebo

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Serm | Number of Fractures, Placebo | Odds Ratio (95% CI)
Vertebral Fracture
Original 2007 Report
Reid, 2004^122^ | 36 months | Vertebral | 4/193^*^ | 1/90 | 1.72 (0.26, 11.05)
Update Report
Ensrud, 2008^120^ | 5.6 years | Vertebral | 64/5,044 | 97/5,057 | 0.66 (0.48, 0.90)
Silverman, 2008^121^ | 3 years | Vertebral | 43/1,849 | 77/1,885 | 0.57 (0.39, 0.82)
Silverman, 2008^121^ | 3 years | Vertebral - with prevalent fracture | 50/1,849 | 90/1,885 | 0.56 (0.40, 0.79)
Silverman, 2008^121^ | 3 years | Vertebral - without prevalent fracture | 33/1,849 | 58/1,885 | 0.58 (0.38,.88)
Clinical Vertebral
Original 2007 Report
Barrett-Connor125 | 5.6 years | Clinical | 64/5,044 | 97/5,057 | 0.66 (0.48. 0.90)
Update Report: No new studies
Nonvertebral
Original Report: No comparable studies from the original report
Update Report
Ensrud, 2008^120^ | 5.6 years | Nonvertebral | 428/5,044 | 438/5,057 | 0.99 (0.86, 1.13)
Silverman, 2008^121^ | 3 years | Nonvertebral | 60/1,849 | 99/1,885 | 0.61 (0.44, 0.84)
Hip/femur
Original Report: No comparable studies from the original report
Update Report
Ensrud, 2008^120^ | 5.6 years | Hip/femur fracture | 89/5,044 | 103/5,057 | 0.86 (0.65, 1.15)
Wrist
Original Report: No comparable studies from the original report
Update Report
Ensrud, 2008^120^ | 5.6 years | Wrist | 107/5,044 | 111/5,057 | 0.97 (0.74, 1.26)

* 60 mg and 150 mg dose groups combined.

Using the criteria of Gartlehner et al.25 to assess the applicability of the newly identified studies, we determined their applicability to be moderately high although one study was a large clinical trial with many exclusion criteria.

##### Peptide Hormones

In this section, we present the results of studies assessing the effects of parathyroid hormone (PTH, i.e., teriparatide, PTH [1-34]) on fracture risk. The original report included the peptide hormone calcitonin, but it has been excluded from this report at the subject matter experts' request, since most authorities no longer consider calcitonin to be appropriate treatment for osteoporosis.

###### Parathyroid Hormone

Parathyroid hormone (PTH) has been investigated for use in osteoporosis in several forms, including PTH 1-34 (teriparatide) and PTH 1-84. However, only teriparatide is approved for use in the US for treating osteoporosis.

###### Prior Systematic Reviews

The original report identified one systematic review on parathyroid hormone.32 The meta-analysis conducted for this review included data from five RCTs of teriparatide and examined risk of vertebral, nonvertebral, and hip fractures. One additional systematic review was identified for the current report126 (Table 19); it provided two new pooled estimates regarding fracture risk with use of teriparatide versus placebo or no treatment (Table 20). Teriparatide was associated with reduced relative risk of vertebral fractures, with RR's ranging from 0.31 to 0.36, and reduced relative risk of nonvertebral fractures, with RR's ranging from 0.60 to 0.65.

Table 19 Randomized controlled trials included in meta-analysis of effect of parathyroid hormone on fracture relative to placebo by fracture type

| Systematic Review (Author, Year)
| Stevenson, 2005^32^ | | | | | Vestergaard, 2007^126^
| Fracture Type
RCTs (Author, Year) | V | NV | H | W | Hum | V | NV | H
Cosman, 2004 131 | | | | | | X | X | X
Cosman, 2001 | X
Greenspan, 2005^132^ | | | | | | X | X
Kurland, 2000 133 | | | | | | | | X
Lane, 1998 | | | | | | X | X | X
Neer, 2001 134 | X | X | X | X | X | X | X
Orwoll, 2003 135 | | | | | | X | X

V = vertebral; NV = nonvertebral; H = hip; X = included in pooled analysis

Table 20 Pooled risk estimates of fracture for parathyroid hormone relative to placebo or no treatment^*^

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Original 2007 Report
Stevenson, 2005^32^
All subjects, dose 20 μg/d | 1 | 892 | 0.35 | (0.22, 0.55)
All subjects, dose 40 μg/d | 1 | 882 | 0.31 | (0.19, 0.50)
Subjects with severe osteoporosis | 1 | 892 | 0.35 | (0.22, 0.55)
Update Report
Vestergaard, 2007 126 | 7 | 4,359 | 0.36 | (0.28, 0.47)
Nonvertebral Fractures
Original 2007 Report
Stevenson, 2005^32^
All subjects, dose 20 μg/d | 1 | 1,085 | 0.65 | (0.43, 0.98)
All subjects, dose 40 μg/d | 1 | 1,096 | 0.60 | (0.39, 0.91)
Subjects with severe osteoporosis | 1 | 1,085 | 0.65 | (0.43, 0.98)
Update Report
Vestergaard, 2007^126^ | 5 | 2,377 | 0.62 | (0.48, 0.82)
Hip Fractures
Original 2007 Report
Stevenson, 2005^32^
Subjects with severe osteoporosis | 1 | NR | 0.50 | (0.09, 2.73)
Update Report: no new studies
Wrist Fractures
Original 2007 Report
Stevenson, 2005^32^
Subjects with severe osteoporosis | 1 | NR | 0.54 | (0.22, 1.35)
Update Report: No new studies
Humerus Fractures
Original 2007 Report
Stevenson, 2005^32^
Subjects with severe osteoporosis | 1 | NR | 0.80 | (0.22, 2.98)
Update Report: No new studies

* Stevenson: severe osteoporosis defined as T score <- 2.5 SD AND at least one documented fracture; osteoporosis defined as T score <- 2.5 SD without prior fracture; osteopenia defined as T-score between -1 and -2.5 SD.

###### Original Placebo-Controlled Studies

No new studies of teriparatide were identified for this report. The original report included three studies of teriparatide (Table 21).127-129

Table 21 Risk of fracture for parathyroid hormone, relative to placebo, by fracture group

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Teriparatide | Number of Fractures, Placebo | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Kaufman, 2005^128^ | 30 months | Moderate or severe | 2/176^*^ | 7/103 | 0.16 (0.04, 0.65)
Update Report: No new studies
Vertebral Fractures
Original 2007 Report
Gallagher, 2005^127^ | 21 months | Vertebral | 22/403 | 62/398 | 0.34 (0.22, 0.54)
Kaufman, 2005^128^ | 30 months | Vertebral | 10/176^*^ | 12/103 | 0.44 (0.18, 1.09)
Update Report: No new studies
Nonvertebral Fractures
Original 2007 Report
Gallagher, 2005^127^ | 21 months | Nonvertebral | 30/467 | 46/464 | 0.63 (0.39, 1.00)
Orwoll, 2003^129^ | 11 months | Nonvertebral | 3/290^*^ | 3/147 | 0.48 (0.09, 2.62)
Update Report: No new studies

* 20 μg and 40 μg dose groups combined.

All Fractures. Compared to placebo, teriparatide was associated with a statistically significant 84 percent reduction (one RCT).128

Vertebral Fractures. In the RCT with the fewest number of vertebral fracture events, vertebral fracture risk was no different with PTH than placebo;128 however, the remainder of the RCTs demonstrated vertebral fracture risk to be statistically significantly lower with PTH than with placebo (RRs ranging from 0.34-0.44.^127,129,130^

Nonvertebral Fractures. For nonvertebral fractures, risk with teriparatide was not statistically different from that of placebo in three trials.127,129,130

This finding contrasts with a pooled analysis126 that included two of the three trials along with three other trials, and found a statistically significant 38 percent relative risk reduction with teriparatide treatment.

In summary, compared to placebo, teriparatide, the form of PTH currently available in the U.S., is associated with reduced risk of vertebral fractures and nonvertebral fractures among postmenopausal women with osteoporosis.

##### Steroid Hormones

This section presents the results of studies of menopausal estrogen therapy for women. The original report included both estrogen/progestin and testosterone; however, testosterone has been omitted from this report as it has not been and is not likely to be approved for prevention or treatment of osteoporosis.

###### Menopausal Estrogen Therapy or Combination Estrogen Plus Progestogen Therapy for Women

The original report relied strongly on data from the Women's Health Initiative (WHI), which enrolled postmenopausal women in a randomized comparison of menopausal hormone therapy and assessed a number of different outcomes (cardiovascular, neurologic, etc.) in addition to fracture outcomes. Of note, women were not selected for inclusion based on a diagnosis of osteopenia or osteoporosis, and thus the WHI would not, strictly speaking, be an eligible study for inclusion in this evidence report. Nevertheless, the WHI dwarfs all other studies of menopausal hormone therapy in size and scope and provides the best evidence about its benefits and harms. The WHI, in both its estrogen-only comparison and its estrogen and progesterone comparison, provided strong evidence that menopausal hormone therapy reduces the risk of vertebral fracture and hip fracture.

###### Original Placebo-Controlled Studies

We found one study that provided two new estimates of effects of menopausal estrogen therapy on fracture risk relative to placebo, one for vertebral, and one for nonvertebral fracture (Jadad score 5) (Table 22).136 Overall, RCTs were 24 months, 36 months, or 48 months in duration. Among both the older and the new RCTs, only the RCT with the largest number of vertebral fracture events found a significant association between menopausal estrogen therapy and reduction in risk of overall fractures, vertebral fractures, or nonvertebral fractures compared to placebo.137

Table 22 Risk of fracture for menopausal estrogen therapy, relative to placebo, by fracture group

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Estrogen^†^ | Number of Fractures, Placebo or Control | Odds Ratio (95% CI)
All Fractures
Original 2007 report
Bone, 2000^58^ | 24 months | Any clinical | 10/143 | 4/50 | 0.86 (0.25, 2.97)
Greenspan, 2003^59^ | 36 months | Clinical | 5/93 | 9/93 | 0.54 (0.18, 1.60)
Update Report: No new studies
Vertebral Fractures
Original 2007 Report
Ishida, 2004^137^ | 24 months | Vertebral | 7/66^*^ | 17/66^†^ | 0.36 (0.15, 0.88)
Reid, 2004^122^ | 36 months | Vertebral | 1/102 | 1/90 | 0.88 (0.05, 14.27)
Wimalawansa, 1998^138^ | 48 months | Vertebral | 2/15^*^ | 5/14^†^ | 0.31 (0.06, 1.64)
Update Report
Boone, 2006^136^ | 24 months | Vertebral | 0/16 | 2/15 | 0.12 (.01, 1.98)
Nonvertebral Fractures
Original 2007 Report
Wimalawansa, 1998^138^ | 48 months | Nonvertebral | 1/15^*^ | 1/14^†^ | 0.93 (0.06, 15.69)
Update Report
Boone, 2006^136^ | 24 months | Nonvertebral | 0/16 | 0/15 | NC

NC = not calculable

* Bone, 2000: conjugated equine estrogen; Greenspan, 2003: conjugated equine estrogen±medroxyprogesterone acetate; Reid, 2004: conjugated equine estrogen; Wimalawansa, 1998: conjugated equine estrogen+norgestrel; Boon, 2006: combination topical (patch) estradiol+norethindrone acetate.

† Control group.

Head-to-head trials did not compare antifracture effects of menopausal estrogen therapy alone (ET) and menopausal estrogen + progestogen therapy (EPT). Too few studies and low numbers of fracture events (Table 22) did not permit us to make conclusions regarding relative effectiveness of ET and EPT.

The number of events in all trials was very low, sample sizes in these trials were less than 200 subjects (compared to several thousand in studies of bisphosphonates) and confidence intervals are very wide, meaning that clinically important effects cannot be excluded. Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately low; the population was small and consisted entirely of women with primary biliary cirrhosis.

##### Dietary Supplements

This section presents the results of studies examining the effects of calcium with or without vitamin D; and various forms of vitamin D, with or without calcium, on preventing and treating osteoporotic fractures.

###### Calcium and Vitamin D

###### Prior Systematic Reviews

For calcium alone, four systematic reviews conducted meta-analyses that included a total of 23 RCTs comparing fracture risk with calcium to that of placebo or no treatment (Table 23). Of these four meta-analyses, one meta-analysis examined vertebral fracture risk, two examined nonvertebral fracture risk, two examined hip fracture risk, and one examined overall fracture risk.

Table 23 Randomized controlled trials included in systematic reviews of effect of calcium on fracture relative to placebo or no treatment

| Systematic Review (Author, Year)
| Shea, 2002^165^ | | Bischoff-Ferrari, 2007^139^ | | Boonen, 2007^140^ | Tang, 2007^141^
| Fracture Type
RCTs (Author, Year) | V | NV | NV | H | H | A
Bischoff-Ferrari, 2006/2008^166^ | | | X | X
Chapuy, 1992^167^ | | | | | | X
Chapuy, 1994^168^ | | | | | X
Chapuy, 2002^169^ | | | | | X | X
Chevally, 1994^170^ | X | X | X | | | X
Dawson-Hughes, 1997^171^ | | | | | X | X
Fujita, 2004^158^ | | | | | | X
Grant, 2005^153^ | | | X | X | X | X
Hansson, 1987^172^ | X
Harwood, 2004^173^ | | | | | | X
Jackson, 2006^151^ | | | | | X | X
Larsen, 2004^150^ | | | | | | X
Peacock, 2000^174^ | | | | | | X
Porthouse, 2005^152^ | | | | | X | X
Prince, 1995^175^ | | | | | | X
Prince, 2006^156^ | | | X | X
Recker, 1996^176^ | X | | | | | X
Reid, 1993^177^ | X | | | | | X
Reid, 1995^178^ | | | X | X
Reid, 2006^67^ | | | X | X | | X
Riggs, 1998^179^ | X | X | X | | | X

V = vertebral, NV = non-vertebral, H = hip, A = all; X = Included in pooled analysis

For vitamin D alone, 16 meta-analyses addressed a total of 43 RCTs comparing fracture risk with vitamin D compared to placebo or no treatment (Table 24). Of these 16 meta-analyses, nine meta-analyses examined vertebral fracture risk, 12 examined nonvertebral fracture risk, nine examined hip fracture risk, and three examined overall fracture risk.

Table 24 Randomized controlled trials included in systematic reviews of effect of vitamin D on fracture relative to placebo or no treatment

| Systematic Review (Author, Year)
| Ave, 2005^143^ | | | Bis, 2005^180^ | | Pap, 2002^181^ | | Ste, 2005^32^ | | Ric, 2004^182^ | | Ric, 2005^142^ | | Abr, 2010^146^ | | | Ave, 2009^145^ | | | | | Ber, 2010^147^ | | Bis, 2009^183^ | | Boo, 2007^140^ | Iza, 2007^148^ | | Jac, 2007^184^ | | O'Do, 2008^144^ | | Tan, 2007^141^ | Lai, 2010^149^
| Fracture Type
RCTs (Author, Year) | V | NV | H | NV | H | V | NV | V | NV | V | NV | V | NV | A | V | H | A | V | NV | H | W | NV | H | NV | H | H | NV | H | V | NV | V | NV | A | H
Adachi, 1996^185^ | | | | | | | | | | | | X
Aloia, 1988^186^ | | | | | | | | X | | X
Avenell, 2004^187^ | X | | X | | | | | | | | | | | | | | X | X | X | X | | | | | | | | | | | | | X
Baeksgaard, 1998^188^ | | | | | | X
Bolton-Smith, 2007^189^ | | | | | | | | | | | | | | | | | | | X
Cannigia, 1984^190^ | | | | | | X | | X | | | | | | | | | | X | | | | | | | | | | | | | X
Chapuy, 1992^167^ | | | | | | | X | | | | | | X | | | | | | X | X | | X | X
Chapuy, 1994^168^ | | | | X | X | | | | | | | | | | | | | | | | | | | X | X | X | X | X
Chapuy, 2002^169^ | | | | X | X | | | | | | | | | | | | | | X | X | | X | X | X | X | X | X | X
Dawson-Hughes, 1997^171^ | | | | X | X | | X | | | | | X | | | | | | | X | X | | | | X | | X | X
Dukas, 2004^191^ | | X | | | | | | | | | | | | | | | | | X
Ebeling, 2001^192^ | | | | | | | | | | X | | X
Flicker, 2005^193^ | | | | | | | | | | | | | | | | | X | X | | X | | | | X | | | | | | | | X
Gallagher, 1989^194^ | | | | | | | | | | X | | | X | | | | | X
Gallagher, 1990^195^ | | | | | | | | | | X | | X
Gallagher, 2001^196^ | | | X | | | X | | | X | X | X | X | X | | | | | X | X | X | | | | | | | | | | | X | X
Gorai,1999^197^ | | X | | | | | | | | | | | | | | | | | X | | | | | | | | | | | | X
Grant, 2005^153^ | X | | | | | | | | | | | | | X | X | X | X | X | X | X | | | | X | X | X | | X | | X | | | X | X
Geusens, 1986^198^ | | | | | | X
Harwood, 2004^173^ | | | X | | | | | | | | | | | | | | X | | X | X
Hayashi, 1992^199^ | | | | | | | | | | X | | X
Ishida, 2004^137^ | | | | | | | | | | | | | | | | | | X | X | X | | | | | | | | | | | X | X
Jackson, 2006^151^ | | | | | | | | | | | | | | X | X | X | | X | X | X | | | | X | X | X | | X
Jensen, 1985^200^ | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | X
Komulainen, 1998^201^ | | | | | | | | | | | | | X | | | | | | X | | | | | | | | | | | X
Larsen, 2004^150^ | | | | | | | | | | | | | | X | X | X
Law, 2006^163^ | | | | | | | | | | | | | | | | | X | | | X | | | | | | | | | | | | | | X
Lips, 1996^202^ | | | X | X | X | | X | | | | | | X | | | | X | | | X | | | | X | X | X | X | X | | X | | | | X
Lyons, 2007^203^ | | | | | | | | | | | | | | X | X | X | X | | | X | | | | X | X | | | | | | | | | X
Menczel, 1994^204^ | | | | | | | | | | | X | | X
Meyer, 2002^205^ | | | X | X | X | | | | | | | | X | X | | X | X | | | X | | | | X | | X | X | X | | | | | | X
Orimo, 1987^206^ | | | | | | X | | | | | | V
Orimo, 1994^207^ | | | | | | | | | | | | X | | | | | | | | | | | | | | | | | | | X | X
Ott, 1989^208^ | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | X | X
Peacock, 2000^174^ | | | | | | | | | | | | | | | | | X | | | X | | | | | | | | | X | X
Pfeifer, 2008 209 | | | | | | | | | | | | | | | | | | | | | | | | X
Porthouse, 2005^152^ | | | | | | | | | | | | | | X | X | X | | | X | X | | | X | | | X | | X
Reid, 1993^177^ | | | | | | | | | | | | | | | | | | | | | | | | | | X
Sato, 1999^210^ 211 | | | | | | | | | | | | | | | | | | | | X
Smith, 2007^162^ | | | | | | | X | | | | | | | X | X | X | X | | | X | | | | | | | | | | | | | | X
Tilyard, 1992 212 | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | X | X
Trivedi, 2003 213 | | | | | | | | | | | | X | | | | | X | | | X | | | | X | X | X | X | X | X | X | | | | X
Ushiroyama, 2001 214 | | | | | | | | | | | | | | | | | | | X | | | | | | | | | | | | X

V = vertebral; NV = nonvertebral; H = hip; A = all; W = wrist/forearm; X = included in pooled analysis

References for systematic reviews: Avenell, Cochrane Database Syst Rev, 2005^143^; Bischoff-Ferrari, JAMA, 2005^180^; Papadimitropoulos, Endocr Rev, 2002^181^; Stevenson, Health Technol Assess, 2005^32^; Richy, Osteoporos Int, 2004^182^; Richy, Calcif Tissue Int, 2005^142^; Abrahamsen, BMJ, 2010^146^; Avenell, Cochrane Database Syst Rev, 2009^145^; Bergman, Curr Med Res Opin, 2010^147^; Bischoff-Ferrari, Arch Intern Med, 2009^183^; Boonen, J Clin Endocrinol Metab, 2007^140^; Izaks, BMC Musculoskelet Disord, 2007^148^; Jackson, Qjm, 2007^184^; O'Donnell, J Bone Miner Metab, 2008^144^; Tang, Lancet, 2007^141^; Lai, BMC Public Health, 2010^149^

Calcium alone did not reduce vertebral or nonvertebral fracture risk significantly relative to placebo or no treatment (Table 25). Although there was a statistically significantly (64 percent) increased risk of hip fracture associated with calcium supplementation in one pooled estimate,139 the pooled estimate of another meta-analysis with an almost 10-fold higher number of included participants found a statistically significant 25 percent reduction in relative risk of hip fracture with calcium compared to placebo.140 There was a statistically significantly higher reduction in overall fracture risk with calcium ≥ 1,200 mg/d compared to <1,200mg/d.141 Thus, data on calcium supplementation alone and fracture risk are conflicting.

Table 25 Pooled risk estimates of fracture for calcium relative to placebo, or no treatment

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Original Report
Shea, 2002^165,*,†^ | 5 | 576 | 0.77 | (0.54, 1.09)
Nonvertebral Fractures
Original Report
Shea, 2002^165,*,†^ | 2 | 222 | 0.86 | (0.43, 1.72)
Update Report
Bischoff-Ferrari, 2007^139^ | 5 | 6,740 | 0.92 | (0.81, 1.05)
Hip
Original Report: No comparable studies from the original report
Update Report
Bischoff-Ferrari, 2007^139^
Men and women | 4 | 6,504 | 1.64 | (1.02, 2.64)
Boonen, 2007^140^ | 10 | 54,592 | 0.75 | (0.58, 0.96)
All Types of Fracture
Original Report: No comparable studies from the original report
Update Report
Tang, 2007^141,‡^ | 9
Any calcium | | 6,517 | 0.90 | (0.80, 1.00)
Calcium <1,200 mg/d | | 47,359 | 0.94 | (0.89, 0.99)
Calcium 1,200 mg/d | | 5,266 | 0.80 | (0.72, 0.89)

* Postmenopausal women only.

† In one included study, participants received a baseline vitamin D injection.

‡ Age 50 and over. P value for comparison of RR of fracture for studies of <1,200 mg vs. ≥1,200 mg/d was 0.006.

In general, in systematic reviews of vitamin D alone, results varied markedly across studies. Some discrepancies across estimates are certainly due to methodological differences, in that many pooled analyses varied in whether they compared vitamin D to placebo, to calcium, or to either calcium or placebo (Table 26). Although a large number of comparisons are displayed in the table, we focus here on the comparisons between vitamin D, administered with or without calcium, and placebo (head-to-head comparisons of calcium and vitamin D are reported later).

Table 26 Pooled risk estimates of fracture for Vitamin D relative to placebo, vitamin D plus calcium, or no treatment

Author, Year | # Studies | Sample Size | RR | (95% CI) | Comparison
Vertebral Fractures
Original 2007 Report
Avenell, 2005^143^
Not selected on basis of prior osteoporotic fracture | 2 | 2,953 | 0.96 | (0.42, 2.21) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo
Selected on basis of prior osteoporotic fracture | 1 | 2,745 | 3.97 | (0.44, 35.45) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo
Either selected or not selected on basis of prior osteoporotic fracture | 3 | 5,698 | 1.13 | (0.50, 2.55) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo
Either selected or not selected on basis of prior osteoporotic fracture | 2 | 2,708 | 0.34 | (0.01, 8.34) | Standard vitamin D [D2, D3, or 25(OH)D] + calcium vs. placebo/control
Either selected or not selected on basis of prior osteoporotic fracture | 3 | 327 | 0.75 | (0.40, 1.41) | Calcitriol vs. placebo/control
Papadimitropoulos, 2000^181^
Postmenopausal women | 1 | 160 | 0.33 | (0.01, 8.05) | Standard vitamin D [D2, D3, or 25(OH)D] vs. calcium or placebo
Postmenopausal women | 7 | 970 | 0.64 | (0.44, 0.92) | Calcitriol (1,25-OH vitamin D) vs. calcium or placebo
Postmenopausal women | 8 | 1,130 | 0.63 | (0.45, 0.88) | Either Standard vitamin D or Calcitriol vs. calcium or placebo
Richy, 2004^182^
Primary osteoporosis | 9 | 1,665 | 0.53 | (0.47, 0.60) | Alfacalcidol or calcitriol vs. calcium or placebo
Primary osteoporosis | 6 | 896 | 0.52 | (0.41, 0.67) | Calcitriol vs. calcium or placebo
Primary osteoporosis | 3 | 769 | 0.53 | (0.46, 0.61) | Alphacalcidol vs. calcium or placebo
Primary osteoporosis | 2 | 106 | 0.33 | (0.07, 1.51) | GC-induced (calcitriol only) vs. calcium or placebo
Richy, 2005^142^
Primary osteoporosis (24 mos) | 5 | 1,972 | 15%^*^ | (10, 20%) | Alfacalcidol or calcitriol vs. placebo
Primary osteoporosis (24 mos) | 2 | 3,075 | 1.6%^*^ | (0.4, 2.6%) | Standard vitamin D vs. placebo
GC treatment | 3 | 300 | 9% | (-2, 22%) | Alfacalcidol or calcitriol vs. placebo
GC treatment | 1 | 62 | 6% | (-23, 10%) | Standard vitamin D vs. placebo
Stevenson, 2005^32^
Women with severe osteoporosis | 3 | 109 | 1.02 | (0.44, 2.32) | Calcitriol vs. placebo
Elderly women not selected for BMD | 1 | NR | 4.44 | (0.50, 39.03) | Calcitriol vs. placebo
Elderly women not selected for BMD | | | 2.95 | (0.21, 71.21) | Calcium + vitamin D vs. placebo
Update Report
Avenell, 2009 145
Persons sustaining new vertebral fracture or deformity Either selected or not selected on basis of prior osteoporotic fracture | 5 | 9,138 | 0.90 | (0.42, 1.92) | Vitamin D alone vs. placebo or no treatment
Persons sustaining new vertebral fracture Selected on the basis of previous osteoporotic fracture | 2 | 2,681 | 0.14 | (0.01, 2.77) | Vitamin D plus calcium vs. calcium
Persons sustaining new vertebral fracture or deformity Either selected or not selected on the basis of prior osteoporotic fracture | 3 | 2,976 | 2.21 | (1.08, 4.53)^†^ | Vitamin D vs. calcium
Persons sustaining new vertebral fracture Either selected or not selected on basis of prior osteoporotic fracture | 3 | 38,990 | 0.91 | (0.75, 1.11) | Vitamin D plus calcium vs. placebo or no treatment
Persons sustaining new vertebral fracture Selected on the basis of a previous osteoporotic fracture | 1 | 132 | 0.65 | (0.33, 1.27) | Alfacalcidol vs. placebo or no treatment
Persons sustaining new vertebral deformity Selected on the basis of previous osteoporotic fracture | 3 | 259 | 0.50 | (0.20, 1.23) | Alfacalcidol plus calcium vs. Calcium
Persons sustaining new vertebral deformity Selected on the basis of previous osteoporotic fracture | 1 | 23 | 0.95 | (0.52, 1.74) | Alfacalcidol vs. calcium^‡^
Persons sustaining new vertebral fracture or deformity Selected on the basis of previous osteoporotic fracture | 1 | 148 | 0.81 | (0.29, 2.30) | Alfacalcidol vs. vitamin D and calcium^‡^
Persons sustaining new vertebral deformity Either selected or not selected on the basis of previous osteoporotic fracture | 3 | 327 | 0.75 | (0.40, 1.41) | Calcitriol vs. placebo or no treatment^‡^
Persons developing new vertebral deformity Selected on the basis of previous osteoporotic fracture | 1 | 86 | 1.50 | (0.58, 3.85) | Calcitriol plus calcium vs. calcium^c^
Persons developing new vertebral deformity Selected on the basis of previous osteoporotic fracture | 2 | 84 | 0.79 | (0.41, 1.52) | Calcitriol plus vitamin D and calcium vs. vitamin D and calcium^‡^
Persons developing new vertebral deformity Selected on the basis of previous osteoporotic fracture | 2 | 556 | 1.69 | (0.25, 11.28) | Calcitriol vs. calcium
Persons developing new vertebral deformity Selected on the basis of previous osteoporotic fracture | 2 | 96 | 1.38 | (0.55, 3.47) | Calcitriol vs. vitamin D
Jackson, 2007 184
Women (and men) Not selected on the basis of previous osteoporotic fracture | 2 | 902 | 1.22 | (0.64, 2.31) | Cholecalciferol vs. calcium or placebo
O'Donnell, 2008 144
Postmenopausal women and older men | 13 | 1,396 | 0.89 | (0.57, 1.39) | Calcitriol or alfacalcidol vs. calcium or placebo
Postmenopausal women and older men | 5 | 410 | 0.50 | (0.25, 0.98) | Alfacalcidol vs. calcium or placebo
Postmenopausal women and older men | 8 | 986 | 1.19 | (0.70, 2.02) | Calcitriol vs. calcium or placebo
DiPART Group 2010^146^ | n/a | n/a | 0.85^#^ | (0.66, 1.11) | Vitamin D plus Calcium vs. placebo or control
DiPART Group 2010^146^ | n/a | n/a | 1.12^#^ | (0.70, 1.79) | Vitamin D vs. placebo or control
DiPART Group 2010^146^ | n/a | n/a | 0.86^#^ | (0.65, 1.14) | 10 μg vitamin D with calcium vs. placebo or control
DiPART Group 2010^146^ | n/a | n/a | 0.97^#^ | (0.48, 1.98) | 20 μg with calcium vs. placebo or control
DiPART Group 2010^146^ | n/a | n/a | 1.10^#^ | (0.69, 1.76) | 20 μg without calcium vs. placebo or control
Nonvertebral Fractures
Original 2007 Report
Avenell, 2005^143^
Not selected on basis of prior osteoporotic fracture | 2 | 466 | 0.40 | (0.05, 3.08) | Alphacalcidol vs. placebo/control
Not selected on basis of prior osteoporotic fracture | 1 | 246 | 0.46 | (0.18, 1.18) | Calcitriol vs. placebo/control
Not selected on basis of prior osteoporotic fracture | 7 | 10,376 | 0.87 | (0.78, 0.97) | Vitamin D (D2, D3, or 25 (OH) D) + calcium vs. placebo/control
Bischoff-Ferrari, 2005^180^ | 7 | 9,820 | 0.83 | (0.70, 0.98) | All doses (D2, D3) +/- calcium vs. placebo or calcium
Bischoff-Ferrari, 2005^180^ | 5 | 6098 | 0.77 | (0.68, 0.87) | 700-800IU/d +/- calcium vs. placebo or calcium
Bischoff-Ferrari, 2005^180^ | 2 | 3,722 | 1.03 | (0.86, 1.24) | 400IU/d +/- calcium vs. placebo or calcium
Stevenson, 2005 32
Women with severe osteoporosis or osteoporosis | 1 | 86 | 2.50 | (0.51, 12.19) | Calcitriol vs. placebo
Elderly women not selected for BMD | 1 | 213 | 0.46 | (0.17, 1.27) | Calcitriol vs. placebo
Elderly women not selected for BMD | 1 | 3,270 | 0.79 | (0.69, 0.92) | Vitamin D vs. placebo
Papadimitropoulos, 2002^181^
Postmenopausal women | 3 | 5399 | 0.78 | (0.55, 1.09) | Standard vitamin D [D2, D3, or 25(OH)D] vs. calcium or placebo
Postmenopausal women | 3 | 788 | 0.87 | (0.29, 2.59) | Calcitriol (1,25-OH vitamin D) vs. calcium or placebo
Postmenopausal women | 6 | 6,187 | 0.77 | (0.57, 1.04) | Either Standard vitamin D or Calcitriol vs. calcium or placebo
Richy, 2004^182^
Primary osteoporosis | 11 | 1310 | 0.34 | (0.16, 0.71) | Calcitriol or alphacalcidol vs. calcium or placebo
Richy, 2005^142^
Primary osteoporosis | 7 | 913 | 8%^ | (2, 13%) | Vitamin D analogues vs. placebo
Primary osteoporosis | 6 | 7,058 | 2%^ | (1, 3%) | Standard vitamin D vs. placebo
Update Report
Bergman, 2010^147^ | 4 | 3,510 | 0.77^**^ | (0.63, 0.93)^†^ | Cholecalciferol (D3) plus calcium vs. placebo
Avenell, 2009^145^
Persons sustaining new nonvertebral fracture Not selected on the basis of prior osteoporotic fracture | 1 | 3,440 | 0.96 | (0.80, 1.15) | Vitamin D alone vs. placebo or no treatment
Persons sustaining new nonvertebral fracture Either selected or not selected on the basis of prior osteoporotic fracture | 4 | 3,061 | 0.96 | (0.79, 1.16) | Vitamin D plus calcium vs. calcium alone
Persons sustaining new nonvertebral fracture Either selected or not selected on the basis of prior osteoporotic fracture | 3 | 2,976 | 1.08 | (0.90, 1.31) | Vitamin D vs. calcium
Persons sustaining new nonvertebral fracture Either selected or not selected on the basis of prior osteoporotic fracture | 9 | 46,781 | 0.95 | (0.90, 1.00) | Vitamin D plus calcium vs. placebo or no treatment
Selected on the basis of prior osteoporotic fracture | 4 | 6,134 | 0.93 | (0.79, 1.10) | Vitamin D plus calcium vs. placebo or no treatment
Not selected on the basis of prior osteoporotic fracture | 5 | 40,647 | 0.95 | (0.90, 1.01) | Vitamin D plus calcium vs. placebo or no treatment
Selected on the basis of institutional residence | 2 | 3,853 | 0.85 | (0.74, 0.98) | Vitamin D plus calcium vs. placebo or no treatment
Selected on the basis of community residence | 7 | 42,928 | 0.97 | (0.91, 1.02) | Vitamin D plus calcium vs. placebo or no treatment
Either selected or not selected on the basis of prior osteoporotic fracture | 5 | 744 | 0.39 | (0.15, 1.00) | Alfacalcidol vs. placebo or no treatment
Not selected on the basis of prior osteoporotic fracture | 1 | 246 | 0.46 | (0.18, 1.18) | Calcitriol vs. placebo or no treatment
Selected on the basis of prior osteoporotic fracture | 2 | 663 | 1.19 | (0.09, 15.77) | Calcitriol vs. calcium
Selected on the basis of prior osteoporotic fracture | 1 | 86 | 1.16 | (0.40. 3.37) | Calcitriol vs. vitamin D
Bischoff-Ferrari, 2009^183^
Persons ≥65 years of age | 12 | 42,279 | 0.86 | (0.77, 0.96) | Vitamin D +/- calcium vs. calcium or placebo, all trials
Persons ≥65 years of age | 9 | 33,265 | 0.80 | (0.72, 0.89) | Vitamin D +/- calcium vs. calcium or placebo, (≥400IU/d
Institutionalized persons | 4 | 6,951 | 0.85 | (0.76, 0.94) | Vitamin D +/- calcium vs. calcium or placebo
O'Donnell, 2008 144 | 6 | 1,014 | 0.51 | (0.30, 0.88) | Calcitriol or alfacalcidol +/- calcium vs. calcium or placebo
Jackson, 2007 184
All participants | 6 | 8,524 | 0.96 | (0.84, 1.09) | Vitamin D3 +/- calcium vs. calcium or placebo
Postmenopausal women | 3 | 622 | 0.81 | (0.48, 1.34) | Vitamin D3 +/- calcium vs. calcium or placebo
Izaks, 2007^148^
Institutionalized persons | 3 | n/a | 0.80 | (0.70, 0.90) | Standard Vitamin D (D2, D3, or 25 (OH) Vit D2) ≥700IU/d + calcium vs. placebo^††^
General population | 4 | n/a | 0.88 | (0.75, 1.04) | Standard Vitamin D (D2, D3, or 25 (OH) Vitamin D2) ≥700IU/d + calcium vs. placebo
Hip Fractures
Original 2007 Report
Avenell, 2005^143^
Not selected on basis of prior osteoporotic fracture | 4 | 15,948 | 1.20 | (0.98, 1.47) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo or control
Selected on basis of prior osteoporotic fracture | 3 | 2,820 | 1.08 | (0.72, 1.62) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo or control
Either selected or not selected on basis of prior osteoporotic fracture | 7 | 18,668 | 1.17 | (0.98, 1.41) | Standard vitamin D [D2, D3, or 25(OH)D] vs. placebo or control
Either selected or not selected on basis of prior osteoporotic fracture | 7 | 10,376 | 0.81 | (0.68, 0.96) | Standard vitamin D [D2, D3, or 25(OH)D] + calcium vs. placebo or control
Not selected on basis of prior osteoporotic fracture | 3 | 239 | 0.16 | (0.04, 0.69) | Alphacalcidol vs. placebo or control
Not selected on basis of prior osteoporotic fracture | 1 | 246 | 0.33 | (0.01, 8.10) | Calcitriol (1,25-OH vitamin D) vs. placebo or control
Bischoff-Ferrari, 2005^180^ | 5 | 9294 | 0.88 | (0.69, 1.13) | All doses (D2, D3) +/- calcium vs. placebo or calcium
Bischoff-Ferrari, 2005^180^ | 3 | 5,572 | 0.74 | (0.61, 0.88) | 700-800IU/d +/- calcium vs. placebo or calcium
Bischoff-Ferrari, 2005^180^ | 2 | 3,722 | 1.15 | (0.88, 1.50) | 400IU/d +/- calcium vs. placebo or calcium
Stevenson 2005 32
Elderly women not selected for low BMD | 2 | 2,886 | 0.72 | (0.59, 0.88) | Vitamin D3 + calcium vs. placebo
Update Report
Bergman, 2010^147^ | 5 | 7,473 | 0.70^**^ | (0.63, 0.90)^†^ | Cholecalciferol (D3) + calcium vs. placebo
Avenell, 2009^145^
Persons sustaining new hip fracture Selected or not selected on basis of prior osteoporotic fracture | 9 | 24,749 | 1.15 | (0.99, 1.33) | Vitamin D (D2, D3, or 25(OH)D) alone vs. placebo or no treatment
Persons sustaining new hip fracture Selected or not selected on basis of prior osteoporotic fracture | 4 | 6,988 | 0.83 | (0.61, 1.12) | Vitamin D (D2, D3, or 25(OH)D)+ calcium vs. calcium alone
Selected on basis of prior osteoporotic fracture | 2 | 2,718 | 0.90 | (0.61, 1.32) | Vitamin D (D2, D3, or 25(OH)D) vs. calcium
Selected on basis of prior osteoporotic fracture | 4 | 6,134 | 1.02 | (0.71, 1.47) | Vitamin D (D2, D3, or 25(OH)D) + calcium vs. placebo or no treatment
Not selected on basis of prior osteoporotic fracture | 4 | 40,524 | 0.81 | (0.71, 0.93)^†^ | Vitamin D (D2, D3, or 25(OH)D) + calcium vs. placebo or no treatment
Either selected or not selected on basis of prior osteoporotic fracture | 8 | 46,658 | 0.84 | (0.73, 0.96)^†^ | Vitamin D (D2, D3, or 25(OH)D) + calcium vs. placebo or no treatment
Selected on basis of institutional residence | 2 | 3,853 | 0.75 | (0.62, 0.92)^†^ | Vitamin D (D2, D3, or 25(OH)D) + calcium vs. placebo or no treatment
Selected on basis of community residence | 6 | 42,805 | 0.91 | 0.76, 1.08) | Vitamin D (D2, D3, or 25(OH)D) + calcium vs. placebo or no treatment
Either selected or not selected on basis of prior osteoporotic fracture | 4 | 371 | 0.18 | (0.05, 0.67)^†^ | Alfacalcidol vs. placebo or no treatment
Selected on basis of prior osteoporotic fracture | 1 | 113 | 0.20 | (0.01, 4.00) | Alfacalcidol plus calcium vs. calcium^‡^
Not selected on basis of prior osteoporotic fracture | 1 | 246 | 0.33 | (0.01, 8.10) | Calcitriol vs. placebo or no treatment^‡^
Bischoff-Ferrari, 2009^183^ | 8 | 40,886 | 0.91 | (0.78, 1.05) | Oral Vitamin D (all types and doses analyzed jointly) +/- calcium vs. calcium or placebo
Bischoff-Ferrari, 2009^183^ | 5 | 31,872 | 0.82 | (0.69, 0.97) | Oral Vitamin D ≥400IU/d +/- calcium vs. calcium or placebo
Boonen, 2007^140^
Postmenopausal women or older men (≥50 years) | 10^‡‡^ | 54,592 | 0.75 | (0.58, 0.96)^†^ | Vitamin D + calcium vs. Vitamin D
Postmenopausal women or older men (≥50 years) | 4 | | 1.10 | (0.89, 1.36) | Vitamin D vs. placebo/no treatment
Postmenopausal women or older men (≥50 years) | 6 | | 0.82 | (0.71, 0.94)^†^ | Vitamin D + calcium vs. placebo
DIPART Group, 2010^146^ | 7 | 68,517 | 0.74^#^ | (0.60, 0.91)^†^ | Vitamin D with or without calcium vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.84^#^ | (0.70, 1.01)^†^ | Vitamin D plus Calcium vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 1.09^#^ | (0.92, 1.29) | Vitamin D vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.93^#^ | (0.81, 1.06) | Vitamin D oral vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 1.46^#^ | (1.99, 2.13) | Vitamin D injected vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.74^#^ | (0.60, 0.91) | 10 μg vitamin D with calcium vs. placebo or control
DIPART Group, 2010^146^ | | | 1.10^#^ | (0.74, 1.64) | 10 μg vitamin D without calcium vs. placebo or control^##^
DIPART Group, 2010^146^ | n/a | n/a | 1.30^#^ | (0.88, 1.92) | 20ug with calcium vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 1.08^#^ | (0.89, 1.30) | 20ug without calcium vs. placebo or control
Izaks, 2007^148^
Institutionalized persons | 2 | n/a | 0.72 | (0.0.59, 0.88) | Standard Vitamin D (D2, D3, or 25 (OH) Vit D2) ≥700IU/d + calcium vs. placebo
General population | 2 | n/a | 1.04 | (0.72, 1.50) | Standard Vitamin D (D2, D3, or 25 (OH) Vitamin D2) ≥700IU/d + calcium vs. placebo
Lai, 2010^149^ | 7 | 25,680 | 1.13 | (0.98, 1.29) | Standard Vitamin D (D2 or D3) vs. placebo or control
<800IU/day | 2 | 3,722 | 1.14 | (0.86, 1.49) | Standard Vitamin D (D2 or D3) vs. placebo or control
≥800IU/day | 5 | 21,958 | 1.12 | (0.96, 1.32) | Standard Vitamin D (D2 or D3) vs. placebo or control
≥800IU/day | 3 | 16,597 | 1.21 | (0.99, 1.48) | Vitamin D2
≥800IU/day | 4 | 9,083 | 1.06 | (0.88, 1.28) | Vitamin D3
Nonvertebral, Non-hip Fractures
Original Report: No comparable studies from the original report
Bergman, 2010^147^ | 5 | 7,473
Bergman, 2010^147^ | | | 0.84^**^ | (0.67, 1.04)^†^ | Cholecalciferol (D_3_) plus calcium vs. placebo
Bergman, 2010^147^ | | | 0.64^**^ | (0.38, 0.99)^†^ | Cholecalciferol (D3) plus calcium vs. calcium
All Types of Fracture
Original Report: No comparable studies from the original report
Avenel, 2006^143^
Persons sustaining any new fracture | 8 | 18,935 | 1.02 | (0.93, 1.11) | Vitamin D (D2, D3, or 25 (OH)D) vs. placebo or control
Richy, 2004^182^
Primary osteoporosis | 11 | 1,310 | 0.52 | (0.46, 0.59) | Calcitriol or alphacalcidol vs. calcium or placebo
Update Report
Tang, 2007^141,‡,#^ | 17 | 52,625 | 0.88 | (0.83, 0.95) | Calcium and calcium plus vitamin D vs. placebo
Tang, 2007^141,‡,#^ | 8 | 55,751 | 0.87 | (0.77, 0.97) | Vitamin D plus calcium vs. placebo
Tang, 2007^141,‡,#^ | 8 | 9,437 | 0.84 | (0.75, 0.94) | ≥800 IU vs. placebo
Tang, 2007^141,‡,#^ | 8 | 36,671 | 0.87 | (0.71, 1.05) | <800 IU vs. placebo
DIPART Group, 2010^146^ | n/a | n/a | 0.92^#^ | (0.86, 0.99)^†^ | Vitamin D plus Calcium vs. placebo or control (p=0.025)
DIPART Group, 2010^146^ | n/a | n/a | 1.01^#^ | (0.92, 1.12) | Vitamin D vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.93^†, #^ | (0.87, 0.99 | Vitamin D oral vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 1.11^#^ | (0.95, 1.31) | Vitamin D injected vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.91^†,#^ | (0.85, 0.99) | 10 μg vitamin D with calcium vs. placebo or control
DIPART Group, 2010^146^ | | | 0.93^#^ | (0.67, 1.28) | 10 μg vitamin D without calcium vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 0.95^#^ | (0.80, 1.14) | 20ug with calcium vs. placebo or control
DIPART Group, 2010^146^ | n/a | n/a | 1.02^#^ | (0.92, 1.14) | 20ug without calcium vs. placebo or control
Avenell, 2009^145^
Persons sustaining any new fracture Selected or not selected on basis of prior osteoporotic fracture | 10 | 25,016 | 1.01 | (0.93, 1.09)^†^ | Vitamin D (D2, D3, or 25 (OH)D) vs. placebo or control
Persons sustaining any new fracture Not selected on the basis of prior osteoporotic fracture | 2 | 927 | 0.76 | 0.48, 1.21 | Vitamin D (D2, D3, or 25 (OH)D) plus calcium vs. calcium

Table Notes: Calcitriol is 1,25 dihydroxyvitamin D3 (1,25 (OH)2 D3), which is equivalent to renal and liver activation; Alfacalcidol is 1-alpha-hydrovitamin D3, which is equivalent to renal activation; Ergocalciferol is Vitamin D2; Cholecalciferol is Vitamin D3; Calcidiol is 25-hydroxyvitamin D (25 (OH)D), which is equivalent to liver activation; for Avenell, 2009, Vitamin D refers to either D2, D3, or 25(OH)D.

* Fracture results were expressed as rate differences, so the results are presented not as a relative risk but rather as risk difference. Difference between treatments was significant and favored the analogs (P < 0.001, delta RD = 13.4% (95%CI, 7.7 to 19.8).

† Statistically significant.

‡ New vertebral deformities.

# Individual patient data HR for trials using vit D + Ca cf. vitamin D alone.

^ Results expressed as rate difference (RD, difference in fracture rate between treatment and placebo or no treatment).

** Odds ratio.

†† This study could not examine lower dose (400 IUD/d) Vitamin D because there were too few studies to allow meta-analysis.

‡‡ Ca + vitamin D vs. vitamin D alone indirect comparison: 6 trials of vitamin D + Ca vs. 4 trials of vitamin D alone.

## According to the author 10μg means 400 IU and 20ug means 800 IU.

Vertebral Fractures. For vertebral fractures, compared to placebo, vitamin D was associated with statistically significant reductions in risk among people with primary osteoporosis: 15 (95% CI: 10, 20) for alfacalcidol or calcitriol, 1.6 (0.4, 2.6) for standardized vitamin D vs. placebo.142 However, among populations not selected on the basis of osteoporotic fracture,143,144 those with prior fractures,145 women with severe osteoporosis32 or those taking glucocorticoid treatment,142 vitamin D (versus placebo) was not associated with statistically significant vertebral fracture risk reduction. In comparison with placebo, vitamin D + calcium was not associated with statistically significant reductions in vertebral fracture in populations selected or not selected for prior osteoporotic fractures.32,143,145,146

There were no statistically significant differences in vertebral risk in comparisons of alfacalcidol vs. vitamin D + calcium, or calcitriol vs. vitamin D.145 In one pooled analysis, neither 10 μg^e^ nor 20 μg doses of vitamin D altered vertebral fracture risk in comparison with placebo, even when given in conjunction with calcium.146 In summary, pooled analyses suggest that vitamin D compared to placebo may reduce the risk of vertebral fractures, but results are not consistent across the pooled studies. In the pooled analyses, various forms of vitamin D do not appear to have differing effects on vertebral fracture risk.

Nonvertebral Fracture. Statistically significant decreases in nonvertebral fracture risk were found for vitamin D compared to placebo in several pooled analyses: standard vitamin D (vitamin D2, D3, or 25(OH)D) among elderly women not selected for prior osteoporotic fracture (RR 0.87), vitamin D analogues for primary osteoporosis, and standard vitamin D for primary osteoporosis.142 In contrast, the following were not associated with statistically significant reductions in nonvertebral fracture risk: alfacalcidol, calcitriol, or vitamin D among people not selected on the basis of prior osteoporotic fracture, calcitriol among women with severe osteoporosis.32,143,145

In combination with calcium, vitamin D was associated with a statistically significant reduction in nonvertebral fracture risk among populations not selected on the basis of prior osteoporotic fractures.143,147 Among institutionalized persons, vitamin D + calcium was associated with 15 percent decrease (statistically significant) in nonvertebral fracture risk.145 In contrast, vitamin D + calcium was not associated with a statistically significantly decreased risk of nonvertebral fractures among those who were not selected on the basis of prior osteoporotic fractures, those who were selected on the basis of prior osteoporotic fractures, or among community-dwellers.145 Standard vitamin D doses of ≥700 IU/d + calcium are associated with statistically significant reductions in nonvertebral fracture risk among institutionalized persons (RR 0.80).148

In summary, compared to placebo, vitamin D + calcium decreases the risk of nonvertebral fractures among the institutionalized by 15-20 percent. Vitamin D may be effective compared to placebo in reducing risk among populations with primary osteoporosis, although evidence was not consistent.

Hip Fracture. For hip fracture, compared to placebo, alfacalcidol reduced relative risk of fracture by 84 percent.143 Standard vitamin D was not statistically significantly more effective than placebo in reducing hip fracture risk among those who were not selected, nor among those who were selected, on the basis of previous osteoporotic fractures.140,143,146 Nor was calcitriol more effective than placebo in reducing hip fracture risk among those not selected on the basis of prior osteoporotic fractures.145 One pooled estimate even showed a statistically significantly increased risk of hip fracture in associated with injection of vitamin D compared to placebo.146

In contrast to the situation with vitamin D alone, vitamin D + calcium (vs. placebo) was associated with statistically significantly reduced risk of hip fracture, ranging about 20 to 30 percent, in those selected or not selected on the basis of prior osteoporotic fractures (in some studies), not selected on the basis of low BMD, and among the institutionalized.32,140,143,145,147 Vitamin D + calcium did not decrease hip fracture risk more than placebo among community dwellers and general populations, even at high (≥700 IU/d) doses.145,148 Vitamin D doses of 10 μg were not effective in decreasing hip fracture risk unless they were given with calcium; the RR of hip fracture with vitamin D 10 μg + calcium vs. placebo was 0.74 (0.60, 0.91).146 Dosing of ≥700 IU of vitamin D was associated with a 28 percent lower risk of hip fractures among institutionalized persons (RR 0.72, 95% CI: 0.59, 0.88).148

A new systematic review found that vitamin D supplementation did not statistically significantly alter hip fracture risk, but the authors analyzed vitamin D plus calcium and vitamin D jointly, in comparison to a reference group of placebo or calcium, respectively.149

In summary, evidence was most consistent for beneficial effects of vitamin D administered with calcium on the risk for hip fracture, as opposed to alone, especially among institutionalized persons. There is increasing evidence in recent years that an adequately high dose of vitamin D is required for reduction of hip fractures, and that heterogeneity in vitamin D dosing across studies (in addition to heterogeneous baseline risk across studies) may have partly explained prior conflicting evidence regarding antifracture effects of vitamin D.

Nonvertebral Nonhip Fracture. The one available estimate suggested that vitamin D with calcium was associated with statistically significant reduction in nonvertebral nonhip fracture risk compared to calcium alone, but not to placebo.

Overall Fracture Risk. For overall risk of clinical fractures, although some pooled estimates showed no significant benefit of vitamin D, several pooled analyses showed efficacy of oral vitamin D alone (7 percent lower relative risk vs. placebo ) and efficacy of vitamin D + calcium in reducing overall clinical fractures about 10 to 15 percent compared to placebo.141,146 Vitamin D injection did not reduce overall clinical fracture risk compared to placebo. As was the case for hip fractures, there was evidence for the importance of adequately high doses of vitamin D in relation to clinical fractures. Compared to placebo, doses of <800 IU/d did not statistically significantly reduce overall fracture risk, whereas doses ≥800 IU/day were associated with 16 percent lower overall fracture risk.141 Vitamin D 10 μg with calcium, but not without calcium, was associated with statistically significantly lower overall fracture risk compared to placebo.146 A similar pattern was apparent for vitamin D 20 μg with and without calcium, whereby the relative risk of fracture was decreased with vitamin D 20 μg + calcium (although not statistically significantly so), and not with vitamin D 20 μg alone. In summary, the strongest evidence for benefits of vitamin D on reducing overall fracture risk are for oral vitamin D combined with calcium, and in doses of ≥800 IU daily.

###### Original Placebo-Controlled Trials

For this report, one new RCT of calcium+vitamin D+ an environmental modification, two studies of vitamin D + calcium, three new RCTs of vitamin D alone, and two studies of calcium alone were identified.

Calcium+Vitamin D+Environmental Modification. In one RCT, a combined calcium + vitamin D + environmental modification intervention reduced the overall risk of fracture among women, but not men (Table 27) (Jadad score 0).150

Table 27 Calcium/vitamin D group and environmental and health group versus placebo

Author, Year | Study Duration | Fracture Type | Number of Fractures, Both Programs^*^ | Number of Fractures, Placebo | Odds Ratio (95% CI)
Original Report: No comparable studies from the original report
Update Report
Larsen, 2004^150^ | 42 months | All fractures – men | 33/954 | 26/843 | 1.13 (0.67, 1.89)
Larsen, 2004^150^ | 42 months | All fractures – women | 131/157 | 141/1,273 | 0.73 (0.56, 0.93)

* Calcium/Vitamin D group & Environmental & Health Group.

Among women, but not men, a combination calcium + vitamin D and environmental safety modification was efficacious in reducing overall fracture risk (RR 0.73, 0.56, 0.93) (Table 27).150 Using the criteria of Gartlehner et al.25to assess the applicability of this study, we determined its applicability to be moderately high.

Calcium+Vitamin D. Three RCTs from the original report151-153 and two new RCTs identified for this report150 assessed the effects of calcium+vitamin D on fracture risk. One of the newer RCTs was a population-based study that reported lower risks of overall, distal forearm, and upper extremity fractures with vitamin D (800 IU) and calcium vs. placebo among a group of elderly women living at a Northern (Finnish) latitude (Jadad score 2) , but none of the decreases in risk reached statistical significance.154 Thus, with the exception of one RCT showing a 25 percent lower overall risk of fracture,150 the risks of fractures (overall), vertebral fractures, hip fractures, and wrist fractures were not statistically different with calcium plus vitamin D compared to placebo (Table 28). Using the criteria of Gartlehner et al.25 to assess the applicability of the new studies, we determined their applicability to be moderately high to high.

Table 28 Risk of vertebral fracture for calcium plus vitamin D, relative to placebo

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Calcium Plus Vit D | Number of fractures, Placebo or Control | Odds Ratio (95% CI)
All Fractures
Original Report
Grant, 2005^153^ | 62 months | New | 104/1,306 | 196/1,332 | 0.95 (0.76, 1.18)
Jackson, 2006^151^ | 84 months | Total | 2,101/18,176 | 2,158/18,106 | 0.97 (0.91, 1.03)
Porthouse, 2005^152^ | 24 months | All | 24/607 | 22/602 | 1.09 (0.6, 1.96)
Update Report
Larsen, 2005^150^ | 42 months | All fractures – men | 60/1,974 | 26/843 | 0.99 (0.62, 1.57)
Larsen, 2005^150^ | 42 months | All fractures – women | 285/2,983 | 141/1,273 | 0.75 (0.6, 0.94)
Salovaara, 2010^154^ | 36 months | Any | 78/1,586 | 94/1,609 | 0.83 (0.61, 1.13)
Vertebral Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | Clinical vertebral | 0/1,306 | 1/1,332 | 0.14 (0, 6.96)
Jackson, 2006^151^ | 84 months | Clinical vertebral | 181/18,176 | 197/18,106 | 0.91 (0.75, 1.12)
Update Report
Salovaara, 2010^154^ | 36 months | Vertebral | 9/1586 | 13/1609 | 0.70 (030, 1.63)
Hip Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | Proximal femur | 46/1,306 | 41/1,332 | 1.15 (0.75, 1.76)
Jackson, 2006^151^ | 84 months | Hip | 175/18,176 | 199/18,106 | 0.87 (0.71, 1.07)
Porthouse, 2005^152^ | 24 months | Hip | 5/607 | 2/602 | 2.35 (0.53, 10.36)
Update Report
Salovaara, 2010^154^ | 36 months | Hip | 4/1,586 | 2/1,609 | 1.98 (0.4, 9.81)
Wrist Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | Distal forearm | 33/1,306 | 28/1,332 | 1.21 (0.73, 2.01)
Jackson, 2006^151^ | 84 months | Lower arm or wrist | 565/18,176 | 557/18,106 | 1.01 (0.9, 1.14)
Update Report
Salovaara, 2010^154^ | 36 months | Distal forearm | 23/1,586 | 32/1,609 | 0.73 (0.43, 1.24)

Calcium Alone. Four RCTs from the original report67,153,155,156 and two new RCTs identified for this report157,158 assessed the effect of calcium alone on fracture risk (Jadad scores 1 and 2). With the exception of one RCT from the original report that showed a 37 percent lower overall risk of fracture,156 the risks of fractures (overall), vertebral fractures, and wrist fractures were not statistically different with calcium compared to placebo (Table 29). Using the criteria of Gartlehner et al.25 to assess the applicability of the new studies, we determined their applicability to be low. Both small studies, one study enrolled only hospital inpatients and the other enrolled only men with congestive heart failure.

Table 29 Risk of fracture for calcium, relative to placebo, by fracture group

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Calcium | Number of Fractures, Placebo or Control^†^ | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Campbell, 2004^155^ | 60 months | New symptomatic vertebral and non-vertebral | 7/85 | 7/95^*^ | 1.13 (0.38, 3.35)
Prince, 2006^156,†^ | 60 months | Any site | 110/728 | 126/728 | 0.85 (0.64, 1.12)
Prince, 2006^156,‡^ | 60 months | Any site | 43/422 | 63/409 | 0.63 (0.42, 0.94)
Update Report: No new studies
Vertebral Fractures
Original 2007 Report
Campbell, 2004^155^ | 60 months | New symptomatic or semi-quantitative vertebral | 15/85 | 19/95^*^ | 0.86 (0.41, 1.81)
Grant, 2005^153^ | 62 months | Clinical vertebral | 3/1311 | 1/1332 | 2.77 (0.39, 19.65)
Prince, 2006^156,†^ | 60 months | Vertebral deformity | 44/431 | 50/450 | 0.91 (0.59, 1.40)
Prince, 2006^156,‡^ | 60 months | Vertebral deformity | 22/306 | 32/305 | 0.66 (0.38, 1.16)
Reid, 2006^67^ | 60 months | Vertebral | 27/739 | 38/732 | 0.70 (0.42, 1.14)
Update Report
Frost, 2007^157^ | 12 months | Vertebral | 1/17 | 1/16 | 0.94 (0.06, 15.72)
Fujita, 2007^158^ | 2 years | Vertebral | 2/7 | 3/6 | 0.43 (0.05, 3.73)
Fujita, 2007^158^ | 2 years | Vertebral | 0/6 | 3/6 | 0.09 (0.01, 1.06)
Wrist Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | Distal forearm | 33/1,311 | 28/1,332 | 1.20 (0.72, 2.00)
Prince, 2006^156,†^ | 60 months | Wrist or hand | 21/724 | 20/741 | 1.08 (0.58, 2.00)
Prince, 2006^156,‡^ | 60 months | Wrist or hand | 10/417 | 12/414 | 0.82 (0.35, 1.92)
Reid, 2006^67^ | 60 months | Distal forearm | 28/739 | 44/732 | 0.62 (0.39, 1.00)
Update Report: No new studies

* Control group.

† Intention to treat analysis.

‡ Compliant with medication.

Vitamin D Alone. Four RCTs from the original report137,153,159,160 and four new RCTs identified for this report161-164 assessed the effect of vitamin D alone on fracture risk (Jadad scores for new studies 4, 5, 3, and 5). One of the RCTs that examined hip fracture risk in relation to vitamin D160 showed an 88 percent lower risk (0.01, 0.90);160 but two RCTs showed an increased risk for hip fracture, 49 percent in one case (95% CI: 1.03, 2.18)162 and 26 percent in the other (95% CI: 0.64, 2.49).164 The risks of fractures (overall), vertebral fractures, nonvertebral fractures, and wrist fractures were not statistically different with vitamin D compared to placebo (Table 30). Using the criteria of Gartlehner et al.25 to assess the applicability of the new studies, we determined their applicability to be moderately high to high.

Table 30 Risk of vertebral fracture for vitamin D, relative to placebo

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Vit D | Number of Fractures, Placebo | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Torres, 2004^159^ | 12 months | Symptomatic | 0/41 | 0/45 | NC
Update Report
Sanders, 2010^164^ | 35.5 months | Any | 155/1,131 | 125/1,125 | 1.27 (0.99, 1.63)
Vertebral Fractures
Original 2007 Report: No studies from the original report
Update Report
Shiraki, 1996^161^ | 2 years | Vertebral | 2/37 | 3/42 | 0.75 (0.12, 4.55)
Sanders, 2010^164^ | 35.5 months | Vertebral | 35/1,131 | 28/1,125 | 1.25 (0.76, 2.06)
Nonvertebral Fractures
Original 2007 Report: No studies from the original report
Update Report
Smith, 2007^162^ | 36 Months | Nonvertebral | 306/4,727 | 279/4,713 | 1.1 (0.93, 1.3)
Shiraki, 1996^161^ | 2 Years | Nonvertebral | 0/37 | 3/42 | 0.15 (0.01, 1.44)
Shiraki, 1996^161^ | 10 Months | Nonvertebral | 64/1,762 | 51/1,955 | 1.41 (0.97, 2.04)
Hip Fractures
Original 2007 report
Sato, 2005^160^ | 24 months | Hip | 0/24 | 4/24 | 0.12 (0.01, 0.90)
Update Report
Smith, 2007^162^ | 36 months | Hip or femur | 66/4,727 | 44/4,713 | 1.49 (1.03, 2.18)
Law, 2006^163^ | 10 months | Hip | 24/1,762 | 20/1,955 | 1.34 (0.74, 2.42)
Sanders, 2010^164^ | 35.5 months | Hip | 19/1,131 | 15/1,125 | 1.26 (0.64, 2.49)
Wrist Fractures
Original 2007 Report
Grant, 2006^153^ | 62 months | Distal forearm | 33/1,343 | 28/1,332 | 1.17 (0.71, 1.95)
Ishida, 2004^137^ | 24 months | Vertebral | 11/66 | 17/66 | 0.58 (0.25, 1.34)
Update Report
Smith, 2007^162^ | 36 months | Wrist | 64/4,727 | 52/4,713 | 1.23 (0.85, 1.77)

NC = not calculable

##### Lifestyle Interventions

This section presents the results of studies of lifestyle interventions such as physical activity programs on the risk for osteoporotic fracture. The original report assessed the results of interventions aimed at preventing falls, which may indirectly help decrease the risk for osteoporotic fractures; however, assessing this category of indirect interventions was determined to be beyond the scope of this report.

###### Physical Activity

###### Prior Systematic Reviews

One systematic review evaluated the effects of physical activity relative to placebo on fracture risk (Table 31). The systematic review, which encompassed data from seven RCTs, examined fractures overall, vertebral fractures, hip fractures, and wrist fractures. Information from RCTs regarding effects of physical activity on fracture risk is available only for vertebral fractures (Table 32). In the one pooled estimate (three studies), the RR of vertebral fractures was not significantly different with physical activity relative to placebo or no treatment. However, the specific physical activity interventions, and the comparators (e.g. upper body exercise, heat/massage, electrotherapy) differed across the trials.

Table 31 Randomized controlled trials included in systematic review of effect of physical activity on fracture relative to placebo or no treatment by fracture type

| Systematic Review (Author, Year)
| Lock, 2006 216
| Fracture Type
RCTs (Author, Year) | A | V | H | W
Ebrahim, 1997 217 | | X
Jensen, 2002 218 | | | X
Preisinger, 1996 219 | X | X | | X
Sato, 2003 220 | | | X
Sinaki, 1989 221 | | X
Sinaki, 2002 222 | | X
Vetter, 1992 223 | X | | X

A = all; V = vertebral; H = hip; W = wrist/forearm; X = included in pooled analysis

Table 32 Pooled risk estimates of fracture for physical activity relative to placebo or no treatment

Author, Year | # Studies | Sample Size | RR | (95% CI)
Vertebral Fractures
Original 2007 Report: No comparable studies from the original report
Update Report
Lock, 2006 216 | 3 | 322 | 0.52 | (0.17, 1.60)

A RCT of a one-month exercise intervention that enrolled 160 Finnish women with osteopenia reported fracture rates after an average of seven years of followup (Jadad 2, moderately high applicability). The rate of incident fractures during followup was 0.05 per thousand person years in the exercise group, compared with 0.08 in the control group (Poisson incidence RR 0.68 [95% CI: 0.34, 1.32]). No hip fractures occurred in the exercise group, compared with 5 hip fractures in the control group.215 However, the study was not designed with sufficient statistical power to detect a difference in antifracture efficacy between groups.

##### Head-to-Head Comparisons of Agents

This section presents the results of studies that directly compared the effect of one agent against that of another agent (within the same class or across classes) within the same study.

###### Menopausal Estrogen Therapy vs. Bisphosphonate therapy

No new studies were identified for this comparison. Studies that directly compared fracture risk in association with menopausal estrogen therapy to fracture risk with bisphosphonate therapy spanned 12 months to 48 months in duration and collectively addressed vertebral, nonvertebral, and overall clinical fractures (Table 33). The odds of fracture with menopausal estrogen therapy compared to alendronate, etidronate, risedronate, or pamidronate were not statistically significantly different. Numbers of studies and fracture events were too sparse for us to determine relative efficacy of any one type of ET or EPT regimen compared to bisphosphonate therapy.

Table 33 Fractures with bisphosphonate relative to menopausal estrogen therapy or menopausal estrogen plus progestogen therapy among postmenopausal women

Author, Year | Study Duration | Fracture Type | Number of Fractures, Bisphosphonate | Number of Fractures, Estrogen^*^ | Odds Ratio (95% CI)
Alendronate
Original 2007 Report
Hosking, 1998^48^ | 24 months | Nonvertebral | 44/897 | 6/204 | 1.58 (0. 56, 4.43)
Bone, 2000^58^ | 24 months | Clinical | 5/92 | 10/143 | 0.77 (0. 26, 2.25)
Greenspan, 2003^59^ | 34 months | Clinical | 7/93 | 5/93 | 1.43 (0. 44, 4.58)
Update report: No new studies
Etidronate
Original 2007 Report
Ishida, 2004^137^ | 24 months | Vertebral | 8/66 | 7/66† | 1.16 (0. 40, 3.39)
Wimalawansa, 1998^138^ | 48 months | Nonvertebral | 1/14 | 1/15 | 1.07 (0. 06, 18.10)
Wimalawansa, 1998^138^ | 48 months | Vertebral | 3/14 | 2/15 | 1.73 (0. 26, 11.50)
Update report: No new studies
Risedronate
Original 2007 Report
Tauchmanova, 2006^228^ | 12 months | Subclinical vertebral | 2/15 | 1/15 | 2.05 (0.20, 21.36)
Update report: No new studies
Pamidronate
Original 2007 Report
Tauchmanova, 2006^228^ | 12 months | Subclinical vertebral | 3/15 | 1/15 | 3.05 (0.38, 24.18)
Update report: No new studies

* Hosking: participants received estrogen plus progestin; Bone, 2005: conjugated equine estrogen; Greenspan, 2003: conjugated equine estrogen ±medroxyprogesterone acetate; Ishida, 2004: conjugated equine estrogen+medroxyprogesterone acetate; Wimalawansa, 1998: conjugated equine estrogen+norgestrel; Tauchmanova, 2006: estradiol+progesterone.

###### Bisphosphonate Therapy Versus Calcium

No new studies were identified for this comparison. The two trials performing direct comparisons of bisphosphonates and calcium included very small numbers of fracture events: 12 symptomatic vertebral or nonvertebral fractures in one trial, and one atraumatic vertebral fracture in the other trial (Table 34). In these two studies, the odds of fracture with bisphosphonates relative to calcium were not statistically significantly different.

Table 34 Randomized controlled trials assessing fractures with bisphosphonates relative to calcium, by bisphosphonate

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Bisphosphonate | Number of Fractures, Calcium | Odds Ratio (95% CI)
Etidronate
Original 2007 Report
Campbell, 2004^155^ | 60 months | New symptomatic, vertebral or nonvertebral | 5/81 | 7/85 | 0.74 (0. 23, 2.38)
Update Report: No new studies
Pamidronate
Boutsen, 1997^232^ | 12 months | Atraumatic vertebral | 1/14 | 0/13 | 6.88 (0.14, 347.65)
Update Report: No new studies

###### Bisphosphonate Therapy Versus Raloxifene

No new studies were identified for this comparison. The bisphosphonates that were directly compared to raloxifene in RCTs were alendronate and risedronate (Table 35). The odds for overall fracture, vertebral fracture, nonvertebral fracture, hip fracture, and wrist fracture with raloxifene vs. alendronate were not statistically significantly different. These comparisons are based on three RCTs. Because RCTs directly comparing risedronate with raloxifene had no fracture events, we could not provide comparisons of the odds of fracture with the two agents.

Table 35 Fractures with bisphosphonates relative to raloxifene

Author, Year | Study Duration | Fracture Type | Number of Fractures, Bisphosphonate | Number of Fractures, Raloxifene | Odds Ratio (95% CI)
Alendronate
Total Fractures
Original 2007 Report
Luckey, 2004^233^ | 12 months | All clinical | 5/221 | 8/230 | 0.65 (0.22, 1.95)
Uchida, 2005^234^ | 12 months | Vertebral or nonvertebral | 22/713 | 20/699 | 1.08 (0.59, 2.0)
Update Report: No new studies
Vertebral Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Vertebral | 6/1,000 | 0/100 | NC
Uchida, 2005^234^ | 12 months | Vertebral | 8/713 | 5/699 | 1.56 (0.52, 4.65)
Update Report: No new studies
Nonvertebral Fractures
Original 2007 Report
Uchida, 2005^234^ | 12 months | Nonvertebral | 14/713 | 15/699 | 0.94 (0.44, 1.91)
Update Report: No new studies
Hip Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Femoral | 3/1,000 | 0/100 | NC
Uchida, 2005^234^ | 12 months | Hip | 1/713 | 2/699 | 0.5 (0.05, 4.84)
Update Report: No new studies
Wrist Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Radial | 1/1,000 | 0/100 | NC
Uchida, 2005^234^ | 12 months | Wrist | 6/713 | 8/699 | 0.74 (0.26, 2.11)
Update Report: No new studies
Risedronate
Vertebral Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Vertebral | 0/100 | 0/100 | NC
Update Report: No new studies
Hip Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Femoral | 0/100 | 0/100 | NC
Update Report: No new studies
Wrist Fractures
Original 2007 Report
Muscoso, 2004^235^ | 24 months | Radial | 0/100 | 0/100 | NC
Update Report: No new studies

NC = not calculable

###### Alendronate vs. Risedronate in Women With Osteoporosis

No new studies were identified for this comparison. In four RCTs, the odds of overall fractures with alendronate versus risedronate were not statistically different (Table 36). Numbers of fractures were insufficient to permit comparisons for vertebral, hip, and wrist fractures.

Table 36 Fractures with alendronate relative to risedronate, by fracture type among postmenopausal women with osteoporosis

Author, Year | Study Duration | Type of Fracture | Number of Fractures, Alendronate | Number of Fractures, Risedronate | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Bonnick, 2006^236^ | 24 months | Clinical | 34/410 | 34/415 | 1.01 (0.62, 1.66)
Hosking, 2003^60^ | 12 months | Clinical | 6/172 | 6/178 | 1.04 (0.33, 3.27)
Rosen, 2005^237^ | 12 months | Any | 26/520 | 20/533 | 1.35 (0.75, 2.43)
Muscoso, 2004^235^ | 12 months | Total | 2/1,000 | 0/100 | 3.01 (0.02, 373.9)
Update Report: No new studies
Vertebral Fractures
Original 2007 report
Muscoso, 2004^235^ | 12 months | Vertebral | 2/1,000 | 0/100 | NC
Muscoso, 2004^235^ | 24 months | Vertebral | 4/1,000 | 0/100 | NC
Update Report: No new studies
Hip Fractures
Muscoso, 2004^235^ | 12 months | Femoral | 1/1,000 | 0/100 | NC
Muscoso, 2004^235^ | 24 months | Femoral | 2/1,000 | 0/100 | NC
Update Report: No new studies
Wrist Fractures
Original 2007 Report
Muscoso, 2004^235^ | 12 months | Radial | 1/1,000 | 0/100 | NC
Muscoso, 2004^235^ | 24 months | Radial | 0/1,000 | 0/100 | NC
Update Report: No new studies

NC = not calculable

###### Alendronate vs. PTH Among Postmenopausal Women

No new studies were identified for this comparison. In the one available direct comparison of alendronate vs. PTH with respect to fracture risk, the odds of nonvertebral fracture were not statistically significantly different with alendronate versus PTH (Table 37).

Table 37 Fractures with alendronate relative to PTH (Teriparatide) among postmenopausal women

Author, Year | Study Duration | Fracture Type | Number of Fractures, Alendronate | Number of Fractures, PTH | Odds Ratio (95% CI)
Nonvertebral
Original 2007 Report
Body, 2002^238^ | 14 months | Nonvertebral | 10/73 | 3/73 | 3.24 (1.04, 10.07)
Update Report: No new studies

###### Alendronate 10 mg/day vs. Teriparatide 20 μg/day

In one 36-month RCT of people taking glucocorticoids, newly identified for this report (Jadad score 2),224 the odds of vertebral fracture were higher, and the risk of nonvertebral fracture was similar, with alendronate 10 mg/day versus teriparatide 20 μg/day (Table 38). Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately high.

Table 38 Alendronate 10mg/day versus teriparatide 20 μg/day among individuals taking glucocorticoids

Author, Year | Study Duration | Fracture Type | Number of Fractures, Alendronate 10 mg/day | Number of Fractures, Teriparatide 20 μg/day | Odds Ratio (95% CI)
Original 2007 Report: No comparable studies from the original report
Update Report
Saag, 2009^224^ | 36 MOS | Nonvertebral | 15/214 | 16/214 | 0.93 (0.45, 1.95)
Saag, 2009^224^ | 36 MOS | Vertebral | 13/169 | 3/173 | 3.79 (1.39, 10.32)

###### Alendronate + Vitamin D vs. Alendronate + Alfacalcidol

In one 24-month RCT, newly identified for this report (Jadad score 0),56 the odds of nonvertebral and vertebral fractures were similar with alendronate + vitamin D vs. alendronate + alfacalcidol (Table 39). Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately high.

Table 39 Alendronate plus vitamin D versus alendronate plus alfacalcidol

Author, Year | Study Duration | Fracture Type | Number of Fractures, Alendronate + vit. d | Number of Fractures, Alendronate + Alfacalcidol | Odds Ratio (95% CI)
Original 2007 Report: No comparable studies from the original report
Update Report
Ringe, 2007^56^ | 24 months | Nonvertebral | 6/30 | 4/30 | 1.6 (0.42, 6.16)
Ringe, 2007^56^ | 24 months | Vertebral | 4/30 | 1/30 | 3.62 (0.59, 22.26)

###### Alfacalcidol + Prednisolone + Alendronate vs. Alfacalcidol + Prednisolone

One RCT newly identified for this report reported a 90 percent lower odds of vertebral fracture with alfacalcidol + prednisolone + alendronate vs. alfacalcidol + prednisolone (Jadad score 1) (Table 40).225 Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be low.

Table 40 Alfacalcidol plus prednisolone and alendronate versus alfacalcidol plus prednisolone

Author, Year | Study Duration | Fracture Type | Number of Fractures, Alfacalcidol + Prednisolone & Alendronate | Number of Fractures, Alfacalcidol | Odds Ratio (95% CI)
Original 2007 Report: No comparable studies from the original report
Update Report
Okada, 2008^225^ | 18 months | Vertebral | 0/17 | 4/16 | 0.1 (0.01, 0.81)

###### Alendronate vs. Alendronate + Calcium

A RCT newly identified for this report found a three-fold higher odds of any clinical fracture with alendronate vs. alendronate + calcium (Table 41).226 Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately high; however, the study assessed and reported fractures as adverse events.

Table 41 Alendronate versus alendronate plus calcium

Author, Year | Study Duration | Fracture Type | Number of Fractures, Alendronate | Number of Fractures, Alendronate + Calcium | Odds Ratio (95% CI)
Any Clinical Fracture
Original 2007 report: No comparable studies from the original report
Update Report
Bonnick, 2007^226^ | 2 years | Any clinical fracture | 28/281 | 9/282 | 3.01 (1.54, 5.85)

###### Rocaltrol + Caltrate D vs. Caltrate D

A 12-month RCT newly identified for this report found that rocaltrol + Caltrate D did not statistically significantly decrease the odds of vertebral fracture compared to Caltrate D (Jadad score 3) (Table 42).227 Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately high.

Table 42 Rocaltrol+Caltrate D versus Caltrate D

Author, Year | Study Duration | Fracture Type | Number of Fractures, Rocaltrol+Caltrate D | Number of Fractures, Caltrate D | Odds Ratio (95% CI)
Original 2007 Report: No comparable studies from the original report
Update Report
Xia, 2009^227^ | 12 months | Vertebral | 1/74 | 2/76 | 0.52 (0.05, 5.1)

###### Risedronate vs. Zoledronic Acid

No new studies were identified for this comparison. In one 12-month RCT identified for the original report, the odds of subclinical vertebral fracture with risedronate was similar to that with zoledronic acid (Table 43).228

Table 43 Risk of fracture for risedronate relative to zoledronic acid, by fracture type

Author, Year | Study Duration | Fracture Type | Number of Fractures, Risedronate | Number of Fractures, Zoledronic Acid | Odds Ratio (95% CI)
Subclinical Vertebral Fractures
Original 2007 Report
Tauchmanova, 2006^228^ | 12 months | Subclinical vertebral fractures | 2/15 | 3/15 | 0.63 (0.10, 4.15)
Update Report: No new studies

###### Etidronate vs. Calcitonin

No new studies were identified for this comparison. Two RCTs identified for the original report found that the odds of vertebral fracture with etidronate and calcitonin were not statistically significantly different (Table 44).137,229

Table 44 Fractures with etidronate relative to calcitonin, by fracture type

Author, Year | Study Duration | Fracture Type | Number of Fractures, Etidronate | Number of Fractures, Calcitonin | Odds Ratio (95% CI)
Vertebral
Original 2007 Report
Ishida, 2004^137^ | 24 months | Vertebral | 8/66 | 8/66 | 1.00 (0. 35, 2.83)
Garcia-Delgado, 1997^229^ | 18 months | Vertebral | 3/14 | 4/13 | 0.63 (0. 12, 3.39)
Update Report: No new studies

###### Raloxifene vs. Menopausal Estrogen Therapy

No new studies were identified for this comparison. One RCT identified for the original report found that the odds of vertebral fracture with raloxifene and menopausal estrogen therapy were not statistically significantly different (Table 45).230

Table 45 Risk of fracture for raloxifene, relative to estrogen, among postmenopausal women

Author, Year | Study Duration | Fracture Type | Number of Fractures, Raloxifene | Number of Fractures, Estrogen | Odds Ratio (95% CI)
Vertebral Fractures
Original 2007 Report
Reid, 2004^122^ | 36 months | Vertebral | 4/193^*^ | 1/102 | 1.9 (0.03, 12.22)
Update Report: No new studies

* 60 and 150 mg dose groups combined.

###### Menopausal Estrogen Therapy vs. Vitamin D

One new RCT was identified for this report. In an RCT identified for the original report, the odds of vertebral fracture associated with estrogen (conjugated equine estrogen plus medroxyprogesterone acetate) were decreased compared to vitamin D, but not significantly so (Table 46).137 Another RCT, newly identified for this report that examined vertebral and nonvertebral fractures in aggregate found that the odds of fracture were not statistically significantly different with menopausal estrogen + progestogen therapy vs. vitamin D. (Jadad score 3).231 Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately low: the population comprised a small group of asthma patients who were using glucocorticoids.

Table 46 Risk of fracture for estrogen, relative to vitamin D, by anatomical fracture site

Author, Year | Study Duration | Fracture Type | Number of Fractures, Estrogen^*^ | Number of Fractures, Vitamin D | Odds Ratio (95% CI)
Vertebral Fractures
Original 2007 Report
Ishida, 2004^137^ | 24 months | Vertebral | 7/66^*^ | 11/66 | 0.6 (0.22, 1.62)
Update Report: No new studies
Vertebral & Nonvertebral Fractures
Original Report: no comparable studies from the original report
Update Report
Campbell, 2009^231^ | 5 years | Vertebral & non-vertebral- menopausal hormone therapy | 0/23 | 3/24 | 0.13 (0.01, 1.31)

* For Ishida, 2004: CEE plus medroxyprogesterone; for Campbell, 2009: minimum estrogen dose of 2 mg estradiol or 0.625 mg CEE or 50 μg transdermal estradiol.

###### Calcium vs. Vitamin D or Vitamin D vs. Calcium

Six systematic reviews encompassing seven RCTs reported pooled risk estimates for vitamin D vs. calcium. One systematic review assessed overall fractures, six assessed nonvertebral fractures, four assessed hip fractures, and one assessed wrist fractures (Table 48). Table 26 presents pooled estimates of the antifracture effects of vitamin D vs. calcium. Based on the pooled analyses of trials directly comparing vitamin D alone with calcium alone, the antifracture effects of calcium and vitamin D are not statistically significantly different from each other for hip, vertebral, or nonvertebral fractures.

Table 48 Randomized controlled trials included in systematic review of effect of vitamin D on fracture relative to calcium by fracture type

| Systematic Review (Author, Year)
| Avenell, 2009^145^ | | | | | Bergman, 2010^147^ | | Bischoff-Ferrari, 2009^183^ | | Izaks, 2007^148^ | | Jackson, 2007^184^ | | O'Donnell, 2008^144^
| Fracture Type
RCTs (Author, Year) | A | NV | H | V | W | NV | H | NV | H | NV | H | V | NV | V | NV
Avenell, 2004 187 | X | X | X | X
Grant, 2005^153^ | | | X | X
Peacock, 2000^174^ | X
Pfeifer, 2000^239^ | | | | | | X | X | X | | X | | | X
Pfeifer, 2008^209^ | | | | | | | | X
Shiraki, 1996 161 | | | | | | | | | | | | | | X | X
Trivedi, 2003^213^ | | | | | | X | X

A = all; NV = nonvertebral; H = hip; V = vertebral; W = wrist/forearm; X = included in pooled analysis

No new original studies were identified for this comparison. In one RCT of 62 months duration identified for the original report, the odds of overall fracture, vertebral fracture, hip fracture, and wrist fracture were not statistically significantly different with calcium vs. vitamin D (Table 47).153

Table 47 Risk of fracture for calcium, relative to vitamin D, by fracture group

Author, Year | Study Duration | Fracture Type | Number of Fractures, Calcium | Number of Fractures, Vitamin D^*^ | Odds Ratio (95% CI)
All Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | New | 189/1,311 | 212/1,343 | 0.90 (0.73, 1.11)
Update Report: No new studies
Vertebral Fractures
Original 2007 Report
Grant, 2005^153^ | 62 months | Clinical vertebral | 3/1,311 | 4/1,343 | 0.77 (0.17, 3.39)
Update Report: No new studies
Hip
Original 2007 Report
Grant, 2005^153^ | 62 months | Proximal femur | 49/1,311 | 47/1,343 | 1.07 (0.71, 1.60)
Update Report: No new studies
Wrist
Original 2007 Report
Grant, 2005^153^ | 62 months | Distal forearm | 33/1,311 | 33/1,343 | 1.02 (0.63, 1.67)
Update Report: No new studies

* Control group.

In summary, studies that performed head-to-head comparisons of FDA-approved pharmacotherapies for osteoporosis have not discerned statistically significantly different effects on fracture risk reduction.

##### Combinations or Sequential Use of Above

No RCTs tested combinations of osteoporosis therapies or sequential use of osteoporosis therapies in relation to fracture outcomes.

## Key Question 2 How Does Fracture Risk Reduction Resulting From Treatments Vary Between Individuals With Different Risks for Fracture as Determined by Bone Mineral Density, FRAX or Other Risk Assessment Score, Prior Fractures, age, sex, Race/Ethnicity and Glucocorticoid use, and Other Factors (e.g., Community Dwelling vs. Institutionalized, Vitamin D Deficient vs. not)?

### Key Findings for Key Question 2

- Bone Mineral Density. Moderate evidence (post hoc analysis of one large RCT) showed that low femoral neck BMD did not predict the effect of alendronate on clinical vertebral or nonvertebral fracture risk. Post hoc analysis of two-year followup data from a large RCT of postmenopausal women with osteopenia and no prevalent vertebral fractures showed that risedronate significantly reduced the risk of fragility fracture in this group, comparable to reductions seen in women with osteoporosis.
- FRAX Risk Assessment. Moderate evidence (post hoc analysis of data from one large RCT) showed no effect of fracture risk as assessed by WHO/FRAX on the effects of raloxifene in reducing risk for morphometric vertebral fracture among elderly women.
- Prevalent Fractures.
  ○ Evidence is insufficient regarding the association between prevalent fractures and the efficacy of alendronate in reducing the risk for fractures. Post hoc analysis of a large RCT) showed that prevalent vertebral fractures do not predict the efficacy of alendronate; however another post hoc analysis of data from the same trial found that alendronate reduced the risk of incident nonvertebral fractures to a greater extent among women without prevalent fractures (but with T-scores ≤-2.5) than among women with prevalent fractures or without prevalent fractures and with T-score -2 to -2.5.
  ○ Evidence is insufficient regarding prevalent fracture and the efficacy of raloxifene. A post hoc analysis of one large RCT showed that raloxifene decreased the risk of major nonvertebral fracture among women with prevalent vertebral fracture, but not among women without prevalent vertebral fracture. However, two other RCTs found no influence of prevalent fracture.
  ○ Evidence is moderate (a post hoc analysis of one RCT) that prevalent fractures increased the relative efficacy of teriparatide in preventing fractures in postmenopausal women.
- Age.
  ○ In general, a high level of evidence suggests that bisphosphonates are at least as effective for older persons as for younger.
  ○ One RCT found no effect of age on the efficacy of risedronate.
  ○ One RCT found no influence of age on the effect of zoledronic acid in lowering the risk for vertebral or nonvertebral fractures but found that only women under 75 experienced a benefit in reduced risk for hip fracture. Another RCT found that age influences the effect of zoledronic acid on the risk for vertebral fracture risk but not the risk for nonvertebral or hip fracture. However these studies were not powered to detect differences across age groups.
  ○ The relative effect of teriparatide on reducing the incidence of new vertebral fractures and nonvertebral fragility fractures was statistically indistinguishable in younger and older patients.
- Sex.
  ○ Evidence is insufficient regarding the effectiveness of therapies to prevent or treat osteoporosis in men. Only one RCT was identified that actually assessed the effect of sex on response to treatment. This study found that calcium plus vitamin D_3_ reduced the risk of fracture among elderly women but not elderly men.
- Race/Ethnicity.
  ○ A high level of evidence (one post hoc pooled analysis of two RCTs) showed that raloxifene decreases the risk of vertebral fracture but not non-vertebral or hip fracture among Asian women; this finding is similar to that of US and international studies of raloxifene.
- Glucocorticoid Treatment.
  ○ Evidence is insufficient regarding the effect of glucocorticoid treatment on response to therapies. One new RCT found that teriparatide treatment was more effective in reducing risk of vertebral fractures than alendronate but equally effective in reducing risk for nonvertebral fractures.
- Renal Function.
  ○ Evidence is insufficient from trials assessing the effect of renal function on the efficacy of alendronate, raloxifene, and teriparatide. Two trials report no effect of renal function on the effects of these agents. However, in a third trial, impaired renal function reduced the efficacy of zoledronic acid in preventing vertebral (but not nonvertebral or hip) fractures.

### Overview of Results for Key Question 2

To respond to this question, we identified reports of original research and post hoc analyses of original research data that conducted stratified analyses of fracture risk reduction. Evidence Table C-2 in Appendix C includes a table that summarizes key aspects of post hoc and subgroup analyses pertinent to this question of whether fracture reduction during osteoporosis pharmacotherapy varies according to differing risk factors and other individual characteristics. The prespecified risk factors on which we focused are each addressed individually below.

#### Baseline Bone Mineral Density

In a post hoc analysis of FIT/FLEX, postmenopausal women with low femoral neck BMD who had initially completed 5 years of oral alendronate therapy were assigned to receive alendronate for 5 further years or placebo.240 Both treatment arms received calcium and vitamin D. Cumulative incidence of nonvertebral and clinical vertebral fractures did not significantly differ among women who had lower BMD at baseline than among women with higher femoral neck BMD.

A post hoc analysis of risedronate efficacy was performed among women with femoral T-score between -1 and -2.5 without prevalent fracture (osteopenia).241 Cumulative 2-year fragility fracture incidence was statistically significantly (73 percent) lower among women assigned to risedronate compared with women assigned to placebo, and comparable to reductions seen in women with osteoporosis.

#### FRAX or Other Risk Assessment Score

In a post hoc analysis of the MORE raloxifene trial, the decrease in risk of overall clinical fracture and of incident morphometric vertebral fractures associated with raloxifene vs. placebo did not very statistically significantly according to FRAX score.242 Moreover, at age 75 years, vertebral fracture risk reduction was 31 percent irrespective of FRAX score. At younger ages, effectiveness increased with decreasing fracture risk.

#### Prior Fractures (Prevention vs. Treatment)

In a post hoc analysis of FIT/FLEX, postmenopausal women with low femoral neck BMD who had initially completed 5 years of alendronate therapy were assigned to receive alendronate for 5 further years or placebo.240 Both treatment groups received calcium and vitamin D. Cumulative incidence of nonvertebral and clinical vertebral fractures did not significantly differ among women who had prevalent vertebral fractures at baseline.

In another post hoc analysis of the FIT trial with the same 5-year extension as the previously described study, among women with prevalent vertebral fracture at baseline, continued alendronate reduced the risk of clinical (but not morphometric) vertebral fractures, but not morphometric or nonvertebral fractures.243 In contrast, among women without vertebral fractures at baseline, alendronate continuation reduced nonvertebral fractures among women with baseline femoral neck T-score ≤-2.5, but not with T-score between -2 and -2.5.

An extension of the MORE trial of raloxifene examined the relative efficacy of raloxifene among women with, compared to without, prevalent vertebral fractures.244 Although raloxifene did not statistically significantly influence nonvertebral fracture risk, raloxifene did decrease the risk of major nonvertebral fracture (clavicle, humerus, wrist, pelvis, hip, lower leg) among women with prevalent vertebral fracture, but not among women without prevalent vertebral fracture at baseline.

A post hoc analysis examined the effects of raloxifene on new vertebral fractures according to the presence or absence of prevalent fractures.245 The efficacy of raloxifene compared to placebo on decreasing vertebral fractures did not differ statistically significantly between women with and without prevalent fractures, (-8.21%, -0.75% vs. -2.83%, -1.21%, respectively).

Among postmenopausal women with osteoporosis who were randomized to teriparatide therapy in the Fracture Prevention Trial, the absolute benefit of teriparatide was greater among women with the highest number and severity of prevalent vertebral fractures.246

#### Age

A post hoc analysis examined the relationship between age and the effect of risedronate treatment on fracture risk among postmenopausal women with osteoporosis.247 Irrespective of age, compared to placebo, treatment decreased the risk of each type of fracture statistically significantly: RR any fracture 0.58 (0.48, 0.70), RR clinical fracture 0.54 (0.41, 0.69), RR nonvertebral fracture 0.59 (0.44, 0.79), and RR morphometric vertebral fracture 0.54 (0.43, 0.68). In another post hoc analysis of postmenopausal women with osteoporosis, zoledronic acid significantly reduced clinical fractures, clinical vertebral fractures, and non-vertebral fractures to a similar extent among women younger than 75 years and women ≥75 years, so that treatment efficacy did not vary statistically significant according to age.248 However, only women aged less than 75 years, but not 75 years or over, had a statistically significant reduction in hip fracture risk at 3 years.

In a post hoc analysis of the HORIZON trial, antifracture effects of zoledronic acid was evaluated in relation to subgroups defined by age, body mass index, and renal function.249 The effects of zoledronic acid on reducing vertebral fracture risk were statistically significantly greater among women < 70 years old. However, no such treatment-age interaction was apparent for nonvertebral or hip fractures.

In a post hoc analysis of the MORE raloxifene trial, antifracture effects of raloxifene vs. placebo was higher at younger ages.242

In a post hoc analysis of the Fracture Prevention Trial of postmenopausal women with osteoporosis, the relative risk of new vertebral fracture associated with teriparatide vs. placebo was similar among age subgroups.250 The relative risk of vertebral fracture was 0.35 among both women under 75 years and women 75 and over (statistically significant in both cases). For nonvertebral fractures, relative risk of fracture was 0.41 among women under 75 years (statistically significant), and 0.75 (not statistically significant) among women 75 years and over. However, treatment by age interactions were not statistically significant.

Compared to placebo, annual intramuscular injection of vitamin D_2_ (ergocalciferol) 300,000 IU for 3 years among men and women aged 75 years and over did not reduce the risk of any first fracture, or wrist fracture, and it increased the risk of hip fracture (HR 1.49, 95% CI: 1.02, 2.18).162 Associations of vitamin D_2_ with fracture risk did not vary according to sex, age, previous fracture, or mobility.

#### Sex

The 2007 report found “few studies that assessed the effect of [these] agents to reduce fracture risk among men.” Since that time, there continue to be no published trials assessing the antifracture effects of any of these agents in men that are comparable to the large (thousands of subjects), international, placebo-controlled trials that exist for women. In this update review, we identified nine trials that enrolled either all male subjects or had greater than 50 percent male subjects enrolled. However, these trials were either about special populations (cystic fibrosis,55,114 congestive heart failure,157 Parkinson's disease,72 cardiac transplant patients,106), were not powered to detect fracture risk outcomes,74 or were open-label.73

Two trials of Vitamin D were large, included sufficient numbers of men, and reported fracture outcomes. A factorial, cluster-randomized intervention study administered calcium carbonate and vitamin D_3_ 400 IU to community-dwelling residents aged 66+ years-old.150 Overall osteoporotic fracture risk was statistically significantly reduced among women offered calcium and vitamin D (RR 0.81, 95% CI: 0.68, 0.95). In contrast, possibly because fractures were relatively rare in the elderly men, fracture risk was not statistically significantly reduced among the male participants. In another trial, among 9,440 men and women over the age of 75 living in Wales, those randomized to receive 300,000 IU of ergocalciferol by intramuscular injection had no statistically significant benefit in terms of overall fracture reduction or fracture at specific sites. In fact, women had an increased risk of wrist fracture in the Vitamin D treated group; there were no statistically significant differences seen in men.162

#### Race/Ethnicity

A post hoc analysis of the HORIZON trial in 323 Chinese women from Taiwan and Hong Kong found that once-yearly zoledronic acid was associated with a significant 52 percent reduction in morphometric vertebral fracture at 3 years (RR 0.48, 95% CI 0.24, 1.00).251

A pooled analysis of two studies of Asian postmenopausal women with osteoporosis (one Chinese, one Japanese) examined the effects of raloxifene (60 mg/d or 120 mg/d vs. placebo).252 Raloxifene statistically significantly reduced the incidence of vertebral fractures and any new clinical fractures, but not nonvertebral fractures, compared to placebo.

#### Other Factors

##### Glucocorticoid Use

As described above, a small 18-month study that compared patients treated with glucocorticoid and given alendronate with those given alfacalcidol observed a small decrease in the risk for fracture among patients taking alendronate (0.68, 95% CI: 0.12, 3.99), but the study was not powered to assess fracture risk.57 Also, as described above, in a 36-month RCT of people taking glucocorticoids, newly identified for this report (Jadad score 2),224 the odds of vertebral fracture were higher, and the risk of nonvertebral fracture was similar, with alendronate 10 mg/day vs. teriparatide 20 μg/day (Table 38). Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately high. Another RCT newly identified for this report that examined vertebral and nonvertebral fractures in aggregate found that the odds of fracture were not significantly different with menopausal estrogen + progestogen therapy vs. vitamin D. (Jadad score 3).231 Using the criteria of Gartlehner et al.25 to assess the applicability of the new study, we determined its applicability to be moderately low: the population comprised a small group of asthma patients who were using glucocorticoids.

##### Renal Function

In a subgroup analysis of the FIT alendronate trial of women with osteoporosis, alendronate reduced the risk of spine fractures and overall clinical fractures to a similar extent to those without reduced renal function.253,254

A post hoc analysis from the MORE raloxifene trial showed that irrespective of kidney function (creatinine clearance level at baseline), raloxifene treatment was associated with a reduction in vertebral fractures, and no effect on nonvertebral fractures, compared to placebo.255

In a post hoc analysis of the HORIZON trial, antifracture effects of zoledronic acid were evaluated in relation to subgroups defined by age, body mass index, and renal function.249 The effects of zoledronic acid on reducing vertebral fracture risk were statistically significantly greater among women who were overweight or obese, and those who had creatinine clearance >60 ml/minute. However, no such treatment-factor interactions were apparent for nonvertebral or hip fractures. In contrast, in another post-hoc analysis, the lower incidence of vertebral and nonvertebral fractures in teriparatide-treated versus placebo-treated patients was statistically consistent among patients with normal and impaired renal function.256

##### Timing of Initiation of Treatment

A post hoc study focused on the timing of administration of zoledronic acid among men and women in the first 90 days after surgical hip fracture repair.257 Clinical fracture reduction was statistically significant, and was not significantly different, among participants who had initiated zoledronic acid within 6 weeks (33 percent) compared with after 6 weeks (37 percent).

##### Cystic Fibrosis

A systematic review that included five trials of persons with cystic fibrosis (CF) who had not undergone lung transplants assessed the efficacy of bisphosphonates for fracture prevention in this group.258 Bisphosphonates increased BMD but had no significant effect on incident fracture in this population, a finding attributed, at least in part, to the small sample size and short duration of followup.

#### Studies Assessing Multiple Subgroups in a Single Manuscript

A post hoc analyses of the RUTH raloxifene trial performed several stratified analyses, with associated statistical interaction testing, to determine if certain factors predicted the efficacy of raloxifene in reducing vertebral fracture risk among women with, or at high risk for, coronary heart disease.120 Age, smoking, prior fracture, family history of hip fracture, weight loss in the past year, and body mass index were each found not to be statistically significantly associated with the risk of clinical vertebral fractures with raloxifene vs. placebo.

In a RCT, oral vitamin D_2_ (ergocalciferol) 100,000 IU or placebo was administered every four months for 3 years to institutionalized men and women in Wales.203 Compared with placebo, vitamin D was not associated with statistically significant reduction in the incidence of first fracture. In subgroup analyses, the authors report no statistically significant difference in fracture incidence between intervention and control according to mobility level, cognitive function, visual acuity, and type of care home, but details of these subgroup analyses are not provided.

## Key Question 3 Regarding Treatment Adherence and Persistence: a) What are the Adherence and Persistence With Medications for the Treatment and Prevention of Osteoporosis? b) What Factors Affect Adherence and Persistence? c) What are the Effects of Adherence and Persistence on the Risk of Fractures?

For this question, we identified two new systematic reviews, 18 RCTs, and 59 observational studies.

### Key Findings for Key Question 3

- Definitions of adherence and persistence vary widely across studies and over time.
- Adherence rates are higher in clinical trials than in real life and therefore in observational studies, which likely reflects the select populations and controlled environments in trials.
- The rates of adherence and persistence observed in the studies reviewed for this report reflect closely the rates seen and examined in prior systematic reviews on the topic, as well as the previous report. Adherence and persistence as measured in observational studies is poor. In the US studies, overall, about half of patients appeared to show persistence with osteoporosis treatment at 1 year, with adherence ranging widely across studies.
- Many potential barriers have been identified to adherence and persistence. Five of the most commonly assessed in published studies include age, prior history of fracture, dosing frequency, concomitant use of other medications, and adverse effects of the osteoporosis medications. The frequency with which these potential barriers appear in the literature does not necessarily correspond to their importance as barriers/factors related to adherence.
- Age, history of fracture, and number of concurrent medications do not appear to have an important independent association with adherence/persistence.
- Dosing frequency appears to affect adherence/persistence to a point: adherence is improved with weekly compared to daily regimens, but current evidence is lacking to show that monthly regimens improve adherence over that of weekly regimens.
- Adverse effects—and concerns about adverse effects—appear to be important predictors of adherence and persistence. Evidence from a systematic review and 15 out of 17 observational studies suggest that decreased adherence to bisphosphonates is associated with an increased risk of fracture (vertebral, nonvertebral or both).
- The evidence on adherence to raloxifene, teriparatide, and other drugs and its association with fracture risk is insufficient to make conclusions.

#### Key Question 3a What are the Adherence and Persistence With Medications for the Treatment and Prevention of Osteoporosis?

Several methods of measuring adherence are used in the medical literature, including self-report (which suffers from recall bias and may overestimate adherence); electronic devices (which are accurate but expensive); pill counts (which are limited in that the use of pills is assumed if not counted in the bottle); and administrative databases from pharmacies or health plans (which have the advantage of being objective and providing information over a large time span, but are limited in that they include only what is in the database)

Using the databases to measure adherence can be done in several ways. Commonly used is the medication possession ratio (MPR), which is a ratio of the days of medication supplied divided by the days between the first fill and the last fill of the medication. Also measured are the proportion of days covered (PDC), for which pharmacy fills are used to determine what proportion of all days within a specified time period a patient had enough medication, and the percentage of doses taken as prescribed, which is the percentage of prescribed doses taken as directed by the patient during a specified time. Persistence, on the other hand, is typically measured either as a continuous variable and reported as the number of days on a medication until discontinuation or as a dichotomous variable, reporting the proportion of study subjects still on the medication after a period of time.

In the original report, we identified 10 studies that assessed adherence to osteoporosis medications, and 12 studies that assessed persistence.14 Adherence was poor across the 10 observational studies that included alendronate, etidronate, risedronate, calcitonin, menopausal hormone therapy, raloxifene, and calcium/vitamin D, with often less than half of patients achieving a medication possession ratio (MPR) over 80 percent. The adherence rates varied widely across studies. The randomized trials reviewed generally showed higher levels of adherence, with some trials approaching 100 percent adherence. Persistence rates were just as variable across the 12 studies reviewed, with discontinuation rates at 1 year ranging from a low of 14 percent to a high of 84 percent.

##### Prior Systematic Reviews and Meta-analyses

Several recent systematic reviews and meta-analyses have been published on the topic of adherence to medications for osteoporosis.141,259-263 However, each review varies in quality and completeness, and each also reports a wide range of adherence/persistence rates across studies. Cramer reviewed 14 observational studies through May 2006, limiting to those using pharmacy claims databases, and found that the 1-year persistence with bisphosphonates ranged from 17.9 percent to 78.0 percent, and the mean MPR ranged from 0.59 to 0.81.^259^ A more recent systematic review and meta-analysis, by Imaz and colleagues, included all studies from the Cramer systematic review and extended the search through March 2009 to include 15 observational studies of adherence/persistence to bisphosphonates.260 They limited their review to studies using administrative data and pool adherence/persistence rates for only a small minority of included studies (also excluding those studies that focus on dosing regimen effects). In their systematic review of persistence rates, they included five studies with 236,540 patients followed for one year, and found a pooled persistence mean of 184 days, with a range from 98 days to 243 days. In the meta-analysis of bisphosphonate adherence, the authors included only five studies that used the MPR, and found a pooled MPR mean of 66.9 percent with a range from 54 percent to 81 percent over one year. Finally, Siris et al published a systematic review of treatment adherence, focusing on 17 observational studies published through November 2007 that examined the relationship between adherence and fracture rates.262 Adherence and persistence were both described as poor, with a wide range of rates reported in studies, as seen in the review by Imaz.

Most prior reviews of adherence/persistence to osteoporosis medications excluded randomized trials, as rates of adherence in trials are unlikely to reflect true real-world adherence.261 However, a previous systematic review of interventions to improve adherence/persistence with osteoporosis medications was published in 2009 by Gleeson et al., reviewing the literature from January 1990 until July 2008.^263^ Only seven relevant randomized trials (interventions to improve adherence) were found, of which five provided complete adherence/persistence rates for analysis. Few interventions were successful, with three out of the five adherence interventions showing statistically significant improvements in adherence (with modest effect sizes), and only one out of the five showing improvements in persistence. The interventions included telephone followups, counseling, and informational brochures. As in the present review, the authors described inconsistent definitions of adherence and persistence that preclude meta-analytic comparisons between groups. The adherence rates were measured using techniques that ranged from pill counts, to administrative data, to self-reported questionnaires, with rates of adherence (however defined) ranging from 41 percent to 76 percent in the control groups of these trials. The definition and rates of persistence similarly varied. The authors conclude that there are no clear trends in successful intervention techniques in the reviewed studies, although “periodic followup interaction between patients and health professionals appears to be beneficial.”263

##### Rates of Adherence in new Studies

###### Randomized Trials

Just as in the observational studies discussed above, the measurement of adherence and persistence in trials suffers from methodologic limitations. These limitations are coupled with limited ability to generalize findings of adherence/persistence in the trials to the population not enrolled in trials. Nonetheless, several of the trials included in this review report rates of adherence and/or persistence and are discussed below (Table 49).55,264,265 74,85,86,120,136,266-271 Note that most trials report adherence rates for only those who complete the study, which leads to higher than typical adherence rates, as those who stop the drug due to side effects or adverse events drop out of the study.

Table 49 Clinical trials reporting adherence/persistence rates

Author, Year | Drug(s) | Trial Length (Months) | Adherence Definition | Adherence (Persistence) Rate
Binkley, 2009^264^ | Alendronate +Vitamin D | 6 | Missed <6 doses | 94%
Papaioannou, 2008^55^ | Alendronate | 12 | Received at least 80% study drug | 93%
Tseng, 2006^265^ | Alendronate + HRT | 36 | Consuming >85% of Pills | 100%
Delmas, 2008^85^ | Risedronate (two doses/ month) | 24 | Consuming at least 80% of pills | 96%
Delmas, 2008^86^ | Risedronate (one dose/month) | 24 | Consuming at least 80% of pills | 97%
Anastasilakis, 2008^266^ | Risedronate (one dose/week) | 12 | Pill Count (threshold not reported) | 87%
Anastasilakis, 2008^266^ | Teriparatide | 12 | Volume of med remaining | 93%
Boonen, 2009^74^ | Risedronate (one dose/week) | 24 | Pill count (threshold not reported) | 98%
Delmas, 2007^267^ | Risedronate (one dose/day) | 12 | % patients ‘persistent’ and compliant' | 77%
Bonnick, 2009^269^ | Ibandronate (one dose/month) | 6 | Taking at least 5 of 6 doses dispensed | 94%
Binkley, 2009^268^ | Ibandronate (one dose/month) | 6 | Taking at least 5 of 6 doses dispensed | 90%
Ensrud, 2008^120^ | Raloxifene | 60 | Consuming at least 80% of pills | 70%
Gorai, 2009^270^ | Raloxifene | 12 | Adherence: MPR>80% | 65%
Gorai, 2009^270^ | Raloxifene | 12 | Persistence: percent taking pills 7 of last 14 days prior to one year visit | 94%
Adachi, 2007^271^ | Teriparatide | 6 | Administering >80% daily injections | 89%
Adachi, 2007^271^ | Teriparatide | 18 | Administering >80% daily injections | 82%
Boone, 2006^136^ | Transdermal HRT | 24 | Percent of patches used (overall) | 82%
Orwoll 2010^274^ | Alendronate (one dose/month) | 24 | Consuming >80% pills | 81%
Brown 2009^275^ | Denosumab vs. Alendronate | 12
Kendler 2010^276^ | Denosumab vs. Alendronate | 12 | Denosumab: taking both injections | 90.5% (89.7%)
Kendler 2010^276^ | Denosumab vs. Alendronate | 12 | Alendronate: MEMS >80% | 78.2% (79.8%)
Karkkainen 2010^273^ | Calcium + Vitamin D | 36 | Received at least 80% study drug | 63.8%

Three trials of alendronate report adherence rates.55,264,265 A randomized trial of a combination tablet of alendronate and vitamin D alone compared to the combination tablet plus additional vitamin D reported high levels of adherence over 24 weeks, with 96 percent of the patients on the combination pill and 94 percent in the comparator group reporting missing fewer than 6 tablets.264 In a 12-month randomized trial comparing alendronate to placebo among patients with cystic fibrosis, 93 percent of patients in the alendronate arm were adherent to therapy, meaning they received at least 80 percent of the study drug (although the exact method to measure this adherence is unknown).55 In a three-year randomized single blind trial in Taiwan of patients on alendronate plus menopausal hormone therapy compared to alone, the authors report a 100 percent adherence rate over the study; more than 85 percent of pills were consumed by participants at each study visit.265

Five trials of risedronate reported adherence rates.74,85,86,266,267 In two randomized trials comparing daily versus monthly doses of risedronate (one using 75 mg dose on two consecutive days each month,85 and the other using 150 mg monthly86, adherence was high for all groups based on tablet counts; over 95 percent of study participants took at least 80 percent of their pills over the course of the 2-year studies. In a small randomized trial of 44 Greek women, comparing weekly risedronate to daily teriparatide, rates of adherence for both groups were high.87 percent of risedronate patients were adherent based on pill counts and 93 percent of teriparatide patients were adherent based on volume of medication remaining at each visit.266 However, the thresholds for determining adherence were not provided. In an open-label randomized trial of an adherence intervention (included in the prior systematic review of adherence interventions,263 patients on risedronate were randomized to receive feedback about bone turnover).267 There was no difference in persistence with therapy (defined as discontinuation of therapy) between the intervention group (80 percent persistence at 1 year) and the control group (77 percent persistence at 1 year). Both groups had unexpectedly high levels of adherence. In a study of men with osteoporosis comparing 35 mg risedronate weekly with placebo, adherence based on pill count was high, with 98 percent of risedronate patients ‘compliant with drug’ (exact definition of compliance is not described).74

Two studies report on adherence with monthly ibandronate using data from the CURRENT trial, a six-month trial of monthly ibandronate among postmenopausal women currently taking weekly alendronate or risedronate.268,269 The trial was industry-funded and compared women at baseline to 6 months after starting ibandronate without a control group. Adherence was measured using drugs dispensed and returned and defined as taking at least five of the six specified doses. Overall, 94 percent of women were adherent to therapy,269 and among those with baseline gastrointestinal symptoms, 90 percent were adherent.268

Two studies reported adherence with raloxifene.120,270 In a secondary analysis of data from the RUTH trial, which compared raloxifene 60mg/day to placebo over five years, when adherence was defined based on pill count showing at least 70 percent of pills taken, approximately 70 percent of study subjects were defined as adherent.120 In a small randomized trial of 137 postmenopausal Japanese women, comparing raloxifene to alfacalcidol and to the combination of the two, both adherence and persistence were measured.270 Adherence was defined based on an MPR greater than 80 percent over the one-year study. Persistence was defined as continuing to take the therapy at one year, which was operationalized as reporting taking medication at least seven of the last 14 days immediately prior to the one-year visit. Persistence rates at one year were 61 percent, 65 percent, and 55 percent for alfacalcidol, raloxifene, and the combination, respectively. The percent of patients adherent at one year was 78 percent for alfacalcidol, 94 percent in the raloxifene group, and 78 percent in the combination group; these differences were not statistically significant.

One additional study included teriparatide.271,272 In this uncontrolled open-label intervention, women who had failed previous antiresorptive treatment were administered teriparatide. Adherence was defined as administering more than 80 percent of daily injections; adherence was 89 percent at six months, and 82 percent at 18 months.

One RCT examined adherence to calcium and vitamin D supplementation in older women over a 3-year period.273 Adherence was defined as taking at least 80 percent of study medication, although the exact measurement of adherence was not provided. Overall, 63.8 percent of women achieved an 80 percent level of adherence.

Finally, one small (31 participants) double-blind randomized trial compared transdermal estrogen/progestin with placebo for treatment of osteoporosis in postmenopausal women with primary biliary cirrhosis.136 Adherence rates were not specifically reported except that participants overall used 82 percent of patches supplied to them, with no difference between groups.

###### Observational Studies

Adherence and persistence rates in observational studies are substantially lower than those in clinical trials. Our review found rates of adherence and persistence similar to the prior meta-analyses on the topic,260,262 although, as in prior studies, the rates and methods of measurement of adherence vary widely. In total, 59 observational studies contributed to our analysis of ‘real-world’ adherence and persistence rates (i.e. coming from data outside of the clinical trial setting). 277-317 Twenty studies focused on adherence alone,278-284 277,285-287,318-326 13 studies focused on persistence alone,288-293 294-298,327,328 and 24 studies examined both adherence and persistence.299-315,329-331 All but three of the studies used pharmacy claims database analysis.324,327,332 In two of the studies, 316,317 the actual outcome measured could not be determined from the article; each of those were small non-US studies that describe rates of “adherence” in their results, but whether they truly measured adherence or persistence is not clear. Adherence and persistence rates for all of these studies can be found in the adherence evidence table in Appendix C.

Of the included studies, 25 examined adherence/persistence exclusively in the US; these studies are discussed further below. All of these studies are industry funded except for a small study of 198 men at a single VA278 and a larger study of seniors in the Pennsylvania PACE prescription assistance program.322 Thirteen of the articles describe adherence only,278,281,282,286,287,318,319,321-324,333,334 six describe persistence only,291-293,297,298,327 and six describe both adherence and persistence.304,306-308,331,332 None of the articles describe primary nonadherence (nonfulfillment), which refers to prescriptions not filled at a pharmacy after they are written. All studies included bisphosphonate use, except one that described adherence to and persistence with teriparatide.331

###### Adherence

Ten of the thirteen adherence studies employed the MPR or PDC threshold of more than 80 percent for their calculations of adherence and used pharmacy claims data. These ten studies all found rates of adherence well under 50 percent.

Several of these studies used data from large US health plans. In a study of 101,000 health plan members, 44 percent of individuals had an MPR over 80 at 1 year, 39 percent at 2 years, and 35 percent at 3 years.282 Similarly, in a study of 3,658 women in one health plan, 45 percent had an MPR over 80 percent for their bisphosphonate.286 Two other studies of individuals in health plans revealed low rates of adherence (32 percent had an MPR over 80 percent at 12 months,318 and 48.7 percent had a PDC greater than 80 percent at 12 months.321 In the only large nonindustry-funded study examining adherence in a US health plan, researchers examined 32,697 seniors in the Pennsylvania PACE program, finding that 49.8 percent of those on bisphosphonates had a PDC greater than 80 percent, 52.6 percent of those on raloxifene, and only 10 percent of those on calcitonin.322 Finally, an examination of 21,655 members of a large health plan found 42.7 percent adherent among commercially insured members, and 33.7 percent among those in Medicare Advantage plans.333

Several of the studies used the MarketScan claims database, which combines data from many large employers, health plans, and government organizations. In a study of 61,000 women in this database, 49 percent had an MPR over 80 percent on monthly ibandronate, 49 percent on weekly bisphosphonate, and 23 percent on daily bisphosphonate.281 In another large study of 460,584 women from MarketScan using bisphosphonates for variable periods of time, 32.7 percent of women had an MPR >80% 319. Finally, 5,500 new users of once-weekly bisphosphonates, again from the MarketScan database, had adherence rate of 37 percent at 12 months if they did not switch medications, 48 percent if they switched to another weekly bisphosphonate, and 42 percent if they switched to a once-monthly bisphosphonate.323

The studies that did not use pharmacy claims were substantially smaller in size. In a study of 176 women from a group practice that used the number of months a prescription was obtained during the study period as the measure of adherence, overall 70 percent of women were adherent to daily bisphosphonates, and 69 percent to estrogen.287 Another study of 25 women receiving free alendronate/cholecalciferol for 6 months found an adherence rate by pill count of 52 percent.324 In the final adherence-only study, and the only study to include only men, 198 men at a VA in Wisconsin had an average adherence of 54 percent for alendronate, as measured by the prescription refill ratio at 2 years.278

Two studies examining both adherence and persistence to bisphosphonates reported a mean MPR among over 200,000 respondents of 83 percent for weekly and 78 percent for monthly bisphosphonates at six months,307 and 80 percent and 75 percent at 12 months.308 The two other studies used the proportion of days covered as their adherence measurement: One found a rate of adherence (defined by proportion of days covered [PDC] over 60 percent) at one year of 55 percent and 45 percent at two years,304 and the other found an overall rate of adherence of 61 percent at one year.306 The final study that examined both adherence and persistence to bisphosphonates used a questionnaire to examine cross sectional self-reported adherence (based on missing at least 1 dose over the last month) and found a rate of 65 percent.332

Data on adherence to teriparatide come from two analyses from the MarketScan databases.331 In the analysis of 2,218 commercially insured and Medicare beneficiaries, 58 percent had an MPR greater than 80 percent at 6 months, and in the analysis of 824 Medicaid beneficiaries, only 33.5 percent had an MPR over 80 percent at 6 months.

###### Persistence

The studies that report on persistence have as much variability in their results and methods as the adherence studies already discussed. Of the six studies above that discuss both adherence and persistence, one defined persistence using a refill gap of 30 days (i.e. discontinuation of drug is defined by a gap of 30 days or greater between refills),306 one used a gap of 60 days,331 while two others use a gap of more than 90 days,307,308 and one used a questionnaire to determine if patients had stopped taking their medication for more than a month.332 Persistence at 12 months was an average of 196 days in the study using a 30-day gap, and 250 days in the study using a gap greater than 90 days.308 In each of the studies of bisphosphonate that used pharmacy claims data, fewer than half of the patients were still persistent at 12 months. In the one study of 729 patients that used a questionnaire, 65.8 percent of patients were persistent. In the study of teriparatide, in which persistence was measured based on a gap of 60 days, 56.9 percent of patients overall were persistent at 1 year.331 The final study examining adherence and persistence appeared to combine the two measures,304 such that they reported the percent of individuals still on the medication with a PDC over 60 percent (55 percent overall at one year).

In those studies that focused specifically on persistence, rates of persistence were similarly low. In a study of 211,319 health plan members that defined persistence as filling at least one day of medication each month, 56 percent of weekly bisphosphonate users, and 40 percent of daily users were persistent at one year.291 In a study of 1,092 patients using one national pharmacy chain, persistence at seven months (based on continuing to take the bisphosphonate) was 55 percent overall.298 The one study that was based on self report and defined discontinuation as, “no medication for at least 3 months,” found a rate of persistence at one year of 66 percent.327

The remaining three persistence studies all used a gap of over 30 days to define nonpersistence. In a study of 4,769 health plan members on alendronate, overall persistence at two years was 43 percent, with persistence defined as being on alendronate without a gap for at least 182 days, or six months.292 A larger study of 91,630 health plan members reported that approximately 30 percent of patients starting on bisphosphonates were no longer on the medication after 90 days, based on a gap of 30 days for weekly and 45 days for monthly bisphosphonates.293 Finally, in a study of 166,000 patients from the Information Management System (IMS) database, mean one-year persistence was 116 days, 113 days, and 98 days for weekly alendronate, weekly risedronate, and monthly ibandronate, respectively.297 Only approximately half of all individuals in the study persisted with the medication after their first prescription (based on a gap of less than 30 days).

In summary, the rates of adherence and persistence seen in the reviewed studies reflect closely the rates seen and examined in prior systematic reviews on the topic, as well as the previous report. Adherence and persistence are poor, variable, and measured in different ways and over different periods of time. In the US studies, overall about half of patients appeared to be persistent at one year, with adherence ranging widely across studies.

#### Key Question 3b What Factors Affect Adherence and Persistence?

An evidence review of the factors affecting adherence and persistence with medications for osteoporosis is fraught with challenges, the most important of which is the tremendous heterogeneity in how adherence is defined and measured. Additionally, medication-taking is a “private behavior” and is not easily measurable and is subject to the ‘Hawthorne Effect,’ where subjects change their behavior because they know they are being studied.335,336 To fully understand how patients take their medications, they cannot know they are being studied, which is rarely the case. Not only is adherence difficult to measure, but the factors affecting adherence are often measured in different ways across studies, further complicating a synthesis of the literature. No prior systematic review has been published on the factors affecting adherence and persistence to drugs for osteoporosis.

In the original report, we identified 25 studies that discussed factors that may affect adherence or persistence with medications for osteoporosis.14 Side effects (five studies), absence of symptoms (four studies), comorbid conditions (two studies), age (four studies), ethnicity and socioeconomic status (4 studies), and dosing regimens (eight studies) were reviewed. Studies consistently reported higher adherence and persistence rates with weekly bisphosphonate dosing as compared to daily, and additional patient preference studies reported patients preferred less frequent dosing of medications. These findings are consistent with prior systematic reviews of regimen complexity that found that more complex regimens (increased dosing frequency) are associated with decreased adherence across a range of diseases.337-340

For the current report, we identified 41 studies that discussed factors potentially affecting adherence or persistence or associated with adherence or persistence. Evidence Table C-5 in Appendix C lists each of the potential barriers (or factors) identified in the review, ordered by the number of studies discussing each particular potential barrier. Many of the barriers listed are reviewed in only a few studies. We focus the discussion below on five of the top factors that are discussed, acknowledging that several other barriers/factors related to adherence are important, including some not listed here. Cost-sharing, the presence of comorbidities, knowledge about osteoporosis, and several other factors are important barriers to osteoporosis medication adherence but are not discussed in detail below.

##### Age

We identified 31 articles that included age as a factor in predicting medication adherence or persistence. None of the studies had their main focus on the effect of age, but rather they all had age as a covariate in analyses predicting adherence or persistence. Most of the articles focused on bisphosphonates. Several included bisphosphonates in analyses of all osteoporosis medications,318,320,327,330,341 and three included raloxifene in addition to bisphosphonates.283,299,313 One study focused exclusively on teriparatide,331 and one focused on calcium and vitamin D.314 Almost all used pharmacy records and automated measures of adherence/persistence in their analyses except five.283,285,299,320,332 Two of these studies were small international studies: one from Croatia285 that examined only unadjusted correlations between age and adherence, and the other from the Czech Republic.283 The latter, interestingly, found no association between age and ‘drug compliance,’ but found an association between decreased ‘compliance with dosing instructions’ and increased age, which illustrates the very complicated nature of adherence measurement.

The results overall were mixed, with four studies finding increased age associated with better adherence,280,300,309,332 four studies finding increased age associated with worse adherence283,285,314,321 (although two of these studies285,314 examined only unadjusted results), and fourteen studies finding no association between age and adherence or persistence278,298,303,305,306,313,317 318,320,327-329,331,341 (note: some overlap is possible between studies that examined both persistence and adherence). In those studies that examined persistence, six found increased age associated with better persistence,291,292,295,300,309,330 and six found increased age associated with worse persistence.290,294,296,297,299,314 One study of 729 women from a large multispecialty clinic in the US that used only self-report to measure persistence and adherence found mixed results, with age associated with better adherence but no association of age with persistence.332

Eleven of the reviewed articles assessing the effect of age on adherence/persistence were based in the U.S.,278,291,292,297,298,306 318,321,327,331,332 and these also revealed mixed results. All focused exclusively on bisphosphonates, except one that examined teriparatide,331 in which age had no association with persistence. Three studies found no independent effect of age on adherence or persistence,278,298,306,318 and two others examined only persistence and also found no association.327,331 Those studies that found an association between age and adherence were evenly split between an association with age and better adherence 280,300,309 and an association with worse adherence.283,285,314,321

Only two studies found that age was associated with increased persistence.291,292 The latter292 was only an unadjusted comparison, using data from a large US health plan to examine the relationship between persistence and fracture risk for 4,769 patients on alendronate; 46 percent of patients who were older (over age 65) were persistent to their meds, compared to 43 percent of 55-64 year olds, and 41 percent of 45-54 year olds. The one study that found increased age associated with lower persistence297 used IMS longitudinal prescription data for 166,000 women to examine difference in persistence between weekly and monthly bisphosphonates; in adjusted analyses, the rate of discontinuation of bisphosphonates and the odds of discontinuing were both higher for older patients compared to younger patients (50-54 year olds).

The reviewed literature, both US-based and non-US-based, would suggest that age by itself cannot be used as a predictor of adherence or persistence in the treatment of osteoporosis.

##### History of Fracture

Sixteen studies assessed prior history of fracture as a factor in adherence. Of the 16, four were US studies;278,327,331,332 the remainder were conducted in Canada (two),296,342 Croatia (one),285 Czech Republic (one),283 France (two),305,320 Germany (one),312 Japan,328 Netherlands (one),280 Sweden,341 and UK (two).300,315

Three of the sixteen studies found that a history of prior (osteoporotic) fracture was significantly associated with increased rates of adherence and persistence to osteoporosis therapy,280,312,^341^12 studies found no significant association between prior fracture and adherence or persistence to osteoporotic medications, and one study found an association between prior fracture and increased risk for discontinuing.328

The three studies that identified an association with prior fracture were observational studies based on large administrative databases. One study of 8,822 Dutch women, 45 and over, who had a diagnosis of postmenopausal osteoporosis and were new users of alendronate or risedronate, found that osteoporotic fracture or hospitalization for osteoporosis in the year before the start of therapy was associated with decreased odds of noncompliance (adjusted OR 0.65; 95% CI: 0.47, 0.88), as measured by MPR.280 In a second study, among 4,451 German women 45 and older who were enrolled in a health plan for at least 90 days between 2000 and 2004 and were prescribed oral bisphosphonates for the treatment of osteoporosis, MPR-based adherence was higher in those with previous fractures than in those with no prior fractures (61.6 percent vs.55.6 percent at 180 days; 42.1 percent vs. 39.7 percent at 720 days).312 A third study, which identified 56,586 participants in the Swedish Prescribed Drug Register through prescriptions for alendronate, risedronate, strontium, and raloxifene between 2005 and 2009, used survival analysis to measure persistence and MPR to measure compliance in persistent individuals. Any prevalent fracture was associated with a higher rate of persistence (HR 0.96, 95% CI: 0.93, 0.99, p<0.01). All three studies were industry-funded.

None of the US studies found a link between prior fracture and persistence or adherence. In one US study, among 198 male veterans treated with alendronate for osteoporosis, adherence during the first year of treatment (as determined by prescription refill ratio in pharmacy records) was not associated with prior fracture, although the response rate in this study was very low.278 A 2010 prospective cohort study of 3,007 adults (the POSSIBLE US study) found no increased chance of discontinuing or switching medication among adults with a history of fracture after the age of 45 (HR 1.01, 95% CI: 0.87, 1.18).327 A study of all adults 45 and over with at least one prescription claim in the MarketScan database for teriparatide from 2004 to 2006 (n=3,042) found no difference in time to discontinuation or gaps in use between individuals with prior vertebral, hip, or other fractures and those with no prior fractures; the population comprised those with commercial, Medicare, and Medicaid coverage.331 Finally, a cross-sectional survey and medical record review of 729 adults in a multiple-specialty clinic who received a prescription for a bisphosphonate between 2006 and 2007 found no difference in persistence with the medications between those with documented prevalent vertebral fracture and those without.332

Therefore, the literature we identified does not point to an association between prior history of fracture and medication adherence or persistence.

##### Dosing Frequency

We identified 20 articles that examined the effect of dosing frequency on adherence. Five studies compared monthly to weekly dosing regimens.297,305,307,308,323 Twelve studies compared weekly to daily regimens,280,283,291,292,300,306,309,310,311,313,317,341 and three studies compared monthly, weekly, and daily regimens.281,320,330 Out of the 20, 15 were industry-funded; the five studies not funded by industry report on results from Australia, Israel, Belgium, and the Czech Republic.283,309,310,313,317

Of the five studies that directly compare monthly to weekly dosing regimens,281,297,305,307,308,323 all found a significant difference in adherence between the dosing regimens, with three favoring weekly and two favoring monthly. In a study of 240,000 patients from the IMS database in the US, mean adherence and persistence were significantly improved in weekly risedronate compared to monthly ibandronate, although the adherence results were no different when focusing on adherence in new users.307 The mean MPR and mean days persistent on medication were 83.3 percent and 144 days, respectively, for risedronate, while the mean MPR and days' persistence for monthly ibandronate were 78.5 percent and 100 days, respectively. The study was industry-funded and authored. Very similar results were found in a 2009 study by the same authors and funders examining the same drugs;308 some differences in results between the overall sample and new users led the authors to conclude that adherence and persistence were similar for monthly ibandronate and weekly risedronate dosing, although in the overall sample, adherence and persistence were significantly better among weekly users. In yet another study using the IMS prescription database, this time of 166,000 women newly started on bisphosphonates, and industry-funded and, in part, industry-authored, mean persistence was worse with monthly ibandronate (98 days mean persistence) than with weekly alendronate and risedronate (116 days and 113 days, respectively).297 However, after removing patients who failed to refill after their first prescription, persistence was the same across the three bisphosphonates.

In a study of almost 3,000 patients from France comparing monthly ibandronate to weekly bisphosphonate, partly industry-funded and authored, adherence and persistence were superior with monthly ibandronate compared to weekly bisphosphonates.305 In an interrupted time-series analysis of new users of once-weekly bisphosphonates in the MarketScan databases, those who switched to one-monthly treatment had a decrease in the number of adherence failures, while no change in adherence was found for those who did not switch or those who switched to another weekly agent (although the proportion of those adherent was lower in the once-monthly switchers than one-weekly switchers).323

Three studies included rates of adherence or persistence with daily, weekly, and monthly osteoporosis medications.281,320,330In a study of 61,000 new users of bisphosphonates from the MarketScan database, there were no differences between monthly and weekly users in adherence over one year (49 percent with MPR over 80), although users of daily bisphosphonates had worsened rate of adherence (23 percent with MPR >80 percent).281 In an analysis of the Dutch IMS database, only small (but statistically significant) differences in adherence (MPR greater than 80 percent) were observed between monthly ibandronate (89 percent) and the weekly or daily bisphosphonates (91 to 93 percent);330 Persistence with monthly bisphosphonates was similar to weekly bisphosphonates and better than daily. Finally, in an analysis in France using the Morisky scale to measure adherence using self-report, monthly administration had higher adjusted odds (OR 2.23 95% CI: 1.37, 3.64) for adherence than daily (monthly vs. weekly was not studied).320 In the same analysis, sponsored by the makers of ibandronate, users of monthly treatment were more satisfied with their treatment than those on weekly or daily regimens

The remaining 12 studies found that overall adherence to and persistence with bisphosphonates was improved in weekly compared to daily regimens. Three of the studies were based in the US291,292,306 and all but three310,311,317 found that weekly regimens resulted in improved adherence and/or persistence than daily regimens. The three studies finding no effect of dosing regimen on adherence were small predominately non-US studies whose main goal was something other than studying the relationship between dosing frequency and adherence: the studies examined 793 patients in Australia,317 1,376 patients in Belgium,310 and 200 patients in the Czech Republic.283

In summary, the evidence points to improved adherence for bisphosphonates in weekly rather than daily dosing. This conclusion is supported by prior literature, including the prior evidence review,14 prior systematic reviews337-340and prior meta-analyses.306 The evidence reviewed here also suggests that monthly bisphosphonates do not result in better adherence/persistence than weekly treatment, although there are too few studies in this area to make any firm conclusions and the industry sponsorship of these individual studies may have introduced bias.

##### Number of Concurrent Medications

Polypharmacy is often cited as a potential barrier to medication adherence. In the current review, the use of concomitant medications was included in the analysis of medication adherence/persistence in 15 studies.278,280,283-285,297-299,305,306,315,316,318,329,332 However, the definition of concomitant medication use differed substantially across studies; in some cases the number of medications present among study participants at baseline was analyzed, whereas in other cases the number of medications dispensed in the year prior to the start of bisphosphonates was studied, and in other cases the variable was dichotomized, to indicate whether or not patients took concomitant medications at all. In no case was concurrent medication use the primary independent predictor of interest in these studies, but instead was an included covariate. Note that causality is difficult to establish in studies linking the number of concurrent medications with adherence. Almost by definition, patients who are more adherent or persistent with medications are likely to be taking more medications; thus any relationship between adherence/persistence and number of concomitant medications may be seriously confounded.

Only three of the 15 studies280,297,306 found a significant association between the number of concomitant medications and medication adherence. All other studies found no relationship. In a study of 2,741 postmenopausal women with osteoporosis from the US that focused on dosing regimens, the number of medications used 90 days prior to bisphosphonate use was an independent predictor of persistence (not adherence), although the direction of this association is not indicated.306 In a large cohort study of new female users of bisphosphonates from the PHARMO data base in the Netherlands, the number of comedications in the year prior to starting the bisphosphonate was associated with adherence.280 Women using more than 10 medications in the prior year had 1.87 times the odds of nonadherence compared to women using no medications, with smaller but significant odds ratios for women using fewer medications as compared to no medication. Finally, in a large U.S. study using the IMS database, number of unique medication classes dispensed in the 12 months prior to the start of bisphosphonate therapy was an independent predictor of persistence (adherence not measured).297

The remaining 12 studies found no independent association between number of medications and medication adherence or persistence. In each case, concomitant medication use was defined differently, and in each case was a covariate in the analysis rather than the main independent variable of interest. The four additional US-based studies278,298,318,332 (out of a total of seven that assessed concurrent medications) included the only all-male sample included in this review (with 198 male veterans from one VA medical center),278 and a telephone interview of 1,092 women with a low response rate of 33 percent.298 In the latter study, respondents who were adherent took more medications at baseline than nonadherents, although the medication variable was not included in the final multivariate model (and is likely explained as a function of, rather than a cause of, the respondents' nonadherence). In the other two studies, one of which was a study of 142 women developing a prediction rule for very low adherence (MPR <20%) and the other a study of 729 women using self-reported adherence and persistence, the number of medications taken daily had no independent association with adherence, although certain beliefs about medications related to concomitant medication use were relevant.318,332 For example, agreeing that one was taking too many different medications was one of the seven predictors included in the final prediction rule for low adherence, even though number of concomitant medications was not an independent predictor.318

In conclusion, the evidence does not support a firm role for the number of concomitant medications in determining adherence or persistence to bisphosphonates, although variability in how concomitant medication use is measured is a substantial limitation to assessing the literature. In addition, the actual number of medications taken may be less important to determine adherence and persistence than beliefs about the value of those medications and any additional new medication.

##### Adverse Effects

Nine studies assessed the association of adverse effects from medications used to treat osteoporosis with treatment adherence and/or persistence.278,290,316,317 280,283,298,318,327 All nine reported a significant effect of medication-associated adverse events on adherence or persistence. Among the studies, four were conducted in the US,278,298,318,327 two were Japanese,290,316 and the remainder were conducted in Australia,317 Netherlands,280 and the Czech Republic.283

In one US study of 198 male veterans treated with alendronate for osteoporosis, adherence was determined by prescription refill ratio in pharmacy records. During the two-year interval following onset of alendronate therapy, nonadherent men were significantly more likely than adherent men to describe side effects of alendronate (47 percent versus 29 percent, p=0.01).278

The second US study assessed persistence with bisphosphonate treatment among 1,092 women by analyzing pharmacy claims data (the outcome measured was discontinuation for seven months). Troublesome side effects were the most common reason for discontinuation of bisphosphonates (OR 6.78, 95% CI: 4.67, 9.86).298 In a third study, 3,000 postmenopausal women on osteoporosis treatment were followed for one year and reported persistence with medications;327 the probability of either discontinuing or switching their original medication was greater for those who attributed more severe side effects to their osteoporosis therapy. Finally, in an analysis of 142 women developing a prediction rule for very low adherence (MPR<20%), worry about side effects (as opposed to actually experiencing side effects, which was not measured) was an important independent predictor of low adherence.318

In summary, adverse effects—and concerns about adverse effects— do appear, based on the literature, to be an important factor affecting adherence and persistence with bisphosphonates and other osteoporosis medications as well.

#### Key Question 3c What are the Effects of Adherence and Persistence on the Risk of Fractures?

In the original report, three observational studies examining the effect of adherence on risk of fracture were identified, and in all three studies, the fracture risk varied with the level of adherence. In one study, low adherence (MPR <80%) was associated with a 17 percent increased risk of fracture.343 In a second study, adherence to medications was associated with a 25 percent relative risk reduction for all osteoporotic fractures, and persistence with therapy was associated with a 29 percent reduction in vertebral fractures and a 45 percent reduction in hip fractures. A third study344 found that women who were adherent (MPR>80%) had a 16 percent lower fracture rate. All three of these studies were included in the systematic review described below.

For the present report, we identified one high-quality systematic review,260 one comprehensive systematic review without meta-analysis,262 two randomized trials,120,345 and seventeen observational studies277,279,282,286,292,300,302,304,311-313,319,322,333,334,341,346 that examined the association between adherence/persistence/compliance and fracture risk. All of the observational studies utilized registries or claims databases from pharmacy and/or medical records. Eight of the studies were based solely on US data.282,286,292,304,319,322,333,334 The RCTs and 15 of the 17 observational studies found that decreased adherence was associated with an increased risk of fracture (either vertebral, nonvertebral or both), although the risk varied depending on the drug examined and on whether use was for primary or secondary prevention of osteoporosis.

Below we describe the two reviews as well as the original studies identified in our search. Eight of the studies we identified were already included in the systematic reviews (four in the review by Imaz, five in the review by Siris, and one in both). Table 50 shows the studies included in each review as well those included in the original report and those identified for this report). These studies are described only briefly; the others are described in more detail.

Table 50 Adherence studies included in systematic reviews

| Review
Original Studies | Imaz | Siris
Blouin, 2008 * | X
Briesacher, 2006 | | X (abstract)
Briesacher, 2007 * | | X
Caro, 2004 † | X | X
Curtis, 2007(M444) | | X (abstract)
Curtis, 2008 * | X | X
Gallagher, 2008^300,*^ | X
Goettsch, 2005 | | X (abstract)
Gold, 2007^292,*^ | | X
Gothe, 2007 | | X (abstract)
Huybrechts, 2006 † | X | X
Jaglal, 2007 | | X (abstract)
Mccombs, 2004 | | X
Penning-van Beest, 2008 *,† | X | X
Rabenda, 2008 * | | X
Sebaldt, 2004 | | X (abstract)
Sheehy, 2009 | X
Siris, 2006^†^ | X | X
Van den Boogaard, 2006 * | | X
Weycker, 2007 | | X

* Identified in the search for the current report.

† Included in the original report.

##### Systematic Reviews and Meta-analyses

Imaz conducted a meta-analysis of articles published prior to March 22, 2009 on the association of adherence to bisphosphonate treatment with fracture risk,260 adopting the following definition of persistence: “the duration of time from the initiation to discontinuation of therapy.” Compliance (adherence) was defined as “the extent to which a patient acts in accordance with the prescribed interval and dose of a dosing regimen.” For persistence, the included studies had to define “discontinuation” as a gap in refills greater than 30 days within one year of beginning treatment for osteoporosis. Compliance studies were limited to those that used the MPR for at least one year. The assessment of the influence of low compliance on fracture risk included observational studies that compared participants determined to be of higher and lower compliance over 1 to 2.5 years. The authors conducted meta-analyses based on data at one year of follow up, to assess overall persistence (mean persistent days) and compliance (MPR), and the estimated association between level of compliance and fracture risk. Included studies reported only clinical fractures as their key outcomes. The meta-analysis to assess the association of level of bisphosphonate compliance with fracture risk combined data from eight studies. Six of the studies (171,063 patients) reported total fracture risk, for a pooled risk of 1.46 (95% CI: 1.34, 1.60). The risk for site-specific fractures was lower among more compliant bisphosphonate users than less compliant bisphosphonate users: 16 percent for nonvertebral fractures (pooled RR 1.16 95% CI: 1.07, 1.26) and 28 percent for hip fractures (pooled RR 1.28, 95% CI: 1.06, 1.53). In sensitivity analyses, the authors found that the effect of varying levels of compliance on fracture risk was further affected by sole use of bisphosphonates versus concurrent use of menopausal hormone therapy.

Siris conducted a systematic review of the literature prior to November 2007 (but not a meta-analysis).262 Eligible for inclusion were observational or retrospective analyses of compliance, persistence, and adherence with treatment for osteoporosis and their relation to fracture rates. Excluded were RCTs, meta-analyses, case-control studies, and reviews of previously published data. Compliance and persistence were defined as above.

Of the 461 citations identified by the literature review, 17 were found to meet the inclusion criteria, including both published articles and abstracts (Table 50). The duration of followup varied from 2 to 7.5 years. The authors noted that direct comparisons of fracture rates were not possible because of the various methodologies used in the different studies and the additional variables that were included in the analyses. In U.S.-based studies, fracture risk was reduced 18.7 percent to 23 percent over 2 years.304 In general, the studies supported the findings that individuals with the highest compliance with bisphosphonate treatment (>90% MPR) had a reduced risk for fracture compared to people with low levels of compliance (<30%) (OR, 0.70: 95% CI: 0.52, 0.93). However, in five studies that showed a decreased risk of fracture with increasing compliance, no dose-response relationship was observed between compliance and fracture risk.

The original studies included in these reviews that were also identified for the current report included several that assessed the association between compliance and fracture risk in unique populations or had particularly unique findings. For example, in the study by Blouin et al.,277 of community-dwelling elderly (over 68) women, the association increased when the analyses were limited to women over 80 years of age (RR 1.48; 95% CI: 1.19, 1.85), and the effect of lower compliance increased with increasing duration of followup. A US study by Curtis et al282 that was also included in the Siris review utilizing administrative claims data from a U.S. health care organization for approximately 17 million adults also found an increased risk for fracture with increasing age at the same level of adherence. The study by Gallagher,300 which included a wider age range (adults 18 years of age and older), also found an inverse linear relationship between compliance with bisphosphonate therapy and risk for fracture (p <0.05).

A retrospective cohort study by Penning-van Beest,279 included in both reviews stratified over 8,000 new bisphosphonate users in the PHARMO Record Linkage System into quintiles of compliance (MPR), finding that the least compliant (<20 percent) were 80 percent more likely to be hospitalized for a fracture than the most compliant (≥90%). Using the same database, Van den Boogaard311 (included in the Siris review) conducted a case control study of 541 women hospitalized for an osteoporotic fracture (compared to 5,283 matched controls, all new users of bisphosphonates) and found that persistence with treatment for at least one year reduced the fracture rate at one year (OR 0.74; 95% CI: 0.57, 0.95) and two years (OR 0.68; 95% CI: 0.47, 0.96).

Using a Cox proportional hazards model, a study by Gold292 (included in the Siris review) that assessed the effect of persistence with alendronate among 4,769 women, 45 years of age and older, with commercial insurance coverage, found a 26 percent decrease in the risk for fracture among those who were persistent. Similarly, in a study by Rabenda313 of 99,924 postmenopausal women, aged 45 years or older, identified from a national social security database, the risk of hip fracture increased 0.4 percent (OR 0.996; 95% CI: 0.994, 0.998; p <.001) for each decrease in MPR and hip fracture risk differed significantly between persistent and nonpersistent women (HR: 0.404; 95% CI: 0.357, 0.457).

##### Original RCTs and Observational Studies not Included in Prior Reviews

Ensrud conducted an analysis of the effect of compliance using the global, multicenter, randomized, double-blind, placebo-controlled trial of raloxifene, RUTH (n = 10,101).120 Women 55 years of age or older, who were one or more years postmenopausal and had established coronary heart disease (CHD) or were at high risk for CHD were included. Fractures (vertebral or nonvertebral), which were a secondary endpoint of the trial, were reported by participants and confirmed by x-ray or medical records. In these analyses, the authors assessed the effect of raloxifene on vertebral and nonvertebral fractures across fracture risk. When the analyses were limited to the women who were at least 70 percent adherent to treatment on the basis of pill count, fracture risk did not change.

The second randomized trial actually examined the relationship between placebo adherence and fracture using data from the Fracture Intervention Trial, a randomized trial of over 6,000 women testing the efficacy of alendronate. 345. The analysis was performed because of concern about the “healthy adherer” effect, in which the relationship between adherence and fracture outcomes is confounded by other factors/behaviors that may lower the risk of fractures in adherent patients not related to medication use. Here, the authors find that women with high compliance with placebo had fewer hip fractures compared to those with lower compliance with placebo (rate of 3.6 per 1,000 person years vs. 5.0 per 1,000 person years), although the results were not statistically significant. There was no relationship between adherence to placebo and any other fractures.

Cadarette et al. also examine the possibility of a healthy adherer effect using an observational cohort of older women in Pennsylvania who were new users of bisphosphonates, calcitonin, and raloxifene. 322 In cox proportional hazards model, the authors found no difference in nonvertebral fracture risk between different levels of adherence to calcitonin, bisphosphonates for primary prevention, or raloxifene for secondary prevention; they do however find that patients with high adherence to bisphosphonates for secondary prevention had lower fracture rates (HR 0.53, 95% CI: 0.38, 0.74). The authors had hypothesized that, since only the bisphosphonates have good evidence to support their role in reducing nonvertebral fracture risk, if adherence to calcitonin and raloxifene had been associated with fracture prevention, that would have been evidence of a healthy adhere effect. Both this study and the RCT discussed above thus find no strong evidence for a healthy adherer effect in osteoporosis and fracture prevention.

Four additional observational studies using data from the US found an association between adherence to bisphosphonates and lower fracture risk. Abrahamsen conducted a matched cohort study with data from a national registry.302 Individuals with a baseline fracture (except hip) (160,565) were included, and the study analyzed the association between first hip/femoral fractures and bisphosphonate compliance (MPR). A higher MPR was associated with a lower risk of fracture at both the hip (HR = 0.47; 95% CI: 0.34, 0.65; p<0.001) and atypical sites (HR 0.28; 95% CI: 0.12, 0.63; p < 0.01) Siris et al examine over 460,000 women from two large medical claims databases from 2001-2008 and find that women with the highest adherence (MPR>80%) had significantly lower hazard ratios for both vertebral (HR 0.78, 95% CI: 0.70, 0.87) and nonvertebral (HR 0.91, 95% CI: 0.87, 0.96) fractures. In another study from US claims data, 16,295 commercially insured women and 5,360 Medicare Advantage women were studied to determine the association between low adherence (MPR <50%) and risk of any fracture. 333. The analysis, which controlled for baseline fracture risk, did find that, compared to those with high adherence (MPR >80%), low adherence among commercial patients was associated with higher fracture risk (HR=1.37, 95% CI: 1.12, 1.68), but there was no relationship among Medicare Advantage patients (HR 1.07, 95% CI: 0.83, 1.38). Finally, a large study using both the Ingenix and MarketScan databases, examined new users of risedronate and raloxifene and compared risk of hip fracture among those with high adherence (MPR>80%) and low adherence.334 Among those on risedronate therapy, the incidence of hip fracture decreased from baseline to 12 month follow up among those adherent (RR 0.70, 95% CI: 0.59, 0.84) while hip fracture incidence did not change among those not adherent to therapy. There was no effect for raloxifene on hip fracture in either the adherent or nonadherent population.

A German study assessed the effects of both persistence and adherence on fracture risk. Hoer312conducted a retrospective cohort study using claims data covering approximately 1.4 million lives through the German statutory sickness fund. Individuals were identified who were at least 45 years old with at least one prescription for an oral bisphosphonate for treatment of osteoporosis (3,289/4,451 were women). The main outcomes were incident fractures of the femur, hip, wrist and hand, lumbar vertebrae, forearm and shoulder/upper arm within 180, 360, and 720 days after initiation of treatment. Among individuals with a prior fracture, persistence was associated with a 29 percent reduction in fracture risk at 180 days and a 45 percent reduction at 360 days; however, at 720 days, decrease in fracture risk was nonsignificant (9 percent). For people with no prior fracture, fracture risk was not significantly affected by treatment persistence, possibly due to the low incident fracture rate. When the effect of adherence was assessed, it was associated with a significantly reduced fracture risk (HR 0.61; 95% CI: 0.47, 0.78) in the whole group, in those with a prior fracture (HR 10.32; 95% CI: 8.09, 13.16) and in those older than 65 years (HR 1.61; 95% CI: 1.24, 2.07). An additional German study of 4,000 women from the IMS database who were newly prescribed a bisphosphonate found that women with an MPR greater than 80 percent had fewer fractures (defined using ICD-10 codes) than did nonadherent women (88.1 percent vs. 85 percent fracture free, p=0.01);346 in multivariate cox regression analysis, treatment compliance remained associated with risk of fracture, although many important confounders were not present in the model.

Two of the observational studies found no relationship between adherence and risk of fracture (in addition to the subpopulation of Medicare Advantage patients in the above study333). Feldstein286 conducted a retrospective cohort study in a not-for-profit group-model HMO. The authors identified women 55 years of age and older eligible for treatment (1,829) and matched them with similar controls (1,829) for a total cohort of 3,658. Among treated women, fracture risk was not significantly different for MPR less than 80 percent or greater than 80 percent. A separate study of 56,586 Swedish users of alendronate, risedronate, strontium, and raloxifene found no significant relationship between adherence as measured by MPR and risk of fracture;341 the study measured adherence only during the time the patient was persistent with therapy and measured hospitalized fractures. The study did find a relationship between treatment persistence and lower risk of fracture; compared to less than one month on treatment, those on treatment for one month to one year had a lower rate of fracture (HR 0.86, 95% CI: 0.72, 1.02), as did those on therapy one to two years (HR 0.67, 95% CI: 0.56, 0.82) and two to three years (HR 0.59, 95% CI: 0.48, 0.72). However, the study may not have adjusted for all relevant confounders (such as BMD) and may have overestimated risk of fractures, since all fractures were included in the analysis regardless of cause

In summary, most of the studies analyzed, with the notable exception of a large placebo-controlled trial of raloxifene, found an association between adherence or persistence and fracture risk. No strong evidence of a “healthy adherer” effect was observed, although subsequent observational studies should account for the possibility of this effect when studying the relationship between hip fractures and bisphosphonate adherence.

## Key Question 4 What are the Short- and Long-term Harms (Adverse Effects) of the Above Therapies (When Used Specifically To Treat or Prevent low Bone Density/Osteoporotic Fracture), and do These Vary by any Specific Subpopulations (e.g., the Subpopulations Identified in Key Question 2)?

For this question, we included 11 systematic reviews, 67 RCTs, 12 large observational studies, and six post-hoc analyses.

### Key Findings for Key Question 4

- Acute Coronary Syndrome, Including Myocardial Infarction (MI). Evidence is low (a new meta-analysis of 15 placebo-controlled trials of calcium (administered for bone health in all cases but one) for a small but significant increase in the risk for myocardial infarction in pooled results of five trials that contributed patient-level data; however serious concerns have been raised about methodological issues that may have led to bias.
- Atrial Fibrillation. Evidence is insufficient regarding the risk for this event. The original report identified one study that showed a significant increase in the risk of atrial fibrillation for zoledronic acid relative to placebo but another that did not; the current report identified one additional trial that when pooled with the two earlier trials of zoledronic acid, showed a significant increase in the risk for atrial fibrillation. A large Bayesian meta-analysis among users of bisphosphonates that did not reach statistical significance and several additional meta-analyses showed mixed results. In March 2010, the FDA issued a followup to its 2007 safety review, noting the inconsistency in the data and requesting that providers and patients report such side effects. Thus, a relationship between zoledronic acid and atrial fibrillation is unproven but still an area of active surveillance.
- Pulmonary Embolism (PE). The original report identified two large studies that showed higher odds for PE among raloxifene participants than among placebo participants. The current report identified two additional studies that when pooled with the original two, showed even higher risk for PE. Evidence is high for an increased risk for this event.
- Venous Thromboembolic Events. The original report identified four studies that showed higher risk of thromboembolic events for raloxifene-treated participants than for placebo participants. For the current report, four additional studies were identified that narrowed the confidence interval. Evidence is high for an increased risk for this event.
- Vasomotor Flushing (hot Flashes). A pooled analysis of eight studies, three from the original report and five identified for the current report that compared raloxifene and placebo found a significant increase in vasomotor flushing among raloxifene users. Evidence is high for an increased risk for this event.
- Esophageal Cancer. Four large observational studies identified for this report examined the risk of esophageal cancer among users of bisphosphonates. A prospective cohort study using a UK database found no increase in the risk for esophageal cancer but two nested case control studies on the same dataset did identify an increased risk. A nested case control study of patients with Barrett's Esophagus who developed esophageal cancer also found no association with use of bisphosphonates. Evidence is insufficient regarding the risk for this event.
- Mild Upper Gastrointestinal (GI) Events. We categorized conditions such as acid reflux, esophageal irritation, nausea, vomiting, and heartburn as “mild upper GI events.” Pooled analysis of 50 studies of alendronate showed greater odds of all mild upper gastrointestinal (GI) events for alendronate than for placebo. In a head-to-head comparison of alendronate with denosumab, alendronate was also more strongly associated with mild upper GI events than was denosumab. Evidence is high regarding the risk for alendronate and mild upper GI events.
- Osteonecrosis of the Jaw. The original report identified case series and case reports describing 41 cases of osteonecrosis of the jaw in cancer patients taking intravenous bisphosphonates. One trial, two large observational studies, a post hoc analysis, and a systematic review that reported on the incidence of osteonecrosis of the jaw among individuals taking bisphosphonates to prevent or treat osteoporosis were identified for the current report. Cohort and case control studies range in their estimates of the incidence of osteonecrosis of the jaw associated with the use of bisphosphonates to prevent or treat osteoporosis from fewer than one case to 28 cases per 100,000 person-years of treatment. Thus evidence is high that the prevention and treatment of osteoporosis remains a relatively minor contributor to the development of osteonecrosis of the jaw.
- Atypical Fractures of the Femur. Seven observational studies, a pooled analysis of three trials, and a comprehensive review identified a small increase in the risk for atypical, low-trauma subtrochanteric fragility fractures of the femur with long-term use of bisphosphonates for prevention or treatment of osteoporosis. Based on this American Society of Bone and Mineral Research review, on 13 October 2010, the Food and Drug Administration, which has been conducting its own ongoing review of atypical subtrochanteric femur fracture, updated the risk of atypical fractures to the Warnings and Precautions level, acknowledging that the risk remains low compared with the numbers of osteoporotic fractures prevented by the drugs. Evidence is low for this conclusion.
- Rashes, Injection Site Reactions, and Infection. Pooled analysis of four trials of denosumab found an increased rate of rash but no increase in the rate of injection site reactions for the biological agent denosumab, compared with placebo. Based on evidence for an increased risk of infection, the FDA has issued a Risk Evaluation and Mitigation Strategy for the drug. A systematic review of four trials confirms the increased risk for infection. Evidence is high for these conclusions.

For these analyses, we pooled the results of the controlled trials found through our primary electronic searches for the present report with the results of the trials identified for the original report. We focus on the adverse events that were identified as most important by our Technical Expert Panel (TEP) and other subject matter experts: cardiovascular, malignancy, upper gastrointestinal, osteonecrosis, and low-stress subtrochanteric/femur fractures. To evaluate the prevalence of adverse events selected for special attention, we also performed broader literature searches focused on those adverse events. For particularly rare adverse events, where aggregated data from large clinical trials might not provide a sufficient sample size to observe any cases, we searched for relevant reports with other study designs, including cohorts, case control studies, and even case series and case reports.

Below, we present the results by drug class and category of events. For each category, we also provide a summary of the findings of the original report. All results are expressed as odds ratios. Because many adverse events are quite rare, we also calculated the risk differences (the percentages that reported the adverse event) for each type of event; the text and tables report only the significant risk differences (RDs). Table C-5 (Appendix C) displays all the adverse events identified for the present report. This table includes information on cancer, cardiac, dermatologic, ear/nose/throat, gastrointestinal (serious, mild), genitourinary, gynecologic, hematologic, hypertension, immunologic, metabolic, musculoskeletal, neurologic, peripheral vascular disease, psychiatric, pulmonary, renal, special senses, sweats/fever/hot flashes, and death not otherwise specified.

#### Bisphosphonates

Table 52 shows the risks of adverse events for bisphosphonates compared with placebo. Forest plots were constructed for comparisons comprising ten or more studies.

Table 52 Risks of Adverse Events for bisphosphonates versus placebo

Event Group | Alendronate | | Ibandronate | | Risedronate | | Zoledronic acid
Event Group | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI) | # of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 3 | 3.59 (0.35, 180) | 2 | 1.06 (0.41, 2.96) | 3 | 0.4 (0.06, 2.39) | 2 | 0.82 (0.55, 1.21)
Cerebrovascular Death | 2 | Inf+(0.13, Inf+)^*^ | 2 | 1.06 (0.41, 2.96) | 2 | Inf+ (0.13, Inf+)^*^ | 2 | 0.61 (0.26, 1.37)
Atrial Fibrillation | 1 | 1.26 (0.96, 1.66) | 0 | NR | 1 | Inf+ (0.02, Inf+)^*^ | 2 | 1.45 (1.14, 1.86)
Cerebrovascular Accidents (serious) | 0 | NR | 2 | 0.32 (0, 27.3) | 0 | NR | 2 | 1.13 (0.9, 1.42)
Pulmonary Embolism | 0 | NR | 0 | NR | 2 | 0.74, (0.08, 8.89) | 0 | NR
Thromboembolic Events | 1 | Inf+ (0.03, Inf+)^*^ | 0 | NR | 0 | NR | 0 | NR
Cancer
Breast Cancer | 1 | Inf+ (0.09, Inf+)^*^ | 1 | Inf+ (0.01, Inf+)^*^ | 0 | NR | 0 | NR
Colon Cancer | 0 | NR | 0 | NR | 0 | NR | 0 | NR
Esophageal Cancer | No trials examined individual bisphosphonates. Pooled results for two observational studies: OR 1.23 (1.01, 1.49); see text for descriptions of findings of additional observational studies.
Lung Cancer | 0 | NR | 0 | NR | 1 | 0.49 (0.01, 38.4) | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR | 0 | NR | 0 | NR
GI (mild)
GI (mild) All | 50 | 1.08 (1.01, 1.15) | 10 | 1.03 (0.92, 1.14) | 21 | 1.03 (0.95, 1.13) | 3 | 1.44 (0.84, 2.5)
GI (Serious)
Esophageal (serious) | 5 | 1.39 (0.75, 2.65) | 1 | 1.5 (0.12, 78.7) | 4 | 0.74 (0.38, 1.46) | 0 | NR
Upper GI Perforations, Ulcers, or Bleeds (not esophageal) | 10 | 0.88 (0.66, 1.18) | 2 | 0.33 (0.14, 0.74) | 7 | 0.64 (0.27, 1.53) | 0 | NR
Musculoskeletal
Arthritis and Arthralgias | 3 | 0.27 (0.09, 0.70) | 1 | 0.53 (0.11, 2.43) | 5 | 0.77 (0.45, 1.32) | 5 | 2.31 (1.90, 2.82)
Myalgias, Cramps, Limb Pain | 4 | 1.14 (0.18, 8.18) | 2 | 2.25 (1.57, 3.29) | 0 | NR | 6 | 4.15 (3.41, 5.08)
Atypical Fractures | See text for description of comprehensive review and subsequent observational studies of all bisphosphonates.
Osteonecrosis of the Jaw | See text for description of reviews and observational studies.

INF = infinite; OR = odds ratio; NR = not reported

* For comparisons with zero events in one arm the odds ratio and the upper bound of the confidence interval is infinity.

##### Cardiovascular Events

We classified the following adverse event descriptions as serious cardiac events: acute coronary syndrome (including myocardial infarction), atrial fibrillation, cardiac death, ventricular arrhythmia, and death due to arrhythmia.

###### Acute Coronary Syndrome

Neither the original report nor the updated pooled analyses showed any differences between any of the bisphosphonates and placebo regarding the incidence of acute coronary syndrome. Pooled odds ratios (OR) were 3.59 (95% CI: 0.35, 180.00), 1.06 (95% CI: 0.41, 2.96), 0.4 (0.06, 2.39), and 0.82 (95% CI: 0.55, 1.21) for alendronate,59,347,348 ibandronate,104,349 risedronate,74,350,351 and zoledronic acid111,113 vs. placebo.

###### Atrial Fibrillation

The original report identified two large trials that showed a trend toward an increased incidence of atrial fibrillation (AF) with alendronate and a significantly increased incidence with once-yearly zoledronic acid relative to placebo, respectively.111,352 The current report identified several new original studies and systematic reviews. A meta-analysis of all RCTs of at least 3 months duration on the use of alendronate to treat or prevent osteoporosis by the Merck Corporation (32 trials, more than 17,000 participants) found no effect of alendronate on the incidence of atrial fibrillation.353 A pooled analysis of the results of the pivotal trials of ibandronate showed no effect on the incidence of AF.354 One new study of zoledronic acid was pooled with the original study to show an increase in the incidence of AF with zoledronic acid (pooled OR 1.45, 95% CI: 1.14, 1.86).113

Five systematic reviews were identified that combined studies of different bisphosphonates. Two 2009 systematic reviews that conducted meta-analyses of the same four trials and two observational studies reported a significant association between bisphosphonate exposure and the risk for serious atrial fibrillation.355,356 A 2009 Bayesian meta-analysis that included four original reports of RCTs (including the two large trials described above), two post hoc analyses of combined data from multiple RCTs, and three observational studies found a nonsignificantly increased risk of AF among bisphosphonate users (pooled OR for overall risk of AF from RCTs 1.18, 95% CI: 0.84, 1.66; pooled OR for serious AF from RCTs 1.59, 95% CI: 0.61, 3.75; pooled OR for observational studies 1.25, 95% CI: 0.98, 1.73).357 A 2010 systematic review of seven observational studies found no evidence for an association between bisphosphonate use and increased risk for atrial fibrillation; however, the I-squared statistic suggested moderate heterogeneity.358 A 2010 systematic review of 16 RCTs, observational studies, and prior systematic reviews that included some of the same studies as the systematic reviews identified for the original report found some evidence of an association of bisphosphonate use with increased risk for AF.359 Consistent with this evidence, in March 2010, the FDA issued a followup to its 2007 safety review, noting the inconsistency in the data and requesting that providers and patients report side effects.360

###### Cerebrovascular Accidents (CVA) and Death

We found no trials of alendronate that reported CVAs. In two older trials of ibandronate (OR 0.32, 95% CI: 0, 27.3),104,108 and one older trial111 and one new trial of zoledronic acid113 (OR 1.13, 95% CI: 0.9, 1.42) that reported CVE, there were no significant differences between the drugs and placebo. Two studies of zoledronic acid vs. placebo that assessed the incidence of cerebrovascular death found a nonsignificant increase in the treated group (OR 1.5, 95% CI: 0.87, 2.64).111,113

###### Pulmonary Embolism (PE)

We found no trials of alendronate, ibandronate, or zoledronic acid that reported PE. In two trials of risedronate vs. placebo, one old89 and one new,74 differences between drug and placebo were not significant (OR 0.74, 95% CI: 0.08, 8.89).

###### Thromboembolic Events

We found no trials of ibandronate, risedronate, or zoledronic acid that reported thromboembolic events. In one trial of alendronate, there was no significant difference between drug and placebo (OR Inf+, 95% CI: 0.03, Inf+, where Inf+ signifies positive infinity. An upper limit of Inf+ results when 0 events occur in the second treatment group. A true OR cannot be estimated because the denominator is 0; thus, the estimate is infinity.).59

###### Cardiovascular Death

The original report found no differences between alendronate (in two trials),347,348 ibandronate (in two trials),104,349 or risedronate (in one trial),351 and placebo in cardiac death; no studies were found for that report on zoledronic acid that reported cardiovascular deaths. For the present report, one new study on zoledronic acid,113 and one new study on risedronate74 found no differences (pooled OR for risedronate Inf+, 95% CI: 0.13, Inf+); and zoledronic acid (OR 0.61 95% CI: 0.26, 1.37).

##### Cancer

###### Breast Cancer

The original report identified one study of ibandronate that found no significant differences with placebo on the risk for breast cancer (OR Inf+, 95% CI: 0.01, Inf+);104 breast cancer was not reported in trials of the other bisphosphonates. The current report identified one study on alendronate that found no significant differences (OR Inf+, 95% CI: 0.09, Inf+).361

###### Colon Cancer

No trials of the bisphosphonates reported on colon cancer in either report. A large case control study of bisphosphonate use and gastrointestinal cancers in the UK found no differences in the risk for colorectal cancer between users of bisphosphonates and matched controls (RR 0.87, (95% CI: 0.77, 1.00).362

###### Esophageal Cancer

No trials examined the incidence of esophageal cancer in the original report. Four large observational studies examined the incidence of esophageal cancer among bisphosphonate users. A cohort study (Newcastle-Ottawa [N-O] 8/9) that extracted data from the UK General Practice Research Database on 41,826 users and a matched set of controls (81 percent women, mean age 70, mean followup time 4.5 years) found no difference in the risk for esophageal cancer between cohorts (adjusted HR 1.07, 95% CI: 0.77, 1.49).363 A case-control study (N-O 9/9) that used the same database and matched 2,954 cases with 14,721 controls (36 percent women, mean followup time 7.7 years) found that individuals with at least one prescription for oral bisphosphonates had a significantly increased risk for esophageal cancer (adjusted RR 1.30, 95% CI: 1.02, 1.66, p=0.02).362 Pooling two additional large observational studies found a significantly increased risk for esophageal cancer in the bisphosphonate-treated group (pooled OR 1.23, 95% CI: 1.01, 1.49).362,363 A third (case-control) study (N-O 5/9: reported in a letter) that used the same database to conduct a case-control analysis on individuals diagnosed with esophageal cancer found an increased likelihood of bisphosphonate use among cases (OR 1.24, 95% CI: 1.08, 1.44 for men and women together; OR 1.40, 95% CI: 1.18, 1.67 for women alone).364 A fourth (case-control) study (N-O 9/9) examined the association between bisphosphonate use and development of esophageal cancer in a nested case control study of patients with Barrett's Esophagus. Among 116 cases (out of a cohort of over 11,000 patients) and 696 matched controls, no increased risk for esophageal cancer was observed among those who used bisphosphonates.365

###### Gastrointestinal Cancer

The original report identified one study each on ibandronate366 and risedronate367 that found no significant differences in the risk for [in the risk for gastrointestinal cancers (not otherwise specified).

###### Lung Cancer

No trials of the bisphosphonates reported on lung cancer in the original report. The current report identified one trial on risedronate that found no differences (OR 0.49, 95% CI: 0.01, 38.4).74

##### Gastrointestinal (Serious)

We classified the following adverse events as serious gastrointestinal adverse events: upper gastrointestinal perforations, ulcerations and bleeds (PUBs); deaths due to PUBs; upper gastrointestinal (other); esophageal (serious); and hepatobiliary (serious). No differences were seen for total serious GI adverse events among any of the bisphosphonates (Figures 3 and 4). Perforations, ulcerations, and bleeds (PUB) were reported (for both active treatment and placebo groups) in trials of all the bisphosphonates except zoledronic acid. The only significant difference was seen in two pooled trials of oral daily ibandronate in the original report, in which participants in the treatment group had lower odds of esophageal ulcerations than did placebo participants (OR 0.33, 95% CI: 0.14, 0.74); 107,366 10 trials of alendronate 368,369,361,370-376 (Figure 5) and seven trials of risedronate showed similar trends.60,90-92,97,377,378 One head-to-head comparison of alendronate with risedronate reported one death due to PUB in the alendronate group (compared with none in the risedronate group (OR 0, 95% CI: 0, 40).60

Figure 3 Total serious gastrointestinal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 16 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.06 to 7.84 (pooled OR 1.09, [95% CI 0.89, 1.33]), slightly but not significantly favoring placebo; however, the studies were not statistically heterogeneous (I-squared 26.7%, p=0.155).

Figure 4 Total serious gastrointestinal adverse events in trials of risedronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 12 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.46 to 7.64 (pooled OR 0.94, [95% CI 0.75, 1.19]), slightly but not significantly favoring risedronate; the studies were not statistically heterogeneous (I-squared 0.0%, p=0.875).

Figure 5 Upper gastrointestinal perforations, ulcers, or bleeds in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 10 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.14 to 7.84 (pooled OR 0.89 [95% CI 0.63, 1.25]), slightly but not significantly favoring alendronate; the studies were not statistically heterogeneous (I-squared 6.5%, p=0.382).

No significant differences were seen among any of the comparisons of other serious upper gastrointestinal events (alendronate vs. placebo OR 1.06, 95% CI: 0.74, 1.51;^375,376,379-381^ risedronate vs. placebo OR 1.03, 95% CI: 0.78, 1.36).88,89,91,351

Nonsignificant increases in the risk for serious esophageal adverse events were seen in five studies comparing alendronate with placebo (OR 1.39, 0.75, 2.65)44,371,375,382,383 and one study comparing ibandronate with placebo (OR1.5, 95% CI: 0.12, 78.7),107 but not in four studies of risedronate vs. placebo (OR 0.74, 95% CI: 0.38, 1.46).90,92,94,97

No hepatobiliary adverse events were reported for bisphosphonates.

To estimate the possible role of dosing frequency and route of administration in the development of serious GI events among bisphosphonate users, we conducted further pooled analyses. Because few such comparisons were conducted within studies, we compared the pooled OR for studies with daily oral administration to those with weekly oral administration; injections or infusions every three, six, or 12 months; and cyclic dosing schedules. Too few studies reported serious GI side effects to see any differences according to dosing schedule (Table 51).

Table 51 Gastrointestinal adverse events by dosing schedule and route of administration

Drug and Dosing Comparison | Number of Included Studies | Drug 1 Number of events | Drug 1 Sample Size | Drug 2 Number of Events | Drug 2 Sample Size | Odds Ratio (95% Confidence Interval)^a^
Mild Adverse Events
Alendronate daily oral vs. placebo | 42 | 3,799 | 10,062 | 3,249 | 8,323 | 1.03 (0.96, 1.1)
Alendronate weekly oral vs. placebo | 7 | 225 | 1,179 | 159 | 1,077 | 1.56 (1.24, 1.98)^*^
Alendronate weekly oral vs. denosumab every 3 or 6 months injection | 1 | 26 | 46 | 97 | 314 | 2.9 (1.48, 5.77)^*^
Alendronate weekly oral vs. denosumab every 6 months injection | 1 | 168 | 586 | 164 | 593 | 1.05 (0.81, 1.37)
Alendronate daily oral vs. raloxifene daily oral | 3 | 77 | 832 | 40 | 822 | 1.99 (1.32, 3.04)^*^
Alendronate weekly oral vs. raloxifene daily oral | 3 | 79 | 513 | 83 | 520 | 0.95 (0.67, 1.35)
Alendronate daily oral vs. estrogen | 4 | 78 | 255 | 68 | 306 | 1.57 (1, 2.46)
Alendronate weekly oral vs. risedronate daily oral | 1 | 5 | 219 | 4 | 222 | 1.27 (0.27, 6.5)
Alendronate weekly oral vs. risedronate weekly oral | 2 | 159 | 1,040 | 154 | 1,066 | 1.07 (0.83, 1.37)
Alendronate weekly oral vs. zoledronic acid 1, 5mg injection | 1 | 2 | 112 | 6 | 113 | 0.33 (0.03, 1.87)
Alendronate weekly oral vs. zoledronic acid, 1 dose injection | 1 | 24 | 59 | 29 | 69 | 0.95 (0.44, 2.03)
Alendronate daily oral vs. calcium | 1 | 157 | 281 | 82 | 138 | 0.86 (0.56, 1.33)
Alendronate daily oral vs. vitamin D | 8 | 143 | 612 | 120 | 557 | 1.2 (0.88, 1.62)
Risedronate weekly vs. teriparatide 25 microgram daily injection | 1 | 2 | 22 | 2 | 22 | 1 (0.07, 15.1)
Risedronate daily oral vs. placebo | 16 | 2001 | 9,239 | 1231 | 5,349 | 1.04 (0.95, 1.13)
Risedronate daily or weekly oral vs. placebo | 1 | 22 | 82 | 9 | 41 | 1.3 (0.5, 3.6)
Risedronate weekly oral vs. placebo | 2 | 25 | 76 | 21 | 74 | 1.44 (0.44, 4.89)
Risedronate 35mg weekly oral vs. placebo | 1 | 22 | 191 | 9 | 93 | 1.21 (0.51, 3.13)
Raloxifene daily oral vs. placebo | 7 | 279 | 7,097 | 126 | 3,714 | 1.01 (0.81, 1.27)
Raloxifene 1 dose oral vs. placebo | 1 | 1 | 102 | 6 | 102 | 0.16 (0, 1.35)
Raloxifene daily oral vs. estrogen | 2 | 16 | 671 | 16 | 804 | 1.13 (0.52, 2.45)
Raloxifene daily oral vs. vitamin D | 1 | 1 | 45 | 0 | 44 | Inf+(0.03, Inf+)
Ibandronate daily oral vs. placebo | 2 | 247 | 641 | 68 | 192 | 1.07 (0.75, 1.53)
Ibandronate daily or every two days oral vs. placebo | 2 | 637 | 2,113 | 307 | 1,056 | 1.05 (0.89, 1.24)
Ibandronate weekly oral vs. placebo | 1 | 23 | 472 | 5 | 158 | 1.57 (0.57, 5.37)
Ibandronate monthly oral vs. placebo | 1 | 44 | 108 | 12 | 36 | 1.37 (0.59, 3.35)
Ibandronate every 3 months injection vs. placebo | 3 | 844 | 2,404 | 412 | 1,104 | 0.96 (0.83, 1.12)
Ibandronate once-a-month 150 mg oral vs. placebo | 1 | 9 | 87 | 2 | 48 | 2.64 (0.51, 26.1)
Ibandronate every 3 months injection vs. | 2 | 31 | 110 | 35 | 109 | 0.83 (0.44, 1.54)
Zoledronic acid every 3 or 6 months injection vs. placebo | 1 | 26 | 292 | 3 | 59 | 1.82 (0.53, 9.73)
Zoledronic acid every 3 months injection vs. placebo | 1 | 9 | 55 | 8 | 51 | 1.05 (0.33, 3.44)
Zoledronic acid 1 dose or every 12 months injection vs. placebo | 1 | 21 | 181 | 16 | 202 | 1.52 (0.73, 3.24)
Denosumab every 3 or 6 months injection vs. placebo | 1 | 97 | 314 | 9 | 46 | 1.83 (0.83, 4.5)
Denosumab every 6 months injection vs. placebo | 2 | 104 | 4,052 | 61 | 4,042 | 1.73 (1.24, 2.42)^*^
Teriparatide daily 20 or 40 microgram injection vs. placebo | 1 | 99 | 1,093 | 44 | 544 | 1.13 (0.77, 1.68)
Teriparatide daily injection vs. placebo | 1 | 34 | 290 | 5 | 147 | 3.76 (1.42, 12.6)^*^
Serious Adverse Events
Alendronate daily vs. placebo | 15 | 229 | 7,217 | 177 | 6,803 | 1.13 (0.92, 1.4)
Alendronate daily vs. weekly | 0
Alendronate weekly vs. placebo | 4 | 2 | 892 | 4 | 788 | 0.5 (0.05, 3.52)
Alendronate weekly vs. cyclic daily (1 month on, 2 months off) vs. placebo | 1 | 3 | 42 | 0 | 41 | Inf+ (0.42, Inf+)^†^
Alendronate weekly vs. cyclic daily (1 month on, 2 months off) vs. vitamin D | 1 | 1 | 35 | 0 | 34 | Inf+ (0.02, Inf+)^†^
Risedronate daily vs. placebo | 9 | 152 | 4,880 | 133 | 4,575 | 1.13 (0.87, 1.45)
Risedronate daily vs. weekly vs. placebo | 1 | 1 | 41 | 0 | 41 | Inf+ (0.03, Inf+)^†^
Risedronate weekly vs. placebo | 1 | 16 | 31 | 17 | 29 | 0.76 (0.24, 2.35)
Risedronate daily vs. cyclic (2 weeks on, 10 weeks off) vs. placebo | 2 | 9 | 128 | 6 | 84 | 1 (0.3, 3.61)
Ibandronate daily vs. placebo | 2 | 15 | 1,141 | 18 | 1,137 | 0.83 (0.39, 1.75)
Ibandronate every 3 months injected vs. placebo | 1 | 79 | 956 | 42 | 950 | 1.95 (1.31, 2.94)^*^
Alendronate weekly vs. risedronate daily | 1 | 0 | 219 | 2 | 222 | 0 (0, 5.39)
Alendronate weekly vs. risedronate weekly | 1 | 1 | 520 | 1 | 533 | 1.03 (0.01, 80.6)
Alendronate daily vs. raloxifene | 1 | 104 | 716 | 77 | 707 | 1.39 (1, 1.93)
Alendronate weekly vs. denosumab every 6 months | 1 | 0 | 586 | 4 | 593 | 0 (0, 1.53)

* Significant difference.

† Inf+ signifies positive infinity. An upper limit of Inf+ results when 0 events occur in the second treatment group. A true OR cannot be estimated because the denominator is 0; thus, the estimate is infinity.

##### Gastrointestinal (Mild)

We categorized gastrointestinal conditions such as reflux and esophageal irritation, nausea, vomiting, heartburn, diarrhea, and constipation as “Mild.” Pooled analyses of 50 studies of alendronate and ten studies of ibandronate showed no differences in overall mild gastrointestinal symptoms (Figures 6 and 7, respectively); pooled analysis of 21 studies of risedronate showed an increase in mild gastrointestinal adverse events compared with placebo (Figure 8).

Figure 6 Total mild gastrointestinal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 50 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.06 to 22.09 (pooled OR 1.07 [95% CI 1.00, 1.14]), slightly but not significantly favoring placebo; however, the studies were statistically heterogeneous (I-squared 55.0%, p=0.000).

Figure 7 Total mild gastrointestinal adverse events in trials of ibandronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 10 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.71 to 2.27 (pooled OR 1.03 [95% CI 0.93, 1.14]), slightly but not significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 0.0%, p=0.577).

Figure 8 Total mild gastrointestinal adverse events in trials of risedronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 21 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.28 to 7.56 (pooled OR 1.03 [95% CI 0.95, 1.12]), significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 45.3%, p=0.013).

Pooled analysis of 49 studies of alendronate showed greater odds of all mild upper gastrointestinal (GI) events (Figure 9) than did placebo (OR 1.08, 95% CI: 1.01, 1.15).38,39,44,46,50,51,58-61,63,64,347,348,361,369-376,379,380,382,383,385-406 There were no differences between ibandronate, risedronate (Figure 10), or zoledronic acid and placebo regarding any mild upper GI events. Pooled analysis of 25 studies of alendronate showed no differences in reflux esophagitis between alendronate and placebo-treated groups (Figure 11); pooled analysis of 13 studies showed no differences in reflux esophagitis between risedronate and placebo (Figure 12). Pooled analysis of 24 studies showed a nonsignificant increase in other upper GI adverse events for alendronate over placebo (Figure 13), and pooled analysis of 13 studies showed no effect for risedronate (Figure 14).

Figure 9 Mild upper gastrointestinal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 44 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.06 to 22.09 (pooled OR 1.09 [95% CI 0.98, 1.12]), significantly favoring placebo; however, the studies were statistically heterogeneous (I-squared 51.3%, p=0.000).

Figure 10 Mild upper gastrointestinal adverse events in trials of risedronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 18 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.50 to 7.39 (pooled OR 1.06 [95% CI 0.96, 1.18]), slightly but not significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 28.0%, p=0.125).

Figure 11 Reflux and esophageal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 25 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.06 to 7.44 (pooled OR 1.11 [95% CI 0.99, 1.23]), slightly but not significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 0.00%, p=0.823).

Figure 12 Reflux and esophageal adverse events in trials of risedronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 14 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.23 to 7.44 (pooled OR 0.88 [95% CI 0.69, 1.14]), slightly but not significantly favoring active treatment; the studies were not statistically heterogeneous (I-squared 22.3%, p=0.212).

Figure 13 Mild upper gastrointestinal adverse events other than reflux and esophageal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 24 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.53 to 11.52 (pooled OR 1.01 [95% CI 0.93, 1.10]), slightly but not significantly favoring placebo; however, the studies were statistically heterogeneous (I-squared 58.2%, p=0.000).

Figure 14 Mild upper gastrointestinal adverse events other than reflux and esophageal adverse events in trials of risedronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 13 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.31 to 4.28 (pooled OR 1.06 [95% CI 0.94, 1.19]), slightly but not significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 24.0%, p=0.201).

Head-to-head comparisons of a bisphosphonate with another agent showed one significant difference in mild GI events. Pooled analysis of six studies showed an increased risk of mild GI events for alendronate compared with raloxifene (RD 0.025 95% CI: 0.002, 0.047).233,385,406-409

To estimate the possible role of dosing frequency and route of administration in the development of mild GI events among bisphosphonate users, we conducted further pooled analyses. Because few such comparisons were conducted within studies, we compared the pooled OR for studies with daily oral administration to those with weekly oral administration; and injections or infusions every three, six, or 12 months; and cyclic dosing schedules. In an indirect comparison, weekly alendronate was more strongly associated with mild GI adverse events than was daily alendronate, when compared with placebo (Table 51).

##### Musculoskeletal

This category includes arthritis and arthralgias; myalgias, cramps, and limb pain; atypical fractures; and osteonecrosis.

Pooled analysis of 17 trials showed no effect of alendronate on total musculoskeletal events (Figure 15). In three pooled trials identified for the original report,111,112,417 zoledronic acid participants had higher odds of these events than did placebo participants (OR 4.52, 95% CI: 3.78, 5.43). Three trials were identified for the current report,113,114,418 and the difference was smaller but still significant (OR3.36, 95% CI: 2.96, 3.82).

Figure 15 Musculoskeletal adverse events in trials of alendronate versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 17 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.02 to 7.39 (pooled OR 1.06 [95% CI 0.91, 1.23]), slightly but not significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 0.0%, p=0.480).

In two head-to-head trials identified for the original report,238,419 alendronate participants had greater odds of these events than did participants taking teriparatide (OR 3.84, 95% CI: 2.22, 6.80).

###### Arthritis and Arthralgias

Pooled analysis of two trials comparing alendronate with placebo showed a decreased risk for arthritis and arthralgias in the treated group (OR 0.27, 95% CI: 0.09, 0.70; RD -0.111, 95% CI: -0.223, 0.001)),61,63 but an increased risk among individuals taking zoledronic acid in four pooled trials (OR 2.67, 95% CI: 2.14, 3.35; RD 0.039, 95% CI: 0.028, 0.044).111-113,417 One trial of ibandronate vs. placebo411 and five trials of risedronate vs. placebo74,82,95,97,384 found no significant differences.

In two head-to-head trials, alendronate was significantly less likely to be associated with arthritis and arthralgias than denosumab (OR 0.65, 95% CI: 0.46, 0.92).61,275

###### Myalgias, Cramps, and Limb Pain

Studies were identified that compared alendronate, ibandronate, and zoledronic acid with placebo. Pooled analysis of two trials of ibandronate108,420 and six trials of zoledronic acid111-114,417,421 showed increased risk for this category of events for the active treatments over placebo (OR 2.25, 95% CI: 1.57, 3.29 and OR 4.15, 95% CI: 3.41, 5.08; RD 0.071, 95% CI: 0.063, 0.080, respectively)

###### Atypical Fractures

This category of adverse events was not included in the original report.

A post hoc (secondary) analysis was conducted with the combined results of three large RCTs of bisphosphonates (FIT, FLEX, and HORIZON/PFT) that included review of fracture records for all reported hip and femur fractures to identify fractures “below the lesser trochanter and above the distal metaphyseal flare,” and to assess whether these fractures represented atypical fractures. This review of 284 records (among 14,195 women) identified 12 such fractures (relative HR 1.03, 95% CI: 0.06, 16.46 for alendronate in the FIT trial; 1.50, 95% CI: 0.25, 9.00 for zoledronic acid use in the HORIZON/PFT; 1.33, 95% CI: 0.12, 14.67 for longer-term alendronate use in the FLEX trial).422 The authors concluded that although no significant increase in the atypical fractures was seen, the analysis was underpowered to draw definitive conclusions.

A case series that reviewed 152 femoral fractures among 152 elderly patients (mean age 78±5, 87 percent women) admitted to an Australian tertiary care center from 2003 through 2008 found that of 20 fractures classified (blind to treatment) as atypical, 17 of the patients were on oral bisphosphonate therapy at the time of the fracture. Fifteen were taking alendronate (mean duration 5.1 years) and two were taking risedronate (mean duration 3 years). Of those 132 whose fractures did not fulfill the criteria for being atypical, two patients were taking alendronate (mean duration 3.5 years), and one was taking risedronate (one year). Other factors associated with fracture risk were history of low-energy fracture, prolonged glucocorticoid use, active rheumatoid arthritis, and low serum vitamin D levels.423

On 14 September, 2010, a task force of the American Society of Bone and Mineral Research (ASBMR) on atypical subtrochanteric fracture published a comprehensive review of the published and unpublished literature on the association between atypical femur fractures and the use of bisphosphonates that included the two studies just described and that concluded that although the risk for this type of fracture is low, it appears to increase with increasing duration of use of bisphosphonates for the treatment of osteoporosis.424 The task force determined that “Based on published and unpublished data and the widespread use of bisphosphonates the incidence of atypical femoral fractures associated with bisphosphonate therapy for osteoporosis appears to be very low, particularly compared to the number of vertebral, hip and other fractures that are prevented by bisphosphonates. Moreover, a causal association between bisphosphonates and atypical fractures has not been established.” Based on this review, on 13 October 2010, the Food and Drug Administration, which has been conducting its own ongoing review of atypical subtrochanteric femur fracture, updated the risk of atypical fractures to the Warnings and Precautions level, stating “…Although it is not clear if bisphosphonates are the cause, these unusual femur fractures have been predominantly reported in patients taking bisphosphonates.”425 This warning pertains to alendronate, risedronate, ibandronate, and zoledronic acid used in the prevention and treatment of osteoporosis.

A nested case control study that was not included in the ASBMR review assessed the possible association between use of bisphosphonates and other osteoporosis medications and a different type of atypical fracture, nonunion fractures of the humerus, among a large cohort of older adults (cases of nonunion were identified as those with an orthopedic procedure associated with nonunion 91 to 365 days after an initial humerus fracture). In fully-adjusted multi-variate analysis, use of a bisphosphonate in the post-fracture period was associated with an increased risk of nonunion (OR 2.37, 95% CI: 1.13, 4.96). This increase was also seen in the small subpopulation of individuals with no prior history of osteoporosis or fractures (OR 1.91, 95% CI: 0.75, 4.83).426

A systematic review of cases and case series that described atypical femoral fractures among users of bisphosphonates and appeared just prior to the ASBMR statement identified 141 women with such fractures, treated for an average of 71.5±40.0 months.427 Risk factors associated with the fractures included use of glucocorticoids and proton pump inhibitors.

One nested case control and five cohort studies appeared concurrent with or subsequent to the ASBMR report. The nested case control study ( N-O 9/9) found that use of bisphosphonates for five or more years was associated with an increased risk of subtrochanteric or femoral fracture (adjusted OR, 2.74; 95% CI: 1.25, 6.02); however, the overall incidence was low: 71 among 52,595 women over one year (0.13 percent).428 A 2011 epidemiological study that examined age-adjusted trends in the incidence of subtrochanteric fragility fractures and osteoporotic femoral fractures in the National Inpatient Sample and compared it to trends in the use of bisphosphonates for osteoporosis from 1996 to 2007 found approximately one new fragility fracture for every 100 fewer hip fractures.429 A cohort study that included more than 40,000 men and women in the Danish National Hospital Discharge Register (N-O 9/9) found an increase in the risk for atypical fractures among users of alendronate compared with nonusers (HR 2.6, 95% CI: 2.29, 2.95); however, higher cumulative doses were not associated with a greater risk than smaller cumulative doses, suggesting the possibility that osteoporosis itself could be responsible for the fractures.430 A subsequent study of subtrochanteric fractures among users of alendronate and raloxifene in the same database by another group (N-O 8/9) found an increase in the rate of such fractures among alendronate users (HR 2.41, 95% CI: 1.78, 3.27) compared with users of raloxifene but also found that the increased risk was present prior to the start of therapy.431 Finally, a large 2011 cohort study (N-O 9/9) that used propensity-score matching of individuals in health care utilization databases from two US states found no increased risk of subtrochanteric fracture among individuals with at least one prescription for a bisphosphonate for osteoporosis therapy compared with those with prescriptions for calcitonin or raloxifene (HR 1.03, 95% CI: 0.70. 1.52);432 however, the proportion of the cohort treated with bisphosphonates longer than 5 years was sufficiently small that an association of long-term use with atypical fractures could not be ruled out.

###### Osteonecrosis of the Jaw

The original report identified case series and case reports describing 41 cases of osteonecrosis of the jaw in cancer patients taking intravenous bisphosphonates. Cases involved pamidronate, zoledronic acid, and alendronate. One trial, two large observational studies, a post hoc analysis, and a systematic review that reported on the incidence of osteonecrosis of the jaw among individuals taking bisphosphonates to prevent or treat osteoporosis were identified for the current report. A RCT that assessed the effect of one intravenous dose of zoledronic acid for the prevention of osteoporosis reported no cases of osteonecrosis of the jaw over the following three years.418 A large recent case series reviewed 2,408 cases of osteonecrosis of the jaw to assess the possible association between use of bisphosphonates and osteonecrosis.433 Of these cases, 88 percent were associated with intravenous therapy, primarily with zoledronic acid. Whereas 89 percent of the total cases were associated with the treatment of a malignant condition, ten percent were associated with the prevention or treatment of osteoporosis (treatment of Paget's disease and other benign conditions accounted for the remaining one percent). A survey of more than 8,000 members of a northern California integrated health care system who had received chronic oral bisphosphonates identified 9 cases of osteonecrosis of the jaw, for an estimated frequency of 28 cases per 100,000 person-years of treatment and a prevalence of 0.10 percent (95% CI: 0.05, 0.20).434 After the identification of one case of osteonecrosis of the jaw in the HORIZON PFT trial of once yearly zoledronic acid for the treatment of osteoporosis,435 the incidence was assessed in the remaining four HORIZON trials: No further cases of osteonecrosis of the jaw were identified, among more than 5,900 patients, resulting in an incidence of less than 1 in 14,200 patient-treatment years.436 One systematic review identified five reports that attempted to estimate the frequency of osteonecrosis of the jaw among individuals treated for osteoporosis: the composite estimate was less than one case per 100,000 person-years of exposure.437Thus the prevention and treatment of osteoporosis remains a relatively minor contributor to the development of osteonecrosis of the jaw.

##### Fracture Healing

The association between bisphosphonate use and subsequent fracture healing has been examined in one post hoc analysis and one nested case-control study. A post hoc analysis of patients in the HORIZON PFT trial assessed the relationship between timing of administration of zoledronic acid and fracture healing among patients who experienced a new hip fracture; the study found no association between the timing of infusion of zoledronic acid and delayed fracture healing.438 A nested case control study that assessed bisphosphonate use among individuals with nonunion of humeral fractures (81 cases in more than 19,000 with humeral fractures) found increased odds of nonunion fractures among patients who took bisphosphonates in the post-fracture period (OR 2.37, 95% CI: 1.13, 4.96) regardless of prior history of osteoporosis or fracture.426

##### Metabolic Adverse Events

This category includes hyper- and hypocalcemia, and hypercalciuria. No studies compared the effects of bisphosphonates with placebo with respect to hypercalcemia or hypercalciuria. In two trials included in the original report, alendronate patients had increased odds of hypocalcemia relative to placebo patients.379,402 Two trials of zoledronic acid, one included in the original report439 and one identified for the present report,113 found an increased risk for hypocalcemia with zoledronic acid compared with placebo (OR 7.22, 95% CI: 1.81, 42.70).

##### Adverse Events in Subpopulations

A post hoc analysis of the Fracture Intervention Trial, which assessed the effect of alendronate on fracture prevention in postmenopausal women, assessed whether adverse events differed between women of normal and impaired renal function.254No differences were seen in adverse events.

A 24-month multicenter randomized double-dummy comparative effectiveness trial compared the incidence of adverse events between a once-yearly intravenous infusion of zoledronic acid (5 mg) and weekly oral alendronate (70-mg capsule) in 261 men with primary or hypogonadism-induced osteoporosis.274 The overall incidence of adverse events and serious adverse events was similar in both groups (93.5 percent vs. 93.2 percent and 17.6 percent vs. 20.9 percent, respectively). Within 3 days after administration, the incidence of many adverse events (e.g., arthralgia, myalgias, chills, fatigue, headache, and pyrexia was higher in the group receiving zoledronic acid, but the differences disappeared after 3 days.

The safety of once yearly infusions of zoledronic acid was also assessed in a post-hoc analysis of the 3-year HORIZON-PFT randomized placebo-controlled trial, which enrolled 323 women with osteoporosis in Taiwan and Hong Kong.251 The overall incidence of adverse events was lower in the treatment group than in the placebo group (20 percent vs. 33 percent, p=0.012). As with the previous study, the most frequently occurring symptoms in the first three days after infusion were pyrexia, arthralgia, myalgia, fatigue, and headache. Eight participants in the zoledronic acid group and three in the placebo group died during the study. No inflammatory ocular disorders, atrial fibrillation, osteonecrosis of the jaw, abnormalities in hematology or biochemistry values or in serum creatinine or calculated creatinine clearance were observed.

#### SERMS

Table 53 shows the risks of adverse events for the SERM raloxifene compared with placebo.

Table 53 Risks of adverse events for raloxifene versus placebo

Event Group | Raloxifene
Event Group | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 7 | 1.07 (0.95, 1.21)
Cardiovascular Death | 3 | 1.03 (0.89, 1.20)
Cerebrovascular Accidents | 6 | 1.12 (1.00, 1.25)
Pulmonary Embolism | 4 | 5.27 (1.29, 46.4)^*^
Thromboembolic Events | 8 | 1.63 (1.36, 1.98)^*^
Cancer
Breast Cancer | 4 | 0.79 (0.32, 1.97)
Colon Cancer | 0 | NR
Lung Cancer | 2 | 0.39 (0.01, 7.87)
Osteosarcoma | 0 | NR
GI
GI (mild) | 9 | 0.97 (0.78, 1.21)
Upper GI (excluding esophagus) | 3 | 1.1 (0.68, 1.81)
Reflux and Esophageal | 0 | NR
GI (serious) | 1 | 0.49 (0.01, 39.1)
Esophageal (serious) | 0 | NR
Upper GI Perforations, Ulcers, or Bleeds (not esophageal) | 1 | 0.33 (0.01, 4.17)
Musculoskeletal
Myalgias, Cramps, and Limb Pain | 11 | 1.53 (1.29, 1.81)
Arthritis and Arthralgias | 1 | Inf+ (0.01, Inf+)
Sweats/Fevers/Hot Flashes
Hot flashes | 8 | 1.58 (1.35, 1.84)

* Statistically Significant.

##### Cardiovascular

A pooled analysis of 16 trials showed a small but significant increase in serious cardiovascular adverse effects for raloxifene compared with placebo (Figure 16).

Figure 16 Serious cardiovascular adverse events in trials of raloxifene versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 16 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.05 to 7.39 (pooled OR 1.20 [95% CI 1.11, 1.29]), slightly but significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 43.8%, p=0.031).

###### Acute Coronary Syndrome

The original report identified four trials of raloxifene122,440-442 that found no significant effect of the drug compared with placebo. For the current report, we identified an additional three trials;121,443,444 the pooled OR for the seven trials was 1.07 (95% CI: 0.95, 1.21).

###### Atrial Fibrillation

One study was identified for the current report that compared the risk of atrial fibrillation between raloxifene- and placebo-treated patients; this study found no effect (OR 0.97 95% CI: 0.82, 1.14).443

###### Cardiovascular Death

The original report identified two trials of raloxifene440,442 that reported cardiac deaths and found no differences between drug and placebo. One additional study was identified for the current report;443 the pooled OR for the three studies was 1.03 (95% CI: 0.89, 1.20), again showing no difference.

###### CVA

The original report identified three trials of raloxifene441,442,445 that reported CVA; there were no significant differences between either drug and placebo. The current report identified three new studies of raloxifene121,443,444 that reported on CVAs; pooled analysis of the six raloxifene studies found no significant effect on the risk for CVA (OR 1.12, 95% CI: 1.00, 1.25).

###### Pulmonary Embolism

The original report identified two large studies that showed higher odds for pulmonary embolism among raloxifene participants than among placebo participants (OR 6.26, 95% CI: 1.55, 54.80).440,446 The current report identified two additional studies121,443; among the four studies, the pooled odds ratio for pulmonary embolism in the treated group was 5.27 (95% CI: 1.29, 46.4).

###### Venous Thromboembolic Events

The original report identified four studies that showed higher risk of thromboembolic events for raloxifene-treated participants than for placebo participants (OR 2.08, 95% CI: 1.47, 3.02).406,440,447,448 For the current report, four additional studies were identified (OR 1.63, 95% CI: 1.36, 1.98) that narrowed the confidence interval (RD 0.011 95% CI: 0.007, 0.014).121,443,444,449

##### Cancer

###### Breast Cancer

The original report identified two studies that, when pooled, showed no significant differences between raloxifene and placebo.440,447 For the current report, two additional studies were identified.121,444 Pooled analysis of the four studies also showed no significant difference (OR 0.79, 95% CI: 0.32, 1.97). A pooled analysis of ten studies found no increase in overall breast abnormalities with raloxifene compared with placebo (Figure 17).

Figure 17 Breast abnormalities (other than cancer) in trials of raloxifene versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 10 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.11 to 7.39 (pooled OR 0.97 [95% CI 0.70, 1.35]), slightly but not significantly favoring raloxifene; the studies were not statistically heterogeneous (I-squared 32.3%, p=0.150).

###### Lung Cancer

The original report identified two placebo-controlled trials of raloxifene, 440,446 that reported lung cancer and found no significant differences. No new studies were found that reported on lung cancer risk.

##### Gastrointestinal (Serious)

###### PUBs

Two studies identified for the current report found no significant difference in the incidence of these events between raloxifene and placebo.445,456

##### Gastrointestinal (Mild)

The original report identified and pooled eight placebo-controlled trials of raloxifene and found no significant difference in the incidence of mild GI events (OR 0.98 95% CI: 0.78, 1.22).122,385,406,440,445,447,450,457 One new study identified for this report did not change that finding (OR 0.97 95% CI: 0.78, 1.21).456

##### Musculoskeletal

This category includes arthritis and arthralgia; and myalgias, muscle cramps, and limb pain. A pooled analysis of 13 studies identified a significant increase in such events for raloxifene compared with placebo (Figure 18). A pooled analysis of 11 placebo-controlled trials, seven identified for the original report122,406,441,445,447,457,458 and four identified for the current report,121,444,449,456 found a significant increase in myalgias, cramps, and limb pain for raloxifene (OR 1.53, 95% CI: 1.29, 1.81; RD 0.031, 95% CI: 0.019, 0.043) (Figure 19). A single placebo-controlled study found no effect on reports of arthritis and arthralgias for raloxifene (OR Inf+ 95% CI 0.01, Inf+).450

Figure 18 Musculoskeletal adverse events in trials of raloxifene versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 13 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.19 to 7.95 (pooled OR 1.42 [95% CI 1.21, 1.67]), significantly favoring placebo; however, the studies were statistically heterogeneous (I-squared 50.7%, p=0.018).

Figure 19 Myalgias, cramps, and limb pain in trials of raloxifene versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 11 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 1.03 to 7.80 (pooled OR 1.51 [95% CI 1.29, 1.78]), significantly favoring placebo; the studies were not statistically heterogeneous (I-squared 10.0%, p=0.349).

##### Sweats/Fever/Vasomotor Flushing/Hot Flashes

This category includes fever, hot flashes (vasomotor flushing), weight gain, pain, and flushing. A pooled analysis of eight placebo-controlled trials found that raloxifene significantly increased the incidence of hot flashes and flushing over that of placebo (OR 1.58 95% CI: 1.35, 1.84; RD 0.046 95% CI: 0.031, 0.060) (Figure 20).121,122,385,447,452,457-459

Figure 20 Sweats/fever/vasomotor flushing (hot flashes) in trials of raloxifene versus placebo

This forest plot displays the odds ratios (OR), 95% confidence intervals (CI), numbers of adverse events in the active treatment groups, and numbers of adverse events in the placebo groups for 15 parallel design trials. The sample sizes for each trial are reflected in shaded squares surrounding the OR points. The OR range from 0.14 to 8.42 (pooled OR 1.52 [95% CI 1.33, 1.73]), significantly favoring placebo; however, the studies were statistically heterogeneous (I-squared 55.0%, p=0.005).

#### Parathyroid Hormone

Table 54 shows the risks of adverse events for parathyroid hormone (teriparatide) compared with placebo.

Table 54 Risks of adverse events for parathyroid hormone versus placebo

Event Group | PTH
Event Group | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 1 | 0.97 (0.01, 76.1)
Cardiac Death | 1 | 0.97 (0.01, 76.1)
Cerebrovascular Events (serious) | 1 | 0 (0.0, 37.8)
Pulmonary Embolism | 0 | NR
Thromboembolic Events | 0 | NR
Cancer
Cancer, not specified | 2 | 0.49 (0.27, 0.9)^*^
Breast Cancer | 0 | NR
Colon Cancer | 0 | NR
Lung Cancer | 0 | NR
Osteosarcoma | 0 | NR
GI
GI (mild) | 2 | 1.39 (0.98, 2.00)
Upper GI (excluding esophagus) | 2 | 1.39 (0.98, 2.00)^*^
Reflux and Esophageal | 0 | NR
GI (serious) | 0 | NR
Esophageal (serious) | 0 | NR
Upper GI Perforations, Ulcers or Bleeds (not esophageal) | 0 | NR
Neurologic (mild)
Headaches | 3 | 1.44 (1.24, 1.67)^*^
Metabolic
Hypercalcemia | 4 | 12.9 (10.49, 16.00)^*^

* Statistically significant

##### Cardiovascular

###### Acute Coronary Syndrome, Including Myocardial Infarction

No studies were identified for the original or the current report that reported on these events with use of parathyroid hormone (PTH).

###### Cardiac Death

The original or current report identified no trials of PTH that reported cardiac death.

###### CVA

The original and current report found no trials of PTH that reported CVA.

###### Pulmonary Embolism

No trials were identified for the original or the current report that reported pulmonary embolism with use of PTH.

###### Venous Thromboembolic Events

No trials were identified for the original or the current report of that reported thromboembolic events with use of PTH.

##### Cancer

The original report identified two placebo controlled trials of teriparatide that reported on the incidence of various types of cancer.129,134 Participants in the teriparatide groups had lower odds of cancer than did placebo participants (OR 0.49, 95% CI: 0.27, 0.90; RD -0.018, 95% CI: -0.034, -0.003)). Incidences for specific types of cancers such as breast cancer, colon cancer, lung cancer, or osteosarcoma were not reported in these trials. The current report identified no trials that reported on cases of cancer with use of PTH.

##### Gastrointestinal (Mild)

###### Upper Gastrointestinal

The original report identified two placebo-controlled trials of teriparatide129,134 that reported on mild upper GI events and found no significant differences between treatment and placebo groups regarding mild upper GI adverse events. For the current report, there were no new studies of teriparatide.

##### Gastrointestinal (Serious)

###### Upper GI PUBs

No trials of PTH were identified that reported these events.

##### Neurologic (Mild)

This category consisted of headaches. A pooled analysis of two placebo-controlled trials of teriparatide showed a significant increase in reports of headache in the treated group (OR 1.44 95% CI: 1.24, 1.67).129,130,134

##### Metabolic

This category comprised hypercalcemia, hypercalciuria, hypocalcemia, and hyperuricemia.

###### Hypercalcemia

A pooled analysis of three placebo-controlled trials of teriparatide showed a significant increase in reports of hypercalcemia (OR 12.9 95% CI: 10.49, 16.00).130,133,134,460

##### Adverse Events in Subpopulations

A post-hoc analysis of the FPT assessed the association between impaired renal function and the risk for adverse effects from the use of teriparatide among postmenopausal women with mild or moderate renal impairment. Women with renal impairment tended to be older, had been postmenopausal longer, and lower baseline BMD. Teriparatide therapy was associated with mild hypercalcemia regardless of renal function status, and with a dose-dependent increase in the incidence of hyperuricemia regardless of renal function but no increase in the risk for gout, arthralgia, or nephrolithiasis.256

#### Estrogen or Estrogen Plus Progestin

The original report described in detail the harms associated with menopausal hormone therapy that were identified in the WHI; these harms included venous thromboembolic events, stroke, and a variable effect on breast cancer. Routine use of hormone replacement therapy in postmenopausal women is now discouraged. Two followup analyses of data from the Women's Health Initiative were identified that assessed the association between estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women in the wake of the declining use of menopausal hormone therapy. One assessment reported that the elevated incidence of breast cancer associated with use of estrogen plus progestin declined significantly over the two years following discontinuation of the combined therapy and that this change was not associated with any change in the frequency of mammography.461 A subsequent report presented an intention-to-treat analysis of cumulative breast cancer incidence after a mean followup of 11 years: combined therapy was associated with more invasive breast cancers than placebo (HR 1.25, 95% CI: 1.07, 1.46), tumors that were more likely to be node positive (HR 1.78, 95% CI: 1.23, 1.58), and more deaths attributed to breast cancer (HR 1.96, 95% CI: 1.00, 4.04).462

#### Denosumab

Denosumab was not examined in the original report. Table 55 shows the risks of adverse events for denosumab compared with placebo.

Table 55 Risks of adverse events for biologics (denosumab)

Event Group | Denosumab
Event Group | Number of Trials | OR (95% CI)
Cardiovascular
Cardiac (serious) | 3 | 1.04 (0.87, 1.25)
Cardiac Death | 0 | NR
Atrial Fibrillation | 1 | 1.00 (0.57, 1.73)
Cerebrovascular Events | 1 | 1.03 (0.7, 1.54)
Thromboembolic Events | 0 | NR
Cancer
Cancer | 2 | 0.49 (0.27, 0.9)^*^
Breast Cancer | 0 | NR
Colon Cancer | 0 | NR
Lung Cancer | 0 | NR
Osteosarcoma | 0 | NR
GI (mild)
Reflux and Esophageal | 2 | 2.13 (1.11, 4.4)^*^
GI (serious) | 0 | NR
Esophageal (serious) | 0 | NR
Upper GI Perforations, Ulcers or Bleeds (not esophageal) | 0 | NR
Dermatologic
Injection Site Reactions | 1 | Inf+ (0.06, Inf+)
Rash | 4 | 2.01 (1.5, 2.73)^*^
Infection
Infection – Not otherwise specified and not pulmonary, GI, ear, eye | 4 | 1.01 (0.92, 1.1)
Infection^†^ | 4 | 1.28 (1.02, 1.60)
Infection, excluding Ellis, 2008^†^ | 3 | 1.25 (1.00, 1.59)
Genitourinary
Urinary Tract Infection | 3 | 1.78 (0.96, 3.45) RD 0.030 (-0.017, 0.077)

* Statistcally significant.

† Previously published pooled analysis.465

##### Gastrointestinal (Mild)

###### Upper Gastrointestinal

Pooled results from one placebo-controlled trial identified for the original report showed an increase in reflux and esophageal complaints as well as other mild upper GI adverse events with denosumab (OR 2.13 95% CI: 1.11, 4.4; RD 0.013, 95% CI: 0.006, 0.019).61

##### Dermatologic

This category includes reactions at the site of injection/application and rash. No significant increases were found in reports of injection site reactions in one placebo-controlled trial of denosumab (OR Inf+ 95% CI: 0.06, Inf+).463 Pooled results of three placebo-controlled trials identified an increase in rash (OR 2.01 95% CI: 1.5, 2.73; RD 0.016, 95% CI: 0.009, 0.023).61,117,118

##### Other

Upon approval of denosumab for release, the FDA issued a Risk Evaluation and Mitigation Strategy for the drug that cited an increased risk for infection.464 A recent meta-analysis465 that updated a previous meta-analysis115 with the addition of a large RCT118 found a significantly increased risk of infection in the group given denosumab (OR 1.28, 95% CI: 1.02, 1.60; p=0.04, I^2^=44%). When a study that enrolled only participants with cancer was excluded,116 a small increased risk remained (RR=1.25, 95% CI: 1.00, 1.59; p=0.05, I^2^=41%).

#### Vitamin D and Calcium

Table 56 shows the risks of adverse events for vitamin D and calcium compared with placebo.

Table 56 Dietary supplements (Vitamin D and calcium)

Event Group | Calcium | | Vitamin D
Event Group | Number of Trials | OR (95% CI) | Number of Trials | OR (95% CI)
Cardiovascular
Acute Coronary Syndrome | 0 | NR | 0 | NR
Cardiac Death | 0 | NR | 0 | NR
Myocardial infarction | 5 | 1.31 (1.02, 1.67)^*,†^ | 0 | NR
Cerebrovascular Events (serious) | 1 | 1.56 (1.05, 2.33)^*^ | 0 | NR
Pulmonary Embolism | 0 | NR | 0 | NR
Thromboembolic Events | 0 | NR | 0 | NR
Cancer
Cancer | 0 | NR | 0 | NR
Breast Cancer | 0 | NR | 0 | NR
Colon Cancer | 0 | NR | 0 | NR
Lung Cancer | 0 | NR | 0 | NR
Osteosarcoma | 0 | NR | 0 | NR
GI
GI (mild) | 1 | 0.79 (0.33, 1.87) | 1 | 0.27 (0.04, 1.11)
Upper GI (excluding esophagus) | 1 | 0.79 (0.33, 1.87) | 2 | 0.27 (0.04, 1.11)
Reflux and Esophageal | 0 | NR | 0 | NR
GI (serious) | 0 | NR | 0 | NR
Esophageal (serious) | 0 | NR | 0 | NR
Upper GI Perforations, Ulcers or Bleeds (not esophageal) | 0 | NR | 0 | NR
Metabolic
Hypercalciuria | 0 | NR | 1 | 19.8 (3.19, 819)

* Significantly different.

† Hazard ratio.

##### Cardiovascular

###### Acute Coronary Syndrome, Including MI

No studies identified for the original or the current report found any cases of acute coronary syndromes in trials of vitamin D or calcium. A new meta-analysis of 15 placebo-controlled trials of calcium (administered for bone health in all cases but one) identified a small but significant increase in the risk for myocardial infarction in pooled results of five trials that contributed patient-level data (HR 1.31, 95% CI: 1.02, 1.67, p=0.035).466 The pooled results of trial-level data showed a similar effect (pooled RR 1.27, 95% CI: 1.01, 1.59, p=0.038). However, a number of letters written in response to the review pointed out multiple concerns with the analyses that could have resulted in biased results. The analysis excluded any studies that co-administered vitamin D with calcium (whereas guidelines recommend administering both); the study did not account for dietary calcium or vitamin D intake or status; and compliance with calcium supplementation was poor (as is usually the case). MI was not a pre-specified endpoint in any of the studies; the MI data for the study that more than half the reported events were unpublished, and in this same study, supplements were mailed and adverse events were assessed through mailed patient surveys (whose response rate was not revealed) and not verified by chart review; and compliance with Ca supplementation was not verified among patients who reported an MI.467,468

###### CVA

No reports of CVA were identified for the original report. One placebo-controlled trial of calcium identified for the current report found an increase in CVA among users (OR 1.56 95% CI: 1.05, 2.33).469

##### Cancer

Cancers were not reported in any trials of vitamin D or calcium.

##### Gastrointestinal (Serious)

No events were reported in trials of vitamin D or calcium.

##### Gastrointestinal (Mild)

In one trial of calcium155 [original report says ref. 269 included also] and one trial of vitamin D,396 identified for the original report, there were no significant differences between treatment and placebo groups regarding mild upper GI adverse events. One new trial that assessed the association of vitamin D to mild gastrointestinal events was identified for the current report; no difference was seen.470

##### Metabolic

A single placebo-controlled trial of Vitamin D identified for the current report showed an increased risk for hypercalciuria (OR 19.8, 95% CI: 3.19, 819).470

## Key Question 5 With Regard to Treatment for Preventing Osteoporotic Fracture: a) How Often Should Patients be Monitored (via Measurement of Bone Mineral Density) During Therapy, how Does Bone Density Monitoring Predict Antifracture Benefits During Pharmacotherapy, and Does the Ability of Monitoring to Predict Antifracture Effects of a Particular Pharmacologic Agent Vary Among the Pharmacotherapies? b) How Does the Antifracture Benefit Vary With Long-term Continued use of Pharmacotherapy, and What are the Comparative Antifracture Effects of Continued Long-term Therapy With the Various Pharmacotherapies?

For this question, we identified one systematic review and 4 RCTs.

### Key Findings for Key Question 5

- No evidence exists from RCTs regarding how often patients' BMD should be monitored during osteoporosis therapy
- A high level of evidence exists from RCTs that lumbar spine and femoral neck BMD changes from serial monitoring predict only a small percentage of the change or do not predict the change in fracture risk from treatment with antiresorptives, including alendronate, risedronate, raloxifene, and teriparatide
- In RCTs, even people who lose BMD during antiresorptive therapy benefit from a substantial reduction in risk of vertebral fracture. Greater increases in BMD did not necessarily predict greater decreases in fracture risk. Thus, improvement in spine bone mineral density during treatment with currently available osteoporosis medications accounts for a predictable but small part of the observed reduction in the risk of vertebral fracture. Vertebral fracture risk is reduced in women who lose femoral neck BMD with teriparatide treatment. Evidence is high for this conclusion.
- Evidence is moderate (one large RCT) that, compared to using alendronate for 5 years followed by discontinuation after 5 years, continuous use of alendronate for 10 years resulted in a lower risk of vertebral fracture.

### Summary of Findings for Key Question 5

#### Key Question 5a1 How Often Should Patients be Monitored via Measurement of Bone Mineral Density During Therapy?

We did not identify any RCTs that have directly compared various schedules of serial BMD monitoring during osteoporosis pharmacotherapy in relation to optimal fracture prediction.

However, post hoc analyses from RCTs of pharmacotherapy have addressed the related important question of the extent to which changes in BMD during pharmacotherapy predict the magnitude of antifracture effects of pharmacotherapy. These analyses are discussed below.

#### Key Question 5a2 How Does Bone Density Monitoring Predict Antifracture Benefits During Pharmacotherapy?

##### Prior Systematic Reviews

Cummings and colleagues performed a meta-analysis to assess the evidence on the relation between improvement in spine BMD and reduction in risk of vertebral fracture in postmenopausal women receiving anti-resorptive treatment (etidronate, alendronate, tiludronate, risedronate, estradiol, raloxifene, and calcitonin).471 The authors used logistic regression models to estimate the proportion of the reduction in risk of an outcome (e.g., vertebral fracture) explained by the effects of treatment on an intermediary variable (spine bone mineral density). The proportion of the reduction in the risk of fracture (p) that was explained by changes in a marker was estimated as follows: p =( 1-β*/β) where β = log (unadjusted odds ratio [OR]) and β* = log (OR adjusted for bone mineral density). Based on data from 12 trials, they concluded that the reduction in vertebral fracture risk was greater than predicted from improvement in BMD. That is, based on improvement in BMD, treatments would have been predicted to reduce fracture risk by 20 percent, whereas treatments actually reduced fracture risk by 45 percent. The study concluded that improvement in spine BMD during treatment with antiresorptive drugs accounts for a small part of the observed reduction in vertebral fracture risk.

A new meta-analysis reported that there was no association between BMD changes and reduction in risk of fracture among patients receiving calcium with or without vitamin D supplementation, so that the fracture reduction effects of calcium and/or vitamin D may be via a mechanism that is independent of BMD.472

##### Post hoc Analyses of Randomized Controlled Trial Data

###### Alendronate

Studies from the Fracture Intervention Trial (FIT) of alendronate vs. placebo (5 mg daily for the first two years, then 10 mg/day) among postmenopausal women showed that among participants taking at least 60 percent of assigned study medication, women who gained 0 percent to 4 percent of BMD after 1-2 years during treatment had a decrease in vertebral risk of 51 percent (OR = 0.49, 95% CI: 0.30, 0.78) after 3-4 years of followup. However, women who had lost 0 percent to 4 percent of lumbar spine BMD during alendronate therapy had a 60 percent lower risk of vertebral fractures (OR = 0.40, 95% CI: 0.16, 0.99) compared to their counterparts assigned to placebo473 Bell and colleagues analyzed 3-year followup data from FIT.474 Nearly all (97.5 percent of) participants gained BMD during alendronate treatment. However, the between-person variation in the effects of alendronate was small in magnitude compared with the within-person variation. The study concluded that monitoring bone mineral density in postmenopausal women in the first three years after starting treatment with a potent bisphosphonate is unnecessary and may be misleading. In another analysis of the FIT data, improvement in spine BMD after one year of alendronate use explained only 16 percent (95% CI: 11, 27) of the reduction in the risk of vertebral fracture after three years of therapy.471,f

###### Risedronate

Among postmenopausal osteoporotic women assigned to 2.5 mg or 5 mg daily of risedronate, the incidence of nonvertebral fractures during followup of up to three years was not different between women whose spine BMD decreased (cumulative fracture incidence of 7.8 percent) and those whose spine BMD increased (cumulative fracture incidence 6.4 percent) (hazard ratio 0.79, 95% CI: 0.50, 1.25).475 Another study by the same authors estimated the proportion of fracture risk reduction attributable to change in BMD by calculating the ratio of the regression coefficients, where the numerator is the risk reduction explained by the surrogate, and the denominator is the overall risk reduction by treatment. Similarly, the incidence of nonvertebral fractures among women treated with risedronate was not different between women whose femoral neck BMD decreased (7.6 percent) and those femoral neck BMD increased (7.5 percent) (hazard ratio 0.93, 95% CI: 0.68, 1.28). This study reported that fracture risk was similar (about 10 percent), in risedronate-treated women whose increases in BMD were <5 percent, (the median change from baseline) and those whose increases were ≥5 percent.476 Thus, greater increases in BMD did not necessarily predict greater decreases in vertebral fracture risk. Similarly, the incidence of nonvertebral fractures among women treated with risedronate was not different between women whose femoral neck BMD decreased (7.6 percent) and those whose femoral neck BMD increased (7.5 percent) (hazard ratio 0.93, 95% CI: 0.68, 1.28). Changes in lumbar spine and femoral neck explained 12% (95% CI: 2, 21) of the reduction in nonvertebral fracture risk associated with risedronate therapy. Changes in femoral neck BMD explained 7 percent (95% CI: 2, 13) of reduction in nonvertebral fracture risk associated with risedronate therapy.475

###### Ibandronate

In a post-hoc pooled analysis of two RCTs, increases in hip and lumbar spine BMD during oral or intravenous ibandronate administration were statistically significantly associated with vertebral fracture rate.477 However, changes in total hip and lumbar spine BMD explained only 23 percent to37 percent of the antifracture effect at 2 and 3-year followup.

###### Raloxifene

Sarkar and colleagues analyzed data from the Multiple Outcomes of Raloxifene Evaluation (MORE) Trial of raloxifene (60 mg or 120 mg) vs. placebo in postmenopausal women with osteoporosis.478 The reduction in fracture risk with raloxifene was similar regardless of percentage change in lumbar spine or femoral neck BMD at three years. At any percentage change in femoral neck and lumbar spine BMD at one year, raloxifene treatment decreased the risks of new vertebral fractures at three years by 38 percent and 41 percent, respectively. The magnitude of change in BMD during raloxifene therapy accounted for 4 percent of the observed vertebral fracture reduction, i.e. 96 percent of reduction in vertebral fracture risk in women assigned to raloxifene therapy was unexplained.

###### Teriparatide

In the Fracture Prevention Trial (teriparatide 20 or 40 μg/day vs. placebo in postmenopausal women), women who lost greater than 4 percent at the femoral neck during the first 12 months of teriparatide treatment had significant reductions in vertebral fracture risk compared to placebo during a median of 19 month followup (RR 0.11, 95% CI: 0.03, 0.45).479 Compared to women assigned to placebo, the decrease in vertebral fracture risk in women assigned to teriparatide was similar across categories of femoral neck BMD change from baseline to 12 months. Vertebral fracture risk was decreased among women who lost femoral neck BMD during teriparatide therapy. Among women assigned to teriparatide, increases in spine BMD accounted for 30 percent to 41 percent of the reduction in vertebral fracture risk.480

##### Summary of Results of KQ5a2: BMD Monitoring and Fracture Risk Reduction During Osteoporosis Pharmacotherapy

Among patients treated with bisphosphonates, raloxifene, or teriparatide, increases in lumbar spine and femoral neck BMD from serial BMD monitoring predict only a small proportion of antifracture effects. In RCTs, even people who lose BMD during anti-resorptive therapy benefit from a substantial reduction in risk of vertebral fracture. Greater increases in BMD did not necessarily predict greater decreases in fracture risk. Thus, improvement in spine bone mineral density during treatment with currently available osteoporosis medications accounts for a predictable but small part of the observed reduction in the risk of vertebral fracture. Vertebral fracture risk is reduced in women who lose femoral neck BMD with teriparatide treatment.

The reason for the low association of changes in BMD and fracture risk reduction during pharmacotherapy appears to be that the majority of fracture risk reduction results from improvements in non-BMD determinants of bone strength.480

#### Key Question 5a3 Does the Ability of Monitoring To Predict Antifracture Efficacy of a Particular Pharmacologic Agent Vary Among the Pharmacotherapies?

We did not identify RCTs or systematic reviews that conducted head-to-head comparisons of the ability of monitoring to predict antifracture effects among various pharmacotherapies.

#### Key Question 5b How Does the Antifracture Benefit Vary With Long-term Continued use of Pharmacotherapy, and What are the Comparative Antifracture Efficacies of Continued Long-term Therapy With the Various Pharmacotherapies?

Some studies, such as those of Ensrud and colleagues,120 focused on the effects of extended duration of therapy (this is discussed in the section of key question 1 above), but did not focus on the comparison of longer with shorter duration of therapy. A goal of this report was to examine studies that directly compared longer (3 to 5 years or longer) vs. shorter durations of therapy.

The only studies that we found that met these criteria, i.e. that focused on the comparison of longer with shorter durations of therapy were open-label extensions of the FIT RCT. In the FLEX 5-year extension of the FIT RCT (original trial alendronate vs. placebo for 5 years among postmenopausal women), several analyses have addressed longer (10-year) vs. shorter (5-year) therapy with alendronate. At 10-year followup, the cumulative risk of nonvertebral fractures was not significantly different between those continuing (19 percent) and discontinuing (18.9 percent) alendronate.240 Among women who continued alendronate, there was a significantly lower risk of clinically-recognized vertebral fractures (5.3 percent for placebo vs. 2.4 percent for alendronate; RR, 0.45; 95% CI: 0.24, 0.85) but no significant reduction in morphometric vertebral fractures. In a recent post hoc analysis of the FLEX data investigators assessed whether baseline BMD or pre-existing fracture could influence the effects of longer duration (10 year vs. 5 years) of therapy. Among women without vertebral fracture at FLEX baseline, alendronate continuation reduced nonvertebral fracture among women with FLEX baseline femoral neck T-scores of -2.5 or less [RR 0.50, 95% CI: 0.26, 0.96] but not among women with T-scores between -2.5 and -2 or less (RR 0.79, 95% CI: 0.37, 1.66) or with T-scores of greater than -2 (RR 1.41, 95% CI: 0.75, 2.66; p for interaction =.019). The investigators concluded that the continuation of alendronate for 10 years instead of stopping after 5 years reduces nonvertebral fracture risk in women without prevalent vertebral fracture whose femoral neck T-scores, achieved after 5 years of alendronate, are -2.5 or less but does not reduce risk of nonvertebral fracture risk among women without prevalent vertebral fractures whose T-scores are >-2.^243^ Thus a limitation of this analysis is that it is post hoc with caveat these data support the thesis that certain features predict continued fracture reduction with a 10-year instead of 5 year duration of alendronate therapy: BMD T-score above -2 if women have baseline fractures, and BMD T-score <-2 if women do not have baseline fractures. The primary analysis of FLEX supports the thesis that for other women there is no evidence of a benefit on nonvertebral fracture reduction by continuing alendronate for ten as opposed to five years.

Data supporting the effectiveness of osteoporosis pharmacotherapy are much stronger for people who have established osteoporosis, as opposed to primary prevention. Regarding glucocorticoid-induced osteoporosis, the original review identified evidence from a systematic review and six additional RCTs. Results of these studies were mixed and overall the evidence was inconclusive, although suggestive of possible benefits for bisphosphonates. We did not identify any new studies to alter these conclusions.

e Some studies report vitamin D doses in international units(IU), whereas some report the doses in micrograms (ug). One IU vitamin D is equivalent to 0.025 μg cholecalciferol. We report doses in the units used in individual studies.

f The dose of alendronate in FIT was 5 mg daily for 1st two years, and then 10 mg/day.