# References

Note: Several studies in this report have been retracted. They are indicated in the References section. More information is located on the journals’ websites and the Retraction Watch database.

1 NIH Consensus Development Panel on Osteoporosis Prevention D, Theapy. (2001). Osteoporosis prevention, diagnosis, and therapy. JAMA.
2 Sasser AC, Rousculp MD, Birnbaum HG, et al. (2005). Economic burden of osteoporosis, breast cancer, and cardiovascular disease among postmenopausal women in an employed population. Womens Health Issues.
3 National Osteoporosis Foundation. (2010). Clinician's Guide to Prevention and Treatment of Osteoporosis.
4 Burge R, Dawson-Hughes B, Solomon DH, et al. (2007). Incidence and economic burden of osteoporosis-related fractures in the United States, 2005-2025. J Bone Miner Res.
5 Nelson HD, Haney EM, Dana T, et al. (2010). Screening for Osteoporosis: An update for the U.S. Preventive Services Task Force. Annals of Internal Medicine.
6 Kanis JA, Melton LJ, Christiansen C, et al. (1994). The diagnosis of osteoporosis. J Bone Miner Res.
7 World Health Organization Collaborating Centre for Metabolic Bone, Diseases University of Sheffield, UK. WHO Fracture Risk Assessment Tool.
8 Kanis JA, Johnell O, Oden A, et al. (2008). FRAX and the assessment of fracture probability in men and women from the UK. Osteoporos Int.
9 Kanis JA, Oden A, Johnell O, et al. (2007). The use of clinical risk factors enhances the performance of BMD in the prediction of hip and osteoporotic fractures in men and women. Osteoporos Int.
10 Lewiecki EM, Binkley N. (2009). Evidence-based medicine, clinical practice guidelines, and common sense in the management of osteoporosis. Endocr Pract.
11 Kanis JA, Johansson H, Oden A, et al. (2009). Assessment of fracture risk. Eur J Radiol.
12 Colman EG. (2003). The Food and Drug Administration's Osteoporosis Guidance Document: past, present, and future. J Bone Miner Res.
13 (1994). Guidelines for Preclinical and Clinical Evaluation of Agents Used in the Prevention or Treatment of Postmenopausal Osteoporosis.
14 MacLean C, Alexander A, Carter J, et al. (2007). Comparitive Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis.
15 Shekelle PG, Newberry SJ, Maglione M, et al. (2009). Evaluation of the need to update comparative effectiveness reviews.
16 Cramer JA, R A, Burrell A, Fairchild CJ, Fuldeore MJ, Ollendorf DA, Wong PK. (2008). Medication compliance and persistence: terminology and definitions. Value Health.
17 World Health Organization. (2003). Adherence to Long-Term Therapies: Evidence for Action.
18 StatXact. (2009). StatXact 9 for Windows.
19 Yusuf S, Peto R, Lewis J, et al. (1985). Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis.
20 Bradburn MJ, Deeks JJ, Berlin JA, et al. (2006). Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med.
21 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
22 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet.
23 Wells GA, S B, O'Connell D, Peterson J, Welch V, Losos M, Tugwell P. (2004). Newcastle-Ottawa Quality Assessment Scale, Cohort Studies. Quality Assessment Scales for Observational Studies.
24 Fullerton DS, Atherly DS. (2004). Formularies, therapeutics, and outcomes: new opportunities. Med Care.
25 Gartlehner G, Hansen RA, Nissman D, et al. (2006). A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol.
26 Owens DK, L KN, Atkins D, et al. (2010). AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol.
27 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. BMJ.
28 Whitlock EP, Lin JS, Chou R, et al. (2008). Using existing systematic reviews in complex systematic reviews. Ann Intern Med.
29 Cranney A, Wells G, Willan A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev.
30 Karpf DB, Shapiro DR, Seeman E, et al. (1997). Prevention of nonvertebral fractures by alendronate. A meta-analysis. Alendronate Osteoporosis Treatment Study Groups. JAMA.
31 Papapoulos SE, Quandt SA, Liberman UA, et al. (2005). Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int.
32 Stevenson M, Lloyd Jones M, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
33 Nguyen ND, Eisman JA, Nguyen TV. (2006). Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res.
34 Boonen S, Laan RF, Barton IP, et al. (2005). Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int.
35 Sawka AM, Papaioannou A, Adachi JD, et al. (2005). Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord.
36 Jansen JP, Bergman GJ, Huels J, et al. (2009). Prevention of vertebral fractures in osteoporosis: mixed treatment comparison of bisphosphonate therapies. Curr Med Res Opin.
37 Wells GA, Cranney A, Peterson J, et al. (2008). Alendronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev.
38 Adami S, Passeri M, Ortolani S, et al. (1995). Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone.
39 Ascott-Evans BH, Guanabens N, Kivinen S, et al. (2003). Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy: a randomized controlled trial. Arch Intern Med.
40 Black DM, Cummings SR, Karpf DB, et al. (1996). Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet.
41 Bone HG, Downs RW, Tucci JR, et al. (1997). Dose-response relationships for alendronate treatment in osteoporotic elderly women. Alendronate Elderly Osteoporosis Study Centers. J Clin Endocrinol Metab.
42 Bonnick S, Rosen C, Mako B, et al. (1998). Alendronate vs calcium for treatment of osteoporosis in postmenopausal women. Bone.
43 Chesnut CH, McClung MR, Ensrud KE, et al. (1995). Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. Am J Med.
44 Cummings SR, Black DM, Thompson DE, et al. (1998). Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA.
45 Dursun N, Dursun E, Yalcin S. (2001). Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract.
46 Greenspan SL, Parker RA, Ferguson L, et al. (1998). Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res.
47 Greenspan SL, Schneider DL, McClung MR, et al. (2002). Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
48 Hosking D, Chilvers CE, Christiansen C, et al. (1998). Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med.
49 Liberman UA, Weiss SR, Broll J, et al. (1995). Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. The Alendronate Phase III Osteoporosis Treatment Study Group. N Engl J Med.
50 McClung M, Clemmesen B, Daifotis A, et al. (1998). Alendronate prevents postmenopausal bone loss in women without osteoporosis. A double-blind, randomized, controlled trial. Alendronate Osteoporosis Prevention Study Group. Ann Intern Med.
51 Orwoll E, Ettinger M, Weiss S, et al. (2000). Alendronate for the treatment of osteoporosis in men. N Engl J Med.
52 Pols HA, Felsenberg D, Hanley DA, et al. (1999). Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Foxamax International Trial Study Group. Osteoporos Int.
53 Ringe JD, Dorst A, Faber H, et al. (2004). Alendronate treatment of established primary osteoporosis in men: 3-year results of a prospective, comparative, two-arm study. Rheumatol Int.
54 Weinstein RS, Bone H, Tucci J, et al. (1994). Alendronate treatment of osteoporosis in elderly women. J Bone Miner Res.
55 Papaioannou A, Kennedy CC, Freitag A, et al. (2008). Alendronate once weekly for the prevention and treatment of bone loss in Canadian adult cystic fibrosis patients (CFOS trial). Chest.
56 Ringe JD, Farahmand P, Schacht E, et al. (2007). Superiority of a combined treatment of Alendronate and Alfacalcidol compared to the combination of Alendronate and plain vitamin D or Alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int.
57 de Nijs RN, Jacobs JW, Lems WF, et al. (2006). Alendronate or alfacalcidol in glucocorticoid-induced osteoporosis. N Engl J Med.
58 Bone HG, Greenspan SL, McKeever C, et al. (2000). Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab.
59 Greenspan SL, Resnick NM, Parker RA. (2003). Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA.
60 Hosking D, Adami S, Felsenberg D, et al. (2003). Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Curr Med Res Opin.
61 McClung MR, Lewiecki EM, Cohen SB, et al. (2006). Denosumab in postmenopausal women with low bone mineral density. N Engl J Med.
62 Quandt SA, Thompson DE, Schneider DL, et al. (2005). Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of-1.6 to -2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc.
63 Zein CO, Jorgensen RA, Clarke B, et al. (2005). Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology.
64 Retracted: Sato Y, Iwamoto J, Kanoko T, et al. (2006). Alendronate and vitamin D2 for prevention of hip fracture in Parkinson's disease: A randomized controlled trial. Mov Disord.
65 Cranney A, Tugwell P, Adachi J, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev.
66 Miller PD, Roux C, Boonen S, et al. (2005). Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res.
67 Reid IR, Mason B, Horne A, et al. (2006). Randomized controlled trial of calcium in healthy older women. Am J Med.
68 Wallach S, Cohen S, Reid DM, et al. (2000). Effects of risedronate treatment on bone density and vertebral fracture in patients on corticosteroid therapy. Calcif Tissue Int.
69 Bianchi G, Sambrook P. (2008). Oral nitrogen-containing bisphosphonates: a systematic review of randomized clinical trials and vertebral fractures. Curr Med Res Opin.
70 Wells G, Cranney A, Peterson J, et al. (2008). Risedronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev.
71 Zhong ZM, Chen JT. (2009). Anti-fracture efficacy of risedronic acid in men: A meta-analysis of randomized controlled trials. Clin Drug Investig.
72 Retracted: Sato Y, Honda Y, Iwamoto J. (2007). Risedronate and ergocalciferol prevent hip fracture in elderly men with Parkinson disease. Neurology.
73 Ringe JD, Farahmand P, Faber H, et al. (2009). Sustained efficacy of risedronate in men with primary and secondary osteoporosis: results of a 2-year study. Rheumatol Int.
74 Boonen S, Orwoll ES, Wenderoth D, et al. (2009). Once-weekly risedronate in men with osteoporosis: results of a 2-year, placebo-controlled, double-blind, multicenter study. J Bone Miner Res.
75 Palomba S, Manguso F, Orio F, et al. (2008). Effectiveness of risedronate in osteoporotic postmenopausal women with inflammatory bowel disease: a prospective, parallel, open-label, two-year extension study. Menopause.
76 Kanaji A, Higashi M, Namisato M, et al. (2006). Effects of risedronate on lumbar bone mineral density, bone resorption, and incidence of vertebral fracture in elderly male patients with leprosy. Lepr Rev.
77 Retracted: Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med.
78 Retracted: Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
79 Retracted: Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology.
80 Sorensen OH, Crawford GM, Mulder H, et al. (2003). Long-term efficacy of risedronate: a 5-year placebo-controlled clinical experience. Bone.
81 Ringe JD, Faber H, Farahmand P, et al. (2006). Efficacy of risedronate in men with primary and secondary osteoporosis: results of a 1-year study. Rheumatol Int.
82 Milgrom C, Finestone A, Novack V, et al. (2004). The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone.
83 Greenspan SL, Bhattacharya RK, Sereika SM, et al. (2006). Prevention of Bone Loss in Survivors of Breast Cancer: A Randomized, Double-Blind, Placebo-Controlled Clinical Trial. J Clin Endocrinol Metab.
84 Palomba S, Orio F, Manguso F, et al. (2005). Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int.
85 Delmas PD, Benhamou CL, Man Z, et al. (2008). Monthly dosing of 75 mg risedronate on 2 consecutive days a month: efficacy and safety results. Osteoporos Int.
86 Delmas PD, McClung MR, Zanchetta JR, et al. (2008). Efficacy and safety of risedronate 150 mg once a month in the treatment of postmenopausal osteoporosis. Bone.
87 Watts NB, Josse RG, Hamdy RC, et al. (2003). Risedronate prevents new vertebral fractures in postmenopausal women at high risk. J Clin Endocrinol Metab.
88 Clemmesen B, Ravn P, Zegels B, et al. (1997). A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int.
89 Cohen S, Levy RM, Keller M, et al. (1999). Risedronate therapy prevents corticosteroid-induced bone loss: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum.
90 Fogelman I, R C, Smith R, Ethgen D, Sod E, Reginster JY. (2000). Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab.
91 Harris ST, Watts NB, Genant HK, et al. (1999). Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA.
92 Hooper MJ, Ebeling PR, Roberts AP, et al. (2005). Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric.
93 McClung M, Bensen W, Bolognese M, et al. (1998). Risedronate increases bone mineral density at the hip, spine and radius in postmenopausal women with low bone mass. Osteoporos Int.
94 McClung MR, Geusens P, Miller PD, et al. (2001). Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med.
95 Mortensen L, Charles P, Bekker PJ, et al. (1998). Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab.
96 Reginster J, Minne HW, Sorensen OH, et al. (2000). Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Vertebral Efficacy with Risedronate Therapy (VERT) Study Group. Osteoporos Int.
97 Reid DM, Hughes RA, Laan RF, et al. (2000). Efficacy and safety of daily risedronate in the treatment of corticosteroid-induced osteoporosis in men and women: a randomized trial. European Corticosteroid-Induced Osteoporosis Treatment Study. J Bone Miner Res.
98 Reid DM, Adami S, Devogelaer JP, et al. (2001). Risedronate increases bone density and reduces vertebral fracture risk within one year in men on corticosteroid therapy. Calcif Tissue Int.
99 Kishimoto H, Fukunaga M, Kushida K, et al. (2006). Efficacy and tolerability of once-weekly administration of 17.5 mg risedronate in Japanese patients with involutional osteoporosis: a comparison with 2.5-mg once-daily dosage regimen. J Bone Miner Metab.
100 Brown JP, Kendler DL, McClung MR, et al. (2002). The efficacy and tolerability of risedronate once a week for the treatment of postmenopausal osteoporosis. Calcif Tissue Int.
101 Harris ST, Watts NB, Li Z, et al. (2004). Two-year efficacy and tolerability of risedronate once a week for the treatment of women with postmenopausal osteoporosis. Curr Med Res Opin.
102 Cranney A, Wells GA, Yetisir E, et al. (2009). Ibandronate for the prevention of nonvertebral fractures: a pooled analysis of individual patient data. Osteoporos Int.
103 Harris ST, Blumentals WA, Miller PD. (2008). Ibandronate and the risk of non-vertebral and clinical fractures in women with postmenopausal osteoporosis: results of a meta-analysis of phase III studies. Curr Med Res Opin.
104 Ravn P, Clemmesen B, Riis BJ, et al. (1996). The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone.
105 Grotz W, Nagel C, Poeschel D, et al. (2001). Effect of ibandronate on bone loss and renal function after kidney transplantation. JASN.
106 Fahrleitner-Pammer A, Piswanger-Soelkner JC, Pieber TR, et al. (2009). Ibandronate prevents bone loss and reduces vertebral fracture risk in male cardiac transplant patients: a randomized double-blind, placebo-controlled trial. J Bone Miner Res.
107 Chesnut CH, Skag A, Christiansen C, et al. (2004). Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. J Bone Miner Res.
108 Recker R, Stakkestad JA, Chesnut CH, et al. (2004). Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone.
109 Miller PD, McClung MR, Macovei L, et al. (2005). Monthly oral ibandronate therapy in postmenopausal osteoporosis: 1-year results from the MOBILE study. J Bone Miner Res.
110 Delmas PD, Adami S, Strugala C, et al. (2006). Intravenous Ibandronate Injections in Postmenopausal Women With osteoporosis: one-year results from the dosing intravenous administration study. Arthritis Rheum.
111 Black DM, Delmas PD, Eastell R, et al. (2007). Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med.
112 Reid IR, Brown JP, Burckhardt P, et al. (2002). Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med.
113 Lyles KW, Colon-Emeric CS, Magaziner JS, et al. (2007). Zoledronic acid and clinical fractures and mortality after hip fracture. N Engl J Med.
114 Chapman I, Greville H, Ebeling PR, et al. (2009). Intravenous zoledronate improves bone density in adults with cystic fibrosis (CF). Clin Endocrinol (Oxf).
115 Anastasilakis AD, Toulis KA, Goulis DG, et al. (2009). Efficacy and Safety of Denosumab in Postmenopausal Women with Osteopenia or Osteoporosis: A Systematic Review and a Meta-analysis. Horm Metab Res.
116 Ellis GK, Bone HG, Chlebowski R, et al. (2008). Randomized trial of denosumab in patients receiving adjuvant aromatase inhibitors for nonmetastatic breast cancer. J Clin Oncol.
117 Bone HG, Bolognese MA, Yuen CK, et al. (2008). Effects of denosumab on bone mineral density and bone turnover in postmenopausal women. J Clin Endocrinol Metab.
118 Cummings SR, Martin JS, McClung MR, et al. (2009). Denosumab for Prevention of Fractures in Postmenopausal Women with Osteoporosis. N Engl J Med.
119 Lewiecki EM, Miller PD, McClung MR, et al. (2007). Two-year treatment with denosumab (AMG 162) in a randomized phase 2 study of postmenopausal women with low BMD. J Bone Miner Res.
120 Ensrud KE, Stock JL, Barrett-Connor E, et al. (2008). Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res.
121 Silverman SL, Christiansen C, Genant HK, et al. (2008). Efficacy of bazedoxifene in reducing new vertebral fracture risk in postmenopausal women with osteoporosis: results from a 3-year, randomized, placebo-, and active-controlled clinical trial. J Bone Miner Res.
122 Reid IR, Eastell R, Fogelman I, et al. (2004). A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med.
123 Schachter HM, Clifford TJ, Cranney A, et al. (2005). Raloxifene for primary and secondary prevention of osteoporotic fractures in postmenopausal women: a systematic review of efficacy and safety evidence.
124 Seeman E, Crans GG, Diez-Perez A, et al. (2006). Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int.
125 Barrett-Connor E, Mosca L, Collins P, et al. (2006). Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med.
126 Vestergaard P, Jorgensen NR, Mosekilde L, et al. (2007). Effects of parathyroid hormone alone or in combination with antiresorptive therapy on bone mineral density and fracture risk--a meta-analysis. Osteoporos Int.
127 Gallagher JC, Genant HK, Crans GG, et al. (2005). Teriparatide reduces the fracture risk associated with increasing number and severity of osteoporotic fractures. JCEM.
128 Kaufman JM, Orwoll E, Goemaere S, et al. (2005). Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int.
129 Orwoll ES, Scheele WH, Paul S. (2003). The effects of teriparatide[human parathyroid hormone(1-34)] therapy on bone density in men with osteoporosis. J Bone Miner Res.
130 Greenspan SL, Bone HG, Ettinger MP, et al. (2007). Effect of recombinant human parathyroid hormone (1-84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med.
131 Cosman F, Lindsay R. (2004). Therapeutic potential of parathyroid hormone. Curr Osteoporos Rep.
132 Greenspan SL, Bone HG, Marriott TBEa. (2005). Preventing the first vertebral fracture in postmenopausal women with low bone mass using PTH(1-84): results from the TOP study (Abstract). J Bone Miner Res.
133 Kurland ES, Cosman F, McMahon DJ, et al. (2000). Parathyroid hormone as a therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab.
134 Neer RM, Arnaud CD, Zanchetta JR, et al. (2001). Effect of parathyroid hormone (1-34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med.
135 Orwoll ES, Scheele WH, Paul S, et al. (2003). The effect of teriparatide. J Bone Miner Res.
136 Boone RH, Cheung AM, Girlan LM, et al. (2006). Osteoporosis in primary biliary cirrhosis: a randomized trial of the efficacy and feasibility of estrogen/progestin. Dig Dis Sci.
137 Ishida Y, Kawai S. (2004). Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. Am J Med.
138 Wimalawansa SJ. (1998). A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med.
139 Bischoff-Ferrari HA, Dawson-Hughes B, Baron JA, et al. (2007). Calcium intake and hip fracture risk in men and women: a meta-analysis of prospective cohort studies and randomized controlled trials. Am J Clin Nutr.
140 Boonen S, Lips P, Bouillon R, et al. (2007). Need for additional calcium to reduce the risk of hip fracture with vitamin d supplementation: evidence from a comparative metaanalysis of randomized controlled trials. J Clin Endocrinol Metab.
141 Tang BM, Eslick GD, Nowson C, et al. (2007). Use of calcium or calcium in combination with vitamin D supplementation to prevent fractures and bone loss in people aged 50 years and older: a meta-analysis. Lancet.
142 Richy F, Schacht E, Bruyere O, et al. (2005). Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: a comparative meta-analysis. Calcif Tissue Int.
143 Avenell A, Gillespie WJ, Gillespie LD, et al. (2005). Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev.
144 O'Donnell S, Moher D, Thomas K, et al. (2008). Systematic review of the benefits and harms of calcitriol and alfacalcidol for fractures and falls. J Bone Miner Metab.
145 Avenell A, Gillespie WJ, Gillespie LD, et al. (2009). Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev.
146 (2010). Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. BMJ.
147 Bergman GJ, Fan T, McFetridge JT, et al. (2010). Efficacy of vitamin D3 supplementation in preventing fractures in elderly women: a meta-analysis. Curr Med Res Opin.
148 Izaks GJ. (2007). Fracture prevention with vitamin D supplementation: considering the inconsistent results. BMC Musculoskelet Disord.
149 Lai JK, Lucas RM, Clements MS, et al. (2010). Hip fracture risk in relation to vitamin D supplementation and serum 25-hydroxyvitamin D levels: a systematic review and meta-analysis of randomised controlled trials and observational studies. BMC Public Health.
150 Larsen ER, Mosekilde L, Foldspang A. (2004). Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: a pragmatic population-based 3-year intervention study. J Bone Miner Res.
151 Jackson RD, LaCroix AZ, Gass M, et al. (2006). Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med.
152 Porthouse J, Cockayne S, King C, et al. (2005). Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ.
153 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet.
154 Salovaara K, Tuppurainen M, Karkkainen M, et al. (2010). Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res.
155 Campbell IA, Douglas JG, Francis RM, et al. (2004). Five year study of etidronate and/or calcium as prevention and treatment for osteoporosis and fractures in patients with asthma receiving long term oral and/or inhaled glucocorticoids. Thorax.
156 Prince RL, Devine A, Dhaliwal SS, et al. (2006). Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med.
157 Frost RJ, Sonne C, Wehr U, et al. (2007). Effects of calcium supplementation on bone loss and fractures in congestive heart failure. Eur J Endocrinol.
158 Fujita T, Ohue M, Fujii Y, et al. (2004). Reappraisal of Katsuragi calcium study, a prospective, double-blind, placebo-controlled study of the effect of active absorbable algal calcium (AAACa) on vertebral deformity and fracture. J Bone Miner Metab.
159 Torres A, Garcia S, Gomez A, et al. (2004). Treatment with intermittent calcitriol and calcium reduces bone loss after renal transplantation. Kidney Int.
160 Retracted: Sato Y, Iwamoto J, Kanoko K, et al. (2005). Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis.
161 Shiraki M, Kushida K, Yamazaki K, et al. (1996). Effects of 2 years' treatment of osteoporosis with 1alphahydroxy vitamin D3 on bone mineral density and incidence of fracture: a placebo-controlled, double-blind prospective study. Endocr J.
162 Smith H, Anderson F, Raphael H, et al. (2007). Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology (Oxford).
163 Law M, Withers H, Morris J, et al. (2006). Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing.
164 Sanders KM, Stuart AL, Williamson EJ, et al. (2010). Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA.
165 Shea B, Wells G, Cranney A, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VII. Meta-analysis of calcium supplementation for the prevention of postmenopausal osteoporosis. Endocr Rev.
166 Meunier PJ, Roux C, Ortolani S, et al. (2009). Effects of long-term strontium ranelate treatment on vertebral fracture risk in postmenopausal women with osteoporosis. Osteoporos Int.
167 Chapuy MC, Arlot ME, Duboeuf F, et al. (1992). Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med.
168 Chapuy MC, Arlot ME, Delmas PD, et al. (1994). Effect of calcium and cholecalciferol treatment for three years on hip fractures in elderly women. BMJ.
169 Chapuy MC, Pamphile R, Paris E, et al. (2002). Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int.
170 Chevalley T, Rizzoli R, Nydegger V, et al. (1994). Effects of calcium supplements on femoral bone mineral density and vertebral fracture rate in vitamin-D-replete elderly patients. Osteoporos Int.
171 Dawson-Hughes B, Harris SS, Krall EA, et al. (1997). Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med.
172 Hansson T, Roos B. (1987). The effect of fluoride and calcium on spinal bone mineral content: a controlled, prospective (3 years) study. Calcif Tissue Int.
173 Harwood RH, Sahota O, Gaynor K, et al. (2004). A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing.
174 Peacock M, Liu G, Carey M, et al. (2000). Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab.
175 Prince R, Devine A, Dick I, et al. (1995). The effects of calcium supplementation (milk powder or tablets) and exercise on bone density in postmenopausal women. J Bone Miner Res.
176 Recker RR, Hinders S, Davies KM, et al. (1996). Correcting calcium nutritional deficiency prevents spine fractures in elderly women. J Bone Miner Res.
177 Reid IR, Ames RW, Evans MC, et al. (1993). Effect of calcium supplementation on bone loss in postmenopausal women. N Engl J Med.
178 Reid IR, Ames RW, Evans MC, et al. (1995). Long-term effects of calcium supplementation on bone loss and fractures in postmenopausal women: a randomized controlled trial. Am J Med.
179 Riggs BL, O'Fallon WM, Muhs J, et al. (1998). Long-term effects of calcium supplementation on serum parathyroid hormone level, bone turnover, and bone loss in elderly women. J Bone Miner Res.
180 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. (2005). Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA.
181 Papadimitropoulos E, Wells G, Shea B, et al. (2002). Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev.
182 Richy F, Ethgen O, Bruyere O, et al. (2004). Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int.
183 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. (2009). Prevention of nonvertebral fractures with oral vitamin D and dose dependency: a meta-analysis of randomized controlled trials. Arch Intern Med.
184 Jackson C, Gaugris S, Sen SS, et al. (2007). The effect of cholecalciferol (vitamin D3) on the risk of fall and fracture: a meta-analysis. QJM.
185 Adachi JD, Bensen WG, Bianchi F, et al. (1996). Vitamin D and calcium in the prevention of corticosteroid induced osteoporosis: a 3 year followup. J Rheumatol.
186 Aloia JF, Vaswani A, Ellis K, et al. (1985). A model for involutional bone loss. J Lab Clin Med.
187 Avenell A, Grant AM, McGee M, et al. (2004). The effects of an open design on trial participant recruitment, compliance and retention--a randomized controlled trial comparison with a blinded, placebo-controlled design. Clin Trials.
188 Baeksgaard L, Andersen KP, Hyldstrup L. (1998). Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int.
189 Bolton-Smith C, McMurdo ME, Paterson CR, et al. (2007). Two-year randomized controlled trial of vitamin K1 (phylloquinone) and vitamin D3 plus calcium on the bone health of older women. J Bone Miner Res.
190 Caniggia A, Delling G, Nuti R, et al. (1984). Clinical, biochemical and histological results of a double-blind trial with 1,25-dihydroxyvitamin D3, estradiol and placebo in post-menopausal osteoporosis. Acta Vitaminol Enzymol.
191 Dukas L, Bischoff HA, Lindpaintner LS, et al. (2004). Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc.
192 Ebeling PR, Russell RG. (2003). Teriparatide (rhPTH 1-34) for the treatment of osteoporosis. Int J Clin Pract.
193 Flicker L, MacInnis RJ, Stein MS, et al. (2005). Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. J Am Geriatr Soc.
194 Gallagher JC, Riggs BL, Recker RR, et al. (1989). The effect of calcitriol on patients with postmenopausal osteoporosis with special reference to fracture frequency. Proc Soc Exp Biol Med.
195 Gallagher JC, Goldgar D. (1990). Treatment of postmenopausal osteoporosis with high doses of synthetic calcitriol. A randomized controlled study. Ann Intern Med.
196 Gallagher JC, Fowler SE, Detter JR, et al. (2001). Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab.
197 Gorai I, Chaki O, Taguchi Y, et al. (1999). Early postmenopausal bone loss is prevented by estrogen and partially by 1alpha-OH-vitamin D3: therapeutic effects of estrogen and/or 1alpha-OH-vitamin D3. Calcif Tissue Int.
198 Geusens P, Dequeker J. (1986). Long-term effect of nandrolone decanoate, 1 alpha-hydroxyvitamin D3 or intermittent calcium infusion therapy on bone mineral content, bone remodeling and fracture rate in symptomatic osteoporosis: a double-blind controlled study. Bone Miner.
199 Hayashi Y, Fujita T, Inoue T. (1992). Decrease of vertebral fracture in osteoporotics by administration of 1a-hydroxy-vitamin D3. J Bone Miner Metab.
200 Jensen GF, Meinecke B, Boesen J, et al. (1985). Does 1,25(OH)2D3 accelerate spinal bone loss? A controlled therapeutic trial in 70-year-old women. Clin Orthop Relat Res.
201 Komulainen MH, Kroger H, Tuppurainen MT, et al. (1998). HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas.
202 Lips P, Graafmans WC, Ooms ME, et al. (1996). Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med.
203 Lyons RA, Johansen A, Brophy S, et al. (2007). Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int.
204 Menczel J, Foldes J, Steinberg R, et al. (1994). Alfacalcidol (alpha D3) and calcium in osteoporosis. Clin Orthop Relat Res.
205 Meyer HE, Smedshaug GB, Kvaavik E, et al. (2002). Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res.
206 Orimo H, Shiraki M, Hayashi T, et al. (1987). Reduced occurrence of vertebral crush fractures in senile osteoporosis treated with 1 alpha (OH)-vitamin D3. Bone Miner.
207 Orimo H, Shiraki M, Hayashi Y, et al. (1994). Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis. Calcif Tissue Int.
208 Ott SM, Chesnut CH. (1989). Calcitriol treatment is not effective in postmenopausal osteoporosis. Ann Intern Med.
209 Pfeifer M, Begerow B, Minne HW, et al. (2009). Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int.
210 Retracted: Sato Y, Kuno H, Kaji M, et al. (1999). Effect of ipriflavone on bone in elderly hemiplegic stroke patients with hypovitaminosis D. Am J Phys Med Rehabil.
211 Retracted: Sato Y, Manabe S, Kuno H, et al. (1999). Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson's disease. J Neurol Neurosurg Psychiatry.
212 Tilyard MW, Spears GF, Thomson J, et al. (1992). Treatment of postmenopausal osteoporosis with calcitriol or calcium. N Engl J Med.
213 Trivedi DP, Doll R, Khaw KT. (2003). Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ.
214 Ushiroyama T, Ikeda A, Sakai M, et al. (2001). Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas.
215 Korpelainen R, Keinanen-Kiukaanniemi S, Nieminen P, et al. (2010). Long-term outcomes of exercise: follow-up of a randomized trial in older women with osteopenia. Arch Intern Med.
216 Lock CA, Lecouturier J, Mason JM, et al. (2006). Lifestyle interventions to prevent osteoporotic fractures: a systematic review. Osteoporos Int.
217 Ebrahim S, Thompson PW, Baskaran V, et al. (1997). Randomized placebo-controlled trial of brisk walking in the prevention of postmenopausal osteoporosis. Age Ageing.
218 Jensen J, Lundin-Olsson L, Nyberg L, et al. (2002). Fall and injury prevention in older people living in residential care facilities. A cluster randomized trial. Ann Intern Med.
219 Preisinger E, Alacamlioglu Y, Pils K, et al. (1996). Exercise therapy for osteoporosis: results of a randomised controlled trial. Br J Sports Med.
220 Retracted: Sato Y, Metoki N, Iwamoto J, et al. (2003). Amelioration of osteoporosis and hypovitaminosis D by sunlight exposure in stroke patients. Neurology.
221 Sinaki M, Wahner HW, Offord KP, et al. (1989). Efficacy of nonloading exercises in prevention of vertebral bone loss in postmenopausal women: a controlled trial. Mayo Clin Proc.
222 Sinaki M, Itoi E, Wahner HW, et al. (2002). Stronger back muscles reduce the incidence of vertebral fractures: a prospective 10 year follow-up of postmenopausal women. Bone.
223 Vetter NJ, Lewis PA, Ford D. (1992). Can health visitors prevent fractures in elderly people?. BMJ.
224 Saag KG, Zanchetta JR, Devogelaer JP, et al. (2009). Effects of teriparatide versus alendronate for treating glucocorticoid-induced osteoporosis: Thirty-six-month results of a randomized, double-blind, controlled trial. Arthritis Rheum.
225 Okada Y, Nawata M, Nakayamada S, et al. (2008). Alendronate protects premenopausal women from bone loss and fracture associated with high-dose glucocorticoid therapy. J Rheumatol.
226 Bonnick S, Broy S, Kaiser F, et al. (2007). Treatment with alendronate plus calcium, alendronate alone, or calcium alone for postmenopausal low bone mineral density. Curr Med Res Opin.
227 Xia WB, Zhang ZL, Wang HF, et al. (2009). The efficacy and safety of calcitriol and/or Caltrate D in elderly Chinese women with low bone mass. Acta Pharmacol Sin.
228 Tauchmanova L, De Simone G, Musella T, et al. (2006). Effects of various antireabsorptive treatments on bone mineral density in hypogonadal young women after allogeneic stem cell transplantation. Bone Marrow Transplant.
229 Garcia-Delgado I, Prieto S, Gil-Fraquas L, et al. (1997). Calcitonin, etidronate, and calcidiol treatment in bone loss after cardiac transplantation. Calcif Tissue Int.
230 Lindsay R, Ste-Marie LG, Scheele WH. (2004). Bone mineral density changes during an 18 month observational period following discontinuation of recombinant human parathyroid humone (1-34) treatment of postmenopausal women receiving hormone replacement therapy. JAMA.
231 Campbell IA, Douglas JG, Francis RM, et al. (2009). Hormone replacement therapy (HRT) or etidronate for osteoporosis in postmenopausal asthmatics on glucocorticoids: a randomised factorial trial. Scott Med J.
232 Boutsen Y, Jamart J, Esselinckx W, et al. (1997). Primary prevention of glucocorticoid-induced osteoporosis with intermittent intravenous pamidronate: a randomized trial. Calcif Tissue Int.
233 Luckey M, Kagan R, Greenspan S, et al. (2004). Once-weekly alendronate 70 mg and raloxifene 60 mg daily in the treatment of postmenopausal osteoporosis. Menopause.
234 Uchida S, Taniguchi T, Shimizu T, et al. (2005). Therapeutic effects of alendronate 35 mg once weekly and 5 mg once daily in Japanese patients with osteoporosis: a double-blind, randomized study. J Bone Miner Metab.
235 Muscoso E, Puglisi N, Mamazza C, et al. (2004). Antiresorption therapy and reduction in fracture susceptibility in the osteoporotic elderly patient: open study. Eur Rev Med Pharmacol Sci.
236 Bonnick S, Saag KG, Kiel DP, et al. (2006). Comparison of Weekly Treatment of Postmenopausal Osteoporosis with Alendronate versus Risedronate Over Two Years. J Clin Endocrinol Metab.
237 Rosen CJ, Hochberg MC, Bonnick SL, et al. (2005). Treatment with once-weekly alendronate 70 mg compared with once-weekly risedronate 35 mg in women with postmenopausal osteoporosis: a randomized double-blind study. J Bone Miner Res.
238 Body JJ, Gaich GA, Scheele WH, et al. (2002). A randomized double-blind trial to compare the efficacy of teriparatide. J Clin Endocrinol Metab.
239 Pfeifer M, Begerow B, Minne HW, et al. (2000). Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res.
240 Black DM, Schwartz AV, Ensrud KE, et al. (2006). Effects of continuing or stopping alendronate after 5 years of treatment: the Fracture Intervention Trial Long-term Extension (FLEX): a randomized trial. JAMA.
241 Siris ES, Simon JA, Barton IP, et al. (2008). Effects of risedronate on fracture risk in postmenopausal women with osteopenia. Osteoporos Int.
242 Kanis JA, Johansson H, Oden A, et al. (2010). A meta-analysis of the efficacy of raloxifene on all clinical and vertebral fractures and its dependency on FRAX(R). Bone.
243 Schwartz AV, Bauer DC, Cummings SR, et al. (2010). Efficacy of continued alendronate for fractures in women with and without prevalent vertebral fracture: The FLEX trial. J Bone Miner Res.
244 Siris ES, Harris ST, Eastell R, et al. (2005). Skeletal effects of raloxifene after 8 years: results from the continuing outcomes relevant to Evista (CORE) study. J Bone Miner Res.
245 Sontag A, Wan X, Krege JH. (2009). Benefits and risks of raloxifene by vertebral fracture status. Curr Med Res Opin.
246 Prevrhal S, Krege JH, Chen P, et al. (2009). Teriparatide vertebral fracture risk reduction determined by quantitative and qualitative radiographic assessment. Current Medical Research and Opinion.
247 Boonen S, Klemes AB, Zhou X, et al. (2010). Assessment of the relationship between age and the effect of risedronate treatment in women with postmenopausal osteoporosis: a pooled analysis of four studies. J Am Geriatr Soc.
248 Boonen S, Black DM, Colon-Emeric CS, et al. (2010). Efficacy and safety of a once-yearly intravenous zoledronic acid 5 mg for fracture prevention in elderly postmenopausal women with osteoporosis aged 75 and older. J Am Geriatr Soc.
249 Eastell R, Black DM, Boonen S, et al. (2009). Effect of once-yearly zoledronic acid 5 mg on fracture risk and change in femoral neck bone mineral density. J Clin Endocrinol Metab.
250 Boonen S, Marin F, Mellstrom D, et al. (2006). Safety and efficacy of teriparatide in elderly women with established osteoporosis: bone anabolic therapy from a geriatric perspective. J Am Geriatr Soc.
251 Hwang JS, Chin LS, Chen JF, et al. (2010). The effects of intravenous zoledronic acid in Chinese women with postmenopausal osteoporosis. J Bone Miner Metab.
252 Nakamura T, Liu JL, Morii H, et al. (2006). Effect of raloxifene on clinical fractures in Asian women with postmenopausal osteoporosis. J Bone Miner Metab.
253 Warriner AH, Outman RC, Saag KG, et al. (2009). Management of osteoporosis among home health and long-term care patients with a prior fracture. South Med J.
254 Jamal SA, Bauer DC, Ensrud KE, et al. (2007). Alendronate treatment in women with normal to severely impaired renal function: an analysis of the fracture intervention trial. J Bone Miner Res.
255 Ishani A, Blackwell T, Jamal SA, et al. (2008). The effect of raloxifene treatment in postmenopausal women with CKD. J Am Soc Nephrol.
256 Miller PD, Schwartz EN, Chen P, et al. (2007). Teriparatide in postmenopausal women with osteoporosis and mild or moderate renal impairment. Osteoporos Int.
257 Eriksen EF, Lyles KW, Colon-Emeric CS, et al. (2009). Antifracture efficacy and reduction of mortality in relation to timing of the first dose of zoledronic acid after hip fracture. J Bone Miner Res.
258 Conwell LS, Chang AB. (2009). Bisphosphonates for osteoporosis in people with cystic fibrosis. Cochrane Database Syst Rev.
259 Cramer JA, Gold DT, Silverman SL, et al. (2007). A systematic review of persistence and compliance with bisphosphonates for osteoporosis. Osteoporos Int.
260 Imaz I, Zegarra P, Gonzalez-Enriquez J, et al. (2010). Poor bisphosphonate adherence for treatment of osteoporosis increases fracture risk: systematic review and meta-analysis. Osteoporos Int.
261 Kothawala P, Badamgarav E, Ryu S, et al. (2007). Systematic review and meta-analysis of real-world adherence to drug therapy for osteoporosis. Mayo Clin Proc.
262 Siris ES, Selby PL, Saag KG, et al. (2009). Impact of osteoporosis treatment adherence on fracture rates in North America and Europe. Am J Med.
263 Gleeson T, Iversen MD, Avorn J, et al. (2009). Interventions to improve adherence and persistence with osteoporosis medications: a systematic literature review. Osteoporos Int.
264 Binkley N, Ringe JD, Reed JI, et al. (2009). Alendronate/vitamin D3 70 mg/2800 IU with and without additional 2800 IU vitamin D3 for osteoporosis: results from the 24-week extension of a 15-week randomized, controlled trial. Bone.
265 Tseng LN, Sheu WH, Ho ES, et al. (2006). Effects of alendronate combined with hormone replacement therapy on osteoporotic postmenopausal Chinese women. Metabolism.
266 Anastasilakis AD, Goulis DG, Polyzos SA, et al. (2008). Head-to-head comparison of risedronate vs. teriparatide on bone turnover markers in women with postmenopausal osteoporosis: a randomised trial. Int J Clin Pract.
267 Delmas PD, Vrijens B, Eastell R, et al. (2007). Effect of monitoring bone turnover markers on persistence with risedronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
268 Binkley N, Martens MG, Silverman SL, et al. (2009). Improved GI tolerability with monthly ibandronate in women previously using weekly bisphosphonates. South Med J.
269 Bonnick SL, Silverman S, Tanner SB, et al. (2009). Patient Satisfaction in Postmenopausal Women Treated with a Weekly Bisphosphonate Transitioned to Once-Monthly Ibandronate. J Womens Health (Larchmt).
270 Gorai I, Tanaka Y, Hattori S, et al. (2009). Assessment of adherence to treatment of postmenopausal osteoporosis with raloxifene and/or alfacalcidol in postmenopausal Japanese women. J Bone Miner Metab.
271 Adachi JD, Hanley DA, Lorraine JK, et al. (2007). Assessing compliance, acceptance, and tolerability of teriparatide in patients with osteoporosis who fractured while on antiresorptive treatment or were intolerant to previous antiresorptive treatment: an 18-month, multicenter, open-label, prospective study. Clin Ther.
272 Fogelman I, Fordham JN, Fraser WD, et al. (2008). Parathyroid hormone(1-84) treatment of postmenopausal women with low bone mass receiving hormone replacement therapy. Calcif Tissue Int.
273 Karkkainen M, Tuppurainen M, Salovaara K, et al. (2010). Effect of calcium and vitamin D supplementation on bone mineral density in women aged 65-71 years: a 3-year randomized population-based trial (OSTPRE-FPS). Osteoporos Int.
274 Orwoll ES, Miller PD, Adachi JD, et al. (2010). Efficacy and safety of a once-yearly i.v. Infusion of zoledronic acid 5 mg versus a once-weekly 70-mg oral alendronate in the treatment of male osteoporosis: a randomized, multicenter, double-blind, active-controlled study. J Bone Miner Res.
275 Brown JP, Prince RL, Deal C, et al. (2009). Comparison of the effect of denosumab and alendronate on BMD and biochemical markers of bone turnover in postmenopausal women with low bone mass: a randomized, blinded, phase 3 trial. J Bone Miner Res.
276 Kendler DL, McClung MR, Freemantle N, et al. (2010). Adherence, preference, and satisfaction of postmenopausal women taking denosumab or alendronate. Osteoporos Int.
277 Blouin J, Dragomir A, Moride Y, et al. (2008). Impact of noncompliance with alendronate and risedronate on the incidence of nonvertebral osteoporotic fractures in elderly women. Br J Clin Pharmacol.
278 Hansen KE, Swenson ED, Baltz B, et al. (2008). Adherence to alendronate in male veterans. Osteoporos Int.
279 Penning-van Beest FJ, Erkens JA, Olson M, et al. (2008). Loss of treatment benefit due to low compliance with bisphosphonate therapy. Osteoporos Int.
280 Penning-van Beest FJ, Erkens JA, Olson M, et al. (2008). Determinants of non-compliance with bisphosphonates in women with postmenopausal osteoporosis. Curr Med Res Opin.
281 Briesacher BA, Andrade SE, Harrold LR, et al. (2010). Adoption of once-monthly oral bisphosphonates and the impact on adherence. Am J Med.
282 Curtis JR, Westfall AO, Cheng H, et al. (2008). Benefit of adherence with bisphosphonates depends on age and fracture type: results from an analysis of 101,038 new bisphosphonate users. J Bone Miner Res.
283 Vytrisalova M, Blazkova S, Palicka V, et al. (2008). Self-reported compliance with osteoporosis medication-qualitative aspects and correlates. Maturitas.
284 Palacios S, Sanchez-Borrego R, Neyro JL, et al. (2009). Knowledge and compliance from patients with postmenopausal osteoporosis treatment. Menopause Int.
285 Grazio S, Babic-Naglic D, Kehler T, et al. (2008). Persistence of weekly alendronate: a real-world study in Croatia. Clin Rheumatol.
286 Feldstein AC, Weycker D, Nichols GA, et al. (2009). Effectiveness of bisphosphonate therapy in a community setting. Bone.
287 Yood RA, Emani S, Reed JI, et al. (2003). Compliance with pharmacologic therapy for osteoporosis. Osteoporos Int.
288 Ringe JD, Moller G. (2009). Differences in persistence, safety and efficacy of generic and original branded once weekly bisphosphonates in patients with postmenopausal osteoporosis: 1-year results of a retrospective patient chart review analysis. Rheumatol Int.
289 Sewerynek E, Dabrowska K, Skowronska-Jozwiak E, et al. (2009). Compliance with alendronate 10 treatment in elderly women with postmenopausal osteoporosis. Endokrynol Pol.
290 Ideguchi H, Ohno S, Takase K, et al. (2008). Outcomes after switching from one bisphosphonate to another in 146 patients at a single university hospital. Osteoporos Int.
291 Ettinger MP, Gallagher R, MacCosbe PE. (2006). Medication persistence with weekly versus daily doses of orally administered bisphosphonates. Endocr Pract.
292 Gold DT, Martin BC, Frytak JR, et al. (2007). A claims database analysis of persistence with alendronate therapy and fracture risk in post-menopausal women with osteoporosis. Curr Med Res Opin.
293 Harris ST, Reginster JY, Harley C, et al. (2009). Risk of fracture in women treated with monthly oral ibandronate or weekly bisphosphonates: the eValuation of IBandronate Efficacy (VIBE) database fracture study. Bone.
294 Ideguchi H, Ohno S, Hattori H, et al. (2007). Persistence with bisphosphonate therapy including treatment courses with multiple sequential bisphosphonates in the real world. Osteoporos Int.
295 Jones TJ, Petrella RJ, Crilly R. (2008). Determinants of persistence with weekly bisphosphonates in patients with osteoporosis. J Rheumatol.
296 Sheehy O, Kindundu CM, Barbeau M, et al. (2009). Differences in persistence among different weekly oral bisphosphonate medications. Osteoporos Int.
297 Weiss TW, Henderson SC, McHorney CA, et al. (2007). Persistence across weekly and monthly bisphosphonates: analysis of US retail pharmacy prescription refills. Curr Med Res Opin.
298 McHorney CA, Schousboe JT, Cline RR, et al. (2007). The impact of osteoporosis medication beliefs and side-effect experiences on non-adherence to oral bisphosphonates. Curr Med Res Opin.
299 Ringe JD, Christodoulakos GE, Mellstrom D, et al. (2007). Patient compliance with alendronate, risedronate and raloxifene for the treatment of osteoporosis in postmenopausal women. Curr Med Res Opin.
300 Gallagher AM, Rietbrock S, Olson M, et al. (2008). Fracture outcomes related to persistence and compliance with oral bisphosphonates. J Bone Miner Res.
301 Roughead EE, Ramsay E, Priess K, et al. (2009). Medication adherence, first episode duration, overall duration and time without therapy: The example of bisphosphonates. Pharmacoepidemiol Drug Saf.
302 Abrahamsen B, Eiken P, Eastell R. (2009). Subtrochanteric and diaphyseal femur fractures in patients treated with alendronate: a register-based national cohort study. J Bone Miner Res.
303 Blouin J, Dragomir A, Ste-Marie LG, et al. (2007). Discontinuation of antiresorptive therapies: a comparison between 1998-2001 and 2002-2004 among osteoporotic women. J Clin Endocrinol Metab.
304 Briesacher BA, Andrade SE, Yood RA, et al. (2007). Consequences of poor compliance with bisphosphonates. Bone.
305 Cotte FE, Fardellone P, Mercier F, et al. (2009). Adherence to monthly and weekly oral bisphosphonates in women with osteoporosis. Osteoporos Int.
306 Cramer JA, Lynch NO, Gaudin AF, et al. (2006). The effect of dosing frequency on compliance and persistence with bisphosphonate therapy in postmenopausal women: a comparison of studies in the United States, the United Kingdom, and France. Clin Ther.
307 Gold DT, Safi W, Trinh H. (2006). Patient preference and adherence: comparative US studies between two bisphosphonates, weekly risedronate and monthly ibandronate. Curr Med Res Opin.
308 Gold DT, Trinh H, Safi W. (2009). Weekly versus monthly drug regimens: 1-year compliance and persistence with bisphosphonate therapy. Curr Med Res Opin.
309 Kertes J, Dushenat M, Vesterman JL, et al. (2008). Factors contributing to compliance with osteoporosis medication. Isr Med Assoc J.
310 Rabenda V, Vanoverloop J, Fabri V, et al. (2008). Low incidence of anti-osteoporosis treatment after hip fracture. J Bone Joint Surg Am.
311 van den Boogaard CH, Breekveldt-Postma NS, Borggreve SE, et al. (2006). Persistent bisphosphonate use and the risk of osteoporotic fractures in clinical practice: a database analysis study. Curr Med Res Opin.
312 Hoer A, Seidlitz C, Gothe H, et al. (2009). Influence on persistence and adherence with oral bisphosphonates on fracture rates in osteoporosis. Patient Prefer Adherence.
313 Rabenda V, Mertens R, Fabri V, et al. (2008). Adherence to bisphosphonates therapy and hip fracture risk in osteoporotic women. Osteoporos Int.
314 Castelo-Branco C, Cortes X, Ferrer M. (2009). Treatment persistence and compliance with a combination of calcium and vitamin D. Climacteric.
315 Dugard MN, Jones TJ, Davie MW. (2009). Uptake of treatment for osteoporosis and compliance after bone density measurement in the community. J Epidemiol Community Health.
316 Kamatari M, Koto S, Ozawa N, et al. (2007). Factors affecting long-term compliance of osteoporotic patients with bisphosphonate treatment and QOL assessment in actual practice: alendronate and risedronate. J Bone Miner Metab.
317 Berecki-Gisolf J, Hockey R, Dobson A. (2008). Adherence to bisphosphonate treatment by elderly women. Menopause.
318 Solomon DH, Brookhart MA, Tsao P, et al. (2010). Predictors of very low adherence with medications for osteoporosis: towards development of a clinical prediction rule. Osteoporos Int.
319 Siris ES, Pasquale MK, Wang Y, et al. (2010). Estimating bisphosphonate use and fracture reduction among U.S. women age 45 and older, 2001-2008. J Bone Miner Res.
320 Huas D, Debiais F, Blotman F, et al. (2010). Compliance and treatment satisfaction of post menopausal women treated for osteoporosis. Compliance with osteoporosis treatment. BMC Womens Health.
321 Copher R, Buzinec P, Zarotsky V, et al. (2010). Physician perception of patient adherence compared to patient adherence of osteoporosis medications from pharmacy claims. Curr Med Res Opin.
322 Cadarette SM, Solomon DH, Katz JN, et al. (2010). Adherence to osteoporosis drugs and fracture prevention: no evidence of healthy adherer bias in a frail cohort of seniors. Osteoporos Int.
323 Briesacher BA, Andrade SE, Harrold LR, et al. (2010). Adherence and occurrence of fractures after switching to once-monthly oral bisphophonates. Pharmacoepidemiol Drug Saf.
324 Berry SD, Misra D, Hannan MT, et al. (2010). Low acceptance of treatment in the elderly for the secondary prevention of osteoporotic fracture in the acute rehabilitation setting. Aging Clin Exp Res.
325 Boonen S, Kay R, Cooper C, et al. (2009). Osteoporosis management: a perspective based on bisphosphonate data from randomised clinical trials and observational databases. Int J Clin Pract.
326 Cosman F, Wermers RA, Recknor C, et al. (2010). Effects of teriparatide in postmenopausal women with osteoporosis on prior alendronate or raloxifene: Differences between stopping and continuing the antiresorptive agent: Editorial Comment. Obstetrical and Gynecological Survey.
327 Tosteson AN, Do TP, Wade SW, et al. (2010). Persistence and switching patterns among women with varied osteoporosis medication histories: 12-month results from POSSIBLE US. Osteoporos Int.
328 Iwamoto J, Miyata A, Sato Y, et al. (2009). Factors affecting discontinuation of alendronate treatment in postmenopausal Japanese women with osteoporosis. J Chin Med Assoc.
329 Ziller V, Wetzel K, Kyvernitakis I, et al. (2010). Adherence and persistence in patients with postmenopausal osteoporosis treated with raloxifene. Climacteric.
330 Netelenbos JC, Geusens PP, Ypma G, et al. (2010). Adherence and profile of non-persistence in patients treated for osteoporosis-a large-scale, long-term retrospective study in The Netherlands. Osteoporos Int.
331 Foster SA, Foley KA, Meadows ES, et al. (2010). Adherence and persistence with teriparatide among patients with commercial, Medicare, and Medicaid insurance. Osteoporos Int.
332 Schousboe JT, Dowd BE, Davison ML, et al. (2010). Association of medication attitudes with non-persistence and non-compliance with medication to prevent fractures. Osteoporos Int.
333 Halpern R, Becker L, Iqbal SU, et al. (2011). The association of adherence to osteoporosis therapies with fracture, all-cause medical costs, and all-cause hospitalizations: a retrospective claims analysis of female health plan enrollees with osteoporosis. J Manag Care Pharm.
334 Ferrari S, Nakamura T, Hagino H, et al. (2011). Longitudinal change in hip fracture incidence after starting risedronate or raloxifene: an observational study. J Bone Miner Metab.
335 Park D, J TR. (1997). Medication Adherence and Aging. Fisk A, R WA, editors. Handbook of Human Factors and the Older Adult.
336 McCarney R, W J, Iliffe S, van Haselen R, Griffin M, Fisher P. (2007). The Hawthorne Effect: a randomised, controlled trial. BMC Med Res Methodol.
337 Claxton AJ, C J, Pierce C. (2001). A systematic review of the associations between dose regimens and medication compliance. Clin Ther.
338 Ingersoll KS, C J. (2008). The impact of medication regimen factors on adherence to chronic treatment: a review of literature. J Behav Med.
339 Iskedjian M, E TR, MacKeigan LD, Shear N, Addis A, Mittmann N, Ilersich AL. (2002). Relationship between daily dose frequency and adherence to antihypertensive pharmacotherapy: evidence from a meta-analysis. Clin Ther.
340 Saini SD, S P, Kaulback K, Dubinsky MC. (2009). Effect of medication dosing frequency on adherence in chronic diseases. Am J Manag Care.
341 Landfeldt E, Strom O, Robbins S, et al. (2011). Adherence to treatment of primary osteoporosis and its association to fractures-the Swedish Adherence Register Analysis (SARA). Osteoporos Int.
342 Binkley N, Krueger D. (2005). Combination therapy for osteoporosis: considerations and controversy. Curr Osteoporos Rep.
343 Huybrechts KF, Ishak KJ, Caro JJ. (2006). Assessment of compliance with osteoporosis treatment and its consequences in a managed care population. Bone.
344 Caro JJ, Ishak KJ, Huybrechts KF, et al. (2004). The impact of compliance with osteoporosis therapy on fracture rates in actual practice. Osteoporos Int.
345 Curtis JR, Delzell E, Chen L, et al. (2010). The relationship between bisphosphonate adherence and fracture: Is it the behavior or the medication? results from the placebo arm of the fracture intervention trial. J Bone Miner Res.
346 Hadji P, Claus V, Ziller V, et al. (2011). GRAND: the German retrospective cohort analysis on compliance and persistence and the associated risk of fractures in osteoporotic women treated with oral bisphosphonates. Osteoporos Int.
347 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, et al. (2003). Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. Journal of bone and mineral metabolism.
348 Palomba S, Orio F, Colao A, et al. (2002). Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
349 Riis BJ, Ise J, von Stein T, et al. (2001). Ibandronate: a comparison of oral daily dosing versus intermittent dosing in postmenopausal osteoporosis. J Bone Miner Res.
350 Zegels B, Eastell R, Russell RG, et al. (2001). Effect of high doses of oral risedronate (20 mg/day) on serum parathyroid hormone levels and urinary collagen cross-link excretion in postmenopausal women with spinal osteoporosis. Bone.
351 Agrawal S, Krueger DC, Engelke JA, et al. (2006). Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc.
352 Cummings SR, Schwartz AV, Black DM. (2007). Alendronate and atrial fibrillation. N Engl J Med.
353 Barrett-Connor E, Swern AS, Hustad CM, et al. (2011). Alendronate and atrial fibrillation: a meta-analysis of randomized placebo-controlled clinical trials. Osteoporos Int.
354 Lewiecki EM, Cooper C, Thompson E, et al. (2010). Ibandronate does not increase risk of atrial fibrillation in analysis of pivotal clinical trials. Int J Clin Pract.
355 Loke YK, Jeevanantham V, Singh S. (2009). Bisphosphonates and atrial fibrillation: systematic review and meta-analysis. Drug Saf.
356 Bhuriya R, Singh M, Molnar J, et al. (2010). Bisphosphonate use in women and the risk of atrial fibrillation: A systematic review and meta-analysis. Int J Cardiol.
357 Mak A, Cheung MW, Ho RC, et al. (2009). Bisphosphonates and atrial fibrillation: Bayesian meta-analyses of randomized controlled trials and observational studies. BMC Musculoskelet Disord.
358 Kim SY, Kim MJ, Cadarette SM, et al. (2010). Bisphosphonates and risk of atrial fibrillation: a meta-analysis. Arthritis Res Ther.
359 Howard PA, Barnes BJ, Vacek JL, et al. (2010). Impact of bisphosphonates on the risk of atrial fibrillation. American Journal of Cardiovascular Drugs.
360 (2008). Update of Safety Review Follow-up to the October 1, 2007 Early Communication about the Ongoing Safety Review of Bisphosphonates.
361 Adachi JD, Faraawi RY, O'Mahony MF, et al. (2009). Upper gastrointestinal tolerability of alendronate sodium monohydrate 10 mg once daily in postmenopausal women: a 12-week, randomized, double-blind, placebo-controlled, exploratory study. Clin Ther.
362 Green J, Czanner G, Reeves G, et al. (2010). Oral bisphosphonates and risk of cancer of oesophagus, stomach, and colorectum: case-control analysis within a UK primary care cohort. BMJ.
363 Cardwell CR, Abnet CC, Cantwell MM, et al. (2010). Exposure to oral bisphosphonates and risk of esophageal cancer. JAMA.
364 Wright E, Seed PT, Schofield P, et al. (2010). Bisphosphonates and cancer More data using same database. BMJ.
365 Nguyen DM, Schwartz J, Richardson P, et al. (2010). Oral Bisphosphonate Prescriptions and the Risk of Esophageal Adenocarcinoma in Patients with Barrett's Esophagus. Dig Dis Sci.
366 McClung MR, Wasnich RD, Recker R, et al. (2004). Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res.
367 Adachi JD, Adami S, Miller PD, et al. (2001). Tolerability of risedronate in postmenopausal women intolerant of alendronate. Aging (Milano).
368 Chow CC, Chan WB, Li JK, et al. (2003). Oral alendronate increases bone mineral density in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
369 Saag KG, Emkey R, Schnitzer TJ, et al. (1998). Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med.
370 Sambrook PN, Rodriguez JP, Wasnich RD, et al. (2004). Alendronate in the prevention of osteoporosis: 7-year follow-up. Osteoporos Intl.
371 Ensrud KE, Barrett-Connor EL, Schwartz A, et al. (2004). Randomized trial of effect of alendronate continuation versus discontinuation in women with low BMD: results from the Fracture Intervention Trial long-term extension. J Bone Miner Res.
372 Uusi-Rasi K, Kannus P, Cheng S, et al. (2003). Effect of alendronate and exercise on bone and physical performance of postmenopausal women: a randomized controlled trial. Bone.
373 Greenspan S, Field-Munves E, Tonino R, et al. (2002). Tolerability of once-weekly alendronate in patients with osteoporosis: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc.
374 Kung AW, Yeung SS, Chu LW. (2000). The efficacy and tolerability of alendronate in postmenopausal osteoporotic Chinese women: a randomized placebo-controlled study. Calcif Tissue Int.
375 Bauer DC, Black D, Ensrud K, et al. (2000). Upper gastrointestinal tract safety profile of alendronate: the fracture intervention trial. Arch Intern Med.
376 Cryer B, Binkley N, Simonelli C, et al. (2005). A randomized, placebo-controlled, 6-month study of once-weekly alendronate oral solution for postmenopausal osteoporosis. Am J Geriatr Pharmacother.
377 Eastell R, Devogelaer JP, Peel NF, et al. (2000). Prevention of bone loss with risedronate in glucocorticoid-treated rheumatoid arthritis patients. Osteoporos Int.
378 Ilter E, Karalok H, Tufekci EC, et al. (2006). Efficacy and acceptability of risedronate 5 mg daily compared with 35 mg once weekly for the treatment of postmenopausal osteoporosis. Climacteric.
379 Tucci JR, Tonino RP, Emky RD, et al. (1996). Effect of three years of oral alendronate treatment in postmenopausal women with osteoproris. Am J Med.
380 Adachi JD, Saag KG, Delmas PD, et al. (2001). Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum.
381 Rossini M, Gatti D, Girardello S, et al. (2000). Effects of two intermittent alendronate regimens in the prevention or treatment of postmenopausal osteoporosis. Bone.
382 Eisman JA, Rizzoli R, Roman-Ivorra J, et al. (2004). Upper gastrointestinal and overall tolerability of alendronate once weekly in patients with osteoporosis: results of a randomized, double-blind, placebo-controlled study. Curr Med Res Opin.
383 Murphy MG, Weiss S, McClung M, et al. (2001). Effect of alendronate and MK-677 (a growth hormone secretagogue), individually and in combination, on markers of bone turnover and bone mineral density in postmenopausal osteoporotic women. JCEM.
384 Henderson S, Hoffman N, Prince R. (2006). A double-blind placebo-controlled study of the effects of the bisphosphonate risedronate on bone mass in patients with inflammatory bowel disease. Am J Gastroenterol.
385 Johnell O, Scheele WH, Lu Y, et al. (2002). Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
386 Tonino RP, Meunier PJ, Emkey R, et al. (2000). Skeletal benefits of alendronate: 7-year treatment of postmenopausal osteoporotic women. Phase III Osteoporosis Treatment Study Group. J Clin Endocrinol Metab.
387 Torregrosa JV, Moreno A, Gutierrez A, et al. (2003). Alendronate for treatment of renal transplant patients with osteoporosis. Transplantation proceedings.
388 Bell NH, Bilezikian JP, Bone HG, et al. (2002). Alendronate increases bone mass and reduces bone markers in postmenopausal African-American women. JCEM.
389 Sharma RK, Kaushal R, Gupta A, et al. (2002). Role of oral alendronate in prevention of bone loss in adult nephrotics on steroid treatment. Indian J Nephrol.
390 Lau EM, Woo J, Chan YH, et al. (2001). Alendronate for the prevention of bone loss in patients on inhaled steroid therapy. Bone.
391 Haderslev KV, Tjellesen L, Sorensen HA, et al. (2000). Alendronate increases lumbar spine bone mineral density in patients with Crohn's disease. Gastroenterology.
392 Lau EM, Woo J, Chan YH, et al. (2000). Alendronate prevents bone loss in Chinese women with osteoporosis. Bone.
393 Downs RW, Bell NH, Ettinger MP, et al. (2000). Comparison of alendronate and intranasal calcitonin for treatment of osteoporosis in postmenopausal women. J Clin Endocrinol Metab.
394 Miller PD, Woodson G, Licata AA, et al. (2000). Rechallenge of patients who had discontinued alendronate therapy because of upper gastrointestinal symptoms. Clinical therapeutics.
395 Yang TS, Tsan SH, Chen CR, et al. (1998). Effects of alendronate on bone turnover markers in early postmenopausal women. Zhonghua Yi Xue Za Zhi (Taipei).
396 Frediani B, Allegri A, Bisogno S, et al. (1998). Effects of combined treatment with calcitriol plus alendronate on bone mass and bone turnover in postmenopausal osteoporosis: Two years of continuous treatment. Clinical Drug Investigation.
397 Devogelaer JP, Broll H, Correa-Rotter R, et al. (1996). Oral alendronate induces progressive increases in bone mass of the spine, hip, and total body over 3 years in postmenopausal women with osteoporosis. Bone.
398 Harris ST, Gertz BJ, Genant HK, et al. (1993). The effect of short term treatment with alendronate on vertebral density and biochemical markers of bone remodeling in early postmenopausal women. J Clin Endocrinol Metab.
399 Adami S, Baroni MC, Broggini M, et al. (1993). Treatment of postmenopausal osteoporosis with continuous daily oral alendronate in comparison with either placebo or intranasal salmon calcitonin. Osteoporos Int.
400 Cryer B, Miller P, Petruschke RA, et al. (2005). Upper gastrointestinal tolerability of once weekly alendronate 70 mg with concomitant non-steroidal anti-inflammatory drug use. Aliment Pharmacol Ther.
401 Morabito N, Lasco A, Gaudio A, et al. (2002). Bisphosphonates in the treatment of thalassemia-induced osteoporosis. Osteoporos Int.
402 El-Agroudy AE, El-Husseini AA, El-Sayed M, et al. (2005). A prospective randomized study for prevention of postrenal transplantation bone loss. Kidney Int.
403 Golden NH, Iglesias EA, Jacobson MS, et al. (2005). Alendronate for the treatment of osteopenia in anorexia nervosa: a randomized, double-blind, placebo-controlled trial. J Clin Endocrinol Metab.
404 Moran de Brito CM, Battistella LR, Saito ET, et al. (2005). Effect of alendronate on bone mineral density in spinal cord injury patients: a pilot study. Spinal Cord.
405 Aris RM, Lester GE, Caminiti M, et al. (2004). Efficacy of alendronate in adults with cystic fibrosis with low bone density. Am J Respir Crit Care Med.
406 Michalska D, Stepan JJ, Basson BR, et al. (2006). The effect of raloxifene after discontinuation of long-term alendronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab.
407 Sambrook PN, Geusens P, Ribot C, et al. (2004). Alendronate produces greater effects than raloxifene on bone density and bone turnover in postmenopausal women with low bone density: results of EFFECT (Efficacy of FOSAMAX versus EVISTA Comparison Trial) International. J Intern Med.
408 Recker RR, Kendler D, Recknor CP, et al. (2006). Comparative effects of raloxifene and alendronate on fracture outcomes in postmenopausal women with low bone mass. Bone.
409 Sanad Z, Ellakwa H, Desouky B. (2011). Comparison of alendronate and raloxifene in postmenopausal women with osteoporosis. Climacteric.
410 Adami S, Felsenberg D, Christiansen C, et al. (2004). Efficacy and safety of ibandronate given by intravenous injection once every 3 months. Bone.
411 Orwoll ES, Binkley NC, Lewiecki EM, et al. (2010). Efficacy and safety of monthly ibandronate in men with low bone density. Bone.
412 Reginster JY, Wilson KM, Dumont E, et al. (2005). Monthly oral ibandronate is well tolerated and efficacious in postmenopausal women: results from the monthly oral pilot study. J Clin Endocrinol Metab.
413 Tanko LB, Felsenberg D, Czerwinski E, et al. (2003). Oral weekly ibandronate prevents bone loss in postmenopausal women. Journal of internal medicine.
414 Thiebaud D, Burckhardt P, Kriegbaum H, et al. (1997). Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis. Am J Med.
415 Shiraki M, Fukunaga M, Kushida K, et al. (2003). A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int.
416 McClung MR, Wasnich RD, Hosking DJ, et al. (2004). Prevention of postmenopausal bone loss: six-year results from the Early Postmenopausal Intervention Cohort Study. J Clin Endocrinol Metab.
417 Smith MR, Eastham J, Gleason DM, et al. (2003). Randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. J Uro.
418 Grey A, Bolland M, Wattie D, et al. (2010). Prolonged antiresorptive activity of zoledronate: A randomized, controlled trial. J Bone Miner Res.
419 McClung MR, San Martin J, Miller PD, et al. (2005). Opposite bone remodeling effects of teriparatide and alendronate in increasing bone mass. Arch Intern Med.
420 Stakkestad JA, Benevolenskaya LI, Stepan JJ, et al. (2003). Intravenous ibandronate injections given every three months: a new treatment option to prevent bone loss in postmenopausal women. Ann Rheum Dis.
421 McClung M, Miller P, Recknor C, et al. (2009). Zoledronic acid for the prevention of bone loss in postmenopausal women with low bone mass: a randomized controlled trial. Obstet Gynecol.
422 Black DM, Kelly MP, Genant HK, et al. (2010). Bisphosphonates and Fractures of the Subtrochanteric or Diaphyseal Femur. N Engl J Med.
423 Girgis CM, Sher D, Seibel MJ. (2010). Atypical femoral fractures and bisphosphonate use. N Engl J Med.
424 Shane E, Burr D, Ebeling PR, et al. (2010). Atypical subtrochanteric and diaphyseal femoral fractures: Report of a task force of the American Society for Bone and Mineral Research. J Bone Miner Res.
425 US Food and Drug Administration (FDA). (2010). FDA Drug Safety Communication: Safety update for osteoporosis drugs, bisphosphonates, and atypical fractures.
426 Solomon DH, Hochberg MC, Mogun H, et al. (2009). The relation between bisphosphonate use and non-union of fractures of the humerus in older adults. Osteoporos Int.
427 Giusti A, Hamdy NAT, Papapoulos SE. (2010). Atypical fractures of the femur and bisphosphonate therapy. A systematic review of case/case series studies. Bone.
428 Park-Wyllie LY, Mamdani MM, Juurlink DN, et al. (2011). Bisphosphonate use and the risk of subtrochanteric or femoral shaft fractures in older women. JAMA.
429 Wang Z, Bhattacharyya T. (2011). Trends in Incidence of Subtrochanteric Fragility Fractures and Bisphosphonate Use Among the US Elderly, 1996-2007. J Bone Miner Res.
430 Abrahamsen B, Eiken P, Eastell R. (2010). Cumulative Alendronate Dose and the Long-Term Absolute Risk of Subtrochanteric and Diaphyseal Femur Fractures: A Register-Based National Cohort Analysis. J Clin Endocrinol Metab.
431 Vestergaard P, Schwartz F, Rejnmark L, et al. (2011). Risk of femoral shaft and subtrochanteric fractures among users of bisphosphonates and raloxifene. Osteoporos Int.
432 Kim SY, Schneeweiss S, Katz JN, et al. (2010). Oral bisphosphonates and risk of subtrochanteric or diaphyseal femur fractures in a population-based cohort. J Bone Miner Res.
433 Abrahamsen B. (2010). Bisphosphonate adverse effects, lessons from large databases. Curr Opin Rheumatol.
434 Lo JC, O'Ryan FS, Gordon NP, et al. (2010). Prevalence of osteonecrosis of the jaw in patients with oral bisphosphonate exposure. J Oral Maxillofac Surg.
435 Grbic JT, Landesberg R, Lin SQ, et al. (2008). Incidence of osteonecrosis of the jaw in women with postmenopausal osteoporosis in the health outcomes and reduced incidence with zoledronic acid once yearly pivotal fracture trial. J Am Dent Assoc.
436 Grbic JT, Black DM, Lyles KW, et al. (2010). The incidence of osteonecrosis of the jaw in patients receiving 5 milligrams of zoledronic acid: data from the health outcomes and reduced incidence with zoledronic acid once yearly clinical trials program. J Am Dent Assoc.
437 Khan AA, Sandor GK, Dore E, et al. (2009). Bisphosphonate associated osteonecrosis of the jaw. J Rheumatol.
438 Colon-Emeric C, Nordsletten L, Olson S, et al. (2010). Association between timing of zoledronic acid infusion and hip fracture healing. Osteoporos Int.
439 Crawford BA, Kam C, Pavlovic J, et al. (2006). Zoledronic acid prevents bone loss after liver transplantation: a randomized, double-blind, placebo-controlled trial. Ann Intern Med.
440 Grady D, Ettinger B, Moscarelli E, et al. (2004). Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol.
441 Zheng S, Wu Y, Zhang Z, et al. (2003). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in postmenopausal women: a randomized clinical trial in Beijing. Chin Med J (Engl).
442 Ensrud K, Genazzani AR, Geiger MJ, et al. (2006). Effect of raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am J Cardiol.
443 Mosca L, Grady D, Barrett-Connor E, et al. (2009). Effect of raloxifene on stroke and venous thromboembolism according to subgroups in postmenopausal women at increased risk of coronary heart disease. Stroke.
444 Miller PD, Chines AA, Christiansen C, et al. (2008). Effects of bazedoxifene on BMD and bone turnover in postmenopausal women: 2-yr results of a randomized, double-blind, placebo-, and active-controlled study. J Bone Miner Res.
445 Liu JL, Zhu HM, Huang QR, et al. (2004). Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serum lipids in Chinese postmenopausal women with osteoporosis: a multi-center, randomized, placebo-controlled clinical trial. Chin Med J (Engl).
446 Smith MR, Fallon MA, Lee H, et al. (2004). Raloxifene to prevent gonadotropin-releasing hormone agonist-induced bone loss in men with prostate cancer: a randomized controlled trial. JCEM.
447 Johnston CC, Bjarnason NH, Cohen FJ, et al. (2000). Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med.
448 Meunier PJ, Vignot E, Garnero P, et al. (1999). Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int.
449 McClung MR, Siris E, Cummings S, et al. (2006). Prevention of bone loss in postmenopausal women treated with lasofoxifene compared with raloxifene. Menopause.
450 Morii H, Ohashi Y, Taketani Y, et al. (2003). Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int.
451 Rubin MR, Lee KH, McMahon DJ, et al. (2003). Raloxifene lowers serum calcium and markers of bone turnover in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab.
452 Delmas PD, Bjarnason NH, Mitlak BH, et al. (1997). Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med.
453 Doran PM, Riggs BL, Atkinson EJ, et al. (2001). Effects of raloxifene, a selective estrogen receptor modulator, on bone turnover markers and serum sex steroid and lipid levels in elderly men. J Bone Miner Res.
454 Draper MW, Flowers DE, Huster WJ, et al. (1996). A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women. J Bone Miner Res.
455 Freedman M, San Martin J, O'Gorman J, et al. (2001). Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J Natl Cancer Inst.
456 Mok CC, Ying KY, To CH, et al. (2010). Raloxifene for prevention of glucocorticoid-induced bone loss: a 12-month randomised double-blinded placebo-controlled trial. Ann Rheum Dis.
457 Kung AW, Chao HT, Huang KE, et al. (2003). Efficacy and safety of raloxifene 60 milligrams/day in postmenopausal Asian women. J Clin Endocrinol Metab.
458 Jolly EE, Bjarnason NH, Neven P, et al. (2003). Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause.
459 Nickelsen T, Lufkin EG, Riggs BL, et al. (1999). Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology.
460 Miller PD, Bilezikian JP, Diaz-Curiel M, et al. (2007). Occurrence of hypercalciuria in patients with osteoporosis treated with teriparatide. J Clin Endocrinol Metab.
461 Chlebowski RT, Kuller LH, Prentice RL, et al. (2009). Breast cancer after use of estrogen plus progestin in postmenopausal women. N Engl J Med.
462 Chlebowski RT, Anderson GL, Gass M, et al. (2010). Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA.
463 Bekker PJ, Holloway DL, Rasmussen AS, et al. (2004). A single-dose placebo-controlled study of AMG 162, a fully human monoclonal antibody to RANKL, in postmenopausal women. J Bone Miner Res.
464 Risk Evaluation and Mitigation Strategy (REMs).
465 Toulis K, Anastasilakis A. (2010). Increased risk of serious infections in women with osteopenia or osteoporosis treated with denosumab. Osteoporos Int.
466 Bolland MJ, Avenell A, Baron JA, et al. (2010). Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ.
467 Dawson-Hughes B. (2010). Calcium and heart attacks The heart of the matter. BMJ.
468 Nordin BE, Daly RM, Horowitz J, et al. (2010). Calcium and heart attacks Making too much of a weak case. BMJ.
469 Bolland MJ, Barber PA, Doughty RN, et al. (2008). Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ.
470 Matsumoto T, Miki T, Hagino H, et al. (2005). A new active vitamin D, ED-71, increases bone mass in osteoporotic patients under vitamin D supplementation: a randomized, double-blind, placebo-controlled clinical trial. J Clin Endocrinol Metab.
471 Cummings SR, Karpf DB, Harris F, et al. (2002). Improvement in spine bone density and reduction in risk of vertebral fractures during treatment with antiresorptive drugs. Am J Med.
472 Rabenda V, Bruyere O, Reginster JY. (2011). Relationship between bone mineral density changes and risk of fractures among patients receiving calcium with or without vitamin D supplementation: a meta-regression. Osteoporos Int.
473 Chapurlat RD, Palermo L, Ramsay P, et al. (2005). Risk of fracture among women who lose bone density during treatment with alendronate. The Fracture Intervention Trial. Osteoporos Int.
474 Bell KJ, Hayen A, Macaskill P, et al. (2009). Value of routine monitoring of bone mineral density after starting bisphosphonate treatment: secondary analysis of trial data. BMJ.
475 Watts NB, Geusens P, Barton IP, et al. (2005). Relationship between changes in BMD and nonvertebral fracture incidence associated with risedronate: reduction in risk of nonvertebral fracture is not related to change in BMD. J Bone Miner Res.
476 Watts NB, Cooper C, Lindsay R, et al. (2004). Relationship between changes in bone mineral density and vertebral fracture risk associated with risedronate: greater increases in bone mineral density do not relate to greater decreases in fracture risk. J Clin Densitom.
477 Miller PD, Delmas PD, Huss H, et al. (2010). Increases in hip and spine bone mineral density are predictive for vertebral antifracture efficacy with ibandronate. Calcif Tissue Int.
478 Sarkar S, Mitlak BH, Wong M, et al. (2002). Relationships between bone mineral density and incident vertebral fracture risk with raloxifene therapy. J Bone Miner Res.
479 Watts NB, Miller PD, Kohlmeier LA, et al. (2009). Vertebral fracture risk is reduced in women who lose femoral neck BMD with teriparatide treatment. J Bone Miner Res.
480 Chen P, Miller PD, Delmas PD, et al. (2006). Change in lumbar spine BMD and vertebral fracture risk reduction in teriparatide-treated postmenopausal women with osteoporosis. J Bone Miner Res.
481 Russell RG, Watts NB, Ebetino FH, et al. (2008). Mechanisms of action of bisphosphonates: similarities and differences and their potential influence on clinical efficacy. Osteoporos Int.
482 Baron R, Ferrari S, Russell RG. (2011). Denosumab and bisphosphonates: different mechanisms of action and effects. Bone.
483 Watts NB, Brown JP, Cline G. (2010). Risedronate on 2 Consecutive Days a Month Reduced Vertebral Fracture Risk at 1Year Compared With Historical Placebo. J Clin Densitom.
484 Prince R, Sipos A, Hossain A, et al. (2005). Sustained nonvertebral fragility fracture risk reduction after discontinuation of teriparatide treatment. J Bone Miner Res.
485 Reginster J, M H, Sorensen OH. (2000). Randomized trial of the effects of risedronate on vetebral fractures in women with established postmenopausal osteoporosis. Osteoposos Int.
486 Ettinger B, Black DM, Mitlak BH, et al. (1999). Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA.
487 Hagino H, Nishizawa Y, Sone T, et al. (2009). A double-blinded head-to-head trial of minodronate and alendronate in women with postmenopausal osteoporosis. Bone.
488 Heckbert SR, Li G, Cummings SR, et al. (2008). Use of alendronate and risk of incident atrial fibrillation in women. Arch Intern Med.
489 Lems WF, Lodder MC, Lips P, et al. (2006). Positive effect of alendronate on bone mineral density and markers of bone turnover in patients with rheumatoid arthritis on chronic treatment with low-dose prednisone: a randomized, double-blind, placebo-controlled trial. Osteoporos Int.
490 Yan Y, Wang W, Zhu H, et al. (2009). The efficacy and tolerability of once-weekly alendronate 70 mg on bone mineral density and bone turnover markers in postmenopausal Chinese women with osteoporosis. J Bone Miner Metab.
491 Bunch TJ, Anderson JL, May HT, et al. (2009). Relation of bisphosphonate therapies and risk of developing atrial fibrillation. Am J Cardiol.
492 Cartsos VM, Zhu S, Zavras AI. (2008). Bisphosphonate use and the risk of adverse jaw outcomes: a medical claims study of 714,217 people. J Am Dent Assoc.
493 Payer J, Cierny D, Killinger Z, et al. (2009). Preferences of patients with post-menopausal osteoporosis treated with bisphosphonates--the VIVA II study. J Int Med Res.
494 Eisman JA, Civitelli R, Adami S, et al. (2008). Efficacy and tolerability of intravenous ibandronate injections in postmenopausal osteoporosis: 2-year results from the DIVA study. J Rheumatol.
495 McClung MR, Bolognese MA, Sedarati F, et al. (2009). Efficacy and safety of monthly oral ibandronate in the prevention of postmenopausal bone loss. Bone.
496 Stakkestad JA, Lakatos P, Lorenc R, et al. (2008). Monthly oral ibandronate is effective and well tolerated after 3 years: the MOBILE long-term extension. Clin Rheumatol.
497 Adami S, Pavelka K, Cline GA, et al. (2005). Upper gastrointestinal tract safety of daily oral risedronate in patients taking NSAIDs: a randomized, double-blind, placebo-controlled trial. Mayo Clin Proc.
498 Barrera BA, Wilton L, Harris S, et al. (2005). Prescription-event monitoring study on 13,164 patients prescribed risedronate in primary care in England. Osteoporos Int.
499 Li Y, Zhang Z, Deng X, et al. (2005). Efficacy and safety of risedronate sodium in treatment of postmenopausal osteoporosis. J Huazhong Univ Sci Technolog Med Sci.
500 Mok CC, Tong KH, To CH, et al. (2008). Risedronate for prevention of bone mineral density loss in patients receiving high-dose glucocorticoids: a randomized double-blind placebo-controlled trial. Osteoporos Int.
501 Ste-Marie LG, Brown JP, Beary JF, et al. (2009). Comparison of the effects of once-monthly versus once-daily risedronate in postmenopausal osteoporosis: a phase II, 6-month, multicenter, randomized, double-blind, active-controlled, dose-ranging study. Clin Ther.
502 Boonen S, Sellmeyer DE, Lippuner K, et al. (2008). Renal safety of annual zoledronic acid infusions in osteoporotic postmenopausal women. Kidney Int.
503 McClung M, Recker R, Miller P, et al. (2007). Intravenous zoledronic acid 5 mg in the treatment of postmenopausal women with low bone density previously treated with alendronate. Bone.
504 Etminan M, Aminzadeh K, Matthew IR, et al. (2008). Use of oral bisphosphonates and the risk of aseptic osteonecrosis: a nested case-control study. J Rheumatol.
505 Emkey R, Delmas PD, Bolognese M, et al. (2009). Efficacy and tolerability of once-monthly oral ibandronate (150 mg) and once-weekly oral alendronate (70 mg): additional results from the Monthly Oral Therapy With Ibandronate For Osteoporosis Intervention (MOTION) study. Clin Ther.
506 Hadji P, Minne H, Pfeifer M, et al. (2008). Treatment preference for monthly oral ibandronate and weekly oral alendronate in women with postmenopausal osteoporosis: A randomized, crossover study (BALTO II). Joint Bone Spine.
507 Li M, Xing XP, Zhang ZL, et al. (2009). Infusion of ibandronate once every 3 months effectively decreases bone resorption markers and increases bone mineral density in Chinese postmenopausal osteoporotic women: a 1-year study. J Bone Miner Metab.
508 Cadarette SM, Katz JN, Brookhart MA, et al. (2009). Comparative gastrointestinal safety of weekly oral bisphosphonates. Osteoporos Int.
509 Reid DM, Hosking D, Kendler D, et al. (2006). Alendronic acid produces greater effects than risedronic acid on bone density and turnover in postmenopausal women with osteoporosis : results of FACTS -international. Clin Drug Investig.
510 Breart G, Cooper C, Meyer O, et al. (2009). Osteoporosis and venous thromboembolism: a retrospective cohort study in the UK General Practice Research Database. Osteoporos Int.
511 Saag K, Lindsay R, Kriegman A, et al. (2007). A single zoledronic acid infusion reduces bone resorption markers more rapidly than weekly oral alendronate in postmenopausal women with low bone mineral density. Bone.
512 Reid DM, Devogelaer JP, Saag K, et al. (2009). Zoledronic acid and risedronate in the prevention and treatment of glucocorticoid-induced osteoporosis (HORIZON): a multicentre, double-blind, double-dummy, randomised controlled trial. Lancet.
513 Grosso A, Douglas I, Hingorani A, et al. (2009). Oral bisphosphonates and risk of atrial fibrillation and flutter in women: a self-controlled case-series safety analysis. PLoS One.
514 Hong JW, Nam W, Cha IH, et al. (2009). Oral bisphosphonate-related osteonecrosis of the jaw: the first report in Asia. Osteoporos Int.
515 Blumentals WA, Harris ST, Cole RE, et al. (2009). Risk of severe gastrointestinal events in women treated with monthly ibandronate or weekly alendronate and risedronate. Ann Pharmacother.
516 Kendler DL, Roux C, Benhamou CL, et al. (2009). Effects of Denosumab on Bone Mineral Density and Bone Turnover in Postmenopausal Women Transitioning from Alendronate Therapy. J Bone Miner Res.
517 Miller PD, Bolognese MA, Lewiecki EM, et al. (2008). Effect of denosumab on bone density and turnover in postmenopausal women with low bone mass after long-term continued, discontinued, and restarting of therapy: a randomized blinded phase 2 clinical trial. Bone.
518 Antoniucci DM, Sellmeyer DE, Bilezikian JP, et al. (2007). Elevations in serum and urinary calcium with parathyroid hormone (1-84) with and without alendronate for osteoporosis. J Clin Endocrinol Metab.
519 Huang WF, Tsai YW, Wen YW, et al. (2009). Osteoporosis treatment and atrial fibrillation: alendronate versus raloxifene. Menopause.
520 Obermayer-Pietsch BM, Marin F, McCloskey EV, et al. (2008). Effects of two years of daily teriparatide treatment on BMD in postmenopausal women with severe osteoporosis with and without prior antiresorptive treatment. J Bone Miner Res.
521 McComsey GA, Kendall MA, Tebas P, et al. (2007). Alendronate with calcium and vitamin D supplementation is safe and effective for the treatment of decreased bone mineral density in HIV. AIDS.
522 Vestergaard P, Schwartz K, Pinholt EM, et al. (2010). Risk of atrial fibrillation associated with use of bisphosphonates and other drugs against osteoporosis: a cohort study. Calcif Tissue Int.
523 Vestergaard P, Schwartz K, Pinholt EM, et al. (2009). Use of bisphosphonates and raloxifene and risk of deep venous thromboembolism and pulmonary embolism. Osteoporos Int.
524 Pelayo I, Haya J, De la Cruz JJ, et al. (2008). Raloxifene plus ossein-hydroxyapatite compound versus raloxifene plus calcium carbonate to control bone loss in postmenopausal women: a randomized trial. Menopause.
525 Recker RR, Marin F, Ish-Shalom S, et al. (2009). Comparative effects of teriparatide and strontium ranelate on bone biopsies and biochemical markers of bone turnover in postmenopausal women with osteoporosis. J Bone Miner Res.
526 Cohen SB, Dore RK, Lane NE, et al. (2008). Denosumab treatment effects on structural damage, bone mineral density, and bone turnover in rheumatoid arthritis: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, phase II clinical trial. Arthritis Rheum.
527 Lewis JR, Calver J, Zhu K, et al. (2011). Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res.