# Peer Reviewers

Steve Cummings, M.D., FACP

San Francisco Coordinating Center

California Pacific Medical Center

California Pacific Medical Center Research Institute

University of California, San Francisco

San Francisco, CA

Rochelle Fu, Ph.D.

Oregon Health and Science University

Portland, OR

Conrad C. Johnston, M.D.

Indiana University School of Medicine

Indianapolis, IN

Ethel Siris, M.D.

Columbia University Medical Center

New York, NY

Disclosure: Service as a TEP member or peer reviewer should not be construed as agreeing with or endorsing the content of the report.