# Technical Expert Panel

Roberta Biegel

Senior Director

Public Policy and Government Relations

National Osteoporosis Foundation

Washington, DC

Bruce Ettinger, M.D.

Clinical Professor

University of California San Francisco

San Francisco, CA

Theodore Hahn, M.D.

Professor in Residence

UCLA Medical Center,

Geriatric Research Education and Clinical Center

and VA Greater Los Angeles Healthcare System

Los Angeles, CA

Marc Hochberg, M.D., M.P.H.

Professor of Medicine

Head, Division of Rheumatology and Clinical Immunology

Professor of Epidemiology and Preventive Medicine

University of Maryland

Baltimore, MD

Hau Liu, M.D.

Director, Chronic Care Management

Associate Chief, Endocrinology and Metabolism

Santa Clara Valley

Clinical Assistant Professor of Medicine

Stanford University

San Jose and Stanford, CA

Catherine Maclean, M.D., Ph.D.

Staff Vice President, Performance Measurement

WellPoint, Inc.

Thousand Oaks, CA

Paul Miller, M.D.

Medical Director

Colorado Center for Bone Research

Lakewood, CO

Eric Orwoll, M.D.

Endocrinologist

Oregon Health and Science University

Portland, OR

Marcel Salive, M.D., M.P.H.

Director, Division of Medical and Surgical Services

Centers for Medicare and Medicaid Services

Baltimore, MD

William Schwab, M.D., Ph.D., AGSF

Chief of Geriatric Services

Kaiser Permanente of Ohio

Cleveland Heights, OH

Daniel Solomon, M.D., M.P.H,

Associate Professor of Medicine

Harvard Medical School

Brigham and Women's Hospital

Division of Rheumatology, Immunology and Allergy

Boston, MA