# Appendix D List of Excluded Studies

## Excluded at Short Form Review

### Reject: Irrelevant Design (N=213)

1 (2010). Oral bisphosphonates and risk of cancer of oesophagus, stomach, and colorectum: case-control analysis within a UK primary care cohort. Br Dent J.
2 Abelson A, Ringe JD, Gold DT, Lange JL, Thomas T. (2009). Longitudinal change in clinical fracture incidence after initiation of bisphosphonates. Osteoporos Int.
3 Adachi J, Lynch N, Middelhoven H, Hunjan M, Cowell W. (2007). The association between compliance and persistence with bisphosphonate therapy and fracture risk: a review. BMC Musculoskelet Disord.
4 Adami S, Giannini S, Bianchi G, Sinigaglia L, Di Munno O, Fiore CE, et al. (2009). Vitamin D status and response to treatment in post-menopausal osteoporosis. Osteoporos Int.
5 Aghaloo TL, Felsenfeld AL, Tetradis S. (2010). Osteonecrosis of the jaw in a patient on Denosumab. J Oral Maxillofac Surg.
6 Ahn JK, Lee J, Cha HS, Koh EM. (2010). Non-traumatic fracture of the femoral shaft in a patient taking long-term bisphosphonate therapy. Rheumatol Int.
7 Al-Azzawi F. (2008). Prevention of postmenopausal osteoporosis and associated fractures: Clinical evaluation of the choice between estrogen and bisphosphonates. Gynecol Endocrinol.
8 Aleid W, Sidebottom A. (2009). Oral mucosal irritation with incorrect use of alendronate. Br J Oral Maxillofac Surg.
9 Alexander W, Boonen S. (2009). American Society for Bone and Mineral Research: Denosumab (Prolia): A subgroup analysis. P and T.
10 Ali T, Jay RH. (2009). Spontaneous femoral shaft fracture after long-term alendronate. Age Ageing.
11 Amling M, Kurth A. (2009). Ibandronate: a review of its vertebral and nonvertebral antifracture efficacy. Womens Health (Lond Engl).
12 Anastasilakis A, Goulis DG, Koukoulis G, Kita M, Slavakis A, Avramidis A. (2007). Acute and chronic effect of teriparatide on glucose metabolism in women with established osteoporosis. Exp Clin Endocrinol Diabetes.
13 (2010). Management of Corticosteroid-Induced Osteoporosis. Drug and Therapeutics Bulletin.
14 Arai T, Inoue Y, Hayashi S, Yamamoto S, Sakatani M. (2005). Risedronate induced BOOP complicated with sarcoidosis. Thorax.
15 Assael LA. (2009). Oral bisphosphonates as a cause of bisphosphonate-related osteonecrosis of the jaws: clinical findings, assessment of risks, and preventive strategies. J Oral Maxillofac Surg.
16 Atik OS, Suluova F, Gormeli G, Yildirim A, Ali A. (2010). Insufficiency femoral fractures in patients undergoing prolonged alendronate therapy. Eklem Hastalik Cerrahisi.
17 Azevedo GD, Franco RF, Baggio MS, Maranhao TM, Sa MF. (2005). Procoagulant state after raloxifene therapy in postmenopausal women. Fertil Steril.
18 Badamgarav E, Fitzpatrick LA. (2006). A new look at osteoporosis outcomes: the influence of treatment, compliance, persistence, and adherence. Mayo Clin Proc.
19 Bagan JV, Jimenez Y, Murillo J, Hernandez S, Poveda R, Sanchis JM, et al. (2006). Jaw osteonecrosis associated with bisphosphonates: multiple exposed areas and its relationship to teeth extractions. Study of 20 cases. Oral Oncol.
20 Baio G, Barbagallo M, D'Avola G, Di Luccio A, Di Tanna GL, Falaschi P, et al. (2011). Improving adherence in osteoporosis: a new management algorithm for the patient with osteoporosis. Expert Opin Pharmacother.
21 Bamias A, Terpos E, Dimopoulos MA. (2010). Avascular osteonecrosis of the jaw as a side effect of bisphosphonate treatment. Onkologie.
22 Bamrungsong T, Pongchaiyakul C. (2010). Bilateral atypical femoral fractures after long-term alendronate therapy: a case report. J Med Assoc Thai.
23 Bauer DC. (2010). Bisphosphonate use and atypical femoral fractures: getting down to brass tacks. J Clin Endocrinol Metab.
24 Bedogni A, Bettini G, Totola A, Saia G, Nocini PF. (2010). Oral bisphosphonate-associated osteonecrosis of the jaw after implant surgery: a case report and literature review. J Oral Maxillofac Surg.
25 Belhadjali H, Slim R, Aouam K, Youssef M, Zili J. (2008). Cutaneous vasculitis induced by risedronate. Allergy.
26 Bell BM, Bell RE. (2008). Oral bisphosphonates and dental implants: a retrospective study. J Oral Maxillofac Surg.
27 Bhutta MF, Rance M, Gillett D, Weighill JS. (2005). Alendronate-induced chemical laryngitis. J Laryngol Otol.
28 Bilezikian JP. (2009). Efficacy of bisphosphonates in reducing fracture risk in postmenopausal osteoporosis. Am J Med.
29 Bobba RS, Beattie K, Parkinson B, Kumbhare D, Adachi JD. (2006). Tolerability of different dosing regimens of bisphosphonates for the treatment of osteoporosis and malignant bone disease. Drug Saf.
30 Bock O, Boerst H, Thomasius FE, Degner C, Stephan-Oelkers M, Valentine SM, et al. (2007). Common musculoskeletal adverse effects of oral treatment with once weekly alendronate and risedronate in patients with osteoporosis and ways for their prevention. J Musculoskelet Neuronal Interact.
31 Brandao CM, Lima MG, Silva AL, Silva GD, Guerra AA, Acurcio Fde A. (2008). Treatment of postmenopausal osteoporosis in women: a systematic review. Cad Saude Publica.
32 Brandi ML. (2008). New dosing options in osteoporosis treatment: clinical evidence on risedronate 75 mg monthly treatment. Clin Case Min Bone Metab.
33 Breglia MD, Carter JD. (2010). Atypical insufficiency fracture of the tibia associated with long-term bisphosphonate therapy. J Clin Rheumatol.
34 Brooks JK, Gilson AJ, Sindler AJ, Ashman SG, Schwartz KG, Nikitakis NG. (2007). Osteonecrosis of the jaws associated with use of risedronate: report of 2 new cases. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
35 Brown JP. (2010). Administration of annual oral high-dose vitamin D to community-dwelling older women in autumn and winter months increases risk of falls and fractures. Evid Based Med.
36 Bunning RD, Rentfro RJ, Jelinek JS. (2010). Low-energy femoral fractures associated with long-term bisphosphonate use in a rehabilitation setting: a case series. PM R.
37 Bushardt RL, Turner JL, Ragucci KR, Askins DG. (2006). Non-estrogen treatments for osteoporosis: an evidence-based review. JAAPA.
38 Capeci CM, Tejwani NC. (2009). Bilateral low-energy simultaneous or sequential femoral fractures in patients on long-term alendronate therapy. J Bone Joint Surg Am.
39 Cermak K, Shumelinsky F, Alexiou J, Gebhart MJ. (2010). Case reports: subtrochanteric femoral stress fractures after prolonged alendronate therapy. Clin Orthop Relat Res.
40 Chapurlat RD. (2008). Single annual injectable treatment for postmenopausal osteoporosis. Expert Opin Drug Deliv.
41 Chesnut CH. (2006). Treating osteoporosis with bisphosphonates and addressing adherence: a review of oral ibandronate. Drugs.
42 Cheung RK, Leung KK, Lee KC, Chow TC. (2007). Sequential non-traumatic femoral shaft fractures in a patient on long-term alendronate. Hong Kong Med J.
43 Clarke BM, Boyette J, Vural E, Suen JY, Anaissie EJ, Stack BC. (2007). Bisphosphonates and jaw osteonecrosis: the UAMS experience. Otolaryngol Head Neck Surg.
44 Colon-Emeric CS, Lyles KW. (2009). Should there be a fracas over FRAX and other fracture prediction tools?: Comment on “A comparison of prediction models for fractures in older women”. Arch Intern Med.
45 Cranney A, Papaioannou A, Zytaruk N, Hanley D. (2006). Clin Guidelines Comm. Parathyroid Hormone for the Treatment of Osteoporosis: A Systematic Review. Canadian Medical Association Journal.
46 Curtis JR, Westfall AO, Cheng H, Saag KG, Delzell E. (2009). RisedronatE and ALendronate Intervention over Three Years (REALITY): minimal differences in fracture risk reduction. Osteoporos Int.
47 Dannemann C, Gratz KW, Riener MO, Zwahlen RA. (2007). Jaw osteonecrosis related to bisphosphonate therapy: a severe secondary disorder. Bone.
48 de Vries F. (2010). Bisphosphonates and cancer. Two studies, same data source, two answers. BMJ (Clinical research ed).
49 Dogru T, Sonmez A, Tasci I, Genc H. (2005). Symptomatic hypocalcemia due to oral risedronate therapy. Indian J Med Sci.
50 Dore RK, Feldman RG, Taylor KA, See K, Dalsky GP, Warner MR. (2009). Patient experience with a new teriparatide delivery device. Curr Med Res Opin.
51 Edwards MH, McCrae FC, Young-Min SA. (2009). Alendronate-related femoral diaphysis fracture-what should be done to predict and prevent subsequent fracture of the contralateral side?. Osteoporos Int.
52 Elliott ME. (2010). Prevention and Management of Osteoporosis. Journal of the Pharmacy Society of Wisconsin.
53 Engroff SL, Coletti D. (2008). Bisphosphonate related osteonecrosis of the palate: report of a case managed with free tissue transfer. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
54 Ensrud KE, Schousboe JT. (2011). Clinical practice. Vertebral fractures. N Engl J Med.
55 Epstein S, Jeglitsch M, McCloskey E. (2009). Update on monthly oral bisphosphonate therapy for the treatment of osteoporosis: focus on ibandronate 150 mg and risedronate 150 mg. Curr Med Res Opin.
56 Erbagci Z, Tuncel A, Erkilic S, Ozkur M. (2005). Progressive pigmentary purpura related to raloxifene. Saudi Med J.
57 Etminan M. (2011). Long-term use of oral bisphosphonates increases the risk of oesophageal but not gastric or colorectal cancer. Evidence-Based Medicine.
58 Favia G, Pilolli GP, Maiorano E. (2009). Osteonecrosis of the Jaw Correlated to Bisphosphonate Therapy in Non-oncologic Patients: Clinicopathological Features of 24 Patients. J Rheumatol.
59 Fedele S, Porter SR, D'Aiuto F, Aljohani S, Vescovi P, Manfredi M, et al. (2010). Nonexposed variant of bisphosphonate-associated osteonecrosis of the jaw: a case series. Am J Med.
60 Feskanich D, Willett W, Colditz G. (2002). Walking and leisure-time activity and risk of hip fracture in postmenopausal women. JAMA.
61 Filip R, Huk J, Jarosz B, Skrzydlo-Radomanska B. (2009). Endoscopic and histological verification of upper GI tract side effects after long-term therapy with alendronate and strontium ranelate. Przeglad Gastroenterologiczny.
62 Filleul O, C E, Saussez S. (2010). Bisphosphonate-induced osteonecrosis of the jaw: a review of 2,400 patient cases. J Cancer Res Clin Oncol.
63 Fit KE, Burkiewicz JS, Griffin BL, Meyer CM. (2008). Acute phase reaction with intravenous ibandronate. Am J Med.
64 Francis RM, Anderson FH, Patel S, Sahota O, van Staa TP. (2006). Calcium and vitamin D in the prevention of osteoporotic fractures. Qjm.
65 French DD, Margo CE. (2008). Postmarketing surveillance rates of uveitis and scleritis with bisphosphonates among a national veteran cohort. Retina.
66 Gaal J, Bender T, Varga J, Horvath I, Kiss J, Somogyi P, et al. (2009). Overcoming resistance to bisphosphonates through the administration of alfacalcidol: results of a 1-year, open follow-up study. Rheumatol Int.
67 Girgis CM, Sher D, Seibel MJ. (2010). Atypical femoral fractures and bisphosphonate use. N Engl J Med.
68 Giusti A, Hamdy NA, Dekkers OM, Ramautar SR, Dijkstra S, Papapoulos SE. (2010). Atypical fractures and bisphosphonate therapy: A cohort study of patients with femoral fracture with radiographic adjudication of fracture site and features. Bone.
69 Goddard MS, Reid KR, Johnston JC, Khanuja HS. (2009). Atraumatic bilateral femur fracture in long-term bisphosphonate use. Orthopedics.
70 Goh SK, Yang KY, Koh JS, Wong MK, Chua SY, Chua DT, et al. (2007). Subtrochanteric insufficiency fractures in patients on alendronate therapy: a caution. J Bone Joint Surg Br.
71 Gomez Font R, Martinez Garcia ML, Olmos Martinez JM. (2008). Osteochemonecrosis of the jaws due to bisphosphonate treatments. Update. Med Oral Patol Oral Cir Bucal.
72 Gomez V, Xiao SY. (2009). Alendronate-induced Esophagitis in an Elderly Woman. Int J Clin Exp Pathol.
73 Gonzalez-Moles MA, Bagan-Sebastian JV. (2000). Alendronate-related oral mucosa ulcerations. J Oral Pathol Med.
74 Goss A, Bartold M, Sambrook P, Hawker P. (2010). The nature and frequency of bisphosphonate-associated osteonecrosis of the jaws in dental implant patients: a South Australian case series. J Oral Maxillofac Surg.
75 Goss AN. (2007). Bisphosphonate-associated osteonecrosis of the jaws. Climacteric.
76 Grana J, Mahia IV, Meizoso MO, Vazquez T. (2008). Multiple osteonecrosis of the jaw, oral bisphosphonate therapy and refractory rheumatoid arthritis (Pathological fracture associated with ONJ and BP use for osteoporosis). Clin Exp Rheumatol.
77 Green R, Blackmore K, Robson A. (2010). Case of maxillary avascular necrosis due to oral bisphosphonates, presenting with signs of malignancy. J Laryngol Otol.
78 Gwynne Jones DP, Savage RL, Highton J. (2008). Alendronate-induced synovitis. J Rheumatol.
79 Harper KD, Krege JH, Marcus R, Mitlak BH. (2007). Osteosarcoma and teriparatide?. J Bone Miner Res.
80 Heras Rincon I, Zubillaga Rodriguez I, Castrillo Tambay M, Montalvo Moreno JJ. (2007). Osteonecrosis of the jaws and bisphosphonates. Report of fifteen cases. Therapeutic recommendations. Med Oral Patol Oral Cir Bucal.
81 Hess LM, Jeter JM, Benham-Hutchins M, Alberts DS. (2008). Factors associated with osteonecrosis of the jaw among bisphosphonate users. Am J Med.
82 Hoefert S, Eufinger H. (2005). Mund Kiefer Gesichtschir.
83 Hoefert S, Eufinger H. (2005). Necrosis of the jaws under bisphosphonate therapy. Orthopade.
84 Hokama A, Ihama Y, Nakamoto M, Kinjo N, Kinjo F, Fujita J. (2007). Esophagitis dissecans superficialis associated with bisphosphonates. Endoscopy.
85 Imai K, Yamamoto S, Anamizu Y, Horiuchi T. (2007). Pelvic insufficiency fracture associated with severe suppression of bone turnover by alendronate therapy. J Bone Miner Metab.
86 Inderjeeth CA, Foo AC, Lai MM, Glendenning P. (2009). Efficacy and safety of pharmacological agents in managing osteoporosis in the old old: review of the evidence. Bone.
87 Ing-Lorenzini K, Desmeules J, Plachta O, Suva D, Dayer P, Peter R. (2009). Low-energy femoral fractures associated with the long-term use of bisphosphonates: a case series from a Swiss university hospital. Drug Saf.
88 Isaacs JD, Shidiak L, Harris IA, Szomor ZL. (2010). Femoral insufficiency fractures associated with prolonged bisphosphonate therapy. Clin Orthop Relat Res.
89 Isik A, Uras I, Uyar ME, Karakurt F, Kaftan O. (2009). Alendronate-induced asthma. Ann Pharmacother.
90 Iwamoto J, Takeda T, Sato Y, Uzawa M. (2007). Comparison of the effect of alendronate on lumbar bone mineral density and bone turnover in men and postmenopausal women with osteoporosis. Clin Rheumatol.
91 Jansen JP, Bergman GJ, Huels J, Olson M. (2009). Prevention of vertebral fractures in osteoporosis: mixed treatment comparison of bisphosphonate therapies. Curr Med Res Opin.
92 Jansen JP, Bergman GJD, Huels J, Olson M. (2011). The Efficacy of Bisphosphonates in the Prevention of Vertebral, Hip, and Nonvertebral-Nonhip Fractures in Osteoporosis: A Network Meta-Analysis. Seminars in Arthritis and Rheumatism.
93 Jones DG, Savage R, Highton J. (2005). Synovitis induced by alendronic acid can present as acute carpal tunnel syndrome. Bmj.
94 Jones HT, Howard E. (2010). Combination therapy for postmenopausal osteoporosis. American Family Physician.
95 Junquera L, Gallego L, Cuesta P, Pelaz A, de Vicente JC. (2009). Clinical experiences with bisphosphonate-associated osteonecrosis of the jaws: analysis of 21 cases. Am J Otolaryngol.
96 Kakaria PJ, Nashel DJ, Nylen ES. (2005). Debilitating muscle cramps after teriparatide therapy. Ann Intern Med.
97 Katayama K, Matsuno T. (2008). Effects of bisphosphonates on fracture incidence and bone metabolism in rheumatoid arthritis patients in general practice taking long-term corticosteroid therapy: a retrospective study. Clin Drug Investig.
98 Kauffman RP. (2010). Simple models predicted 10-year fracture risk in older women as accurately as more complex FRAX models: Commentary. Annals of Internal Medicine.
99 Khamaisi M, Regev E, Yarom N, Avni B, Leitersdorf E, Raz I, et al. (2007). Possible association between diabetes and bisphosphonate-related jaw osteonecrosis. J Clin Endocrinol Metab.
100 Khan AA, Sandor GK, Dore E, Morrison AD, Alsahli M, Amin F, et al. (2009). Bisphosphonate associated osteonecrosis of the jaw. J Rheumatol.
101 King AE, Umland EM. (2008). Osteonecrosis of the jaw in patients receiving intravenous or oral bisphosphonates. Pharmacotherapy.
102 Kos M, Brusco D, Kuebler J, Engelke W. (2010). Clinical comparison of patients with osteonecrosis of the jaws, with and without a history of bisphosphonates administration. Int J Oral Maxillofac Surg.
103 Kos M, Kuebler JF, Luczak K, Engelke W. (2009). Bisphosphonate-related osteonecrosis of the jaws: A review of 34 cases and evaluation of risk. J Craniomaxillofac Surg.
104 Krueger CD, West PM, Sargent M, Lodolce AE, Pickard AS. (2007). Bisphosphonate-induced osteonecrosis of the jaw. Ann Pharmacother.
105 Kuehn BM. (2006). Reports of adverse events from bone drugs prompt caution. JAMA.
106 Kuehn BM. (2010). Prolonged bisphosphonate use linked to rare fractures, esophageal cancer. JAMA.
107 Kumar SK, Meru M, Sedghizadeh PP. (2008). Osteonecrosis of the jaws secondary to bisphosphonate therapy: a case series. J Contemp Dent Pract.
108 Kwek EB, Goh SK, Koh JS, Png MA, Howe TS. (2008). An emerging pattern of subtrochanteric stress fractures: a long-term complication of alendronate therapy?. Injury.
109 Langsetmo LA, Morin S, Richards JB, Davison KS, Olszynski WP, Prior JC, et al. (2009). Effectiveness of antiresorptives for the prevention of nonvertebral low-trauma fractures in a population-based cohort of women. Osteoporos Int.
110 Lazarovici TS, Yahalom R, Taicher S, Elad S, Hardan I, Yarom N. (2009). Bisphosphonate-related osteonecrosis of the jaws: a single-center study of 101 patients. J Oral Maxillofac Surg.
111 Lazarovici TS, Yahalom R, Taicher S, Schwartz-Arad D, Peleg O, Yarom N. (2010). Bisphosphonate-related osteonecrosis of the jaw associated with dental implants. J Oral Maxillofac Surg.
112 Lee JK. (2009). Bilateral atypical femoral diaphyseal fractures in a patient treated with alendronate sodium. International Journal of Rheumatic Diseases.
113 Lee P, van der Wall H, Seibel MJ. (2007). Looking beyond low bone mineral density: multiple insufficiency fractures in a woman with post-menopausal osteoporosis on alendronate therapy. J Endocrinol Invest.
114 Lekkerkerker F, Kanis JA, Alsayed N, Bouvenot G, Burlet N, Cahall D, et al. (2007). Adherence to treatment of osteoporosis: a need for study. Osteoporos Int.
115 Lenart BA, Lorich DG, Lane JM. (2008). Atypical fractures of the femoral diaphysis in postmenopausal women taking alendronate. N Engl J Med.
116 Lenart BA, Neviaser AS, Lyman S, Chang CC, Edobor-Osula F, Steele B, et al. (2009). Association of low-energy femoral fractures with prolonged bisphosphonate use: a case control study. Osteoporos Int.
117 Leung S, Ashar BH, Miller RG. (2005). Bisphosphonate-associated scleritis: a case report and review. South Med J.
118 Levin L, L A, Schwartz-Arad D. (2007). Denture-related osteonecrosis of the maxilla associated with oral bisphosphonate treatment. J Am Dent Assoc.
119 Lewiecki EM. (2007). Long dosing intervals in the treatment of postmenopausal osteoporosis. Curr Med Res Opin.
120 Majumdar SR. (2008). Oral bisphosphonates and atrial fibrillation. BMJ.
121 Malden NJ, Pai AY. (2007). Oral bisphosphonate associated osteonecrosis of the jaws: three case reports. Br Dent J.
122 Mamdani M, Kopp A, Hawker G. (2007). Hip fractures in users of first- vs. second-generation bisphosphonates. Osteoporos Int.
123 Marunick M, Miller R, Gordon S. (2005). Adverse oral sequelae to bisphosphonate administration. J Mich Dent Assoc.
124 Marunick M, Miller R, Gordon S. (2006). Recent reports link bisphosphonates use to osteonecrosis. Todays FDA.
125 Marx RE, Cillo JE, Ulloa JJ. (2007). Oral bisphosphonate-induced osteonecrosis: risk factors, prediction of risk using serum CTX testing, prevention, and treatment. J Oral Maxillofac Surg.
126 Marx RE, Sawatari Y, Fortin M, Broumand V. (2005). Bisphosphonate-induced exposed bone (osteonecrosis/osteopetrosis) of the jaws: risk factors, recognition, prevention, and treatment. J Oral Maxillofac Surg.
127 Mavrokokki T, Cheng A, Stein B, Goss A. (2007). Nature and frequency of bisphosphonate-associated osteonecrosis of the jaws in Australia. J Oral Maxillofac Surg.
128 McKague M, Jorgenson D, Buxton KA. (2010). Ocular side effects of bisphosphonates: A case report and literature review. Canadian Family Physician.
129 Mehanna P, Goddard R. (2010). Bisphosphonate associated osteonecrosis: an unusual case. Australian dental journal.
130 Melo MD, Obeid G. (2005). Osteonecrosis of the jaws in patients with a history of receiving bisphosphonate therapy: strategies for prevention and early recognition. J Am Dent Assoc.
131 Merigo E, Manfredi M, Meleti M, Guidotti R, Ripasarti A, Zanzucchi E, et al. (2006). Bone necrosis of the jaws associated with bisphosphonate treatment: a report of twenty-nine cases. Acta Biomed.
132 Meunier PJ, Reginster JY. (2003). Design and methodology of the phase 3 trials for the clinical development of strontium ranelate in the treatment of women with postmenopausal osteoporosis. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
133 Meyer G, Kopke S. (2009). Vitamin D and falls. Information on harm is missing. BMJ.
134 Migliorati CA, Casiglia J, Epstein J, Jacobsen PL, Siegel MA, Woo SB. (2005). Managing the care of patients with bisphosphonate-associated osteonecrosis: an American Academy of Oral Medicine position paper. J Am Dent Assoc.
135 Migliorati CA, Schubert MM, Peterson DE, Seneda LM. (2005). Bisphosphonate-associated osteonecrosis of mandibular and maxillary bone: an emerging oral complication of supportive cancer therapy. Cancer.
136 Milillo P, Garribba AP, Favia G, Ettorre GC. (2007). Jaw osteonecrosis in patients treated with bisphosphonates: MDCT evaluation. Radiol Med.
137 Miller PD. (2005). Bone density and markers of bone turnover in predicting fracture risk and how changes in these measures predict fracture risk reduction. Curr Osteoporos Rep.
138 Minamitani C, Takai S, Matsushima-Nishiwaki R, Hanai Y, Otuka T, Kozawa O, et al. (2008). Raloxifene-induced acceleration of platelet aggregation. Intern Med.
139 Minne H, Audran M, Simoes ME, Obermayer-Pietsch B, Sigurethsson G, Marin F, et al. (2008). Bone density after teriparatide in patients with or without prior antiresorptive treatment: one-year results from the EUROFORS study. Curr Med Res Opin.
140 Najm S, Lysitsa S, Carrel J. (2005). Bisphosphonates-related jaw osteonecrosis. Presse Med.
141 Naniwa T, Maeda T, Mizoshita T, Hayami Y, Watanabe M, Banno S, et al. (2008). Alendronate-induced esophagitis: possible pathogenic role of hypersensitivity to alendronate. Intern Med.
142 Nase JB, Suzuki JB. (2006). Osteonecrosis of the jaw and oral bisphosphonate treatment. J Am Dent Assoc.
143 Neviaser AS, Lane JM, Lenart BA, Edobor-Osula F, Lorich DG. (2008). Low-energy femoral shaft fractures associated with alendronate use. J Orthop Trauma.
144 Nieto EJ. (2010). Non-traumatic fracture of the femur in a healthy woman who had been taking alendronate for a long time: A case report. Osteoporosis International.
145 Nieves JW, Barrett-Connor E, Siris ES, Zion M, Barlas S, Chen YT. (2008). Calcium and vitamin D intake influence bone mass, but not short-term fracture risk, in Caucasian postmenopausal women from the National Osteoporosis Risk Assessment (NORA) study. Osteoporos Int.
146 Odvina CV, Levy S, Rao S, Zerwekh JE, Sudhaker Rao D. (2009). Unusual mid-shaft fractures during long term bisphosphonate therapy. Clin Endocrinol (Oxf).
147 Ornoy A, Wajnberg R, Diav-Citrin O. (2006). The outcome of pregnancy following pre-pregnancy or early pregnancy alendronate treatment. Reprod Toxicol.
148 Ortolani S, Vai S. (2006). Strontium ranelate: an increased bone quality leading to vertebral antifracture efficacy at all stages. Bone.
149 Palaska PK, Cartsos V, Zavras AI. (2009). Bisphosphonates and time to osteonecrosis development. Oncologist.
150 Park W, Kim NK, Kim MY, Rhee YM, Kim HJ. (2009). Osteonecrosis of the jaw induced by oral administration of bisphosphonates in Asian population: five cases. Osteoporos Int.
151 Pasala S, Burshell A, Ogden F. (2010). Long-term alendronate therapy and subtrochanteric femoral fractures. Ochsner Journal.
152 Pazianas M, Miller P, Blumentals WA, Bernal M, Kothawala P. (2007). A review of the literature on osteonecrosis of the jaw in patients with osteoporosis treated with oral bisphosphonates: prevalence, risk factors, and clinical characteristics. Clin Ther.
153 Phal PM, Myall RW, Assael LA, Weissman JL. (2007). Imaging findings of bisphosphonate-associated osteonecrosis of the jaws. AJNR Am J Neuroradiol.
154 Phillips MB. (2007). Risedronate-induced Hepatitis. Am J Med.
155 Purcell PM, Boyd IW. (2005). Bisphosphonates and osteonecrosis of the jaw. Med J Aust.
156 Pyon EY. (2006). Once-monthly ibandronate for postmenopausal osteoporosis: review of a new dosing regimen. Clin Ther.
157 Raja V, Sandanshiv P, Neugebauer M. (2007). Risedronate induced transient ocular myasthenia. J Postgrad Med.
158 Reginster JY, Deroisy R, Jupsin I. (2003). Strontium ranelate: a new paradigm in the treatment of osteoporosis. Drugs Today (Barc).
159 Richards JC, Wiffen SJ. (2006). Corneal graft rejection precipitated by uveitis secondary to alendronate sodium therapy. Cornea.
160 Ringe JD, Faber H, Fahramand P, Schacht E. (2005). Alfacalcidol versus plain vitamin D in the treatment of glucocorticoid/inflammation-induced osteoporosis. J Rheumatol Suppl.
161 Ringe JD, Schacht E. (2009). Potential of alfacalcidol for reducing increased risk of falls and fractures. Rheumatol Int.
162 Rizos EC, Milionis HJ, Elisaf MS. (2006). Fever with rash following zolendronic acid administration. Clin Exp Rheumatol.
163 Rizzoli R, Akesson K, Bouxsein M, Kanis JA, Napoli N, Papapoulos S, et al. (2011). Subtrochanteric fractures after long-term treatment with bisphosphonates: a European Society on Clinical and Economic Aspects of Osteoporosis and Osteoarthritis, and International Osteoporosis Foundation Working Group Report. Osteoporos Int.
164 Rubegni P, Fimiani M. (2006). Images in clinical medicine. Bisphosphonate-associated contact stomatitis. N Engl J Med.
165 Ruggiero SL, Mehrotra B, Rosenberg TJ, Engroff SL. (2004). Osteonecrosis of the jaws associated with the use of bisphosphonates: a review of 63 cases. J Oral Maxillofac Surg.
166 Sanfelix-Genoves J, Gil-Guillen VF, Orozco-Beltran D, Giner-Ruiz V, Pertusa-Martinez S, Reig-Moya B, et al. (2009). Determinant factors of osteoporosis patients' reported therapeutic adherence to calcium and/or vitamin D supplements: a cross-sectional, observational study of postmenopausal women. Drugs Aging.
167 Saussez S, Javadian R, Hupin C, Magremanne M, Chantrain G, Loeb I, et al. (2009). Bisphosphonate-related osteonecrosis of the jaw and its associated risk factors: a Belgian case series. Laryngoscope.
168 Sayed-Noor AS, Sjoden GO. (2008). Subtrochanteric displaced insufficiency fracture after long-term alendronate therapy--a case report. Acta Orthop.
169 Sayed-Noor AS, Sjoden GO. (2009). Case reports: two femoral insufficiency fractures after long-term alendronate therapy. Clin Orthop Relat Res.
170 Schmitt NM, Schmitt J, Doren M. (2009). The role of physical activity in the prevention of osteoporosis in postmenopausal women-An update. Maturitas.
171 Schneider JP. (2006). Should bisphosphonates be continued indefinitely? An unusual fracture in a healthy woman on long-term alendronate. Geriatrics.
172 Schwartz HC. (2005). Bisphosphonate-associated osteonecrosis of the jaws. J Oral Maxillofac Surg.
173 Sedghizadeh PP, Stanley K, Caligiuri M, Hofkes S, Lowry B, Shuler CF. (2009). Oral bisphosphonate use and the prevalence of osteonecrosis of the jaw: an institutional inquiry. J Am Dent Assoc.
174 Seeman E, Kotowicz MA, Nash PT, Sambrook PN. (2009). Inappropriate prescribing for osteoporosis. Med J Aust.
175 Sharma NS, Ooi JL, Masselos K, Hooper MJ, Francis IC. (2008). Zoledronic acid infusion and orbital inflammatory disease. N Engl J Med.
176 Shlomi B, Levy Y, Kleinman S, Better H, Kahn A, Shtabsky A, et al. (2005). Harefuah.
177 Silverman SL. (2011). Defining zoledronate's duration of action and optimal dosing interval for an effective therapy. Current Osteoporosis Reports.
178 Siris ES, Baim S, Nattiv A. (2010). Primary Care Use of Frax(R): Absolute Fracture Risk Assessment in Postmenopausal Women and Older Men. Postgraduate Medicine.
179 Sitters MA, Caldwell CS. (2005). Bisphosphonates, dental care and osteonecrosis of the jaws. Tex Dent J.
180 Somford MP, Draijer FW, Thomassen BJ, Chavassieux PM, Boivin G, Papapoulos SE. (2009). Bilateral Fractures of the Femur Diaphysis in a Patient with Rheumatoid Arthritis on Long-term Treatment with Alendronate : Clues to the Mechanism of Increased Bone Fragility. J Bone Miner Res.
181 Song KE, Min YK, Lee JK, Lee KB, Chung YSea. (2008). A Probable Case of Oral Bisphosphonate-Associated Osteonecrosis of the Jaw and Recovery with Parathyroid Hormone Treatment. Current Therapeutic Research, Clinical and Experimental.
182 Spangler M, Phillips BB, Ross MB, Moores KG. (2011). Calcium supplementation in postmenopausal women to reduce the risk of osteoporotic fractures. Am J Health Syst Pharm.
183 Stack R, Tarr K. (2006). Drug-induced optic neuritis and uveitis secondary to bisphosphonates. N Z Med J.
184 Stefanick ML. (2006). Risk-benefit profiles of raloxifene for women. N Engl J Med.
185 Stevenson M, Davis S, Lloyd-Jones M, Beverley C. (2007). The clinical effectiveness and cost-effectiveness of strontium ranelate for the prevention of osteoporotic fragility fractures in postmenopausal women. Health Technol Assess.
186 Strampel W, Emkey R, Civitelli R. (2007). Safety considerations with bisphosphonates for the treatment of osteoporosis. Drug Saf.
187 Tabbara KF. (2008). Nodular scleritis following alendronate therapy. Ocul Immunol Inflamm.
188 Tan YL, Sims J, Chee SP. (2009). Bilateral uveitis secondary to bisphosphonate therapy. Ophthalmologica.
189 Tembe AG, B K, S SK, B C, J VR. (2007). Avascular necrosis of bone while on alendronate: Report of a case. Indian Journal of Rheumatology.
190 Terashima T, Hiramatsu K, Shimatani A, Matsuda M, Ogino H, Satomura Y, et al. (2006). An esophageal ulcer mimicking advanced esophageal cancer in a patient on alendronate sodium treatment for osteoporosis. Endoscopy.
191 Thumbigere-Math V, Sabino MC, Gopalakrishnan R, Huckabay S, Dudek AZ, Basu S, et al. (2009). Bisphosphonate-related osteonecrosis of the jaw: clinical features, risk factors, management, and treatment outcomes of 26 patients. J Oral Maxillofac Surg.
192 Toulis K, Anastasilakis A. (2010). Increased risk of serious infections in women with osteopenia or osteoporosis treated with denosumab. Osteoporos Int.
193 Trevisani VF, Riera R, Imoto AM, Saconato H, Atallah AN. (2008). Teriparatide (recombinant human parathyroid hormone 1-34) in postmenopausal women with osteoporosis: systematic review. Sao Paulo Med J.
194 Van den Wyngaert T, Huizing MT, Vermorken JB. (2006). Bisphosphonates and osteonecrosis of the jaw: cause and effect or a post hoc fallacy?. Ann Oncol.
195 Vasikaran SD. (2009). Association of low-energy femoral fractures with prolonged bisphosphonate use: a case--control study. Osteoporos Int.
196 Vestergaard P, Rejnmark L, Mosekilde L. (2006). Fracture reducing potential of hormone replacement therapy on a population level. Maturitas.
197 Vieillard MH, Maes JM, Penel G, Facon T, Magro L, Bonneterre J, et al. (2008). Thirteen cases of jaw osteonecrosis in patients on bisphosphonate therapy. Joint Bone Spine.
198 Visekruna M, Wilson D, McKiernan FE. (2008). Severely suppressed bone turnover and atypical skeletal fragility. J Clin Endocrinol Metab.
199 Wang HL, Weber D, McCauley LK. (2007). Effect of long-term oral bisphosphonates on implant wound healing: literature review and a case report. J Periodontol.
200 Wass JA. (2008). Biphosphonate-induced osteonecrosis of the jaws: CT and MRI spectrum of findings in 32 patients. Clin Radiol.
201 Watts NB. (2010). Bone: Bone density screening leads to reduced fracture risk. Nature Reviews Endocrinology.
202 Watts NB, Diab DL. (2010). Long-term use of bisphosphonates in osteoporosis. J Clin Endocrinol Metab.
203 Wong YK, Cheng JC. (2008). Bisphosphonate-related osteonecrosis of the jaws--report of 2 cases and strategies on prevention and management. Quintessence Int.
204 Wongchuensoontorn C, Liebehenschel N, Wagner K, Fakler O, Gutwald R, Schmelzeisen R, et al. (2009). Pathological fractures in patients caused by bisphosphonate-related osteonecrosis of the jaws: report of 3 cases. J Oral Maxillofac Surg.
205 Woodis CB. (2008). Once-yearly administered intravenous zoledronic acid for postmenopausal osteoporosis. Ann Pharmacother.
206 Wysowski DK. (2009). Reports of esophageal cancer with oral bisphosphonate use. N Engl J Med.
207 Wysowski DK. (2010). Oral bisphosphonates and oesophageal cancer. BMJ.
208 Wysowski DK, Chang JT. (2005). Alendronate and risedronate: reports of severe bone, joint, and muscle pain. Arch Intern Med.
209 Yanik B, Turkay C, Atalar H. (2007). Hepatotoxicity induced by alendronate therapy. Osteoporos Int.
210 Yarom N, Yahalom R, Shoshani Y, Hamed W, Regev E, Elad S. (2007). Osteonecrosis of the jaw induced by orally administered bisphosphonates: incidence, clinical features, predisposing factors and treatment outcome. Osteoporos Int.
211 Yeo AC, Lye KW, Poon CY. (2005). Bisphosphonate-related osteonecrosis of the jaws. Singapore Dent J.
212 Young-Min SA, Herbert L, Dick M, Fordham J. (2005). Weekly alendronate-induced acute pseudogout. Rheumatology (Oxford).
213 Zafran N, Liss Z, Peled R, Sherf M, Reuveni H. (2005). Incidence and causes for failure of treatment of women with proven osteoporosis. Osteoporos Int.

### Reject: No Enrollment Criteria (N=6)

1 Benderson D, Karakunnel J, Kathuria S, Badros A. (2006). Scleritis complicating zoledronic acid infusion. Clin Lymphoma Myeloma.
2 Bolland MJ, Siu AT, Mason BH, Horne AM, Ames RW, Grey AB, et al. (2011). Evaluation of the FRAX and Garvan fracture risk calculators in older women. J Bone Miner Res.
3 Dore DD, Trivedi AN, Mor V, Friedman JH, Lapane KL. (2009). Atypical antipsychotic use and risk of fracture in persons with Parkinsonism. Mov Disord.
4 Herbozo PJ, Briones DL, Ferres AJ, Torrealba RL. (2007). Severe spontaneous cases of bisphosphonate-related osteonecrosis of the jaws. J Oral Maxillofac Surg.
5 Jung TI, Hoffmann F, Glaeske G, Felsenberg D. (2009). Disease-specific risk for an osteonecrosis of the jaw under bisphosphonate therapy. J Cancer Res Clin Oncol.
6 Woo C, Gao G, Wade S, Hochberg MC. (2010). Gastrointestinal side effects in postmenopausal women using osteoporosis therapy: 1-year findings in the POSSIBLE US study. Curr Med Res Opin.

### Reject: No Relevant Interventions (N=45)

1 Adami S. (2006). Protelos: nonvertebral and hip antifracture efficacy in postmenopausal osteoporosis. Bone.
2 Adami S. (2008). Full length parathyroid hormone, PTH(1-84), for the treatment of severe osteoporosis in postmenopausal women. Curr Med Res Opin.
3 Arase Y, Suzuki F, Suzuki Y, Akuta N, Kobayashi M, Kawamura Y, et al. (2008). Prolonged-efficacy of bisphosphonate in postmenopausal women with osteoporosis and chronic liver disease. J Med Virol.
4 Blake GM, Fogelman I. (2006). Strontium ranelate: a novel treatment for postmenopausal osteoporosis: a review of safety and efficacy. Clin Interv Aging.
5 Boada A, Carrascosa JM, Leal L, Ferrandiz C. (2009). Generalized cutaneous drug eruption due to strontium ranelate. J Eur Acad Dermatol Venereol.
6 Collette J, Bruyere O, Kaufman JM, Lorenc R, Felsenberg D, Spector TD, et al. (2009). Vertebral anti-fracture efficacy of strontium ranelate according to pre-treatment bone turnover. Osteoporos Int.
7 Cummings SR, Ensrud K, Delmas PD, Lacroix AZ, Vukicevic S, Reid DM, et al. (2010). Lasofoxifene in Postmenopausal Women with Osteoporosis. N Engl J Med.
8 Delmas PD. (2005). Clinical effects of strontium ranelate in women with postmenopausal osteoporosis. Osteoporos Int.
9 Fogelman I, Fordham JN, Fraser WD, Spector TD, Christiansen C, Morris SA, et al. (2008). Parathyroid hormone(1-84) treatment of postmenopausal women with low bone mass receiving hormone replacement therapy. Calcif Tissue Int.
10 Fujita T, Orimo H, Inoue T, Kaneda K, Sakurai M, Morita R, et al. (2007). Clinical effect of bisphosphonate and vitamin D on osteoporosis: reappraisal of a multicenter double-blind clinical trial comparing etidronate and alfacalcidol. J Bone Miner Metab.
11 Greenspan SL, Bone HG, Ettinger MP, Hanley DA, Lindsay R, Zanchetta JR, et al. (2007). Effect of recombinant human parathyroid hormone (1-84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med.
12 Groves C, McMenamin ME, Casey M, Barnes L. (2008). Interstitial granulomatous reaction to strontium ranelate. Arch Dermatol.
13 Hwang JS, Chen JF, Yang TS, Wu DJ, Tsai KS, Ho C, et al. (2008). The effects of strontium ranelate in Asian women with postmenopausal osteoporosis. Calcif Tissue Int.
14 Jonville-Bera AP, Crickx B, Aaron L, Hartingh I, Autret-Leca E. (2009). Strontium ranelate-induced DRESS syndrome: first two case reports. Allergy.
15 Kanis JA, Johansson H, Oden A, McCloskey EV. (2009). Bazedoxifene reduces vertebral and clinical fractures in postmenopausal women at high risk assessed with FRAX. Bone.
16 Kanis JA, Johansson H, Oden A, McCloskey EV. (2011). A meta-analysis of the effect of strontium ranelate on the risk of vertebral and non-vertebral fracture in postmenopausal osteoporosis and the interaction with FRAX((R)). Osteoporos Int.
17 Lee HY, Lie D, Lim KS, Thirumoorthy T, Pang SM. (2009). Strontium ranelate-induced toxic epidermal necrolysis in a patient with post-menopausal osteoporosis. Osteoporos Int.
18 Makras P, Hamdy NA, Zwinderman AH, Ballieux BE, Papapoulos SE. (2009). Bisphosphonate dose and incidence of fractures in postmenopausal osteoporosis. Bone.
19 Manfredi M, Merigo E, Guidotti R, Meleti M, Vescovi P. (2011). Bisphosphonate-related osteonecrosis of the jaws: a case series of 25 patients affected by osteoporosis. Int J Oral Maxillofac Surg.
20 Matsumoto T, Hagino H, Shiraki M, Fukunaga M, Nakano T, Takaoka K, et al. (2009). Effect of daily oral minodronate on vertebral fractures in Japanese postmenopausal women with established osteoporosis: a randomized placebo-controlled double-blind study. Osteoporos Int.
21 Meunier PJ, Roux C, Ortolani S, Diaz-Curiel M, Compston J, Marquis P, et al. (2009). Effects of long-term strontium ranelate treatment on vertebral fracture risk in postmenopausal women with osteoporosis. Osteoporos Int.
22 Meunier PJ, Roux C, Seeman E, Ortolani S, Badurski JE, Spector TD, et al. (2004). The effects of strontium ranelate on the risk of vertebral fracture in women with postmenopausal osteoporosis. N Engl J Med.
23 Meunier PJ, Slosman DO, Delmas PD, Sebert JL, Brandi ML, Albanese C, et al. (2002). Strontium ranelate: dose-dependent effects in established postmenopausal vertebral osteoporosis--a 2-year randomized placebo controlled trial. J Clin Endocrinol Metab.
24 Miller RG, Chretien KC, Meoni LA, Liu YP, Klag MJ, Levine MA. (2005). Comparison of intravenous pamidronate to standard therapy for osteoporosis: use in patients unable to take oral bisphosphonates. J Clin Rheumatol.
25 Monegal A, Guanabens N, Suarez MJ, Suarez F, Clemente G, Garcia-Gonzalez M, et al. (2009). Pamidronate in the prevention of bone loss after liver transplantation: a randomized controlled trial. Transpl Int.
26 O'Donnell S, Cranney A, Wells GA, Adachi JD, Reginster JY. (2006). Strontium ranelate for preventing and treating postmenopausal osteoporosis. Cochrane Database Syst Rev.
27 Ozkurt ZN, Guliter S, Keles I, Keles H. (2005). Risedronate-induced intravascular haemolysis complicated by acute tubular necrosis. Clin Rheumatol.
28 Rabenda V, Reginster JY. (2010). Positive impact of compliance to strontium ranelate on the risk of nonvertebral osteoporotic fractures. Osteoporos Int.
29 Ramasamy B, Quah S, Sahni JN, Palimar P. (2007). Bilateral severe fibrinous anterior uveitis--an unusual complication of pamidronate therapy exacerbated by topical latanoprost. J Ocul Pharmacol Ther.
30 Reginster JY, Bruyere O, Sawicki A, Roces-Varela A, Fardellone P, Roberts A, et al. (2009). Long-term treatment of postmenopausal osteoporosis with strontium ranelate: Results at 8 years. Bone.
31 Reginster JY, Deroisy R, Dougados M, Jupsin I, Colette J, Roux C. (2002). Prevention of early postmenopausal bone loss by strontium ranelate: the randomized, two-year, double-masked, dose-ranging, placebo-controlled PREVOS trial. Osteoporos Int.
32 Reginster JY, Felsenberg D, Boonen S, Diez-Perez A, Rizzoli R, Brandi ML, et al. (2008). Effects of long-term strontium ranelate treatment on the risk of nonvertebral and vertebral fractures in postmenopausal osteoporosis: Results of a five-year, randomized, placebo-controlled trial. Arthritis Rheum.
33 Reginster JY, Meunier PJ. (2003). Strontium ranelate phase 2 dose-ranging studies: PREVOS and STRATOS studies. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA.
34 Reginster JY, Seeman E, De Vernejoul MC, Adami S, Compston J, Phenekos C, et al. (2005). Strontium ranelate reduces the risk of nonvertebral fractures in postmenopausal women with osteoporosis: Treatment of Peripheral Osteoporosis (TROPOS) study. J Clin Endocrinol Metab.
35 Rizzoli R. (2005). A new treatment for post-menopausal osteoporosis: strontium ranelate. J Endocrinol Invest.
36 Roux C, Fechtenbaum J, Kolta S, Isaia G, Andia JB, Devogelaer JP. (2008). Strontium ranelate reduces the risk of vertebral fracture in young postmenopausal women with severe osteoporosis. Ann Rheum Dis.
37 Roux C, Reginster JY, Fechtenbaum J, Kolta S, Sawicki A, Tulassay Z, et al. (2006). Vertebral fracture risk reduction with strontium ranelate in women with postmenopausal osteoporosis is independent of baseline risk factors. J Bone Miner Res.
38 Sainz M, del Pozo JG, Arias LH, Carvajal A. (2009). Strontium ranelate may cause alopecia. Bmj.
39 Sandhu SK, Nguyen ND, Center JR, Pocock NA, Eisman JA, Nguyen TV. (2009). Prognosis of fracture: evaluation of predictive accuracy of the FRAX algorithm and Garvan nomogram. Osteoporos Int.
40 Sato S, Takada T, Katsuki Y, Kimura N, Kaneko Y, Suwa A, et al. (2008). Longterm effect of intermittent cyclical etidronate therapy on corticosteroid-induced osteoporosis in Japanese patients with connective tissue disease: 7-year followup. J Rheumatol.
41 Seeman E, Devogelaer JP, Lorenc R, Spector T, Brixen K, Balogh A, et al. (2008). Strontium ranelate reduces the risk of vertebral fractures in patients with osteopenia. J Bone Miner Res.
42 Seeman E, Vellas B, Benhamou C, Aquino JP, Semler J, Kaufman JM, et al. (2006). Strontium ranelate reduces the risk of vertebral and nonvertebral fractures in women eighty years of age and older. J Bone Miner Res.
43 Tournis S, Economopoulos D, Lyritis GP. (2006). Strontium ranelate: a novel treatment in postmenopausal osteoporosis. Ann N Y Acad Sci.
44 Watanabe H, Yamada S, Anayama S, Sato E, Maekawa S, Sugiyama H, et al. (2006). Pseudogout attack induced during etidronate disodium therapy. Mod Rheumatol.
45 Wells GA, Cranney A, Peterson J, Boucher M, Shea B, Robinson V, et al. (2008). Etidronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev.

### Reject: No Relevant Outcomes (N=80)

1 Adami S, Isaia G, Luisetto G, Minisola S, Sinigaglia L, Silvestri S, et al. (2008). Osteoporosis treatment and fracture incidence: the ICARO longitudinal study. Osteoporos Int.
2 Aurich-Barrera B, Wilton L, Harris S, Shakir SA. (2006). Ophthalmological events in patients receiving risedronate: summary of information gained through follow-up in a prescription-event monitoring study in England. Drug Saf.
3 Barrett-Connor E, Cox DA, Song J, Mitlak B, Mosca L, Grady D. (2009). Raloxifene and risk for stroke based on the framingham stroke risk score. Am J Med.
4 Bell KJ, Hayen A, Macaskill P, Irwig L, Craig JC, Ensrud K, et al. (2009). Value of routine monitoring of bone mineral density after starting bisphosphonate treatment: secondary analysis of trial data. BMJ.
5 Bisdas S, Chambron Pinho N, Smolarz A, Sader R, Vogl TJ, Mack MG. (2008). Biphosphonate-induced osteonecrosis of the jaws: CT and MRI spectrum of findings in 32 patients. Clin Radiol.
6 Blonk MC, Erdtsieck RJ, Wernekinck MG, Schoon EJ. (2007). The fracture and osteoporosis clinic: 1-year results and 3-month compliance. Bone.
7 Boivin G, Meunier PJ. (2003). The mineralization of bone tissue: a forgotten dimension in osteoporosis research. Osteoporos Int.
8 Bolland MJ, Grey AB, Gamble GD, Reid IR. (2010). Effect of osteoporosis treatment on mortality: A meta-analysis. Obstetrical and Gynecological Survey.
9 Bolton-Smith C, McMurdo ME, Paterson CR, Mole PA, Harvey JM, Fenton ST, et al. (2007). Two-year randomized controlled trial of vitamin K1 (phylloquinone) and vitamin D3 plus calcium on the bone health of older women. J Bone Miner Res.
10 Boonen S, Marin F, Obermayer-Pietsch B, Simoes ME, Barker C, Glass EV, et al. (2008). Effects of previous antiresorptive therapy on the bone mineral density response to two years of teriparatide treatment in postmenopausal women with osteoporosis. J Clin Endocrinol Metab.
11 Brookhart MA, Avorn J, Katz JN, Finkelstein JS, Arnold M, Polinski JM, et al. (2007). Gaps in treatment among users of osteoporosis medications: the dynamics of noncompliance. Am J Med.
12 Buckwalter JG, Geiger AM, Parsons TD, Handler J, Howes J, Lehmer RR. (2007). Cognitive effects of short-term use of raloxifene: a randomized clinical trial. Int J Neurosci.
13 Burkiewicz JS, Scarpace SL, Bruce SP. (2009). Denosumab in osteoporosis and oncology. Ann Pharmacother.
14 Cadarette SM, Katz JN, Brookhart MA, Sturmer T, Stedman MR, Solomon DH. (2008). Relative effectiveness of osteoporosis drugs for preventing nonvertebral fracture. Annals of Internal Medicine.
15 Chan SS, Rosenberg ZS, Chan K, Capeci C. (2010). Subtrochanteric femoral fractures in patients receiving long-term alendronate therapy: imaging features. AJR Am J Roentgenol.
16 Checa MA, Del Rio L, Rosales J, Nogues X, Vila J, Carreras R. (2005). Timing of follow-up densitometry in hormone replacement therapy users for optimal osteoporosis prevention. Osteoporos Int.
17 Chen P, Miller PD, Delmas PD, Misurski DA, Krege JH. (2005). Change in bone mineral density (BMD) and fracture risk reduction in teriparatide-treated women with osteoporosis. Journal of Bone and Mineral Research.
18 Conley E, Muth B, Samaniego M, Lotfi M, Voss B, Armbrust M, et al. (2008). Bisphosphonates and bone fractures in long-term kidney transplant recipients. Transplantation.
19 Cotte FE, Cortet B, Lafuma A, Avouac B, Hasnaoui AE, Fardellone P, et al. (2008). A model of the public health impact of improved treatment persistence in post-menopausal osteoporosis in France. Joint Bone Spine.
20 Curtis JR, Westfall AO, Cheng H, Delzell E, Saag KG. (2008). Risk of hip fracture after bisphosphonate discontinuation: implications for a drug holiday. Osteoporos Int.
21 Danese MD, Badamgarav E, Bauer DC. (2009). The Effect of Adherence on Lifetime Fractures in Osteoporotic Women Treated with Daily and Weekly Bisphosphonates. J Bone Miner Res.
22 Delmas PD, Adami S, Strugala C, Stakkestad JA, Reid DM, et al. (2006). Intravenous Ibandronate Injections in Postmenopausal Women With osteoporosis: one-year results from the dosing intravenous administration study. Arthritis and Rheumatism.
23 Demonaco HJ. (2009). Patient- and physician-oriented web sites and drug surveillance: bisphosphonates and severe bone, joint, and muscle pain. Arch Intern Med.
24 den Uyl D, Geusens PP, van Berkum FN, Houben HH, Jebbink MC, Lems WF. (2010). Patient preference and acceptability of calcium plus vitamin D3 supplementation: a randomised, open, cross-over trial. Clin Rheumatol.
25 Donaldson MG, Palermo L, Schousboe JT, Ensrud KE, Hochberg MC, Cummings SR. (2009). FRAX and risk of vertebral fractures: the fracture intervention trial. J Bone Miner Res.
26 Duarte JW, Bolge SC, Sen SS. (2007). An evaluation of patients' preferences for osteoporosis medications and their attributes: the PREFER-International study. Clin Ther.
27 Dunford JE, Kwaasi AA, Rogers MJ, Barnett BL, Ebetino FH, Russell RG, et al. (2008). Structure-activity relationships among the nitrogen containing bisphosphonates in clinical use and other analogues: time-dependent inhibition of human farnesyl pyrophosphate synthase. J Med Chem.
28 Dusdal K, Grundmanis J, Luttin K, Ritchie P, Rompre C, Sidhu R, et al. (2011). Effects of therapeutic exercise for persons with osteoporotic vertebral fractures: a systematic review. Osteoporos Int.
29 Ensrud KE, Lui LY, Taylor BC, Schousboe JT, Donaldson MG, Fink HA, et al. (2009). A comparison of prediction models for fractures in older women: is more better?. Arch Intern Med.
30 Frampton JE. (2009). Risedronate on two consecutive days per month. Drugs Aging.
31 Francis KL, Matthews BL, Van Mechelen W, Bennell KL, Osborne RH. (2009). Effectiveness of a community-based osteoporosis education and self-management course: a wait list controlled trial. Osteoporos Int.
32 Franek E, Talalaj M, Wichrowska H, Czerwienska B, Filip R, Safranow K, et al. (2008). Common drug switching during long-term antiresorptive treatment: experience of four osteoporosis centers in Poland (2001-2005). Aging Clin Exp Res.
33 Gallagher JC, Rosen CJ, Chen P, Misurski DA, Marcus R. (2006). Response rate of bone mineral density to teriparatide in postmenopausal women with osteoporosis. Bone.
34 Goldstein SR, Neven P, Cummings S, Colgan T, Runowicz CD, Krpan D, et al. (2010). Postmenopausal Evaluation and Risk Reduction With Lasofoxifene trial: 5-year gynecological outcomes. Menopause.
35 Greenspan SL, Bone HG, Marriott TBEa. (2005). Preventing the first vertebral fracture in postmenopausal women with low bone mass using PTH(1-84): results from the TOP study (Abstract). J Bone Miner Res.
36 Grima DT, Papaioannou A, Airia P, Ioannidis G, Adachi JD. (2010). Adverse events, bone mineral density and discontinuation associated with generic alendronate among postmenopausal women previously tolerant of brand alendronate: a retrospective cohort study. BMC Musculoskelet Disord.
37 Hiligsmann M, Vanoverberghe M, Neuprez A, Bruyere O, Reginster JY. (2010). Cost-effectiveness of strontium ranelate for the prevention and treatment of osteoporosis. Expert Review of Pharmacoeconomics and Outcomes Research.
38 Hoes JN, Jacobs JW, Hulsmans HM, De Nijs RN, Lems WF, Bruyn GA, et al. (2010). High incidence rate of vertebral fractures during chronic prednisone treatment, in spite of bisphosphonate or alfacalcidol use. Extension of the alendronate or alfacalcidol in glucocorticoid-induced osteoporosis-trial. Clin Exp Rheumatol.
39 Imai K, Ohnishi I, Matsumoto T, Yamamoto S, Nakamura K. (2009). Assessment of vertebral fracture risk and therapeutic effects of alendronate in postmenopausal women using a quantitative computed tomography-based nonlinear finite element method. Osteoporosis International.
40 Ishani A, Blackwell T, Jamal SA, Cummings SR, Ensrud KE. (2008). The effect of raloxifene treatment in postmenopausal women with CKD. J Am Soc Nephrol.
41 Johnell K, Fastbom J. (2009). Undertreatment of osteoporosis in the oldest old? A nationwide study of over 700,000 older people. Arch Osteoporos.
42 Jones M, Wilkinson A. (2006). Adverse effects and persistence with therapy in patients taking oral alendronate, etidronate, or risedronate: systematic reviews. Report commisioned by NHS R&D HTA Programme on behalf of the National Institute for Clinical Excellence.
43 Jonsson B, Strom O, Eisman JA, Papaioannou A, Siris ES, Tosteson A, et al. (2011). Cost-effectiveness of Denosumab for the treatment of postmenopausal osteoporosis. Osteoporos Int.
44 Kaji H, Hisa I, Inoue Y, Naito J, Sugimoto T, Kasuga M. (2009). Analysis of factors affecting increase in bone mineral density at lumbar spine by bisphosphonate treatment in postmenopausal osteoporosis. J Bone Miner Metab.
45 Kerschan-Schindl K, Uher E, Kainberger F, Kaider A, Ghanem AH, Presinger E. (2000). Long-term home exercise program: effect in women at high risk of fracture. Arch Phys Med Rehabil.
46 Kimber CM, Grimmer-Somers KA. (2009). Multifaceted guideline implementation strategies improve early identification and management of osteoporosis. Aust Health Rev.
47 Langdahl BL, Marin F, Shane E, Dobnig H, Zanchetta JR, Maricic M, et al. (2009). Teriparatide versus alendronate for treating glucocorticoid-induced osteoporosis: an analysis by gender and menopausal status. Osteoporos Int.
48 Langdahl BL, Rajzbaum G, Jakob F, Karras D, Ljunggren O, Lems WF, et al. (2009). Reduction in Fracture Rate and Back Pain and Increased Quality of Life in Postmenopausal Women Treated with Teriparatide: 18-Month Data from the European Forsteo Observational Study (EFOS). Calcif Tissue Int.
49 Lewiecki EM, Binkley N. (2009). Evidence-based medicine, clinical practice guidelines, and common sense in the management of osteoporosis. Endocr Pract.
50 Lewiecki EM, Miller PD, McClung MR, Cohen SB, Bolognese MA, Liu Y, et al. (2007). Two-year treatment with denosumab (AMG 162) in a randomized phase 2 study of postmenopausal women with low BMD. J Bone Miner Res.
51 Majima T, Shimatsu A, Komatsu Y, Satoh N, Fukao A, Ninomiya K, et al. (2009). Effects of risedronate or alfacalcidol on bone mineral density, bone turnover, back pain, and fractures in Japanese men with primary osteoporosis: results of a two-year strict observational study. J Bone Miner Metab.
52 Martino S, Disch D, Dowsett SA, Keech CA, Mershon JL. (2005). Safety assessment of raloxifene over eight years in a clinical trial setting. Curr Med Res Opin.
53 Maugeri D, Russo E, Luca S, Leotta C, Mamazza G, Sorace R, et al. (2009). Changes of the quality-of-life under the treatment of severe senile osteoporosis with teriparatide. Arch Gerontol Geriatr.
54 McHorney CA, Victor Spain C, Alexander CM, Simmons J. (2009). Validity of the adherence estimator in the prediction of 9-month persistence with medications prescribed for chronic diseases: a prospective analysis of data from pharmacy claims. Clin Ther.
55 Meyer HE, Lofthus CM, Sogaard AJ, Falch JA. (2009). Change in the use of hormone replacement therapy and the incidence of fracture in Oslo. Osteoporos Int.
56 Miller PD. (2008). Non-vertebral fracture risk reduction with oral bisphosphonates: challenges with interpreting clinical trial data. Curr Med Res Opin.
57 Miyakoshi N, Shimada Y, Ando S, Minato T, Itoi E. (2006). Effects of alfacalcidol alone or in combination with elcatonin on incidence of osteoporotic vertebral fractures in postmenopausal women with spondylosis. J Bone Miner Metab.
58 Nikander R, Sievanen H, Heinonen A, Daly RM, Uusi-Rasi K, Kannus P. (2010). Targeted exercise against osteoporosis: A systematic review and meta-analysis for optimising bone strength throughout life. BMC Med.
59 O'Sullivan SM, Grey AB, Singh R, Reid IR. (2006). Bisphosphonates in pregnancy and lactation-associated osteoporosis. Osteoporos Int.
60 Parikh S, Avorn J, Solomon DH. (2009). Pharmacological management of osteoporosis in nursing home populations: a systematic review. J Am Geriatr Soc.
61 Qaseem A, Snow V, Shekelle P, Hopkins R, Forciea MA, Owens DK. (2008). Pharmacologic treatment of low bone density or osteoporosis to prevent fractures: A clinical practice guideline from the American College of Physicians. Annals of Internal Medicine.
62 Rajzbaum G, Jakob F, Karras D, Ljunggren O, Lems WF, Langdahl BL, et al. (2008). Characterization of patients in the European Forsteo Observational Study (EFOS): postmenopausal women entering teriparatide treatment in a community setting. Curr Med Res Opin.
63 Reid DM, Hosking D, Kendler D, Brandi ML, Wark JD, Marques-Neto JF, et al. (2008). A comparison of the effect of alendronate and risedronate on bone mineral density in postmenopausal women with osteoporosis: 24-month results from FACTS-International. Int J Clin Pract.
64 Reid IR, Gamble GD, Mesenbrink P, Lakatos P, Black DM. (2010). Characterization of and risk factors for the acute-phase response after zoledronic acid. J Clin Endocrinol Metab.
65 Richards JB, Cherkas LF, Spector TD. (2007). An analysis of which anti-osteoporosis therapeutic regimen would improve compliance in a population of elderly adults. Curr Med Res Opin.
66 Robbins J, Aragaki AK, Kooperberg C, Watts N, Wactawski-Wende J, Jackson RD, et al. (2007). Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA.
67 Roux C, Goldstein JL, Zhou X, Klemes A, Lindsay R. (2011). Vertebral fracture efficacy during risedronate therapy in patients using proton pump inhibitors. Osteoporos Int.
68 Saag KG, Geusens P. (2009). Progress in osteoporosis and fracture prevention: focus on postmenopausal women. Arthritis Res Ther.
69 Saag KG, Shane E, Boonen S, Marin F, Donley DW, Taylor KA, et al. (2007). Teriparatide or alendronate in glucocorticoid-induced osteoporosis. N Engl J Med.
70 Sambrook P, Cranney A, Adachi JD. (2010). Risk reduction of non-vertebral fractures with intravenous ibandronate: post-hoc analysis from DIVA. Curr Med Res Opin.
71 Sato Y, Iwamoto J, Honda Y. (2010). An Open-Label Trial Comparing Alendronate and Alphacalcidol in Reducing Falls and Hip Fractures in Disabled Stroke Patients. J Stroke Cerebrovasc Dis.
72 Sedghizadeh PP, Kumar SK, Gorur A, Schaudinn C, Shuler CF, Costerton JW. (2009). Microbial biofilms in osteomyelitis of the jaw and osteonecrosis of the jaw secondary to bisphosphonate therapy. J Am Dent Assoc.
73 Shea B, Bonaiuti D, Iovine R, Negrini S, Robinson V, Kemper HC, et al. (2004). Cochrane Review on exercise for preventing and treating osteoporosis in postmenopausal women. Eura Medicophys.
74 Silverman SL, Cummings SR, Watts NB. (2008). Recommendations for the clinical evaluation of agents for treatment of osteoporosis: consensus of an expert panel representing the American Society for Bone and Mineral Research (ASBMR), the International Society for Clinical Densitometry (ISCD), and the National Osteoporosis Foundation (NOF). J Bone Miner Res.
75 Silverman SL, Shen W, Minshall ME, Xie S, Moses KH. (2007). Prevalence of depressive symptoms in postmenopausal women with low bone mineral density and/or prevalent vertebral fracture: results from the Multiple Outcomes of Raloxifene Evaluation (MORE) study. J Rheumatol.
76 Takata S, Abbaspour A, Yonezu H, Yasui N. (2007). Differences of therapeutic effects on regional bone mineral density and markers of bone mineral metabolism between alendronate and alfacalcidol in Japanese osteoporotic women. J Med Invest.
77 Vanelli M, Pedan A, Liu N, Hoar J, Messier D, Kiarsis K. (2009). The role of patient inexperience in medication discontinuation: a retrospective analysis of medication nonpersistence in seven chronic illnesses. Clin Ther.
78 Vestergaard P, Rejnmark L, Mosekilde L. (2011). Are antiresorptive drugs effective against fractures in patients with diabetes?. Calcif Tissue Int.
79 Waalen J, Bruning AL, Peters MJ, Blau EM. (2009). A telephone-based intervention for increasing the use of osteoporosis medication: a randomized controlled trial. Am J Manag Care.
80 Zanchetta JR, Bogado CE, Cisari C, Aslanidis S, Greisen H, Fox J, et al. (2010). Treatment of postmenopausal women with osteoporosis with PTH(1-84) for 36 months: treatment extension study. Curr Med Res Opin.

### Reject: Population Not Relevant (N=40)

1 Abu-Id MH, Warnke PH, Gottschalk J, Springer I, Wiltfang J, Acil Y, et al. (2008). “Bis-phossy jaws” - high and low risk factors for bisphosphonate-induced osteonecrosis of the jaw. J Craniomaxillofac Surg.
2 Baqain ZH, Sawair FA, Tamimi Z, Bsoul N, Al Edwan G, Almasad JK, et al. (2010). Osteonecrosis of jaws related to intravenous bisphosphonates: the experience of a Jordanian teaching hospital. Ann R Coll Surg Engl.
3 Battley J, Jayathissa S, Seneviratne E. (2006). Jaw osteonecrosis associated with bisphosphonates. N Z Med J.
4 Bhoopalam N, Campbell SC, Moritz T, Broderick WR, Iyer P, Arcenas AG, et al. (2009). Intravenous Zoledronic Acid to Prevent Osteoporosis in a Veteran Population With Multiple Risk Factors for Bone Loss on Androgen Deprivation Therapy. Journal of Urology.
5 Bischoff-Ferrari HA, Rees JR, Grau MV, Barry E, Gui J, Baron JA. (2008). Effect of calcium supplementation on fracture risk: a double-blind randomized controlled trial. Am J Clin Nutr.
6 Braun E, Iacono VJ. (2006). Bisphosphonates: case report of nonsurgical periodontal therapy and osteochemonecrosis. Int J Periodontics Restorative Dent.
7 Carter G, Goss AN, Doecke C. (2005). Bisphosphonates and avascular necrosis of the jaw: a possible association. Med J Aust.
8 Curtis JR, McClure LA, Delzell E, Howard VJ, Orwoll E, Saag KG, et al. (2009). Population-based fracture risk assessment and osteoporosis treatment disparities by race and gender. J Gen Intern Med.
9 Durie BG, Katz M, Crowley J. (2005). Osteonecrosis of the jaw and bisphosphonates. N Engl J Med.
10 Gallego L, Junquera L. (2009). Consequence of therapy discontinuation in bisphosphonate-associated osteonecrosis of the jaws. Br J Oral Maxillofac Surg.
11 Gilhotra JS, Gilhotra AK, Holdaway IM, Donaldson ML. (2006). Acute retinal pigment epitheliitis associated with intravenous bisphosphonate. Br J Ophthalmol.
12 Kanat O, Ozet A, Ataergin S, Kuzhan O, Arpaci F, Ozturk B, et al. (2007). Bisphosphonate treatment as a cause of jaw osteonecrosis. Oral Dis.
13 Katz H. (2005). Endodontic implications of bisphosphonate-associated osteonecrosis of the jaws: a report of three cases. J Endod.
14 Khan AM, Sindwani R. (2009). Bisphosphonate-related osteonecrosis of the skull base. Laryngoscope.
15 Kumar V, Pass B, Guttenberg SA, Ludlow J, Emery RW, Tyndall DA, et al. (2007). Bisphosphonate-related osteonecrosis of the jaws: a report of three cases demonstrating variability in outcomes and morbidity. J Am Dent Assoc.
16 Magopoulos C, Karakinaris G, Telioudis Z, Vahtsevanos K, Dimitrakopoulos I, Antoniadis K, et al. (2007). Osteonecrosis of the jaws due to bisphosphonate use. A review of 60 cases and treatment proposals. Am J Otolaryngol.
17 Marie PJ, Ammann P, Boivin G, Rey C. (2001). Mechanisms of action and therapeutic potential of strontium in bone. Calcif Tissue Int.
18 Mauri D, Valachis A, Polyzos IP, Polyzos NP, Kamposioras K, Pesce LL. (2009). Osteonecrosis of the jaw and use of bisphosphonates in adjuvant breast cancer treatment: a meta-analysis. Breast Cancer Res Treat.
19 Melo MD, Obeid G. (2005). Osteonecrosis of the maxilla in a patient with a history of bisphosphonate therapy. J Can Dent Assoc.
20 Merigo E, Manfredi M, Meleti M, Corradi D, Vescovi P. (2005). Jaw bone necrosis without previous dental extractions associated with the use of bisphosphonates (pamidronate and zoledronate): a four-case report. J Oral Pathol Med.
21 Migliorati CA. (2003). Bisphosphanates and oral cavity avascular bone necrosis. J Clin Oncol.
22 Mortensen M, Lawson W, Montazem A. (2007). Osteonecrosis of the jaw associated with bisphosphonate use: Presentation of seven cases and literature review. Laryngoscope.
23 Naik NH, Russo TA. (2009). Bisphosphonate-related osteonecrosis of the jaw: the role of actinomyces. Clin Infect Dis.
24 Navarro M, Lopez R, Alana M, Ocana A, Leno R, Sanchez F, et al. (2007). Tonic-clonic seizure as the presentation symptom of severe hypocalcemia secondary to zoledronic acid administration. J Palliat Med.
25 Oh HK, Chambers MS, Martin JW, Lim HJ, Park HJ. (2009). Osteoradionecrosis of the mandible: treatment outcomes and factors influencing the progress of osteoradionecrosis. J Oral Maxillofac Surg.
26 Oltolina A, Achilli A, Lodi G, Demarosi F, Sardella A. (2005). Osteonecrosis of the jaws in patients treated with bisphosphonates. Review of the literature and the Milan experience. Minerva Stomatol.
27 Polizzotto MN, Cousins V, Schwarer AP. (2006). Bisphosphonate-associated osteonecrosis of the auditory canal. Br J Haematol.
28 Pozzi S, Marcheselli R, Falorio S, Masini L, Stelitano C, Falcone A, et al. (2009). Bisphosphonates-associated osteonecrosis of the jaw: A long-term follow-up of a series of 35 cases observed by GISL and evaluation of its frequency over time. Am J Hematol.
29 Pozzi S, Marcheselli R, Sacchi S, Baldini L, Angrilli F, Pennese E, et al. (2007). Bisphosphonate-associated osteonecrosis of the jaw: A review of 35 cases and an evaluation of its frequency in multiple myeloma patients. Leuk Lymphoma.
30 Reilly MM. (2007). Osteonecrosis of the jaw in a patient receiving bisphosphonate therapy. Oncol Nurs Forum.
31 Reiriz AB, De Zorzi Pde M, Lovat CP. (2008). Bisphosphonates and osteonecrosis of the jaw: a case report. Clinics (Sao Paulo).
32 Salesi N, Pistilli R, Marcelli V, Govoni FA, Bozza F, Bossone G, et al. (2006). Bisphosphonates and oral cavity avascular bone necrosis: a review of twelve cases. Anticancer Res.
33 Sanna G, Zampino MG, Pelosi G, Nole F, Goldhirsch A. (2005). Jaw avascular bone necrosis associated with long-term use of biphosphonates. Ann Oncol.
34 Sarathy AP, Bourgeois SL, Goodell GG. (2005). Bisphosphonate-associated osteonecrosis of the jaws and endodontic treatment: two case reports. J Endod.
35 Sarzi Amade D, Tallarico M, Loreti MC, Montecchi PP, Niccoli A. (2008). Clinical guidelines for prevention of osteonecrosis of the jaws in patients in treatment with bisphosphonates: literature review and report of three cases. Minerva Stomatol.
36 Sayin M, Yazici G. (2009). Hyperparathyroidism secondary to zoledronic acid infusion: case report. Support Care Cancer.
37 Shirota T, Nakamura A, Matsui Y, Hatori M, Nakamura M, Shintani S. (2009). Bisphosphonate-related osteonecrosis of the jaw around dental implants in the maxilla: report of a case. Clin Oral Implants Res.
38 Stumpe MR, Chandra RK, Yunus F, Samant S. (2009). Incidence and risk factors of bisphosphonate-associated osteonecrosis of the jaws. Head Neck.
39 Topakian R, Stieglbauer K, Rotaru J, Haring HP, Aichner FT, Pichler R. (2006). Hypocalcemic choreoathetosis and tetany after bisphosphonate treatment. Mov Disord.
40 Young P, Finn BC, Bruetman JE. (2008). Numb chin syndrome by biphosphonates. Eur J Intern Med.

## Excluded at Long Form

### Adherence, Inappropriate for Analysis (N=8)

1 Cauley JA, Lacroix AZ, Robbins JA, Larson J, Wallace R, Wactawski-Wende J, et al. (2009). Baseline serum estradiol and fracture reduction during treatment with hormone therapy: The Women's Health Initiative randomized trial. Osteoporos Int.
2 Lewiecki EM, Babbitt AM, Piziak VK, Ozturk ZE, Bone HG. (2008). Adherence to and gastrointestinal tolerability of monthly oral or quarterly intravenous ibandronate therapy in women with previous intolerance to oral bisphosphonates: a 12-month, open-label, prospective evaluation. Clin Ther.
3 Meijer WM, Beest FJ, Olson M, Herings RM. (2008). Relationship between duration of compliant bisphosphonate use and the risk of osteoporotic fractures. Curr Med Res Opin.
4 Pasion EG, Sivananthan SK, Kung AW, Chen SH, Chen YJ, Mirasol R, et al. (2007). Comparison of raloxifene and bisphosphonates based on adherence and treatment satisfaction in postmenopausal Asian women. J Bone Miner Metab.
5 Segal E, Ish-Shalom S. (2009). Two years adherence to anti-osteoporotic medications in postmenopausal Israeli women. Arch Gerontol Geriatr.
6 Arden NK, Earl S, Fisher DJ, Cooper C, Carruthers S, Goater M. (2006). Persistence with teriparatide in patients with osteoporosis: the UK experience. Osteoporos Int.
7 Sunyecz J, Gallager R, MacCosbe P. (2006). Persistence with medication in women taking daily versus weekly bisphosphonates for osteoporosis. Female Patient.
8 Salovaara K, Tuppurainen M, Karkkainen M, Rikkonen T, Sandini L, Sirola J, et al. (2010). Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res.

### Adverse Events, Inappropriate for Analysis (N=22)

1 Sorensen HT, Christensen S, Mehnert F, Pedersen L, Chapurlat RD, Cummings SR, et al. (2008). Use of bisphosphonates among women and risk of atrial fibrillation and flutter: population based case-control study. BMJ.
2 Recker RR, Marin F, Ish-Shalom S, Moricke R, Hawkins F, Kapetanos G, et al. (2009). Comparative effects of teriparatide and strontium ranelate on bone biopsies and biochemical markers of bone turnover in postmenopausal women with osteoporosis. J Bone Miner Res.
3 Urushihara H, Kikuchi N, Yamada M, Yoshiki F, Miyauchi A. (2009). Raloxifene and stroke risks in Japanese postmenopausal women with osteoporosis on postmarketing surveillance. Menopause.
4 Abrahamsen B, Eiken P, Brixen K. (2009). Atrial fibrillation in fracture patients treated with oral bisphosphonates. J Intern Med.
5 Bayram M, Soyer C, Kadioglu E, Sardas S. (2006). Assessment of DNA damage in postmenopausal women under osteoporosis therapy. Eur J Obstet Gynecol Reprod Biol.
6 Fahrleitner-Pammer A, Piswanger-Soelkner JC, Pieber TR, Obermayer-Pietsch BM, Pilz S, Dimai HP, et al. (2009). Ibandronate prevents bone loss and reduces vertebral fracture risk in male cardiac transplant patients: a randomized double-blind, placebo-controlled trial. J Bone Miner Res.
7 Fernandes CE, Zerbini C, Russo LA, Albernaz MA, Eis SR, Szejnfeld VL, et al. (2009). Effects of short-term risedronate on bone resorption and patient satisfaction in postmenopausal osteoporosis patients. J Clin Densitom.
8 Lewiecki EM, Babbitt AM, Piziak VK, Ozturk ZE, Bone HG. (2008). Adherence to and gastrointestinal tolerability of monthly oral or quarterly intravenous ibandronate therapy in women with previous intolerance to oral bisphosphonates: a 12-month, open-label, prospective evaluation. Clin Ther.
9 Yanik B, Bavbek N, Yanik T, Inegol I, Kanbay M, Turgut FH, et al. (2007). The effect of alendronate, risedronate, and raloxifene on renal functions, based on the Cockcroft and Gault method, in postmenopausal women. Ren Fail.
10 Valimaki MJ, Farrerons-Minguella J, Halse J, Kroger H, Maroni M, Mulder H, et al. (2007). Effects of risedronate 5 mg/d on bone mineral density and bone turnover markers in late-postmenopausal women with osteopenia: a multinational, 24-month, randomized, double-blind, placebo-controlled, parallel-group, phase III trial. Clin Ther.
11 Arden NK, Earl S, Fisher DJ, Cooper C, Carruthers S, Goater M. (2006). Persistence with teriparatide in patients with osteoporosis: the UK experience. Osteoporos Int.
12 Castelo-Branco C, Cortes X, Ferrer M. (2009). Treatment persistence and compliance with a combination of calcium and vitamin D. Climacteric.
13 Chung YS, Lim SK, Chung HY, Lee IK, Park IH, Kim GS, et al. (2009). Comparison of Monthly Ibandronate Versus Weekly Risedronate in Preference, Convenience, and Bone Turnover Markers in Korean Postmenopausal Osteoporotic Women. Calcif Tissue Int.
14 Mosca L, Barrett-Connor E, Wenger NK, Collins P, Grady D, Kornitzer M, et al. (2001). Design and methods of the Raloxifene Use for The Heart (RUTH) study. Am J Cardiol.
15 Shiraki M, Kushida K, Yamazaki K, Nagai T, Inoue T, Orimo H. (1996). Effects of 2 years' treatment of osteoporosis with 1alphahydroxy vitamin D3 on bone mineral density and incidence of fracture: a placebo-controlled, double-blind prospective study. Endocr J.
16 Vestergaard P, Schwartz K, Pinholt EM, Rejnmark L, Mosekilde L. (2010). Gastric and esophagus events before and during treatment of osteoporosis. Calcif Tissue Int.
17 Vestergaard P, Schwartz K, Pinholt EM, Rejnmark L, Mosekilde L. (2011). Stroke in relation to use of raloxifene and other drugs against osteoporosis. Osteoporos Int.
18 Lamberg AL, Horvath-Puho E, Christensen S, Sorensen HT. (2010). Use of oral bisphosphonates and risk of venous thromboembolism: a population-based case-control study. Osteoporos Int.
19 Christensen S, Mehnert F, Chapurlat RD, Baron JA, Sorensen HT. (2010). Oral bisphosphonates and risk of ischemic stroke: a case-control study. Osteoporos Int.
20 Caplan L, Pittman CB, Zeringue AL, Scherrer JF, Wehmeier KR, Cunningham FE, et al. (2010). An observational study of musculoskeletal pain among patients receiving bisphosphonate therapy. Mayo Clin Proc.
21 Cosman F, Wermers RA, Recknor C, Mauck KF, Xie L, Glass EV, et al. (2010). Effects of teriparatide in postmenopausal women with osteoporosis on prior alendronate or raloxifene: Differences between stopping and continuing the antiresorptive agent: Editorial Comment. Obstetrical and Gynecological Survey.
22 Elmariah S, Delaney JA, O'Brien KD, Budoff MJ, Vogel-Claussen J, Fuster V, et al. (2010). Bisphosphonate Use and Prevalence of Valvular and Vascular Calcification in Women MESA (The Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol.