# Appendix C Evidence Tables

Evidence Table C-1 Randomized Controlled Trials

Evidence Table C-2 Post-hoc and Subgroup Analyses and Follow-up Studies

Evidence Table C-3 Large Randomized Controlled Trials from Original Report

Evidence Table C-4 Adherence

Evidence Table C-5 Adverse Events

Evidence Table C-6 Applicability Assessments