# Appendix B Data Abstraction Forms

Short Form Screener for all studies

Long Form for Trials

Long Form for Observational Studies (Questions highlighted in yellow)

Long Form for Adherence Studies