# Appendix A Search Methodology

## LOW BONE DENSITY SEARCH METHODOLOGIES

INITIAL SEARCHES RAN SEPTEMBER 2009, COVERING 2005-DECEMBER2009

UPDATE SEARCHES PERFORMED IN OCTOBER/NOVEMBER 2010 COVERING JUNE 2009-OCT/NOV 2010. FINAL UPDATE SEARCH PERFORMED IN MARCH 2011 COVERING NOV 2010-END OF MARCH 2011. PUBMED ALERTS WERE SENT PERIODICALLY THROUGH THE PROJECT.

SEARCH #1A (Run 9/4/09):

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-8/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab

NOT

animal* NOT (human OR humans*)

NUMBER OF ITEMS RETRIEVED: 1953

===============================================================

SEARCH #1B (Run 9/4/09):

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-8/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

bisphosphonate*

NOT

animal* NOT (human OR humans*)

NUMBER OF ITEMS RETRIEVED: 1018

===============================================================

SEARCH #2A:

DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts – 2005-6/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2n)mineral OR bone(2n)density

AND

alendronate? OR fosamax OR risedronate? OR actonel OR etidronate? OR didronel OR ibandronate? OR boniva OR pamidronate? OR aredia OR zoledronic()acid OR zometa OR droloxifene? OR denosumab

NUMBER OF ITEMS RETRIEVED: 522

===============================================================

SEARCH #2B:

DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts – 2005-6/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2n)mineral OR bone(2n)density

AND

bisphosphonate?

NUMBER OF ITEMS RETRIEVED: 263

=========================================================

SEARCH #3A:

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2n)mineral OR bone(2n)density

AND

alendronate? OR fosamax OR risedronate? OR actonel OR etidronate? OR didronel OR ibandronate? OR boniva OR pamidronate? OR aredia OR zoledronic()acid OR zometa OR droloxifene? OR denosumab

NUMBER OF ITEMS RETRIEVED: 2471

===============================================================

SEARCH #3B:

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 2005-6/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2n)mineral OR bone(2n)density

AND

bisphosphonate?

NOT

Results of Search 3A

NUMBER OF ITEMS RETRIEVED: 558

===============================================================

SEARCH #4A (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen OR bazedoxifene* OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms

NUMBER OF ITEMS RETRIEVED: 780

===============================================================

SEARCH #4B (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

strontium

NUMBER OF ITEMS RETRIEVED: 222

===============================================================

SEARCH #4C (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

tibolone

NUMBER OF ITEMS RETRIEVED: 69

===============================================================

SEARCH #4D (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

pth OR parathyroid hormone*

NOT

animal* NOT (human OR humans) OR rat OR rats OR mice

NOT

Results of previous searches

NUMBER OF ITEMS RETRIEVED: 1486

===============================================================

SEARCH #4E (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

“Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol*

NOT

animal* NOT (human OR humans) OR rat OR rats OR mice OR monkey*

NOT

Results of previous searches

NUMBER OF ITEMS RETRIEVED: 927

===============================================================

SEARCH #4F (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

calcium

NOT

animal* NOT (human OR humans) OR rat OR rats OR mice

NOT

Results of previous searches

NUMBER OF ITEMS RETRIEVED: 2874

===============================================================

SEARCH #4G (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

vitamin d

NOT

animal* NOT (human OR humans) OR rat OR rats OR mice OR monkey*

NOT

Results of previous searches

NUMBER OF ITEMS RETRIEVED: 655

===============================================================

SEARCH #4H (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-9/2009

SEARCH STRATEGY:

teriparatide

NOT

pth OR parathyroid hormone*

NUMBER OF ITEMS RETRIEVED: 216

===============================================================

SEARCH #4I (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase– 2005-11/5/2009

LANGUAGE: English

OTHER LIMITERS: Human

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2w)mineral OR bone(2n)density/ in Title, Subject Heading fields

and

calcium or vitamin()d ORr estrogen OR oestrogen OR estradiol? OR lasofoxifene? OR pth OR parathyroid()hormone? OR teriparatide OR forteo OR preos OR raloxifene? OR evista OR selective()estrogen()receptor()modulator? OR serm OR serms OR exercise OR physical()activity/ in Title, Subject Heading fields

NOT

editorial OR letter

NUMBER OF ITEMS RETRIEVED: 8608

===============================================================

SEARCH #4J (Efficacy) :

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase– 2005-11/17/2009

LANGUAGE: English

OTHER LIMITERS: Human

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2w)mineral OR bone(2n)density in Title, Subject Heading fields

and

lasofoxifene? OR denosumab OR pth OR parathyroid()hormone? OR teriparatide? OR forteo OR preos

NOT

editorial OR letter

NUMBER OF ITEMS RETRIEVED: 2793

===============================================================

SEARCH #5A (Compliance) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-10/14/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

noncomplian* OR non-complian* OR nonadher* OR non-adher* OR refuse OR refusal OR treatment refusal OR patient compliance OR complian* OR comply OR complies OR complying OR adher* OR persistence

NOT

animal* NOT (human OR humans)

NUMBER OF ITEMS RETRIEVED: 1258

===============================================================

SEARCH #5B(Compliance revision) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-10/14/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

noncomplian* OR non-complian* OR nonadher* OR non-adher* OR refuse OR refusal OR treatment refusal OR patient compliance OR complian* OR comply OR complies OR complying OR adher* OR persistence

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen OR bazedoxifene* OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms OR calcium OR pth OR parathyroid hormone* OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR vitamin d OR testosterone OR exercise* OR exercising OR physical activity OR “Exercise Therapy”[Mesh] OR drug therapy OR drug[tiab] OR drugs[tiab] OR medication* OR therapy[tiab] OR therapies[tiab] OR treatment[tiab]

NUMBER OF ITEMS RETRIEVED: 953

NUMBER OF ITEMS RETRIEVED AFTER MANUALLY REMOVING DUPLICATES FROM SEARCH 4A AND REMOVING ANIMAL-ONLY STUDIES: 389

===============================================================

SEARCH #6A(Frax) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/11/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

frax

NUMBER OF ITEMS RETRIEVED: 49

===============================================================

SEARCH #6B(Frax) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/11/2009

LANGUAGE: English

SEARCH STRATEGY:

frax

NUMBER OF ITEMS RETRIEVED: 100

===============================================================

SEARCH #6C(Frax) :

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 2005-11/12/2009

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture? OR bone(2w)mineral OR bone(2n)density

AND

frax

NUMBER OF ITEMS RETRIEVED: 31

===============================================================

SEARCH #7(Monitoring) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/11/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

monitor*

NOT

animal* NOT (human OR humans)

NUMBER OF ITEMS RETRIEVED: 1369

===============================================================

SEARCH #8(Related Articles) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/11/2009

SEARCH STRATEGY:

“Related Articles” search on:

Bell, K.J.L., “Value of routine monitoring of bone mineral density after starting bisphosphonate treatment: secondary analysis of trial data.” BMJ Online First, 2009.

BMJ. 2009 Jun 23;338:b2266.

NUMBER OF ITEMS RETRIEVED: 100

===============================================================

SEARCH #9A(Adverse Effects) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/17/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture* OR bone mineral OR fractures[mh] OR bone density

AND

“adverse effects “[Subheading] OR (“Drug Toxicity”[Mesh] OR “toxicity “[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab]

AND

raloxifene* OR evista OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms OR calcium OR “vitamin d” OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR oestrogen OR pth OR parathyroid hormone* OR teriparatide OR forteo OR preos OR alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab

NOT

animal* NOT (human OR humans) OR rat[ti] OR rats[ti] OR mice[ti] OR murine[ti]

NOT

review[pt]

NUMBER OF ITEMS RETRIEVED: 1746

===============================================================

SEARCH #9B(Adverse Effects) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-11/17/2009

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis OR osteopenia OR osteopaenia OR fracture* OR bone mineral OR fractures[mh] OR bone density

AND

“adverse effects “[Subheading] OR (“Drug Toxicity”[Mesh] OR “toxicity “[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab]

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate OR bisphosphonates

NOT

animal* NOT (human OR humans) OR rat[ti] OR rats[ti] OR mice[ti] OR mouse[ti] OR murine[ti]

NOT

review[pt]

NUMBER OF ITEMS RETRIEVED: 877

===============================================================

SEARCH #9C(Adverse Effects) :

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 2005-12/3/2009

LANGUAGE: English

OTHER LIMITERS: Human

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate* OR raloxifene OR lasofoxifene OR serm OR serms OR selective estrogen receptor modulator* OR calcium OR “vitamin d” OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR oestrogen OR pth OR parathyroid hormone* OR teriparatide OR forteo OR preos

AND

“adverse effects “[Subheading] OR (“Drug Toxicity”[Mesh] OR “toxicity “[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab] OR risk OR risks OR risking

OR

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

raloxifene OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR oestrogen OR (hormone* AND menopaus*)

AND

thrombosis OR thrombophlebitis OR phlebitis OR clot OR clots OR clotting

OR

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate*

AND

esophageal OR esophagus OR fibrillat*

OR

raloxifene

AND

flash* OR flush*

NUMBER OF ITEMS RETRIEVED (AFTER REMOVAL OF DUPLICATES): 441

===============================================================

PUBMED ALERT – ESTABLISHED 12/2009

meta-analysis as topic OR meta analy*[tiab] OR meta-analy*[tiab] OR metaanaly*[tiab] Limits: English

Note – Records pertinent to low bone density project are identified and sent to research staff

FINAL SEARCH RESULTS FILTERING:

Search results were aggregated into one master EndNote file, where duplicates were removed. Animal-only studies were identified by searching both “Animal NOT Human” in the Keyword field and terms for specific animals in the title, and were manually removed from the database.

================================================================================================================================================

SEARCHES PERFORMED IN OCTOBER/NOVEMBER 2010 COVERING FROM JUNE 2009-OCT/NOV 2010:

SEARCH #1A PUBMED (BISPHOSPHONATES)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate*

NOT

animal* NOT (human OR humans*)

NOT

mice OR mouse OR murine OR rat OR rats

NUMBER OF ITEMS RETRIEVED: 1030

===================================================================

SEARCH #1B PUBMED (SERMS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen OR bazedoxifene* OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms

NOT

animal* NOT (human OR humans*)

NOT

mice OR mouse OR murine OR rat OR rats

NUMBER OF ITEMS RETRIEVED: 204

===================================================================

SEARCH #1C PUBMED (TESTOSTERONE/ EXERCISE)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

testosterone OR exercise* OR exercising OR physical activity OR “Exercise Therapy”[Mesh] NOT

animal* NOT (human OR humans*)

NOT

mice OR mouse OR murine OR rat OR rats

NUMBER OF ITEMS RETRIEVED: 846

===================================================================

SEARCH #1D PUBMED (OTHER TREATMENTS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

strontium OR tibolone OR pth OR parathyroid hormone* OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR calcium OR vitamin d OR teriparatide OR forteo OR preos

NOT

animal* NOT (human OR humans*)

NOT

mice OR mouse OR murine OR rat OR rats

NUMBER OF ITEMS RETRIEVED: 2312

===================================================================

SEARCH #1E PUBMED (COMPLIANCE)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

noncomplian* OR non-complian* OR nonadher* OR non-adher* OR refuse OR refusal OR treatment refusal OR patient compliance OR complian* OR comply OR complies OR complying OR adher* OR persistence

NOT

animal* NOT (human OR humans*)

NUMBER OF ITEMS RETRIEVED: 458

===================================================================

SEARCH #1F PUBMED (FRAX)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

frax

NUMBER OF ITEMS RETRIEVED: 89

===================================================================

SEARCH #1G PUBMED (MONITORING)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/12/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

monitor*

NUMBER OF ITEMS RETRIEVED: 516

===================================================================

SEARCH #1H PUBMED (ADVERSE EFFECTS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 6/2009-11/15/2010

LANGUAGE: English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

“adverse effects “[Subheading] OR (“Drug Toxicity”[Mesh] OR “toxicity “[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab] OR ((raloxifene OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR oestrogen OR (hormone* AND menopaus*) AND (thrombosis OR thrombophlebitis OR phlebitis OR clot OR clots OR clotting)) OR ((alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate*) AND (esophageal OR esophagus OR fibrillat*)) OR (raloxifene AND (flash* OR flush*))

NOT

animal* NOT (human OR humans)

NUMBER OF ITEMS RETRIEVED: 3069

===================================================================

SEARCH #2A EMBASE (BISPHOSPHONATES)

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 6/2009-11/17/2010

LANGUAGE: English

SEARCH STRATEGY:

‘osteoporosis’/exp OR osteoporosis OR ‘osteopenia’/exp OR osteopenia OR osteopaenia OR fracture* OR ((‘bone’/exp OR bone) AND (‘mineral’/exp OR mineral)) OR ((‘bone’/exp OR bone) AND (‘density’/exp OR density))

AND

alendronate* OR ‘fosamax’/exp OR fosamax OR risedronate* OR ‘actonel’/exp OR actonel OR etidronate* OR ‘didronel’/exp OR didronel OR ibandronate? OR ‘boniva’/exp OR boniva OR pamidronate* OR ‘aredia’/exp OR aredia OR zoledronic AND (‘acid’/exp OR acid) OR ‘zometa’/exp OR zometa OR droloxifene* OR ‘denosumab’/exp OR denosumab OR bisphosphonate*

NUMBER OF ITEMS RETRIEVED: 991

===================================================================

SEARCH #2B EMBASE (OTHER TREATMENTS)

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 6/2009-11/17/2010

LANGUAGE: English

SEARCH STRATEGY:

‘osteoporosis’/exp OR osteoporosis OR ‘osteopenia’/exp OR osteopenia OR osteopaenia OR fracture* OR ((‘bone’/exp OR bone) AND (‘mineral’/exp OR mineral)) OR ((‘bone’/exp OR bone) AND (‘density’/exp OR density))

AND

‘calcium’ OR ‘calcium’/exp OR calcium OR ‘vitamin d’/exp OR ‘vitamin d’ OR ‘estrogen’ OR ‘estrogen’/exp OR estrogen OR ‘oestrogen’ OR ‘oestrogen’/exp OR oestrogen OR estradiol* OR lasofoxifene* OR ‘pth’ OR ‘pth’/exp OR pth OR ‘parathyroid’ OR ‘parathyroid’/exp OR parathyroid AND hormone* OR ‘teriparatide’ OR ‘teriparatide’/exp OR teriparatide OR ‘forteo’ OR ‘forteo’/exp OR forteo OR ‘preos’ OR ‘preos’/exp OR preos OR raloxifene* OR ‘evista’ OR ‘evista’/exp OR evista OR (selective AND (‘estrogen’ OR ‘estrogen’/exp OR estrogen) AND (‘receptor’ OR ‘receptor’/exp OR receptor) AND modulator*) OR ‘serm’ OR ‘serm’/exp OR serm OR serms OR ‘exercise’ OR ‘exercise’/exp OR exercise OR (physical AND activity)

AND

humans

NUMBER OF ITEMS RETRIEVED: 2074

===================================================================

SEARCH #2B EMBASE (FRAX)

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase – 6/2009-11/17/2010

LANGUAGE: English

SEARCH STRATEGY:

‘osteoporosis’/exp OR osteoporosis OR ‘osteopenia’/exp OR osteopenia OR osteopaenia OR fracture* OR ((‘bone’/exp OR bone) AND (‘mineral’/exp OR mineral)) OR ((‘bone’/exp OR bone) AND (‘density’/exp OR density))

AND

frax

AND

humans

NUMBER OF ITEMS RETRIEVED: 84

===================================================================

SEARCH #3 INTERNATIONAL PHARMACEUTICAL ABSTRACTS

DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts – 2009-10/2010 (NOTE – THIS SEARCH COVERED ALL OF 2009)

LANGUAGE: English

SEARCH STRATEGY:

OSTEOPOROSIS OR OSTEOPENIA OR OSTEOPAENIA OR FRACTURE? OR BONE(2N)MINERAL OR BONE(2N)DENSITY

AND

ALENDRONATE? OR FOSAMAX OR RISEDRONATE? OR ACTONEL OR ETIDRONATE? OR DIDRONEL OR IBANDRONATE? OR BONIVA OR PAMIDRONATE? OR AREDIA OR ZOLEDRONIC()ACID OR ZOMETA OR DROLOXIFENE? OR DENOSUMAB OR BISPHOSPHONATE?

NUMBER OF ITEMS RETRIEVED: 110

===================================================================

===================================================================

SEARCHES PERFORMED MARCH 2011:

SEARCH #1A PUBMED (BISPHOSPHONATES)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate*

NUMBER OF ITEMS RETRIEVED: 376

===================================================================

SEARCH #1B PUBMED (SERMS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen OR bazedoxifene* OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms

NUMBER OF ITEMS RETRIEVED: 72

===================================================================

SEARCH #1C PUBMED (TESTOSTERONE/ EXERCISE)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

testosterone OR exercise* OR exercising OR physical activity OR “Exercise Therapy”[Mesh])

NUMBER OF ITEMS RETRIEVED: 230

===================================================================

SEARCH #1D PUBMED (OTHER TREATMENTS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

strontium OR tibolone OR pth OR parathyroid hormone* OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR calcium OR vitamin d OR teriparatide OR forteo OR preos

NUMBER OF ITEMS RETRIEVED: 839

===================================================================

SEARCH #1E PUBMED (COMPLIANCE)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

noncomplian* OR non-complian* OR nonadher* OR non-adher* OR refuse OR refusal OR treatment refusal OR patient compliance OR complian* OR comply OR complies OR complying OR adher* OR persistence

NUMBER OF ITEMS RETRIEVED: 130

===================================================================

SEARCH #1F PUBMED (FRAX)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

frax

NUMBER OF ITEMS RETRIEVED: 39

===================================================================

SEARCH #1G PUBMED (MONITORING)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

monitor*

NUMBER OF ITEMS RETRIEVED: 139

===================================================================

SEARCH #1H PUBMED (ADVERSE EFFECTS)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 11/2010-3/14/2011

LANGUAGE:

English

SEARCH STRATEGY:

osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures[mh] OR bone density

AND

adverse effects[Subheading] OR Drug Toxicity[Mesh] OR toxicity[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab]) OR thrombosis OR thrombophlebitis OR phlebitis OR clot OR clots OR clotting OR esophageal OR esophagus OR fibrillat* OR (raloxifene AND (flash* OR flush*))

NUMBER OF ITEMS RETRIEVED: 721

===================================================================

SEARCH #2 EMBASE (ALL TOPICS)

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase –2010-3/14/2011 (NOTE – THIS SEARCH COVERED ALL OF 2010)

LANGUAGE:

English

SEARCH STRATEGY:

‘osteoporosis’ OR ‘osteoporosis’/exp OR osteoporosis OR ‘osteopenia’ OR ‘osteopenia’/exp OR osteopenia OR osteopaenia OR fracture* OR ‘bone mineral’/exp OR ‘bone mineral’ OR ‘bone minerals’ OR (bone* AND dens*)

AND

alendronate* OR ‘fosamax’/exp OR ‘fosamax’ OR risedronate* OR ‘actonel’/exp OR ‘actonel’ OR etidronate* OR ‘didronel’/exp OR ‘didronel’ OR ibandronate? OR ‘boniva’/exp OR ‘boniva’ OR pamidronate* OR ‘aredia’/exp OR ‘aredia’ OR zoledron* OR ‘zometa’/exp OR ‘zometa’ OR droloxifene* OR ‘denosumab’/exp OR ‘denosumab’ OR bisphosphonate* OR ‘calcium’ OR ‘calcium’/exp OR calcium OR ‘vitamin d’/exp OR ‘vitamin d’ OR ‘estrogen’ OR ‘estrogen’/exp OR estrogen OR ‘oestrogen’ OR ‘oestrogen’/exp OR oestrogen OR estradiol* OR lasofoxifene* OR ‘pth’ OR ‘pth’/exp OR pth OR ‘parathyroid’ OR ‘parathyroid’/exp OR parathyroid AND hormone* OR ‘teriparatide’ OR ‘teriparatide’/exp OR teriparatide OR ‘forteo’ OR ‘forteo’/exp OR forteo OR ‘preos’ OR ‘preos’/exp OR preos OR raloxifene* OR ‘evista’ OR ‘evista’/exp OR evista OR ‘selective estrogen receptor’ OR ‘selective estrogen receptors’ OR ‘selective oestrogen receptor’ OR ‘selective oestrogen receptors’ OR ‘serm’/exp OR ‘serm’ OR serms OR ‘exercise’ OR ‘exercise’/exp OR exercise OR (physical AND activity) OR frax OR monitor* OR noncomplian* OR ‘non compliant’ OR ‘non compliance’ OR nonadher* OR ‘non adherent’ OR ‘non adherence’ OR refuse OR refusal OR ‘treatment refusal’/exp OR ‘treatment refusal’ OR complian* OR comply OR complies OR complying OR adher* OR persistence

AND

Humans

NUMBER OF ITEMS RETRIEVED: 2027

===================================================================

SEARCH #3A INTERNATIONAL PHARMACEUTICAL ABSTRACTS

DATABASE SEARCHED & TIME PERIOD COVERED:

International Pharmaceutical Abstracts –2010-3/21/2011 (NOTE – THIS SEARCH COVERED ALL OF 2010)

SEARCH STRATEGY:

OSTEOPOROSIS OR OSTEOPENIA OR OSTEOPAENIA OR FRACTURE? OR BONE(2N)MINERAL OR BONE(2N)DENSITY

AND

ALENDRONATE? OR FOSAMAX OR RISEDRONATE? OR ACTONEL OR ETIDRONATE? OR DIDRONEL OR IBANDRONATE? OR BONIVA OR PAMIDRONATE? OR AREDIA OR ZOLEDRONIC()ACID OR ZOMETA OR DROLOXIFENE? OR DENOSUMAB OR BISPHOSPHONATE?

NUMBER OF ITEMS RETRIEVED: 61

===================================================================

SEARCH #3B INTERNATIONAL PHARMACEUTICAL ABSTRACTS

OSTEOPOROSIS OR OSTEOPENIA OR OSTEOPAENIA OR FRACTURE? OR BONE(2N)MINERAL OR BONE(2N)DENSITY

NOT

RESULTS OF SEARCH #1

NUMBER OF ITEMS RETRIEVED:144

Combined results from Searches 3A and 3B, after manually removing animal studies and duplicates from selected previous searches: 91

===================================================================

===================================================================

COMBINED TOTAL OF ALL SEARCHES – DUPLICATES NOT REMOVED: 16,447

===================================================================

===================================================================

PubMed ALERT (established 6/3/11)

osteoporosis OR osteopenia OR osteopaenia OR fracture* OR bone mineral OR fractures[mh] OR bone density

AND

alendronate* OR fosamax OR risedronate* OR actonel OR etidronate* OR didronel OR ibandronate* OR boniva OR pamidronate* OR aredia OR zoledronic acid OR zometa OR droloxifene* OR denosumab OR bisphosphonate* OR raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen OR bazedoxifene* OR lasofoxifene* OR selective estrogen receptor modulators OR serm OR serms OR strontium OR tibolone OR pth OR parathyroid hormone* OR “Estrogens”[Mesh] OR “Estrogens “[Pharmacological Action] OR estrogen*[tiab] OR estradiol* OR calcium OR vitamin d OR teriparatide OR forteo OR preos OR testosterone OR exercise* OR exercising OR physical activity OR “Exercise Therapy”[Mesh] OR noncomplian* OR non-complian* OR nonadher* OR non-adher* OR refuse OR refusal OR treatment refusal OR patient compliance OR complian* OR comply OR complies OR complying OR adher* OR persistence OR frax OR monitor* OR (“adverse effects “[Subheading] OR (“Drug Toxicity”[Mesh] OR “toxicity “[Subheading]) OR adverse OR harm OR harmful OR safe[tiab] OR safety[tiab] OR toxic*[tiab] OR thrombosis OR thrombophlebitis OR phlebitis OR clot OR clots OR clotting OR esophageal OR esophagus OR fibrillat* OR flash* OR flush*))

Limits: English

Alert results:

6/12/11 – 163 total.

Removed: 6 dups, 18 animal-only studies

139 results.