# Acknowledgments

This study was supported by the Agency for Healthcare Research and Quality. The investigators deeply appreciate the considerable support, commitment and contributions of Megan Clifford, Jianhui Hu, Breanne Johnsen, Tanja Perry and Di Valentine.