# Abbreviations

ACE: Annual Cumulative Exposure
ACP: American College of Physicians
AE: Adverse Events
AF: Atrial Fibrillation
AHRQ: Agency for Healthcare Research and Quality
BALP: Bone Alkaline Phosphatase
BMD: Bone Mineral Density
CABG: Coronary Artery Bypass Graft
CEE: Conjugated Equine Estrogen
CER: Comparative Effectiveness Review
CFOS: Cystic Fibrosis Osteoporosis Study
CHD: Coronary Heart Disease
CI: Confidence Interval
CTX: Carboxy-Terminal Collagen Crosslinks
CVA: Cerebrovascular Accidents
DVT: Deep Venous Thrombosis
DXA: Dual Energy X-ray Absorptiometry
E: Estradiol
EPC: Evidence-based Practice Center
EPT: Combined Estrogen-Progestogen Therapy
ET: Estrogen Therapy
FDA: Food and Drug Administration
FIT: Fracture Intervention Trial
FRAX: Fracture Risk Assessment Tool
GC: Glucocorticoid
GI: Gastrointestinal
H: Hip
HORIZON: Health Outcomes and Reduced Incidence with Zoledronic Acid Once Yearly
HR: Hazard Ratio
HT: Hormone Therapy (encompassing both ET and EPT)
IMS: Information Management System
ISPOR: International Society for Pharmacoeconomics and Outcomes Research
KQ: Key Question
Local Therapy: Vaginal ET administration that does not result in clinically significant systematic absorption
MeSH: Medical Subject Headings
MI: Myocardial Infarction
MORE: Multiple Outcomes of Raloxifene Evaluation
MPA: Medroxyprogesterone
MPR: Medication Possession Ratio
NC: Not Calculable
NE: Norgestimate
NE: Not Estimable
NR: Not Reported
NV: Non-Vertebral
NYHA: New York Heart Association
OR: Odds-ratios
PDC: Proportion of days covered
PE: Pulmonary Embolism
Progestogen: Encompassing both progesterone and progestin
PTH: Parathyroid Hormone
PUB: Perforations, Ulcerations, and Bleeds
RCT: Randomized Controlled Trial
RD: Rate Difference
RR: Relative Risks
SCHIP: State Children's Health Insurance Program
SERM: Selective Estrogen Receptor Modulator
SRC: Scientific Resource Center
Systematic therapy: HT administration that results in absorption in the blood high enough to provide clinically significant effects
TEP: Technical Expert Panel
Timing of HT initiation: Length of time after menopause when HT is initiated
TOP: Treatment of Osteoporosis with Parathyroid Hormone Study
UTI: Urinary Tract Infection
V: Vertebral
VA: Veterans Administration
VERT: Vertebral Efficacy with Risedronate Therapy
W: Wrist/Forearm
YRS: Years