# References

The recently published articles added in this update are in bold text.

1 Balk E, Raman G, Chung M, Ip S, Tatsioni A, Alonso A, Kupelnick B, Chew P, DeVine D, Gilbert S, Lau J. Comparative Effectiveness of Management Strategies for Renal Artery Stenosis. Comparative Effectiveness Review No. 5.(Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. Dec. 2006. Available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Balk E, Raman G, Chung M, et al. Effectiveness of management strategies for renal artery stenosis: a systematic review. Ann Intern Med. 2006;145:901-912. [pmid: 17062633].
3 Cooper CJ, Murphy TP, Matsumoto A, et al. Stent revascularization for the prevention of cardiovascular and renal events among patients with renal artery stenosis and systolic hypertension: rationale and design of the CORAL trial. Am Heart J. 2006;152:59-66. [pmid: 16824832].
4 Safian RD, Textor SC. Renal-artery stenosis. N Engl J Med. 2001;344:431-442. [pmid: 11172181].
5 Harding MB, Smith LR, Himmelstein SI, et al. Renal artery stenosis: prevalence and associated risk factors in patients undergoing routine cardiac catheterization. J Am Soc Nephrol. 1992;2:1608-1616. [pmid: 1610982].
6 Missouris CG, Buckenham T, Cappuccio FP, MacGregor GA. Renal artery stenosis: a common and important problem in patients with peripheral vascular disease. Am J Med. 1994;96:10-14. [pmid: 8304356].
7 United States Renal Data System (USRDS). 1997 Annual Data Report Bethesda, Maryland, US Department of Health and Human Services/National Institutes of Health/National Institute of Diabetes and Digestive and Kidney Diseases. 1997.
8 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic). J Am Coll Cardiol. 2006;47:1239-1312. [pmid: 16545667].
9 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic). Circulation. 2006;113:e463-e654. [pmid: 16549646].
10 Murphy TP, Soares G, Kim M. Increase in utilization of percutaneous renal artery interventions by medicare beneficiaries, 1996–2000. AJR Am J Roentgenol. 2004;183:561-568. [pmid: 15333335].
11 The fifth report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (JNC V). Arch Intern Med. 1993;153:154-183. [pmid: 8422206].
12 Webster J, Marshall F, Abdalla M, et al. Randomised comparison of percutaneous angioplasty vs continued medical therapy for hypertensive patients with atheromatous renal artery stenosis. Scottish and Newcastle Renal Artery Stenosis Collaborative Group. J Hum Hypertens. 1998;12:329-335. [pmid: 9655655].
13 Plouin PF, Chatellier G, Darne B, Raynaud A. Blood pressure outcome of angioplasty in atherosclerotic renal artery stenosis: a randomized trial. Essai Multicentrique Medicaments vs Angioplastie (EMMA) Study Group. Hypertension. 1998;31:823-829. [pmid: 9495267].
14 van Jaarsveld BC, Krijnen P, Pieterman H, et al. The effect of balloon angioplasty on hypertension in atherosclerotic renal-artery stenosis. Dutch Renal Artery Stenosis Intervention Cooperative Study Group. N Engl J Med. 2000;342:1007-1014. [pmid: 10749962].
15 van Jaarsveld BC, Krijnen P. Prospective studies of diagnosis and intervention: the Dutch experience. Semin Nephrol. 2000;20:463-473. [pmid: 11022900].
16 Krijnen P, van Jaarsveld BC, Deinum J, Steyerberg EW, Habbema JD. Which patients with hypertension and atherosclerotic renal artery stenosis benefit from immediate intervention?. J Hum Hypertens. 2004;18:91-96. [pmid: 14730323].
17 Pizzolo F, Mansueto G, Minniti S, et al. Renovascular disease: effect of ACE gene deletion polymorphism and endovascular revascularization. J Vasc Surg. 2004;39:140-147. [pmid: 14718831].
18 Pillay WR, Kan YM, Crinnion JN, Wolfe JH, Joint Vascular Research Group. Prospective multicentre study of the natural history of atherosclerotic renal artery stenosis in patients with peripheral vascular disease. Br J Surg. 2002;89:737-740. [pmid: 12027983].
19 Uzzo RG, Novick AC, Goormastic M, Mascha E, Pohl M. Medical versus surgical management of atherosclerotic renal artery stenosis. Transplant Proc. 2002;34:723-725. [pmid: 12009679].
20 Johansson M, Herlitz H, Jensen G, Rundqvist B, Friberg P. Increased cardiovascular mortality in hypertensive patients with renal artery stenosis. Relation to sympathetic activation, renal function and treatment regimens. J Hypertens. 1999;17:1743-1750. [pmid: 10658941].
21 Englund R, Brown MA. Renal angioplasty for renovascular disease: a reappraisal. J Cardiovasc Surg (Torino). 1991;32:76-80.
22 Taylor DC, Moneta GL, Strandness DE Jr. Follow-up of renal artery stenosis by duplex ultrasound. J Vasc Surg. 1989;9:410-415. [pmid: 2522152].
23 Krijnen P, van Jaarsveld BC, Hunink MG, Habbema JD. The effect of treatment on health-related quality of life in patients with hypertension and renal artery stenosis. J Hum Hypertens. 2005;19:467-470. [pmid: 15759023].
24 Losito A, Errico R, Santirosi P, Lupattelli T, Scalera GB, Lupattelli L. Long-term follow-up of atherosclerotic renovascular disease. Beneficial effect of ACE inhibition. Nephrol Dial Transplant. 2005;20:1604-1609. [pmid: 15870215].
25 Nordmann AJ, Woo K, Parkes R, Logan AG. Balloon angioplasty or medical therapy for hypertensive patients with atherosclerotic renal artery stenosis? A meta-analysis of randomized controlled trials. Am J Med. 2003;114:44-50. [pmid: 12557864].
26 Nordmann AJ, Logan AG. Balloon angioplasty versus medical therapy for hypertensive patients with renal artery obstruction. Cochrane Database Syst Rev. 2003:CD002944.
27 Hanzel G, Balon H, Wong O, Soffer D, Lee DT, Safian RD. Prospective evaluation of aggressive medical therapy for atherosclerotic renal artery stenosis, with renal artery stenting reserved for previously injured heart, brain, or kidney. Am J Cardiol. 2005;96:1322-1327. [pmid: 16253607].
28 Franklin SS, Smith RD. Comparison of effects of enalapril plus hydrochlorothiazide versus standard triple therapy on renal function in renovascular hypertension. Am J Med. 1985;79:14-23. [pmid: 2996342].
29 Franklin SS, Smith RD. A comparison of enalapril plus hydrochlorothiazide with standard triple therapy in renovascular hypertension. Nephron. 1986;44:73-82. [pmid: 3018602].
30 Ogihara T, Kaneko Y, Ikeda M, et al. Clinical evaluation of delapril in Japan. Report from the Japan Study Group on Delapril. Am J Hypertens. 1991;4:42S-45S. [pmid: 2009147].
31 Tillman DM, Malatino LS, Cumming AM, et al. Enalapril in hypertension with renal artery stenosis: long-term follow-up and effects on renal function. J Hypertens Suppl. 1984;2:S93-S100. [pmid: 6100883].
32 Takabatake T, Ohta H, Yamamoto Y, et al. Effect of angiotensin blockade and converting enzyme inhibition on renovascular hypertension: comparison between unilateral and bilateral renal artery stenosis. Angiology. 1987;38:434-439. [pmid: 3035964].
33 Jackson B, Murphy BF, Johnston CI, KincaidSmith P, Whitworth JA. Renovascular hypertension: treatment with the oral angiotensin-converting enzyme inhibitor enalapril. Am J Nephrol. 1986;6:182-186. [pmid: 3017107].
34 Jackson B, McGrath BP, Matthews PG, Wong C, Johnston CI. Differential renal function during angiotensin converting enzyme inhibition in renovascular hypertension. Hypertension. 1986;8:650-654. [pmid: 3015794].
35 Hricik DE, Browning PJ, Kopelman R, Goorno WE, Madias NE, Dzau VJ. Captopril-induced functional renal insufficiency in patients with bilateral renal-artery stenoses or renal-artery stenosis in a solitary kidney. N Engl J Med. 1983;308:373-376. [pmid: 6337327].
36 Caps MT, Zierler RE, Polissar NL, et al. Risk of atrophy in kidneys with atherosclerotic renal artery stenosis. Kidney Int. 1998;53:735-742. [pmid: 9507221].
37 Conlon PJ, Little MA, Pieper K, Mark DB. Severity of renal vascular disease predicts mortality in patients undergoing coronary angiography. Kidney Int. 2001;60:1490-1497. [pmid: 11576364].
38 Fergany A, Novick AC, Goldfarb DA. Management of atherosclerotic renal artery disease in younger patients. J Urol. 1994;151:10-12. [pmid: 8254782].
39 Houston JG, Gandy SJ, Milne W, Dick JB, Belch JJ, Stonebridge PA. Spiral laminar flow in the abdominal aorta: a predictor of renal impairment deterioration in patients with renal artery stenosis?. Nephrol Dial Transplant. 2004;19:1786-1791. [pmid: 15161949].
40 Uzu T, Takeji M, Yamada N, et al. Prevalence and outcome of renal artery stenosis in atherosclerotic patients with renal dysfunction. Hypertens Res. 2002;25:537-542. [pmid: 12358138].
41 Iglesias JI, Hamburger RJ, Feldman L, Kaufman JS. The natural history of incidental renal artery stenosis in patients with aortoiliac vascular disease. Am J Med. 2000;109:642-647. [pmid: 11099684].
42 Cheung CM, Wright JR, Shurrab AE, et al. Epidemiology of renal dysfunction and patient outcome in atherosclerotic renal artery occlusion. J Am Soc Nephrol. 2002;13:149-157. [pmid: 11752032].
43 Blum U, Krumme B, Flugel P, et al. Treatment of ostial renal-artery stenoses with vascular endoprostheses after unsuccessful balloon angioplasty. N Engl J Med. 1997;336:459-465. [pmid: 9017938].
44 Bucek RA, Puchner S, Reiter M, Dirisamer A, Minar E, Lammer J. Long-term follow-up after renal artery stenting. Wien Klin Wochenschr. 2003;115:788-792. [pmid: 14743583].
45 Dangas G, Laird JR Jr, Mehran R, Lansky AJ, Mintz GS, Leon MB. Intravascular ultrasound-guided renal artery stenting. J Endovasc Ther. 2001;8:238-247. [pmid: 11491257].
46 Dorros G, Jaff M, Jain A, Dufek C, Mathiak L. Follow-up of primary Palmaz-Schatz stent placement for atherosclerotic renal artery stenosis. Am J Cardiol. 1995;75:1051-1055. [pmid: 7747688].
47 Dorros G, Jaff M, Mathiak L, et al. Four-year follow-up of Palmaz-Schatz stent revascularization as treatment for atherosclerotic renal artery stenosis. Circulation. 1998;98:642-647. [pmid: 9715856].
48 Dorros G, Jaff MR, Mathiak L, et al. Stent revascularization for atherosclerotic renal artery stenosis. 1-year clinical follow-up. Tex Heart Inst J. 1998;25:40-43. [pmid: 9566062].
49 Dorros G, Jaff M, Mathiak L, He T, Multicenter RP. Multicenter Palmaz stent renal artery stenosis revascularization registry report: four-year follow-up of 1,058 successful patients. Catheter Cardiovasc Interv. 2002;55:182-188. [pmid: 11835644].
50 Dorros G, Jaff M, Mathiak L, et al. Renal function and survival after renal artery stent revascularization may be influenced by embolic debris. J Invasive Cardiol. 2004;16:189-195. [pmid: 15152144].
51 Gill KS, Fowler RC. Atherosclerotic renal arterial stenosis: clinical outcomes of stent placement for hypertension and renal failure. Radiology. 2003;226:821-826. [pmid: 12601202].
52 Gill-Leertouwer TC, Gussenhoven EJ, Deinum J, van Dijk LC, Pattynama PM. Shrinkage of the distal renal artery 1 year after stent placement as evidenced with serial intravascular ultrasound. Br J Radiol. 2002;75:879-883. [pmid: 12466252].
53 Gill-Leertouwer TC, Gussenhoven EJ, Bosch JL, et al. Predictors for clinical success at one year following renal artery stent placement. J Endovasc Ther. 2002;9:495-502. [pmid: 12223011].
54 Gray BH, Olin JW, Childs MB, Sullivan TM, Bacharach JM. Clinical benefit of renal artery angioplasty with stenting for the control of recurrent and refractory congestive heart failure. Vasc Med. 2002;7:275-279. [pmid: 12710843].
55 Gross CM, Kramer J, Waigand J, et al. Ostial renal artery stent placement for atherosclerotic renal artery stenosis in patients with coronary artery disease. Cathet Cardiovasc Diagn. 1998;45:1-8. [pmid: 9736342].
56 Harden PN, Macleod MJ, Rodger RS, et al. Effect of renal-artery stenting on progression of renovascular renal failure. Lancet. 1997;349:1133-1136. [pmid: 9113012].
57 Harjai K, Khosla S, Shaw D, et al. Effect of gender on outcomes following renal artery stent placement for renovascular hypertension. Cathet Cardiovasc Diagn. 1997;42:381-386. [pmid: 9408615].
58 Henry M, Henry I, Klonaris C, et al. Renal angioplasty and stenting under protection: the way for the future?. Catheter Cardiovasc Interv. 2003;60:299-312. [pmid: 14571477].
59 Iannone LA, Underwood PL, Nath A, Tannenbaum MA, Ghali MG, Clevenger LD. Effect of primary balloon expandable renal artery stents on long-term patency, renal function, and blood pressure in hypertensive and renal insufficient patients with renal artery stenosis. Cathet Cardiovasc Diagn. 1996;37:243-250. [pmid: 8974797].
60 Kennedy DJ, Colyer WR, Brewster PS, et al. Renal insufficiency as a predictor of adverse events and mortality after renal artery stent placement. Am J Kidney Dis. 2003;42:926-935. [pmid: 14582036].
61 Burket MW, Cooper CJ, Kennedy DJ, et al. Renal artery angioplasty and stent placement: predictors of a favorable outcome. Am Heart J. 2000;139:64-71. [pmid: 10618564].
62 Lederman RJ, Mendelsohn FO, Santos R, Phillips HR, Stack RS, Crowley JJ. Primary renal artery stenting: characteristics and outcomes after 363 procedures. Am Heart J. 2001;142:314-323. [pmid: 11479472].
63 Ramos F, Kotliar C, Alvarez D, et al. Renal function and outcome of PTRA and stenting for atherosclerotic renal artery stenosis. Kidney Int. 2003;63:276-282. [pmid: 12472793].
64 Rivolta R, Bazzi C, Stradiotti P, Paparella M. Stenting of renal artery stenosis: is it beneficial in chronic renal failure?. J Nephrol. 2005;18:749-754. [pmid: 16358234].
65 Rocha-Singh K, Jaff MR, Rosenfield K. Evaluation of the safety and effectiveness of renal artery stenting after unsuccessful balloon angioplasty: the ASPIRE-2 study. J Am Coll Cardiol. 2005;2005:776-783. [pmid: 16139124].
66 Rocha-Singh KJ, Mishkel GJ, Katholi RE, et al. Clinical predictors of improved long-term blood pressure control after successful stenting of hypertensive patients with obstructive renal artery atherosclerosis. Catheter Cardiovasc Interv. 1999;47:167-172. [pmid: 10376497].
67 Tuttle KR, Chouinard RF, Webber JT, et al. Treatment of atherosclerotic ostial renal artery stenosis with the intravascular stent. Am J Kidney Dis. 1998;32:611-622. [pmid: 9774123].
68 White CJ, Ramee SR, Collins TJ, Jenkins JS, Escobar A, Shaw D. Renal artery stent placement: utility in lesions difficult to treat with balloon angioplasty. J Am Coll Cardiol. 1997;30:1445-1450. [pmid: 9362400].
69 Zeller T, Frank U, Muller C, et al. Stent-supported angioplasty of severe atherosclerotic renal artery stenosis preserves renal function and improves blood pressure control: long-term results from a prospective registry of 456 lesions. J Endovasc Ther. 2004;11:95-106. [pmid: 15056029].
70 Zeller T, Frank U, Muller C, et al. Technological advances in the design of catheters and devices used in renal artery interventions: impact on complications. J Endovasc Ther. 2003;10:1006-1014. [pmid: 14656167].
71 Zeller T, Frank U, Muller C, et al. Predictors of improved renal function after percutaneous stent-supported angioplasty of severe atherosclerotic ostial renal artery stenosis. Circulation. 2003;108:2244-2249. [pmid: 14557357].
72 Zeller T, Muller C, Frank U, et al. Survival after stenting of severe atherosclerotic ostial renal artery stenoses. J Endovasc Ther. 2003;10:539-545. [pmid: 12932166].
73 Zeller T, Muller C, Frank U, et al. Gold coating and restenosis after primary stenting of ostial renal artery stenosis. Catheter Cardiovasc Interv. 2003;60:1-6. [pmid: 12929094].
74 Gross CM, Kramer J, Weingartner O, et al. Determination of renal arterial stenosis severity: comparison of pressure gradient and vessel diameter. Radiology. 2001;220:751-756. [pmid: 11526278].
75 Spinosa DJ, Matsumoto AH, Angle JF, et al. Safety of CO(2)- and gadodiamide-enhanced angiography for the evaluation and percutaneous treatment of renal artery stenosis in patients with chronic renal insufficiency. AJR Am J Roentgenol. 2001;176:1305-1311. [pmid: 11312200].
76 van de Ven PJ, Kaatee R, Beutler JJ, et al. Arterial stenting and balloon angioplasty in ostial atherosclerotic renovascular disease: a randomised trial. Lancet. 1999;353:282-286. [pmid: 9929021].
77 Goncalves JA, Amorim JE, Soares Neto MM, Ribeiro AB, Lima VC. Clinical efficacy of percutaneous renal revascularization with stent placement in atherosclerotic renovascular disease. Arq Bras Cardiol. 2007;88:85-90. [pmid: 17364124].
78 Holden A, Hill A, Jaff MR, Pilmore H. Renal artery stent revascularization with embolic protection in patients with ischemic nephropathy. Kidney Int. 2006;70:948-955. [pmid: 16837918].
79 Ruchin PE, Baron DW, Wilson SH, Boland J, Muller DW, Roy PR. Long-Term Follow-up of Renal Artery Stenting in an Australian Population. Heart Lung Circ. 2007;16:79-84. [pmid: 17317314].
80 Sapoval M, Zahringer M, Pattynama P, et al. Low-profile stent system for treatment of atherosclerotic renal artery stenosis: the GREAT trial. J Vasc Interv Radiol. 2005;16:1195-1202. [pmid: 16151060].
81 Tsao CR, Lee WL, Liu TJ, Chen YT, Ting CT. Delicate percutaneous renal artery stenting minimizes postoperative renal injury and protects kidney in patients with severe atherosclerotic renal artery stenosis and impaired renal function. Int Heart J. 2005;46:1061-1072. [pmid: 16394602].
82 Zeller T, Rastan A, Kliem M, et al. Impact of carbon coating on the restenosis rate after stenting of atherosclerotic renal artery stenosis. J Endovasc Ther. 2005;12:605-611. [pmid: 16212462].
83 Alhadad A, Ahle M, Ivancev K, Gottsater A, Lindblad B. Percutaneous transluminal renal angioplasty (PTRA) and surgical revascularisation in renovascular disease--a retrospective comparison of results, complications, and mortality. Eur J Vasc Endovasc Surg. 2004;27:151-156. [pmid: 14718896].
84 Galaria II, Surowiec SM, Rhodes JM, et al. Percutaneous and open renal revascularizations have equivalent long-term functional outcomes. Ann Vasc Surg. 2005;19:218-228. [pmid: 15735947].
85 Cherr GS, Hansen KJ, Craven TE, et al. Surgical management of atherosclerotic renovascular disease. J Vasc Surg. 2002;35:236-245. [pmid: 11854720].
86 Deitch JS, Hansen KJ, Craven TE, Flack JM, Appel RG, Dean RH. Renal artery repair in African-Americans. J Vasc Surg. 1997;26:465-472. [pmid: 9308592].
87 Hansen KJ, Cherr GS, Craven TE, et al. Management of ischemic nephropathy: dialysis-free survival after surgical repair. J Vasc Surg. 2000;32:472-481. [pmid: 10957653].
88 Hansen KJ, Cherr GS, Dean RH. Dialysis-free survival after surgical repair of ischemic nephropathy. Cardiovasc Surg. 2002;10:400-404. [pmid: 12359416].
89 Hansen KJ, Wilson DB, Edwards MS. Surgical revascularization of atherosclerotic renovascular disease: State of the art. Pers Vasc Surg Endovasc Ther. 2004;16:281-298.
90 Marone LK, Cambria RP. Revascularization for renal function retrieval: which patients will benefit?. Pers Vasc Surg Endovasc Ther. 2004;16:249-260.
91 K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. Am J Kidney Dis. 2002;39:S1-S246. [pmid: 11904577].
92 Garcia-Criado A, Gilabert R, Nicolau C, et al. Value of Doppler sonography for predicting clinical outcome after renal artery revascularization in atherosclerotic renal artery stenosis. J Ultrasound Med. 2005;24:1641-1647. [pmid: 16301720].
93 Diamond GA. Limited assurances. Am J Cardiol. 1989;63:99-100. [pmid: 2909164].