# Abbreviations

ACC: American College of Cardiology
ACE: Angiotensin converting enzyme
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
ARAS: Atherosclerotic renal artery stenosis
ARB: Angiotensin-receptor blocker
BP: Blood pressure
CER: Comparative Effectiveness Review
CKD: Chronic kidney disease
CMS: Centers for Medicare and Medicaid Services
CORAL: Cardiovascular Outcomes in Renal Atherosclerotic Lesions trial
CrCl: Creatinine clearance
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
DRASTIC: Dutch Renal Artery Stenosis Intervention Cooperative trial
EMMA: Essai Multicentrique Medicaments vs. Angioplastie trial
EPC: Evidence-based Practice Center
GFR: Glomerular filtration rate
JNC-5: 5^th^ Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (1993)
KDOQI: Kidney Disease Outcomes Quality Initiative
KQ: Key Question
LDL: Low density lipoprotein
MedCAC: Medicare Evidence Development & Coverage Advisory Committee
MEDPAR: Medicare Provider Analysis and Review
mo: Month
QoL: Quality of life
RAS: Renal artery stenosis
RCT: Randomized controlled trial
RI: Resistive index
SBP: Systolic blood pressure
SCr: Serum creatinine
SNRASCG: Scottish and Newcastle Renal Artery. Stenosis Collaborative Group trial
TEP: Technical expert panel