# Discussion

Nine recently published articles met eligibility criteria for inclusion in this systematic review of interventions for RAS. In general, these new studies had the same limitations as the other 72 studies included in the original CER. Namely, none of the studies evaluated the principal question of interest, the relative effects of intensive medical therapy and angioplasty with stent for patients with ARAS; the quality of the studies was limited due to inadequate reporting and/or collection of data, incomplete analyses, and often inconsistent use of interventions (e.g., combining angioplasty with and without stent); limited or difficult to assess applicability due to restrictive patient eligibility or inadequate reporting; inconsistent outcome metrics; and limited power of studies due to small sample size. Importantly, only two small RCTs (about 50 patients randomized in each) compared angioplasty and medical therapy with at least 6 month outcomes. Including a third RCT with a substantial treatment crossover (medical therapy to angioplasty) at 3 months, only 4 patients had stents placed and only some patients were treated with ACE inhibitors; statins and antiplatelet agents were not included in drug protocols. Therefore these trials may be of limited relevance to current practice.

It is important to note that this review focuses on comparative studies and larger, more recent single-arm studies. Many hundreds of other studies have been published that did not meet eligibility criteria, particularly single-arm studies of angioplasty without stent. Thus, there may be evidence for specific issues that are not addressed by this report. These may include some diagnostic tests and special high risk populations such as people with rapid declines in kidney function, recurrent flash pulmonary edema, or unstable angina in the setting of RAS. This report also does not address the management of fibromuscular dysplasia, renal transplant recipients, or patients who have a previous, failed revascularization. The reviewed studies did not explicitly address the population of patients who may need acute intervention because of rapid clinical deterioration, so the conclusions of this review do not apply to these patients. The approach of this systematic review, and of most of the primary studies, was to evaluate the average outcome of treated patients. In many studies a group of individuals had rapid, marked improvement in blood pressure and/or kidney function, but others had worsening function. Additional research is needed to determine which patients would be most likely to benefit (or be harmed) by the various interventions. Furthermore, none of the studies explicitly evaluated patients being aggressively treated with ACE inhibitors or angiotensin reuptake blockers, statins, and antiplatelet agents, regardless of other interventions being used. This further complicates any direct or indirect comparisons of invasive interventions to available medical treatment. In addition, another important consideration when evaluating the current literature to answer the comparative value of the intervention alternatives is that our limited ability to make comparisons across types of studies. It is highly likely that the types of patients included in cohort studies of angioplasty – based on disease severity, comorbidities, general health, socioeconomic factors, etc. – were very different than those who remained on medical treatment. Thus expected rates of outcomes including death, cardiovascular disease, and kidney failure, may be very different across studies based more on the patients’ underlying disease than on the intervention.

Overall, the findings of the new studies were consistent with the previously summarized studies. The only newly reported result was in a new article about the previously described DRASTIC study that compared immediate angioplasty with either medical therapy or delayed angioplasty. This study evaluated quality of life and found no consistent difference between patients who had immediate angioplasty and those who remained on medical therapy. Otherwise, our findings remain generally the same:

- Almost two-thirds of the studies were of poor methodological quality and more than half were of limited applicability to the population of interest.
- No RCTs compare angioplasty with stent and aggressive medical treatment with ACE inhibitors, statins, and anti-platelet drugs (Tier I studies).
- The two most relevant RCTs (Tier II studies) do not compare interventions that are currently used for patients with RAS; only 2 patients received stents and ACE inhibitors were rarely employed.
- Other comparative studies (Tier III) are methodologically flawed or did not compare angioplasty and medical treatment.
- There are a substantial number of cohort studies (Tier IV) that prospectively evaluated angioplasty with stent, but very few cohort studies of medications, none of which explicitly evaluated aggressive medical treatment with ACE inhibitors, statins, and anti-platelet drugs. Thus indirect comparisons across the cohort studies are limited.
- Among the comparative studies there was some evidence of a relative benefit in blood pressure after angioplasty, particularly in patients with bilateral disease; however, this conclusion is based largely on the end-of-study (not primary endpoint, after which some treatment cross-over occurred) of one RCT (Webster 1998) and either clinically though not statistically significant differences, partially statistically significant differences, or nonrandomized trial data.
- Among the comparative studies there was no difference in kidney function outcomes, and possibly no differences in mortality, cardiovascular event rates, and quality of life, although studies generally included too few patients and were of too short a duration to make definitive assessments regarding these clinical event outcomes.
- Comparison of adverse events and complications across the various interventions is difficult. However, it is clear that various complications after revascularization do occur in a small percentage of patients, and each of the antihypertensive drugs has associated adverse events.
- Although studies were generally too small to detect any but large differences in mortality rates, no differences in mortality were found between interventions, up to about 5 years. Very high mortality rates, over 40 percent within 6 years, occurred mostly in studies of patients with either high-grade stenosis (>75 percent) or bilateral disease.
- Direct and indirect comparisons of interventions mostly found no clinical or statistically significant differences in kidney outcomes. However, only in some of the angioplasty with stent placement studies did patients have improved kidney function. This implies that, at least in a (poorly described) subset of patients with ARAS, kidney function is more likely to improve after angioplasty with stent placement than with continued medical treatment.
- Both trials and most of the other comparative studies found some evidence of greater blood pressure improvement after angioplasty than with medical treatment; although the benefit of angioplasty may be limited to patients with bilateral disease. In contrast, cohort studies of angioplasty generally found somewhat lower reductions in blood pressure (6–32/0–17 mm Hg) than cohorts of medical interventions (20–50/8–42 mm Hg), though it is not possible to draw conclusions about the relative effect on blood pressure measurements of the different interventions.
- Comparative studies found similar rates of cardiovascular disease regardless of intervention, though these studies were not designed to find significant differences in cardiovascular events. The data from cohort studies on cardiovascular events were too sparse to draw conclusions.
- A single trial found no consistent difference in quality of life between angioplasty and medical therapy.
- Adverse events, variably defined, occurred in up to 13 percent of patients receiving angioplasty, though serious long-term adverse events were rare. Reported adverse events from antihypertensives were relatively minor and transient.
- A variety of indicators of the severity of ARAS and of health problems, such as poorer kidney function, severity of stenosis, and coexisting cardiovascular disease predict poorer outcomes in patients with ARAS. The reviewed studies did not report any indicators that may predict improved outcomes. Two trials found that patients with bilateral RAS had better outcomes after angioplasty than medical therapy, compared to patients with unilateral disease.
- In comparative studies, captopril test, renogram, recent hypertension, and stenosis greater than 80 percent were not predictors of either worse outcome overall or of which intervention would result in better outcomes. Among patients receiving angioplasty, there was little consistent evidence about which diagnostic tests would predict more favorable outcomes. Two studies found that Doppler ultrasonography findings were predictive of outcomes after angioplasty, but they disagreed as to whether resistive index predicted worse or better outcomes.
- No study that met eligibility criteria reported analyses of whether periprocedural interventions, such as different drugs or different approaches, affected either complications or long-term outcomes.

Our conclusions about the evidence are:

- Overall, the evidence does not currently support one treatment approach over the other for the general population of people with ARAS.
- The evidence on this topic is generally inconclusive due to small numbers of RCTs with few patients comparing angioplasty to medical therapy, questions of relevance of trials to current practice due to lack of stent placement and relative lack of ACE inhibitor use, and poor quality and limited applicability of many of the remaining, primarily cohort, studies. No trials comparing interventions commonly in use (Tier I) have been published.
- Weak evidence suggests no difference in mortality rates with medical treatment alone or with angioplasty.
- There is acceptable evidence that overall there is no difference in kidney outcomes between patients treated medically only or those receiving angioplasty without stent; though the relevance of this finding to current practice is questionable due to changes in treatment options. However, improvements in kidney function were only reported among patients receiving angioplasty.
- There is acceptable evidence that combination antihypertensive treatment results in large decreases in blood pressure. The evidence regarding the relative effect of angioplasty and medication on blood pressure control is inconsistent. The RCTs did not find a consistent effect; other comparative studies mostly found no difference; cohorts of medical treatment generally found larger decreases in blood pressure than cohorts of angioplasty with stent. However, cohort studies of angioplasty with stent did report that up to 18 percent of patients had cure of hypertension.
- There is weak evidence suggesting similar rates of cardiovascular events between interventions; however, it is likely that the studies were too small to detect different rates of cardiovascular events.
- Weak evidence suggests no difference in quality of life with medical treatment alone or with angioplasty.
- The evidence does not adequately assess the relative harms due to adverse events and complications of medical treatment and angioplasty.
- There is weak evidence that patients with bilateral RAS may have more favorable outcomes with angioplasty than with medical therapy compared to patients with unilateral disease.
- Weak or inconsistent evidence does not support whether any other clinical features or diagnostic tests predict outcomes after angioplasty or with medical therapy.
- There is no evidence regarding the value of interventions done at the time of angioplasty (Key Question 3).