# Results

The original search yielded 2,163 citations. Members of the Technical Expert Panel and other domain experts added an additional 28 articles for consideration. We identified 375 of these as potentially relevant and retrieved them for further evaluation. Of these 303 did not meet eligibility criteria. Many articles represented multiple publications arising from the same studies. Thus the original report evaluated 60 unique studies, 5 of which met criteria only to provide data on adverse events.

The updated search yielded 185 new citations. An additional 9 articles met eligibility criteria. These represented 8 new studies and 1 article with newly reported data from a previously reported trial. Figure 2 summarizes the search and selection of articles. Table 1 summarizes the evaluated studies.

Figure 2

Search and selection of studies for review

Table 1

Summary of reviewed studies^*^

Study Type | Evidence Tier † | Intervention | Studies, n | Quality †, n | | | Applicability †, n | | | Participants, n | Years of Intervention
Study Type | Evidence Tier † | Intervention | Studies, n | Good | Fair | Poor | High | Moderate | Low | Participants, n | Years of Intervention
Randomized trials | I | Angioplasty + stent placement vs medical therapy | 0
Randomized trials | II | Angioplasty ± stent placement vs medical therapy | 2^‡^ | | 2 | | | 1 | 1 | 103 | 1992–1995^§^
Randomized trials | III | Angioplasty ± stent placement vs medical therapy ± subsequent angioplasty | 1 | | 1 | | 1 | | | 106 | 1993–1998
Comparison studies^#^ | III | Revascularization vs medical therapy | 8^‡^ | | 2 | 6 | | 1 | 7 | 681 | 1981–2003^§^
Cohort studies | IV | Medical treatment | 4 | | 1 | 3 | | 1 | 3 | 83 | Not reported
Cohort studies | IV | Natural history | 8 | | 3 | 5 | | 3 | 5 | 721 | 1970–1998^§^
Cohort studies | IV | Angioplasty + stent placement | 27 | | 14 | 13 | 6 | 16 | 5 | 3750 | 1989–2004^§^
Cohort studies | IV | Surgical revascularization | 4 | | | 4 | | | 4 | 921 | 1980–2004
Any | II–IV | Studies that reported adverse events | 37 | | | | | | | 5503 | 1989–2004

* This table is updated from Table 1 in Balk et al. Effectiveness of management strategies for renal artery stenosis: a systematic review. Ann Intern Med. 145(12):901–12, 2006 Dec 19.^2^

† See Methods, Assessing the Quality, Applicability, and Relevance of the Evidence, pages 7–10.

‡ One study had both a randomized and nonrandomized component.

§ Some studies did not report the intervention years.

# Combination angioplasty and surgery or surgery versus medical therapy (randomized or nonrandomized study), or angioplasty versus medical therapy in a nonrandomized study.

## Key Question 1: Clinical Effects of Interventions

### Direct Comparisons of Angioplasty (or Surgery) With Medical Treatment of Atherosclerotic Renal Artery Stenosis (Appendix Tables 2 -3, Figures 3-5)

The original CER included three RCTs published in five articles involving a total of 208 patients with ARAS (analyzed, in their randomized arms) that compared angioplasty to medical treatments.12–16 Six additional studies,17–22 and a nonrandomized third arm from one of the RCTs,12 reported comparisons of either angioplasty or surgery and various medical treatments in a total of 491 patients with RAS; it is unclear how many of these patients had ARAS.

Figure 3 Cumulative mortality after intervention (or start of study period) from 6 months to 6 years, with estimated confidence intervals

Studies reporting mortality rates at multiple time points within the time period of interest have been connected with solid lines. Letters A,12 B,18 C,20 and D17 indicate that these studies reported mortality rates for both medical treatment and an invasive intervention. Conlon 2001^37^ reports different mortality rates for 3 subsets of patients with different degrees of stenosis (see Appendix E Figure for details) so is represented by grey boxes.

See Appendix Figure for study specific mortality data.

Figure 4 Forest plot of change in kidney function after interventions

Studies categorized by intervention (angioplasty with stent studies, medicine alone studies, and comparative studies that report net difference between angioplasty (without stent) and medicine. SCr, serum creatinine; CrCl, creatinine clearance (or glomerular filtration rate). 95% confidence intervals were estimated based on reported data (generally the baseline and final standard deviations). Open circles represent studies for which 95% confidence intervals could not be calculated. Studies ordered from longest to shortest duration of followup, then sample size.

Figure 5 Forest plot of change in blood pressure (BP) after interventions

Studies categorized by intervention (angioplasty with stent studies, medicine alone studies, and comparative studies that report net difference between angioplasty (without stent) and medicine. DBP/SBP, diastolic/systolic blood pressure. 95% confidence intervals were estimated based on reported data (generally the baseline and final standard deviations). Open circles represent studies for which 95% confidence intervals could not be calculated. Studies ordered from longest to shortest duration of followup, then sample size.

In the update, two additional articles met criteria. One23 is a further analysis of a previously included RCT.14–16 The other is a newly published nonrandomized study comparing two cohorts of patients treated either medically or with angioplasty.24

#### Description of randomized controlled trials of angioplasty vs. medical treatment

No studies were of Tier I evidence (RCTs of angioplasty with stent vs. aggressive medical therapy).

Two RCTs met eligibility criteria for Tier II evidence, comparing angioplasty without stent to medical treatment, with at least 6 months of followup. Notably, the trials were small and clearly too small to be adequately powered for clinical outcomes including mortality, cardiovascular and kidney events. Stents were used only rarely and medical therapies varied both between and within studies. One study did not use ACE inhibitors12 and the other used enalapril in only some patients.13 Thus neither trial compared patients being treated with interventions currently being used. The trials were of fair quality and either moderate or low applicability to the general population with ARAS. Because these trials are the most pertinent studies that address the key questions, they are summarized in some detail. This information is largely reproduced from the original RAS Comparative Effectiveness Review.1

The SNRASCG study (Webster 1998) was designed to determine if invasive intervention or continued medical therapy resulted in improved blood pressure and preservation of kidney function in hypertensive patients with ARAS.12 In a multicenter study, 55 patients with resistant hypertension with at least 50 percent stenosis were randomized to either angioplasty without stent placement (n=25) or treatment with, preferentially, atenolol, bendrofluazide and/or a calcium antagonist (n=30). Other eligibility criteria applied. Their protocol resulted in two randomized groups (bilateral and unilateral disease) and a nonrandomized group of patients with unilateral disease. Five of the 25 patients randomized to angioplasty had either a nephrectomy or a surgical bypass at the discretion of the local investigators. Patients were followed at 1 month, 3 months, and 6 months after the end of a run-in period or after angioplasty, and then at 6 month intervals thereafter; the primary endpoint was at 6 months. During the followup period (3 to 54 months) five patients (6 percent) who had been randomly or nonrandomly assigned to medical treatment had an angioplasty. The nonrandomized comparisons are included with the other comparative studies below.

The EMMA study (Plouin 1998) compared angioplasty (mostly without stent placement) to drug treatment, primarily for blood pressure outcomes.13 The multicenter trial randomized 49 patients referred for hypertension and unilateral ARAS of at least 60 percent with a positive lateralization test or stenosis of at least 75 percent without thrombosis, from 1992 to 1995. Patients had resistant hypertension, but a creatinine clearance of at least 50 mL/min. Other eligibility criteria applied. Patients were randomized either to angioplasty alone (n=21) or with stent placement (n=2) or to drug treatment (n=26) by a predefined protocol based on diastolic blood pressure. Seven patients randomized to medical treatment were subsequently excluded from analysis due to a major hypotensive event in one patient and to refractory hypertension for which angioplasty was performed prior to 6 months in six patients. The principal results were recorded at 6 months.

#### Description of the comparative studies

Nine other studies compared various interventions in randomized and nonrandomized studies (Tier III evidence). The DRASTIC trial (van Jaarsveld 2000), which has had multiple articles published with results,14–16,23 including a new article found for the update23 randomized patients between immediate angioplasty without stent placement (angioplasty was performed at the start of the trial) and drug therapy (followed by angioplasty if hypertension persisted or kidney function deteriorated). Because the randomized portion of the study ended after 3 months, prior to the agreed upon minimum duration of interest for this review (6 months), we categorized this trial as Tier III. Patients were randomized to receive either immediate angioplasty (n=56) or to drug therapy (n=50, either amlodipine with atenolol, enalapril with hydrochlorothiazide, or other drug regimens if patients could not tolerate the drugs). After 3 months of medical treatment patients were offered angioplasty if resistant hypertension or kidney deterioration continued. Likewise, a second treatment, including surgical revascularization, was considered after 3 months in patients who received immediate angioplasty. The goal of the study was to evaluate changes in blood pressure and kidney function after 1 year of treatment. The multicenter study included 106 patients between 1993 and 1998 who had difficult to treat hypertension associated with normal kidney function or a serum creatinine up to 2.26 mg/dL and were found to have ARAS of 50 percent or more by digital subtraction angiography. Other eligibility criteria applied. Results were reported at both 3 and 12 months by intention to treat analysis. By 12 months, 22 of the 50 patients randomized to drug treatment had received angioplasty; 28 remained on antihypertensive treatment alone.

The other comparative studies include 3 prospective12,22,24 and 2 retrospective17,21 nonrandomized comparisons of angioplasty (mostly without stent use) and medical therapy, 2 prospective nonrandomized comparisons of angioplasty or surgery on one hand and medical therapy on the other, 18,20 and 1 randomized trial of surgery versus medical therapy. 19

The recently published study, Losito 2005^24^ compared patients who were referred either from a renal unit where they were treated medically or from units that routinely performed angioplasty, mostly without stents. Patients were followed for an average of 4.5 years.

#### Outcomes

##### Mortality (study duration 6 months or greater)

Figure 3 graphically presents mortality rates over time in studies of the different interventions, including 4 of the comparative studies. Although mortality was commonly stated to be a primary outcome of the comparative studies, no study was reported to be adequately powered to detect a difference between interventions for this outcome. Among the RCTs of angioplasty versus medical therapy, only the SNRASCG randomized trial (Webster 1998) reported mortality data.12 The survival curves were nearly identical for the two groups over 42 months. Five of the other comparative studies, including Losito 2005, reported mortality analyses.17–20,24 Most found no difference in mortality rates. Only the retrospective study found that patients treated with angioplasty (with or without stent) had a lower mortality rate than those treated medically;17 however, the medically treated patients were older and probably had more severe cardiovascular disease and worse cardiovascular risk factors.

Overall, the comparative studies do not indicate a survival difference between the two modes of intervention.

##### Kidney function

The two RCTs (Webster 1998 and Plouin 1998) found no significant, clinically meaningful or consistent differences in change in kidney function between those who received angioplasty and those who were treated medically. Figure 4 presents forest plots of changes in kidney function after different interventions, including the net differences between angioplasty and medical therapy from the two RCTs. The remaining comparative studies had inconsistent findings. Four studies (including the recently added study) found that kidney function after angioplasty (or surgery) was better than with continuing medical therapy,15,17,22,24 though not all studies performed statistical analyses; one study found significantly worse change in serum creatinine after angioplasty or surgery;18 and three studies found no difference.12,19,21 Notably, only one study (Taylor 1989 22) found that kidney function, on average, improved after angioplasty or surgery, though this was a poor quality study that was extremely small (5 with angioplasty, 15 without).

Overall, the comparative studies provide evidence that the different modes of intervention do not result in different changes in kidney function.

##### Blood pressure control

The two RCTs (Webster 1998 and Plouin 1998) had heterogeneous (inconsistent) findings in regard to the comparative effect on blood pressure control of angioplasty or medical treatment. In the SNRASCG study (Webster 1998),12 among those with unilateral ARAS at 6 months (the primary endpoint) no difference in blood pressure was found. However, an analysis of the final blood pressure readings recorded, adjusted for time (but over a period in which some patients assigned to medical treatment had angioplasty), found a larger reduction in blood pressure occurred among patients treated medically (−10/−2 mm Hg) than those treated with angioplasty (−2/−2 mm Hg); although this difference was not statistically significant. In contrast, among patients with bilateral disease, there was a large decrease in blood pressure (−24/−9 mm Hg at 6 months and −34/−11 mm Hg at final visit) in those who had angioplasty compared to a more modest reduction among patients treated medically (−13/−10 mm Hg at 6 months and −8/−1 mm Hg at final visit). However, only the differences at the final visit, adjusted for time, were statistically significant. Similarly, although to a lesser extent, EMMA (Plouin 1998) found a greater reduction in blood pressure after angioplasty (−14/−8 mm Hg) than with medical treatment (−7/−1 mm Hg, nonsignificant for systolic blood pressure, P=0.04 for diastolic blood pressure).13 Figure 5 presents forest plots of changes in blood pressure after different interventions, including the net differences at 6 months between angioplasty and medical therapy from the two RCTs.

Of note, a Cochrane review performed metaanalysis on different blood pressure results than reviewed here because it used the 3 month data for the DRASTIC study, prior to any crossover of patients from medical treatment to angioplasty.25,26

The other comparative studies mostly found no difference in effect on blood pressure. Six of eight studies found no significant difference in blood pressure, with a mix of whether blood pressures were lower after angioplasty/surgery, or with continued medical therapy. The recent study, Losito 2005,^24^ and a similar retrospective comparison17 found significantly greater improvement in blood pressure after angioplasty or surgery.

Overall, the evidence found that both invasive and medical therapy result in decreases in blood pressure, but the evidence only weakly supports a conclusion that angioplasty may result in better blood pressure control, particularly in people with bilateral disease.

##### Cardiovascular outcomes

Only Webster 1998 (SNRASCG) reported on cardiovascular outcomes.12 The study combined data from the randomized unilateral and bilateral ARAS arms. Event rates for heart failure, stroke, and myocardial infarction were similar regardless of intervention. Uzzo 2002 in the RCT of surgical versus medical treatment found no difference in a combined stop point of resistant hypertension, kidney function worsening, atherosclerotic cardiovascular event, or death.19

##### Quality of life

Quality of life was not explicitly included in the original CER; however, this decision was made in part due to a lack of data. A recently published article regarding the DRASTIC study (that compared immediate angioplasty versus medical therapy or delayed angioplasty) reported on several measures of quality of life.23 These included a validated questionnaire on physical symptoms associated with hypertension and treatment; SF-36, which measures physical functioning, role functioning, social functioning, psychological well-being, health perceptions, and pain; and EuroQol, which measures ability to walk, to perform activities of daily living, depression, anxiety and pain. Overall, for all three measures no significant differences were found at 3 months comparing all patients who received angioplasty or were treated medically, and at 12 months comparing those immediately treated with angioplasty and those who remained on medical treatment. SF-36 social functioning was better at 3 months among patients after angioplasty, but at 12 months was better among those who never received angioplasty.

##### Adverse events (including 30 day mortality)

No new data on adverse event rates among comparative studies has been reported. The following summary is from the original CER.

None of the studies reported data to allow a comparison of adverse event or other complication rates between patients receiving angioplasty and those receiving only medical treatment. In general, complication rates related to angioplasty (or angiography) alone were reported. Therefore, these data have been added to the adverse event section below on angioplasty cohort studies.

Only Englund 1991, in a retrospective study of 38 patients from the 1980s, clearly reported 30-day mortality.21 Similar 30-day mortality rates, given the small number of patients, were found in both the angioplasty (3 percent) and medical treatment (5 percent) arms.

### Cohort Studies of Medical Therapy or Natural History (Appendix Tables 4 , 5 -6, Figures 3–5)

No new cohort studies of medical therapy or natural history of RAS have been published since the original CER (Tier IV evidence). To briefly summarize the CER findings, four prospective studies, including 83 participants, evaluated different medical therapy regimens for patients with ARAS. 27–31 Three additional studies provided only adverse event data. 32–35 These included multidrug regimens (aspirin, statins, and antihypertensive agents) and/or specific angiotensin converting enzyme (ACE) inhibitors. One study was of fair quality and moderate applicability; the other studies were of poor quality and low applicability, largely due to incomplete reporting. An additional eight studies, six of which were prospective, followed the natural history of 721 patients who mostly received various medical therapies.18,36–42 Three were of fair quality and five of poor quality; three were of moderate applicability and five of low applicability.

Among the drug studies, all four showed that, on average, the various treatment regimens examined were effective for lowering blood pressures in ARAS patients to or near the normal range. Two studies reported that kidney function worsened over time.27,31 One study reported an overall mortality rate of 5 percent after 8 to 32 months of followup.31 In one study of 40 ARAS patients on aggressive medical treatment including blood lipid control, one patient (2.5 percent) experienced stroke and one patient (2.5 percent) experienced myocardial infarction during the follow-up period.27 A wide variety of adverse effects were reported for each antihypertensive agent.

Among the natural history studies, kidney function outcomes were reported in six studies; in general patients’ kidney function deteriorated over time, although to different degrees in the different studies. Two studies reported blood pressure outcomes. In one study of 35 people with unilateral ARAS, median diastolic blood pressure did not change significantly over time.18 In a second study of 20 ARAS patients, two-thirds of whom had bilateral stenosis, mean blood pressures decreased substantially (39/17 mm Hg) after medical treatment.38 One study reported eight fatal cardiovascular events in 20 patients with severe stenosis (≥ 75 percent) during 3 to 36 months followup.40 Mortality outcomes were reported in four studies.37,40–42 Six-month, 2-, 4-, and 5-year survival rates were 77 percent, 60 to 68 percent, 64 percent, and 38 percent, respectively.

The studies found that antihypertensive therapy is effective at reducing blood pressure in patients with RAS. However, data on clinical outcome event rates were sparse or inconsistent across studies.

### Cohort Studies of Angioplasty With Stent (Appendix Tables 7–8, Figures 3–5)

#### Summary of cohort studies

The original CER evaluated 21 studies (with a total of 3,368 patients) in 28 publications that placed stents in all patients (Tier IV evidence).43–73 Two additional studies74,75 that reported only adverse events were also included. The studies followed patients from 6 months to 48 months. The original CER included a separate section on four studies that evaluated patients who received angioplasty with or without stent. One of these was an RCT of stent versus no stent.76 For the purposes of this update, we have added the stent arm of this study to the collection of cohort studies of angioplasty with stent.

In the update, six additional articles77–82 met eligibility criteria, one of which reported only adverse event data.82 These studies included a total of 431 patients and followed patients from 6 months to 84 months. One additional recent cohort study evaluated patients who received angioplasty either with or without stent placement. This study is not included here, but is discussed below under Key Question 2.

#### Outcomes

##### Mortality (study duration 6 months or greater)

In the original CER, data on mortality 30 days after angioplasty with stent placement was reported in 18 studies. Only one of the new studies reported mortality data.79 Overall, the mortality rates ranged from 0.5 to 53 percent up to about 5 years; eight studies reported 10 percent or greater mortality at follow up. The most common cause of mortality reported was due to cardiovascular-related deaths. Across studies, there was an expected rise in mortality with increasing duration of followup. However, by visual inspection, there appear to be two groups of studies, those with mortality rates rising from approximately 12 to 30 percent over 4 years, and those with lower mortality rates rising from 0 percent to under 10 percent over 5 years. However, no obvious factors were reported to explain the different mortality rates.

Overall no unifying pattern was found regarding mortality rates after angioplasty with stent.

##### Kidney function

Overall, 22 studies reported kidney outcomes as either changes in estimated glomerular filtration rate (or creatinine clearance) or changes in serum creatinine during followup; five of these were published recently.77–81 A quarter of the studies reported statistically significant improvements in kidney function during followup, on average across all patients. Kidney outcomes were quantified using different definitions and categorized as improved, unchanged, and worsened in 16 studies. Patients with improved kidney function ranged from 8 to 51 percent. Patients with worse kidney function ranged from 0 to 31 percent. Studies also noted that some patients were able to stop dialysis.

The cohort studies found a range of effects on kidney function of angioplasty with stent; however, consistent with the comparative studies and in contrast to patients treated medically, some patients were found to have improved kidney function.

##### Blood pressure control

Twenty-seven studies, five of which were published recently77–81 reported blood pressure outcomes. All studies reported blood pressure outcomes as change from baseline and/or categories of cured, improved, unchanged, and worsened hypertension. Cure generally was defined as maintaining normal blood pressure without medication. Hypertension cure ranged from 4 to 18 percent; hypertension improvement ranged from 35 to 79 percent; and worsening in hypertension ranged from 0 to 13 percent. The majority of the patients had cured or improved blood pressure rates at followup compared to baseline.

The majority of studies observed consistent systolic or diastolic blood pressure reduction at followup after stent placement.

##### Cardiovascular outcomes

Only three studies reported cardiovascular event rates, including one of the recently published studies.45,60,77 They found that patients remain at increased risk of cardiovascular disease after angioplasty with stent placement. A fourth study reported a statistically significant reduction in the New York Heart Association Functional Class after stent placement.54

##### Restenosis rate

Restenosis was evaluated between 3 to 40 months after percutaneous interventions and the rates of restenosis ranged from 6 to 21 percent. A total of 22 studies evaluated restenosis rates during follow-up, including four new studies.78–81 Of these only three studies evaluated the whole cohort of patients who underwent stent placement for restenosis at follow-up.43,44,54 A proportion of the original cohort who presented with clinical symptoms was evaluated in the remainder of the studies. The majority of the studies used stenosis greater than 50 percent as their definition and utilized angiography to evaluate or confirm restenosis. Only one study utilized duplex ultrasound.59 One study noted a statistically significant higher rate of restenosis among those who had undergone stent placement for ostial lesions compared to those with nonostial lesions.63

The cohort studies found that restenosis after stent placement occurs in up to a fifth of renal arteries.

##### Adverse events (including 30 day mortality)

A total of 22 studies reported adverse events immediately following angioplasty with stent intervention. The 30-day mortality was reported in 12 studies and ranged from <1 to 3 percent. A transient deterioration in kidney function following procedure was reported in nine studies, which ranged from 1 to 13 percent, including five studies that reported contrast-induced nephropathy. A severe decline in kidney function was reported in four studies (“severe deterioration of kidney function” in 1.5 percent of patients in one study; kidney failure in 6 to 12 percent of patients in three studies).45,67,69,76 Renal artery or parenchymal injury during procedures ranged from <1 to 10 percent in eight studies. Other complications included: major hemorrhage 1 percent (two studies); renal artery occlusion or spasm 0.5 to 4 percent (six studies); false aneurysms 0.7 to 9 percent (eight studies); severe bleeding 1 to 16 percent (six studies); and localized hematoma 0.4 to 10 percent (seven studies).

### Cohort Studies of Surgical Interventions (Appendix Tables 11–12)

In the original CER, four studies of surgical interventions met eligibility criteria (Tier IV evidence).83–90 No recent studies were found. All four studies were retrospective; they included 921 patients. The mean follow up times in these studies ranged from 4 months to 56 months. All four studies were of methodologically poor quality. The results from these studies are generally applicable to patients with hypertension, chronic kidney disease, and hemodynamically significant ARAS.

All four studies reported similar long-term mortality (about 30–40 percent at 5 years). In one study, three-quarters of the late deaths were due to cardiovascular disease.85 Three studies reported kidney function data. One study found that 74 percent of patients were free of kidney disease at 5 years.84 One study found that glomerular filtration rate (GFR) rose by a small but statistically significant amount (from 41 to 48 mL/min P <0.0001);85 17 percent of patients eventually became dialysis dependent over 1 to 159 months. The third study found that 72 percent of patients had improved or unchanged kidney function up to 46 months after surgery;90 17 percent of patients developed end stage renal disease up to 17 months after surgery. One study reported cured or improved hypertension in 68 percent of the patients at 3 years and 59 percent of the patients had improvement at 5 years.84 Another study reported that 12 percent were cured of hypertension and 73 percent had improved blood pressure 8 weeks or more after surgery.85

These four studies described the following adverse events. Thirty-day mortality rates in the four studies were 3.7 percent,84 4.6 percent,85 6.0 percent,90 and 9.4 percent.83 One study reported that perioperative morbidity occurred in 16 percent of patients, including myocardial infarction, stroke, significant arrhythmia, and pneumonia.85 Another study reported a procedural complication rate of 22 percent, including bleeding/hematoma, occlusion/thrombosis, infection, and distal embolism.83

### Mortality Findings Across Study Designs

We compiled mortality data from all studies. We updated Figure 3 (and the Appendix figure, which includes study details) with the three recently published studies that provided mortality data. Our findings remain the same, that regardless of intervention mortality rates rise over a period of 5 to 10 years. The range of mortality rates is wide for each type of intervention and we found no consistent factor to explain differences across studies. The current data are inadequate to determine whether mortality rates differ based on intervention, though there are no clear differences based on intervention.

## Key Question 2: Predictors of Outcomes

In the original CER, 37 studies provided some data relevant to whether any pre-intervention factors may predict clinical outcomes. The synthesis from the Executive Summary of the original CER is provided below, followed by a description of the findings of two relevant recently published studies.

Among the studies reviewed, the value of diagnostic tests either for predicting long-term outcomes or to help determine the best treatment is unclear. A variety of indicators of the severity of ARAS and of health problems, such as poorer kidney function, worse blood pressure, and coexisting cardiovascular disease predict poorer outcomes in patients with ARAS. The reviewed studies did not report any indicators that may predict improved outcomes.

Neither Tier II evidence RCT directly analyzed whether any baseline predictors, including diagnostic tests, would predict relative outcomes between interventions. Although, in one RCT patients with bilateral stenosis had larger decreases in blood pressure after angioplasty than with medical treatment, in contrast to patients with unilateral disease.

The Tier III RCT (DRASTIC), comparing early versus either delayed or no revascularization, found that in contrast to patients with unilateral disease, patients with bilateral disease had better improvement in diastolic blood pressure, but not in creatinine clearance. Captopril test, renogram, recent hypertension, and stenosis greater than 80 percent were not predictors of either worse outcome overall or of which intervention would result in better outcomes.

Among angioplasty studies with (or without) stent, worse baseline kidney function was associated with increased mortality, poor clinical outcomes, and relatively worse blood pressure after revascularization. A history or markers of some cardiovascular diseases were associated with increased mortality, poor clinical outcomes, and relatively worse kidney function after revascularization.

Age and beta blocker or diuretic use at baseline were not significant predictors of mortality or other clinical outcomes. Baseline captopril test, renogram, arterial norepinephrine, and ACE genotype were generally not associated with outcomes.15–17,20 The association between baseline predictors and outcomes was uncertain for several factors including baseline kidney function as a predictor of followup kidney function, baseline cardiovascular disease as a predictor of blood pressure effect, percent stenosis before angioplasty, bilateral vs. unilateral ARAS, and sex.

Associations between baseline variables and outcomes in natural history studies are generally weak since each association was analyzed by one or two studies only. Among the studies, worse kidney function, higher grade stenosis, various markers of cardiac disease, and older age were associated with higher mortality or dialysis. Patients with nonspiral blood flow in the renal arteries were found to have significant progression in kidney impairment, while those with spiral flow did not.78

Holden 2006^78^ categorized patients prior to angioplasty with stent according to modified KDOQI (Kidney Disease Outcomes Quality Initiative91)criteria of chronic kidney disease (CKD) stage, namely: CKD 3A, GFR 41–59 mL/min; CKD 3B, GFR 30–40 mL/min; and CKD 4, GFR 15–29 mL/min. The effect of angioplasty with stent in the three categories was analyzed separately. At 6 months, they found no difference in percent of patients with improved, stable, or worse kidney function across the three CKD stages.

Garcia-Criado 2005^92^ evaluated preangioplasty renal artery blood flow by Doppler examination (resistive index [RI] and acceleration). After angioplasty (with or without stent), blood pressure improved in 85 percent of patients with RI<0.8 and improved in 50 percent of patients with an RI>0.80 (P < 0.05). Acceleration was not predictive of the effect of angioplasty on blood pressure.

## Key Question 3: Treatment Variables as Predictors of Outcomes After Angioplasty

No recent studies addressed this question. Two prospective cohort studies found no difference in blood pressure and kidney outcomes between patients who had stents placed and those who did not. However, no study that met eligibility criteria reported analyses of whether other periprocedural interventions, such as different drugs or different approaches, affected either complications or long-term outcomes.