# Methods

## Data Sources and Selection

This chapter was largely reproduced from both Balk et al. in the Annals of Internal Medicine2 and the original RAS Comparative Effectiveness Review.1

For the original report we searched the MEDLINE database from inception to 6 September 2005 for studies involving adults with atherosclerotic renal artery stenosis. This update includes articles in the MEDLINE database as of April 23, 2007.

We combined search terms for renal artery stenosis, renal hypertension, and renal vascular disease, and we limited the search to English-language articles of studies in adult humans that had relevant research designs. We included peer reviewed primary studies of adult patients treated for ARAS and excluded studies that evaluated patients with RAS in the setting of a transplanted kidney, renal artery aneurysm requiring repair, aortic disease requiring invasive intervention, or concurrent cancer or patients who had had previous surgical or angioplasty interventions for RAS. We included only studies that reported outcomes of interest (mortality rate, kidney function, blood pressure, cardiovascular events, and quality of life) at 6 months or more after the initial intervention. We excluded studies in which more than 20 percent of patients had RAS due to other causes.

We used different eligibility criteria for studies of different interventions, based on the varying number of studies available for each intervention and the relevance of the intervention to current practice. The criteria were made in conjunction with a Technical Expert Panel (TEP) convened for the original report. We included all direct comparisons of medical treatment with angioplasty and all uncontrolled (cohort) studies of medical treatment that had at least 10 patients in each group, regardless of study design. For angioplasty, surgical, or natural history studies, we included only those in which at least some patients were recruited in 1993 or later, after the publication of the Fifth Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (JNC-5). These guidelines marked a substantial change from previous guidelines in treatment recommendations for hypertension, including more aggressive blood pressure targets.11 In addition, at this time point, angiotensin-converting enzyme inhibitors began to be used more routinely in the treatment of patients with severe hypertension.

We included angioplasty studies only if they used stent placement in at least some patients, were prospective, and had at least 30 patients; and retrospective surgery studies that included at least 100 patients. Any prospective surgery study (with at least 10 subjects) that otherwise met criteria was eligible.

## Assessing the Quality, Applicability, and Relevance of the Evidence

The system used for grading the quality and applicability used here is well-established, though not universally used, by EPCs. The Tufts-New England Medical Center EPC has been using a similar system for almost all its systematic reviews for almost a decade. The system used for grading the body of evidence is based on a system being used for all the CERs; however, this system is still evolving. The system for assessing the relevance of the individual studies (tiers of evidence) was designed de novo specifically for this report. It was designed to clarify the relevance of a body of evidence that fails to directly address the main questions of interest. It should be noted that none of the systems used directly correspond to the “Levels of Evidence” used by the ACC/AHA guidelines for the management of patients with peripheral arterial disease, which simply denote the study designs of the evaluated literature.8,9

### Data Extraction

Data from each study were extracted by one of the authors and confirmed by another. The extracted data included information about patient samples, interventions, outcomes, adverse events, study design, quality, and applicability. For most outcomes, only data from the last reported time point were included. Mortality data from all 6-month intervals from baseline and the final value were extracted.

### Quality Assessment

We used predefined criteria to grade study quality as good, fair, or poor. This system defines a generic grading system that is applicable to varying study designs including RCTs, nonrandomized comparative trials, cohort, and case-control studies. For RCTs, we mainly considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described, as well as clearly reported. Only RCTs could receive an A grade. For nonrandomized trials and prospective and retrospective cohort studies, we used (as applicable) the report of eligibility criteria, and the similarity of the comparative groups in terms of baseline characteristics and prognostic factors, the report of intention-to-treat analysis, and the crossovers, important differential loss to followup between the comparative groups or overall high loss to followup, the validity, and the adequacy of the description of outcomes and results.

A (good)

Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.

B (fair)

Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

C (poor)

Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information, or discrepancies in reporting.

### Applicability Assessment

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (e.g., disease status, age, comorbidities). Some may be implicit or due to unintentional biases, such as those related to location (e.g., multicenter vs. single center, hypertension clinic vs. surgical practice), intervention (e.g., stent or no stent placement, which antihypertensive agents were used, angioplasty vs. surgery), factors resulting in study withdrawals or issues related to compliance with stated criteria, and other issues. The applicability of a study is dictated by the key questions, the populations, and the interventions that are of interest to this review, as opposed to those of interest to the original investigators.

To address this issue, we categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

High

Sample is representative of the target population. It should be sufficiently large to cover a range of ARAS severity, including percent stenosis, percent with bilateral stenosis, blood pressure, and kidney function. The mean values of these parameters should be at least broadly similar to the mean for the typical patient receiving treatment for ARAS. In addition, the intervention should be applicable to currently used interventions, including angioplasty with stent placement and/or those antihypertensive drugs currently used commonly. At least 30 subjects analyzed.

Moderate

Sample is representative of a relevant subgroup of the target population, but not the entire population, or interventions used were similar to those of primary interest to this review (e.g., angioplasty without stent placement). Limitations include such factors as narrow age range, inclusion of patients without ARAS, atypically high blood pressure, or serum creatinine.

Low

Sample is representative of a narrow subgroup of subjects only, and is of limited applicability to other subgroups. For example, a study of a surgical intervention or mostly from the early 1980s when ACE inhibitors, calcium antagonists, and beta-blockers were either not or rarely used.

### Grading a Body of Evidence for Each Key Question

We assigned an overall grade describing the body of evidence for each key question that was based on the number and quality of individual studies, duration of followup and the consistency across studies. The grades provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, they may oversimplify the many complex issues involved in appraising a body of evidence. The individual studies involved in formulating the composite grade differed in their design, reporting, and quality. As a result, the strengths and weaknesses of the individual reports addressing each key question should also be considered, as described in detail in the text and tables.

The original Comparative Effectiveness Review used the terminology Robust, Acceptable, and Weak to describe the levels of evidence. To improve clarity the levels of evidence, for the purposes of this update, the category Inconsistent was added, as described below:

Robust

There is a high level of assurance with validity of the results for the key question based on at least two high quality studies with long-term followup of a relevant population. There is no important scientific disagreement across studies in the results for the key question.

Acceptable

There is a good to moderate level of assurance with validity of the results for the key question based on fewer than two high quality studies or in high quality studies that lack long-term outcomes of relevant populations. There is little disagreement across studies in the results for the key question.

Weak

There is a low level of assurance with validity of results for the key question based on either moderate to poor quality studies or on studies of a population that may have little direct relevance to the key question.

Inconsistent

There is disagreement across or within studies, preventing a conclusion about the actual effect.

### Tiers of Evidence

For the purposes of this systematic review, where there is no evidence directly addressing the primary Key Questions and few comparative studies of any kind, we developed tiers of evidence to highlight the relevance of particular groups of studies to the Key Questions. These are:

Tier I

RCTs that compared angioplasty with stent placement to aggressive medical therapy. These studies would directly address Key Question 1. No published studies qualify for Tier I.

Tier II

RCTs that compared angioplasty with or without stent to medical therapy with at least 6 months of followup. These were the best available studies that studied interventions similar to those of interest.

Tier III

Other comparative studies that compared angioplasty or vascular surgery to medical therapy (regardless of followup time). These are less relevant comparative studies or comparative studies with poorer study designs than Tier II studies.

Tier IV

Noncomparative cohort (pre-post) studies of interventions of interest. These studies do not directly provide information about the relative value of different interventions.