# Supplemental Tables and Figure

Table 2

Direct comparisons of angioplasty or surgery and medical treatment for renal artery stenosis (new results in italics)

Author, Year | Intervention | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | | Qual
Author, Year | Intervention | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | CVD (%) | Qual
Study Design | Intervention | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | Worse | CVD (%) | Appl
Angioplasty vs Medical Treatment, RCT
Webster, 1998^12^ SNRASCG | Angioplasty | 190/99 | >50% | 12 | Ostial 46% | | | | | | | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
Webster, 1998^12^ SNRASCG | No stent | [2.1] | >50% | (12) | Ostial 46% | | 6 mo BP Δ = −24/−9 Adj BP Δ = −34/−11 (adjusted for followup time) | | | | 6 mo SCr Δ = +0.01 Final SCr Δ = +0.11 “Renal failure”:^A^ 8% | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (bilateral disease, see other entries) | Medicine | 190/101 | 100% | 16 | nd | (3–54 mo) | | | | | | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (bilateral disease, see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.7] | 100% | (16) | nd | (3–54 mo) | 6 mo BP Δ = −13/−10 NS (net) Adj BP Δ = −8/−1 P=0.02 (net) | | | | 6 mo SCr Δ = +0.10 NS (net) Final SCr Δ = +0.05 NS (net) “Renal failure”:^A^ 7% | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (unilateral disease, see other entries) | Angioplasty | 189/105 | >50% | 13 | Ostial 52% | | | | | | | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | No stent | [1.6] | >50% | (13) | Ostial 52% | | 6 mo BP Δ =−19/−11 Adj BP Δ = −2/−2 | | | | 6 mo SCr Δ = +0.07 Final SCr Δ = +0.09 | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | Medicine | 182/99 | 0% | 14 | nd | (3–54 mo) | | | | | | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.9] | 0% | (14) | nd | (3–54 mo) | 6 mo BP Δ =−19/−15 NS Adj BP Δ = −10/−2 NS (net) | | | | 6 mo SCr Δ = +0.44 NS (net) Final SCr Δ = 0 NS (net) | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
Plouin, 1998^15^ EMMA | Angioplasty | 165/98 | >60% | 23 | Ostial 39% | 6 mo | | | | | | | 0/23 | | B
Plouin, 1998^15^ EMMA | +/−stent^C^ | 73 | >60% | (23) | Ostial 39% | 6 mo | BP Δ = −14/−8 | | | | CrCl Δ = +4 | | | | B
RCT | Medicine^D^ | 165/96 | 0% | 25 | 1992–1995 | | | | | | | | 1/19^E^ | | Low
RCT | Multiple regimens^F^ | 73 | 0% | (25) | 1992–1995 | | BP Δ = −7/−1 p=NS/0.04 (net) | | | | CrCl Δ = 0 NS (net) | | | | Low
Angioplasty vs Medical Treatment or Delayed Angioplasty, RCT
van Jaarsveld, 2000^13,14,16,23^ DRASTIC | Angioplasty | 179/104 | 76% | 56 | nd | 1 yr | | | | | | | 4% | | B
van Jaarsveld, 2000^13,14,16,23^ DRASTIC | No stent^G^ | 67 | 23% | (56) | nd | 1 yr | BP Δ = −19/−12 | | | | CrCl Δ = +3 | | | | B
RCT | Medicine^H^ (n=28) | | | | | | | | | | | | 12% | | High
RCT | Multiple regimens I | 180/103 | 72% | 50 | 1993–1998 | | BP Δ = −17/−7 NS (net) | | | | CrCl Δ = +2 NS (net) | | | | High
RCT | Delayed angioplasty (n=22) | 60 | 22% | (50) | 1993–1998 | | BP Δ = −17/−7 NS (net) | | | | CrCl Δ = +2 NS (net) | | | | High
RCT | | | | | | Quality of Life: | Physical complaints: Number of complaints decreased more after angioplasty than medicine, NS EuroQol and MOS: Overall NS MOS social functioning: 3 mo: angioplasty better than medicine (+11 v 0, p=.06) 12 mo: medicine better than angioplasty (+20 v −2, p=0.04) | | | | | | | | High
Angioplasty vs Medical Treatment, Nonrandomized, Controlled Trial
Losito, 2005 24 | Angioplasty | 166/92 | 74% | 136 | Proximal 79%, Ostial 6%, Distal 15% | 54.4 mo | | | | | | | | | B
Losito, 2005 24 | Few with stent | [1.8] | 74% | (136) | Proximal 79%, Ostial 6%, Distal 15% | 54.4 mo | BP Δ = −22/−10 | | | | SCr Δ = +0.48 ESRD = 9.4% | | | | B
Prosp | Medicine | 160/89 | 26% | 54 | 1992–2000 | nd | | | | | | | | | Mod
Prosp | nd | [1.7] | 26% | (54) | 1992–2000 | nd | BP Δ= −11/−8 P<0.05 (net) | | | | SCr Δ= +1.29 P=0.04 (net) ESRD = 13.0% NS (net) | | | | Mod
Webster, 1998^12^ | Angioplasty | 196/109 | >50% | 28 | Ostial 63% | nd | | | | | | | | | B
Webster, 1998^12^ | No stent | [1.9] | >50% | (28) | Ostial 63% | nd | Adj BP Δ= −13/−11 | | | | Final SCr Δ= +0.15 | | | | B
NRCT (see other entries) | Medicine | 197/103 | nd | 51 | nd | (3–54 mo) | | | | | | | | | Low
NRCT (see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.6] | nd | (51) | nd | (3–54 mo) | Adj BP Δ = −12/−6 NS (net) | | | | Final SCr Δ = 0.05 NS (net) | | | | Low
Taylor, 1989^22^ | Angioplasty | 160/96 | >60% | 5 | nd | 6.5 mo | | | nd | | | | | | C
Taylor, 1989^22^ | No stent | nd | >60% | (nd) | nd | 1–21 mo | BP Δ = −23/−6 | | | | SCrΔ = −0.5 (including 7 receiving surgery) | | | | C
Prosp | No revascularization | 174/100 | nd | 15 | nd | 13 mo | | | 20% | | | | | | Low
Prosp | nd (0–3 drugs) | nd | nd | (nd) | nd | 7–20 mo | BP Δ = −24/−20 | | | | SCr Δ = +1.0 P=0.08 (base); P<0.01 (net) | | | | Low
Englund, 1991^21^ | Angioplasty | 165/96 | nd | 21 | nd | 17 mo | 0 | | | | | | | | C
Englund, 1991^21^ | No stent | [3.9] | nd | (?19–21) | nd | nd | BP Δ = −9/−5 | | | | SCr Δ = +1.05 | | | | C
Retro | Medicine | 185/101 | nd | 17 | 1981–1988 | 16 mo | 0 | | | | | | | | Low
Retro | nd | [3.8] | nd | (17) | 1981–1988 | nd | BPΔ = −24/−12 NS (net) | | | | SCr Δ = 0.+69 NS (net) | | | | Low
Pizzolo, 2004^17^ J | Angioplasty | 168/95 | ~88% | 63 | nd | 28 mo | 0 | 57% | 43% | | 82% | 18% | | | C
Pizzolo, 2004^17^ J | +/−stent^K^ | [1.5] | 30% | (63) | nd | 28 mo | | | | | | | | | C
Retro | Medicine | 159/91 | ~79% | 37 | 1996–2002 | 1–60 mo | 0 | 29% | 71% | | 52% | 48% | | | Low
Retro | Multiple regimens^L^ | [1.4] | 27% | (37) | 1996–2002 | 1–60 mo | P<0.05 | | | | | | | | Low
Angioplasty or Surgery vs Medical Treatment, Nonrandomized, Controlled Trial
Pillay, 2002^18^ | Procedure | nd | >50% | 12 | nd | 2.5 yr | | | | | | | | | C
Pillay, 2002^18^ | Various^M^ | nd | >50% | (nd) | nd | 2.5 yr | DBP Δ = −15 | | | | SCr Δ = +0.6 P=0.01 (base) Dialysis: 1/12 | | | | C
Prosp | Medicine | | 100% | 21 | 1994–1998 | >2 yr | | | | | | | | | Low
Prosp | nd | | 100% | (nd) | 1994–1998 | >2 yr | DBP Δ = −6 NS (net) | | | | SCr Δ = 0 NS (base) Dialysis 0/12 | | | | Low
Johansson, 1999^20^ | Procedure | 179/91 | ≥ 50% | 105 | nd | 7.1 yr | 53% (1 yr) | | | | | | | | C
Johansson, 1999^20^ | Various^N^ | 179/91 | ≥ 50% | (~91) | nd | 7.1 yr | | | | | | | | | C
Prosp | Medicine | 61 | nd | 64 | 1983–1984 & 1988–1994 | | nd | | | | | | | | Low
Prosp | nd | 61 | nd | (~56) | 1983–1984 & 1988–1994 | | | | | | | | | | Low
Surgery vs Medical Treatment, RCT
Uzzo, 2002^19^ | Surgery | nd | ≥ 75% | 25 | nd | 6.2 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | Stop point:^O^68% | C
Uzzo, 2002^19^ | Multiple | nd | ≥ 75% | (25) | nd | 6.2 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | Stop point:^O^68% | C
RCT | Medicine | nd | nd | 27 | nd | up to 7 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | 67% | Low
RCT | nd | nd | nd | (27) | nd | up to 7 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | NS^P^ | Low

Δ, change; Adj, adjusted; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CHF, congestive heart failure; CKD, chronic kidney disease; CVA, cerebrovascular event (stroke); CVD, cardiovascular disease; DBP, diastolic blood pressure; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m^2^); HTN, hypertension; Imp, improved; MI, myocardial infarction; mo, months; nd, no data; NS, nonsignificant; Qual, quality rating; RAS, renal artery stenosis; Rx, prescriptions; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); yr, years.

A Combined unilateral and bilateral RAS.

B Or, frusemide, methyldopa, or prazosin. Angiotensin converting enzyme inhibitors were not allowed. ^C^ 21 angioplasty alone, 2 angioplasty with stent.

D Intention to treat. 7 of 26 patients randomized to medical therapy received angioplasty within 6 months.

E ≥50% increase in plasma creatinine.

F Goal diastolic blood pressure (DBP)<95 mm Hg, using, if necessary, atenolol 50 mg, furosemide 40 mg, and/or enalapril 10 mg.

G Protocol called for no stent, but stents were placed in 2 patients.

H Intention to treat. 22 of 50 patients randomized to medical therapy at 3 months received angioplasty because of persistent hypertension or deterioration of kidney function.

I Randomized to amlodipine 10 mg (+ atenolol 50 mg if age >40 yr) or enalapril 20 mg (+ hydrochlorothiazide 25 mg if age >40 yr), or if could not tolerate either regimen, atenolol 100 mg (+ hydrochlorothiazide 25 mg if age >40 yr).

J Entry criteria for those receiving angioplasty and those receiving medical therapy were markedly different. Those receiving angioplasty had primary evaluation for resistant hypertension or unexplained azotemia. Those receiving conservative therapy had angiographic evaluation for other causes, primarily lower extremity arteriopathy. Endovascular therapy not considered for this latter group.

K 21 angioplasty alone; 42 angioplasty with stent.

L Goal BP≤140/90. Most frequent used classes of drugs were ACE inhibitors (62%), diuretics (62%), calcium antagonists (49%), and beta-blockers (30%).

M Among 12 patients, “9 angioplasties (1 failure) and 1 bilateral stent. 4 kidneys had… surgery.”

N 88 angioplasty, 17 reconstructive surgery or nephrectomy.

O DBP>100 on treatment, or kidney function worsening (by GFR, SCr, or dialysis), or atherosclerotic cardiovascular event, or death.

P By Cox proportional hazard survival analysis.

Table 3

Adverse events associated with medical and angioplasty treatments of renal artery stenosis in direct comparison studies See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Pizzolo 2004^17^ | 122 (122) | Angioplasty (+/− stent) vs Medical (multiple regimens) | Partial kidney infarction 3% (Angioplasty) Periprocedure acute worsening kidney insufficiency 3% (Angioplasty) | Periprocedure MI 1.6% (Angioplasty) | Cholesterol embolism 1.6% (Angioplasty) | | | 3 of the 4 adverse events occurred in the same person. No data on adverse events in medicine arm
Webster 1998^12^ | 55 (55) | Angioplasty (no stent) vs. Medical (atenolol, bedrofluazide, and/or calcium antagonist, or others) | | In hospital stroke 5% (Angioplasty) Symptomatic hypotension 2% (Angioplasty) | No dissections, perforation, or renal artery thrombosis | Bleeding at arterial site 20% (Angioplasty) | No deaths | Pain requiring narcotic analgesic 10% (Angioplasty) No data on adverse events in medicine arm
Plouin 1998^15^ | 49 (49) | Angioplasty (+/− stent) vs. Medical (multiple regimens) | Renal artery dissection 4% (Angioplasty) 0% (Medical) | | No occlusions | Hematoma at puncture site 22% (Angioplasty) 4% (Medical)
Englund 1991^21^ | 38 (36) | Angioplasty (no stent) vs. Medical (nd) | Rupture of dilated renal artery & nephrectomy 3% (Angioplasty) | | | | 3% (Angioplasty) 5% (Medical)
Van Jaarsveld 2000^13,14,16^ | 106 (106) | Angioplasty (no stent) vs. Medical (multiple regimens) or delayed angioplasty | | Periprocedural angina 0% (Angioplasty) 2% (Medical/Delayed angioplasty) Periprocedural MI 0% (Angioplasty) 2% (Medical/Delayed angioplasty) | Occlusion of affected artery 0% (Angioplasty) 16% (Medical/Delayed angioplasty) Rupture of affected artery 0% (All) | Groin hematoma necessitating transfusion or intervention 4% (Angioplasty) 8% (Medical/Delayed angioplasty) | | Embolization of cholesterol crystals 0% (Angioplasty) 14% (Medical/Delayed angioplasty) Symptomatic hypotension at angioplasty 1.8% (Angioplasty) 0% (Medical/Delayed angioplasty)

ARAS, atherosclerotic renal artery stenosis; CVD, cardiovascular disease; d, day; MI, myocardial infarction; N, number evaluated; nd, no data; RAS, renal artery stenosis.

Table 4

Medical treatments for blood pressure maintenance of atherosclerotic renal artery stenosis (no new data)

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | Intervention | Mean Followup Duration | Results | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Study Years | (Range) | BP Control | Kidney Function | Cardio-vascular Disease | Appl
Hanzel, 2005^27^ | 154/77 | ≥70% | 40 | Aspirin, statin, and antihypertensive therapy^A^ | 21 mo | BP Δ −11/−5 P=0.03/0.01 | SCr Δ +0.1 (+7%) P=0.02 GFR Δ −4 (−6%) P=0.03 | Stroke 1/40 MI 1/40 | B
Prosp | 61 [1.3] | 18% | (40) | nd | (nd) | BP Δ −11/−5 P=0.03/0.01 | SCr Δ +0.1 (+7%) P=0.02 GFR Δ −4 (−6%) P=0.03 | Stroke 1/40 MI 1/40 | Mod
Franklin, 1985^28,29^ | 180/106 | >50% | 13 | Triple-drug regimen cross to enalapril 5–20 mg | 7.5^D^ mo | BP Δ −50/−29 P≤0.01 | | | C
RCT & Prosp^B^ | [1.3]^C^ | 49%^C^ | (nd) | nd | (nd) | BP Δ −50/−29 P≤0.01 | | | Low
Ogihara, 1991^30^ | 172/103 | nd | 10 | Delapril 7.5–120 mg | Mostly 12 wk >1 yr in some | 8/10 BP Δ ≥ −20/−10 | | | C
Prosp | nd | nd | (nd) | nd | Mostly 12 wk >1 yr in some | 5/10 BP Δ ≥ −30/−15 | | | Low
Tillman, 1984^31^ | 180/104^E^ | nd | 20 | Enalapril 10–40 mg | 19 mo | BP Δ −40/−19^D^ P<0.05 | SCr Δ +0.3 P<0.05 | | C
Prosp | [1.3] | 25% | (≤19) | nd | (8–32 mo) | BP Δ −40/−19^D^ P<0.05 | SCr Δ +0.3 P<0.05 | | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; GFR, glomerular filtration rate (mL/min or mL/min/1.73 m^2^); HTN, hypertension; mo, months; nd, no data; Mod, moderate; Prosp, prospective nonrandomized study; Qual, quality rating; RAS, renal artery stenosis; RCT, randomized controlled trial; SCr, serum creatinine (mg/dL); wk, weeks; yr, year.

A All patients received aspirin 325 mg/day and a statin to achieve LDL cholesterol <100 mg/dl. Antihypertensive therapy was initiated with an ACE inhibitor or ARB, and other agents were added as necessary. Six patients (15%) developed progressive decreases in single-kidney GFR underwent late renal artery stenting. After stenting, patients received ticlopidine 250 mg twice daily or clopidogrel 75 mg/day for more than 30 days.

B Initially an RCT, then an open-label trial during a “maintenance period.”

C Data was based on the total of 39 patients who were randomized to standard triple therapy group. Of these, in 13 patients therapy was switched from the triple-drug regimen to enalapril during the extension period, and the outcomes were based on these 13 patients.

D Median

E Value was estimated from graph.

Table 5

Adverse events associated with the medical treatment of renal artery stenosis (no new data)

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Franklin 1985^28,29^ | 75 (57) | Medical (Enalapril vs STT) | | Orthostatic hypotension 11% (enalapril) CNS symptoms 18% (STT) | | | | No leucopenia, dysgeusia, rash, or proteinuria
Takabatake 1987^32^ | 21 | Medical (Captopril) | | Hypotension comparable in bilateral and unilateral stenosis (nd on %)
Tillman 1984^31^ | 20 (≤ 19) | Medical (Enalapril) | | Symptomatic tachycardia 20% Angina 5%
Jackson 1986^33,34^ | 16 (16) | Medical (Enalapril) | Increased SCr 25% | | | | | No rash, taste disturbance, or neutropenia
Hricik 1983^35^ | 11 (nd) | Medical (Captopril) | Transient kidney insufficiency 100%

ARAS, atherosclerotic renal artery stenosis; CNS, central nervous system; CVD, cardiovascular disease; d, day; GFR, glomerular filtration rate; MI, myocardial infarction; N, number evaluated; nd, no data; RAS, renal artery stenosis; STT, “standard triple therapy”; SCr, serum creatinine.

A All patients received aspirin 325 mg/day and a statin to achieve LDL cholesterol <100 mg/dl. Antihypertensive therapy was initiated with an ACE inhibitor or ARB, and other agents were added as necessary. Six patients (15%) developed progressive decreases in single-kidney GFR underwent late renal artery stenting. After stenting, patients received ticlopidine 250 mg twice daily or clopidogrel 75 mg/day for more than 30 days.

Table 6

Natural history or nonspecified medical treatments of atherosclerotic renal artery stenosis (no new data)

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | Intervention | Mean Followup Duration | Results | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Study Years | (Range) | BP Control | Kidney Function | Cardiovascular Disease | Appl
Caps, 1998^36^ | 163/84^A^ | ≥60% | 100^B^ | Medical Rx | nd | | Kidney atrophy: 21%^C^ | | B
Prosp | [1.6]^A^ | nd | (100) | 1990–1993 | (2–24 mo) | | Kidney atrophy: 21%^C^ | | Mod
Cheung, 2002^42^ | 167/87 | ≥50% | 26 or 11^D^ | Mostly medical Rx^E^ | 35 mo | | Δ GFR: −4.9/yr (n=11) GFRΔ >20%: 6/11 | | C
Prosp & Retro | 35.5 | 100% | (nd) | nd | (1–82 mo) | | Δ GFR: −4.9/yr (n=11) GFRΔ >20%: 6/11 | | Low
Conlon 2001^37^ | nd | ≥50% | 362 | Various | 3.2 y | | Only mortality data reported | | B
Prosp | [1.2] | 17% | (nd) | nd | (6–90 mo) | | Only mortality data reported | | Low
Fergany, 1994^38^ | 179/102 | nd | 20 | Medical Rx | 43 mo | BP Δ −39/−17 P=0.03 | SCr Δ +0.2 NS | | C
Prosp | [1.2] | 65% | (nd) | 1970–1990 | (4–120 mo) | BP Δ −39/−17 P=0.03 | SCr Δ +0.2 NS | | Low
Houston, 2004^39^ | nd | >60% | 45 | nd | 9 yr | | SCr Δ +0.3^F^ P=0.004 | | C
Prosp | [~1.8]^F^ | nd | (nd) | nd | | | SCr Δ +0.3^F^ P=0.004 | | Mod
Iglesias, 2000^41^ | 143/84 | >20% | 96 or 78^G^ | nd | 55 mo | | Δ SCr: +0.06/yr (n=78) | | C
Retro | [1.2] | 20% | (nd) | nd | (nd) | | Δ SCr: +0.06/yr (n=78) | | Mod
Pillay, 2002^18^ | nd/88^F^ | >50% | 52 or 35^H^ | Medical Rx | 2 yr | DBPΔ −8^F^ P=NS | SCrΔ +0.2^F^ (n=35) P=0.002 Dialysis: 2/52 | | C
Prosp | [1.2]^F^ | 0% | (nd) | 1994–1998 | (2 yr) | DBPΔ −8^F^ P=NS | SCrΔ +0.2^F^ (n=35) P=0.002 Dialysis: 2/52 | | Low
Uzu, 2002^40^ | 170/77 | ≥75% | 20 | Medical Rx | nd | | Dialysis: 8/20 | CVD deaths: 8/20 | B
Prosp | [3.2] | 59% | (nd) | 1996–1998 | (3–36 mo) | | Dialysis: 8/20 | CVD deaths: 8/20 | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CVD, cardiovascular disease; DBP, diastolic blood pressure; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m^2^); mo, months; Mod, moderate; nd, no data; NS, nonsignificant; Qual, quality rating; RAS, renal artery stenosis; Rx, prescription; SCr, serum creatinine (mg/dL); yr, years.

A Data were based on all 204 kidneys, including 43 (21 percent) kidneys with normal baseline arteries at baseline.

B Number of kidneys

C Cumulative incidence of kidney atrophy (a reduction in kidney length >1 cm during followup compared to the length at baseline examination) over a period of 2 year

D Only nondialysis and survived patients with baseline renal functional data were analyzed for followup renal function analyses.

E Very few patients received angioplasty; of which only one received stent.

F Value was estimated from graph.

G Patients who died within 180 days excluded from analyses of annual changes SCr. These patients had better survival rate than the whole cohort.

H Survivors only.

Table 7

Angioplasty with stent placement for treatment of renal artery stenosis (new studies in italics)

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | | | Qual
Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | | % Restenosis | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | | Worse | % Restenosis | Appl
Kennedy, 2003^60,61^ A | 168/82 | >60^B^ | 261 | nd | 21 mo | | | | | | | | | 48 | B
Prosp | 51 | 38 | (253) | 1993–2001 | 1–85 | BP Δ = −19/−6 P=0.0001 | | | | CrCl Δ = −2 P <0.05 | | | | 17 mo | High
Ruchin, 2007 79 | 162/78 | 84 | 89 | nd | 28 mo | | | | | | | | | 6.2 | B
Prosp | 50 | nd | (87) | 1997–2003 | 6–84 | BP Δ = −23/−1.7 P<0.0001/NS | | | | eGFR Δ = +2.0 NS | | | | nd | High
van de Ven, 1999^76^ | 186/103 | >50 | 40 | Ostial 100% | 6 mo | 15 | 43 | 43 | | 13 | 65 | | 20 | 14 | B
Prosp | [1.8] | 18 | (40) | 1993–1997 | nd | | | | | | | | | | High
Zeller, 2004^69–73^ | 102 | >70 | 354^K^ | Ostial 95% | 34 mo | | 46 | 43 | 11 | 10 | 39 | | 27 | | B
Prosp | [1.5] | nd | (340) | 1996–2002 | 2–79 | MAP Δ = −8 P<0.0001 | | | | GFR Δ = +3.0 NS | | | | nd | Mod
Rocha-Singh, 2005^65^ | 168/82 | >70 | 208 | Ostial 100% | nd | | | | | | | | | 17^C^ | B
Prosp | [1.4] | 21 | (208) | 1997–1999 | 9–24 mo | BP Δ = −19/−5 P=0.001 | | | | SCr Δ = +0.10 P<0.04 | | | | 9 mo | Mod
Dangas, 2001^45^ D | 170/84 | 74 | 131 | Ostial 75% | 15 mo | | 47 | 40 | 13 | 18 | 61 | | 21 | | B
Prosp | [1.9] | 17 | (nd) | nd | nd | BP Δ = −25/−10 P<0.001 | | | | SCr Δ = +0.1 NS | | | | nd | Mod
White, 1997^68^ | 173/88 | >50 | 100 | Ostial 81% | 6 mo | | | | | | | | | 19^C^ | B
Prosp | [2.4] | 33 | (100) | 1992–1994 | nd | BP Δ = −27/−11 P<0.01 | | | | | | | | 6 mo | Mod
Gill, 2003^51^ | 191/98^E^ | >50^F^ | 100^G^ | Ostial 78% | 25 mo | 4 | 79 | 17 | | 31 | 42 | | 31 | 66^H^ | B
Prosp | [2.7] I | 26 | (100) | 1993–1999 | 1–66 | BP Δ = −27/−12 P<0.01 | | | | SCr Δ = −0.6 mg/dL^J^ NS | | | | 11 mo | Mod
Iannone, 1996^59^ | 160/80 | 67 | 63 | Ostial 78% | 10 mo | 4 | 35 | 54 | 7 | 36 | 46 | | 18 | 14^c^ | B
Prosp | [1.8] | 22 | (63) | 1992–1993 | 1–22 | BP Δ = −12/−1 P=0.01/NS | | | | SCr Δ = −0.1 NS | | | | 11 mo | Mod
Sapoval, 2005 80 | 172/92 | 68 | 52 | Ostial 62% | 6 mo | 5 | 61 | 34 | | | | | 3.8 | 14.3 | B
Prosp | [1.2] | nd | (52) | 2001–2002 | nd | BP Δ = −20/−7 NS | | | | SCr Δ = −.07 NS | | | | 6 mo | Mod
Harden, 1997^56^ | 169/95 | >50 | 32 | Ostial 75% | 17 mo | | | | | 34 | 34 | | 28 | 12.5 | B
Prosp | nd | 34 | (32) | 1992–1995 | nd | BP Δ = −6/−8 NS/<0.01 | | | | | | | | 6 mo | Mod
Tsao, 2005 81 | 146/78 | 86 | 54 | Ostial 95% | 6 mo | | | | | 15 | 79 | | 6 | 3 | B
Prosp | 36 | 22 | (53) | 2001–2004 | nd | BP Δ= −15/−7 P<0.05 | | | | SCr Δ= ~ −0.1 NS | | | | 6 mo | Low
Blum, 1997^43^ | MAP 133 | >50 | 68 | Ostial 100% | 27 mo | 11 | 42 | 15 | | | | | | 12 | B
Prosp | [1.2] | 9 | (68) | 1989–1996 | 3–84 | MAP Δ = −20 P<0.0001 | | | | SCr Δ= 0 NS | | | | 3–24 mo | Low
Gross, 1998^55^ | 163/93 | 75 | 30 | Ostial 100% | 6 mo | | 69 | 31 | | | | | | 12.5 | B
Prosp | [1.4] | 23 | (30) | nd | nd | BP Δ =−18/−10 P=0.004/0.007 | | | | | | | | 6 mo | Low
Dorros, 2002^46–50^ | 168/84 | nd | 1058 | nd | nd | | | | | | | | | nd | C
Prosp | [1.7] | 36 | (1058) | 1990–1997 | 1–4 yr | BP Δ = −21/−6 P<0.05 | | | | SCr Δ = −0.4 P<0.05 | | | | | Mod
Lederman, 2001^62^ | 164/84 | 62 | 300 | Ostial: 95% | 16 mo | | 70 | | | 8 | 78 | | 14 | 21 | C
Prosp and Retro | [1.5] | 41 | (293) | 1993–1998 | 6–24 | BP Δ = −22/−8 | | | | SCr Δ = +0.1 P=0.05 | | | | 17 mo | Mod
Rocha-Singh, 1999^66^ | 110 MAP^L^ | >75 | 150 | Ostial 43% | 13 mo | 6 | 50 | 44 | 23 | 69 | 8 | | | 12^C^ | C
Prosp | [1.5]^M^ | 20^N^ | (150) | 1993–1995 | nd | | | | | SCr Δ = +0.04 NS | | | | 13 mo | Mod
Tuttle, 1998^67^ | 160/84 | >70 | 129 | Ostial 100% | nd | 55 | | | | 15 | 81 | | | 14^C^ | C
Prosp & Retro | 40 | 15 | (129) | 1991–1996 | 6–24 | BP Δ = −8/−4° P<0.05 | | | | CrCl Δ= 0 NS | | | | 8 mo | Mod
Ramos, 2003^63^ | 160/91 | >70 | 105 | Ostial 32% | 12.2 mo | 18 | 47 | | | | | | | 14 | C
Prosp | 54 | 43 | (105) | nd | 3.3–23 | BP Δ = −15/−8 P<0.0001 | | | | GFR Δ = +8 P=0.007 | | | | 12 mo | Mod
Harjai, 1997^57^ | 178/91 | >70 | 66 | Ostial 73% | 19 mo | 66 | | | | | | | | 25 | C
Prosp | [1.6] | 27 | (66) | 1992–1995 | nd | BP Δ = −32/−17 nd | | | | | | | | 9 mo | High
Holden, 2006 78 | 153/101 | nd | 63 | nd | nd | 0 | 55 | | | CKD 3A: 1 CKD 3B 2 : CKD 4: 3 | 52 32 33 | 48 60 67 | 0 8 0 | 8 | C
Prosp | 76% Stage 3 24% Stage 4 | nd | (63) | nd | nd | BP Δ (44 with HTN) = −32/−10 | | | | SCr Δ =~ −0.1 | | | | | High
Goncalves, 2007 77 | 177/98 | nd | 46 | nd | nd | | | | | | | | | nd | C
Prosp | [2.3] | nd | (46) | 1999–2003 | 7–52 mo | BP Δ = −42/−15 P<0.0001 | | | | SCr Δ = −0.4 mg/dL P<0.001 | | | | | High
Henry, 2003^58^ | 169/104 | 85 | 56 | Ostial 100% | 23 mo | 18 | 59 | 23 | | 18 | 82 | | 0 | nd | C
Prosp^P^ | [1.3] | 14 | (56) | 1999–2002 | 2–47 | BP Δ = −19/−11 P<0.01 | | | | SCr Δ = −0.1 mg/dL NS | | | | | Low
Rivolta, 2005^64^ | 161/86 | >70 | 52 | nd | 24 | | | | | 15 | 60 | | 25 | 10 | C
Prosp | [2.9] | 37 | (52) | | 9–54 | BP Δ = −18/−7 P<0.01^Q^ | | | | | | | | 6 mo | Mod
Gill-Leertouwer, 2002^52,53^ | 177/96^R^ [1.3]^S^ | >50 | 40 | nd | 1 yr | | | | | | | | | 14 | C
Prosp | [2.4]^T^ | nd | (40) | 1996–1998 | nd | Clinical success 85% | | | | Clinical success 25% | | | | 12 mo | Low
Bucek, 2003^44^ | nd | >80 | 40 | Ostial 100% | 3.3 yr^U^ | | 38 | 43 | | | | | 25 | 13–15 | C
Prosp & Retro | nd | nd | (40) | 1997–2002 | 0.8–6.3 | | | | | | | | | 40 mo | Low
Gray, 2002^54^ V | 174/85 | >70 | 39 | nd | 21 mo | | 72 | 15 | | 51 | 26 | | 23 | 10 | C
Prosp | [3.2] | 46 | (39) | 1991–1997 | 1–61 | | | | | | | | | 21 mo | Mod

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CrCl, creatinine clearance; CKD, chronic kidney disease; CVD, cardiovascular disease; eGFR, estimated GFR; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m^2^); HTN, hypertension; Imp, improved;, mo, months; MAP, mean arterial pressure; Mod, moderate; nd, no data; NS, nonsignificant; ,Prosp, prospective nonrandomized study; Qual, quality rating; RAS, renal artery stenosis; Retro, retrospective study; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); yr, years.

1 Chronic kidney disease stage 3A, baseline GFR 41–59 mL/min

2 Chronic kidney disease stage 3A, baseline GFR 30–40 mL/min

3 Chronic kidney disease stage 3A, baseline GFR 15–29 mL/min

A CVD outcomes: myocardial infarction 11%; CHF 20%; stroke 7%.

B Diagnosed by digital caliper technique.

C % restenosis reported according to the arteries evaluated.

D Myocardial infarction 5%.

E Among 48/50 with resistant HTN.

F N=102/126 > 85% stenosis.

G N analyzed at baseline for BP=48 and CKD=65.

H Of the arteries evaluated: Neointimal hyperplasia 61%; stent migration 22%, and true stent restenosis 17%.

I Among 65/75 with CKD at baseline.

J N analyzed = 18.

K Evaluated at follow-up n=113.

L Outcomes evaluated n=127.

M Outcomes evaluated n=132.

N Among those with follow-up (n=127).

O Analyzed at 12 mo (n=41).

P Utilized distal protection device and follow-up data available for maximum numbers at 6 month.

Q Significant only for systolic blood pressure.

R 60% less than 2 yr duration of HTN.

S Baseline value among those with clinical success (n=27).

T Baseline value among those with clinical failure (n=13).

U Median.

V New York Heart Association class Δ=−1.4 P<0.001.

Table 8

Adverse events associated with angioplasty with stent placement treatment of renal artery stenosis (new studies in italics)

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Dorros 2002^46–50^ | 1058 | Angioplasty stent placement | Contrast induced acute kidney failure 13% | | | Retroperitoneal hemorrhage 1 % | Deaths 0.3%
Zeller 2004^69–73^ | 340 268 (268) | Angioplasty stent placement | Severe deterioration of kidney function 1.5% Local dissection or perforation 4% | | False aneurysm 1% Access site occlusion 0.3% | Severe access site bleeding 2% | 30 d mortality 0.6% Death after 3 d due to embolic stroke 0.3% | Stent displacement 1%
Lederman 2001^62^ | 300 (293) | Angioplasty stent placement | Guidewire induced dissection of renal artery branch 0.3% | | Intraprocedural thrombosis of the target renal artery 0.3% | | Death from MI 0.3% | Acute/flash pulmonary edema 0.3% Stent migration into aorta 0.3% Aspirin hypersensitivity 0.3%
Kennedy 2003^60,61^ | 261 (253) 127 (127) | Angioplasty stent placement | | | Total occlusion of stented artery 0.8% | Hematuria due to vessel perforation 0.8% | | Access site complications with brachial approach 3% Access site complications with femoral approach 3% Dislodged stent 1.0% Dislodged unexpanded stent 0.8%
Rocha-Singh 2005^65^ | 208 (208) | Angioplasty stent placement | | Major vascular event [underlined: In-hospital] 2.4% [underlined: Out of hospital up to 2 yr] 2.9% Cerebrovascular accident 0% | Major embolic event [underlined: In-hospital] 1.4% [underlined: Out of hospital up to 2 yr] 4.8% | | Major hemorrhage [underlined: In-hospital] 1% [underlined: Out of hospital up to 2 yr 0.5%] | Access site complications 5%
Rocha-Singh 1999^66^ | 150 (150) | Angioplasty stent placement | Contrast induced nephropathy 5% Kidney parenchymal guidewire perforations 1.3% | | | | Death from tubular necrosis and multiorgan failure 0.7% Death from GI hemorrhage after stent implant while on warfarin 0.7% | Overall major complication rate 3%
Dangas 2001^45^ | 131 (nd) | Angioplasty stent placement | Kidney failure 6% | | Femoral artery pseudoaneurysms 1.5% | | Death 0.8%
Tuttle 1998^67^ | 129 (129) | Angioplasty stent placement | Contrast induced acute kidney failure 12% | | Atheroembolic disease 0.7% Arterial thrombosis 0.4% | Groin hematoma 7% Perirenal hematoma 0.4% | Death 3% | Stent migration 0.7%
Zeller 2005 82 | 143 (125) | Angioplasty stent placement | Transient SCr rise 1% | | False aneurysm 5% | Large hematoma 2% | PE death 1%
Gill 2003^51^ | 100 (100) | Angioplasty stent placement | Transient SCr rise 1% | | Transient lobar branch renal artery occlusion 2% Femoral artery false aneurysm 2% Femoral artery trauma 2% Non flow limiting intimal dissection 1% | Groin hematoma 6% | Death after lower limb cholesterol embolization 1% Death after thrombosis of aortofemoral prosthetic graft 1% | Migrating stent 1%
White 1997^68^ | 100 (100) | Angioplasty stent placement | Transient contrast nephropathy 2% No perforations | | Femoral artery pseudoaneurysm 1% Brachial artery occlusion 1% Subacute stent thrombosis after 3 d 1% | Groin hematoma 5% | Ischemic cardiac death after 2 d 1%
Ruchin, 2007 79 | 89 (87) | Angioplasty stent placement | | | Renal and peripheral thromboemboli 1% | Major bleeding 2% | | Puncture site infection 1%
Blum 1997^43^ | 68 (68) | Angioplasty stent placement | | | | Local hematomas at puncture site 4% | | No major complications
Harjai 1997^57^ | 66 (nd) | Angioplasty stent placement | Temporary rise in SCr 5% | | | Minor bleeding from vascular access site 5%
Holden, 2006 78 ] | 63 (63) | Angioplasty stent placement | Acute kidney injury 2%
Iannone 1996^59^ | 63 (61) | Angioplasty stent placement | Acute kidney failure 13% Renal artery perforation 5% | | Psuedoaneurysm at insertion site 1.6% | Minor groin hematoma 10% Bleeding requiring transfusion including peripheral embolus requiring thrombolysis 16% | Death after perirenal bleeding 1.6%
Henry 2003^58^ | 56 (56) | Angioplasty stent placement | | | Arterial spasm at site of protection device 4% | | Death on d 3 from MI 1.8% | No device related complications
Sapoval, 2005 80 | 52 (52) | Angioplasty stent placement | Renal artery dissection 8% | | | Hematoma at puncture site 2%
Goncalves, 2007 77 | 46 (44) | Angioplasty stent placement | Renal artery dissection 2%
van de Ven 1999^76^ | 40 (40) | Angioplasty stent placement | Transient decrease in kidney function due to radiography contrast agent 21% Kidney failure induced by cholesterol embolism 10% Renal artery injury 7% | | Renal artery occlusion 2% Acute thrombosis 2% Femoral artery aneurysm or arteriovenous fistula 7% | Bleeding 19% | | Technical failure 7%
Harden 1997^56^ | 32 (32) | Angioplasty stent placement | | | Femoral artery pseudoaneurysm 9% | Hemorrhage 9% | Death from circulatory collapse after stent placement 3%
Gross 1998^55^ | 30 (30) | Angioplasty stent placement | Dissection after predilatation 10% | | No vessel had early or subacute thrombotic occlusion | | | No guidewire perforation detected.

ARAS, atherosclerotic renal artery stenosis; CKD, chronic kidney disease; CVD, cardiovascular disease; d, days; GI, gastrointestinal; MI, myocardial infarction; N, number of subjects; nd, no data; PTRA, percutaneous renal angioplasty; RAS, renal artery stenosis; SCr, serum creatinine.

Table 11

Surgical renal artery revascularization for the treatment of renal artery stenosis (no new data)

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | | Qual
Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | CVD (%) | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | Worse | CVD (%) | Appl
Cherr, 2002^85–89^ | 200/104 | ≥80% | 500 | Ostial: nd | 4.7 yr | 12% | 73% | | 15% | 43% | 47% | 10% | 74% of late deaths 2° to CVD; nonfatal events28% (angina, MI, PTCA, CABG) | C
Retro | 41 | 59% | (500) | 1987–1999 | 1–159 mo | BP Δ = −53/−23 P<0.0001 (base) | | | | GFR Δ = 7.1 P<0.0001 (base)17% became dialysis dependent | | | 74% of late deaths 2° to CVD; nonfatal events28% (angina, MI, PTCA, CABG) | Low
Galaria, 2005^84^ | 171/82 | ≥50% | 100 | Ostial: nd | 3.5 yr | 68% (3 yr) 59% (5 yr) | | | | | | | | C
Retro | 51 | 44% | (100) | 1984–2004 | 0–17 yr | | | | | CKD eventA = 20% (3 yr), 26% (5 yr) | | | | Low
Alhadad, 2004^83^ | 180/100 | nd | 106 | Ostial: nd% | nd | | | | | | | | | C
Retro | nd | nd | (86) | 1987–1996 | 0–12 yr | Only mortality data reported (after 6 mo). See mortality figure | | | | | | | | Low
Marone, 2004^90^ | nd | Both cohorts ≥ 75% | Cohort 1: 139 (139) | Ostial: nd | 48 mo | Cohort 1: kidney function improved or unchanged in 76% Cohort 2: kidney function improved or unchanged in 72% Dialysis free survival at 5 years was 55% (both cohorts?) | | | | | | | | C
Retro | Cohort 1: [>2]Cohort 2: [≥1.5] | nd | Cohort 2: 96 (96) | Cohort 1: 1980–1990 Cohort 2: 1990–2001 | 6 wk to 12.6 yr | Cohort 1: kidney function improved or unchanged in 76% Cohort 2: kidney function improved or unchanged in 72% Dialysis free survival at 5 years was 55% (both cohorts?) | | | | | | | | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CABG, coronary artery bypass graft; CKD, chronic kidney disease; CVD, cardiovascular disease; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m^2^); HTN, hypertension; Imp, improved; MI, myocardial infarction; mo, months; nd, no data; PTCA, percutaneous transluminal coronary angioplasty; Qual, quality rating; RAS, renal artery stenosis; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); wk, weeks; yr, years.

A Dialysis, CKD-related mortality, or SCr>1.5 mg/dL.

Table 12

Adverse events associated with the surgical treatment of renal artery stenosis (no new data)

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Cherr 2002^85–89^ | 500 (500) | Surgery | | Perioperative: MI 3% Stroke 1% Significant arrhythmia 5% Nonfatal CVD 28% | | | Death: 5% | Perioperative morbidity 17% Including pneumonia 8%
Marone 2004^90^ | 325 (325) | Surgery | | | | | Perioperative mortality 6%, mostly secondary to coronary and cerebrovascular events
Galaria 2005^84^ | 247 (247) | Angioplasty-Surgery | Perioperative kidney morbidity: 0% (Angioplasty) 6% (Surgery) | Perioperative minor cardiac morbidity <1% (Angioplasty) 14% (Surgery) | | | Deaths <0.1% (Angioplasty) (all due to cardiac events) Deaths 0.1% (Surgery) 6/10 due to cardiac complications, 3/10 pulmonary, 1/10 sepsis Major morbidity: 4% (Angioplasty) 4% (Surgery) | Technical complication rate: 18% (Angioplasty) 0% (Surgery) Pulmonary adverse events: 0% (Angioplasty) 9% (Surgery) Systemic infection: 0% (Angioplasty) 8% (Surgery) Other wound related events: 0% (Angioplasty) 6%(Surgery)
Alhadad 2004^83^ | 106 (86) | Angioplasty-Surgery | | | | | 2% (Angioplasty) 9% (Surgical) | Multiorgan failure 0% (Angioplasty) 2% (Surgery) Sepsis 0% (Angioplasty) 1% (Surgery)

ARAS, atherosclerotic renal artery stenosis; CVD, cardiovascular disease; d, day; MI, myocardial infarction; mo, months; N, number evaluated; RAS, renal artery stenosis; SCr, serum creatinine.

Appendix Figure

Mortality study details